# Other Outcomes: Longitudinal Studies

Appendix Table G1 Other outcomes: U.S. longitudinal peer-reviewed studies

Study | Measure | Result | Risk of Bias Rating
Doty et al. 2010^1^ (ASPE private LTC insurance cohort) | Question about satisfaction with services being received | Percent very satisfied at first and last wave: HCBS: 74%, 79% AL: 74%, 72% NH: 60%, 49% | High
Gaugler & Kane 2005^2^ (Oregon Assisted Living study) | Resident social activity based on 5 items | AL residents engaged in more social activity than NH residents at baseline and 6 months, but type of setting was not significantly associated with activity at 1 year or change in activity over the 1 year period. | Moderate
aMitchell et al., 2004^3^ | Whether or not subjects had an advance directive | Adjusted odds ratio advance directive: HCBS reference, NH 1.48 (1.11, 1.96) | High
aSloane et al. 2005^4^ (Collaborative Studies of Long-Term Care sub-sample) | Mean change increase in behavior problems per 12 months; mean change increase in social function per 12 months; mean change increase in social withdrawal per 12 months; new or worsening morbidity as the incidence of worsening of fracture, infection, stroke or paralysis, bleeding from the stomach or bowel, diabetes, heart condition, or skin ulcer reported as incidence rate per 100 participants per quarter | Behavior for residents with mild dementia: AL 1.08, NH 0.69, p = 0.604 Behavior for residents with moderate or severe dementia: AL: 1.72, NH 1.49, p = 0.809 Social function for residents with mild dementia: AL 1.55, NH 1.76, p = 0.568 Social function for residents with moderate or severe dementia: AL: 0.91, NH 1.44, p = 0.110 Social withdrawal for residents with mild dementia: AL 2.84, NH 2.24, p = 0.364 Social withdrawal for residents with moderate or severe dementia: AL: 2.55, NH 1.78, p = 0.307 New or worsening morbidity for residents with mild dementia: AL 23.5, NH 21.8, p = 0.574 New or worsening morbidity for residents with moderate or severe dementia: AL: 21.1, NH 21.7, p = 0.865 There were no significant differences between AL and NH residents in any of these outcomes. | High
aZimmerman et al. 2005^5^ (Dementia Care Project study) | Quality of Life in Alzheimer's Disease | There was no statistically significant difference in the adjusted change in quality of life score by facility type (AL or NH). | High

a Indicates study focused on participants with dementia

HCBS = Home and Community-based Services; NH = Nursing Home; AL = Assisted Living; ASPE=Assistant Secretary for Planning and Evaluation, U.S Department of Health and Human Services

Appendix Table G2 Other outcomes: international longitudinal peer-reviewed studies

Study | Measure | Results | Risk of Bias Rating
Resource Implications Study Group 2000^6^ | Family caregivers' psychological morbidity measured by General Health Questionnaire (GHQ) score | There were no significant changes over 2-year period in GHQ scores for any of the groups of caregivers for residents that remained in either HCBS or NH throughout the entire period, or for residents that transitioned from HCBS to NH during the study period. | High

HCBS = Home and Community-based Services; NH = Nursing Home

## References for Appendix G

1 Doty P, Cohen MA, Miller J, et al. Private long-term care insurance: value to claimants and implications for long-term care financing. Gerontologist. 2010;50(5):613-22. [pmid: 20299425].
2 Gaugler JE, Kane RA. Activity Outcomes for Assisted Living Residents Compared to Nursing Home Residents: Findings from a Longitudinal Study. Activities, Adaptation & Aging. 2005;29(3):33-58. [pmid: 18418292].
3 Mitchell SL, Morris JN, Park PS, et al. Terminal care for persons with advanced dementia in the nursing home and home care settings. Journal of Palliative Medicine. 2004;7(6):808-16. [pmid: 15684848].
4 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
5 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. 2005;45(Special Issue 1):133-46. [pmid: 16230760].
6 Psychological morbidity among informal caregivers of older people: a 2-year follow-up study. The Resource Implications Study Group of the MRC study of cognitive function and ageing (RIS MRC CFAS). Psychological Medicine. 2000;30(4):943-55. [pmid: 11037102].