# Overall Strength of Evidence Assessment

Outcome | Longitudinal Studies Examining the Outcome | Risk of Bias | Directness | Precision | Consistency | Strength of Evidence Rating
Physical Function
AL vs. NH | Frytak et al., 2001^1^ Pruchno & Rose, 2000^2^ Sloane et al., 2005^3^ | High | Direct | Imprecise (different measures) | Consistent | Low (no difference)
HCBS vs. NH | Marek et al., 2005^4^ | High | Direct | Imprecise | Unknown | Insufficient
Cognitive Function
AL vs. NH | Pruchno & Rose, 2000^2^ Sloane et al., 2005^3^ | High | Direct | Imprecise (different measures) | Consistent | Low (no difference)
HCBS vs. NH | Marek et al., 2005^4^ | High | Direct | Imprecise | Unknown | Insufficient
Mental Health
AL vs. NH | Frytak et al., 2001^1^ Pruchno & Rose, 2000^2^ Sloane et al., 2005^3^ | High | Direct | Imprecise (different measures) | Consistent | Low (no difference)
HCBS vs. NH | Marek et al., 2005^4^ | High | Direct | Imprecise | Unknown | Insufficient
Mortality
AL vs. NH | Pruchno & Rose, 2000^2^ Sloane et al., 2005^3^ | High | Direct | Imprecise | Consistent | Low (no difference)
HCBS vs. NH | Wieland et al., 2010^5^ | High | Direct | Imprecise | Unknown | Insufficient
Use of Acute Care
AL vs. NH | Sloane et al., 2005^3^ | High | Direct | Imprecise | Unknown | Insufficient*
HCBS vs. NH | Mitchell et al., 2004^6^ | High | Direct | Imprecise | Unknown | Insufficient
Harms
AL vs. NH | Frytak et al. 2001^1^ | High | Direct | Imprecise | (Sets of harms differed by intervention/comparator) | Insufficient
HCBS vs. NH | Rigler et al., 2004^7^ Mitchell et al., 2004^6^ | High | Direct | Imprecise | (Sets of harms differed by intervention/comparator) | Low
Costs
HCBS vs. NH | Shireman & Rigler, 2004^8^ | High | Direct | Imprecise | Unknown | Insufficient

## References for Appendix F

1 Frytak JR, Kane RA, Finch MD, et al. Outcome trajectories for assisted living and nursing facility residents in Oregon. Health Services Research. 2001;36(1 Pt 1):91-111. [pmid: 11324746].
2 Pruchno RA, Rose MS. Effect of long-term care environments on health outcomes. Gerontologist. 2000;40(4):422-8. [pmid: 10961031].
3 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
4 Marek KD, Popejoy L, Petroski G, et al. Clinical outcomes of aging in place. Nurs Res. May-Jun. 2005;54(3):202-11. [pmid: 15897796].
5 Wieland D, Boland R, Baskins J, et al. Five-Year Survival in a Program of All-Inclusive Care For Elderly Compared With Alternative Institutional and Home- and Community-Based Care. Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2010;65A(7):721-6.
6 Mitchell SL, Morris JN, Park PS, et al. Terminal care for persons with advanced dementia in the nursing home and home care settings. Journal of Palliative Medicine. 2004;7(6):808-16. [pmid: 15684848].
7 Rigler SK, Perera S, Jachna C, et al. Comparison of the association between disease burden and inappropriate medication use across three cohorts of older adults. American Journal of Geriatric Pharmacotherapy. 2004;2(4):239-47. [pmid: 15903282].
8 Shireman TI, Rigler SK. Penny wise, pound wise: a comparison of Medicaid expenditures for home and community-based services versus nursing facility care for older adults. Home Health Care Services Quarterly. 2004;23(4):15-28. [pmid: 15778150].