# Evidence Table

## References for Appendix D

1 Psychological morbidity among informal caregivers of older people: a 2-year follow-up study. The Resource Implications Study Group of the MRC study of cognitive function and ageing (RIS MRC CFAS). Psychological Medicine. 2000;30(4):943-55. [pmid: 11037102].
2 Long-Term Care Community Diversion Pilot Project 2009-2010 Legislative Report Prepared by Department of Elder Affairs State of Florida. 2011. http://elderaffairs.state.fl.us/english/legis/2009%20Long-Term%20Care%20Community%20Diversion%20Pilot%20Project%20Annual%20Report.pdf.
3 Applebaum RA, Mehdizadeh SA, Straker JK. The changing world of long-term care: a state perspective. Journal of Aging & Social Policy. 2004;16(1):1-19. [pmid: 15040704].
4 Beattie ERA, Song J, LaGore S. A comparison of wandering behavior in nursing homes and assisted living facilities. Research & Theory for Nursing Practice. 2005;19(2):181-96. [pmid: 16025697].
5 Boersma F, Eefsting JA, van den Brink W, et al. Care services for dementia patients: predictors for service utilization. International Journal of Geriatric Psychiatry. 1997;12(11):1119-26. [pmid: 9427096].
6 Borrayo EA, Salmon JR, Polivka L, et al. Utilization across the continuum of long-term care services. Gerontologist. 2002;42(5):603-12. [pmid: 12351795].
7 Challis D, Mozley CG, Sutcliffe C, et al. Dependency in older people recently admitted to care homes. Age & Ageing. 2000;29(3):255-60. [pmid: 10855909].
8 Chappell NL, Dlitt BH, Hollander MJ, et al. Comparative costs of home care and residential care. Gerontologist. 2004;44(3):389-400. [pmid: 15197293].
9 Doty P, Cohen MA, Miller J, et al. Private long-term care insurance: value to claimants and implications for long-term care financing. Gerontologist. 2010;50(5):613-22. [pmid: 20299425].
10 Edelman P, Fulton BR, Kuhn D, et al. A comparison of three methods of measuring dementia-specific quality of life: perspectives of residents, staff, and observers. Gerontologist. Oct. Spec No 1. 2005;45(1):27-36. [pmid: 16230747].
11 Franks JS. Comparing Perceived Quality of Life in Nursing Homes and Assisted Living Facilities. Journal of Gerontological Social Work. 2004;43(1):119-30.
12 Frytak JR, Kane RA, Finch MD, et al. Outcome trajectories for assisted living and nursing facility residents in Oregon. Health Services Research. 2001;36(1 Pt 1):91-111. [pmid: 11324746].
13 Gaugler JE. Family Involvement and Resident Psychosocial Status in Long-Term Care. Clinical Gerontologist. 2006;29(4):79-98. [pmid: 22624576].
14 Gaugler JE, Kane RA. Activity Outcomes for Assisted Living Residents Compared to Nursing Home Residents: Findings from a Longitudinal Study. Activities, Adaptation & Aging. 2005;29(3):33-58. [pmid: 18418292].
15 Gruber-Baldini AL, Zimmerman S, Boustani M, et al. Characteristics associated with depression in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):50-5. [pmid: 16230749].
16 Lee T, Kovner CT, Mezey MD, et al. Factors influencing long-term home care utilization by the older population: implications for targeting. Public Health Nursing. 2001;18(6):443-9. [pmid: 11737813].
17 Leon J, Moyer D. Potential cost savings in residential care for Alzheimer's disease patients. Gerontologist. 1999;39(4):440-9. [pmid: 10495582].
18 Marek KD, Popejoy L, Petroski G, et al. Clinical outcomes of aging in place. Nurs Res. May-Jun. 2005;54(3):202-11. [pmid: 15897796].
19 Margallo-Lana M, Swann A, O'Brien J, et al. Prevalence and pharmacological management of behavioural and psychological symptoms amongst dementia sufferers living in care environments. International Journal of Geriatric Psychiatry. 2001;16(1):39-44. [pmid: 11180484].
20 McCann M, O'Reilly D, Cardwell C. A Census-based longitudinal study of variations in survival amongst residents of nursing and residential homes in Northern Ireland. Age & Ageing. 2009;38(6):711-7. [pmid: 19752201].
21 Mehdizadeh S. PASSPORT Cost Neutrality: How Do the Total Medicaid and Other Public Costs of Maintaining a PASSPORT Consumer in the Community Compare to That of a Nursing Facility Resident?. Scripps Gerontology Center Miami University. Oxford, OH. May. 2007.
22 Mehdizadeh SA. Health and Long-Term Care Use Trajectories of Older Disabled Women. Gerontologist. 2002;42(3):304-13. [pmid: 12040132].
23 Miller JS, Shi X, Cohen MA. Private Long-Term Care Insurance: Following an Admission Cohort over 28 Months to Track Claim Experience, Service Use and Transitions. Prepared by LifePlans, Inc. for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services under Contract #HHS-100-02-0014. Washington, D.C. April. 2008. http://aspe.hhs.gov/daltcp/reports/2008/coht28mo.pdf.
24 Mitchell SL, Morris JN, Park PS, et al. Terminal care for persons with advanced dementia in the nursing home and home care settings. Journal of Palliative Medicine. 2004;7(6):808-16. [pmid: 15684848].
25 Ormond BA, Sommers AS, Black KJ. Examination of Texas Rider 37: A Medicaid “Money Follows the Person” Long-Term Care Initiative. Prepared by The Urban Institute for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services under Contract #HHS-100-03-0011. Washington, D.C. May. 2006. http://aspe.hhs.gov/daltcp/reports/2006/TXltc.pdf.
26 Port CL, Zimmerman S, Williams CS, et al. Families filling the gap: comparing family involvement for assisted living and nursing home residents. Gerontologist. 2005;45(Special Issue 1):87-95. [pmid: 16230755].
27 Pruchno RA, Rose MS. Effect of long-term care environments on health outcomes. Gerontologist. 2000;40(4):422-8. [pmid: 10961031].
28 Reinardy J, Kane RA. Choosing an adult foster home or a nursing home: residents' perceptions about decision making and control. Soc Work. Nov. 1999;44(6):571-85. [pmid: 10568028].
29 Rigler SK, Perera S, Jachna C, et al. Comparison of the association between disease burden and inappropriate medication use across three cohorts of older adults. American Journal of Geriatric Pharmacotherapy. 2004;2(4):239-47. [pmid: 15903282].
30 Rothera I, Jones R, Harwood R, et al. Health status and assessed need for a cohort of older people admitted to nursing and residential homes. Age & Ageing. 2003;32(3):303-9. [pmid: 12720617].
31 Rothera IC, Jones R, Harwood R, et al. Survival in a cohort of social services placements in nursing and residential homes: factors associated with life expectancy and mortality. Public Health. 2002;116(3):160-5. [pmid: 12082598].
32 Schroeder JM, Nau KL, Osness WH, et al. A comparison of life satisfaction, functional ability, physical characteristics, and activity level among older adults in various living settings. Journal of Aging & Physical Activity. 1998;6(4):340-9.
33 Shireman TI, Rigler SK. Penny wise, pound wise: a comparison of Medicaid expenditures for home and community-based services versus nursing facility care for older adults. Home Health Care Services Quarterly. 2004;23(4):15-28. [pmid: 15778150].
34 Shugarman LR, Fries BE, James M. A comparison of home care clients and nursing home residents: can community based care keep the elderly and disabled at home?. Home Health Care Serv Q. 1999;18(1):25-45. [pmid: 10947561].
35 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
36 Sloane PD, Zimmerman S, Hanson L, et al. End-of-life care in assisted living and related residential care settings: comparison with nursing homes. Journal of the American Geriatrics Society. 2003;51(11):1587-94. [pmid: 14687388].
37 Spillman BC, Liu K, McGuilliard C. Trends in Residential Long-Term Care: Use of Nursing Homes and Assisted Living and Characteristics of Facilities and Residents. Prepared by The Urban Institute for the Office of Disability, Aging and Long-Term Care Policy, Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services under Contract #HHS-100-97-0010. Washington, D.C. November. 2002. http://aspe.hhs.gov/daltcp/reports/2002/rltct.pdf.
38 Wieland D, Boland R, Baskins J, et al. Five-Year Survival in a Program of All-Inclusive Care For Elderly Compared With Alternative Institutional and Home- and Community-Based Care. Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2010;65A(7):721-6.
39 Williams CS, Zimmerman S, Sloane PD, et al. Characteristics associated with pain in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):68-73. [pmid: 16230752].
40 Wodchis WP, Hirdes JP, Feeny DH. Health-related quality of life measure based on the minimum data set. International Journal of Technology Assessment in Health Care. 2003;19(3):490-506. [pmid: 12962335].
41 Zimmerman S, Gruber-Baldini AL, Sloane PD, et al. Assisted living and nursing homes: apples and oranges?. Gerontologist. 2003;43(Special Issue 2):107-17. Note: Included in special issue “Challenges in Nursing Home Care,” with guest editors Jill Quadagno, Sidney Stahl, and Laurence G. Branch. [pmid: 12711731].
42 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. 2005;45(Special Issue 1):133-46. [pmid: 16230760].