# Excluded Studies

(Note that this set of references is different from those in the text, and the numbers are different.)

(Reason for exclusion shown in italics at the end of each reference.)

1 Andren S, Elmstahl S. Former family carers' subjective experiences of burden: a comparison between group living and nursing home environments in one municipality in Sweden. Dementia. 2002;1(2):241-54. No relevant comparison.
2 Ashcraft AS, Owen DC, Feng D. A comparison of cognitive and functional care differences in four long-term care settings. Journal of the American Medical Directors Association. 2006;7(2):96-101. No relevant settings or sample. [pmid: 16461251].
3 Beland F, Bergman H, Lebel P, et al. A system of integrated care for older persons with disabilities in Canada: results from a randomized controlled trial. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2006;61(4):367-73. No relevant comparison. [pmid: 16611703].
4 Biola H, Sloane PD, Williams CS, et al. Physician communication with family caregivers of long-term care residents at the end of life. Journal of the American Geriatrics Society. 2007;55(6):846-56. No relevant characteristics or outcomes. [pmid: 17537084].
5 Biola H, Sloane PD, Williams CS, et al. Preferences Versus Practice: Life-Sustaining Treatments in Last Months of Life in Long-Term Care. Journal of the American Medical Directors Association. 2010;11(1):42-51. No relevant settings or sample. [pmid: 20129214].
6 Boustani M, Zimmerman S, Williams CS, et al. Characteristics associated with behavioral symptoms related to dementia in long-term care residents. Gerontologist. 2005;45(Special Issue 1):56-61. No relevant characteristics or outcomes. [pmid: 16230750].
7 Boyle G. Facilitating choice and control for older people in long-term care. Health and Social Care in the Community. 2004;12(3):212-20. No relevant characteristics or outcomes. [pmid: 19777711].
8 Buck D, Gregson BA, Bamford CH, et al. Psychological distress among informal supporters of frail older people at home and in institutions. The Resource Implications Study Group of the MRC Cognitive Function and Ageing Study. International Journal of Geriatric Psychiatry. 1997;12(7):737-44. No relevant characteristics or outcomes. [pmid: 9251936].
9 Caprio AJ, Hanson LC, Munn JC, et al. Pain, dyspnea, and the quality of dying in long-term care. Journal of the American Geriatrics Society. 2008;56(4):683-8. No relevant settings or sample. [pmid: 18266666].
10 Castle NG, Lowe TJ, Lucas JA, et al. Use of resident satisfaction surveys in New Jersey nursing homes and assisted living facilities. Journal of Applied Gerontology. 2004;23(2):156-71. No relevant characteristics or outcomes.
11 Chao SY, Lan YH, Tso HC, et al. Predictors of psychosocial adaptation among elderly residents in long-term care settings. Journal of Nursing Research. 2008;16(2):149-59. Non-US, Canadian, European, Australian. [pmid: 18528821].
12 Chiu L, Tang KY, Liu YH, et al. Cost comparisons between family-based care and nursing home care for dementia. Journal of Advanced Nursing. 1999;29(4):1005-12. Non-US, Canadian, European, Australian. [pmid: 10215994].
13 Cohen-Mansfield J, Jensen B. Changes in habits related to self-care in dementia: the nursing home versus adult day care. American Journal of Alzheimer's Disease and Other Dementias. 2007;22(3):184-9. No relevant characteristics or outcomes.
14 Curtis MP, Sales AEB, Sullivan JH, et al. Satisfaction with care among community residential care residents. Journal of Aging & Health. 2005;17(1):3-27. No relevant comparison. [pmid: 15601781].
15 Daaleman TP, Williams CS, Preisser JS, et al. Advance Care Planning in Nursing Homes and Assisted Living Communities. Journal of the American Medical Directors Association. 2009;10(4):243-51. No relevant settings or sample. [pmid: 19426940].
16 Dobbs D, Munn J, Zimmerman S, et al. Characteristics associated with lower activity involvement in long-term care residents with dementia. Gerontologist. Spec No 1. 2005;45(1):81-6. No relevant characteristics or outcomes. [pmid: 16230754].
17 Friedman SM, Mendelson DA, Bingham KW, et al. Hazards of hospitalization: residence prior to admission predicts outcomes. Gerontologist. 2008;48(4):537-41. No relevant settings or sample. [pmid: 18728303].
18 Godden S, Pollock AM. The use of acute hospital services by elderly residents of nursing and residential care homes. Health & Social Care in the Community. 2001;9(6):367-74. No relevant comparison. [pmid: 11846815].
19 Golden AG, Roos BA, Silverman MA, et al. Home and Community-Based Medicaid Options for Dependent Older Floridians. Journal of the American Geriatrics Society. 2010;58(2):371-6. No relevant comparison. [pmid: 20070419].
20 Hanson LC, Eckert JK, Dobbs D, et al. Symptom experience of dying long-term care residents. Journal of the American Geriatrics Society. 2008;56(1):91-8. No relevant settings or sample. [pmid: 17727647].
21 Howard DL, Sloane PD, Zimmerman S, et al. Distribution of African Americans in residential care/assisted living and nursing homes: more evidence of racial disparity?. American Journal of Public Health. 2002;92(8):1272-7. No relevant characteristics or outcomes. [pmid: 12144983].
22 Jackson GA, Templeton GJ, Whyte J. An overview of behaviour difficulties found in long-term elderly care settings. International Journal of Geriatric Psychiatry. 1999;14(6):426-30. No relevant characteristics or outcomes. [pmid: 10398351].
23 Kane RL, Homyak P, Bershadsky B, et al. Patterns of utilization for the Minnesota senior health options program. Journal of the American Geriatrics Society. 2004;52(12):2039-44. No relevant comparison. [pmid: 15571539].
24 Liu LF, Wen MJ. A longitudinal evaluation of residents' health outcomes in nursing homes and residential care homes in Taiwan. Quality of Life Research. 2010;19(7):1007-18. Non-US, Canadian, European, Australian. [pmid: 20449664].
25 Lockhart C, Giles-Sims J, Klopfenstein K. Comparing states' Medicaid nursing facilities and home and community-based services long-term care programs: quality and fit with inclination, capacity, and need. Journal of Aging & Social Policy. 2009;21(1):52-74. No relevant comparison. [pmid: 19197608].
26 Mitchell G 2nd, Salmon JR, Polivka L, et al. The relative benefits and cost of medicaid home- and community-based services in Florida. Gerontologist. 2006;46(4):483-94. No relevant comparison. [pmid: 16921002].
27 Munn JC, Dobbs D, Meier A, et al. End-of-life experience in long-term care: five themes identified from focus groups with residents, family members, and staff. Gerontologist. 2008;48(4):485-94. No relevant comparison. [pmid: 18728298].
28 Page C, Conner T, Prokhorov A, et al. The effect of care setting on elder abuse: results from a Michigan survey. Journal of Elder Abuse & Neglect. 2009;21(3):239-52. No relevant characteristics or outcomes. [pmid: 19827327].
29 Pruchno RA, Rose MS. Time use by frail older people in different care settings. Journal of Applied Gerontology. 2002;21(1):5-23. No relevant characteristics or outcomes.
30 Reed PS, Zimmerman S, Sloane PD, et al. Characteristics associated with low food and fluid intake in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):74-80. No relevant characteristics or outcomes. [pmid: 16230753].
31 Sands LP, Xu H, Weiner M, et al. Comparison of resource utilization for Medicaid dementia patients using nursing homes versus home and community based waivers for long-term care. Med Care. Apr. 2008;46(4):449-53. No relevant settings or sample. [pmid: 18362827].
32 Sloane PD, Zimmerman S, Williams CS, et al. Dying with dementia in long-term care. Gerontologist. 2008;48(6):741-51. No relevant settings or sample. [pmid: 19139248].
33 Small JA, Montoro-Rodriguez J. Conflict resolution styles: a comparison of assisted living and nursing home facilities. Journal of Gerontological Nursing. 2006;32(1):39-45. No relevant characteristics or outcomes. [pmid: 16475464].
34 Stone RI, Reinhard SC. Place of assisted living in long-term care and related service systems. Gerontologist. 2007;47(Special Issue 3):23-32. Review. [pmid: 18162566].
35 Verbeek H, van Rossum E, Zwakhalen SMG, et al. The effects of small-scale, homelike facilities for older people with dementia on residents, family caregivers and staff: design of a longitudinal, quasi-experimental study. BMC Geriatrics. 2009;9:3. No relevant comparison. [pmid: 19154579].
36 Weisman GD, Kovach C, Cashin SE. Differences in dementia services and settings across place types and regions. American Journal of Alzheimer's Disease and Other Dementias. 2004;19(5):291-8. No relevant characteristics or outcomes.
37 Williams SW, Williams CS, Zimmerman S, et al. Characteristics associated with mobility limitations in long-term care residents with dementia. Gerontologist. 2005;45(Special Issue 1):62-7. No relevant characteristics or outcomes. [pmid: 16230751].