# Sources of Grey Literature

Federal and state agencies | - Administration on Aging (AoA); - Agency for Healthcare Research and Quality (AHRQ); - Centers for Medicare & Medicaid Service (CMS); - Congressional Research Service (CRS); - Office of the Assistant Secretary for Planning and Evaluation (ASPE); - U.S. Government Accountability Office (GAO); - State Departments of Health or Health & Human Services; - Veterans Administration
Research organizations, foundations, and advocacy groups | - AARP; - Abt Associates; - Alliance for Health Reform; - American Public Human Services Association Health Services Division; - Center for Excellence in Assisted Living; - Kaiser Family Foundation; - LeadingAge; - Mathematica Policy Research; - Milbank Memorial Fund; - National Academy for State Health Policy; - National Association of Area Agencies on Aging; - National Association of Medicaid Directors; - National Center for Assisted Living; - National Conference of State Legislatures; - National Governors Association; - National Investment Center; - National PACE Association; - PAS Center for Personal Assistance Services, UCSF; - Robert Wood Johnson Foundation; - RTI International; - Scripps Gerontology Center; - The Clearinghouse for Home and Community Based Services; - The Commonwealth Fund; - The Hilltop Institute; - The John A. Hartford Foundation; - The Lewin Group; - The SCAN Foundation; - Urban Institute; - Visiting Nurse Service of New York