# Search Strategy

1. “long-term care”.ti,ab
2. “day care”.ti,ab.
3. “assisted living”.ti,ab.
4. “adult day health center”.ti,ab.
5. “adult day health care”.ti,ab.
6. “adult foster care”.ti,ab.
7. “independent living”.ti,ab.
8. “board and care”.ti,ab.
9. “home health care”.ti,ab.
10. “group residential care”.ti,ab.
11. “residential care”.ti,ab.
12. “home and community based care”.ti,ab.
13. “home and community based services”.ti,ab.
14. “personal care services”.ti,ab.
15. “aging in place”.ti,ab.
16. “continuing care retirement communit$”.ti,ab.
17. “group residential care”.ti,ab.
18. or/1-17
19. exp nursing homes/
20. institutionalization/
21. nursing home$.ti,ab.
22. “institutional care”.ti,ab.
23. (nursing adj home$).tw.
24. (residential adj (aged or elderly or geriatric)).tw.
25. or/19-24
26. 18 and 25
27. Randomized controlled trials as topic/
28. randomized controlled trial/
29. random allocation/
30. double blind method/
31. single blind method/
32. clinical trial/
33. clinical trial, phase i.pt.
34. clinical trial, phase ii.pt.
35. clinical trial, phase iii.pt.
36. clinical trial, phase iv.pt.
37. controlled clinical trial.pt.
38. randomized controlled trial.pt.
39. multicenter study.pt.
40. clinical trial.pt.
41. exp clinical trials as topic/
42. or/27-41
43. epidemiological studies/
44. exp case control studies/
45. exp cohort studies/
46. case control.tw.
47. (cohort adj (study or studies)).tw.
48. cohort analy$.tw.
49. cohort analy$.tw.
50. (follow up adj (study or studies)).tw.
51. (observational adj (study or studies)).tw.
52. longitudinal.tw.
53. retrospective.tw.
54. cross sectional.tw.
55. cross-sectional studies/
56. or/43-55
57. 26 and 42
58. 26 and 56
59. limit 57 to (english language and yr=“1995-Current”)
60. limit 58 to (english language and yr=“1995-Current”)
61. (case reports or comment or editorial or historical article or letter or news or newspaper article or“review”).pt.
62. 59 not 61
63. 60 not 61