# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jeannine Ouellette for her help in writing and editing the report and Marilyn Eells for proofreading and formatting it.