# Abbreviations

ADL: Activities of daily living
AGECAT: Automated Geriatric Examination Computer Assisted Taxonomy
AHRQ: Agency for Healthcare Research and Quality
AL: Assisted living
CAMDEX: Cambridge Examination for Mental Disorders of the Elderly
CDRS: Clinical Dementia Rating Score
CES-D: Center for Epidemiological Studies Depression Scale
CHIP: Children's Health Insurance Program
CIRS-g: Cumulative Illness Rating Scale for Geriatrics
CMS: Centers for Medicare & Medicaid Services
COPD: Chronic obstructive pulmonary disease
CPS: Cognitive Performance Score
CSDD: Cornell Scale for Depression in Dementia
DRA: Deficit Reduction Act
EPC: Evidence-based Practice Center
HCBS: Home and Community-Based Services
IADL: Instrumental activities of daily living
LTC: Long-term care
MAI: Multilevel Assessment Instrument
MDS: Minimum Data Set
MDS-COGS: Minimum Data Set Cognition Scale
MDS-HC: Minimum Data Set – Home Care version
MMSE: Mini-Mental State Exam
MSQ: Mental Status Questionnaire
NH: Nursing home
NR: Not reported
NS: Not significant
OAA: Older Americans Act
PACE: Program of All-Inclusive Care for the Elderly
PGC-PIS: Philadelphia Geriatric Center-Pain Intensity Scale
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
RCF: Residential care facilities
RCTs: Randomized controlled trials
RTI-UNC: RTI International-University of North Carolina
SF-36: Short-form Health Survey (Medical Outcomes Study Short-form 36)
SPMSQ: Short Portable Mental Status Questionnaire
SWLS: Satisfaction with Life Scale
TEP: Technical Expert Panel