# Results

## Article Selection

We identified 6,107 nonduplicate publications through the search process, with 1,026 proceeding to full-text review (Figure 2). Sixty-eight RCTs were included in the review, representing 68 distinct study populations. Sixty-four RCTs were conventional strategy trials and four were RCTs of systems-level strategies. Twenty-nine pre-post studies of large scale health systems changes were also identified.

Figure 2 Disposition of articles identified by the search strategy

KQ = Key Question

^*^ The number of articles addressing Key Questions and those excluded exceed the total number of articles in each category because some articles fit multiple exclusion categories or addressed more than one Key Question.

Figure 2 depicts the disposition of all articles included in the search and lists the reasons for exclusion. The search identified 6,106 non-duplicate articles, of which 6,009 were identified via literature search and 97 via hand-searching of the reference lists of articles. Of the 6,106 non-duplicate articles, 5,081 were excluded at the abstract review phase, and 1,025 moved on to the full text review phase. Of the 1,025 that moved on to the full text review phase, 92 were included in the review and 924 were excluded. Of the 92 articles included, 8 were included in key question 1, 84 in key question 2, zero in key question 3, and 15 in key question 4. Of the 933 articles excluded, 291 were not a randomized controlled trial, 474 were not relevant to strategies to reduce cesarean birth, 20 were not original research, 115 were of women who were not intending a vaginal birth, 52 did not state an intent to reduce cesarean, 6 did not reflect current U.S. practice, one was not published in English, and one was not able to retrieved. The number of articles addressing key question and those excluded exceed the total number of articles in each category because some articles fit multiple exclusion criteria or addressed more than one key question.

The most common reasons for exclusion were irrelevance to the topic and ineligible study design (66%). Nine articles pertain to Key Question (KQ) 1, 88 articles to KQ2, zero articles to KQ3, and 18 articles to KQ4. Tables 2 and 30 provide a summary of the strategies to reduce cesarean represented in this review in order from greatest to least observed reduction in cesarean.

Table 2 Summary of effectiveness of cesarean reduction strategies from greatest to least change

Author, Year Country | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Choudhary et al., 2010^39^ India | Standard obstetric care without amnioinfusion (146) | 63.7 | 34.2 lower
Choudhary et al., 2010^39^ India | Transcervical amnioinfusion (146) | 29.5 | 34.2 lower
Spallicci et al., 2007^40^ Brazil | Placebo cervical injection (85) | 49.0 | 31.0 lower
Spallicci et al., 2007^40^ Brazil | Hyaluronidase injection in cervix (83) | 18.0 | 31.0 lower
Sanchez-Ramos et al., 1996^41^ US | Oxytocin plus placebo (47) | 51.1 | 24.6 lower
Sanchez-Ramos et al., 1996^41^ US | Oxytocin plus propranolol (49) | 26.5 | 24.6 lower
Trueba et al., 2000^42^ Mexico | Standard care (50) | 24.0 | 22.0 lower
Trueba et al., 2000^42^ Mexico | Childbirth educator trained as doula (50) | 2.0 | 22.0 lower
Kuhnert et al., 2004^43^ Germany | Fetal monitoring with cardiotocography and fetal scalp blood sampling only (73) | 37.0 | 20.6 lower
Kuhnert et al., 2004^43^ Germany | Fetal monitoring with cardiotocography and fetal pulse oximetry and fetal scalp blood sampling (73) | 16.4 | 20.6 lower
Abdel-Aleem et al., 2005^44^ Egypt | Standard obstetric care without amnioinfusion (219) | 68.0 | 20.1 lower
Abdel-Aleem et al., 2005^44^ Egypt | Transcervical amnioinfusion (219) | 47.9 | 20.1 lower
Rathor et al., 2002^45^ India | Standard obstetric care without amnioinfusion (100) | 36.0 | 15.0 lower
Rathor et al., 2002^45^ India | Transcervical amnioinfusion (100) | 21.0 | 15.0 lower
McGrath and Kennell, 2008^46^ US | Routine care (196) | 25.0 | 11.6 lower
McGrath and Kennell, 2008^46^ US | Doula support (224) | 13.4 | 11.6 lower
Harvey et al., 1996^47^ Canada | Physician care (93) | 15.1 | 11.1 lower
Harvey et al., 1996^47^ Canada | Nurse-midwife care (101) | 4.0 | 11.1 lower
Kennell et al., 1991^48^ US | Control group assigned after birth (204) | 18.0 | 10.0 (control vs. doula) 5.0 (control vs. observer) lower
Kennell et al., 1991^48^ US | Received support of a doula (212) | 8.0 | 10.0 (control vs. doula) 5.0 (control vs. observer) lower
Kennell et al., 1991^48^ US | Observed by an inconspicuous observer (200) | 13.0 | 10.0 (control vs. doula) 5.0 (control vs. observer) lower
Skrablin et al., 2011^49^ Croatia | Continuous epidural (104) | 14.4 | 9.4 lower
Skrablin et al., 2011^49^ Croatia | Intermittent epidural (101) | 5.0 | 9.4 lower
Pattinson et al., 2003^50^ South Africa | Expectant management (350) | 23.4 | 7.4 lower
Pattinson et al., 2003^50^ South Africa | Aggressive management (344) | 16.0 | 7.4 lower
Lavender et al., 1998^51^ UK | 3-hour partogram (302) | 14.2 | 5.8 (4-hour vs. 3-hour) lower
Lavender et al., 1998^51^ UK | 4-hour partogram (311) | 8.4 | 5.8 (4-hour vs. 3-hour) lower
Lavender et al., 1998^51^ UK | 2-hour partogram (315) | 11.1 | 5.8 (4-hour vs. 3-hour) lower
Homer et al., 2001^52^ Australia | Standard hospital-based care(539) | 17.8 | 4.5 lower
Homer et al., 2001^52^ Australia | Community-based model care (550) | 13.3 | 4.5 lower
Harper et al., 2006^53^ US | Usual care (26) | 39.0 | 22.0 same
Harper et al., 2006^53^ US | Acupuncture sessions (30) | 17.0 | 22.0 same
Bidgood et al., 1987^54^ UK | Observation (20) | 45.0 | 18.7 (high-dose vs. obs.) same
Bidgood et al., 1987^54^ UK | High-dose oxytocin (19) | 26.3 | 18.7 (high-dose vs. obs.) same
Bidgood et al., 1987^54^ UK | Low-dose oxytocin (21) | 33.3 | 18.7 (high-dose vs. obs.) same
Matsuo et al., 2009^55^ US | Usual care (32) | 25.0 | 12.5 same
Matsuo et al., 2009^55^ US | Dental support device during active pushing (32) | 12.5 | 12.5 same
Garite et al., 2000^56^ US | Standard intravenous fluids of 125 ml/hr (94) | 17.0 | 7.1 same
Garite et al., 2000^56^ US | Increased intravenous fluids (101) | 9.9 | 7.1 same
Moodley et al., 1998^57^ South Africa | Standard obstetric care without amnioinfusion (30) | 47.0 | 7.0 same
Moodley et al., 1998^57^ South Africa | Transcervical amnioinfusion (30) | 40.0 | 7.0 same
Karraz, 2003^58^ France | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, non-ambulatory (74) | 16.2 | 7.0 same
Karraz, 2003^58^ France | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, ambulatory (141) | 9.2 | 7.0 same
Strong et al., 1990^59^ US | Standard care (30) | 20.0 | 7.0 same
Strong et al., 1990^59^ US | Amnioinfusion (30) | 13.0 | 7.0 same
Adamsons et al., 1999^60^ Puerto Rico | Usual care (23) | 17.4 | 5.7 same
Adamsons et al., 1999^60^ Puerto Rico | Propranolol during labor (34) | 11.7 | 5.7 same
Saisto et al., 2001^61^ Finland | Conventional therapy (91) | 48.4 | 4.9 same
Saisto et al., 2001^61^ Finland | Intensive therapy (85) | 43.5 | 4.9 same
Nicholson et al., 2008^62^ US | Standard care (134) | 14.9 | 4.6 same
Nicholson et al., 2008^62^ US | Induction of labor (136) | 10.3 | 4.6 same
Olofsson et al., 1998^63^ Sweden | Epidural anesthesia with high dose local anesthetic (0.25% bupivacaine with adrenaline) (435) | 14.7 | 4.5 same
Olofsson et al., 1998^63^ Sweden | Epidural anesthesia with low dose (0.125% bupivacaine with sufentanil 10 μg) (422) | 10.2 | 4.5 same
Rogers et al., 1997^64^ US | Usual care (205) | 11.7 | 4.2 same
Rogers et al., 1997^64^ US | Active management (200) | 7.5 | 4.2 same
Phipps et al.,2009^65^ Australia | Standard care (50) | 26.0 | 4.0 same
Phipps et al.,2009^65^ Australia | Structured education for pushing (50) | 22.0 | 4.0 same
Lopez-Zeno et al., 1992^66^ US | Traditional management (354) | 14.1 | 3.6 same
Lopez-Zeno et al., 1992^66^ US | Active management (351) | 10.5 | 3.6 same
Hemminki et al., 1990^67^ Finland | Usual care (118) | 5.0 | 3.0 same
Hemminki et al., 1990^67^ Finland | Midwifery student support (122) | 2.0 | 3.0 same
McNiven et al., 1998^68^ Canada | Direct admission (104) | 10.6 | 3.0 same
McNiven et al., 1998^68^ Canada | Early labor assessment (105) | 7.6 | 3.0 same
Vayssiere et al., 2007^70^ France | Fetal monitoring with cardiotocography only (400) | 16.3 | 2.8 same
Vayssiere et al., 2007^70^ France | Fetal monitoring with cardiotocography and STAN (399) | 13.5 | 2.8 same
Mahomed et al., 1998^69^ Zimbabwe | Standard obstetric care without amnioinfusion (336) | 11.3^b^ | 1.8 same
Mahomed et al., 1998^69^ Zimbabwe | Transcervical amnioinfusion (325) | 9.5 | 1.8 same
Somprasit et al., 2005^71^ Thailand | Conventional management (640) | 14.7 | 2.8 same
Somprasit et al., 2005^71^ Thailand | Active management (320) | 11.9 | 2.8 same
Bernitz et al., 2011^72^ Norway | Special unit (282) | 18.8 | 2.8 same
Bernitz et al., 2011^72^ Norway | Normal unit (417) | 18.0 | 2.8 same
Bernitz et al., 2011^72^ Norway | Midwife-led unit (412) | 16.0 | 2.8 same
Gagnon et al., 1997^73^ Canada | Usual nursing care (204) | 16.2 | 2.3 same
Gagnon et al., 1997^73^ Canada | One-to-one nursing care (209) | 13.9 | 2.3 same
East et al., 2006^74^ Australia | Fetal monitoring with cardiotocography only (295) | 48.1 | 2.2 same
East et al., 2006^74^ Australia | Fetal monitoring without cardiotocography and fetal pulse oximetry (306) | 45.9 | 2.2 same
Bloom et al., 1998^75^ US | Usual care (531) | 6.0 | 2.0 same
Bloom et al., 1998^75^ US | Walking during 1^st^ stage of labor (536) | 4.0 | 2.0 same
Mehrangiz et al., 2004^76^ Iran | Promethazine only (50) | 4.0 | 2.0 same
Mehrangiz et al., 2004^76^ Iran | Paracervical block with promethazine (50) | 2.0 | 2.0 same
Waldenstrom et al., 1997^77^ Sweden | Standard maternity care (932) | 8.9 | 1.8 same
Waldenstrom et al., 1997^77^ Sweden | Birth center care (928) | 7.1 | 1.8 same
World Health Organization, 1994^78^ Indonesia, Thailand, Malaysia | Baseline (10,049) | 6.2 | 1.7 same
World Health Organization, 1994^78^ Indonesia, Thailand, Malaysia | Use of WHO partogram to guide active management of labor and decisions about cesarean (9,130) | 4.5 | 1.7 same
Cohen et al., 1987^79^ US | Control (75) | 14.6 | 1.3 same
Cohen et al., 1987^79^ US | Early aggressive management (75) | 13.3 | 1.3 same
Bloom et al., 2006^80^ US | Fetal pulse oximetry with oxygen saturation not displayed to clinician (2,712) | 27.5 | 1.2 same
Bloom et al., 2006^80^ US | Fetal pulse oximetry with oxygen saturation displayed to clinician (2,629) | 26.3 | 1.2 same
Hofmeyr et al.,1998^81^ South Africa | Standard obstetric care without amnioinfusion (176) | 43.0 | 1.0 same
Hofmeyr et al.,1998^81^ South Africa | Transcervical amnioinfusion (176) | 42.0 | 1.0 same
Windrim et al., 2007^82^ Canada | Labor progress documented by standard sequential notes (962) | 25.4 | 0.7 same
Windrim et al., 2007^82^ Canada | Partogram added to standard written labor progress notes (970) | 24.7 | 0.7 same
Sadler et al., 2000^83^ New Zealand | Routine management (331) | 9.7 | 0.3 same
Sadler et al., 2000^83^ New Zealand | Active management (320) | 9.4 | 0.3 same
Barakat et al., 2009^84^ Spain | No exercise training (80) | 15.7 | 0.4 same
Barakat et al., 2009^84^ Spain | Exercise training (80) | 15.3 | 0.4 same
Althabe et al., 2004^85^ South America | Usual care (39,175) | 24.9 | 0.2 same
Althabe et al., 2004^85^ South America | Mandatory second opinion driven by evidence-based guidelines for indications (34,735) | 24.7 | 0.2 same
Hodnett et al., 2002^86^ US & Canada | Usual care (3,461) | 12.6 | 0.1 same
Hodnett et al., 2002^86^ US & Canada | Nurse support (3,454) | 12.5 | 0.1 same
Frigoletto et al., 1995^87^ US | Active management (1,009) | 19.5 | 0.1 same
Frigoletto et al., 1995^87^ US | Usual care (906) | 19.4 | 0.1 same
Ajadi et al., 2006^88^ Nigeria | No amniotomy on admission (64) | 1.6 | 0.0 same
Ajadi et al., 2006^88^ Nigeria | Amniotomy on admission (64) | 1.6 | 0.0 same
Elferink-Stinkens et al., 2004^89^ Netherlands | Usual care (>130,000) | NR | 0.0 same
Elferink-Stinkens et al., 2004^89^ Netherlands | Report of departmental data in table and graph form with follow-up (>130,000) | NR | 0.0 same
Hinshaw et al., 2008^90^ UK | Delayed oxytocin (204) | 13.7 | 0.0 same
Hinshaw et al., 2008^90^ UK | Early oxytocin (208) | 13.7 | 0.0 same
Lavender et al., 2006^91^ UK | 4-hour partogram (1,485) | 9.1 | 0.0 same
Lavender et al., 2006^91^ UK | 2-hour partogram (1,490) | 9.1 | 0.0 same
O'Sullivan et al., 2009^92^ UK | Usual care (1,216) | 30.0 | 0.0 same
O'Sullivan et al., 2009^92^ UK | Allowed to eat during labor (1,227) | 30.0 | 0.0 same
Waldenstrom et al., 2001^93^ Sweden | Standard care (505) | 11.9 | 0.0 same
Waldenstrom et al., 2001^93^ Sweden | Team midwife care (495) | 11.9 | 0.0 same
Hamilton et al., 2004^94^ US & Canada | Labor progress evaluated by plotting cervical dilatation against time (2,514) | 16.9 | -0.7 same
Hamilton et al., 2004^94^ US & Canada | Computerized reference range used to evaluate labor progress (2,474) | 17.6 | -0.7 same
Gambling et al., 1998^95^ US | Intravenous meperidine analgesia (607) | 5.6 | -0.7 same
Gambling et al., 1998^95^ US | Combined spinal-epidural anesthesia (616) | 6.3 | -0.7 same
Campbell et al., 2006^96^ US | Standard care (300) | 17.9 | -1.0 same
Campbell et al., 2006^96^ US | Lay doula support (298) | 18.9 | -1.0 same
Norris et al., 2001^97^ US | Epidural analgesia (1,112) | 13.4 | -1.1 same
Norris et al., 2001^97^ US | Combined spinal-epidural anesthesia (1,071) | 14.5 | -1.1 same
Regi et al., 2009^98^ India | Standard obstetric care without amnioinfusion (75) | 37.3 | -1.1 same
Regi et al., 2009^98^ India | Transcervical amnioinfusion (75) | 38.4 | -1.1 same
Ojala et al., 2006^99^ Finland | Fetal monitoring with cardiotocography only (739) | 4.7 | -1.7 same
Ojala et al., 2006^99^ Finland | Fetal monitoring with STAN (733) | 6.4 | -1.7 same
Cox et al., 1999^100^ UK | Usual care (240) | 3.8 | -2.0 same
Cox et al., 1999^100^ UK | Inflatable obstetric belt (260) | 5.8 | -2.0 same
Garite et al., 2000^101^ US | Fetal monitoring with cardiotocography only (502) | 26.0 | -3.0 same
Garite et al., 2000^101^ US | Fetal monitoring with cardiotocography and fetal pulse oximetry (508) | 29.0 | -3.0 same
Janssen et al., 2006^102^ Canada | Telephone triage (731) | 25.4 | -3.2 same
Janssen et al., 2006^102^ Canada | Home-based triage (728) | 28.6 | -3.2 same
Jalil et al., 2009^103^ Malaysia | IM pethidine analgesia (98) | 7.1 | -4.6 same
Jalil et al., 2009^103^ Malaysia | Epidural ropivacaine 0.2% with fentanyl 2 μg/ml (94) | 11.7 | -4.6 same
Palomäki et al., 2006^104^ Finland | Oxytocin plus placebo (55) | 4.0 | -7.0 same
Palomäki et al., 2006^104^ Finland | Oxytocin plus propranolol (55) | 11.0 | -7.0 same
Asher et al., 2009^105^ US | Acupuncture (30) | 20.0 | -10.0 3.0 same
Asher et al., 2009^105^ US | Usual care (no acupuncture) (30) | 10.0 | -10.0 3.0 same
Asher et al., 2009^105^ US | Sham acupuncture (29) | 7.0 | -10.0 3.0 same
Scheepers et al., 2002^106^ Netherlands | Placebo (99) | 7.1 | -13.5 higher
Scheepers et al., 2002^106^ Netherlands | Oral carbohydrate solution (102) | 20.6 | -13.5 higher

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial, higher indicates a higher rate supported by statistical significance

b Reported in text as 12.3, but based on data presented should be 11.3

Table 30 Summary of systems-level strategies to reduce cesarean births

Author, Year Country Study Type; Quality | Health Systems Strategies (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Sanchez-Ramos et al., 1990^152^ US Pre-post; Poor | Baseline: (4,350) | 27.5 | 17.0 lower
Sanchez-Ramos et al., 1990^152^ US Pre-post; Poor | Intervention: New guidelines for managing women with prior CS; also guidelines for evaluation and management of dystocia and fetal distress to reduce primary CS (5,163) | 10.5 | 17.0 lower
Langrew et al., 1996^158^ US Pre-post; Poor | Baseline: (NR) | 31.1 | 15.7 lower
Langrew et al., 1996^158^ US Pre-post; Poor | Intervention: Confidential provider feedback, more aggressive labor techniques (12,118) | 15.4 | 15.7 lower
Berglund et al., 2010^134^ Ukraine Pre-post; Poor | Baseline: (1,696) | 29.9 | 14.5 lower
Berglund et al., 2010^134^ Ukraine Pre-post; Poor | Intervention: WHO Effective Perinatal Care training and implementation ( 2,439) | 15.4 | 14.5 lower
Rust et al., 1993^154^ US Pre-post; Poor | Baseline: (467) | 21.2 | 11.0 lower
Rust et al., 1993^154^ US Pre-post; Poor | Intervention: Vaginal birth after CS, external cephalic version, adequate labor documentation and peer review of all CS for fetal distress (430) | 10.2 | 11.0 lower
Socol et al., 1993^142^ US Pre-post; Good | Baseline: (4,240) | 27.3 | 10.4 lower
Socol et al., 1993^142^ US Pre-post; Good | Intervention: Vaginal birth after CS encouraged, provider data circulated, active management of labor introduced as routine (4,669) | 16.9 | 10.4 lower
Iglesias et al., 1991^143^ Canada Pre-post; Good | Baseline: (237) | 23.0 | 10.0 lower
Iglesias et al., 1991^143^ Canada Pre-post; Good | Intervention: Vaginal birth after CS encourage, breech protocol introduced; guidelines for dystocia indication implemented (242) | 13.0 | 10.0 lower
Maher et al., 1994^162^ Australia Pre-post; Poor | Baseline: (1,112) | 20.6 | 9.6 lower
Maher et al., 1994^162^ Australia Pre-post; Poor | Intervention: Vaginal birth after CS encouraged, active management of labor and regular peer review (1,167) | 11.0 | 9.6 lower
Poma, 1998^146^ US Pre-post; Poor | Baseline: (2,234) | 23.2 | 7.2 lower
Poma, 1998^146^ US Pre-post; Poor | Intervention: Case review of cesareans using ACOG guidelines with feedback to individual providers (1,783) | 16.0 | 7.2 lower
Calvo et al., 2009^135,b^ Spain (Menorca) Pre-post; Poor | Baseline: (NR) | 29.0 | 7.0 lower^c^
Calvo et al., 2009^135,b^ Spain (Menorca) Pre-post; Poor | Intervention: Multifaceted feedback with rating of appropriateness of all CS (NR) | 22.0 | 7.0 lower^c^
Liang et al., 2004^161^ Taiwan Pre-post; Poor | Baseline: (9,864) | 36.7 | 6.5 lower
Liang et al., 2004^161^ Taiwan Pre-post; Poor | Intervention: Peer review included pre CS consultation (required second opinion for all CS) and post CS surveillance. Weekly CS conferences; physicians CS rates presented at conference. Protocol for selective trial of labor for women with prior CS. (7,937) | 30.2 | 6.5 lower
Meyers and Gleicher, 1988, 1993^141, 145^ US Pre-post; Poor | Baseline: (1,697) | 17.5 | 5.6 lower
Meyers and Gleicher, 1988, 1993^141, 145^ US Pre-post; Poor | Intervention: Implementation of six key guidelines with data feedback to individual providers (3,218) | 11.9 | 5.6 lower
Boylan et al., 1991^144^ US Pre-post; Good | Baseline: (1,843) | 24.3 | 5.5 lower
Boylan et al., 1991^144^ US Pre-post; Good | Intervention: Active management of labor introduced as routine (2,057) | 18.8 | 5.5 lower
Main et al., 1999^139^ US Pre-post; Poor | Baseline: (3,200 to 3,600) | 24.0 | 5.5 lower
Main et al., 1999^139^ US Pre-post; Poor | Intervention: Intensive outcomes feedback initially with provider identity coded then public within departments (NR) | 18.5 | 5.5 lower
Sloan et al., 2000^159^ Ecuador Pre-post; Poor | Baseline: (14,743) | 26.6 | 4.5 lower
Sloan et al., 2000^159^ Ecuador Pre-post; Poor | Intervention: Policy to provide co-management for CS candidates, including required second opinion (7,381) | 22.1 | 4.5 lower
Kim et al., 2005^137^ South Korea Pre-post; Good | Baseline: (161,360) | 43.0 | 3.4 lower
Kim et al., 2005^137^ South Korea Pre-post; Good | Intervention: Public media release of hospital cesarean data (NR) | 39.6 | 3.4 lower
Bickell et al., 1996^150^ and Dillon et al., 1992^149^ US Pre-post; Good, Poor | Baseline: (1,430 mean for 45 hospitals) | 29.1 | 3.3 same^c^
Bickell et al., 1996^150^ and Dillon et al., 1992^149^ US Pre-post; Good, Poor | Intervention: External peer review (1,503 mean for 45 hospitals) | 25.8 | 3.3 same^c^
Kiwanuka and Moore, 1993^156^ UK Pre-post; Poor | Baseline: (1,895) | 15.9 | 3.2 lower
Kiwanuka and Moore, 1993^156^ UK Pre-post; Poor | Intervention: Audit and feedback (2,216) | 12.7 | 3.2 lower
Kazandjian and Lied, 1998^140^ US, Canada, UK, Japan Pre-post; Good | Baseline: (NR) | 22.5 | 3.1 lower
Kazandjian and Lied, 1998^140^ US, Canada, UK, Japan Pre-post; Good | Intervention: Reporting of cesarean rates within a quality improvement program (NR) | 19.4 | 3.1 lower
Robson et al., 1996^157^ UK Pre-post; Good | Baseline: (12,628) | 12.0 | 2.5 lower
Robson et al., 1996^157^ UK Pre-post; Good | Intervention: Medical audit(8,497) | 9.5 | 2.5 lower
Smith et al., 2000^136^ US Pre-post; Poor | Baseline: (NR) | 27.0 | 2.5 lower^c^
Smith et al., 2000^136^ US Pre-post; Poor | Intervention: Reporting of cesarean rates within a quality improvement program (NR) | 24.5 | 2.5 lower^c^
Calvo et al., 2009^135,b^ Spain (Llatzer) Pre-post; Poor | Baseline: (NR) | 17.5 | 1.7 same
Calvo et al., 2009^135,b^ Spain (Llatzer) Pre-post; Poor | Intervention: Multifaceted feedback with rating of appropriateness of all CS (NR) | 15.8 | 1.7 same
World Health Organization, 1994^78^ Indonesia, Thailand, Malaysia RCT; Fair | Baseline: (10,049) | 6.2 | 1.7 same
World Health Organization, 1994^78^ Indonesia, Thailand, Malaysia RCT; Fair | Intervention: Use of WHO partogram with action line at 4hrs to guide active management of labor and decisions about cesarean (9,130) | 4.5 | 1.7 same
Gilstrap et al., 1984^151^ US Pre-post; Poor | Baseline: (6,693) | 16.8 | 1.6 lower
Gilstrap et al., 1984^151^ US Pre-post; Poor | Intervention: Informal criteria and policies established to assure adequate trial of labor, monitoring fetal distress, and criteria for management of breech (6,162) | 15.2 | 1.6 lower
Studnicki et al., 1997^160^ US Pre-post; Poor | Baseline: (NR) | 24.5 | 1.0 same^c^
Studnicki et al., 1997^160^ US Pre-post; Poor | Intervention State legislation requiring practice guidelines to staff credentialed for CS deliveries and establishment of peer review boards to review CS deliveries (183,921) | 23.5 | 1.0 same^c^
Tay et al., 1992^153^ Singapore Pre-post; Poor | Baseline: (3,156) | 12.3 | 0.6 same
Tay et al., 1992^153^ Singapore Pre-post; Poor | Intervention: Critical review of indications for CS and departmental audit (5,238) | 11.7 | 0.6 same
Althabe et al.,85 South America RCT; Poor | Control Group: Usual care (39,175) | 24.9 | 0.2 same
Althabe et al.,85 South America RCT; Poor | Intervention: Mandatory second opinion driven by evidence-based guidelines for indications (34,735) | 24.7 | 0.2 same
Elferink-Stinkens et al., 2004^89^ Netherlands RCT; Poor | Control Group: Usual care (>130,000) | NR | 0.0 same
Elferink-Stinkens et al., 2004^89^ Netherlands RCT; Poor | Intervention: Report of departmental data in table and graph form with follow-up (>130,000) | NR | 0.0 same
Gregory et al., 1999^138^ US Pre-post; Poor | Baseline: (5,134) | 29.6 | -0.5 same
Gregory et al., 1999^138^ US Pre-post; Poor | Intervention: 17 sequentially introduced quality improvement interventions (>30,000 births) | 30.1 | -0.5 same
Hamilton et al., 2004^94^ US and Canada RCT; Poor | Control Group: (2,515) | 16.9 | -0.7 same
Hamilton et al., 2004^94^ US and Canada RCT; Poor | Intervention: Computer assisted evaluation of labor progress with visual display of labor curves and reference ranges (2,478) | 17.6 | -0.7 same
Oleske et al., 1992^148^ US Pre-post; Poor | Baseline: (130,249) | 21.2 | -1.2 same
Oleske et al., 1992^148^ US Pre-post; Poor | Intervention: Informational brochures on average cost, length of stay and CS birth rate distributed to patients and providers. Press release of statewide cesarean birth patterns (167,654) | 22.4 | -1.2 same
Porreco, 1990^147^ US Trend; Poor | Baseline: (22,624) | 17.3 | 2.0 higher
Porreco, 1990^147^ US Trend; Poor | Intervention: Educational strategy focused on management of six key drivers of CS rate (23,462) | 19.3 | 2.0 higher
Pridjian et al., 1991^155^ US Pre-post; Poor | Baseline (2,827) | 12.5 | 3.4 higher
Pridjian et al., 1991^155^ US Pre-post; Poor | Intervention: Systematically incorporating VBAC into patient management (3,049) | 15.9 | 3.4 higher

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

b Two entries in table to reflect sites with data that could not be combined and had different outcomes.

c Statistical evidence not provided.

## KQ1 What strategies during pregnancy are effective to reduce the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

### Overview of the Literature

Nine studies of strategies used during pregnancy were included in the review (Table 3).40, 47, 52, 61-62, 65, 77, 84, 93 One study of identifying women at high risk of cesarean and preemptively conducting cervical ripening and induction of labor was done in the United States,62 one study of cervical ripening with injection of hyaluronidase in clinic was conducted in Brazil,40 and the balance were conducted in Europe and Australia. Seven trials were rated as fair,40, 47, 62, 65, 77, 84, 93 and two as poor (Appendices E and H).52, 61

Table 3 Summary of effectiveness of cesarean reduction strategies during pregnancy

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Spallicci et al., 2007^40^ Brazil; Fair | Placebo cervical injection (85) | 49.0 | 31.0 lower
Spallicci et al., 2007^40^ Brazil; Fair | Hyaluronidase injection in cervix (83) | 18.0 | 31.0 lower
Harvey et al., 1996^47^ Canada; Fair | Physician care (93) | 15.1 | 11.1 lower
Harvey et al., 1996^47^ Canada; Fair | Nurse-midwife care (101) | 4.0 | 11.1 lower
Homer et al., 2001^52^ Australia; Poor | Standard hospital-based care (539) | 17.8 | 4.5 lower
Homer et al., 2001^52^ Australia; Poor | Community-based model care (550) | 13.3 | 4.5 lower
Saisto et al., 2001^61^ Finland; Poor | Conventional therapy (91) | 48.4 | 4.9 same
Saisto et al., 2001^61^ Finland; Poor | Intensive therapy (85) | 43.5 | 4.9 same
Nicholson et al., 2009^62^ US; Fair | Standard care (134) | 14.9 | 4.6 same
Nicholson et al., 2009^62^ US; Fair | Induction of labor (136) | 10.3 | 4.6 same
Phipps et al., 2009^65^ Australia; Fair | Standard care (50) | 26.0 | 4.0 same
Phipps et al., 2009^65^ Australia; Fair | Structured education for pushing (50) | 22.0 | 4.0 same
Waldenstrom et al., 1997^77^ Sweden; Fair | Standard maternity care (932) | 8.9 | 1.8 same
Waldenstrom et al., 1997^77^ Sweden; Fair | Birth center care (928) | 7.1 | 1.8 same
Barakat et al., 2009^84^ Spain; Fair | No exercise training (80) | 15.7 | 0.4 same
Barakat et al., 2009^84^ Spain; Fair | Exercise training (80) | 15.3 | 0.4 same
Waldenstrom et al., 2001^93^ Sweden; Fair | Standard care (505) | 11.9 | 0.0 same
Waldenstrom et al., 2001^93^ Sweden; Fair | Team midwife care (495) | 11.9 | 0.0 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

### Key Points

- Evidence about reducing cesarean through antenatal care models designed to enhance continuity is based on four RCTs with 4,337 participants. These studies have inconsistent findings and provide insufficient evidence. Each of the other approaches used during pregnancy is represented by a single trial with fewer than 300 participants and provides insufficient evidence to guide care (Table 34).
- Care from members of a midwifery practice team who provided both prenatal and birth care compared to conventional care demonstrated a modest 4.5-percent reduction in cesarean births in one study (n=1283). Two other studies of team midwifery and birth center prenatal care did not document reductions.
- Injection of hyaluronidase into the cervix, in patients at term with a low Bishop score demonstrated a 31 percent reduction in risk of cesarean birth in one small study (n=168). No other studies were found that repeated evaluation of this strategy.

### Detailed Synthesis

#### Antenatal Care Models

Continuity of care and familiarity of the patient with her care provider and her provider with her history and specific pregnancy details has been proposed to reduce uncertainty in decision making and to preempt strategies like cesarean that might otherwise be undertaken in the context of less shared knowledge and experience. Studies examining care models have typically sought to evaluate if continuity from prenatal into birth care can reduce cesarean. An RCT conducted in Australia randomized 1,283 pregnant women at their first antenatal visit to either a “community model of care” with six midwives, and obstetrician, and a registrar providing consistent care with a team continuity model or to a “standard model of care” with a larger number of midwives, obstetricians, registrars, and general practitioners, without an attempt to have consistency among providers.52 The RCT used the Zelen model of randomization -- the participants were first randomized, and then asked to consent. If a participant randomized to the intervention wished to receive the control care model, she was allowed to do so and was included in the intervention group for intention-to-treat analysis. Cesarean incidence was 13.3 percent in the intervention group and 17.8 percent in the control group. This is an absolute reduction of cesarean use of 4.5 percent among those assigned to team based care compared to usual care (adjusted odds ratio [AOR]=0.6, 95% confidence interval (CI): 0.4, 0.9; p=0.02).52

Another RCT conducted in Australia randomized 1,000 pregnant women with uncomplicated pregnancies prior to 25 weeks gestation to either team midwifery care or standard obstetric care.93 Cesarean risk did not differ between the two groups, by intention-to-treat analysis. Of the women receiving team midwife care, 55 of 464 (11.9%) had a cesarean, compared to 56 of 471 (11.9%) receiving standard care (OR=1.00, 95% CI: 0.66, 1.15). There was no difference between the reported neonatal outcomes for the intervention and control groups (mortality 1.1% vs. 1.5%, 5-minute Apgar <7 1.9% vs. 1.5%, NICU admission 10.3% vs. 7.6% [OR=1.4, 95% CI: 0.87, 2.26]) (Tables 4 and 5).93

Table 4 Maternal outcomes for antenatal strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 2.2-3.0^47, 62^ | NR | 2.6-12.7^47, 52, 77, 93^ (4) | 0^47, 77^
Antenatal care, community model52, birth center77, team midwife care47, 93 | 1.0^47^ | NR | 1.6-12.5^47, 52, 77, 93^ (4) | 0^47, 77^
Exercise training84 | NR | NR | NR | NR
Education on pushing65 | NR | NR | NR | NR
Hyaluronidase injection in cervix40 | NR | NR | NR | NR
Induction62 | 4.4 | NR | NR | NR
Intensive therapy for fear of childbirth61 | NR | NR | NR | NR

NR=not reported

Table 5 Neonatal outcomes for antenatal management strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5 Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality,% (n Studies)
Control | 0.8-8.2^40, 47, 52, 62, 77, 93^ (6)^a^ | 6.7-19.4^47, 52, 62, 77, 93^ (5) | 10.2-17.2^77, 93^ (2) | 0-1.5^47, 52, 77, 93^ (4)
Antenatal care, community model52, birth center77, team midwife care47, 93 | 1.3-4.0^47, 52, 77, 93^ (4) | 7.9-14.5^47, 52, 77, 93^ (4) | 9.6-11.1^77, 93^ (2) | 0-1.1^47, 52, 77, 93^ (4)
Exercise training84 | 9.9 ± 0.2^b^ | NR | NR | NR
Education on pushing65 | NR | NR | NR | NR
Hyaluronidase injection40 | 2.4^b^ | NR | NR | NR
Induction62 | 0 | 1.5 | NR | 0
Intensive therapy for fear of childbirth61 | NR | NR | NR | NR

NICU=neonatal intensive care unit

a Not specified if 1, 5, or 10 minute Apgar score;

b Mean ± SD; Control group: 9.9 ± 0.3^84^

NR=not reported

A pilot study of nurse-midwifery care compared to physician care in Canada randomized 194 women from the community.47 Women in the control group chose their physician, any obstetrician or family physician in the city, using a standard referral process. Women assigned to nurse-midwife care received care from a team of seven nurse-midwives. The scheduling for the midwifery clinic was designed so that women saw as many of the midwives as possible during their antenatal clinic visits. Women who received care from the nurse-midwives were significantly less likely to have a cesarean. Of the women receiving midwifery care 4 of 101 (4.0%) had a cesarean compared to 14 of 93 (15.1%) of those who received physician care (95% CI: 2.89, 19.3%; p=0.01). More infants in the physician care group had Apgar scores less than seven at one minute (13.9% vs. 29.0, 95% CI: 3.75, 26.6%; p=0.013) and were admitted to the NICU (7.9% vs. 19.4, 95% CI: 1.8, 2.1%; p=0.02). There were no neonatal deaths in either group.47

A Swedish RCT randomized 1,860 women at their first or second antenatal visit to either a birth center care model or a standard care model.77 The birth center care model was comprehensive and integrated antenatal, intrapartum and postpartum care with the same team of midwives. Their practice, which is in a hospital-based birth center, includes restricted use of medical technology and discharge within 24 hours. The standard care model was the usual form of public maternity care offered to women in the Greater Stockholm area, with approximately 75 community centers providing antenatal care (two of which were private) and seven hospitals providing intrapartum and postpartum care. While midwives were the primary caregivers in this model, as well, there were separate antenatal and intrapartum midwife teams.77

Women were allowed to change groups, but data analysis was by intention-to-treat so this bias would have tended to lower the measured effect. There was no significant difference in cesarean use: 7.1 percent in the intervention group and 8.9 percent in the control group, an absolute reduction of 1.8 percent (95% CI: -4.3, 0.7; p=0.18).77 Neonatal outcomes for the intervention and control groups did not differ (mortality 0.9% vs. 0.2 percent, five-minute Apgar less than seven 1.3% vs. 1.1 percent, and special care nursery admission 11.1% vs. 9.0%).77

#### Exercise Training

Physical activity has been associated with reduced maternal complications in pregnancy and may have potential to reduce cesarean risk.108-109 An RCT conducted in Spain randomized 160 pregnant women to either light intensity resistance exercise training during the second and third trimesters or to no exercise training.84 Inclusion criteria limited participants to women with uncomplicated pregnancies who were sedentary (not exercising more than 20 minutes on more than three days per week). Analysis was not done using an intention-to-treat approach. There was no difference in the cesarean rate between the intervention and control groups (15.3% vs. 15.7%).84

#### Management of Fear of Childbirth

If fear of labor, interventions, or the birth itself impairs progress in labor or ability to work in partnership with care providers, fear could elevate cesarean risk. A community-based RCT, conducted in Finland, randomized 176 pregnant women with fear of childbirth to either intensive intervention or conventional care.61 The participants were physically healthy with low-risk pregnancies. The intensive intervention included written education materials, questionnaires, cognitive behavioral therapy, provider discussions, and creation of a birth plan. There was no statistical difference in use of cesarean between the two groups: 43.5 percent among those in the intervention and 48.4 in the control group.61

#### Induction of Labor for Women at Risk for Cesarean

A multi-site RCT conducted in the U.S. randomized 270 pregnant women to either induction of labor after 37 weeks and 4 days gestation or to usual care.62 The authors hypothesized that pre-emptive induction of labor rather than spontaneous onset of labor, could prevent cesarean in women who were predicted to be at high risk of cesarean. Between 32 and 37 weeks gestation, pregnant women were assessed for six risk factors for high probability of a cesarean birth: (1) maternal age greater than or equal to 35 at birth, (2) maternal height less than or equal to 62 inches, (3) BMI ≥30 kg/m^2^, (4) blood pressure more than 80 mmHg diastolic or 120 mmHg systolic, (5) hemoglobin less than 11 g/dL in first trimester, (6) history of a prior birthweight more than 8 lbs 8 oz. If the patient had one or more of these risk factors for cesarean, she was invited to enroll in the study; participants were then randomized. Participants in the intervention group who had not given birth by 37 weeks and 4 days were scheduled for cervical ripening and induction of labor one to four days prior to what was considered by the study algorithm to be the upper limit for optimal timing of birth. Data analysis was not by intention-to-treat. Cesarean risk was statistically the same across groups: 10.3 percent among the intervention group and 14.9 percent among those who received standard care, in this study powered to detect a 66 percent relative difference.62 There was no difference between these reported neonatal outcomes for the intervention and control groups: (mortality 0.0% vs. 0.8%, 5-minute mean Apgar score 8.9 vs. 8.9, 5-minute Apgar score less than 7 0.0% vs. 0.8%). NICU admission rates for the intervention were lower for the intervention group (1.5% vs. 6.7%: RR=0.22, 95% CI: 0.05, 0.99; p=0.03).62

#### Structured Education for Pushing

Second stage or “pushing” is the final phase of labor before the birth. Maternal exhaustion, fear, or difficulty in coordinating pushing could theoretically result in a dysfunctional second stage and increase cesarean risk. An RCT conducted in Australia randomized 100 low-risk women who had not previously given birth to either structured education about pushing or routine care.65 The strategy was two 15-minute structured education sessions teaching pushing with observation of the perineum and digital pressure and biofeedback to the levator muscle. Cesarean risk did not differ between the two groups: 22 percent among those who received structured education for pushing and 26 percent among those receiving standard care. The study had inadequate sample size to detect differences in cesarean risk.65 Use of episiotomy and incidence of perineal tears did not differ between the groups.65

#### Hyaluronidase Injection Into the Cervix

Before labor, the cervix typically softens or “ripens” becoming more pliable to allow dilation and effacement during labor. A standardized score, the Bishop score, can be used to describe whether the cervix is favorable or unfavorable for induction of labor. In this case the investigators used that scoring mechanism in a novel way to identify women with little cervical softening in order to use an agent that could accelerate cervical ripening. An RCT conducted in Brazil randomized 168 women with a Bishop Score of less than five to either injection of hyaluronic acid or injection of a placebo mixture.40 The strategy consisted of 5 ml of 20,0000 IU lyophilized hyaluronidase, sodium chloride, mannitol, and thiomersal diluted in distilled water and injected at 12 o'clock and 6 o'clock into the cervix. The control consisted of sodium chloride, mannitol, thiomersal, benzalkonium chloride, and riboflavin phosphate diluted in distilled water and injected at 12 o'clock and 6 o'clock into the cervix. Technically the study compared two strategies: hyaluronidase versus benzalkonium chloride and riboflavin phosphate. Thiomersal contains mercury and could not be given to pregnant women in the United States. Benzalkonium chloride can be toxic in humans and could not be given to pregnant women in the United States. The cesarean rate in the control group of 85 women was 49 percent, and the overall cesarean rate among 2,684 women giving birth at the same hospital over the same period of time was 29 percent. Eighteen percent of women in the intervention group compared to 49 percent in the control group had a cesarean. The absolute risk reduction was 31 percent (95% CI: 18, 44; p<0.0001).40 Apgar scores were not different between the two groups. This systematic literature review and subsequent hand-searching did not identify a published study that preceded or attempted to replicate this research.40

## KQ2 What strategies during labor are effective to reduce the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

### Management of Labor

#### Overview of the Literature

This section presents results of 21 studies meeting our review criteria and addressing strategies for management of labor. These strategies are used almost exclusively during the first stage of labor, which is the time period in which the cervix is dilating and thinning. The strategies include early labor assessment (two trials); 68, 102 a midwife-led unit;72 measurement of labor progress with a partogram, a graphic representation of the progress of labor, or computerized reference curve (four trials);51, 82, 91, 94 active management of labor (six trials);50, 64, 66, 71, 83, 87 management of abnormal labor (five trials);41, 54, 79, 90, 104 amniotomy (one trial);88 intravenous (IV) fluids (one trial);56 and an oral carbohydrate solution (one trial).106 Of the 17 trials, six were conducted in the United States,41, 56, 64, 66, 79, 87 four in the UK,51, 54, 90-91 three in Canada,68, 82, 102 one in the Netherlands,106 one in Norway,72 one in Finland,104 one in New Zealand,83 one in Thailand,71 one in Nigeria,88 one in South Africa,50 and one was multinational (US and Canada)94. All but three of the trials41, 72, 104 included only nulliparous women. Two studies were published in the 1980s,54, 79 six studies in the 1990s,41, 51, 64, 66, 68, 87; and 13 studies in 2000 or later.50, 56, 71-72, 82-83, 88, 90-91, 94, 102, 104, 106 There were five trials of good quality,41, 50-51, 56, 91 seven of fair quality,54, 68, 82, 88, 102, 104, 106 and nine of poor quality (Appendices E and H).64, 66, 71-72, 79, 83, 87, 90, 94

#### Key Points

- Early labor assessment to delay hospital admission until active labor, defined by cervical change, compared with direct admission of women in labor regardless of progression did not reduce the use of cesarean.
- Home-based triage, compared with telephone triage to help a woman judge when to come to the hospital in labor, did not reduce the use of cesarean.
- Each of the early labor assessment strategies was found to provide insufficient evidence (Table 34). The four studies of measurement of labor progress, which enrolled 10,832 women, provide low strength of evidence for lack of benefit of partograms for reducing cesarean. The six RCTs of active management have conflicting findings but as good and poor quality studies of more than 5,300 women, they provide low strength of evidence for lack of evidence of benefit. Single studies provide insufficient evidence to inform care.
- Adding a partogram to standard written labor progress notes did not reduce the use of cesarean. Cesarean rates with 2-hour and 4-hour partograms were equivalent.
- A computerized reference range for assessing labor progress did not reduce the use of cesarean.
- A midwife-led unit, compare to a normal unit and special unit, did not reduce the use of cesarean.
- Active management of labor, as defined by the authors, did not reduce the use of cesarean.
- The only labor management strategies that significantly reduced the use of cesarean were the addition of propranolol to oxytocin for augmentation of dysfunctional labor, a combined strategy of partogram with active management, and use of a 4-hour partogram compared with a three-hour partogram (see Table 2). However, a second study did not find a significant reduction in the use of cesarean when propranolol and oxytocin were initiated simultaneously for dysfunctional labor treatment.
- Cesarean rates were identical in women who did and did not have amniotomy at the time of hospital admission.
- Increased intravenous fluids did not reduce the use of cesarean.
- An oral carbohydrate solution increased the use of cesarean.

#### Detailed Synthesis

##### Early Labor Assessment

The goal of early labor assessment is to delay hospital admission until a woman is in active labor because early admission is associated with increased rates of obstetric intervention, including cesarean.110-111 Two Canadian trials of fair quality assessed the effect of early labor assessment strategies (see Table 6 below).68, 102 A trial of 1,459 nulliparous women compared home-based triage (n=728) with telephone triage (n=731).102 Women in both groups were evaluated for labor progress and abnormalities, fetal movement, and maternal coping. In addition, those women who had home visits also had maternal vital signs checked, abdominal palpation, fetal heart rate auscultation, assessment of contractions, and cervical examination. Women in the telephone group were given suggestions for coping with contractions while women and their partners in the home visit group received education about comfort measures. Criteria for advising women to proceed to the hospital were the same for both groups except cervical dilatation, which was used as an additional criterion for the home visit group. The percentage of women who had a cesarean birth was higher in the home-based triage group (28.6%) than the telephone triage group (25.4%), but this difference was not statistically significant (RR=1.12, 95% CI: 0.94, 1.32). Five-minute Apgar scores (RR=1.52, 95% CI 0.54-4.23), admission to a Level II nursery (RR=0.93, 95% CI: 0.63, 1.37), and admission to a Level III nursery (RR=2.35, 95% CI: 0.90, 6.08) were comparable (Tables 10 and 11).

Table 6 Summary of effectiveness of labor management cesarean reduction strategies: early labor assessment

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
McNiven et al., 1998^68^ Canada; Fair | Direct admission (104) | 10.6 | 3.0 same
McNiven et al., 1998^68^ Canada; Fair | Early labor assessment (105) | 7.6 | 3.0 same
Janssen et al., 2006^102^ Canada; Fair | Telephone triage (731) | 25.4 | -3.2 same
Janssen et al., 2006^102^ Canada; Fair | Home-based triage (728) | 28.6 | -3.2 same

a Same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

Table 10 Maternal outcomes for labor management strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 8.1-19.1^56, 71, 82^ (3) | 0.9-19.1^56, 64, 66, 71, 83^ (5) | 2.2-22.1^51, 56, 64, 83, 90-91, 117^ (7) | NR
Amniotomy at admission88 | NR | NR | NR | NR
High-dose oxytocin54 | NR | NR | NR | NR
Low-dose oxytocin54 | NR | NR | NR | NR
Early aggressive management50, 79 | NR | NR | NR | NR
Increased IV fluids56 | 14.9 | 14.9 | 4.0 | NR
Computerized range for labor progress94 | NR | NR | NR | NR
Early oxytocin90 | NR | NR | 19.7 | NR
Home-based triage102 | NR | NR | NR | NR
2-hour partogram51, 91 | NR | NR | 12.4-12.5 | NR
3-hour partogram51 | NR | NR | 12.9 | NR
4-hour partogram51, 91 | NR | NR | 12.5 | NR
Active management64, 66, 71, 83,87 | 8.1^71^ | 0-14^66, 83,a^ | 4.0-15.0^64, 83^ | NR
Early labor assessment68 | NR | NR | NR | NR
Oxytocin plus propranolol41, 104 | NR | NR | NR | NR
Partogram plus standard labor progress notes82 | 11.8 | NR | NR | NR
Midwife-led unit72 | NR | NR | 1.7 | NR
Oral carbohydrate solution106 | NR | NR | NR | NR

a P<0.01^66^; NR=not reported

Table 11 Neonatal outcomes for labor management strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5 Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0-6.3^41, 50-51, 54, 56, 64, 66, 68, 71-72, 82, 88, 90-91, 94, 102^ (16) | 2.0-11.0^41, 51, 56, 64, 66, 72, 82, 90-91, 102, 104^ (11) | NR | 0-0.5^50, 66, 90^ (3)
Amniotomy at admission88 | 7.8^a^ | NR | NR | NR
High-dose oxytocin54 | 0.0 | NR | NR | NR
Low-dose oxytocin54 | 4.8 | NR | NR | NR
Early aggressive management50, 79 | 0.9^50,d^ | NR | NR | 0.9^50,e^
Increased IV fluids56 | 1.0 | 9.9 | NR | NR
Computerized range for labor progress94 | 2.0 | NR | NR | NR
Early oxytocin90 | 2.5^b^ | 2.9 | NR | 0.5
Home-based triage102 | 1.2 | 8.1^c^ | NR | NR
2-hour partogram51, 91 | 1.5-1.9 | 1.3-1.4 | NR | NR
3-hour partogram51 | 1.3 | 0.3 | NR | NR
4-hour partogram51, 91 | 1.6-2.0 | 0.6-2.0 | NR | NR
Active management64, 66, 71, 83. 87,f | 0.3-1.9 | 0.5-4.0^64, 66^ | NR | 0^66^
Early labor assessment68 | 1.0 | NR | NR | NR
Oxytocin plus propranolol41, 104 | 2.0^41^ | 2.0-11.0 | NR | NR
Partogram plus standard labor progress notes82 | 1.2 | 3.4 | NR | NR
Midwife-led unit72 | 1.0 | 8.0 | NR | NR
Oral carbohydrate solution106 | NR | NR | NR | NR

NICU=neonatal intensive care unit; IV=intravenous; NR=not reported

a One-minute Apgar scores. Five-minute Apgar scores were not provided, but the articles notes were no statistically significant differences in the number of newborns with Apgar scores < 7 at one or five minutes.

b Apgar scores ≤ 7

c Includes admission to Level II or Level III nursery

d Apgar < 8 at 10 minutes

e Includes an intrauterine death known prior to trial enrollment

f One-minute Apgar scores (five-minute Apgar scores not reported)

In a trial that enrolled 209 women without prior births, participants were randomized to early labor assessment or direct admission when they presented to the hospital in labor.68 Women in the early labor assessment group were evaluated and only admitted to the labor and delivery unit if they were in active labor, defined as the presence of regular, painful contractions and cervical dilation greater than 3 cm. Women who were not in active labor were advised to walk outside or return home until active labor began. Women in the control group were not assessed prior to admission to the labor and delivery unit. The percentage of women who had a cesarean birth was lower in the early labor assessment group (7.6%) than the direct admission group (10.6%), but this difference was not statistically significant (OR=0.70, 95% CI: 0.27, 1.81).68 As shown in Table 11, the percentage of infants with Apgar scores lower than seven at five minutes was comparable (p=0.318).68

##### Midwifery-Led Care

According to the U.K.'s National Institute for Health and Clinical Excellence, low-risk women who give birth in a midwife-led unit are more likely to have a normal birth with less intervention.112 A poor quality trial from Norway compared outcomes for nulliparous and multiparous women who gave birth in 1) a midwife-led unit for low-risk women who wanted as little intervention as possible where epidural and augmentation outside of the second phase of second stage of labor were not available (n=412); 2) a normal unit for women with expected normal births where extended surveillance, epidural, operative vaginal birth, cesareans, and induction of labor were offered (n=417); and 3) a special unit for women requiring extended surveillance in the antepartum period, during labor, or after birth (n=282).72 Women expecting normal births can give birth at any of the three units; however, the midwife-led unit only accepts low-risk women. Eligible women who desired to participate were randomized to one of the three units at the onset of spontaneous labor. The percentage of women who had a cesarean birth was lower in the midwife-led unit (16.0%) than the normal unit (18.0%) or special unit (18.8%), but these differences were not statistically significant (midwife-led unit vs. normal unit RR=0.90, 95% CI: 0.67, 1.22; midwife-led unit vs. special unit RR=0.87, 95% CI: 0.62, 1.20).72 The percentage of women with postpartum hemorrhage, neonates with Apgar score less than seven at five minutes, and NICU admissions did not differ significantly across groups (Tables 10 and 11).72

##### Measurement of Labor Progress

The purpose of measuring labor progress is to remain vigilant for and intervene early in abnormal progress, also known as labor dystocia, which is the most common indication for primary cesareans in the United States.113 When dystocia is identified, strategies to improve labor progress, such as augmentation with oxytocin, can be used. Various methods of tracking labor progress are available including the partogram, which is a paper form used to record labor examination findings such as cervical dilation, fetal descent, and contraction frequency. The partogram provides a graphical representation of labor progress and alerts clinicians to abnormal progress.114 Four trials investigated strategies to measure labor progress. Three involved partograms,51, 82, 91 and the fourth used a computerized reference range (Table 7).94

Table 7 Summary of effectiveness of labor management cesarean reduction strategies: measurement of labor progress

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Lavender et al., 1998^51^ UK; Good | 3-hour partogram (302) | 14.2 | 5.8 (4-hour vs. 3-hour) lower
Lavender et al., 1998^51^ UK; Good | 4-hour partogram (311) | 8.4 | 5.8 (4-hour vs. 3-hour) lower
Lavender et al., 1998^51^ UK; Good | 2-hour partogram (315) | 11.1 | 5.8 (4-hour vs. 3-hour) lower
Windrim et al., 2007^82^ Canada; Fair | Labor progress documented by standard sequential notes (962) | 25.4 | 0.7 same
Windrim et al., 2007^82^ Canada; Fair | Partogram added to standard written labor progress notes (970) | 24.7 | 0.7 same
Lavender et al., 2006^91^ UK; Good | 4-hour partogram (1,485) | 9.1 | 0 same
Lavender et al., 2006^91^ UK; Good | 2-hour partogram (1,490) | 9.1 | 0 same
Hamilton et al., 2004^94^ US & Canada; Poor | Labor progress evaluated by plotting cervical dilatation against time (2,514) | 16.9 | -0.7 same
Hamilton et al., 2004^94^ US & Canada; Poor | Computerized reference range used to evaluate labor progress (2,474) | 17.6 | -0.7 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

Use of a partogram in conjunction with standard written labor progress notes was compared to documentation of labor progress solely with sequential notes in a Canadian study with 1,962 participants.82 The proportion of women who had a cesarean birth was lower in the group whose labors were assessed with the partogram compared with those who only had standard notes (24.7 percent vs. 25.4%), but this difference was not statistically significant (p=NS reported with no specific value given).82 The differences in rates of maternal fever, five-minute Apgar scores less than seven, and NICU admission were not statistically significant (test results not reported, see Tables 10 and 11).

Partograms typically include pre-printed alert and action lines. The alert line represents the labor progress of the slowest (less than or equal to the 10^th^ percentile) of nulliparous women. The action line, which prompts clinicians that intervention may be warranted for slow labor progress, is placed a number of hours (usually two to four) after the alert line.114 In two trials in the United Kingdom, women whose labor progress crossed the action line had management for prolonged labor (oxytocin augmentation with amniotomy if membranes were intact).51, 91 In the first trial,51 315 women had a partogram with a two-hour action line, 302 women had a partogram with a three-hour action line, and 311 women had a partogram with a four-hour action line. The rate of cesarean birth was lowest in the women in the 4-hour group (8.4%) followed by the two-hour group (11.1%) and the three-hour group (14.2%).51 When the intervals were compared (2-hour vs. 3-hour, 3-hour vs. 4-hour, and 2-hour vs. 4-hour), only the results for the 4-hour versus the 3-hour were significant (OR=1.8, 95% CI: 1.1, 3.2).51 In the second trial,91 1,490 women had a partogram with a 2-hour action line, and 1,485 women had a partogram with a 4-hour action line. The rate of cesarean birth in both groups was identical (9.1%).91 Both trials had rates of postpartum hemorrhage, 5-minute Apgar scores less than seven, and NICU admission that did not differ significantly across groups (see Tables 10 and 11).51, 91

One trial in 4,988 women evaluated the addition of a computerized reference range to standard measurement of labor progress by plotting cervical dilatation against time in nulliparous women.94 The software combined the results of clinical examinations with contraction frequency from uterine monitoring to produce a percentile comparison to the reference range. Cesareans were performed in 17.6 percent of the experimental group and 16.9 percent of the control group. This difference was not statistically significant (RR=1.04, 95% CI: 0.92, 1.18).94 The only maternal or neonatal outcome of interest that was reported was the percentage of newborns in each group who had five-minute Apgar scores lower than seven, which was nearly identical (see Table 11).

##### Active Management of Labor

Active management of labor is a general term for a multifaceted approach to labor care that includes some or all of the following: “patient education, strict criteria for the diagnosis of labor, strict criteria for the determination of abnormal progress of labor, high-dose oxytocin infusion, one-to-one nursing support in labor, strict criteria for interpretation of fetal compromise, and peer review of operative deliveries.”113 The purpose of active management of labor is to decrease the incidence of dystocia, which should in turn decrease the cesarean rate.66 A Cochrane review of seven active management trials initially did not find a significant reduction in the cesarean rate, but the difference was significant (RR=0.77, 95% CI: 0.63, 0.94) when a trial in which more than one-third of participants become ineligible after randomization was removed from the analysis.115 The Cochrane review differed from this report in that it specifically sought studies examining active management regardless of low-risk status or primary aim of reducing cesarean.115

Six trials examined use of active management of labor for cesarean reduction; one demonstrated effectiveness (Table 8).50, 64, 66, 71, 83, 87 This trial of good quality in South Africa combined use of a partogram with aspects of active management.50 Nulliparous women in active labor, defined as regular and painful contractions with cervical dilatation of four or more centimeters, were assigned to aggressive (n=344) or expectant (n=350) management.50 A partogram with a single alert line was used for the aggressive management group who had a repeat vaginal examination two hours after the first examination. If cervical dilatation had progressed on or above the alert line, the cervix was reexamined in two to four hours depending on when complete cervical dilatation was expected. If cervical dilatation crossed the alert line, fetal heart rate was normal, and gross cephalopelvic disproportion was not present, oxytocin was started. The expectant management group had a partogram with an alert line and a four-hour action line. Their cervical examination was repeated four hours after initial examination. If cervical dilatation had progressed on or above the alert line, the cervix was reexamined in two to four hours depending on current dilatation and expected time of complete dilatation. If cervical dilatation had moved to the right of the alert line, the cervix was reexamined at the time it was anticipated the action line would be crossed. If cervical dilatation reached or crossed the action line, fetal heart rate was normal, and gross cephalopelvic disproportion was not present, oxytocin was started. Amniotomy was not performed due to the high prevalence of HIV and thus need to prevent vertical transmission. The cesarean rate was 16.0 percent in the aggressive management group and 23.4 percent in the expectant management group (RR=0.68, 95% CI: 0.50, 0.93).50 As shown in Table 11, three newborns (one of which was a known intrauterine fetal death [IUFD] prior to enrollment) in the aggressive management group and none in the expectant management group had Apgar scores less than eight at 10 minutes.50 There were three perinatal deaths in the aggressive management group (including the known IUFD) and none in the expectant management group, but this difference was not statistically significant (RR=7.12, 95% CI: 0.37, 137.37).50

Table 8 Summary of effectiveness of labor management cesarean reduction strategies: active management of labor

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Pattinson et al., 2003^50^ South Africa; Good | Expectant management (350) | 23.4 | 7.4 lower
Pattinson et al., 2003^50^ South Africa; Good | Aggressive management (344) | 16.0 | 7.4 lower
Rogers et al., 1997^64^ US; Good | Usual care (205) | 11.7 | 4.2 same
Rogers et al., 1997^64^ US; Good | Active management (200) | 7.5 | 4.2 same
Lopez-Zeno et al., 1992^66^ US; Poor | Traditional management (354) | 14.1 | 3.6 same
Lopez-Zeno et al., 1992^66^ US; Poor | Active management (351) | 10.5 | 3.6 same
Somprasit et al., 2005^71^ Thailand; Poor | Conventional management (640) | 14.7 | 2.8 same
Somprasit et al., 2005^71^ Thailand; Poor | Active management (320) | 11.9 | 2.8 same
Sadler et al., 2000^83^ New Zealand; Poor | Routine management (331) | 9.7 | 0.3 same
Sadler et al., 2000^83^ New Zealand; Poor | Active management (320) | 9.4 | 0.3 same
Frigoletto et al., 1995^87^ US; Poor | Active management (1009) | 19.5 | 0.1 same
Frigoletto et al., 1995^87^ US; Poor | Usual care (906) | 19.4 | 0.1 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

A New Zealand trial of poor quality randomized 551 nulliparous women to active (n=320) or routine (n=331) management when labor was diagnosed, which was defined as regular, painful contractions every five minutes or more lasting at least 40 seconds accompanied by either spontaneous rupture of membranes or complete cervical effacement with cervical dilatation of at least two centimeters.83 In the active management group, amniotomy was encouraged at the time of labor diagnosis, and the cervix was assessed every two hours. Oxytocin augmentation was initiated if cervical dilation was less than one centimeter per hour, descent of the fetal head had not occurred after 30 minutes of pushing, or contractions were more than five minutes apart without imminent birth during the second stage of labor. Oxytocin was started at 6 mU per minute and increased by 6 mU every 15 minutes to a maximum dose of 36 mU per minute. In the routine management group, the caregiver determined use of amniotomy, frequency of cervical examination, and use of oyxtocin.83 The cesarean rate was 9.4 percent in the active management group and 9.7 percent in the routine management group (p=0.5).83 The groups did not differ significantly in maternal infection (RR = 1.12; 95% CI: 0.72, 1.74) or postpartum hemorrhage (RR=1.04, 95% CI: 0.72, 1.51; see Table 10).83

In a U.S. trial of poor quality, nulliparous women were randomized to active management (n=1,009) or usual care (n=906) before 30 weeks' gestation.87 Women in the active management group attended special childbirth classes to explain the protocol, while women in the usual care group were given payment to attend the classes of their choice. Active management was provided in a separate unit by nurse-midwives and nurses who worked exclusively for the study. Active management included one-to-one nursing care and standardized criteria for labor diagnosis (painful contractions with effacement of at least 80 percent, bloody show, or spontaneous rupture of membranes). Women in the active management group had amniotomy within one hour of labor diagnosis and cervical examinations at least every two hours. Women who had inefficient uterine action (cervical dilation of less than one centimeter per hour during first stage or greater than one hour between full dilatation and the fetal head reaching the pelvic floor during second stage) or more than 30 minutes elapsed between the fetal head reaching the pelvic floor and the birth received oxytocin (started at 4 mU per minute and increased by 4 mU every 15 minutes to a maximum dose of 40 mU per minute).87 Care of women with failure to progress (cervical dilation less than one centimeter per hour after efficient uterine action was established with oxytocin or prolonged second stage) was assumed by the woman's regular provider. No constraints were placed on management of the usual care group. Use of amniotomy, initiation of oxytocin, and cervical examination were at the provider's discretion. When oxytocin was used, it was typically started at a dose of one to two mU per minute and increased by 1-2 mU per minute periodically. The rate of cesarean was 19.5 percent in the active management group and 19.4 percent in the usual care group (RR=1.0, 95% CI: 0.8, 1.2).87 Among the protocol-eligible subgroup (n=678 active management, n=585 usual care), incidence of maternal fever was lower in the active management group than the usual care group (n not provided; RR=0.6, 95% CI: 0.4, 0.9).87 There was no significant difference between groups in admission to the NICU (n and statistical test result not provided).87

A U.S. trial of poor quality with 705 nulliparous women enrolled participants in spontaneous labor, which was defined as regular, painful contractions at least every five minutes plus complete cervical effacement or spontaneous rupture of membranes.66 Active management included amniotomy within one hour of labor diagnosis, hourly cervical examinations for the first three hours then examinations every two hours, and high-dose oxytocin augmentation (started at 6 mU per minute and increased by 6 mU per minute every 15 minutes) for cervical dilation of less than one centimeter per hour in the first stage of labor or fetal descent of less than one centimeter per hour in the second stage of labor. In the traditional management group, the physician decided when to perform amniotomy, how often to examine the cervix, and what criteria were used to diagnose inadequate labor progress. When oxytocin augmentation was used, it was typically started at 1 mU per minute and increased by 1-2 mU per minute every 15 minutes until there were eight contractions per 20 minutes. The cesarean rate was 10.5 percent in the active management group, and 14.1 percent in the traditional management group (p=0.18).66 The active management group had a significantly lower rate of chorioamnionitis than the traditional management group (4.6% vs. 9.9% percent, p<0.01).66 Differences in five-minute Apgar scores less than seven and NICU admission rates were not significant (test result not reported, see Table 11).66 No neonatal deaths occurred in either group.66

Another U.S. trial of poor quality enrolled 405 nulliparous women.64 Participants in the active management group were diagnosed with labor when they had regular, painful contractions every two to five minutes with at least 80 percent cervical effacement, regardless of dilatation. They had amniotomy within two hours of admission, cervical examination every two hours, and high-dose oxytocin augmentation (started at 6 mU per minute and increased every 15 minutes) for cervical dilation of less than one centimeter per hour in the first stage of labor or fetal descent of less than one centimeter per hour in the second stage of labor. Participants in the control group were admitted when they had regular, painful contractions every two to five minutes and three to four centimeters of cervical dilatation, regardless of effacement.64 Amniotomy was performed at the physician's discretion. If the cervix did not change 1.25 centimeters per hour once the active phase of labor began, low-dose oxytocin was started (1 mU per minute and increased by 1 mU/min every 30 to 40 minutes). The cesarean rate was 7.5 percent in the active management group and 11.7 percent in the expectant management group, which was not a significant difference.64 Maternal and neonatal outcomes were similar in both groups (not statistically significant, no test results reported, see Tables 10 and 11).64

In a poor quality trial of 960 nulliparous women in Thailand,71 labor was diagnosed when by regular, painful contractions lasting at least 40 seconds and occurring at least once per five minutes plus spontaneous rupture of membranes or bloody show with cervical dilatation and complete effacement. The active management group had amniotomy within one hour of admission, cervical examination every two hours, and high doses of oxytocin (started at 6 mU per minute and increased by 2 mU per minute every 30 minutes until there were five contractions per 10 minutes or the rate was 40 mU per minute) if cervical dilatation was less than one centimeter per hour in the first stage of labor.71 The conventional management group did not have a protocol for amniotomy, cervical examination, or oxytocin initiation. The use of cesarean was lower in the active management group (11.9%) than the conventional management group (14.7%), but this difference was not significant (p-value not reported).71 There were no significant differences (test results not reported) between groups in rates of maternal fever, chorioamnionitis, and one-minute Apgar scores less than seven (Tables 10 and 11).71

##### Management of Abnormal Labor

Five trials assessed strategies for managing abnormal labor (see Table 9).41, 54, 79, 90, 104 One resulted in proven reduction of cesarean. A poor quality trial of early versus delayed oxytocin included 412 nulliparous women with primary dysfunctional labor, diagnosed by cervical dilatation of two centimeters or less over four hours from initial dilatation of three to six centimeters.90 Women with intact membranes had amniotomy prior to randomization. The early oxytocin group started oxytocin within 20 minutes of randomization, while the delayed oxytocin group did not receive oxytocin for eight hours unless intervention was warranted.90 Cesarean risk was identical in the two groups (14%), and there were no significant differences in postpartum hemorrhage (OR=0.87, 95% CI: 0.5, 1.4), five-minute Apgar scores (OR=1.6, 95% CI: 0.4, 7.0), NICU admission (OR=1.2, 95% CI: 0.4, 3.9), or neonatal death (OR=0.98, 95% CI: 0.06, 16) (Tables 10 and 11).90

Table 9 Summary of effectiveness of labor management cesarean reduction strategies: management of abnormal labor

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Sanchez-Ramos et al., 1996^41^ US; Good | Oxytocin plus placebo (47) | 51.1 | 24.6 lower
Sanchez-Ramos et al., 1996^41^ US; Good | Oxytocin plus propranolol (49) | 26.5 | 24.6 lower
Bidgood et al., 1987^54^ UK; Fair | Observation (20) | 45.0 | 18.7 (high-dose vs. obs.) same
Bidgood et al., 1987^54^ UK; Fair | High-dose oxytocin (19) | 26.3 | 18.7 (high-dose vs. obs.) same
Bidgood et al., 1987^54^ UK; Fair | Low-dose oxytocin (21) | 33.3 | 18.7 (high-dose vs. obs.) same
Cohen et al., 1987^79^ US; Poor | Control (75) | 14.6 | 1.3 same
Cohen et al., 1987^79^ US; Poor | Early aggressive management (75) | 13.3 | 1.3 same
Hinshaw et al., 2008^90^ UK; Poor | Delayed oxytocin (204) | 13.7 | 0 same
Hinshaw et al., 2008^90^ UK; Poor | Early oxytocin (208) | 13.7 | 0 same
Palomäki et al., 2006^104^ Finland; Fair | Oxytocin plus placebo (55) | 4.0 | -7.0 same
Palomäki et al., 2006^104^ Finland; Fair | Oxytocin plus propranolol (55) | 11.0 | -7.0 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

Two trials, one of good quality in the U.S.41 and one of fair quality in Finland,104 compared oxytocin alone and with propranolol, a beta receptor blocking agent thought to have the potential to enhance uterine activity, for treatment of abnormal labor progress. These were the only trials related to management of labor that included both nulliparous and multiparous women. The first trial defined dysfunctional labor as no cervical dilatation for at least two hours in the active phase of labor or a deceleration phase of at least three hours in nulliparas and one hour in multiparas.41 All women continued to receive oxytocin. Propranolol (n=49) or placebo (n=47) were administered intravenously and repeated after one hour if cervical dilatation did not change. Cesarean was performed if there was no response within an hour after the second dose.41 The cesarean rate was 26.5 percent in the propranolol group and 51.1 percent in the placebo group (RR=0.58, 95% CI: 0.35, 0.93; p=0.02).41 Differences in Apgar scores and NICU admissions were not significant (Table 11). The second trial defined arrest of labor as hypocontractility with other causes of dystocia, such as disproportion, excluded.104 At the time of diagnosis of arrested labor, oxytocin was initiated along with a dose of propranolol (n=55) or placebo (n=52), which was repeated an hour later if the cervical status was unchanged.104 The timing of cesarean was not specified as it was in the first trial. The cesarean rate was 11 percent in the propranolol group and 4 percent in the placebo group (p=0.154). The difference in NICU admissions was not significant (Table 11).104

One trial of fair quality, done in the United Kingdom, examined three oxytocin protocols in 60 nulliparous women in labor (diagnosed by complete cervical effacement, dilatation greater than or equal to three centimeters, regular contractions with at least one per five minutes, and cervical progress on a partogram) whose cervical dilatation was less than 0.5 centimeters per hour.54 Amniotomy was performed prior to randomization for women with intact membranes. Participants were randomized into three arms: delayed oxytocin for eight hours (n=20); automatic infusion system (AIS) oxytocin (2 mU per minute increased by 2 mU every 15 minutes) for women whose uterine activity was less than 700 kPas per 15 minutes (n=21, 13 received oxytocin); and high-dose oxytocin (7 mU per minute increased by 7 mU every 15 minutes, n=19).54 The cesarean rate was 45 percent in the delayed oxytocin group, 33.3 percent in the AIS oxytocin group, and 26.3 percent in the high-dose oxytocin use. Differences across groups were not statistically significant.54 Five-minute Apgar scores lower than seven (Table 11) did not differ significantly between groups (test result not reported).54

A poor quality U.S. trial of early intervention included 150 primigravid women who had been admitted in labor (diagnosed by contractions plus cervical dilatation of three centimeters or ruptured membranes) and had an inadequate contraction pattern (less than 3 contractions lasting 40 seconds each in a 10-minute time period).79 The early intervention group had amniotomy if membranes were intact, insertion of a fetal electrode and an intrauterine pressure cannula, and initiation of oxytocin infusion, all of which were performed within 30 minutes of admission. The control group had external fetal monitoring and oxytocin infusion if the cervical dilatation did not change for more than two hours or if there was no change in station for one hour during the second stage of labor.79 The cesarean incidence was 13 percent in the early intervention group and 15 percent in the control group, a difference that was not statistically significant.79

##### Amniotomy

Amniotomy, the surgical rupture of fetal membranes, has been purported to shorten the duration of the first stage of labor although a Cochrane review of 15 studies found no statistical difference in first-stage labor length or the rate of cesarean when amniotomy was performed.116 A fair quality trial in Nigeria, randomly assigned 128 women to amniotomy or no amniotomy upon presentation in labor.88 Both groups had identical risk of cesarean (1.6 percent; p>0.05). The only neonatal outcome reported was five-minute Apgar scores, which were comparable between groups (test result not reported, see Table 11).88

##### Increased Intravenous Fluids

One U.S. trial of good quality evaluated the effect of increased intravenous hydration in labor based on the rationale that adequate fluid replacement might improve labor progress, and subsequently reduce the cesarean rate, similar to the effects of adequate hydration on the exercise performance of athletes.56 Women received increased (250 ml/hour, n=101) or standard (125 ml/hour, n=94) rates of lactated Ringer's solution or isotonic sodium chloride solution.56 The percentage of women who had a cesarean birth was lower in the 250-ml group (9.9%) than the 125-ml group (17.0%), but this difference was not statistically significant (p=0.22). Maternal and infant outcomes were similar (no test of statistical significance reported, see Tables 10 and 11).56

##### Oral Carbohydrate Solution

One trial of fair quality from the Netherlands evaluated the effect of an oral carbohydrate solution during labor based on the rationale that carbohydrate intake might reduce the cesarean rate and improve labor progress, similar to the effects of carbohydrate intake on the exercise capacity and fatigue among athletes.106 Women received a carbohydrate (n=102) or placebo (n=99) solution to drink at will. They were not offered other food or drinks but could have small amounts of either upon request.106 The percentage of women who had a cesarean birth was higher in the carbohydrate group (20.6%) than the placebo group (7.1 percent; RR=2.91, 95% CI: 1.29, 6.54).106 Maternal and infant outcomes we extracted were not reported (Tables 10 and 11).106

### Psychosocial Support

“Doula” is a Greek word that refers to a woman caregiver96 or an experienced woman who helps another woman or a new mother.46, 48, 118 Today, the word has come to mean a woman experienced in childbirth who provides continuous physical and emotional support throughout labor and birth.42, 46, 48, 96, 118 Continuous one-on-one nursing support is uninterrupted support by staff nurses with training in labor support.86 Labor support is defined as “the presence of an empathetic person who offers advice, information, comfort measures, and other forms of tangible assistance to help a woman cope with the stress of labor and birth.”86 Unlike standard maternity care for women in labor, with continuous one-on-one nursing, one nurse is assigned to provide uninterrupted care for one laboring patient throughout labor and childbirth.

#### Overview of the Literature

We identified seven RCTs42, 46, 48, 67, 73, 86, 96, 118 that examined the effect of psychosocial support interventions on cesarean births. One study added a non-randomized control group after randomizing participants into two other groups.48 Three studies were conducted in the United States,46, 48, 96 one in Mexico,42 one study in the United States and Canada,86 one in Canada,73 and one in Finland.67 All interventions took place in labor and delivery. Three studies were conducted in community practices42, 46, 48 and three were conducted in academic single sites.67, 73, 96 One study was conducted in multiple settings, including nine academic and four non-academic sites.86 Five of the studies were restricted to nulliparous women, two included nulliparous and parous women.67, 86 We separated the seven studies into three categories: doulas as providers of labor support,42, 46, 48 a female friend or family member as a provider of labor support,96 and nurses and midwifery students as providers of labor support.67, 73, 86 There was one trial of fair quality86 and six of poor quality (Appendices E and H).42, 46, 48, 67, 73, 96

#### Key Points

- Low strength of evidence for benefit of trained doula support for reducing cesarean. The single model in which female friends and family give labor support provides insufficient evidence and nursing models of one-to-one support in three trials with 7,568 participants provide low strength of evidence of lack of benefit (Table 34).
- The three doula support studies showed a reduction in cesarean births for women in the groups who received doula support. The absolute reduction in cesarean ranged from five to 22 percent.
- Cesarean was not reduced by support from a female friend or family member trained to provide labor support.
- Cesarean rates were not lower for women who received continuous labor support from nurses or midwifery students compared to women who received usual labor care.

#### Detailed Synthesis

##### Doulas as Providers of Labor Support

Three doula support studies were included (Table 12).42, 46, 48 All studies of doula support were conducted with participants in labor who had uncomplicated pregnancies at term and were having their first birth. One RCT in Mexico42 compared 50 women who received labor support from childbirth educators who had doula training to 50 women who received usual labor care. The study was conducted at a public hospital with an overall cesarean rate of 40 percent. Doulas were Lamaze-trained childbirth educators, who received doula training as part of the Lamaze Childbirth Education curriculum. During labor and childbirth, doulas provided advice and information, physical assistance and emotional support to the study participants and worked actively to promote natural childbirth.42

Table 12 Summary of effectiveness of cesarean reduction strategies using doula support

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Trueba et al., 2000^42^ Mexico; Poor | Standard care (50) | 24.0 | 22.0 lower
Trueba et al., 2000^42^ Mexico; Poor | Childbirth educator trained as doula (50) | 2.0 | 22.0 lower
McGrath and Kennell, 2008^46^ US; Poor | Routine care (196) | 25.0 | 11.6 lower
McGrath and Kennell, 2008^46^ US; Poor | Doula support (224) | 13.4 | 11.6 lower
Kennell et al., 1991^48^ US; Poor | Control group assigned after delivery (204) | 18.0 | 10.0 lower 5.0
Kennell et al., 1991^48^ US; Poor | Received support of a doula (212) | 8.0 | 10.0 lower 5.0
Kennell et al., 1991^48^ US; Poor | Observed by an inconspicuous observer (200) | 13.0 | 10.0 lower 5.0

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

The proportion of births by cesarean for the doula supported and usual care groups were 2 and 24 percent respectively (p<0.003).42 Labor duration did not differ significantly for the two groups (p-value not reported). Incidence of oxytocin administration for the doula supported and usual care groups were 42 percent and 96 percent respectively (p<0.001).42

In a U.S. trial,46 224 women were assigned to doula support and 196 to usual care. The study was conducted at a university hospital with an overall cesarean rate of 24 percent. All doulas completed training requirements that were equivalent to the Doulas of North America International doula certification. The doula met couples shortly after random assignment and stayed with them throughout labor and birth providing verbal encouragement, reassurance, teaching, and touch, to support the laboring woman and her partner.46 Women in the doula supported group had significantly fewer cesarean births (13.4% vs. 25.0%, p=0.002) and fewer epidurals (64.7% vs. 76.0%, p=0.008). Five-minute Apgar scores did not differ (p=0.30) (Table 14).46

Table 14 Neonatal outcomes for psychosocial/labor support strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5 Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0.7-3.1^46, 86, 96^ (3)^a, b, c^ | 4.9-7.3^73, 86^ (2) | NR | 0-0.03^48, 86^ (2)
Doula support42, 46, 48 | 1.8^46,a,b^ | NR | NR | 0^48^
Observation by inconspicuous observer48 | NR | NR | NR | 0
Nursing support73, 86 | 0.9^86^ 8.9 ± 0.9^b,73^ | 7.1-7.2^73, 86^ | NR | 0.06^86^
Midwifery student support67 | 9.12 ± 0.48^b^ | NR | NR | NR
Trained friend or family member as labor support96 | 0.3^c^ | NR | NR | NR

NICU=neonatal intensive care unit; NR=not reported

a Percent with Apgar ≤ 7 at 5 min46, 86

b Reported mean Agpar ± SD at 5 minutes--Control 8.98 ± 0.45^67^; Control: 9.0 ± 0.8^73^

c Percent with Apgar ≤ 6 at 5 min96

Another U.S. trial48 randomized 412 women to doula support or monitoring by an inconspicuous observer. The authors also selected an additional 204 women for an additional “control” comparison group.48 The trial was conducted at a public hospital where companions were not routinely permitted to be with a woman during labor and birth. For study participants, brief visits by family members were allowed if the labor area was not too busy. All doulas completed a three-week training period.48 They stayed at the patient bedside from admission through birth providing touch, encouragement and information about the labor and childbirth process. The observer stayed in the labor room, but at a distance from the mother, and did not interact with the laboring woman.

The proportions of cesarean births for the doula support, observed, and control groups were 8, 13 and 18 percent respectively (p<0.0001 for all three groups).48 When pair wise comparisons were made, significant differences remained (doula vs. observed, p=0.009 and doula vs. control, p=0.004). This study reported forceps births for 8.2 percent of women in the doula support group and 21.3 percent for women in the observed group (p=0.0006).48 Forceps-assisted births occurred in 26.3 percent of women in the control group (p=0.006, doula support group vs. control group). Among participants who had spontaneous vaginal births, epidural use varied significantly for the doula, observed, and control groups (p<0.0001).48 The mean duration of labor was significantly shorter for the doula group compared to the observed (p<0.02) and control (p<0.02) groups.48 Labor augmentation occurred less frequently in the support group compared to the control group (p<0.0001).48 The percentages for oxytocin use for labor augmentation were 17, 23 and 43.6 percent, across groups (p<0.0001).48 Maternal fever was more common in the observed and control groups than in the supported group, but there was no statistical analysis provided (Table 13).48 The authors noted that the proportion of newborns who remained in the hospital more than 48 hours because of medical problems was lower in the supported group (Table 14).48

Table 13 Maternal outcomes for psychosocial/labor support strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 10.3^48, 86^ (2) | NR | 2.6^86^ | 0^46^
Doula support42, 46, 48 | 1.4^48,a^ | NR | NR | 0^46^
Observation by inconspicuous observer48 | 7.0 | NR | NR | NR
Nursing support73, 86 | 0.7^86^ | NR | 2.7^86^ | NR
Midwifery student support67 | NR | NR | NR | NR
Trained friend or family member as labor support 96 | NR | NR | NR | NR

a One study46 reported fever ≥ 37.5° for the total study population: 17.4%; ≥ 38°: 6.9%; NR=not reported

##### Trained Female Friend or Family Member as Provider of Labor Support

In the RCT that used family or friend supports,96 291 women were assigned to the supported group and 295 women were assigned to usual care. The participant selected a female friend or family member who participated in two 2-hour learning sessions.96 A research assistant who was a doula certified by Doulas of North America conducted training that included: anatomy and physical changes during labor and childbirth, assessing labor progression, coping strategies, how to provide anticipatory guidance, comfort measures and reassurance to laboring women.96 There were no restrictions on visitors or other support for laboring women at the hospital. The primary cesarean rate for the study facility during the enrollment period was 17.9 percent.

In this study, support from a trained friend or family member did not reduce cesarean births. The proportions of cesarean births for the intervention and usual care groups were 18.9 and 17.9 percent respectively (p=0.7).96 Women in the supported group had significantly shorter lengths of labor (p=0.004), greater cervical dilation at the time of epidural (p=0.007), and a higher proportion of five-minute Apgar scores above six (p=0.006).96

##### Nurses and Midwifery Students as Providers of Labor Support

Two studies in the U.S. and Canada investigated the effects of continuous labor support by nurses,73, 86 and one in Finland examined the effects of labor support by midwifery students.67 The effectiveness of these strategies are presented in Table 15.

Table 15 Summary of effectiveness of cesarean reduction strategies: labor support by nurses and midwifery students

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Hemminki et al., 1990^67^ Finland; Poor | Usual care (118) | 5.0 | 3.0 same
Hemminki et al., 1990^67^ Finland; Poor | Midwifery student support (122) | 2.0 | 3.0 same
Gagnon, 1997^73^ Canada; Poor | Usual nursing care (204) | 16.2 | 2.3 same
Gagnon, 1997^73^ Canada; Poor | One-to-one nursing care (209) | 13.9 | 2.3 same
Hodnett et al., 2002^86^ US & Canada; Fair | Usual care (3,461) | 12.6 | 0.1 same
Hodnett et al., 2002^86^ US & Canada; Fair | Nurse support (3,454) | 12.5 | 0.1 same

a Same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

One randomized controlled Canadian trial73 of poor quality, assigned 209 women to one-to-one intrapartum support from a nurse and 204 women to usual care. Usual care consisted of two to three patients per nurse with variable labor support techniques provided. The strategy was almost continuous one-to-one nursing care from the time of randomization until one hour after the birth. In addition to usual intrapartum care, the support nurse provided physical comfort, emotional support, instruction on relaxation and coping with pain, and support for the father. The support nurses completed an initial 30-hour training period and quarterly refresher workshops.73

Cesarean risk was not significantly different.73 The proportion of cesareans in the supported and usual care groups was 13.9 and 16.2 percent, respectively (RR=0.86, 95% CI: 0.54, 1.36). Use of oxytocin stimulation for women in the nurse supported group was 17 percent lower (RR=0.83; 95% CI: 0.67, 1.04).73 There were no significant differences in epidural analgesia (RR=0.96, 95% CI: 0.84, 1.09), instrumented vaginal births (RR=1.06, 95% CI: 0.74, 1.53), five-minute Apgar scores (Mean difference=-0.1, 95% CI: 0.1, 1.05), and NICU admissions (RR=1.46, 95% CI: 0.64, 3.18).73

A RCT86 randomized 6,290 participants to continuous labor support or usual care. Study sites included nine tertiary care and four community hospitals. The strategy was continuous labor support by a specially trained nurse from the time of randomization to birth. Nurses volunteered to participate and completed a two-day training program conducted by an expert labor nurse doula trainer.86 Usual care varied depending on a patient's stage of labor, condition, and nurse workload but did not include care by a nurse with special labor support training.

The proportion of cesarean births in the intervention and usual care groups was 12.5 and 12.6 percent, respectively (p=0.44).86 Labor augmentation for the continuous labor support and usual care groups was 30.1 and 27.2 percent, respectively (p=0.008).86 Assisted vaginal births, duration of labor, and use of epidural did not differ. There were no significant differences in neonatal outcomes including neonatal deaths (p-value not provided), need for higher level of nursery care (p=0.70), five-minute Apgar scores (p=0.50) and length of hospital stay (p-value not provided).86

A study conducted in Finland67 included three trials: one small pilot using laywomen as labor support persons and two trials using midwifery students as labor support persons, one conducted in 1987 and one in 1988. The pilot study with laywoman support was stopped for economic and other reasons.

These studies were conducted at a university hospital.67 At this hospital, normal births are attended by midwives who do not stay with the patient constantly, and usually take care of more than one laboring woman at a time. Fathers are present for 60 to 70 percent of births. The hospital's cesarean birth rate was 9.8 percent. In 1987, 11 midwifery students volunteered to provide support in labor for study participants, and in 1988 all 16 midwifery students were required to participate.67

The 1987 trial randomized 79 women to midwifery student labor support or usual care.67 The 1988 midwifery student trial randomized 161 women to either a midwifery student for labor support or usual care. The authors reported outcomes for each trial year and for both combined.67 Cesarean births were equally common: none among supported and eight percent in the usual care in 1987, three and four percent in 1988, and five and five percent for both years combined. The supported group had significantly shorter labors from admission to birth (p<0.05). Among women giving birth for the first time, a smaller percentage of women in the supported group had labor durations of 11 hours or more (p<0.01).67 The percentage of women whose contractions stopped was significantly lower in the supported group (5 vs. 15%; p<0.01). Postpartum complications (infections, discharge diagnoses and proportion of mothers not nursing at discharge) were rare and similar in both groups. Mean Apgar scores were higher for neonates in the supported group (p<0.05).67

### Pain Management

Methods of pharmacologic pain management include epidurals, spinal blocks, combined spinal-epidurals (CSE), and systemic and local analgesia. Epidural analgesia, in which local anesthetic, usually in conjunction with an opioid, is administered into the lower spinal area, is widely used in the United States. A recent report from 27 states showed more than 60 percent of women who gave birth vaginally in 2008 received epidural or spinal anesthesia.120 Though the technique may be similar there are differences in the medications used and the method of administration (bolus, continuous infusion, patient controlled). A Cochrane review that evaluated epidural versus nonepidural or no analgesia in labor concluded that epidurals as compared to opiates were associated with an increased risk of instrumented birth but not an increased risk of cesarean.121

#### Overview of the Literature

Seven studies compared pain management strategies in labor with a goal of reducing cesarean births.49, 58, 63, 76, 95, 97, 103 Two studies were conducted in the United States,95, 97 three in Europe,49, 58, 63 and two in Asia.76, 103 Six of the studies were randomized clinical trials49, 58, 63, 76, 95, 103 and one was a quasi-randomized trial.97 All studies took place in the labor and delivery suites in single hospitals. Inclusion criteria included term singleton pregnancy without medical complications, vertex presentation, and intention of vaginal birth. One study103 required previous childbirth, and one was restricted to women who had not previously had births.49 Five of the studies included both nulliparous and parous women.58, 63, 76, 95, 97 Six studies used epidural analgesia although each of the studies was unique in their drug regimens and dosages. In four studies all women received epidurals and the intervention was focused on type,97 medication dose,49, 63 or ability to ambulate.58 Two trials compared epidural to analgesia given intravenously (IV) or by intramuscular (IM) injection95, 103 and one evaluated paracervical block with tranquilizer to tranquilizer only.76 Two studies were assessed as being of fair,95, 103 and the remaining five were poor quality (Appendices E and H).49, 58, 63, 76, 97

#### Key Points

- Results across these studies are inconsistent. In total they provide low strength of evidence for lack of benefit of pain management strategies as an approach to reduce cesarean (Table 34).
- One study reported a significantly lower use of cesarean associated with intermittent epidural versus continuous epidural suggesting that lower cumulative doses of epidural analgesia may be associated with lower cesarean risk.49
- Cesarean risk among women receiving epidural analgesia as compared to IV or IM analgesia did not differ.95, 103

#### Detailed Synthesis

Seven studies evaluated the effect of various pain management strategies to reduce cesarean births.49, 58, 63, 76, 95, 97, 103 The effectiveness of these strategies is presented in Table 16 below.

Table 16 Summary of effectiveness of cesarean reduction strategies of pain management

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Skrablin et al., 2011^49^ Croatia; Poor | Continuous epidural (104) | 14.4 | 9.4 lower
Skrablin et al., 2011^49^ Croatia; Poor | Intermittent epidural (101) | 5.0 | 9.4 lower
Karraz, 2003^58^ France; Poor | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, non-ambulatory (74) | 16.2 | 7.0 same
Karraz, 2003^58^ France; Poor | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, ambulatory (141) | 9.2 | 7.0 same
Olofsson et al., 1998^63^ Sweden; Poor | Epidural anesthesia with high dose local anesthetic (0.25% bupivacaine with adrenaline) (435) | 14.7 | 4.5 same
Olofsson et al., 1998^63^ Sweden; Poor | Epidural anesthesia with low dose (0.125% bupivacaine with sufentanil 10 μg (422) | 10.2 | 4.5 same
Mehrangiz et al., 2004^76^ Iran; Poor | Promethazine only (50) | 4.0 | 2.0 same
Mehrangiz et al., 2004^76^ Iran; Poor | Paracervical block with promethazine (50) | 2.0 | 2.0 same
Gambling et al., 1998^95^ US; Fair | Intravenous meperidine analgesia (607) | 4.0 | 2.0 same
Gambling et al., 1998^95^ US; Fair | Combined spinal-epidural anesthesia (616) | 2.0 | 2.0 same
Norris et al., 2001^97^ US; Poor | Epidural analgesia (1112) | 13.4 | -1.1 same
Norris et al., 2001^97^ US; Poor | Combined spinal-epidural anesthesia (1071) | 14.5 | -1.1 same
Jalil et al., 2009^103^ Malaysia;Fair | IM pethidine analgesia (98) | 7.1 | -4.6 same
Jalil et al., 2009^103^ Malaysia;Fair | Epidural ropivacaine 0.2% with fentanyl 2μg/ml (94) | 11.7 | -4.6 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

Two studies examined whether the amount of epidural anesthesia received influences cesarean risk.49, 63 The most recent study conducted in 205 women in Croatia49 reported lower use of cesarean among nulliparous women who received an intermittent epidural (5%) compared to a continuous epidural (14.4%) (RR=2.9, 95% CI: 1.1, 7.7; p=0.03). The mean doses of levobupivacaine and fentanyl were significantly lower in the intermittent group.49 A poor quality trial in Sweden with 1,000 participants63 demonstrated a significantly lower rate of combined instrumented births for women who received an epidural with low dose local anesthesia (bupivacaine 1.25 mg/ml with sufentanil 5 μg/ml) (29.7%) as compared to epidural with high dose of local anesthesia (bupivacaine 2.5 mg/ml with adrenaline 5μg/ml) (48.9%) (p<0.0001). Cesarean births were 10.2 percent and 14.7 percent for the low and high dose respectively, but no statistical analysis was reported.63

A study of 2,182 births in the U.S.97 compared CSE to epidural only and reported no significant difference in cesarean use (14.5% for the CSE group and 13.4% for the epidural only). This poor quality study was unusual in that the anesthesia assignment was randomized by day of birth for a 10-month period.97 Additionally data sheets were missing for more than 600 women. A French study58 investigated the impact of epidural dosing to allow ambulation in 215 women and reported 9.2 percent of women in the ambulatory group compared to 16.2 percent of women in the non-ambulatory group had cesareans (p=0.15). The ambulatory group also had a significantly shorter duration of labor.58

A U.S. study with 1,223 participants95 compared CSE (sufentanil, bupivacaine and fentanyl) to IV meperidine but did not find differences in cesarean (6% and 5.5% respectively, p=ns).95 The use of forceps was higher in the subset of nulliparous women, but not different between the groups (10% for CSE and 9% for IV only; p=NS). A Malaysian study of 192 parous women103 compared epidural (0.2% ropivacaine with fentanyl 2 μg/ml) to IM pethidine/meperidine with no statistically significant difference in cesarean (11.7% among women who received epidurals vs. 7.1% in the IM arm; p=0.19).103 Women who received epidurals were more likely to have an instrumented birth and prolonged first and second stages of labor.103 A study of 100 women in Iran76 compared paracervical block with tranquilizer to tranquilizer only and found no differences in cesarean (p=0.3). Women who received the block had faster pain relief and a shorter duration of the first stage of labor.76

Data on maternal harms were reported in only three studies (Table 17).49, 95, 97 In the first, incidence of fever was similar in the intermittent (23%) and continuous (20%) epidural treatment groups and postpartum hemorrhage was reported in three women.49 Gambling and colleagues95 reported fever in 22 percent of women in the CSE group and only three percent in the IV group (p<0.005). Norris et al.97 reported low rates of accidental dural puncture (1.3% in the CSE group compared to 1.2 percent in the epidural group).

Table 17 Maternal outcomes for pain management strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 3.0^95^ | NR | NR | 0.0^103^
Intermittent epidural49 | 23.0 | NR | 1.0 | NR
Continuous epidural49 | 20.0 | NR | 2.0 | NR
Combined spinal-epidural95, 97 | 22.0^95^ | NR | NR | NR
Epidural with high dose local anesthetic63 | NR | NR | NR | NR
Epidural;103 ambulatory58 | NR | NR | NR | NR
Paracervical block with tranquilizer76 | NR | NR | NR | NR

NR=not reported

Overall data on infant harms were not well reported. No significant differences in five-minute Apgar scores between groups were seen in any of the studies. Data on NICU admissions were not reported in any study. There were no infant deaths in the three studies that reported this information (Table 18).76, 95, 103

Table 18 Neonatal outcomes for labor management strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5 Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0-3.9^63, 76, 95, 103^ (4) | NR | NR | 0^76, 95, 103^ (3)
Intermittent epidural49 | 3.0 | NR | NR | NR
Continuous epidural49 | 1.9 | NR | NR | NR
Combined spinal-epidural95, 97 | 0^95,a^ | NR | NR | 0^95^
Epidural with high dose local anesthetic63 | 4.5 | NR | NR | NR
Epidural;103 ambulatory58 | 1.1^103^ | NR | NR | 0^103^
Paracervical block with tranquilizer76 | 0 | NR | NR | 0

NICU=neonatal intensive care unit; NR=not reported

a Mean Apgar scores of 9 in both groups97

### Fetal Assessments

Electronic fetal monitoring (EFM) uses special equipment to measure the fetal heart rate (FHR) in response to contractions of the uterus. It provides an ongoing record that can be followed by the health care provider. EFM has been the predominant tool used for fetal surveillance during labor. Methods for monitoring can be external, internal, or both. With external fetal monitoring a belt with an ultrasound transducer is strapped around the woman's abdomen to detect the FHR. Another belt is placed on the abdomen to measure the frequency and duration of contractions. The FHR and uterine contraction information is recorded. For internal fetal monitoring, a wire or electrode is placed on the part of the fetus closest to the cervix, which is usually the scalp. This device records the heart rate. Uterine contractions and their strengths also may be monitored with a special intrauterine pressure catheter inserted through the cervix into the uterus. Internal monitoring can be used only after the membranes of the amniotic sac have ruptured. The normal FHR is between 110 and 160 beats per minute and typically changes in response to contractions, slowing down as a contraction begins. Accelerations (increases in the fetal heart rate meeting specific criteria) often indicate the fetus is well oxygenated at the time they are observed. Periodic increases in the heart rate also are normal. These changes form a pattern. Some patterns may suggest that the fetus is not getting enough oxygen.

Intermittent fetal scalp sampling is another way to evaluate fetal status during labor and is sometimes used in conjunction with EFM, with a trend towards less use over time in the United States.43 Fetal scalp sampling helps determine recent fetal oxygenation status by testing the pH of fetal blood during periods of concerning heart rate patterns referred to as nonreassuring FHR patterns. This procedure requires a small blood sample to be taken from the scalp of the fetus. Normal pH documents adequate fetal oxygenation.

Fetal pulse oximetry was first tested in the late 1990s.70 It is another way that has been developed to continuously monitor the fetus during labor. It has been used for research purposed in the United States and is not in general use. It uses far red and near-infrared wavelengths in conjunction with a sensor placed near the fetal cheek to provide a continuous reading of fetal oxygenation during labor.43 Human and animal studies have shown that in the fetus, which normally has an oxygen saturation in labor of 35 percent to 65 percent, an oxygen deficit does not develop until the saturation falls below 30 percent for at least 10 to 15 minutes.122-124 Therefore fetal oxygen saturation 30 percent or greater tends to be considered reassuring, whereas values less than 30 percent for at least 10 minutes require further assessment or intervention.122, 125-128

Most recently, ST segment analysis of fetal electrocardiography (STAN) has emerged as an adjunct for fetal surveillance. STAN is another continuous monitoring device used for analyzing changes in the fetal electrocardiogram.99 The device combines standard EFM technology with the addition of ST waveform analysis to provide a fetal electrocardiogram (ECG). The fetal ECG is obtained via a fetal scalp electrode. The STAN automatically identifies and analyses changes in the T wave and the ST segment of the fetal ECG to give clinicians more detailed information about fetal well-being.

#### Overview of the Literature

Six studies addressing the use of electronic fetal monitoring to reduce cesarean rates were included.43, 70, 74, 80, 99, 101 Two RCTs were conducted in the U.S.;80, 101 three are European studies conducted in Germany, France and Finland;43, 70, 99 and one was conducted in Australia.74 Three studies compared the use of fetal pulse oximetry with fetal heart monitors to the use of fetal heart monitors either alone or with fetal pulse oximetry that did not display the readings.74, 80, 101 One study compared the use of fetal pulse oximetry in additional to fetal heart monitoring and fetal scalp sampling to fetal heart monitoring and fetal scalp sampling alone.43 Two studies compared the use of fetal ST-segment analysis of fetal cardiotocography to cardiotocography either alone or with an additional monitoring device.70, 99 Of six studies, one was good quality80 with five being of fair quality (Appendices E and H).43, 74, 99, 101

#### Key Points

- Across these categories of fetal assessment strategies there is low strength of evidence for lack of benefit, from six studies including more than 9,700 women (Table 34).
- Three of the four studies looking at the use of fetal pulse oximetry demonstrated a significant reduction in cesarean performed for fetal distress; however, knowledge of intrapartum fetal oxygen saturation had no significant effect on overall use of cesarean.
- Fetal pulse oximetry did not slow or interfere with labor, nor did it result in an increase in adverse maternal, fetal, or neonatal outcomes.
- Use of fetal ST-segment analysis in conjunction with FHR monitoring did not reduce total cesareans or cesareans for nonreassuring fetal heart tracing when compared to routine FHR monitoring alone.

#### Detailed Synthesis

##### Fetal Pulse Oximetry

Three studies43, 74, 101 evaluated whether the addition of fetal pulse oximetry to FHR monitoring, fetal scalp sampling or both, would improve fetal assessment and reduce operative birth rates without increasing adverse outcomes for the women, the fetus or the newborn. These trials enrolled women who were at least 36 weeks gestation, with a singleton fetus in vertex presentation, in labor with ruptured membranes (or if not ruptured consented for artificial rupture), and nonreassuring FHR. The effectiveness of these strategies is presented in Table 19.

Table 19 Summary of effectiveness of cesarean reduction strategies: fetal pulse oximetry

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Kuhnert et al., 2004^43^ Germany; Fair | Fetal monitoring with CTG and fetal scalp blood sampling (73) | 37.0 | 20.6 lower
Kuhnert et al., 2004^43^ Germany; Fair | Fetal monitoring with CTG and fetal pulse oximetry and fetal scalp blood sampling (73) | 16.4 | 20.6 lower
East et al., 2006^74^ Australia; Fair | Fetal monitoring with CTG (295) | 48.1 | 2.2 same
East et al., 2006^74^ Australia; Fair | Fetal monitoring without CTG and fetal pulse oximetry (306) | 45.9 | 2.2 same
Bloom et al., 2006^80^ US; Good | Fetal pulse oximetry with oxygen saturation not displayed to clinician (2,712) | 27.5 | 1.2 same
Bloom et al., 2006^80^ US; Good | Fetal pulse oximetry with oxygen saturation displayed to clinician (2,629) | 26.3 | 1.2 same
Garite et al., 2000^101^ US; Fair | Fetal monitoring with CTG (502) | 26.0 | -3.0 same
Garite et al., 2000^101^ US; Fair | Fetal monitoring with CTG and fetal pulse oximetry (508) | 29.0 | -3.0 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

CTG=cardiotocography

The first study was a U.S. multicenter trial at nine centers.101 Patients gave consent for possible study inclusion but were only randomized once one of the pre-determined concerning FHR patterns developed while in labor. Included women also needed to be at least two centimeters dilated and at minus two station or lower in the pelvis. All randomized participants (n=1,010) underwent FHR monitoring with either Doppler or scalp electrode, or both.101 For patients in the intervention group a fetal oxygen sensor was placed against the fetal cheek and connected to a monitor. For women in the control group, only an electronic FHR monitor was used. For both groups the FHR was defined as reassuring, nonreassuring, or ominous. An ominous FHR pattern, defined as FHR persistently less than 70 beats per minute for at least seven minutes, required immediate birth in either group. The difference in management between the two groups occurred among the patients with nonreassuring FHR patterns. In the intervention group a fetus with a nonreassuring FHR tracing was considered to be normally oxygenated if the fetal oxygen saturation was greater than 30 percent at any time between two contractions. However, if the fetal oxygen saturation remained less than 30 percent for the entire interval between two contractions, the clinician reverted back to the FHR and used the same criteria as that used for the standard control group: if the FHR was persistently nonreassuring the clinician could rule out acidosis by examining spontaneous or induced FHR accelerations or scalp pH to rule out fetal acidosis. If reassurance could not be established, cesarean or operative vaginal birth was undertaken.101

Despite randomization, the intervention arm included more women with induced labors and use of prostaglandins for cervical ripening.101 There was a 50 percent relative reduction, in the number of cesareans performed for nonreassuring fetal status (intervention group 4.5% vs. 10.2% for controls) with no significant difference in overall cesarean use between the two groups (29% in the intervention group and 26% in the control group). An independent reviewer evaluated all electronic FHR tracings. The reviewer identified three cesarean births in each group done for nonreassuring fetal status in which there were protocol violations. There were no differences between the two groups in adverse maternal outcomes (including placental abruption, postpartum hemorrhage, wound infection, intrapartum fever, and endometritis).101 Neonatal outcomes were similar with five neonatal deaths, three in the intervention group and two in the control group.101 Four of the five deaths were caused by complex congenital heart anomalies. The fifth occurred in an infant from the intervention group whose five-minute Apgar score and umbilical cord pH were normal, yet postnatally developed bilateral tension pneumothoraces (Table 21).101

Table 21 Neonatal outcomes for fetal assessment strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5 Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0.1-3.8^70, 74, 80, 99, 101,a^ (5) | 1.5-14.7^70, 74, 80, 99, 101^ (5) | NR | 0-0.4^70, 80, 99, 101^ (4)
Fetal monitoring with CTG, fetal pulse oximetry and fetal blood sampling43 | NR | NR | NR | NR
Fetal monitoring with CTG and fetal pulse oximetry74, 101 | 1.6-16.7 (2) | 3.0-18.1 (2) | NR | 0.6^101^
Fetal pulse oximetry with oxygen saturation displayed to clinician80 | 0.2^a^ | 4.8 | NR | 0
Fetal monitoring with CTG and STAN70 | 1.5 | 1.3 | NR | 0
Fetal monitoring with STAN99 | 1.3 | 3.6 | NR | 0

NICU=neonatal intensive care unit; CTG=cardiotocography; STAN=ST analysis; NR=not reported;

a Percent with Apgar < 4 at 5 min

In a German trial,43 146 patients were recruited with nonreassuring FHR patterns (defined by International Federation of Gynaecology and Obstetrics [FIGO] score less than 8).129 Women in the study also needed to be at least two centimeters dilated and at minus two station or lower in the pelvis. They were randomized to two groups: triple fetal surveillance with a FHR monitor, fetal scalp sampling, and fetal pulse oximetry (n=73) or a control group in which women received only FHR monitoring and fetal scalp sampling (n=73).43 After randomization, management of labor varied by group. In the intervention group, if cardiotocography (CTG) was nonreassuring, fetal blood sample (FBS) pH was greater than 7.25, and fetal pulse oximetry was greater than 30 percent, they continued CTG and fetal pulse oximetry and attempted vaginal birth. If the CTG was nonreassuring and the fetal blood sample pH was greater than 7.25, but the fetal pulse oximetry was less than 30 percent, they still continued CTG and fetal pulse oximetry; however, a followup fetal scalp sampling was performed. If that repeat scalp sampling pH was less than or equal to 7.25, clinical intervention was necessary (either tocolysis for intrauterine resuscitation, cesarean, or assisted vaginal birth). In the control group, if CTG was non-reassuring and fetal scalp blood sample pH was greater than 7.25, they continued CTG and attempted vaginal birth. If the fetal blood sample pH was less than or equal to 7.25 clinical intervention was necessary. In either group if CTG was ever found to be pathologic, patients were delivered immediately.43

There was no difference between the two groups in incidence of nonreassuring FHR patterns in the first and second stages of labor.43 The first scalp pH sampling for baseline assessment in the two groups was also similar. The proportion of cesareans was significantly lower in the intervention group than in the control group (16.4% vs. 37%), and the proportion of operative vaginal births for nonreassuring fetal status was also significantly lower in the intervention versus control group (17.8% vs. 30.1%) demonstrating almost a 50 percent reduction in the risk of operative births for nonreassuring fetal status. There were no adverse maternal or neonatal events in either group (Tables 20 and 21).43

Table 20 Maternal outcomes for fetal assessment strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 8.0-29.8^74, 101^ (2) | 10.7^80,a^ | 3.2^101^ | NR
Fetal monitoring with CTG, fetal pulse oximetry and fetal blood sampling43 | NR | NR | NR | NR
Fetal monitoring with CTG and fetal pulse oximetry74, 101 | 9.0-30.8^74, 101^ | NR | 3.0^101^ | NR
Fetal pulse oximetry with oxygen saturation displayed to clinician80 | NR | 10.7^a^ | NR | NR
Fetal monitoring with CTG and STAN70 | NR | NR | NR | NR
Fetal monitoring with STAN99 | NR | NR | NR | NR

CTG=cardiotocography; STAN=ST analysis; NR=not reported;

a Reported chorioamnionitis

The third trial, called the FOREMOST trial, was conducted in four Australian academic hospitals.74 Six-hundred and one women with nonreassuring fetal monitoring were randomly assigned to a group with fetal pulse oximetry with CTG or a control group monitored using conventional CTG alone.74 Monitoring continued from the time a sensor was placed until as close to birth as possible. In either group, if the CTG became reassuring, labor was continued unless otherwise indicated. In both groups, ominous FHR patterns prompted birth. In the control group, a nonreassuring CTG prompted evaluation and management of the FHR pattern. In the intervention group, if oxygen saturation levels were less than 30 percent for 10 minutes or not recording, evaluation and management of FHR pattern was recommended. Evaluation and management could include maternal position change, supplemental oxygen, hydration, correction of hypotension, discontinuation of oxytocin infusion, or birth. Fetal blood scalp sampling was available to all without restriction and the study did not regulate management based on fetal scalp pH or lactate values.74

The primary outcome measured was operative birth (cesarean, forceps, vacuum) for nonreassuring fetal status.74 This study reported a significant reduction in operative births for nonreassuring fetal status in the intervention group compared to those in the control group (24.9% vs. 32.2%; RR=0.77, 95% CI: 0.599, 0.999; p=0.048). Cesareans for nonreassuring fetal status represented 13.8 percent of intervention group and 20 percent of control group births (RR=0.69, 95% CI: 0.48, 0.99; p=0.042).74 However, the overall rate of operative births between the two groups did not differ (intervention group 73% vs. control group 71%; RR=0.77, 95% CI: 0.599, 0.999; p=0.48). Women in the intervention group were more likely to have an operative birth secondary to dystocia than those in the control group. This difference in indication was significant for assisted vaginal birth, not for cesareans. Fetal scalp blood sampling was performed more often in the control group. There were four cases of endometritis in the intervention group and one in the control group (p=0.192). Postpartum maternal fever was similar between the groups (p=0.792) (Table 20). There was also no difference in neonatal outcomes (Apgar score, cord pH/fetal acidosis, NICU admission), or serious adverse events (Table 21).74

The fourth study was conducted by the National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network.80 This RCT enrolled women at 14 academic centers to test whether fetal oximetry in addition to conventional EFM would reduce the overall use of cesarean. The study was launched after a rigorous training phase with the oximetry equipment. During the study, all women recruited underwent placement of fetal pulse oximeter after placement of a standard internal electronic FHR monitor and intrauterine pressure catheter.80 If the oximeter was not placed within three attempts or if a signal registration was not accomplished by 15 minutes the attempt was considered unsuccessful, and the patient was not randomization. One hundred seventy women had failed attempts at sensor placement and 42 other attempts were abandoned secondary to prolonged FHR decelerations during placement. Ultimately, 5,341 women were randomly assigned to open fetal oximetry in addition to conventional electronic fetal monitoring or to masked fetal oximetry with conventional electronic fetal monitoring.80

Nonreassuring FHR patterns were defined according to the criteria used by Garite.101 Intrapartum management in both groups was otherwise left to the discretion of the attending physician.80 Fetal pulse oximeter sensors were removed before study completion in 238 women in the intervention group and 267 women in the masked group (reasons: patient request, n=244; physician request, n=196; technical problems, n=65). Discomfort accounted for 92 percent of patient requests for sensor removal and interference with cervical examination or management of labor for 67 percent of physician requests.80

Cesarean births did not differ between the oximetry and masked groups (26.3 and 27.5%; p=0.31).80 Cesarean births for nonreassuring FHR (7.1 and 7.9%; p=0.30) and dystocia (18.6 and 19.2%; p=0.76) were also similar. Results were similar in the subgroup (n=2,168) of women in whom a nonreassuring FHR was detected prior to randomization as well as those with normal baseline FHR. Maternal and neonatal outcomes did not differ significantly between groups (Tables 20 and 21). One neonatal death occurred due to sepsis in the masked group.80

##### Fetal ST-Segment Analysis Studies

Two RCTs assessed ST-segment analysis (STAN) to provide additional information.70, 99 The effectiveness of these strategies is presented in Table 22 below.

Table 22 Summary of effectiveness of fetal assessment cesarean reduction strategies: fetal STAN

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Vayssiere et al., 2007^70^ France; Fair | Fetal monitoring with CTG (400) | 16.3 | 2.8 same
Vayssiere et al., 2007^70^ France; Fair | Fetal monitoring with CTG and STAN (399) | 13.5 | 2.8 same
Ojala et al., 2006^99^ Finland; Fair | Fetal monitoring with CTG (739) | 4.7 | -1.7 same
Ojala et al., 2006^99^ Finland; Fair | Fetal monitoring with STAN (733) | 6.4 | -1.7 same

a Same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

CTG=cardiotocography; STAN=ST analysis

A study at an academic institution in Finland examined whether intrapartum monitoring with STAN could reduce the rate of neonatal acidemia and operative intervention during labor.99 A total of 1,483 women were randomly assigned to the intervention group, with monitoring by STAN through a scalp electrode, or the control group with monitoring by a conventional FHR monitor either via an internal intrauterine scalp electrode or an external ultrasound signal sensor.99 Fetal blood sampling was optional in both groups, based on clinician judgment. If scalp pH was less than 7.20, immediate birth was recommended. Primary outcome measures were neonatal acidemia (defined as umbilical artery pH less than 7.10), operative interventions (cesarean and vacuum birth), and need for fetal blood sampling.99

An umbilical artery blood gas was available for 714 neonates in the intervention group and 722 in the control group.99 There were 83 cases of inadequate monitoring, five in the control group (secondary to technical difficulties) and 78 in the intervention group. Failure in the intervention group was attributed to: monitoring stopped more than 20 minutes before birth (n=25), poor signal quality (n=21), technical difficulties with scalp electrode (n=19), total recording time less than 20 minutes (n=7) and one case of unsuccessful recording. In the control group, 83 percent used an internal scalp electrode for monitoring, and 17 percent used an external ultrasound sensor. Overall cesarean rate did not differ between the two groups (6.4% intervention vs. 4.7% control; p=0.24).99 Fetal blood sampling was used less in the intervention group compared to the control group (7% vs. 15.6%; p<0.001). When evaluating fetal pH using values less than 7.10 as a criterion of neonatal acidemia, there were no differences between the groups. There were no maternal complications related to the STAN, electronic fetal monitor or fetal blood sampling (Table 20). Neonatal outcomes did not differ between groups with no difference in neonatal acidemia, Apgar scores, need for intubation, or admission to the NICU (Table 21). There were no neonatal deaths.99

In the second study,70 a multicenter trial in France, the authors sought to assess whether STAN reduced operative births for nonreassuring fetal status or reduced need for at least one scalp pH during labor. The study population included participants who either had an abnormal FHR pattern (by FIGO classification) or thick meconium stained amniotic fluid during labor. After rupture of membranes, 799 women were randomized to intervention with both STAN and an electronic fetal monitor for CTG to monitor fetal status in labor or to the control group with only an electronic fetal monitor for CTG to monitor fetal status.70 In the STAN group, fetuses were monitored continuously through a scalp electrode and recommendations were based on STAN guidelines. Scalp pH testing was optional in both groups. If scalp blood pH was less than 7.20, immediate birth was recommended. As soon as possible after birth, umbilical cord artery and vein gases were obtained and analyzed.

The proportion of operative births for nonreassuring fetal status did not differ between the two groups (33.6% for the study group vs. 37% for the control group; RR=0.91, 95% CI: 0.75, 1.10).70 Use of operative interventions for dystocia also did not differ between groups. The percentage of women whose fetus had at least one blood scalp pH measurement during labor was substantially lower in the intervention group (27% compared with 62% in the control group; RR=0.44, 95% CI: 0.36, 0.52). Neonatal outcomes did not differ between groups (acidosis, Apgar score, and NICU admission), with one fetal death in the CTG only group (Table 21).70

### Amnioinfusion

Amnioinfusion (AI) refers to instilling fluid (lactated ringers solution or normal saline) into the amniotic cavity. This procedure is typically performed during labor through a catheter introduced transcervically after rupture of fetal membranes. A nasogastric feeding tube can also be used if an intrauterine pressure catheter is not available.44

Severe reduction of amniotic fluid (oligohydramnios) can increase the risk of a number of pregnancy complications, including FHR deceleration, cord compression during labor, fetal hypoxia and acidosis. Variable FHR decelerations are the most common type, seen in 50 to 80 percent of labors.98 Recurrent variable decelerations have been shown to be due to cord compression in labor in women with oligohydramnios.130 Oligohydramnios can be present before rupture of membranes or more commonly occurs in labor after rupture of membranes. Variable decelerations are common and may accompany each contraction. They are not specifically indicative of distress and are interpreted in the larger context of monitoring patterns; however, when severe or if they remain persistent, they may be associated with fetal compromise as a result of hypoxia and acidemia.131 As a result, severe variable decelerations when recurrent are often nonreassuring and can lead to increased risk of instrumented and cesarean births. Amnioinfusion has been shown to be a simple, inexpensive, effective, and safe method for the relief of significant heart rate abnormalities during prolonged labor with oligohydramnios and has been associated with decreased use of cesarean but debate continues.44, 132

#### Overview of the Literature

We identified eight RCTs addressing use of amnioinfusion to reduce cesarean birth rates.39, 44-45, 57, 59, 69, 81, 98 Three were conducted in India,39, 45, 98 two were conducted in South Africa,57, 69 one in Zimbabwe,69 one in Egypt,44 and one in the United States.59 Four were found to be of fair quality44-45, 59, 69 with the remaining four being of poor quality (Appendices E and H).39, 57, 81, 98

All eight studies compared the use of transcervical amnioinfusion to the use of standard obstetric care without amnioinfusion. Five studies evaluated amnioinfusion in the context of moderate to heavy meconium stained amniotic fluid,39, 45, 57, 69, 81 two studies evaluated use of amnioinfusion in the context of nonreassuring FHR tracings,44, 98 and one evaluated use of prophylactic amnioinfusion in the context of oligohydramnios.59

Although all studies used either warmed or room temperature normal saline, the amnioinfusion protocols varied. In five studies39, 44-45, 69, 98 500 ml of normal saline was initially infused over 30 minutes, followed by slow infusions up to either 1 liter total volume44-45, 69 or until birth.39, 98 Three studies infused normal saline at 15 ml per minute either to a volume of 1 liter,57 800 ml followed by a slower infusion until birth,81 or 250 ml to attain an amniotic fluid index greater than or equal to 8 centimeters.59

#### Key Points

- Studies of amnioinfusion did not find consistent overall decrease in use of cesarean. The strength of evidence is insufficient to support use to prevent cesarean (Table 34).
- Amnioinfusion did not consistently lead to a reduction in overall cesarean rates. When performed for concerning fetal heart tracings, four of eight studies reported a significant reduction in cesareans performed for fetal distress.39, 44-45, 98
- Amnioinfusion for moderate or heavy meconium when performed in under-resourced hospital settings where electronic monitoring was limited or absent, improved neonatal outcomes.
- Prophylactic amnioinfusion for oligohydramnios did not reduce use of cesarean.

#### Detailed Synthesis

Five RCTs39, 45, 57, 69, 81 evaluated the effect of transcervical amnioinfusion during labor complicated by the presence of moderate or heavy meconium. The effectiveness of these strategies is presented in Table 23.

Table 23 Summary of effectiveness of cesarean reduction strategies: amnioinfusion for meconium

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Choudhary et al., 2010^39^ India; Poor | Standard obstetric care without amnioinfusion (146) | 63.7 | 34.2 lower
Choudhary et al., 2010^39^ India; Poor | Transcervical amnioinfusion (146) | 29.5 | 34.2 lower
Rathor et al., 2002^45^ India; Fair | Standard obstetric care without amnioinfusion (100) | 36.0 | 15.0 lower
Rathor et al., 2002^45^ India; Fair | Transcervical amnioinfusion (100) | 21.0 | 15.0 lower
Moodley et al., 1998^57^ South Africa; Poor | Standard obstetric care without amnioinfusion (30) | 47.0 | 7.0 same
Moodley et al., 1998^57^ South Africa; Poor | Transcervical amnioinfusion (30) | 40.0 | 7.0 same
Mahomed et al., 1998^69^ Zimbabwe; Fair | Standard obstetric care without amnioinfusion (336) | 11.3^b^ | 1.8 same
Mahomed et al., 1998^69^ Zimbabwe; Fair | Transcervical amnioinfusion (325) | 9.5 | 1.8 same
Hofmeyr et al.,1998^81^ South Africa; Poor | Standard obstetric care without amnioinfusion (176) | 43.0 | 1.0 same
Hofmeyr et al.,1998^81^ South Africa; Poor | Transcervical amnioinfusion (176) | 42.0 | 1.0 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

b Reported as 12.3 in text, but should be 11.3 based on data presented in paper.

The first two39, 45 were conducted in teaching hospitals in India with women at term who had moderate or thick meconium during labor. In both of these studies in under-resourced areas labors were not monitored continuously by electronic fetal monitors, but instead intermittently (approximately every 15 minutes) via auscultation for FHR, and contractions were assessed every 30 minutes by palpation, evaluating the uterine tone, intensity, frequency, and duration of contractions. Choudhary et al.39 enrolled 292 participants who were randomly assigned to the intervention group and received transcervical amnioinfusion or the control group and received standard labor management. Cesareans were performed if there were FHR abnormalities defined as bradycardia or severe irregularity for 10 to 20 minutes, or if there was a slow progression of labor.

This study reported a significant reduction in the incidence of cesarean birth rates in the amnioinfusion group compared to the control group (29.5% vs. 63.7% cesarean births) with a significantly higher rate of normal vaginal birth in the intervention group compared to the control group (70.5% vs. 31.5%).39 Maternal fever was lower in the intervention group than in the control group, but the difference was not significant (p=0.238) (Table 24). Amnioinfusion during labor was not associated with any significant maternal complications.

Table 24 Maternal outcomes for amnioinfusion strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | 0-12^39, 44-45, 59, 69, 81, 98^ (7) | 0^98^ | NR | NR
Transcervical amnioinfusion39, 44-45, 57, 59, 69, 81, 98 | 0.9-20^39, 44-45, 59, 69, 81, 98^ (7) | 0^98^ | NR | NR

NR=not reported

Amnioinfusion was associated with improved neonatal outcomes as evidenced by the incidence of respiratory distress in the newborn infants, which was greatly reduced by amnioinfusion in the study versus control group (2.7% vs. 23.3%; p=0.000).39 Meconium aspiration syndrome was also markedly reduced by amnioinfusion with 0.68 percent incidence in the intervention group compared to 15.8 percent in the control group (p=0.000). Neonatal mortality was much higher at 10.9 percent in the control group compared to 1.4 percent in the intervention group (p=0.010). Amnioinfusion improved the Apgar score at both one and five minutes in newborns in the study group versus the control group (10.3% vs. 30.8% and 0.7% vs. 8.2%; p=0.000). Amnioinfusion was not associated with increasing any significant neonatal complications (Table 25).39

Table 25 Neonatal outcomes for amnioinfusion to reduce cesarean births

Strategy | Apgar Score <7 at 5-Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0-13.2^39, 44-45, 59, 69, 81, 98^ (7)^a^ | 2.5-22.9^44-45, 69, 81^ (4) | 3.0%^69,b^ | 0-11^39, 44-45, 57, 69, 81^ (6)
Transcervical amnioinfusion39, 44-45, 57, 59, 69, 81, 98 | 0-4.1^39, 44-45, 59, 69, 81, 98^ (7)^a^ | 1.8-12.8^44-45, 69, 81^ (4) | 1.6%^69,b^ | 0-2^39, 44-45, 57, 69, 81^ (6)

NICU=neonatal intensive care unit; NR=not reported

a Reported mean Apgar at 5 minutes ± SD--Intervention: 9.57 ± 0.67; Control: 9.33 ± 1.03^57^

b Reported percent in NICU more than 4 days

In the second study, Rathor and colleagues45 enrolled 200 women in labor, who were randomized to either an amnioinfusion or control group. The authors reported cesarean was significantly less frequent in the amnioinfusion group compared to the control group (21% vs. 36%) with cesarean for fetal distress also reduced to 12 percent in the amnioinfusion group compared to 26 percent in the control group.45 Five percent of infants were born by forceps in the amnioinfusion group versus 14 percent in the control group. The incidence of maternal fever was lower in the amnioinfusion group compared to the control group, but the difference was not significant (Table 24).45 Seven neonatal deaths occurred: two in the amnioinfusion group and five in the control group. Amnioinfusion was associated with a significant improvement in one-minute Apgar scores and fewer admissions to the NICU compared to the control group (Table 25).45

The last two RCTs81 were from different sites of the same trial, the Collaborative Randomized Amnioinfusion for Meconium Project (CRAMP) in South Africa and Zimbabwe. The sample size calculation for the multicenter study was based on an expected incidence of meconium aspiration of 10 percent of the control group. After initiation of the study it became clear that the South African centers had lower incidence of MAS than those used to estimate sample size in Zimbabwe. Therefore the two sites, South Africa (CRAMP 1) and Zimbabwe (CRAMP 2) reported findings separately.69, 81

The South African site (CRAMP 1)81 evaluated 176 women randomized to the amnioinfusion group and a control group of 176 who received standard obstetric care. All women allocated to the intervention group received amnioinfusion. One woman in the control group also received an amnioinfusion but was retained in the control group for intention-to-treat analysis. The care differed in this portion of the study (compared to Zimbabwe) in that electronic fetal monitoring and intrauterine pressure monitoring were available and used in most cases. Cesarean risk was similar with 42 percent in the amnioinfusion group and 43 percent in the control group having cesarean births (RR=0.98, 95% CI: 0.76, 1.26).81 There was no significant difference in assisted vaginal births (RR=0.72, 95% CI: 0.31, 1.67), nor was there significant difference in the incidence of maternal fever (RR=1.23, 95% CI: 0.65, 2.33).81 The study did not report maternal deaths. Overall incidence of meconium aspiration syndrome was much lower than expected, with no significant difference between the two groups (0.02% in the amnioinfusion group vs. 0.03% in the control; RR=0.67, 95% CI: 0.19, 2.33). There were no perinatal deaths and no significant differences in five-minute Apgar scores less than 7 (RR=1.49, 95% CI: 0.43, 5.18) or NICU admissions (RR=0.75, 95% CI: 0.17, 3.28) (Table 25).81

Of 661 women enrolled in the Zimbabwe study (CRAMP 2),69 325 were randomly assigned to amnioinfusion and 336 were assigned to standard obstetric care. No electronic FHR monitors were used in this study, instead patients were auscultated and occasionally a handheld ultrasound detector was used to assess FHR. In this setting the midwives were aware of the need for suctioning of the airway of infants born with meconium but were usually unable to do so because of lack of equipment. Also, the pediatrician was never present at the birth, only being called after birth when there was a problem. The primary outcomes were cesarean, meconium aspiration syndrome, and perinatal death.69 Use of cesarean did not differ between groups (9.5% in the intervention group compared to 12.3% in the control; RR=0.84, 95% CI: 0.53, 1.32), nor were there significant differences in the rate of cesarean births secondary to fetal distress (RR=0.61, 95% CI: 0.24, 1.52).69 MAS was significantly less frequent in the amnioinfusion group (3.1% vs. 12.8% in the control; RR=0.24, 95% CI: 0.12, 0.48). Perinatal morbidity was reduced in the amnioinfusion group in regards to the need for neonatal ventilation (RR=0.31, 95% CI: 0.15, 0.61).69 There were four neonatal deaths in the amnioinfusion group (1.2%) and twelve in the control group (3.6%), which was not significant (RR=0.34, 95% CI: 0.11, 1.06). There were significant reductions in five-minute Apgar scores less than seven (RR=0.35, 95% CI: 0.17, 0.73) as well as NICU admissions (RR=0.56, 95% CI: 0.39, 0.79). No complications of amnioinfusion were detected (Table 25).69

In the fifth study, a separate study from South Africa, 60 patients were randomized into two groups, either amnioinfusion or standard obstetric care.57 Only those in the active phase of labor, with meconium stained amniotic fluid, and a normal electronic fetal monitor recording were allowed to participate. Sixty-five percent of the participants were primigravidas. A total of 12 patients (40%) in the amnioinfusion group gave birth by cesarean, compared to 14 (47%) in the control group.57 Of these, three (10%) in the study group and seven patients (23%) in the control group had cesareans for fetal distress; the remainder in both groups had a cesarean for dystocia. These differences were not statistically significant. There were no maternal complications related to the amnioinfusion. Fewer infants in the study group developed hypoxic-ischemic encephalopathy (HIE) (zero vs. two controls) or MAS (one vs. four controls), neither statistically significant. There were no neonatal deaths (Table 25).57

Two additional RCTs44, 98 conducted in academic hospitals evaluated the use of amnioinfusion in cases of intrapartum fetal distress as noted by moderate or severely abnormal FHR patterns, to reduce need for cesarean (Table 26).

Table 26 Summary of effectiveness of cesarean reduction strategies: amnioinfusion for fetal distress

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Abdel-Aleem et al., 2005^44^ Egypt; Fair | Standard obstetric care without amnioinfusion (219) | 68.0 | 20.1 lower
Abdel-Aleem et al., 2005^44^ Egypt; Fair | Transcervical amnioinfusion (219) | 47.9 | 20.1 lower
Regi et al., 2009^98^ India; Poor | Standard obstetric care without amnioinfusion (75) | 37.3 | -1.1 same
Regi et al., 2009^98^ India; Poor | Transcervical amnioinfusion (75) | 38.4 | -1.1 same

a Lower indicates a lower rate supported by statistical significance; same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

In a study in Egypt at a university hospital,44 women with nonreassuring or ominous FHR tracings were approached for enrollment as long as immediate birth was not contemplated and 438 were randomized. The intervention group received amnioinfusion in addition to conventional treatment, and the control group received standard obstetrical care without amnioinfusion.44 If the FHR pattern did not become reassuring after the first 200 ml of amnioinfusion, a cesarean was performed. However, if the FHR pattern corrected, the infusion was completed and the FHR monitoring continued until birth of infant. Women in the amnioinfusion group also received 1 g of amoxicillin IV for infection prophylaxis prior to the procedure. Amnioinfusion was completed in all but five women. These women were included in the amnioinfusion group for the intent-to-treat analysis.44

The amnioinfusion group had a significant reduction in use of cesarean for fetal distress compared to the control group (47.9% vs. 68%, respectively; RR=0.7, 95% CI: 0.60, 0.83).44 This study also reported a reduction in nonreassuring and ominous FHR patterns in the amnioinfusion group compared to the control group (47.9% vs. 68%, respectively, RR=0.7, 95% CI: 0.60, 0.83). Incidence of uterine hypertonicity and maternal pyrexia did not differ by group. Significantly fewer newborns had Apgar scores less than seven at one (RR=0.38, 95% CI: 0.26, 0.55) and five (RR=0.31, 95% CI: 0.15, 0.64) minutes in the amnioinfusion group compared to the control group (Table 25).44 Also, 14 newborns in the amnioinfusion group were admitted to the NICU, compared to 31 newborns in the control group (RR=0.45, 95% CI: 0.25, 0.83). All newborns in the amnioinfusion group were discharged alive without complication, whereas three newborns in the control group had meconium aspiration syndrome and one died (Table 25).44

An Indian study enrolled 150 women in active labor with repetitive moderate or severe decelerations.98 Women were randomized to amnioinfusion or standard obstetrical care with no amnioinfusion. Cesarean or operative vaginal birth was performed if there was evidence of nonreassuring fetal status. Two women from the amnioinfusion group were excluded, one because the catheter could not be placed, and the other woman gave birth before the amnioinfusion could be started. Most participants (70.9%) were nulliparous. Cesarean risk did not differ between the intervention and control groups (38% vs. 37.3%, respectively).98 Cesareans for fetal distress were less common in the amnioinfusion group (20%) compared to the control group (32%; p=0.009). Variable decelerations fully resolved in 79.5 percent of the amnioinfusion group (p=0.001). There were two cases of maternal fever in the amnioinfusion group; however, this was not significant (Table 24).98 No other adverse maternal outcomes were reported. Birth asphyxia, Apgar scores at one or five minutes, and NICU admission did not differ between the two groups (Table 25).98

In the final study by Strong and colleagues, prophylactic amnioinfusion was performed in the setting of oligohydramnios (amniotic fluid index less than or equal to five) to assess impact on cesarean.59 Women were randomized into two groups: prophylactic amnioinfusion (n=30) and a control group (n=30) who received standard obstetric care without amnioinfusion. Overall risk of cesarean was lower in the amnioinfusion group at 13.3 percent compared to 20 percent in the control group, but not significantly.59 Cesareans performed for fetal distress were similar. There was no difference in rate of forceps births between groups. Maternal fever occurred in 20 percent of the amnioinfusion group compared to seven percent of the control group, but was not statistically significant (Table 24).59 There were no differences in Apgar scores at one or five minutes between the two groups (Table 25).59

### Unique Strategies

#### Overview of the Literature

We identified seven RCTs that explored the effects of various other unique interventions on the incidence of cesarean birth, including two studies examining traditional Chinese medicine acupuncture,53, 105 two assessing devices,55, 100 one assessing the effect of propranolol administration every four hours during labor,60 and two on the role of activities such as walking75 or eating92 during labor. Four of these studies were conducted in the United States,53, 55, 75, 105 two in the United Kingdom,92, 100 and one in Puerto Rico.60 Five studies were completed in academic health sciences centers53, 55, 60, 75, 105 and two were conducted in a non-academic hospital setting.92, 100 All studies employed a usual care comparison group; one study105 also included a sham procedure comparison. Two were good quality,92, 100 two were fair quality,53, 105 and the remaining three were poor quality (Appendices E and H).55, 60, 75

#### Key Points

- As single studies of unique strategies this literature provides insufficient evidence to guide care (Table 34).
- Large single studies of walking, eating, or using an inflatable obstetric belt during labor showed no effect on the incidence of cesarean birth as compared with usual care.
- Small studies of other interventions such as acupuncture, a molded dental device, or propranolol showed no effect of intervention on rates of cesarean birth when compared with standard care approaches.

#### Detailed Synthesis

We identified seven studies evaluating the effect of unique strategies to reduce cesarean births.53, 55, 60, 75, 92, 100, 105 The effectiveness of these strategies is presented in Table 27 below.

Table 27 Summary of effectiveness of cesarean reduction strategies: unique strategies

Author, Year Country; Quality | Strategy (n) | Cesarean Birth, % | Change in Cesarean, %^a^
Harper et al., 2006^53^ US; Fair | Usual care (26) | 39.0 | 22.0 same
Harper et al., 2006^53^ US; Fair | Acupuncture sessions (30) | 17.0 | 22.0 same
Matsuo et al., 2009^55^ US; Poor | Usual care (32) | 25.0 | 12.5 same
Matsuo et al., 2009^55^ US; Poor | Dental support device during active pushing (32) | 12.5 | 12.5 same
Adamsons et al., 1999^60^ Puerto Rico; Poor | Usual care (23) | 17.4 | 5.7 same
Adamsons et al., 1999^60^ Puerto Rico; Poor | Propranolol during labor (34) | 11.7 | 5.7 same
Bloom et al., 1998^75^ US; Poor | Usual care (531) | 6.0 | 2.0 same
Bloom et al., 1998^75^ US; Poor | Walking during 1^st^ stage of labor (536) | 4.0 | 2.0 same
O'Sullivan et al., 2009^92^ UK; Good | Usual care (1,216) | 30.0 | 0 same
O'Sullivan et al., 2009^92^ UK; Good | Allowed to eat during labor (1,227) | 30.0 | 0 same
Cox et al., 1999^100^ UK; Good | Usual care (240) | 3.8 | -2.0 same
Cox et al., 1999^100^ UK; Good | Inflatable obstetric belt (260) | 5.8 | -2.0 same
Asher et al., 2009^105^ US; Fair | Acupuncture (30) | 20.0 | -10.0 3.0 same
Asher et al., 2009^105^ US; Fair | Usual care (no acupuncture) (30) | 10.0 | -10.0 3.0 same
Asher et al., 2009^105^ US; Fair | Sham acupuncture (29) | 7.0 | -10.0 3.0 same

a Same indicates the use of cesarean was not statistically different across the strategy and comparison arms of the trial.

##### Acupuncture

Two RCTs from the same institution evaluated the use of traditional Chinese medicine acupuncture to initiate labor, with secondary objectives including reducing the rate of cesarean.53, 105 In the first trial,53 30 women were randomized to receive acupuncture on three of four consecutive days for initiation of labor, with 26 women randomized to usual care. The incidence of cesarean was 17 percent in the intervention group and 39 percent among control patients (p=0.07). In the second trial,105 participants were randomized to up to five acupuncture treatments over two weeks (n=20), sham acupuncture (n=29), or usual care (n=30). The cesarean rate was 20 percent in the acupuncture group as compared with 57 percent in the usual care group; however, the sham treatment had the lowest incidence of cesarean, at 7 percent (p=0.37 for comparison across the three groups). Both studies found similar maternal and neonatal outcomes for intervention as compared with control participants (Tables 28 and 29).

Table 28 Maternal outcomes for unique strategies to reduce cesarean births

Strategy | Fever, % (n Studies) | Infection, % (n Studies) | Hemorrhage, % (n Studies) | Mortality, % (n Studies)
Control | NR | 7-8^75, 105^ (2) | 0-3.3^60, 100, 105^ (3) | 0.08^92^
Acupuncture53, 105 | NR | 23^105^ | 10^105^ | NR
Sham acupuncture105 | NR | 21 | 7 | NR
Propranolol60 | NR | NR | 0 | NR
Inflatable obstetrical belt100 | NR | NR | 1.2 | NR
Dental support device during pushing55 | NR | NR | NR | NR
Walking during first stage labor75 | NR | 8 | NR | NR
Allowed to eat during labor92 | NR | NR | NR | 0

NR=not reported

Table 29 Neonatal outcomes for unique strategies to reduce cesarean births

Strategy | Apgar Score <7 at 5-Min, % (n Studies) | NICU Admission, % (n Studies) | NICU Days, Mean ± SD (n Studies) | Mortality, % (n Studies)
Control | 0-1.8^75, 92^ 9.0 ± 0.2^105,a^ 9.0^92,b^ (4) | 3.3-9.4^55, 92, 105^ (3) | 1.9 ± 0.5^105^ | 0^75, 100^ (2)
Acupuncture53, 105 | 8.8 ± 0.8^105,a^ | 0^105^ | 2.1 ± 0.5^105^ | NR
Sham acupuncture105 | 8.9 ± 0.4^a^ | 0 | 2.0 ± 0.6^105^ | NR
Propranolol60 | NR | NR | NR | NR
Inflatable obstetrical belt100 | NR | NR | NR | 0
Dental support device during pushing55 | 9^b^ | 9.4 | NR | NR
Walking during first stage labor75 | 0 | NR | NR | 0
Allowed to eat during labor92 | 1.3^c^ | 5.0 | NR | NR

NICU=neonatal intensive care unit; NR=not reported

a Reported mean Apgar at 5 minutes ± SD

b Reported median Apgar at 5 minutes

c Reported Apgar ≤ 7 at 5 minutes

##### Devices

Two trials evaluated the utility of devices for reducing use of cesarean. The larger of these studies100 randomized women to use of an inflatable obstetric belt to provide fundal pressure during contractions (n=260) or to usual care (n=240), finding a similar incidence of cesarean between the groups (5.8 and 3.8% respectively; p=0.29). There were fewer malpositions at birth in the belt group as compared with usual care (15% vs. 20.8%) but the difference was not statistically significant. Other neonatal and maternal outcomes were similar between the two groups (Tables 28 and 29).

Matsuo and colleagues55 assessed whether the use of a molded dental device during active pushing (n=32) had an effect on cesarean as compared with usual care (n=32). The device was designed to optimize dental occlusion, based on evidence indicating this may improve isometric muscle strength.133 The observed incidence of cesarean was 12.5 percent in the intervention group as compared with 25.0 percent in patients treated per usual care (no test of statistical significance reported).

##### Medical Interventions

One small RCT 60 found a modest, insignificant effect of a single intravenous 2 mg dose of propranolol at admission for beta-adrenergic blockage and prevention of dysfunctional labor (n=34), with 11 percent of intervention participants having a cesarean compared with 17.6 percent those receiving usual care (p=0.367). Duration of the first stage of labor was similar between the two groups, while second stage duration was significantly longer in the medication group as compared with usual care (median 31 vs. 19 minutes; p<0.001). Neonatal and other outcomes were similar between the two groups (Tables 28 and 29).

##### Activities

Two RCTs assessed whether simple changes in activities during labor may influence risk of cesarean. A large RCT of walking during the first stage of labor (n=536) found similar use of cesarean as compared with patients who were restricted to bed (n=531), 4 percent and 6 percent respectively (p=0.25).75 Investigators noted that 22 percent of women randomized to walk did not elect to walk. Duration of labor and other maternal and infant outcomes were similar between the walking and usual care groups (Tables 28 and 29).

Another large RCT assessed the incidence of cesarean among women encouraged to eat a light diet during labor (n=1,227) as compared with those limited to water and ice consumption (n=1,216). This trial also found similar incidence of cesarean in both groups (30% in each).92 In terms of adherence to the intervention, 29 percent of those randomized to the eating group chose not to eat, while 20 percent of those randomized to usual care with restricted intake elected to eat during labor. The overall incidence of vomiting was similar between those randomized to eating as compared with those limited to water consumption; no cases of pulmonary aspiration were observed in either group (Tables 28 and 29).

### Systems-Level Strategies

#### Overview of the Literature

We classified research as systems-level strategies when an entire administrative unit within a health system was responsible for implementing policies or procedures that were aimed at reducing cesarean birth rates. The level from which strategies were launched ranged from a national health ministry and multi-hospital quality improvement teams, to individual departments' decisions about labor and delivery routines. Strategies included varied scopes of influence from a national media focus on publically released cesarean birth rates for all hospitals in South Korea, to introduction of a new computerized system to analyze progress of labor in a single facility. Common strategies included audit and feedback of hospital and physician data about cesarean trends, and implementation of guidelines or standardized protocols for particular procedures such as management of vaginal breech births.

We identified a total of 31 studies with 33 publications that were designed to investigate the effectiveness of one or more systems-level strategies for reducing use of cesarean birth.78, 85, 89, 94, 134-162 Multiple publications from the same study were instances in which authors extended the length of followup. Because systems-level randomized trials are rare, we elected during design of this review that system-level strategies would be the only portion of the systematic review to include studies that are not randomized. Twenty-seven studies compared a baseline period with subsequent trends in cesarean after implementation of the strategy(ies) intended to decrease rates of cesarean.134-144, 146-148, 150-162 For brevity in tables and text we have called these pre-post assessments. There were seven unique pre-post studies of good quality137, 140, 142-144, 150, 157 and 22 of poor quality (Appendices E and H).146-149, 151-156, 158-162

Four studies provide outcomes from randomized trials: three conducted outside the United States78, 85, 89 and one within a consortium of U.S. and Canadian hospitals.94 Of the 27 pre-post assessment studies, 16 were conducted in the United States,136, 138-139, 141-142, 144, 146-148, 150-152, 154-155, 158, 160 four in Europe,134-135, 156-157 three in Asia,137, 153, 161 one in Australia,162 one in Canada,143 one in South America,159 and one spanned multiple continents.140 There was one trial of fair quality78 and three of poor quality.85, 89, 94

#### Key Points

- No system-level strategies are supported by clinical trials. The content of strategies examined in observational studies is varied. Overall the evidence is insufficient to determine if systems-based strategies reduce cesarean (Table 34).
- Seventeen of 31 studies reported statistically significant reductions in cesarean with a range of 1.6 to 17.0 percent decreases.
- No randomized trials documented the effectiveness of strategies.
- Twelve observational studies reported achieving a reduction of 5 percent or more.
- More than 16 categories of components have been used in various combinations in these systems strategies. The most common component was audit and feedback of data.
- Ten pre-post studies documented reductions in cesarean from implementing varied forms of auditing of trends with regular feedback of data to either the organizational unit (hospital, department, labor and delivery staff) or the individual care providers, or both.
- The next most common components of successful strategies, with a 5 percent or greater reduction, were tracking of progress in labor and protocols for active management of labor.
- These same components were also common in systems-level strategies that failed to reduce cesarean use; thus it is not possible to say which components are superior.

#### Detailed Synthesis

##### Overview

The outcomes of systems-levels strategies are summarized in Table 30. Both randomized trials and pre-post study types are included. The indication that cesarean risk was the “same” in a study is based on small effect size with lack of statistical significance. Indication of higher risk means the risk was statistically higher in the intervention portion of trials or at the end of the intervention period than at baseline.

##### Randomized Clinical Trials

Each of the four trials grouped hospitals in pairs matched for key characteristics. The researchers randomly assigned a member of the pair to implement the strategy while the other member of the pair continued usual practice.78, 85, 89, 94 Each trial evaluated a different type of strategy and none demonstrated effectiveness for reducing use of cesarean.

- Nationwide trial of annual audit and feedback in the Netherlands. The intervention consisted of annual reports summarizing each department's cesarean profile in the context of anonymized data from other departments. Several analyses were provided that included graphs and figures to make clear the status of a particular department. The departmental leadership was contacted after receipt of the report to followup and to answer questions. This ensured the reports were reviewed. Over the course of three years during which the reports evolved from only departmental data to include individual provider data in context, the variation in cesarean use within hospital in the intervention decreased but there was no overall difference at the end of the trial between those randomized to receive or not receive reports and followup.89
- Implementation of the World Health Organization partogram with four hour action line to guide active management of labor. The trial was conducted in Indonesia, Thailand, and Malaysia. The authors do not report an intention-to-treat analysis of the hospitals as randomized but do reveal the overall change from baseline at intervention hospitals was a 1.7 percent reduction that was not statistically meaningful.78
- Requirement for a second opinion of a higher or equal rank physician with application of evidence-based guidelines for each category of indications for cesarean (e.g., elective, breech, failure to progress, emergent, etc.). In the intervention group cesarean was the route for 24.9 percent of births, compared with 24.7 in the hospitals that did not implement the requirements.85
- Use of a novel computer system for evaluation of labor progress in a consortium of Canadian and U.S. hospitals. The computerized system featured visual display of labor curves with addition of references ranges (5^th^, 50^th^, and 95^th^ percentile norms); 16.9 percent of women who gave birth in hospitals that continued their usual care patterns had cesareans compared to 17.6 in the hospitals using the computerized system.94

#### Observational Data

The 27 nonrandomized studies used prospective observational designs in which baseline data about route of birth were collected for an extended period of time prior to implementation of a policy, protocol, or procedure change.134-144, 146-148, 150-162 Then followup data were collected over time after implementation. Across these studies numerous types of strategies were implemented and evaluated. In order to describe content, we grouped strategies into 16 broad categories: (1) active management of labor, (2) group agreement on guidelines (3) audit and feedback of site specific data about cesarean trends at regular intervals, (4) evaluation of labor progression (5) evidence-based practice education and tools, (6) feedback of data to individual providers, (7) goals for increasing vaginal births after prior cesarean, (8) maternal support in labor (partner, doula, etc.), (9) protocols for breech vaginal birth, (10) protocols for induction, (11) protocols for pain management in labor, (12) protocols for twin vaginal birth, (13) quality improvement teams or tools used, (14) required second opinions, (15) World Health Organization initiatives, and (16) miscellaneous unique components. Rarely a study evaluated a single component; most often researchers studied the influence of a combination of approaches. None of the studies demonstrating decreased use of cesarean used only a single component (Table 31).

Table 31 Components of strategies in the United States with at least 5-percent reduction of cesarean

Author, Year | Evaluation of Labor Progress | Audit and Feedback to Units | Feedback to Individual Provider | Goals for Increasing VBAC | Active Management of Labor | Agreed on Guidelines | Protocols for Vaginal Breech | Protocols for Induction of Labor | Other Unique Components | Maternal Support in Labor (Partner/Doula) | Protocols for Vaginal Twins | Protocols for Labor Pain Management | Required Second Opinion | Total Components of 16 Possible | Percent Reduction
Sanchez-Ramos et al., 1990^152^ | ● | ● | | ● | | ● | ● | ● | ● | | ● | | | 8 | 17.0
Langrew et al., 1996^158^ | ● | ● | ● | | ● | | | ● | ● | | | | | 6 | 15.7
Rust et al., 1993^154^ | ● | | | ● | ● | ● | ● | ● | | | | | | 6 | 10.9
Socol et al., 1993^142^ | ● | ● | ● | ● | ● | | | | | ● | | ● | | 7 | 9.4
Poma, 1998^146^ | | ● | ● | | | ● | | | | | | | | 3 | 7.2
Meyers and Gleicher, 1998, 1993^141, 145^ | ● | ● | ● | ● | | | ● | | ● | | | | ● | 7 | 5.6
Boylan et al., 1991^144^ | ● | | | | ● | | | | | | | | | 2 | 5.5
Main et al., 1999^139^ | | ● | ● | | | | | | | | | | | 2 | 5.6
Total studies (n) | 6 | 6 | 5 | 4 | 4 | 4 | 3 | 3 | 3 | 1 | 1 | 1 | 1

Eight studies explicitly included policies about management of vaginal birth after cesarean among other components of a systems-level strategy.138, 141-142, 147-148, 152, 154-155 Other studies that provide limited detail and describe only implementation of uniform policies or review of all cesareans may also have included this element. Since it was a common element, these studies are included. It is important to note that this departs from the overall structure of this review since it means that women who are not at low risk for cesarean are included. This situation would be expected whenever a full health care system implements a policy for all births. However it is a limitation since it means, in the related studies, that some of the change in cesarean use may have been accomplished (or failed) because of the VBAC elements.

Five international studies achieved reductions in cesarean of 5 or more percent from baseline.134-135, 143, 161-162 One focused on implementation of the World Health Organization Effective Perinatal Care Program in the Ukraine and resulted in a 14.5 percent lower proportion of cesarean at the end of the two-year evaluation period.134 A six-component study in Australia that included protocols for vaginal birth after cesarean and audit and feedback through peer review achieved a reduction to an 11.0 percent annual cesarean rate from 20.6 percent, a decrease of 9.6 percent.162 Of the international pre-post intervention studies, this 1994 study bears the most similarities to a U.S. practice setting. A Canadian study in a small hospital with fewer than 300 births a year reduced their annual cesarean rate by 10 percent through implementing protocols for vaginal birth after cesarean, management of breech, and diagnosis of dystocia.143 Another small study in two Spanish hospitals used audit and feedback of data to providers along with appropriateness ratings of all cesareans.135 The authors reported a 7 percent decline in cesarean at one site, and a 1.7 percent decrease at a second site.135 Data were not combined in a single estimate, and the publication did not include statistical testing of the precision of either estimate. Of note, the site with the higher baseline rate (29.0 compared to 17.5%) was the site with the greater reduction in cesarean. The final international study to meet the criteria of important reduction was conducted in Taiwan and included audit and feedback at the departmental and individual level as well as regular cesarean review meetings and protocols for trial of labor among women with prior cesarean.161

In order to examine the total number and type of components used in less successful systems-level strategies in the U.S. we grouped those studies in Table 32 below. While the overall number of components used in any one study is modestly lower than more successful strategies and there is a shift in the components used, commonality with those studies that reported decreased rates is also apparent. This implies that it is not possible to determine from components alone which strategies are destined to succeed.

Table 32 Components of strategies in the United States with least success in reduction of cesarean

Author, Year | Evaluation of Labor Progress | Audit and Feedback to Units | Feedback to Individual Provider | Goals for Increasing VBAC | Active Management of Labor | Agreed on Guidelines | Protocols for Vaginal Breech | Protocols for Induction of Labor | Other Unique Components | Maternal Support in Labor (Partner/Doula) | Protocols for Vaginal Twins | Protocols for Labor Pain Management | Required Second Opinion | Total Components of 16 Possible | Percent Reduction
Gilstrap et al., 1984^151^ | ● | | | | | ● | ● | | | | | | | 3 | 1.6
Studnicki et al., 1997^160^ | | ● | | | | ● | | | | | | | | 2 | 1.5
Gregory et al., 1999^138^ | ● | ● | ● | ● | ● | ● | | ● | ● | ● | | ● | | 10 | -0.5
Hamilton et al., 2004^94^ | ● | | | | | | | | | | | | | 1 | -0.7
Oleske et al., 1992^148^ | | | | ● | | | | | ● | | | | | 2 | -1.2
Porreco, 1990^147^ | ● | | | ● | | | ● | ● | ● | | ● | | | 6 | -2.0
Pridjian et al., 1991^155^ | | | | ● | | | | | | | | | | 1 | -3.4
Total studies (n) | 4 | 2 | 1 | 4 | 1 | 3 | 2 | 2 | 3 | 1 | 1 | 1 | 0

In summary, no system-level strategies are supported by clinical trials. The content of strategies examined in observational studies is varied. Overall the evidence is insufficient to determine if systems based strategies reduce cesarean.

## KQ3 Where head-to-head comparisons are available, what strategies are shown to be superior in reducing the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

No studies addressed KQ3. It is discussed as a part of Future Research. All studies compared the novel strategy to usual care or to a variation on the same strategy.

We did not identify comparisons of distinctive strategies, for instance doula support vs. active management of labor, or pain management strategies compared to fetal monitoring strategies. Several comparisons evaluated different approaches to the same strategy like different approaches to epidural dosing or to monitoring progress of labor. These comparisons of variations on like strategies are noted in the sections that discuss those interventions. For now, there is no evidence to inform prioritization of one type of intervention to another.

## KQ4 What are the nature and frequency of adverse effects resulting from strategies used to reduce cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

### Overview of the Literature

We have included summaries of standard maternal outcomes of labor for each strategy (Tables 4, 10, 13, 17, 20, 24, and 28) in the context of results for KQs 1–2. These include events such as fever, infection, and hemorrhage. We have not considered these to be direct adverse effects, instead we have summarized the adverse effects that are plausibly caused by the strategy, for example dural puncture for epidural and perineal tears for education on pushing. Many of the studies included in this review, such as those related to psychosocial support have no known adverse effects. Of the studies reporting outcomes of strategies employed to reduce cesarean, 18^39-40, 44, 47, 49, 54, 59-60, 65, 80, 84, 90, 92, 95, 97-98, 100, 105^ reported data about outcomes that could be classified as adverse events or harms related to the strategy implemented to reduce cesarean (Table 33).

Table 33 Overview of adverse effects reported in studies of strategies to reduce cesarean birth

Author, Year Country | Strategy (n) | Key Adverse Effects
Abdel-Aleem et al., 2005^44^ Egypt | G1: Transcervical amnioinfusion (219) G2: Standard obstetric care without amnioinfusion (219) | - Maternal fever >38°C in 16 of amnioinfusion group, compared to 13 in the standard care group (RR=1.23, 95% CI: 0.61, 2.50); - Uterine hypertonicity in 16 in amnioinfusion group compared to 14 in standard care group (RR=1.14, 95% CI: 0.57, 2.28)
Asher et al., 2009^105^ US | G1: Acupuncture (30) G2: Sham acupuncture (29) G3: Usual care (no acupuncture) (30) | - Chorioamnionitis was reported in 23% of the acupuncture group, 21% of the sham acupuncture group, and 7% of the usual care group (p=0.20); - No significant difference in postpartum hemorrhage and/or uterine atony among the groups (p=0.70).
Adamsons et al., 1999^60^ Puerto Rico | G1: Propranolol during labor (34) G2: Usual care (23) | - No anesthesia-related morbidity in either group
Barakat et al., 2009^84^ Spain | G1: Exercise training (80) G2: No exercise training (80) | - No exercise-related injuries in either group; - 2 preterm births in the training group vs. 3 in the control group
Bidgood et al., 1987^54^ UK | G1: High-dose oxytocin (19) G2: Low-dose oxytocin (21) G3: Observation (20) | - Hyperstimulation, defined as >7 contractions in 15 min and/or rise in baseline tone >1.33 kPa pressure, in 7 women in the high-dose oxytocin group
Bloom et al., 2006^80^ US | G1: Fetal pulse oximetry with oxygen saturation displayed to clinician (2,629) G2: Fetal pulse oximetry with oxygen saturation not displayed to clinician (2,712) | - Chorioamnionitis was reported in 10.7% of each group; - No significant difference in postpartum endometritis (p=0.87) or wound complications (p=0.72); - Reported facial marks from the sensor (5.8% vs. 3.4%; p=0.74)
Choudhary et al., 2010^39^ India | G1: Transcervical amnioinfusion (146) G2: Standard obstetric care without amnioinfusion (146) | - No significant difference in maternal fever--3% of the amnioinfusion group compared to 5% of standard care (p=0.238)
Cox et al., 1999^100^ UK | G1: Inflatable obstetric belt (260) G2: Usual care (240) | - Significantly more women in the control group had an intact perineum (16.5% vs. 9.6%; OR=1.870; 95% CI: 1.094, 3.193) or experienced a 3^rd^ degree perineal tear (6.5% vs. 0.4%; OR=16.72, 95% CI: 2.81, >2.81); - Six women in the obstetrical belt group needed catheter insertion for urinary retention compared to 2 in the standard care group
Gambling et al., 1998^95^ US | G1: Combined spinal-epidural anesthesia (616) G2: Intravenous meperidine analgesia (607) | - Maternal fever (>38°C was more common in CSE group (22% vs. 3%; p<0.005); - 8 infants delivered by emergency cesarean due to profound fetal bradycardia within 1 hr of analgesia; - Pruritus reported in 48% of participants; - Nausea reported in 2.4% of participants
Harvey et al., 1996^47^ Canada | G1: Nurse-midwife care (101) G2: Physician care (93) | - Postpartum hemorrhage and retained placenta were more common in the nurse-midwife group (5.9% vs. 3.2 and 2.9% vs 2.2).; - Two women in the nurse-midwife group compared to one woman in the physician care group had a fever.
Hinshaw et al., 2008^90^ UK | G1: Early oxytocin (208) G2: Delayed oxytocin (204) | - No significant differences in maternal fever (p=0.48) postpartum hemorrhage (>500 ml; (p=0.87) and blood transfusion rates reported (4.8% vs. 4.9%); - Reported major depression within 48 hours of labor by Edinburgh Postnatal Depression Scale (20% vs. 15%; p=0.22)
Norris et al., 2001^97^ US | G1: Combined spinal-epidural anesthesia (1,071) G2: Epidural analgesia (1,112) | - Accidental dural puncture in 1.3% of CSE group and 1.2% of epidural group; - Intravascular catheter in 6.4% of CSE group and 4.4% of epidural group; - Failed epidural in 0.8% of CSE group and 0.7% of epidural group; - Positional headache in 1.7% of CSE group and 1.6% of epidural group; - Blood patch in 0.4% of CSE group and 0.6% of epidural group
O'Sullivan et al., 2009^92^ UK | G1: Allowed to eat during labor (1,227) G2: Usual care (1,216) | - 35% of those allowed to eat during labor vomited compared to 34% of those only allowed ice chips and water (RR=1.05, 95% CI: 0.94, 1.17; p=0.41)
Phipps et al., 2009^65^ Australia | G1: Structured education for pushing (50) G2: Standard care (50) | - Reported episiotomy and perineal tear rates; - No significant difference in 3^rd^ degree tear rates (p=0.142)
Regi et al., 2009^98^ India | G1: Transcervical amnioinfusion (75) G2: Standard obstetric care without amnioinfusion (75) | - Intrapartum temperature ≥ 38.3°C in 2.7% of the amnioinfusion group, 0% in standard care group.
Skrablin et al., 2011^49^ Croatia | G1: Continuous epidural (104) G2: Intermittent epidural (101) | - Maternal fever (>38.5°C) did not differ between groups (21 vs. 23 women; p=0.38).; - Hypotension was more common in the women who received intermittent epidural (22 vs. 33 women; relative risk=1.53).
Spallicci et al., 2007^40^ Brazil | G1: Hyaluronidase injection in cervix (83) G2: Placebo cervical injection (85) | - No significant difference in those reporting cramps between the two groups (p=0.2709).
Strong et al., 1990^59^ US | G1: Amnioinfusion (30) G2: Standard care (30) | - Maternal fever (>38°C was more common in amnioinfusion group (20% vs. 7%; p=0.06).; - Meconium (13% vs. 37%; p=0.04), severe variable decelerations (7% vs. 27%; p=0.04), and end-stage bradycardia (1 vs. 7; p=0.05) were more common in the standard care group.

### Key Points

Few of the adverse effects presented have a direct relationship to the strategy being used to prevent cesarean birth.

The adverse effects most commonly reported include maternal fever, nausea/vomiting, and anesthesia-related side effects.

### Detailed Synthesis

The most common side effects reported were maternal fever, nausea/vomiting, and anesthesia-related morbidities (Table 33). There were no reports of adverse effects that were directly causally linked to the strategy used to prevent cesarean.

#### Adverse Effects of Strategies Used During Pregnancy

In the Brazilian trial of hyaluronidase injections into the cervix the authors provided little information related to adverse effects. However, they did report that the p-value for cramps was p=0.2709.^40^ The Australian trial of structured education for pushing reported more common occurrence of chorioamnionitis and postpartum hemorrhage and/or uterine atony among the women who received traditional acupuncture compared to those who received no or sham acupuncture.65 In the Canadian trial of nurse-midwifery care compared to physician care postpartum hemorrhage and retained placenta were more common in the nurse-midwifery group.47 There were no exercise related injuries in either the control or intervention group in the trial of exercise training and preterm births were more common in the control group.84

#### Adverse Effects of Strategies Used During Labor

##### Management of Abnormal Labor

Two trials of strategies used to manage abnormal labor reported various adverse effects of the intervention.54, 90 Bidgood and colleagues reported seven women with hyperstimulation within 15 minutes after infusion, all in the high-dose oxytocin group.54 In a trial of early and delayed oxytocin there were no significant differences in maternal fever, postpartum hemorrhage, need for blood transfusion, or major depression.90

##### Pain Management

Two U.S. studies comparing combined spinal-epidural anesthesia and IV meperidine analgesia95 and epidural97 reported several adverse effects. Maternal fever greater than 38°C was more common in the combined spinal-epidural group (22% vs. 3%; p<0.005).95 In addition this study reported that eight infants were delivered by emergency cesarean due to profound fetal bradycardia within one hour of analgesia. Norris and colleagues reported higher rates of accidental dural puncture, intravascular catheterization, failed epidural and positional headache among women who received the combined spinal-epidural.97 However, proportion of participants experiencing a blood patch was higher in the epidural group.97 Maternal fever did not differ significantly among participants in the Croatian trial of continuous versus intermittent epidural.49 Hypotension was more common among women who received the intermittent epidural.49

##### Fetal Assessments

Only one study of fetal pulse oximetry reported adverse effects.80 There were no significant differences in the proportion of chorioamnionitis (10.7% in each group), endometritis, or wound complications. The sensor used in the trial resulted in facial marks on 5.8 percent of infants in the open group versus 3.4 percent in the masked group.80

##### Amnioinfusion

Three of the four studies of amnioinfusion reported higher numbers of maternal fever in the amnioinfusion group compared to standard care without amnioinfusion.44, 59, 98 However, this was not seen in the study by Choudhary and colleagues.39

##### Unique Strategies

Four studies of unique strategies to reduce cesarean report adverse effects.60, 92, 100, 105 Chorioamnionitis was more common among women who received acupuncture in the study of acupuncture compared to sham acupuncture and no acupuncture (23% vs. 21% and 7%).105 There were no significant differences in postpartum hemorrhage and uterine atony across the three groups. Adamsons and colleagues compared propranolol during labor to usual care and reported no anesthesia-related morbidity among study participants.60 In the study examining the effectiveness of an inflatable obstetrical belt,100 significantly more women in the control group experienced a 3rd degree perineal tear (6.5% vs. 0.4%). Six women in the obstetrical belt group needed catheter insertion for urinary retention compared to two women in the standard care group.100 In the study by O'Sullivan and colleagues there was no difference in the percent of women who vomited among those who were allowed to eat in labor versus those only allowed to have ice chips and water.92

Overall the included trials were small and unlikely to detect rate, but potential important events. Those strategies that were directly associates with adverse effects were primarily procedural such as risk of dural puncture with epidural. While this is a known risk of epidural it is not the case that it would be uniquely associated with the particular dosing strategy to be used, for instance continuous versus intermittent dosing. We have considered these sorts of complications as not specific to the intention of the use, and because this is not a review of all the uses of these categories of strategy (social support in labor, fetal monitoring devices, etc), we do not provide estimates per se of these sorts of adverse effects. Overall no adverse effects were identified that were unique or notably exacerbated by use of the intervention for the purpose of attempting to decrease use of cesarean.