# References

1 Menacker F, Hamilton BE. Recent trends in cesarean delivery in the United States. NCHS Data Brief. Mar. 2010;(35):1-8. [pmid: 20334736].
2 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2007. Natl Vital Stat Rep. Aug. 9. 2010;58(24):1-85. [pmid: 21254725].
3 The Joint Commission. Specifications manual for Joint Commission national quality core measures. 2010. http://manual.jointcommission.org/releases/TJC2010B/MIF01067.html. February 4 2011.
4 National Institutes of Health Consensus Development conference statement: vaginal birth after cesarean: new insights March 8-10, 2010. Obstet Gynecol. Jun. 2010;115(6):1279-95. [pmid: 20502301].
5 NIH consensus development statement on cesarean childbirth. The Cesarean Birth Task Force. Obstet Gynecol. Apr. 1981;57(4):537-45. [pmid: 7243111].
6 Getahun D, Oyelese Y, Salihu HM, et al. Previous cesarean delivery and risks of placenta previa and placental abruption. Obstet Gynecol. Apr. 2006;107(4):771-8. [pmid: 16582111].
7 Blanchette H. The rising cesarean delivery rate in America: what are the consequences?. Obstet Gynecol. Sep. 2011;118(3):687-90. [pmid: 21860302].
8 Clark SL, Belfort MA, Hankins GD, et al. Variation in the rates of operative delivery in the United States. Am J Obstet Gynecol. Jun. 2007;196(6):526 e1-5. [pmid: 17547880].
9 Wennberg J. Which rate is right?. N Engl J Med. Jan. 30. 1986;314(5):310-1. [pmid: 3941721].
10 Wennberg JE. Tracking Medicine: A Researcher's Quest to Understand Health Care. Oxford, England. Oxford University Press. 2010.
11 Baicker K, Buckles KS, Chandra A. Geographic variation in the appropriate use of cesarean delivery. Health Aff (Millwood). Sep-Oct. 2006;25(5):w355-67. [pmid: 16895942].
12 Luthy DA, Malmgren JA, Zingheim RW, et al. Physician contribution to a cesarean delivery risk model. Am J Obstet Gynecol. Jun. 2003;188(6):1579-85. discussion 85-7. [pmid: 12824996].
13 National Center for Health Statistics. Healthy People 2000 Final Review. Hyattsville, MD. Public Health Service. 2001.
14 U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. Washington, DC. U.S. Government Printing Office. 2000. www.healthypeople.gov/2010. May 5 2011.
15 U. S. Department of Health and Human Services. Healthy People 2020. Washington, DC. www.healthypeople.gov/2020/default.aspx. May 5, 2011.
16 Cyr RM. Myth of the ideal cesarean section rate: commentary and historic perspective. Am J Obstet Gynecol. Apr. 2006;194(4):932-6. [pmid: 16580278].
17 Resnik R. Can a 29% cesarean delivery rate possibly be justified?. Obstet Gynecol. Apr. 2006;107(4):752-4. [pmid: 16582108].
18 Gruber J, Kim J, Mayzlin D. Physician fees and procedure intensity: the case of cesarean delivery. J Health Econ. Aug. 1999;18(4):473-90. [pmid: 10539618].
19 Zwecker P, Azoulay L, Abenhaim HA. Effect of fear of litigation on obstetric care: a nationwide analysis on obstetric practice. Am J Perinatol. Apr. 2011;28(4):277-84. [pmid: 21249618].
20 Dursun P, Yanik FB, Zeyneloglu HB, et al. Why women request cesarean section without medical indication?. J Matern Fetal Neonatal Med. Sep. 2011;24(9):1133-7. [pmid: 21668323].
21 Quiroz LH, Blomquist JL, Macmillan D, et al. Maternal goals for childbirth associated with planned vaginal and planned cesarean birth. Am J Perinatol. Oct. 2011;28(9):695-702. [pmid: 21660899].
22 O'Boyle AL, Davis GD, Calhoun BC. Informed consent and birth: protecting the pelvic floor and ourselves. Am J Obstet Gynecol. Oct. 2002;187(4):981-3. [pmid: 12388991].
23 Handa VL, Blomquist JL, Knoepp LR, et al. Pelvic floor disorders 5-10 years after vaginal or cesarean childbirth. Obstet Gynecol. Oct. 2011;118(4):777-84. [pmid: 21897313].
24 Bettes BA, Coleman VH, Zinberg S, et al. Cesarean delivery on maternal request: obstetrician-gynecologists' knowledge, perception, and practice patterns. Obstet Gynecol. Jan. 2007;109(1):57-66. [pmid: 17197588].
25 Simpson KR, Thorman KE. Obstetric “conveniences”: elective induction of labor, cesarean birth on demand, and other potentially unnecessary interventions. J Perinat Neonatal Nurs. Apr-Jun. 2005;19(2):134-44. [pmid: 15923963].
26 Bayrampour H, Heaman M. Advanced maternal age and the risk of cesarean birth: a systematic review. Birth. Sep. 2010;37(3):219-26. [pmid: 20887538].
27 Kulie T, Slattengren A, Redmer J, et al. Obesity and women's health: an evidence-based review. J Am Board Fam Med. Jan-Feb. 2011;24(1):75-85. [pmid: 21209347].
28 Khunpradit S, Tavender E, Lumbiganon P, et al. Non-clinical interventions for reducing unnecessary caesarean section. Cochrane Database Syst Rev. 2011;(6):CD005528. [pmid: 21678348].
29 Catling-Paull C, Johnston R, Ryan C, et al. Non-clinical interventions that increase the uptake and success of vaginal birth after caesarean section: a systematic review. J Adv Nurs. Aug. 2011;67(8):1662-76. [pmid: 21535091].
30 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
31 Viswanathan M, Visco AG, Hartmann K, et al. Cesarean delivery on maternal request. Evid Rep Technol Assess (Full Rep). Mar. 2006;(133):1-138. [pmid: 17627329].
32 Caughey AB, Sundaram V, Kaimal AJ, et al. Maternal and neonatal outcomes of elective induction of labor. Evid Rep Technol Assess (Full Rep). Mar. 2009;(176):1-257. [pmid: 19408970].
33 Guise JM, Eden K, Emeis C, et al. Vaginal birth after cesarean: new insights. Evid Rep Technol Assess (Full Rep). Mar. 2010;(191):1-397. [pmid: 20629481].
34 Robinson KA, Dickersin K. Development of a highly sensitive search strategy for the retrieval of reports of controlled trials using PubMed. Int J Epidemiol. Feb. 2002;31(1):150-3. [pmid: 11914311].
35 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
36 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. 2008. www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433403.
37 Higgins JPT, Altman DG, Sterne JAC. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 (updated March 2011). The Cochrane Collaboration. 2011.
38 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective healthcare program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
39 Choudhary D, Bano I, Ali SM. Does amnioinfusion reduce caesarean section rate in meconium-stained amniotic fluid. Arch Gynecol Obstet. Jul. 2010;282(1):17-22. [pmid: 19685066].
40 Spallicci MD, Chiea MA, Singer JM, et al. Use of hyaluronidase for cervical ripening: a randomized trial. Eur J Obstet Gynecol Reprod Biol. Jan. 2007;130(1):46-50. [pmid: 16324780].
41 Sanchez-Ramos L, Quillen MJ, Kaunitz AM. Randomized trial of oxytocin alone and with propranolol in the management of dysfunctional labor. Obstet Gynecol. Oct. 1996;88(4 Pt 1):517-20. [pmid: 8841209].
42 Trueba G, Contreras C, Velazco MT, et al. Alternative strategy to decrease cesarean section: support by Doulas during labor. J Perinat Educ. 2000;9(2):8-13. [pmid: 17273201].
43 Kuhnert M, Schmidt S. Intrapartum management of nonreassuring fetal heart rate patterns: a randomized controlled trial of fetal pulse oximetry. Am J Obstet Gynecol. Dec. 2004;191(6):1989-95. [pmid: 15592281].
44 Abdel-Aleem H, Amin AF, Shokry M, et al. Therapeutic amnioinfusion for intrapartum fetal distress using a pediatric feeding tube. Int J Gynaecol Obstet. Aug. 2005;90(2):94-8. [pmid: 15913621].
45 Rathor AM, Singh R, Ramji S, et al. Randomised trial of amnioinfusion during labour with meconium stained amniotic fluid. BJOG. Jan. 2002;109(1):17-20. [pmid: 11843370].
46 McGrath SK, Kennell JH. A randomized controlled trial of continuous labor support for middle-class couples: effect on cesarean delivery rates. Birth. Jun. 2008;35(2):92-7. [pmid: 18507579].
47 Harvey S, Jarrell J, Brant R, et al. A randomized, controlled trial of nurse-midwifery care. Birth. Sep. 1996;23(3):128-35. [pmid: 8924098].
48 Kennell J, Klaus M, McGrath S, et al. Continuous emotional support during labor in a US hospital. A randomized controlled trial. JAMA. May. 1. 1991;265(17):2197-201. [pmid: 2013951].
49 Skrablin S, Grgic O, Mihaljevic S, et al. Comparison of intermittent and continuous epidural analgesia on delivery and progression of labour. J Obstet Gynaecol. 2011;31(2):134-8. [pmid: 21281028].
50 Pattinson RC, Howarth GR, Mdluli W, et al. Aggressive or expectant management of labour: a randomised clinical trial. BJOG. May. 2003;110(5):457-61. [pmid: 12742329].
51 Lavender T, Alfirevic Z, Walkinshaw S. Partogram action line study: a randomised trial. Br J Obstet Gynaecol. Sep. 1998;105(9):976-80. [pmid: 9763048].
52 Homer CS, Davis GK, Brodie PM, et al. Collaboration in maternity care: a randomised controlled trial comparing community-based continuity of care with standard hospital care. BJOG. Jan. 2001;108(1):16-22. [pmid: 11212998].
53 Harper TC, Coeytaux RR, Chen W, et al. A randomized controlled trial of acupuncture for initiation of labor in nulliparous women. J Matern Fetal Neonatal Med. Aug. 2006;19(8):465-70. [pmid: 16966110].
54 Bidgood KA, Steer PJ. A randomized control study of oxytocin augmentation of labour. 1. Obstetric outcome. Br J Obstet Gynaecol. Jun. 1987;94(6):512-7. [pmid: 3620398].
55 Matsuo K, Mudd JV, Kopelman JN, et al. Duration of the second stage of labor while wearing a dental support device: a pilot study. J Obstet Gynaecol Res. Aug. 2009;35(4):672-8. [pmid: 19751326].
56 Garite TJ, Weeks J, Peters-Phair K, et al. A randomized controlled trial of the effect of increased intravenous hydration on the course of labor in nulliparous women. Am J Obstet Gynecol. Dec. 2000;183(6):1544-8. [pmid: 11120525].
57 Moodley J, Matchaba P, Payne AJ. Intrapartum amnioinfusion for meconium-stained liquor in developing countries. Trop Doct. Jan. 1998;28(1):31-4. [pmid: 9481194].
58 Karraz MA. Ambulatory epidural anesthesia and the duration of labor. Int J Gynaecol Obstet. Feb. 2003;80(2):117-22. [pmid: 12566183].
59 Strong TH Jr., Hetzler G, Sarno AP, et al. Prophylactic intrapartum amnioinfusion: a randomized clinical trial. Am J Obstet Gynecol. Jun. 1990;162(6):1370-4. discussion 4-5. [pmid: 2193511].
60 Adamsons K, de la Vega A, Santiago P. Reduction in the cesarean section rate in nulliparous patients after administration of intravenous propranolol. P R Health Sci J. Mar. 1999;18(1):5-8. [pmid: 10343980].
61 Saisto T, Salmela-Aro K, Nurmi JE, et al. A randomized controlled trial of intervention in fear of childbirth. Obstet Gynecol. Nov. 2001;98(5 Pt 1):820-6. [pmid: 11704175].
62 Nicholson JM, Parry S, Caughey AB, et al. The impact of the active management of risk in pregnancy at term on birth outcomes: a randomized clinical trial. Am J Obstet Gynecol. May. 2008;198(5):511 e1-15. [pmid: 18455526].
63 Olofsson C, Ekblom A, Ekman-Ordeberg G, et al. Obstetric outcome following epidural analgesia with bupivacaine-adrenaline 0.25% or bupivacaine 0.125% with sufentanil--a prospective randomized controlled study in 1000 parturients. Acta Anaesthesiol Scand. Mar. 1998;42(3):284-92. [pmid: 9542554].
64 Rogers R, Gilson GJ, Miller AC, et al. Active management of labor: does it make a difference?. Am J Obstet Gynecol. Sep. 1997;177(3):599-605. [pmid: 9322630].
65 Phipps H, Charlton S, Dietz HP. Can antenatal education influence how women push in labour?. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):274-8. [pmid: 19566559].
66 Lopez-Zeno JA, Peaceman AM, Adashek JA, et al. A controlled trial of a program for the active management of labor. N Engl J Med. Feb. 13. 1992;326(7):450-4. [pmid: 1732771].
67 Hemminki E, Virta A, Koponen P. A trial on continuous human support during labor; Feasibility, interventions and mothers' satisfaction. J Psychosom Obstet Gynaecol. 1990;11(4):239-50.
68 McNiven PS, Williams JI, Hodnett E, et al. An early labor assessment program: a randomized, controlled trial. Birth. Mar. 1998;25(1):5-10. [pmid: 9534499].
69 Mahomed K, Mulambo T, Woelk G, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 2. Zimbabwe. Br J Obstet Gynaecol. Mar. 1998;105(3):309-13. [pmid: 9532992].
70 Vayssiere C, David E, Meyer N, et al. A French randomized controlled trial of ST-segment analysis in a population with abnormal cardiotocograms during labor. Am J Obstet Gynecol. Sep. 2007;197(3):299 e1-6. [pmid: 17826428].
71 Somprasit C, Tanprasertkul C, Kamudhamas A. Reducing cesarean delivery rates: an active management labor program in a setting with limited resources. J Med Assoc Thai. Jan. 2005;88(1):20-5. [pmid: 15960212].
72 Bernitz S, Rolland R, Blix E, et al. Is the operative delivery rate in low-risk women dependent on the level of birth care? A randomised controlled trial. BJOG. Oct. 2011;118(11):1357-64. [pmid: 21749629].
73 Gagnon AJ, Waghorn K, Covell C. A randomized trial of one-to-one nurse support of women in labor. Birth. Jun. 1997;24(2):71-7. [pmid: 9271971].
74 East CE, Brennecke SP, King JF, et al. The effect of intrapartum fetal pulse oximetry, in the presence of a nonreassuring fetal heart rate pattern, on operative delivery rates: a multicenter, randomized, controlled trial (the FOREMOST trial). Am J Obstet Gynecol. Mar. 2006;194(3):606 e1-16. [pmid: 16522387].
75 Bloom SL, McIntire DD, Kelly MA, et al. Lack of effect of walking on labor and delivery. N Engl J Med. Jul. 9. 1998;339(2):76-9. [pmid: 9654537].
76 Mehrangiz Z, Sogra R, Malihe A. Randomized clinical trial to study the effect of paracervical block on reducing pain, improving APGAR Score and on accelerating the active phase of labor. Internet J Pain, Symptom Control & Palliative Care. 2004;3(1):7p.
77 Waldenstrom U, Nilsson CA, Winbladh B. The Stockholm birth centre trial: maternal and infant outcome. Br J Obstet Gynaecol. Apr. 1997;104(4):410-8. [pmid: 9141576].
78 World Health Organization partograph in management of labour. World Health Organization Maternal Health and Safe Motherhood Programme. Lancet. Jun. 4. 1994;343(8910):1399-404. [pmid: 7910888].
79 Cohen GR, O'Brien WF, Lewis L, et al. A prospective randomized study of the aggressive management of early labor. Am J Obstet Gynecol. Nov. 1987;157(5):1174-7. [pmid: 3688070].
80 Bloom SL, Spong CY, Thom E, et al. Fetal pulse oximetry and cesarean delivery. N Engl J Med. Nov. 23. 2006;355(21):2195-202. [pmid: 17124017].
81 Hofmeyr GJ, Gulmezoglu AM, Buchmann E, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 1. South Africa. Br J Obstet Gynaecol. Mar. 1998;105(3):304-8. [pmid: 9532991].
82 Windrim R, Seaward PG, Hodnett E, et al. A randomized controlled trial of a bedside partogram in the active management of primiparous labour. J Obstet Gynaecol Can. Jan. 2007;29(1):27-34. [pmid: 17346475].
83 Sadler LC, Davison T, McCowan LM. A randomised controlled trial and meta-analysis of active management of labour. BJOG. Jul. 2000;107(7):909-15. [pmid: 10901564].
84 Barakat R, Ruiz JR, Stirling JR, et al. Type of delivery is not affected by light resistance and toning exercise training during pregnancy: a randomized controlled trial. Am J Obstet Gynecol. Dec. 2009;201(6):590 e1-6. [pmid: 19608151].
85 Althabe F, Belizan JM, Villar J, et al. Mandatory second opinion to reduce rates of unnecessary caesarean sections in Latin America: a cluster randomised controlled trial. Lancet. Jun. 12. 2004;363(9425):1934-40. [pmid: 15194252].
86 Hodnett ED, Lowe NK, Hannah ME, et al. Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. JAMA. Sep. 18. 2002;288(11):1373-81. [pmid: 12234231].
87 Frigoletto FD Jr., Lieberman E, Lang JM, et al. A clinical trial of active management of labor. N Engl J Med. Sep. 21. 1995;333(12):745-50. [pmid: 7643880].
88 Ajadi MA, Kuti O, Orji EO, et al. The effect of amniotomy on the outcome of spontaneous labour in uncomplicated pregnancy. J Obstet Gynaecol. Oct. 2006;26(7):631-4. [pmid: 17071428].
89 Elferink-Stinkens PM, Brand R, Amelink-Verburg MP, et al. Randomised clinical trial on the effect of the Dutch obstetric peer review system. Eur J Obstet Gynecol Reprod Biol. Apr. 10. 2002;102(1):21-30. [pmid: 12039085].
90 Hinshaw K, Simpson S, Cummings S, et al. A randomised controlled trial of early versus delayed oxytocin augmentation to treat primary dysfunctional labour in nulliparous women. BJOG. Sep. 2008;115(10):1289-95. discussion 95-6. [pmid: 18715415].
91 Lavender T, Alfirevic Z, Walkinshaw S. Effect of different partogram action lines on birth outcomes: a randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):295-302. [pmid: 16880298].
92 O'Sullivan G, Liu B, Hart D, et al. Effect of food intake during labour on obstetric outcome: randomised controlled trial. BMJ. 2009;338:b784. [pmid: 19318702].
93 Waldenstrom U, McLachlan H, Forster D, et al. Team midwife care: maternal and infant outcomes. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):257-64. [pmid: 11592538].
94 Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. Jan-Feb. 2004;26(1):37-44. [pmid: 14763319].
95 Gambling DR, Sharma SK, Ramin SM, et al. A randomized study of combined spinal-epidural analgesia versus intravenous meperidine during labor: impact on cesarean delivery rate. Anesthesiology. Dec. 1998;89(6):1336-44. [pmid: 9856707].
96 Campbell DA, Lake MF, Falk M, et al. A randomized control trial of continuous support in labor by a lay doula. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):456-64. [pmid: 16881989].
97 Norris MC, Fogel ST, Conway-Long C. Combined spinal-epidural versus epidural labor analgesia. Anesthesiology. Oct. 2001;95(4):913-20. [pmid: 11605932].
98 Regi A, Alexander N, Jose R, et al. Amnioinfusion for relief of recurrent severe and moderate variable decelerations in labor. J Reprod Med. May. 2009;54(5):295-302. [pmid: 19517694].
99 Ojala K, Vaarasmaki M, Makikallio K, et al. A comparison of intrapartum automated fetal electrocardiography and conventional cardiotocography--a randomised controlled study. BJOG. Apr. 2006;113(4):419-23. [pmid: 16553653].
100 Cox J, Cotzias CS, Siakpere O, et al. Does an inflatable obstetric belt facilitate spontaneous vaginal delivery in nulliparae with epidural analgesia?. Br J Obstet Gynaecol. Dec. 1999;106(12):1280-6. [pmid: 10609722].
101 Garite TJ, Dildy GA, McNamara H, et al. A multicenter controlled trial of fetal pulse oximetry in the intrapartum management of nonreassuring fetal heart rate patterns. Am J Obstet Gynecol. Nov. 2000;183(5):1049-58. [pmid: 11084540].
102 Janssen PA, Still DK, Klein MC, et al. Early labor assessment and support at home versus telephone triage: a randomized controlled trial. Obstet Gynecol. Dec. 2006;108(6):1463-9. [pmid: 17138781].
103 Jalil NA, Omar M. Does ropivacaine 0.2% with fentanyl change the labour epidural profile?. Int Med J. 2009;16(2):149-55.
104 Palomaki O, Uotila J, Tammela O, et al. A double blind, randomized trial on augmentation of labour with a combination of intravenous propranolol and oxytocin versus oxytocin only. Eur J Obstet Gynecol Reprod Biol. Mar. 1. 2006;125(1):44-9. [pmid: 16051416].
105 Asher GN, Coeytaux RR, Chen W, et al. Acupuncture to initiate labor (Acumoms 2): a randomized, sham-controlled clinical trial. J Matern Fetal Neonatal Med. Oct. 2009;22(10):843-8. [pmid: 19526433].
106 Scheepers HC, Thans MC, de Jong PA, et al. A double-blind, randomised, placebo controlled study on the influence of carbohydrate solution intake during labour. BJOG. Feb. 2002;109(2):178-81. [pmid: 11911101].
107 Waldenstrom U, Nilsson CA. A randomized controlled study of birth center care versus standard maternity care: effects on women's health. Birth. Mar. 1997;24(1):17-26. [pmid: 9271963].
108 Bungum TJ, Peaslee DL, Jackson AW, et al. Exercise during pregnancy and type of delivery in nulliparae. J Obstet Gynecol Neonatal Nurs. May-Jun. 2000;29(3):258-64. [pmid: 10839574].
109 Hall DC, Kaufmann DA. Effects of aerobic and strength conditioning on pregnancy outcomes. Am J Obstet Gynecol. Nov. 1987;157(5):1199-203. [pmid: 3688075].
110 Klein MC, Kelly A, Kaczorowski J, et al. The effect of family physician timing of maternal admission on procedures in labour and maternal and infant morbidity. J Obstet Gynaecol Can. Jul. 2004;26(7):641-5. [pmid: 15248933].
111 Hemminki E, Simukka R. The timing of hospital admission and progress of labour. Eur J Obstet Gynecol Reprod Biol. Jun. 1986;22(1-2):85-94. [pmid: 3721051].
112 Kenyon AP, Piercy CN, Girling J, et al. Obstetric cholestasis, outcome with active management: a series of 70 cases. BJOG. Mar. 2002;109(3):282-8. [pmid: 11950183].
113 ACOG Practice Bulletin Number 49, December 2003: Dystocia and augmentation of labor. Obstet Gynecol. Dec. 2003;102(6):1445-54. [pmid: 14662243].
114 Lavender T, Hart A, Smyth RM. Effect of partogram use on outcomes for women in spontaneous labour at term. Cochrane Database Syst Rev. 2008;(4):CD005461. [pmid: 18843690].
115 Brown HC, Paranjothy S, dowswell T, et al. Package of care for active management in labour for reducing caesarean section rates in low-risk women (Review). Cochrane Database of Systematic Reviews. 2009;(3).
116 Smyth RM, Alldred SK, Markham C. Amniotomy for shortening spontaneous labour. Cochrane Database Syst Rev. 2007;(4):CD006167. [pmid: 17943891].
117 Xia XY, Huang XH, Xia YX, et al. Changes of nerve growth factor in amniotic fluid and correlation with ventriculomegaly. Chin Med Sci J. Jun. 2011;26(2):109-12. [pmid: 21703119].
118 Langer A, Campero L, Garcia C, et al. Effects of psychosocial support during labour and childbirth on breastfeeding, medical interventions, and mothers' wellbeing in a Mexican public hospital: a randomised clinical trial. Br J Obstet Gynaecol. Oct. 1998;105(10):1056-63. [pmid: 9800927].
119 Dongol AS, Shrestha A, Chawla CD. Post partum haemorrhage: prevalence, morbidity and management pattern in Dhulikhel Hospital. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2010;8(30):212-5. [pmid: 21209538].
120 Osterman MJ, Martin JA. Epidural and spinal anesthesia use during labor: 27-state reporting area, 2008. Natl Vital Stat Rep. Apr. 6. 2011;59(5):1-13. 6. [pmid: 21553556].
121 Anim-Somuah M, Smyth R, Howell C. Epidural versus non-epidural or no analgesia in labour. Cochrane Database Syst Rev. 2005;(4):CD000331. [pmid: 16235275].
122 Kuhnert M, Seelbach-Goebel B, Butterwegge M. Predictive agreement between the fetal arterial oxygen saturation and fetal scalp pH: results of the German multicenter study. Am J Obstet Gynecol. Feb. 1998;178(2):330-5. [pmid: 9500495].
123 Seelbach-Gobel B, Heupel M, Kuhnert M, et al. The prediction of fetal acidosis by means of intrapartum fetal pulse oximetry. Am J Obstet Gynecol. Jan. 1999;180(1 Pt 1):73-81. [pmid: 9914582].
124 Carbonne B, Langer B, Goffinet F, et al. Multicenter study on the clinical value of fetal pulse oximetry. II. Compared predictive values of pulse oximetry and fetal blood analysis. The French Study Group on Fetal Pulse Oximetry. Am J Obstet Gynecol. Sep. 1997;177(3):593-8. [pmid: 9322629].
125 Kuehnert M, Seelbach-Goebel B, di Renzo GC, et al. Guidelines for the use of fetal pulse oximetry during labor and delivery. Prenat Neonat Med. 1998;3(4):432-3.
126 Nijland R, Jongsma HW, Crevels J, et al. The ductus arteriosus, pre- and post-ductal oxygen saturation measurements in fetal lambs. Eur J Obstet Gynecol Reprod Biol. Jun. 15. 1994;55(2):135-40. [pmid: 7958151].
127 Nijland R, Jongsma HW, Nijhuis JG, et al. Arterial oxygen saturation in relation to metabolic acidosis in fetal lambs. Am J Obstet Gynecol. Mar. 1995;172(3):810-9. [pmid: 7892869].
128 Dildy GA, Thorp JA, Yeast JD, et al. The relationship between oxygen saturation and pH in umbilical blood: implications for intrapartum fetal oxygen saturation monitoring. Am J Obstet Gynecol. Sep. 1996;175(3 Pt 1):682-7. [pmid: 8828434].
129 International Federation of Gynaecology and Obstetrics. Guidelines for the use of fetal monitoring. Zurich, Switzerland. 1985.
130 Rutherford SE, Phelan JP, Smith CV, et al. The four-quadrant assessment of amniotic fluid volume: an adjunct to antepartum fetal heart rate testing. Obstet Gynecol. Sep. 1987;70(3 Pt 1):353-6. [pmid: 3306497].
131 Kubli FW, Hon EH, Khazin AF, et al. Observations on heart rate and pH in the human fetus during labor. Am J Obstet Gynecol. Aug. 15. 1969;104(8):1190-206. [pmid: 5807980].
132 Miyazaki FS, Taylor NA. Saline amnioinfusion for relief of variable or prolonged decelerations. A preliminary report. Am J Obstet Gynecol. Jul. 15. 1983;146(6):670-8. [pmid: 6869437].
133 Chakfa AM, Mehta NR, Forgione AG, et al. The effect of stepwise increases in vertical dimension of occlusion on isometric strength of cervical flexors and deltoid muscles in nonsymptomatic females. Cranio. Oct. 2002;20(4):264-73. [pmid: 12403184].
134 Berglund A, Lefevre-Cholay H, Bacci A, et al. Successful implementation of evidence-based routines in Ukrainian maternities. Acta Obstet Gynel Scand. 2010;89(2):230-7. [pmid: 20121338].
135 Calvo A, Campillo C, Juan M, et al. Effectiveness of a multifaceted strategy to improve the appropriateness of cesarean sections. Acta Obstet Gynecol Scand. 2009;88(7):842-5. [pmid: 19488884].
136 Smith JE, Fisher DL, Endorf-Olson JJ. Integrating patient satisfaction into performance measurement to meet improvement challenges. Jt Comm J Qual Improv. May. 2000;26(5):277-86. [pmid: 18350772].
137 Kim CY, Ko SK, Kim KY. Are league tables controlling epidemic of caesarean sections in South Korea?. BJOG. May. 2005;112(5):607-11. [pmid: 15842285].
138 Gregory KD, Hackmeyer P, Gold L, et al. Using the continuous quality improvement process to safely lower the cesarean section rate. Jt Comm J Qual Improv. Dec. 1999;25(12):619-29. [pmid: 10605652].
139 Main EK. Reducing cesarean birth rates with data-driven quality improvement activities. Pediatrics. Jan. 1999;103(1 Suppl E):374-83. [pmid: 9917479].
140 Kazandjian VA, Lied TR. Cesarean section rates: effects of participation in a performance measurement project. Jt Comm J Qual Improv. Apr. 1998;24(4):187-96. [pmid: 9589331].
141 Myers SA, Gleicher N. The Mount Sinai cesarean section reduction program: an update after 6 years. Soc Sci Med. Nov. 1993;37(10):1219-22. [pmid: 8272900].
142 Socol ML, Garcia PM, Peaceman AM, et al. Reducing cesarean births at a primarily private university hospital. Am J Obstet Gynecol. Jun. 1993;168(6 Pt 1):1748-54. discussion 54-8. [pmid: 8317517].
143 Iglesias S, Burn R, Saunders LD. Reducing the cesarean section rate in a rural community hospital. CMAJ. Dec. 1. 1991;145(11):1459-64. [pmid: 1959105].
144 Boylan P, Frankowski R, Rountree R, et al. Effect of active management of labor on the incidence of cesarean section for dystocia in nulliparas. Am J Perinatol. Nov. 1991;8(6):373-9. [pmid: 1814299].
145 Myers SA, Gleicher N. A successful program to lower cesarean-section rates. N Engl J Med. Dec. 8. 1988;319(23):1511-6. [pmid: 3185675].
146 Poma PA. Effect of departmental policies on cesarean delivery rates: a community hospital experience. Obstet Gynecol. Jun. 1998;91(6):1013-8. [pmid: 9611015].
147 Porreco RP. Meeting the challenge of the rising cesarean birth rate. Obstet Gynecol. Jan. 1990;75(1):133-6. [pmid: 2296410].
148 Oleske DM, Glandon GL, Tancredi DJ, et al. Information dissemination and the cesarean birth rate. The Illinois experience. Int J Technol Assess Health Care. Fall. 1992;8(4):708-18. [pmid: 1464490].
149 Dillon WP, Choate JW, Nusbaum ML, et al. Obstetric care and cesarean birth rates: a program to monitor quality of care. Obstet Gynecol. Nov. 1992;80(5):731-7. [pmid: 1407907].
150 Bickell NA, Zdeb MS, Applegate MS, et al. Effect of external peer review on cesarean delivery rates: a statewide program. Obstet Gynecol. May. 1996;87(5 Pt 1):664-7. [pmid: 8677064].
151 Gilstrap LC 3rd, Hauth JC, Toussaint S. Cesarean section: changing incidence and indications. Obstet Gynecol. Feb. 1984;63(2):205-8. [pmid: 6694814].
152 Sanchez-Ramos L, Kaunitz AM, Peterson HB, et al. Reducing cesarean sections at a teaching hospital. Am J Obstet Gynecol. Sep. 1990;163(3):1081-7. discussion 7-8. [pmid: 2403133].
153 Tay SK, Tsakok FH, Ng CS. The use of intradepartmental audit to contain cesarean section rate. Int J Gynaecol Obstet. Oct. 1992;39(2):99-103. [pmid: 1358722].
154 Rust OA, Place JC, Melendez D, et al. Lowering the cesarean rate at a small USAF hospital. Mil Med. Jan. 1993;158(1):22-6. [pmid: 8437736].
155 Pridjian G, Hibbard JU, Moawad AH. Cesarean: changing the trends. Obstet Gynecol. Feb. 1991;77(2):195-200. [pmid: 1988880].
156 Kiwanuka AI, Moore WM. Influence of audit and feedback on use of caesarean section in a geographically-defined population. Eur J Obstet Gynecol Reprod Biol. Jun. 1993;50(1):59-64. [pmid: 8365537].
157 Robson MS, Scudamore IW, Walsh SM. Using the medical audit cycle to reduce cesarean section rates. Am J Obstet Gynecol. 1996;174(1):199-205. [pmid: 8572006].
158 Lagrew DC Jr., Morgan MA. Decreasing the cesarean section rate in a private hospital: success without mandated clinical changes. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):184-91. [pmid: 8572004].
159 Sloan NL, Pinto E, Calle A, et al. Reduction of the cesarean delivery rate in Ecuador. Int J Gynaecol Obstet. Jun. 2000;69(3):229-36. [pmid: 10854864].
160 Studnicki J, Remmel R, Campbell R, et al. The impact of legislatively imposed practice guidelines on cesarean section rates: the Florida experience. Am J Med Qual. Spring. 1997;12(1):62-8.
161 Liang WH, Yuan CC, Hung JH, et al. Effect of peer review and trial of labor on lowering cesarean section rates. J Chin Med Assoc. Jun. 2004;67(6):281-6. [pmid: 15366405].
162 Maher CF, Cave DG, Haran MV. Caesarean section rate reduced. Aust N Z J Obstet Gynaecol. Aug. 1994;34(4):389-92. [pmid: 7848224].
163 Jamtvedt G, Young JM, Kristoffersen DT, et al. Does telling people what they have been doing change what they do? A systematic review of the effects of audit and feedback. Qual Saf Health Care. Dec. 2006;15(6):433-6. [pmid: 17142594].
164 Kongnyuy EJ, Uthman OA. Use of criterion-based clinical audit to improve the quality of obstetric care: A systematic review. Acta Obstet Gynecol Scand. 2009;88(8):873-81. [pmid: 19557553].
165 Zhang J, Troendle J, Reddy UM, et al. Contemporary cesarean delivery practice in the United States. Am J Obstet Gynecol. Oct. 2010;203(4):326 e1-e10. [pmid: 20708166].