# Methods

## Topic Development and Refinement

The topic for this report was nominated by a physician and health benefits plan/insurance carrier in a public process using the Effective Health Care Web site. Working from the nomination we drafted the initial Key Questions (KQs) and analytic framework. The KQ and analytic framework were refined with input from Key Informants representing the fields of obstetrics and gynecology, midwifery, nursing, pediatric care, primary care, and patient advocacy. After review from the Agency for Healthcare Research and Quality (AHRQ), the questions and framework were posted online for public comment. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team have any conflicts.

After reviewing the public commentary, we prepared final KQ and submitted them to AHRQ for review. The primary change in response to public comments was to broaden the terminology from “interventions” to “strategies” to more clearly indicate interest in all approaches to reduce cesarean. We identified technical experts on the topic in the fields of maternal and child health, obstetrics, nursing, and midwifery to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of obstetrics and gynecology, midwifery, nursing, pediatric care, primary care, and patient advocacy, contributed to the AHRQ's broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential customers and users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included 12 members serving as technical or clinical experts. To ensure robust, scientifically relevant work, we called on the TEP to review and provide comments as our work progressed. TEP members participated in conference calls and discussions through email to:

- Refine the analytic framework and Key Questions at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria.

## Analytic Framework

We developed the analytic framework (Figure 1) based on clinical expertise and refined it with input from our Key nformants and TEP members. The framework summarizes how strategies to reduce cesarean before and/or during labor may result in intermediate outcomes such as labor progression, maternal coping, and pain management and/or long-term outcomes such as route of birth, maternal morbidity and mortality, or neonatal morbidity. Also, adverse events may occur at any point after the strategy has been implemented.

Figure 1 Analytic framework for strategies to reduce cesarean birth

NICU = neonatal intensive care unit

Note: Numbers in circles indicate the position of Key Questions in the intervention process.

This figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates how strategies to reduce cesarean before and/or during labor may result in intermediate outcomes such as labor progression, maternal coping, and pain management and/or long-term outcomes such as route of birth, maternal morbidity and mortality, or neonatal morbidity. Also, adverse events may occur at any point after the strategy has been implemented.

## Literature Search Strategy

### Databases

We employed search strategies provided in Appendix A to retrieve research on interventions to reduce the incidence of cesarean. Our primary literature search used two databases, MEDLINE^®^ via the PubMed interface and the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^). We also hand-searched the reference lists of all included articles and relevant reviews to identify additional studies for review.

### Search Terms

Our search used a combination of keywords and controlled vocabulary terms used to represent cesarean birth in the medical, nursing, and allied health fields. To refine the search in line with our focus on randomized controlled trials (RCTs) and systems-level strategies, we employed an adapted version of the Cochrane highly sensitive search strategy.34 We also used a variety of indexing terms to exclude undesired publication types (e.g., reviews, case reports, letters) in each database.

Our searches were executed between October 2010 and February 2012. Appendix A provides our search terms and yield for each database.

## Process for Study Selection

For this review, the relevant population for all KQs were low-risk pregnant women who have a singleton pregnancy, a vertex presentation, term birth, and with no previous cesarean births.

### Inclusion and Exclusion Criteria

Table 1 lists the inclusion/exclusion criteria we selected based on our understanding of the literature, the topic-refinement phase, input from the TEP, and established principles of methodological quality.

Table 1 Inclusion and exclusion criteria

Category | Criteria
Study population | Low-risk pregnant women who have a singleton pregnancy, a vertex presentation, term birth, and no previous cesarean birth
Time period | All years
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] Randomized controlled trials of strategies (KQ1–4) Pre- and post-studies related to large-scale health systems changes (KQ2 only) [underlined: Other criteria] Original research studies that provide sufficient detail regarding methods and results to enable interpretation of the data and results Studies must include extractable data for one or more relevant outcomes listed in the PICOTS

KQ=Key Question; PICOTS=population, intervention, comparator, outcome, timing, and setting—refers to the framework used by the Effective Health Care Program to summarize study characteristics.

#### Study Population

For this review, the relevant population for all KQs was low-risk pregnant women who have a singleton pregnancy, a vertex presentation, at-term birth, and no previous cesarean births.

#### Language

We did not have translation services available to us to review non-English papers and our TEP agreed that the vast majority of the relevant literature would be published in English. Furthermore, this review is intended to inform U.S. health care, and most research in the population of pregnant women in the United States is published in English language journals. Empirical evidence on the potential for bias created by excluding non-English studies also suggests little effect.35 We did not review 170 abstracts of probable RCTs that appeared in non-English literature; based on the proportion of includes in the English language materials reviewed, this suggests we excluded fewer than five studies that could have had relevance.

#### Time Period

No time limits were set in this review. Searches were from the earliest literature currently available, 1968.

#### Sample Size

No limits on sample size were set in this review.

#### Study Design

We only reviewed published RCTs of strategies to reduce the rate of cesarean births or those pre- and post-studies related to health system changes (KQ2) to decrease the number of cesareans. In addition, studies were included if the stated or implied aim of the study was to reduce cesarean births (determined by one or more of the following criteria):

- The introduction of the paper includes a literature review of rationale, indicating interest in improving or reducing cesarean risk/rate or in influencing route of birth (vaginal, assisted, cesarean) as an outcome that would be influenced by the strategy under study.
- The stated primary or secondary aims indicate intention to examine influence of the strategy on cesarean risk/rate or route of birth.
- The analytic models indicate the authors conducted data analysis of the effect of the strategy as it relates to cesarean risk/rate or route of birth.
- The results feature data about the relationship of the strategy to cesarean risk/rate or route of birth as reporting of a primary or secondary aim.
- The tables in the results section feature data about the relationship of the strategy to cesarean risk/rate or route of birth as reporting of a primary or secondary aim.
- The discussion interprets the strategy as potentially having value for modifying cesarean risk/rates or influencing route of birth or the authors express dismay that they did not find it had value for modifying cesarean risk/rates or influencing route of birth.

## Outcomes

KQ1 through KQ3 seek to identify strategies that reduce the number and/or proportion of cesarean births between comparison groups. The intermediate outcomes include labor progression, need for augmentation, onset of maternal morbidity, and maternal coping and pain management. The final outcomes of most interest include route of birth (comparing number and/or proportion of cesarean births to those that are spontaneous and assisted vaginal). Additional final outcomes included maternal and neonatal morbidity and mortality, Apgar scores, NICU admission, maternal satisfaction, maternal-infant bonding, and breastfeeding success.

KQ4 seeks to identify any adverse effects resulting from the use of strategies to reduce cesarean birth. Adverse effects include onset of maternal morbidity, need for additional intervention, and fetal distress.

### Screening of Studies

Once we identified articles through the electronic database searches, review articles, and bibliographies (discussed above), we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated each abstract for inclusion or exclusion, using an Abstract Review Form (Appendix D). If at least one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it for full text assessment.

Two reviewers independently assessed the full text of each included study using a standardized form (Appendix D) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a third-party adjudicator. The group of abstract and full text reviewers included expert clinicians and health services researchers.

### Data Extraction and Data Management

Evidence tables, jointly developed and tested by the team, were used as data extraction tools. All data were extracted by one team member and checked by a second. Evidence tables collected descriptive information related to the strategy used to reduce cesarean birth as well as key study design and comparator data. When possible to identify, analyses resulting from the same study were grouped into a single evidence table. The final evidence tables are presented in their entirety in Appendix C.

### Individual Study Quality Assessment

We followed the methods outlined in the Evidence-based Practice Centers' (EPC) Methods Guide for Effectiveness and Comparative Effectiveness Reviews36 and the Cochrane Handbook for Systematic Reviews of Interventions37 to assess the quality of individual RCTs. Decision rules regarding application of the tools were developed a priori by the research team. We developed separate quality assessment approaches for RCTs and the pre- and post-studies related to large-scale health-systems changes studies. Two reviewers independently assessed each study, with disagreements between assessors resolved by a third adjudicator. For all RCTs we assessed each of the following domains, using the Cochrane Risk of Bias (ROB) tool, as having “low risk,” “high risk,” or “unclear risk” of bias:

- Selection bias
  ○ Random sequence generation
  ○ Allocation concealment
- Performance bias
  ○ Blinding of participants and personnel
- Detection bias
  ○ Blinding of outcome assessment
- Attrition bias
  ○ Incomplete outcome data
- Reporting bias
  ○ Selective reporting
- Other bias
  ○ Other sources of bias

We used the Newcastle-Ottawa Quality Assessment Scale (NOQAS) to assess the quality of all nonrandomized studies (pre- and post-studies). This scale assesses three broad perspectives: the selection of study groups, the comparability of study groups, and the ascertainment of the outcome of interest. We describe the individual quality components below and report individual quality assessments for each study in Appendix E.

#### Determining Risk of Bias Levels

For RCTs, according to the criteria determined by Cochrane, we considered a “low-risk” of bias study as one that had low-risk of bias for all domains.37 We considered studies that were assessed to have unclear risk of bias for one or more key items as having “unclear risk” of bias. Studies with a high risk of bias for one or more domains were considered to have a “high risk” of bias.

## Data Synthesis

There was significant heterogeneity among studies reporting results of strategies to reduce cesarean birth, including heterogeneity of population inclusion criteria, heterogeneity of strategy, and heterogeneity of outcome measures. Therefore, it was not appropriate to perform meta-analysis.

## Strength of Evidence for Each KQ

We evaluated the overall strength of the evidence for the primary outcome of reduction of cesarean use for each category of strategy. We used the approach to strength of evidence as described in the EPCs' Methods Guide for Effectiveness and Comparative Effectiveness Reviews.36, 38

We examined the following four major domains using a standardized strength of evidence evaluation sheet with scoring algorithm (Appendix G):

- risk of bias (low, medium, or high),
- consistency of findings (inconsistency not present, inconsistency present, or unknown or not applicable),
- directness (direct comparison of influence on outcomes in RCT, or indirect information from observational research), and
- precision (precise or imprecise based on outcomes rates, size of the individual studies and the total number of women in the studies for the category of strategy).

The key outcome for each category of strategy in the body of literature was use of cesarean.

The overall strength of evidence could be graded as “high” (indicating high confidence that the evidence reflects the true effect and further research is very unlikely to change our confidence in the estimate of effect); “moderate” (indicating moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate); “low” (indicating low confidence that the evidence reflects the true effect and further research is likely to change our confidence in the estimate of effect and is likely to change the estimate); or “insufficient” (indicating that evidence is either unavailable or does not permit estimation of an effect). These overall grades resulted from use of the scoring algorithm.

Strength of evidence was applied both to evidence of benefit and to evidence of lack of benefit. This means for instance that for a category of strategy in which there are multiple studies, with moderate bias and direct evidence showing no effect, and a single study reporting a insignificant reduction, the body of literature for the category of strategy could be scored as low evidence of lack of benefit. Two reviewers independently graded the body of evidence and calculated assigned strength of evidence using the scoring algorithm; disagreements were resolved through discussion or a third reviewer adjudication.

## Applicability

Finally, it is important to consider the ability of the findings to apply both to other populations and to other settings. Our assessment of applicability included determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each strategy category (Appendix F).

## Peer Review and Public Commentary

Experts were invited to provide external peer review. The draft report was posted for four weeks to elicit public comment. We addressed all reviewer comments by revising the text as appropriate. We responded to each comment submitted from peer and public review in a disposition of comments report. This report will be available on the AHRQ Web site 3 months after the posting of this final CER.