# Introduction

## Background

Thirty-two percent of pregnancies in the United States conclude with a cesarean birth.1 This record high rate reflects a relative increase of 53 percent in use of cesarean from 1991 to 2007.^1^ The pattern of increasing use of cesarean has been concerning for decades, with the last decline of 2 to 3 percent occurring in the mid-1990s being fully reversed by 1999 and increasing over 50 percent from 1996 to 2007.^2^ Nearly one in three births by cesarean translates to a total of 1.4 million cesarean births each year, making cesarean the most commonly performed major surgery in the United States.1

The Joint Commission has expressed concern about U.S. cesarean birth rates in its Specifications Manual for Joint Commission National Quality Core Measures, noting that, “There are no data that higher rates improve any outcomes, yet the CS [cesarean section] rates continue to rise.”3 Cesarean birth is not without consequences. In general, cesarean is more costly to the health care system, is associated with increased risk for both mother and infant, and has the potential to complicate subsequent pregnancies.4-5 Previously extraordinarily rare complications like uterine rupture and abnormalities in placental attachment to the uterus, such as placenta accreta and percreta, are becoming more common modern obstetric care challenges.6-7 Uterine rupture occurs along the scar line of a prior cesarean and susceptibility is believed to result from relative weakness of the uterine wall at the point of scarring. Placenta accreta and percreta result when placental implantation occurs over or adjacent to scarring and the placenta invades the uterine muscle more deeply. This is believed to occur because the scarred tissue from prior cesarean has a less robust blood supply and abnormal architecture at the tissue and cellular level. Indeed, because the effects of these complications can be devastating and include fetal death, emergent hysterectomy and maternal mortality from associated bleeding, labor and delivery units have increased the use “code teams” that conduct practice drills to be prepared for such emergencies.

Cesarean birth rates vary considerably by geographic region, ranging from 25 to 38 percent among different states with the highest rates in the southeastern United States.1 One research group examining differences across hospitals documented a span from 9 percent to 37 percent for primary cesarean births.8 While health care providers and health systems initially viewed such variation as a reflection of underlying differences in the risk profile of the women receiving care at the hospitals, it has become increasingly clear, through use of techniques like risk adjustment, that a large proportion of variation is real. It is not explained by some facilities having much higher or lower risk patients than others. In medical care, when there is variation of the magnitude we see in use of cesarean after taking into account differences in patient characteristics, the conclusion is that provider preferences, and to a lesser extent patient preferences are important drivers of variation.9-12

Goals for reducing cesarean in the United States have become less ambitious over time. The Healthy People 2000 goal was to reduce cesarean to 15 percent of all births.13 For Healthy People 2010 this goal was revised to 15 percent among women who had not had a prior cesarean, and in Healthy People 2020 the new target for cesarean among low-risk women in a first pregnancy with full-term singleton pregnancies and vertex presentation is 23.9 percent.14-15 The moving target for both numerator and denominator in these goals reflects ambivalence in knowing what the right rate is for optimal maternal and infant outcomes and doubts about what interventions can safely reduce use of cesarean.16-17

Commentary on the factors driving change in cesarean use have been robust. Putative influences include:

- Changes in reimbursement for births that favor interventions like cesarean18
- Amplified perception of risk of medico-legal liability claims for less than perfect infant outcomes or for failing to intervene19
- Shifts in consumer attitude that include less fear of or regret about cesarean20
- Lower psychosocial or emotional value placed on the experience of vaginal birth21
- Concerns about pelvic floor damage and future continence22-23
- Maternal desire for greater control over the timing and circumstances of birth24 such as maternal request for elective induction and cesarean.25

Research has addressed predictors of cesarean such as the shift toward older maternal age, higher body mass index, greater maternal comorbidity, use of assisted reproductive technology, and increased incidence of multiple gestations.26-27

Nonetheless relatively little focus has been placed on research specifically designed to assess strategies to reduce use of cesarean. The notable exception is a study of approaches to promote trial of vaginal birth after prior cesarean (VBAC). Systematic reviews of VBAC interventions report increases in vaginal births from 6 to 70 percent with strategies to support a trial of labor.28-29 The state of general knowledge about evidence-based approaches to reduce cesarean overall is uncharted. In this review we aim to bring that literature to the forefront by systematically examining the outcomes of interventions intended to reduce use of cesarean among low-risk women.

## Objectives

The goal of this systematic evidence review is to examine the effects of available strategies to reduce cesarean birth among low-risk pregnant women who have a singleton pregnancy focusing on the following outcomes: route of birth, maternal morbidity and mortality, and neonatal morbidity and mortality.

## Strategies

Low-risk pregnant women who have a singleton pregnancy, with a vertex presentation, at term, and no previous cesarean births are the focus of this review. Studies assessed strategies implemented specifically with the goal of reducing cesarean birth, including strategies used during prenatal care, during labor, and as part of health systems strategies (quality assurance, audit and feedback, implementation of guidelines, etc.).

During prenatal care

- Antenatal care models
- Exercise training
- Management of fear of childbirth
- Induction of labor for women at risk for cesarean
- Structured education for pushing
- Hyaluronidase injection in cervix

During labor

- Early labor assessment
- Midwifery-led care
- Measurement of labor progress
- Active management of labor
- Management of abnormal labor
- Amniotomy (surgical rupture of fetal membranes)
- Increased intravenous fluids
- Psychosocial support, including doulas
- Pain management
- Fetal assessment
- Amnioinfusion
- Unique strategies, including acupuncture and devices

## Goal of This Comparative Effectiveness Review (CER)

The overall goal of this CER is to inform clinician and patient decisions about the strategies that could be used to reduce cesarean births. This CER summarizes evidence for the effectiveness of strategies before and during labor to prevent a birth by cesarean. We also address any adverse effects of strategies employed by pregnant women or their health care providers as reported in the literature. “Adverse effects” are defined by the Evidence Based Practice Center program as the totality of all possible adverse consequences of an intervention.30 We also sought not to duplicate efforts of other recent AHRQ reviews including vaginal birth after cesarean, maternal request for cesarean, and elective induction.31-33

### Scope and Key Questions

#### Scope of the Report

Evidence reviews of interventions seek to identify and systematically summarize objective information about the evidence related to factors including the:

- Effectiveness of specific strategies
- Relative benefit of one strategy over another
- Common side effects and serious risks of a strategy

We focused this review on strategies to reduce cesarean birth in low-risk pregnant women who have a singleton pregnancy, a vertex presentation, term birth, and no previous cesarean births.

#### Key Questions

We have synthesized evidence in the published literature to address the following Key Questions (KQs):

KQ1 What strategies during pregnancy are effective to reduce the use of cesarean birth among women with a singleton pregnancy, who are intending a vaginal birth?
KQ2 What strategies during labor are effective to reduce the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?
KQ3 Where head-to-head comparisons are available, what strategies are shown to be superior in reducing the use of cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?
KQ4 What are the nature and frequency of adverse effects resulting from strategies used to reduce cesarean birth among women, with a singleton pregnancy, who are intending a vaginal birth?

## Organization of This Evidence Report

The Methods section describes our processes including our search strategy, inclusion and exclusion criteria, approach to review of abstracts and full publications, and methods for extraction of data into evidence tables, and compiling evidence. We also describe our approach to grading the quality of the literature and to describing the strength of the body of evidence.

The Results section presents the findings of the literature search and the review of the evidence by KQ, synthesizing the findings across strategies. We have organized the sections to (1) summarize the number and crucial descriptors of studies; (2) note the quality of studies; (3) summarize the number of studies that identified benefits of the intervention out of the total; (4) describe interventions that were effective in more detail; and note (5) the overall strength of evidence for an intervention.

The final section of the report discusses the results and enlarges on the methodologic considerations relevant to each KQ. We also outline the current state of the literature and challenges for future research on the strategies to reduce cesarean birth. In addition, we have produced a companion piece to this evidence review: Future Research Needs for Strategies To Reduce Cesarean Birth in Low-Risk Women (Future Research Needs Paper No. 22). Information was gathered from multiple stakeholders, including obstetricians, family physicians, midwives, insurers, advocacy groups, and individual women, and a system of information gathering and surveys was used to prioritize the research most urgently needed.

The report includes a number of appendixes to provide further detail on our methods and the studies assessed. The appendixes are as follows:

- Appendix A: Search Strategy
- Appendix B: List of Excluded Studies
- Appendix C: Evidence Tables
- Appendix D: Data Extraction Forms
- Appendix E: Quality of the Literature
- Appendix F: Applicability Summary Tables
- Appendix G: Strength of the Evidence Calculator
- Appendix H: Summary PICOTS table

We also include a list of abbreviations and acronyms at the end of the report.

## Uses of This Report

We anticipate this report will be of value to all health care providers who take care of women of childbearing age, including members of the American Congress of Obstetricians and Gynecologists; the Association of Women's Health; Obstetric and Neonatal Nurses; the American College of Nurse-Midwives; the American Academy of Family Physicians; the National Association of Nurse Practitioners in Women's Health; and other clinical professional organizations. In addition, this review will be of use to the National Institutes of Health, Centers for Disease Control and Prevention, Centers for Medicare and Medicaid Services, and the Health Resources and Services Administration—all of which have offices or bureaus devoted to women's health issues. In conjunction with existing reviews on related topics such as vaginal birth after cesarean, maternal request for cesarean, and elective induction, this report can bring providers up to date about the current state of evidence, and it provides an assessment of the quality of studies that aim to determine the effectiveness of strategies to reduce cesarean birth.31-33 It will be of interest to individual women and the general public because of the continuing increase in cesarean births, and the recurring need for women and their health care providers to make the best possible decisions and choices from among numerous options. We also anticipate it will be of use to private sector organizations concerned with women's health, such as Childbirth Connection, the March of Dimes, the National Women's Health Network, and Our Bodies Ourselves, as well as childbirth education organizations and professionals.

Researchers can obtain a concise analysis of the current state of knowledge in this field. They will be poised to pursue further investigations that are needed to advance research methods, understand risk factors, develop prevention strategies, develop new treatment options, and optimize the effectiveness and safety of clinical care for low-risk women.