# Peer Reviewers

Jennifer Bailit, M.D., M.P.H.

Director, Labor and Delivery

Associate Professor, Case Western Reserve University School of Medicine

Cleveland, OH

Mark Deutchman

Professor, School of Medicine Department of Family Medicine & School of Dental Medicine

University of Colorado

Aurora, CO

Sharon L Dooley, M.D.

Albert B. Gerbie, M.D., Professor of Obstetrics and Gynecology

Professor in Obstetrics and Gynecology-Maternal Fetal Medicine

Northwestern University Feinberg School of Medicine

Chicago, IL

Janice Gomersall, M.D.

Medicaid Medical Directors Learning Network

Mountain View Family Medical & Obstetrics & Gynecology

Missoula, MT

Heidi Gullett, M.D., M.P.H.

Department of Family Medicine

Oregon Health and Science University

Portland, OR

Andra H. James, M.D.

Division of Maternal and Fetal Medicine, Departments of Obstetrics and Gynecology and Medicine

Duke University

Durham, NC

Valerie King, M.D., M.P.H.

Clinical Epidemiologist, Center for Evidence-based Policy

Associate Professor, Department of Family Medicine

Oregon Health & Science University

OHSU School of Medicine

Portland, OR

Lawrence Leeman, M.D.

Associate Professor

Department of Obstetrics and Gynecology

University of New Mexico Health Sciences Center

Albuquerque, NM

Audrey Lyndon, R.N.C., Ph.D., C.N.S.

Assistant Professor, Department of Family Health Care Nursing

University of California, San Francisco

San Francisco, CA

Howard Minkoff, M.D.

Professor, Obstetrics and Gynecology SUNY-Brooklyn

Maimonides Medical Center

Brooklyn, NY

Amy Romano, M.S.N., C.N.M.

Associate Director of Programs

Childbirth Connection

New York, NY

Sharon Schindler Rising, C.N.M., M.S.N.

Executive Director, Centering Healthcare Institute, Inc.

Cheshire CT

James R. Scott, M.D.

Editor-In-Chief, Obstetrics and Gynecology Professor and Chair Emeritus, Department of Obstetrics and Gynecology

University of Utah Health Care

Salt Lake City, UT

Caroline Signore, M.D., M.P.H.

Medical Officer, Obstetrics

Program Scientist, PASS Network

Pregnancy and Perinatology Branch, Center for Developmental Biology and Perinatal Medicine

Eunice Kennedy Shriver National Institute of Child Health and Human Development

Bethesda, MD

John Thorp, Jr., M.D.

Division Director, Professor University of North Carolina at Chapel Hill

Chapel Hill, NC