# Key Informants

Sean C. Blackwell, M.D.

Associate Professor, Vice Chair for Clinical Research

Director, Larry C. Gilstrap, M.D., Center for Perinatal and Women's Health Research University of Texas Health Science Center at Houston

Houston, TX

Hugh Ehrenberg, M.D.

Associate Professor, Clinical, Obstetrics & Gynecology

Ohio State University Medical Center

Columbus, OH

Janice Gomersall, M.D.

Medicaid Medical Directors Learning Network

Mountain View Family Medical & Obstetrics & Gynecology

Missoula, MT

Tekoa King, C.N.M., M.P.H.

Clinical Professor, Department of Obstetrics, Gynecology, and Reproductive Sciences

University of California, San Francisco

Deputy Editor, Journal of Midwifery & Women's Health

San Francisco, CA

Valerie King, M.D., M.P.H.

Clinical Epidemiologist

Center for Evidence-based Policy

Associate Professor, Department of Family Medicine

Oregon Health & Science University

OHSU School of Medicine

Portland, OR

Audrey Lyndon, R.N.C., Ph.D., C.N.S.

Assistant Professor, Department of Family Health Care Nursing

University of California, San Francisco

San Francisco, CA

Howard Minkoff, M.D.

Professor, Obstetrics and Gynecology SUNY-Brooklyn

Maimonides Medical Center Brooklyn, NY

Sharon Schindler Rising, C.N.M., M.S.N.

Executive Director, Centering Healthcare Institute, Inc.

Cheshire, CT

James R. Scott, M.D.

Editor-In-Chief, Obstetrics and Gynecology

Professor and Chair Emeritus, Department of Obstetrics and Gynecology

University of Utah Health Care

Salt Lake City, UT

Caroline Signore, M.D., M.P.H.

Medical Officer, Obstetrics

Program Scientist, PASS Network

Pregnancy and Perinatology Branch, Center for Developmental Biology and Perinatal Medicine

Eunice Kennedy Shriver National Institute of Child Health and Human Development

Bethesda, MD

Robert M. Silver, M.D.

Professor, Division Chief of Maternal-Fetal Medicine

Department of Obstetrics and Gynecology

University of Utah Health Sciences Center

Salt Lake City, UT

Catherine Y. Spong, M.D.

Chief, Pregnancy and Perinatology Branch

Eunice Kennedy Shriver National Institute of Child Health and Human Development

Bethesda, MD

John Thorp, Jr., M.D.

Division Director, Professor

Department of Obstetrics and Gynecology

University of North Carolina at Chapel Hill

Chapel Hill, NC