# Discussion

## State of the Literature

We identified 6,107 nonduplicate publications through the search process, with 1,025 proceeding to full text review (Figure 2). Ninety-seven publications were included, 68 randomized controlled trials (RCTs) and 29 pre-post studies of large scale health systems changes, representing 96 distinct study populations. Using uniform criteria for assessment we found 16 of these studies to be good quality; 28 fair; and 53 poor. The most common reasons for exclusion were irrelevance to the topic and ineligible study design. Nine articles pertain to Key Question (KQ) 1, 88 articles to KQ2, no articles to KQ3, and 18 articles to KQ4. Few strategies have been studied in more than three trials. Most included trials were the only randomized study of the strategy.

## Summary of Outcomes by KQ

### KQ1 Strategies During Pregnancy

Collaborative consistent midwifery care during pregnancy and in labor, compared to conventional care, reduced cesarean births by 4.5–11.1 percent in two RCTs. No difference was reported in two similar studies. Outpatient injection of hyaluronidase into the cervix, in patients at term with a low Bishop score, decreased cesarean births by 31 percent (from 49% to 18%) in a single Brazilian study. No other studies were found that repeated evaluation of this or other agents for cervical ripening as a means to prevent cesarean. Light exercise, intervention to reduce fear of labor, education about how to push in labor, and pre-emptive management of specific risks detected during antenatal care were among the ineffective outpatient strategies. Each of these strategies was represented by only one study.

### KQ2 Strategies During Labor

#### Management of Labor

The only labor management strategies found to significantly reduce use of cesarean were seen in individual trials of (1) administration of propranolol concurrent with oxytocin for dysfunctional labor treatment, (2) use of a partogram with an active management protocol, and (3) use of a 4-hour partogram compared with a 3-hour partogram, meaning more time was taken to assess/restore labor progress (see Table 2). However, these findings were often not replicated in similar strategies. A second study did not find a significant reduction in the use of cesarean when propranolol and oxytocin were used for similar indications. Adding a partogram to standard written labor progress notes was not effective. Cesarean rates with two-hour and four-hour partograms were equivalent. Providing an individualized, computer-generated reference range for assessing labor progress did not reduce the use of cesarean. Active management of labor was evaluated in six studies and did not reduce the use of cesarean.

Other strategies included home-based triage, which when compared with telephone triage, did not reduce the use of cesarean. Early labor assessment to delay hospital admission until active labor, compared with direct admission of women in labor, did not reduce the use of cesarean. Care in a midwife-led unit did not reduce the use of cesarean compared to a normal unit and special unit. Cesarean rates were identical in women who did and did not have amniotomy at the time of hospital admission. Increased intravenous fluids did not reduce the use of cesarean. An oral carbohydrate solution increased the use of cesarean.

#### Psychosocial Support

Seven studies investigated potential benefits of psychosocial support in labor. One study was assessed as being fair quality and the remaining six studies were poor quality. Three doula support interventions reduced cesarean births. Women who had doula support had five to 22 percent fewer cesareans. In contrast to trained doulas, there were no significant differences in cesarean use for women who received labor support from trained female friends or family members, nurses, or midwifery students compared to women who received usual labor care.

#### Pain Management

We identified seven trials of pain management that aimed to reduce cesarean. One study was assessed as being good quality; two were fair quality; and four were poor quality. A single study, judged to be of poor quality due to the lack of description of the randomization allocation and concealment procedures, reported almost a threefold reduction in cesarean rates for women who received intermittent epidural (5%) as compared to continuous epidural (15%, p=0.03).49 A larger good quality study that compared high versus low dose epidural reported significantly fewer instrumental births (vacuum extraction and cesarean) in women who received the lower dose of analgesia (30% compared with 49% in the high dose group, p<0.00001).63 The cesarean rates for the two groups were 10.2 percent and 14.7 percent for the low and high dose respectively, but no statistical analysis was reported. None of the remaining five studies reported a significant difference in use of cesarean. These studies varied in quality, sample size, comparison of anesthetics used, parity of the study population, and overall rate of cesarean birth. None examined the same intervention.

#### Fetal Assessments

Of six studies investigating means to improve assessment of fetal status, one was good quality with five being of fair quality. Three of four studies investigating use of fetal pulse oximetry demonstrated a significant reduction in cesarean performed for fetal distress. Reduction in cesareans performed for fetal distress ranged from 5.7 to 24.6 percent however, knowledge of intrapartum fetal oxygen saturation did not have a significant effect on overall use of cesarean. Fetal pulse oximetry did not slow or interfere with labor, nor did it result in an increase in adverse maternal, fetal, or neonatal outcomes. Use of ST analysis in conjunction with FHR monitoring did not reduce cesarean rates overall, nor cesarean rates for non-reassuring fetal heart tracing when compared to routine FHR monitoring alone. In total, of the six studies only reported significant reduction in overall cesarean use.

#### Amnioinfusion

Eight studies investigated amnioinfusion as an intervention for fetal benefit that could prevent cesarean. Four studies were assessed to be of fair quality with the remaining four being poor quality. Three of eight studies found a significant reduction in cesarean use. While amnioinfusion did not consistently lead to a reduction in overall cesarean rates when performed for concerning fetal heart tracings, four of eight studies did show a significant reduction in cesareans performed for suspected fetal distress. Amnioinfusion for moderate or heavy meconium, when performed in under-resourced hospital settings where electronic monitoring was limited or absent, improved neonatal outcomes. Prophylactic amnioinfusion for oligohydramnios without fetal distress did not reduce use of cesarean. Amnioinfusion did not increase maternal or neonatal morbidity, mortality, or complications. It appears to be simple, safe, and relatively easy to perform and can be done even in under-resourced or underfunded hospital settings. However, in developed countries there was no evidence to support use of amnioinfusion for the specific purpose of reducing cesarean.

#### Unique Strategies

Seven studies explored the influence of various other unique strategies on the incidence of cesarean birth. Two studies were assessed to be of good quality, two were fair quality, and the remaining three were poor quality. Large single studies of walking, eating, or using an inflatable obstetric belt during labor showed no effect on the incidence of cesarean as compared with usual care. Small studies of other strategies such as acupuncture, a molded dental device, or propranolol had no effect of intervention on rates of cesarean birth when compared with standard care approaches.

#### Systems-Level Strategies

From baseline to followup, 18 of 31 studies achieved statistically significant reductions in cesarean with a range of 1.6 to 17.0 percent decreases. None of the four systems-level RCTs demonstrated effectiveness. Three were poor quality and one fair. Twelve observational studies reported achieving a reduction of 5 percent or more. More than 16 broad categories of components have been used in various combinations in these systems strategies.

Ten pre-post studies documented reductions in cesarean from implementing varied forms of auditing of trends with regular feedback of data to either the organizational unit (hospital, department, labor and delivery staff) or the individual care providers or both. Overall audit and feedback was most often provided at both the unit and individual level. These components individually or combined were the most common component of studies that reported a decrease in cesarean of 5 percent or more. Of the eight studies in which the primary intervention was audit and feedback of cesarean data (not embedded in a larger quality improvement program), five achieved a reduction of use of cesarean ranging from 7.2 to 2.5 percent. This is compatible with systematic reviews of obstetrics and general use of audit and feedback163 suggesting it is effective for changing provider behavior.164

The next most common components of successful strategies, with a 5 percent or greater reduction, were tracking of progress in labor combined with active management. Care must be taken in interpretation because similar components were used in strategies that were associated with decreased rates of cesarean and with unchanged or worse rates.

Caution must be used in interpreting this literature. Both trials and observational studies have limitations in assuring the intervention is the cause of change, or lack of change, in cesarean use. To be a site of a randomized trial, at minimum, the leadership of units involved were invested in the importance of research on reducing cesarean and willing to participate in a study about how best to accomplish that goal. In the included randomized studies, trial assignment could not possibly be masked at all levels-sites would have been able to infer their status. Sites not assigned to implement the study protocol, or to delay, may nonetheless have galvanized inclinations to reduce cesarean and have informally, even unwittingly, initiated changes over multi-year followup periods that reduced cesarean to a degree. If this effect were at work the trials would be biased towards the null meaning they were less likely to detect an effect of intervention.

Especially in pre-post studies, determining with confidence what components are crucial in decreasing cesarean is challenging. As an illustration of the difficulty of determining the importance of specific components, consider Table 32 as an example. This table presents the same analysis of components of strategies as that in Table 31 which features successful strategies in the United States. This table compiles the data for the seven studies in the United States that showed either no benefit or that the strategy was worse than control or baseline. Overall, these less successful strategies included fewer components with the exception of the study that had 10 of the 16 categories we examined. The components used however, overlap with those incorporated into systems-level strategies that had greater effects. In short, there does not appear to be a guaranteed “active component” or threshold number of components that is consistently associated with the desired result of fewer cesareans.

It is possible that the ability to change rates is related to the novelty of the concept that it is possible to exert influence at a systems-level. Some have suggested that the window may be closing in which health care systems are willing to focus efforts on decreasing annual cesarean rate or on improving trends in specific categories of indication for cesarean. In this instance earlier studies would be expected to have greater effect. Including all 33 publications, so that followup data are reflected in the proper timeframe, no clear secular trend is apparent in the outcomes of grouped by calendar time:

- The two strategies published before 1990, significantly reduced cesarean by almost 2 and 6 percent.145, 151
- From 1990 up to 1995, there were 14 reports of which seven reported a significant decrease in cesarean.142-144, 152, 154, 156, 162
- From 1995 up to 2000, there were eight studies of which four reported a significant decrease.158 157 146 140
- In 2000 and after, four of nine reported a significant decrease.94, 134, 159, 161

Neither year of publication nor year of intervention initiation was correlated with effect size.

Similarly, it has been proposed that sites with higher rates of cesarean will experience a greater urgency to reduce that rate or simply that a higher baseline allows greater potential to accomplish decreases in cesarean. We did not find this to be a strong effect. When the baseline cesarean rate for all included studies is plotted against the achieved reduction in cesarean, baseline is modestly correlated (r=0.44, with r^2^=0.19) with the absolute magnitude of reduction in cesarean. However, this contribution is far from suggesting there are sites with rates that make them destined to succeed or doomed to failure.

Seventeen of 31 (55%) of these studies achieved reduction in cesarean that was statistically distinct from their baseline rate. Eleven reduced the rate of cesarean by an absolute amount of 5 percent or more. Since the trend in almost all of these study settings has been for cesarean rates to rise, this suggests that systems-level strategies can contribute to “bending the curve” and reducing or perhaps holding steady the proportion of women who give birth by cesarean. Which components are effective at doing this is unclear.

### KQ3 Head-to-Head Comparisons

All studies compared the novel strategy to usual care or to a variation on the same strategy. We did not identify comparisons of distinctive strategies, for instance doula support versus active management of labor, or pain management strategies compared to fetal monitoring strategies. Several comparisons evaluated different approaches to the same strategy like different approaches to epidural dosing or to monitoring progress of labor. These comparisons of variations on like strategies are noted in the sections that discuss those interventions. For now, there is no evidence to inform prioritization of one type of intervention to another.

### KQ4 Adverse Effects of Strategies

Few of the adverse effects presented have a direct relationship to the strategy used to prevent cesarean birth. The adverse effects most commonly systematically collected by authors included maternal fever, nausea/vomiting, and anesthesia-related side effects. Where devices were used that were introduced into the uterus there was not compelling evidence of increased risk for infection. Some strategies like amnioinfusion were associated in some studies with significant improvements in neonatal outcomes. Many of the studies included in this review, such as those related to psychosocial support have no known adverse effects.

## Strength of the Evidence for Effectiveness of Strategies

### Overview

Overall the strength of evidence to answer the KQs was insufficient to low (Table 34 and Appendix G). Deficiencies in the strength of evidence most often related to:

- High proportion of strategies that were represented by only one study which prevents determination of consistency of findings across studies and populations.
- Preponderance of study designs with high risk of bias in part because means to mask participants and providers to status is challenging.
- Underpowered studies that did not enroll sufficient participants to properly evaluate cesarean as an outcome though reducing cesarean was a stated aim.
- Inconsistent findings across studies; for all strategies in which there was more than one RCT, there was not consistent demonstration of effectiveness.
- Inconsistent selection and definition of outcomes; studies did not consistently report total cesarean, primary cesarean, and repeat cesarean (when applicable).
- Operational definitions of indications for cesarean are incompatible across studies so that these outcomes cannot be aggregated across studies.

In the table that follows we provide strength of evidence ratings grouped by strategies (where applicable) within KQ (Appendix G).

Table 34 Strength of evidence for various strategies to reduce cesarean birth

Strategy n Total Studies (n Total Participants) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
KQ1. Effectiveness of Strategies During Pregnancy to Reduce Cesarean Birth (n=9)
Antenatal Care Model 4 (4,337) | Moderate | Inconsistent | Direct | Imprecise | Insufficient; 3 fair-quality studies , 1 poor-quality study
Exercise training 1 (160) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
Management of fear of childbirth 1 (176) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 poor-quality study
Induction of labor for at-risk 1 (270) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
Education on pushing 1 (100) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
Hyaluronidase 1 (168) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
KQ2. Effectiveness of Strategies During Labor to Reduce Cesarean Birth
Management of Labor (n=21)
Early labor assessment 2 (1,668) | Moderate | Inconsistent | Direct | Imprecise | Insufficient; 2 fair-quality studies with conflicting findings
Midwife-led unit 1 (1,111) | High | N/A | Direct | Imprecise | Insufficient; 1 poor-quality study
Measurement of labor progress 4 (10,823) | Moderate | Inconsistent | Direct | Imprecise | Low strength of evidence for lack of benefit; 2 good-quality studies, 1 fair-quality and 1 poor-quality study
Active management of labor 6 (5,330) | Moderate | Inconsistent | Direct | Imprecise | Low strength of evidence for lack of benefit; 2 good-quality studies, 2 fair-quality studies
Management of abnormal labor 5 (2,764) | Moderate | Inconsistent | Direct | Imprecise | Insufficient; 2 good-quality studies, 2 fair-quality studies, 1 poor-quality study
Amniotomy 1 (128) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
Increased IV fluids 1 (195) | Low | N/A | Direct | Imprecise | Insufficient; 1 good-quality study
Oral carbohydrate solution 1 (201) | Moderate | N/A | Direct | Imprecise | Insufficient; 1 fair-quality study
Psychosocial Support (n=7)
Doula support 3 (1,136) | High | Consistent | Direct | Precise | Low strength of evidence for benefit; 3 poor-quality studies
Trained friend or family as labor support 1 (598) | High | N/A | Direct | Imprecise | Insufficient; 1 poor-quality study
Nursing and midwifery student support 3 (7,568) | High | Consistent | Direct | Imprecise | Low strength of evidence for lack of benefit; 2 poor-quality and 1 fair-quality studies
Pain Management (n=7)
Pain management 7 (5,525) | Moderate | Inconsistent | Direct | Imprecise | Low strength of evidence for lack of benefit; 4 poor-quality studies, 2 fair-quality studies, 1 good-quality study
Fetal Assessment (n=6)
Fetal pulse oximetry 4 (7,098) | Moderate | Inconsistent | Direct | Imprecise | Low strength of evidence for lack of benefit; 1 good-quality study, 3 fair-quality studies
Fetal assessment by STAN 2 (2,271) | Moderate | Consistent | Direct | Imprecise | Low or moderate evidence for lack of benefit; 2 fair-quality studies
Amnioinfusion (n=8)
Amnioinfusion for fetal distress 2 (588) | High | Inconsistent | Direct | Imprecise | Insufficient; 1 fair-quality and 1 poor-quality study
Amnioinfusion for meconium 5 (1,565) | High | Inconsistent | Direct | Imprecise | Insufficient; 3 poor-quality and 2 fair-quality studies
Amnioinfusion for oligohydramnios 1 (60) | High | NA | Direct | Imprecise | Insufficient; 1 fair-quality study
Unique Strategies (n=7)
Other strategies (acupuncture) 2 (145) | High | Inconsistent | Direct | Imprecise | Insufficient; 2 fair-quality studies
Dental device 1 (64) | High | N/A | Direct | Imprecise | Insufficient; 1 poor-quality study
Allowing eating 1 (2,426) | Low | N/A | Direct | Precise | Insufficient; 1 good-quality study
Inflatable obstetric belt 1 (500) | Low | N/A | Direct | Imprecise | Insufficient; 1 good-quality study
Unique Strategies (n=7)
Propranolol 1 (57) | High | N/A | Direct | Imprecise | Insufficient; 1 poor-quality study
Allowing walking 1 (916) | High | N/A | Direct | Precise | Insufficient; 1 poor-quality study
Systems-Level Strategies (n=33)
Systems-level strategies 33 | High | Inconsistent | Indirect | Precise | Insufficient
KQ4. Adverse Effects of Strategies to Reduce Cesarean Birth
Adverse effects 18 (14,075) | Moderate | Inconsistent | Indirect | Imprecise | Insufficient; fair- to poor-quality studies with inconsistent reporting of multiple adverse events

N/A=not applicable

* See Methods for more detail about grading strength of evidence. Assessment of insufficient evidence often resulted from single trials or small numbers of studies with combinations of high risk of bias, inconsistent results, and poor precision. The latter often resulted from relatively limited power of individual or aggregated studies to accurately estimate the effect. Low strength of evidence for lack of benefit was most commonly assigned in the setting of moderate to low risk of bias and larger studies in which the predominance of the literature found no benefit but a single study reported reduction in cesarean.

## Applicability

Studies included in the review were selected to provide data that is relevant to the care of low-risk, term pregnant women. Applicability describes the extent to which study population, interventions, and outcomes in this literature apply to that target group. In this report, the study populations were predominantly low-risk pregnant women at term with a singleton pregnancy, a vertex presentation, and no previous cesarean birth. However, eligibility criteria and participant characteristics were not always clearly described in detail. Some studies that recruited from among laboring women included a proportion of women with multiple gestations, complications of pregnancy, and prior pelvic surgery or cesarean, not meeting the criteria of low-risk.

In these instances the studies reflected the base population of women seeking care in the setting in which the study was done and who were intending vaginal births. We did not include studies focused only on high-risk populations. More than half of the studies were conducted outside the United States and differences in the health systems, homogeneity of the population, and prevailing rates of cesarean are important to note. While we attempted to restrict the review to trials conducted in settings with clinical care settings similar to the United States, this was likely not the case in all instances. Even developed westernized countries may deploy medical resources and have patterns of care that dramatically differ from those in the United States. It is important to note that applicability for guiding care for women in the United States is best served by relatively contemporary U.S. data because cultural norms and health systems factors mitigate against international studies fully capturing the context of care and populations in the United States.

Strategies varied widely with most not being replicated in more than one study. All of the strategies evaluated were of potential utility to the target population for the report. Likewise the comparison group for the RCTs was standard care, which with the exception of international settings with limited resources, is becoming increasingly similar around the globe. Where distinct differences such as midwifery based care or lack of use of electronic monitoring are the norm, we have called attention to this in order to alert the reader to limitations in applicability. Fortunately the outcome of interest—cesarean—is readily measured with accuracy and would not be expected to differ in ways that would affect applicability with the exception of classification of reasons for cesarean which has high variability even among individual providers within the same facilities.

A particular challenge that is difficult to assess is the influence of baseline use of cesarean prior to initiation of the strategy to reduce cesarean. It is likely that the difficulty of changing rates is greater when use is already low. For this reason we have presented the proportion of births in the usual care arms of trials and the baseline data for systems intervention studies. While strategies may well be applicable across setting regardless of how low or high the initial use of cesarean is, it makes this literature more challenging to interpret. In particular, while there is no a priori reason to believe that strategies that work in settings that have low cesarean use could not work in settings with higher use, we recognize that it is harder to dismiss the potential for benefit of a strategy in a higher use setting that did not provide statistically meaningful reductions in a low use setting.

In summary, constraints for applicability are easily identified in this literature and the reader will generally be able to understand any differences in the study setting and their setting. The primary hindrance is the lack of clear evidence to apply. No clearly effective means of decreasing cesarean in the target population emerged from the synthesis of the evidence.

## Future Research

### State of the Science

Recent reports by the Consortium on Safe Labor, a group of 19 U.S. hospitals conducting an observational study on labor progression and the use and timing of cesareans among women with labor protraction and arrest, show that cesarean birth among women having their first birth has risen to almost one in three.165 Much of this increase occurred with the past decade.1 Since the 1980s researchers and policymakers have sought to implement strategies both in the context of trials and systems-level changes to reduce the number of cesarean births in low-risk women. No approaches to prevent cesarean have proven to be effective with moderate or high strength of evidence. Means to forestall a continued rise in cesarean are needed which will require continued research. Some cross-cutting methodologic challenges should be noted in future research.

### Methodologic Issues

- Develop data-driven estimates of plausible decreases in cesarean for use in power calculations.
- Develop definitions of indications for cesarean that can be validated from medical records and case-report forms.
- Include placebo, sham, or attention control comparison groups, and innovative means of masking patients and providers in studies of interventions.
- Conduct studies directly comparing and combining candidate strategies to detect additive and multiplicative effects of combining two effective interventions over each effective intervention alone.
- Design studies with prespecified secondary outcomes and adequate power for these outcomes.
- Conduct studies that allow stratification on patient characteristics such as nulliparity and multiparity and have adequate power to detect differences across strata.
- Track and report total, primary, and repeat cesareans in studies not restricted to nulliparous women.
- Capture all categories of birth outcomes (cesarean, emergent cesarean, assisted vaginal and spontaneous births) and related complications in order to assess if reductions in cesarean occur at the cost of increased use of other interventions or increased complications.
- Include robust measures of maternal coping, satisfaction, and perceived quality of the birth experience. Expand infant outcomes to include a uniform panel of measures that capture infant status better than Apgar scores and NICU admission.
- Include maternal length of stay and incidence of specific complications like chorioamnionitis, endometritis, and wound healing complications, as outcomes.
- Conduct multisite studies to improve applicability and assure power and precision.
- Conduct larger trials of health system interventions.
- Develop registries that capture both short term and long term outcomes.
- Determine the best measures of patient and provider route of birth preferences.
- Determine the scales/indices that best capture factors that mothers and partners value about the birth experience.
- Include longterm followup of infants into childhood to assure any reduction in cesarean is not achieved at the risk of future neurodevelopmental impairments and to determine if outcomes of infants born by cesarean are similar to those resulting from vaginal births.

### Gaps in Areas of Research

We identified gaps using four general strategies: (1) review of the analytic framework and assessment of the degree to which strategies have been examine that attempt to reduce cesarean at different time-points (e.g. during prenatal care, in triage for admission to labor and delivery, during labor); (2) consideration of areas in which we expected to identify literature and did not (e.g. strategies to modify change of shift staffing plans, trials of midwifery care explicitly powered for reduction in cesarean); (3) promising areas of the observational literature not covered in this review that would benefit from examination in a randomized clinical trial; and (4) noting intriguing results from single or lower quality studies included in the review that could benefit from replication.

- Why do some patients prefer to undergo elective cesarean?
- What factors drive a patient's decision to undergo a primary cesarean during labor, e.g. prior cesarean, general fears, fear of future pelvic floor disorders?
- What patient preferences influence decisions to convert to primary cesarean during labor, e.g. pain management, progress of labor, fears about baby's well-being?
- What physician factors contribute to the use of elective cesarean, e.g. residency training, attitude toward elective cesarean, practice size, practice setting, shift/time of day, use of hospitalists, personal birth experience?
- What physician factors contribute to the use of cesarean during labor, e.g. residency training, attitude toward cesarean, practice setting, practice size, shift/time of day, use of hospitalists, personal birth experience?
- To what extent do non-financial incentives such as time savings, control and perceived improvement in patient relations affect physician decisions to use cesarean?
- What nurse or midwife factors contribute to the use of cesarean during labor?
- What nurse or midwife factors contribute to the use of elective cesarean?
- What hospital factors contribute to the use of cesarean during labor, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use?
- What hospital factors contribute to the use of elective cesarean, e.g. teaching status, geographical region, urban location, socioeconomic status of patients, staffing and scheduling pattern, provider attitudes toward cesarean use?
- Do audit and feedback interventions influence physician use of cesarean?
- Do interventions aimed at disrupting staffing and scheduling phenomena – like the increase in cesarean near change of shifts and differential rates through the week – have promise?
- Does use of cesareans correlate with specific days of the week or time of day?
- Do different staffing models like use of hospitalists and integration of midwives reduce the number of cesarean births?
- Do provider peer-review models change provider patterns of cesarean use?
- Do natural experiments in tort reform support assertions that liability concerns contribute to use of cesarean?
- Do natural experiments in payment reform support the assertions that certain incentive structures contribute to the use of cesarean?
- To what degree is use of cesarean driven by uniform compensation for vaginal and cesarean birth as tested by an RCT?
- Does public reporting of hospital primary and total cesarean rates affect hospital cesarean rates over time?
- Does public reporting of hospital primary and total cesarean rates affect hospital induction rates over time?
- Does public reporting of individual physician primary and total cesarean rates affect physician use of cesarean over time?
- Does public reporting of individual physician primary and total cesarean rates affect physician use of induction over time?
- Does use of informed medical decision making models change patient decisions about desire for cesarean or for procedures like induction that may increase risk of cesarean?
- Is the Bishop's score routinely used by providers as a decision making tool? If not, why not?
- To what extent do patient educational and decision support tools affect patient decisions to undergo elective cesarean?
- To what extent do educational tools that manage patient expectations and describe the risks of cesarean influence use of cesareans during labor?
- Do system level changes applied to all patients in a care setting with the goal of reducing cesarean increase risk of neurodevelopmental delays in children evaluated over years after birth?
- When strictly operationalized and compared in clinical trials what components of systems intervention are effective in reducing cesarean use?
- Can technologies to enhance fetal surveillance [specify most promising – are there any technology studies worth doing?] improve infant outcomes while reducing cesarean?
- Does a protocol for use of scalp pH sampling reduce use of cesarean?
- Does outpatient hyaluronidase injection into the cervix for cervical ripening at term reduce risk of cesarean (replication of single promising trial)?
- Does active management of labor, using updated US labor curves, reduce use of cesarean in US community care settings?
- Does use of the Consortium for Safe Labor labor curves reduce use of cesarean?
- Does elective induction at 39 week vs. expectant management at 39 weeks influence use of cesarean?
- Can protocols supporting trial of induction of labor make it realistic for physicians to send a patient home if induction of labor does not progress in a timely fashion?
- What is the mechanism by which doula support exerts an effect?
- Does midwifery care through-out pregnancy in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
- Does midwifery care in labor in a hospital setting reduce use of cesarean among low-risk women when compared in a randomized clinical trial to obstetric care?
- Can tighter standards for elective induction among primiparous patients reduce use of cesarean?
- Can tighter standards for indicated induction among primiparous patients reduce use of cesarean?
- How does implementing uniform definitions for arrest of labor and its management influence use of cesarean?
- How does implementing a standard indication list affect physician's use of cesarean?
- Would changing the definition of when active labor starts reduce use of cesarean?
- Would changing the timeframes for normal progress in latent and active labor reduce primary cesareans?
- Would a tighter definition of elective cesarean affect physician's use of cesarean?
- What scales/indices best capture factors that mothers and partners value about their birth?
- As assessed by sociologic models, to what extent are cesarean rates perceived as concerning or not among members of the public, women of childbearing age, obstetrical care providers, payors, and policy makers?
- What factors have resulted in the change in patterns of the diagnosis of dystocia over the decades?

## Conclusions

No particular intervention strategy was uniformly successful in all trials of the strategy in reducing cesareans. Strength of evidence was low to insufficient across all strategies, with involvement of doulas for personalized support in labor being the only strategy to achieve evidence of benefit which was low related to poor quality of trials.

Several strategies are not supported by the current literature. This does not mean the strategy has no merit and should not be investigated in the future, but does mean that based on the current literature there is not evidence of effectiveness for the purpose of reducing cesarean use among low risk women. These include measurement of progress in labor as the primary component of intervention, active management of labor, nursing and midwifery students as support in labor, modifications of pain management approaches, fetal pulse oximetry and fetal assessment by STAN. For the majority of strategies the evidence is insufficient, including many instances in which a single study is the only evidence about the approach. While certain components of systems-level interventions were common among successful interventions, none were supported by a randomized trial and for each instance of inclusion in a successful pre-post intervention there were instances of unsuccessful use of similar components.

This literature contains intriguing examples of single studies that deserve further exploration. Use of hyaluronidase to hasten cervical changes favorable to labor at term was studied using a vehicle for the injection which is not allowed in the United States. Modifications and safety evaluation would be a prerequisite to future trials. Further exploration of what elements of doula support were common across successful trials would be informative in order to conduct larger scale replications in U.S. populations. Similarly, use of amnioinfusion to reduce fetal distress appears to reduce cesareans for this indication. More information is needed about why it did not reduce overall use of cesarean. Potential explanatory factors include trials that were underpowered; versus use of outcome measurements that allow cesareans undertaken for varied reasons to be grouped in uninformative ways. We also need evaluations of whether components of systems interventions succeed because of the components themselves or because the interventions selected reflect the will of the health system and care providers to promote decreased use of cesarean. Detailed research in the context of multi-site trials is warranted to more carefully parse which tools, individually and combined, have effect. Indeed the need for future research in this area is clear. Defining those needs better is the focus of a companion piece to this evidence review. The forthcoming report gathered information from multiple stakeholders including obstetricians, family physicians, midwives, insurers, advocacy groups, and individual women, and used a system of information gathering and surveys to prioritize which research is most urgently needed.

In conclusion, no approach dominated as a strategy appropriate to reduce use of cesarean in low-risk women in the United States. The literature spans the globe and may not have the level of applicability we would desire to contemporary U.S. populations. This is concerning as cesarean rates among low risk women continue to rise and the individual and public benefits of avoiding unnecessary cesarean may be substantial.