# Summary PICOTS Table

Table H1 Summary of PICOTS (population, intervention, comparator, timing and setting) of cesarean reduction strategies in RCTs

Author, Year Country | Population | Intervention/ Comparator (n) | Timing | Setting
World Health Organization, 1994^1^ Indonesia, Thailand, Malaysia | NR | Baseline (10,049) | During Labor | NR
World Health Organization, 1994^1^ Indonesia, Thailand, Malaysia | NR | Use of WHO partogram to guide active management of labor and decisions about cesarean (9,130) | During Labor | NR
Abdel-Aleem et al., 2005^2^ Egypt | Academic single site | Standard obstetric care without amnioinfusion (219) | During Labor | Labor and delivery suite
Abdel-Aleem et al., 2005^2^ Egypt | Academic single site | Transcervical amnioinfusion (219) | During Labor | Labor and delivery suite
Adamsons et al., 1999^3^ Puerto Rico | Academic single site | Usual care (23) | During Labor | Labor and delivery suite
Adamsons et al., 1999^3^ Puerto Rico | Academic single site | Propanolol labor (34) | During Labor | Labor and delivery suite
Ajadi et al., 2006^4^ Nigeria | Academic single site | No amniotomy on admission (64) | During Labor | Labor and delivery suite
Ajadi et al., 2006^4^ Nigeria | Academic single site | Amniotomy on admission (64) | During Labor | Labor and delivery suite
Althabe et al., 2004^5^ South America | NR | Usual care (39,175) | During Labor | NR
Althabe et al., 2004^5^ South America | NR | Mandatory second opinion by evidence-based guidelines for indications (34,735) | During Labor | NR
Asher et al., 2009^6^ US | Academic single site | Acupuncture (30) | During Labor | Clinic
Asher et al., 2009^6^ US | Academic single site | Usual care (no acupuncture) (30) | During Labor | Clinic
Asher et al., 2009^6^ US | Academic single site | Sham acupuncture (29) | During Labor | Clinic
Barakat et al., 2009^7^ Spain | Academic single site | No exercise training (80) | During Pregnancy | Other
Barakat et al., 2009^7^ Spain | Academic single site | Exercise training (80) | During Pregnancy | Other
Bernitz et al., 2011^8^ Norway | Academic single site | Special unit (282) | During Labor | Labor and delivery suite
Bernitz et al., 2011^8^ Norway | Academic single site | Normal unit (417) | During Labor | Labor and delivery suite
Bernitz et al., 2011^8^ Norway | Academic single site | Midwife-led unit (412) | During Labor | Labor and delivery suite
Bidgood et al., 1987^9^ UK | Academic single site | Observation (20) | During Labor | Antenatal clinic Labor and delivery suite
Bidgood et al., 1987^9^ UK | Academic single site | High-dose oxytocin (19) | During Labor | Antenatal clinic Labor and delivery suite
Bidgood et al., 1987^9^ UK | Academic single site | Low-dose oxytocin (21) | During Labor | Antenatal clinic Labor and delivery suite
Bloom et al., 1998^10^ US | Non-academic single site Community | Usual care (531) | During Labor | Labor and delivery suite
Bloom et al., 1998^10^ US | Non-academic single site Community | Walking during 1^st^ stage of labor (536) | During Labor | Labor and delivery suite
Bloom et al., 2006^11^ US | Academic multisite | Fetal pulse oximetry with oxygen saturation not displayed to clinician (2,712) | During Labor | Labor and delivery suite
Bloom et al., 2006^11^ US | Academic multisite | Fetal pulse oximetry with oxygen saturation displayed to clinician (2,629) | During Labor | Labor and delivery suite
Campbell et al., 2006^12^ US | Academic single site | Standard Care (300) | During Labor | Ambulatory care center, diner, homes, various locations
Campbell et al., 2006^12^ US | Academic single site | Lay doula support (298) | During Labor | Ambulatory care center, diner, homes, various locations
Choudhary et al., 2010^13^ India | Academic single site | Standard obstetric care without amnioinfusion (146) | During Labor | Hospital, labor and delivery suite
Choudhary et al., 2010^13^ India | Academic single site | Transcervical amnioinfusion (146) | During Labor | Hospital, labor and delivery suite
Cohen et al., 1987^14^ US | Community Practice | Control (75) | During Labor | Labor and delivery suite
Cohen et al., 1987^14^ US | Community Practice | Early aggressive management (75) | During Labor | Labor and delivery suite
Cox et al., 1999^15^ UK | Non-academic single site | Usual Care (240) | During Labor | Labor and delivery suite
Cox et al., 1999^15^ UK | Non-academic single site | Inflatable obstetric belt (260) | During Labor | Labor and delivery suite
East et al., 2006^16^ Australia | Academic multisite | Fetal monitoring with cardioocography only (295) | During Labor | Labor and delivery suite
East et al., 2006^16^ Australia | Academic multisite | Fetal monitoring without cardiotocography and fetal pulse oximetry (306) | During Labor | Labor and delivery suite
Elferink-Stinkens et al., 2004^17^ Netherlands | NR | Unusual care (>130,000) | During Labor | NR
Elferink-Stinkens et al., 2004^17^ Netherlands | NR | Report of departmental data with table and graph form with follow-up (130,000) | During Labor | NR
Frigoletto et al., 1995^18^ US | Academic single site | Active management (1,009) | During Labor | Labor and delivery suite
Frigoletto et al., 1995^18^ US | Academic single site | Usual care (906) | During Labor | Labor and delivery suite
Gagnon et al., 1997^19^ Canada | Academic single site | Usual nursing care (204) | During Labor | Labor and delivery suite
Gagnon et al., 1997^19^ Canada | Academic single site | One-to-one nursing care (209) | During Labor | Labor and delivery suite
Gambling et al., 1998^20^ US | Academic single site | Intravenous meperidine analgesia (607) | During Labor | Labor and delivery suite
Gambling et al., 1998^20^ US | Academic single site | Combined spinal-epidural anesthesia (616) | During Labor | Labor and delivery suite
Garite et al., 2000^21^ US | Academic single site | Standard intravenous fluids of 125 ml/hr (94) | During Labor | Labor and delivery suite
Garite et al., 2000^21^ US | Academic single site | Increased intravenous fluids (101) | During Labor | Labor and delivery suite
Garite et al., 2000^22^ US | Academic multisite | Fetal monitoring with cardiotocography only (502) | During Labor | Labor and delivery suite
Garite et al., 2000^22^ US | Academic multisite | Fetal monitoring with cardiotocography and fetal pulse oximetry (508) | During Labor | Labor and delivery suite
Hamilton et al., 2004^23^ US & Canada | NR | Labor progress evaluated by plotting cervical dilatation against time (2,514) | During Labor | NR
Hamilton et al., 2004^23^ US & Canada | NR | Computerized reference range used to evaluate labor progress (2,474) | During Labor | NR
Harper et al., 2006^24^ US | Academic single site | Usual care (26) | During Labor | Clinic
Harper et al., 2006^24^ US | Academic single site | Acupuncture sessions (30) | During Labor | Clinic
Harvey et al., 1996^25^ Canada | Non-academic multi site | Physician care (93) | During Labor | Clinic, labor and delivery suite
Harvey et al., 1996^25^ Canada | Non-academic multi site | Nurse-midwife care (101) | During Labor | Clinic, labor and delivery suite
Hemminki et al., 1990^26^ Finland | Academic single site | Usual care (118) | During Labor | Labor and delivery suite
Hemminki et al., 1990^26^ Finland | Academic single site | Midwifery student support (122) | During Labor | Labor and delivery suite
Hinshaw et al., 2008^27^ UK | Non-academic multi site | Delayed oxytocin (204) | During Labor | Clinic
Hinshaw et al., 2008^27^ UK | Non-academic multi site | Early oxytocin (208) | During Labor | Clinic
Hodnett et al., 2002^28^ US & Canada | Multi-site (9 academic and 4 non-academic) | Usual care (3,461) | During Labor | Labor and delivery suite
Hodnett et al., 2002^28^ US & Canada | Multi-site (9 academic and 4 non-academic) | Nurse support (3,454) | During Labor | Labor and delivery suite
Hofmeyr et al.,1998^29^ South Africa | Academic multisite | Standard obstetric care without amnioinfusion (176) | During Labor | Labor and delivery suite
Hofmeyr et al.,1998^29^ South Africa | Academic multisite | Transcervical amnioinfusion (176) | During Labor | Labor and delivery suite
Homer et al., 2001^30^ Australia | NR | Standard hospital-based care(539) | During Pregnancy | Antenatal clinics, public hospital labor and delivery suite
Homer et al., 2001^30^ Australia | NR | Community-based model care (550) | During Pregnancy | Antenatal clinics, public hospital labor and delivery suite
Jalil et al., 2009^31^ Malaysia | Academic single site | IM pethidine analgesia (98) | During Labor | Labor and delivery suite
Jalil et al., 2009^31^ Malaysia | Academic single site | Epidural ropivacaine 0.2% with fentanyl 2 μg/ml (94) | During Labor | Labor and delivery suite
Janssen et al., 2006^32^ Canada | Multi site | Telephone triage (731) | During Labor | Other
Janssen et al., 2006^32^ Canada | Multi site | Home-based triage (728) | During Labor | Other
Karraz, 2003^33^ France | Non-academic single site | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, non-ambulatory (74) | During Labor | Labor and delivery suite
Karraz, 2003^33^ France | Non-academic single site | Intermittent epidural bolus injections of 0.1% ropivacaine with 0.6 μg/ml sufentanil, ambulatory (141) | During Labor | Labor and delivery suite
Kennell et al., 1991^34^ US | Community practice | Control group assigned after birth (204) | During Labor | Labor and delivery suite
Kennell et al., 1991^34^ US | Community practice | Received support of a doula (212) | During Labor | Labor and delivery suite
Kennell et al., 1991^34^ US | Community practice | Observed by an inconspicuous observer (200) | During Labor | Labor and delivery suite
Kuhnert et al., 2004^35^ Germany | NR | Fetal monitoring with cardiotocography and fetal scalp blood sampling only (73) | During Labor | NR
Kuhnert et al., 2004^35^ Germany | NR | Fetal monitoring with cardiotocography and fetal pulse oximetry and fetal scalp blood sampling (73) | During Labor | NR
Lavender et al., 1998^36^ UK | Academic single site | 3-hour partogram (302) | During Labor | Labor and delivery suite
Lavender et al., 1998^36^ UK | Academic single site | 4-hour partogram (311) | During Labor | Labor and delivery suite
Lavender et al., 1998^36^ UK | Academic single site | 2-hour partogram (315) | During Labor | Labor and delivery suite
Lavender et al., 2006^37^ UK | Academic single site | 4-hour partogram (1,485) | During Labor | Labor and delivery suite, birthing center
Lavender et al., 2006^37^ UK | Academic single site | 2-hour partogram (1,490) | During Labor | Labor and delivery suite, birthing center
Lopez-Zeno et al., 1992^38^ US | Community practice | Traditional management (354) | During Labor | Labor and delivery suite
Lopez-Zeno et al., 1992^38^ US | Community practice | Active management (351) | During Labor | Labor and delivery suite
Mahomed et al., 1998^39^ Zimbabwe | Academic multisite | Standard obstetric care without amnioinfusion (336) | During Labor | Labor and delivery suite
Mahomed et al., 1998^39^ Zimbabwe | Academic multisite | Transcervical amnioinfusion (325) | During Labor | Labor and delivery suite
Matsuo et al., 2009^40^ US | Academic single site | Usual care (32) | During Labor | Hospital, labor and delivery suite
Matsuo et al., 2009^40^ US | Academic single site | Dental support device during active pushing (32) | During Labor | Hospital, labor and delivery suite
McGrath and Kennell, 2008^41^ US | Community practice (childbirth education classes in the greater Cleveland area) | Routine care (196) | During Labor | Labor and delivery suite
McGrath and Kennell, 2008^41^ US | Community practice (childbirth education classes in the greater Cleveland area) | Doula support (224) | During Labor | Labor and delivery suite
McNiven et al., 1998^42^ Canada | Academic single site | Direct admission (104) | During Labor | Labor and delivery suite
McNiven et al., 1998^42^ Canada | Academic single site | Early labor assessment (105) | During Labor | Labor and delivery suite
Mehrangiz et al., 2004^43^ Iran | Academic single site | Promethazine only (50) | During Labor | Labor and delivery suite
Mehrangiz et al., 2004^43^ Iran | Academic single site | Paracervical block with promethazine (50) | During Labor | Labor and delivery suite
Moodley et al., 1998^44^ South Africa | Academic single site | Standard obstetric care without amnioinfusion (30) | During Labor | Labor and delivery suite
Moodley et al., 1998^44^ South Africa | Academic single site | Transcervical amnioinfusion (30) | During Labor | Labor and delivery suite
Nicholson et al., 2008^45^ US | Academic multisite | Standard care (134) | During Pregnancy | Labor and delivery suite
Nicholson et al., 2008^45^ US | Academic multisite | Induction of labor (136) | During Pregnancy | Labor and delivery suite
Norris et al., 2001^46^ US | Academic single site | Epidural analgesia (1112) | During Labor | Labor and delivery suite
Norris et al., 2001^46^ US | Academic single site | Combined spinal-epidural anesthesia (1071) | During Labor | Labor and delivery suite
Ojala et al., 2006^47^ Finland | Academic single site | Fetal monitoring with cardiotocography only (739) | During Labor | Labor and delivery suite
Ojala et al., 2006^47^ Finland | Academic single site | Fetal monitoring with STAN (733) | During Labor | Labor and delivery suite
Olofsson et al., 1998^48^ Sweden | Academic single site | Epidural anesthesia with high dose local anesthetic (0.25% bupivacaine with adrenaline) (435) | During Labor | Labor and delivery suite
Olofsson et al., 1998^48^ Sweden | Academic single site | Epidural anesthesia with low dose (0.125% bupivacaine with sufentanil 10 μg) (422) | During Labor | Labor and delivery suite
O'Sullivan et al., 2009^49^ UK | Academic single site | Usual care (1,216) | During Labor | Hospital, labor and delivery suite
O'Sullivan et al., 2009^49^ UK | Academic single site | Allowed to eat during labor (1,227) | During Labor | Hospital, labor and delivery suite
Palomäki et al., 2006^50^ Finland | Academic single site | Oxytocin plus placebo (55) | During Labor | Labor and delivery suite
Palomäki et al., 2006^50^ Finland | Academic single site | Oxytocin plus propranolol (55) | During Labor | Labor and delivery suite
Pattinson et al., 2003^50^ South Africa | Academic single site | Expectant management (350) | During Labor | Labor and delivery suite
Pattinson et al., 2003^50^ South Africa | Academic single site | Aggressive management (344) | During Labor | Labor and delivery suite
Phipps et al.,2009^51^ Australia | Academic single site | Standard care (50) | During Pregnancy | Antenatal Class
Phipps et al.,2009^51^ Australia | Academic single site | Structured education for pushing (50) | During Pregnancy | Antenatal Class
Rathor et al., 2002^53^ India | Academic single site | Standard obstetric care without amnioinfusion (100) | During Labor | Labor and delivery suite
Rathor et al., 2002^53^ India | Academic single site | Transcervical amnioinfusion (100) | During Labor | Labor and delivery suite
Regi et al., 2009^54^ India | Academic single site | Standard obstetric care without amnioinfusion (75) | During Labor | Labor and delivery suite
Regi et al., 2009^54^ India | Academic single site | Transcervical amnioinfusion (75) | During Labor | Labor and delivery suite
Rogers et al., 1997^55^ US | Academic single site | Usual care (205) | During Labor | Labor and delivery suite
Rogers et al., 1997^55^ US | Academic single site | Active management (200) | During Labor | Labor and delivery suite
Sadler et al., 2000^56^ New Zealand | Academic single site | Routine management (331) | During Labor | Labor and delivery suite
Sadler et al., 2000^56^ New Zealand | Academic single site | Active management (320) | During Labor | Labor and delivery suite
Sadler et al., 2000^56^ New Zealand | Academic single site | Usual care (906) | During Labor | Labor and delivery suite
Saisto et al., 2001^57^ Finland | Community | Conventional therapy (91) | During Pregnancy | Clinic
Saisto et al., 2001^57^ Finland | Community | Intensive therapy (85) | During Pregnancy | Clinic
Sanchez-Ramos et al., 1996^58^ US | Academic single site | Oxytocin plus placebo (47) | During Labor | Labor and delivery suite
Sanchez-Ramos et al., 1996^58^ US | Academic single site | Oxytocin plus propranolol (49) | During Labor | Labor and delivery suite
Scheepers et al., 2002^59^ Netherlands | Academic single site | Placebo (99) | During Labor | Labor and delivery suite
Scheepers et al., 2002^59^ Netherlands | Academic single site | Oral carbohydrate solution (102) | During Labor | Labor and delivery suite
Skrablin et al., 2011^60^ Croatia | Academic single site | Continuous epidural (104) | During Labor | Labor and delivery suite
Skrablin et al., 2011^60^ Croatia | Academic single site | Intermittent epidural (101) | During Labor | Labor and delivery suite
Somprasit et al., 2005^61^ Thailand | Academic single site | Conventional management (640) | During Labor | Labor and delivery suite
Somprasit et al., 2005^61^ Thailand | Academic single site | Active management (320) | During Labor | Labor and delivery suite
Spallicci et al., 2007^62^ Brazil | Academic single site | Placebo cervical injection (85) | During Pregnancy | Labor and delivery suite
Spallicci et al., 2007^62^ Brazil | Academic single site | Hyaluronidase injection in cervix (83) | During Pregnancy | Labor and delivery suite
Strong et al., 1990^63^ US | Academic single site | Standard care (30) | During Labor | Labor and delivery suite
Strong et al., 1990^63^ US | Academic single site | Amnioinfusion (30) | During Labor | Labor and delivery suite
Trueba et al., 2000^64^ Mexico | Community Practice | Standard care (50) | During Labor | Labor and delivery suite
Trueba et al., 2000^64^ Mexico | Community Practice | Childbirth educator trained as doula (50) | During Labor | Labor and delivery suite
Vayssiere et al., 2007^65^ France | Academic multisite | Fetal monitoring with cardiotocography only (400) | During Labor | Labor and delivery suite
Vayssiere et al., 2007^65^ France | Academic multisite | Fetal monitoring with cardiotocography and STAN (399) | During Labor | Labor and delivery suite
Waldenstrom et al., 1997^66^ Sweden | Non-academic single site | Standard maternity care (932) | During Pregnancy | Labor and delivery suite
Waldenstrom et al., 1997^66^ Sweden | Non-academic single site | Birth center care (928) | During Pregnancy | Labor and delivery suite
Waldenstrom et al., 2001^67^ Sweden | Non-academic single site | Standard care (505) | During Pregnancy | Clinic, labor and delivery suite
Waldenstrom et al., 2001^67^ Sweden | Non-academic single site | Team midwife care (495) | During Pregnancy | Clinic, labor and delivery suite
Windrim et al., 2007^68^ Canada | Academic multisite | Labor progress documented by standard sequential notes (962) | During Labor | Labor and delivery suite
Windrim et al., 2007^68^ Canada | Academic multisite | Partogram added to standard written labor progress notes (970) | During Labor | Labor and delivery suite

## References

1 World Health Organization partograph in management of labour. World Health Organization Maternal Health and Safe Motherhood Programme. Lancet. Jun. 4. 1994;343(8910):1399-404. [pmid: 7910888].
2 Abdel-Aleem H, Amin AF, Shokry M, et al. Therapeutic amnioinfusion for intrapartum fetal distress using a pediatric feeding tube. Int J Gynaecol Obstet. Aug. 2005;90(2):94-8. [pmid: 15913621].
3 Adamsons K, de la Vega A, Santiago P. Reduction in the cesarean section rate in nulliparous patients after administration of intravenous propranolol. P R Health Sci J. Mar. 1999;18(1):5-8. [pmid: 10343980].
4 Ajadi MA, Kuti O, Orji EO, et al. The effect of amniotomy on the outcome of spontaneous labour in uncomplicated pregnancy. J Obstet Gynaecol. Oct. 2006;26(7):631-4. [pmid: 17071428].
5 Althabe F, Belizan JM, Villar J, et al. Mandatory second opinion to reduce rates of unnecessary caesarean sections in Latin America: a cluster randomised controlled trial. Lancet. Jun. 12. 2004;363(9425):1934-40. [pmid: 15194252].
6 Asher GN, Coeytaux RR, Chen W, et al. Acupuncture to initiate labor (Acumoms 2): a randomized, sham-controlled clinical trial. J Matern Fetal Neonatal Med. Oct. 2009;22(10):843-8. [pmid: 19526433].
7 Barakat R, Ruiz JR, Stirling JR, et al. Type of delivery is not affected by light resistance and toning exercise training during pregnancy: a randomized controlled trial. Am J Obstet Gynecol. Dec. 2009;201(6):590 e1-6. [pmid: 19608151].
8 Bernitz S, Rolland R, Blix E, et al. Is the operative delivery rate in low-risk women dependent on the level of birth care? A randomised controlled trial. BJOG. Oct. 2011;118(11):1357-64. [pmid: 21749629].
9 Bidgood KA, Steer PJ. A randomized control study of oxytocin augmentation of labour. 1. Obstetric outcome. Br J Obstet Gynaecol. Jun. 1987;94(6):512-7. [pmid: 3620398].
10 Bloom SL, McIntire DD, Kelly MA, et al. Lack of effect of walking on labor and delivery. N Engl J Med. Jul. 9. 1998;339(2):76-9. [pmid: 9654537].
11 Bloom SL, Spong CY, Thom E, et al. Fetal pulse oximetry and cesarean delivery. N Engl J Med. Nov. 23. 2006;355(21):2195-202. [pmid: 17124017].
12 Campbell DA, Lake MF, Falk M, et al. A randomized control trial of continuous support in labor by a lay doula. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):456-64. [pmid: 16881989].
13 Choudhary D, Bano I, Ali SM. Does amnioinfusion reduce caesarean section rate in meconium-stained amniotic fluid. Arch Gynecol Obstet. Jul. 2010;282(1):17-22. [pmid: 19685066].
14 Cohen GR, O'Brien WF, Lewis L, et al. A prospective randomized study of the aggressive management of early labor. Am J Obstet Gynecol. Nov. 1987;157(5):1174-7. [pmid: 3688070].
15 Cox J, Cotzias CS, Siakpere O, et al. Does an inflatable obstetric belt facilitate spontaneous vaginal delivery in nulliparae with epidural analgesia?. Br J Obstet Gynaecol. Dec. 1999;106(12):1280-6. [pmid: 10609722].
16 East CE, Brennecke SP, King JF, et al. The effect of intrapartum fetal pulse oximetry, in the presence of a nonreassuring fetal heart rate pattern, on operative delivery rates: a multicenter, randomized, controlled trial (the FOREMOST trial). Am J Obstet Gynecol. Mar. 2006;194(3):606 e1-16. [pmid: 16522387].
17 Elferink-Stinkens PM, Brand R, Amelink-Verburg MP, et al. Randomised clinical trial on the effect of the Dutch obstetric peer review system. Eur J Obstet Gynecol Reprod Biol. Apr. 10. 2002;102(1):21-30. [pmid: 12039085].
18 Frigoletto FD Jr., Lieberman E, Lang JM, et al. A clinical trial of active management of labor. N Engl J Med. Sep. 21. 1995;333(12):745-50. [pmid: 7643880].
19 Gagnon AJ, Waghorn K, Covell C. A randomized trial of one-to-one nurse support of women in labor. Birth. Jun. 1997;24(2):71-7. [pmid: 9271971].
20 Gambling DR, Sharma SK, Ramin SM, et al. A randomized study of combined spinal-epidural analgesia versus intravenous meperidine during labor: impact on cesarean delivery rate. Anesthesiology. Dec. 1998;89(6):1336-44. [pmid: 9856707].
21 Garite TJ, Weeks J, Peters-Phair K, et al. A randomized controlled trial of the effect of increased intravenous hydration on the course of labor in nulliparous women. Am J Obstet Gynecol. Dec. 2000;183(6):1544-8. [pmid: 11120525].
22 Garite TJ, Dildy GA, McNamara H, et al. A multicenter controlled trial of fetal pulse oximetry in the intrapartum management of nonreassuring fetal heart rate patterns. Am J Obstet Gynecol. Nov. 2000;183(5):1049-58. [pmid: 11084540].
23 Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. Jan-Feb. 2004;26(1):37-44. [pmid: 14763319].
24 Harper TC, Coeytaux RR, Chen W, et al. A randomized controlled trial of acupuncture for initiation of labor in nulliparous women. J Matern Fetal Neonatal Med. Aug. 2006;19(8):465-70. [pmid: 16966110].
25 Harvey S, Jarrell J, Brant R, et al. A randomized, controlled trial of nurse-midwifery care. Birth. Sep. 1996;23(3):128-35. [pmid: 8924098].
26 Hemminki E, Virta A, Koponen P. A trial on continuous human support during labor; Feasibility, interventions and mothers' satisfaction. J Psychosom Obstet Gynaecol. 1990;11(4):239-50.
27 Hinshaw K, Simpson S, Cummings S, et al. A randomised controlled trial of early versus delayed oxytocin augmentation to treat primary dysfunctional labour in nulliparous women. BJOG. Sep. 2008;115(10):1289-95. discussion 95-6. [pmid: 18715415].
28 Hodnett ED, Lowe NK, Hannah ME, et al. Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. JAMA. Sep. 18. 2002;288(11):1373-81. [pmid: 12234231].
29 Hofmeyr GJ, Gulmezoglu AM, Buchmann E, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 1. South Africa. Br J Obstet Gynaecol. Mar. 1998;105(3):304-8. [pmid: 9532991].
30 Homer CS, Davis GK, Brodie PM, et al. Collaboration in maternity care: a randomised controlled trial comparing community-based continuity of care with standard hospital care. BJOG. Jan. 2001;108(1):16-22. [pmid: 11212998].
31 Jalil NA, Omar M. Does ropivacaine 0.2% with fentanyl change the labour epidural profile?. Int Med J. 2009;16(2):149-55.
32 Janssen PA, Still DK, Klein MC, et al. Early labor assessment and support at home versus telephone triage: a randomized controlled trial. Obstet Gynecol. Dec. 2006;108(6):1463-9. [pmid: 17138781].
33 Karraz MA. Ambulatory epidural anesthesia and the duration of labor. Int J Gynaecol Obstet. Feb. 2003;80(2):117-22. [pmid: 12566183].
34 Kennell J, Klaus M, McGrath S, et al. Continuous emotional support during labor in a US hospital. A randomized controlled trial. JAMA. May. 1. 1991;265(17):2197-201. [pmid: 2013951].
35 Kuhnert M, Schmidt S. Intrapartum management of nonreassuring fetal heart rate patterns: a randomized controlled trial of fetal pulse oximetry. Am J Obstet Gynecol. Dec. 2004;191(6):1989-95. [pmid: 15592281].
36 Lavender T, Alfirevic Z, Walkinshaw S. Partogram action line study: a randomised trial. Br J Obstet Gynaecol. Sep. 1998;105(9):976-80. [pmid: 9763048].
37 Lavender T, Alfirevic Z, Walkinshaw S. Effect of different partogram action lines on birth outcomes: a randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):295-302. [pmid: 16880298].
38 Lopez-Zeno JA, Peaceman AM, Adashek JA, et al. A controlled trial of a program for the active management of labor. N Engl J Med. Feb. 13. 1992;326(7):450-4. [pmid: 1732771].
39 Mahomed K, Mulambo T, Woelk G, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 2. Zimbabwe. Br J Obstet Gynaecol. Mar. 1998;105(3):309-13. [pmid: 9532992].
40 Matsuo K, Mudd JV, Kopelman JN, et al. Duration of the second stage of labor while wearing a dental support device: a pilot study. J Obstet Gynaecol Res. Aug. 2009;35(4):672-8. [pmid: 19751326].
41 McGrath SK, Kennell JH. A randomized controlled trial of continuous labor support for middle-class couples: effect on cesarean delivery rates. Birth. Jun. 2008;35(2):92-7. [pmid: 18507579].
42 McNiven PS, Williams JI, Hodnett E, et al. An early labor assessment program: a randomized, controlled trial. Birth. Mar. 1998;25(1):5-10. [pmid: 9534499].
43 Mehrangiz Z, Sogra R, Malihe A. Randomized clinical trial to study the effect of paracervical block on reducing pain, improving APGAR Score and on accelerating the active phase of labor. Internet J Pain, Symptom Control & Palliative Care. 2004;3(1):7p.
44 Moodley J, Matchaba P, Payne AJ. Intrapartum amnioinfusion for meconium-stained liquor in developing countries. Trop Doct. Jan. 1998;28(1):31-4. [pmid: 9481194].
45 Nicholson JM, Parry S, Caughey AB, et al. The impact of the active management of risk in pregnancy at term on birth outcomes: a randomized clinical trial. Am J Obstet Gynecol. May. 2008;198(5):511 e1-15. [pmid: 18455526].
46 Norris MC, Fogel ST, Conway-Long C. Combined spinal-epidural versus epidural labor analgesia. Anesthesiology. Oct. 2001;95(4):913-20. [pmid: 11605932].
47 Ojala K, Vaarasmaki M, Makikallio K, et al. A comparison of intrapartum automated fetal electrocardiography and conventional cardiotocography--a randomised controlled study. BJOG. Apr. 2006;113(4):419-23. [pmid: 16553653].
48 Olofsson C, Ekblom A, Ekman-Ordeberg G, et al. Obstetric outcome following epidural analgesia with bupivacaine-adrenaline 0.25% or bupivacaine 0.125% with sufentanil--a prospective randomized controlled study in 1000 parturients. Acta Anaesthesiol Scand. Mar. 1998;42(3):284-92. [pmid: 9542554].
49 O'Sullivan G, Liu B, Hart D, et al. Effect of food intake during labour on obstetric outcome: randomised controlled trial. BMJ. 2009;338:b784.
50 Palomaki O, Uotila J, Tammela O, et al. A double blind, randomized trial on augmentation of labour with a combination of intravenous propranolol and oxytocin versus oxytocin only. Eur J Obstet Gynecol Reprod Biol. Mar. 1. 2006;125(1):44-9. [pmid: 16051416].
51 Pattinson RC, Howarth GR, Mdluli W, et al. Aggressive or expectant management of labour: a randomised clinical trial. BJOG. May. 2003;110(5):457-61. [pmid: 12742329].
52 Phipps H, Charlton S, Dietz HP. Can antenatal education influence how women push in labour?. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):274-8. [pmid: 19566559].
53 Rathor AM, Singh R, Ramji S, et al. Randomised trial of amnioinfusion during labour with meconium stained amniotic fluid. BJOG. Jan. 2002;109(1):17-20. [pmid: 11843370].
54 Regi A, Alexander N, Jose R, et al. Amnioinfusion for relief of recurrent severe and moderate variable decelerations in labor. J Reprod Med. May. 2009;54(5):295-302. [pmid: 19517694].
55 Rogers R, Gilson GJ, Miller AC, et al. Active management of labor: does it make a difference?. Am J Obstet Gynecol. Sep. 1997;177(3):599-605. [pmid: 9322630].
56 Sadler LC, Davison T, McCowan LM. A randomised controlled trial and meta-analysis of active management of labour. BJOG. Jul. 2000;107(7):909-15. [pmid: 10901564].
57 Saisto T, Salmela-Aro K, Nurmi JE, et al. A randomized controlled trial of intervention in fear of childbirth. Obstet Gynecol. Nov. 2001;98(5 Pt 1):820-6. [pmid: 11704175].
58 Sanchez-Ramos L, Quillen MJ, Kaunitz AM. Randomized trial of oxytocin alone and with propranolol in the management of dysfunctional labor. Obstet Gynecol. Oct. 1996;88(4 Pt 1):517-20. [pmid: 8841209].
59 Scheepers HC, Thans MC, de Jong PA, et al. A double-blind, randomised, placebo controlled study on the influence of carbohydrate solution intake during labour. BJOG. Feb. 2002;109(2):178-81. [pmid: 11911101].
60 Skrablin S, Grgic O, Mihaljevic S, et al. Comparison of intermittent and continuous epidural analgesia on delivery and progression of labour. J Obstet Gynaecol. 2011;31(2):134-8. [pmid: 21281028].
61 Somprasit C, Tanprasertkul C, Kamudhamas A. Reducing cesarean delivery rates: an active management labor program in a setting with limited resources. J Med Assoc Thai. Jan. 2005;88(1):20-5. [pmid: 15960212].
62 Spallicci MD, Chiea MA, Singer JM, et al. Use of hyaluronidase for cervical ripening: a randomized trial. Eur J Obstet Gynecol Reprod Biol. Jan. 2007;130(1):46-50. [pmid: 16324780].
63 Strong TH Jr., Hetzler G, Sarno AP, et al. Prophylactic intrapartum amnioinfusion: a randomized clinical trial. Am J Obstet Gynecol. Jun. 1990;162(6):1370-4. discussion 4-5. [pmid: 2193511].
64 Trueba G, Contreras C, Velazco MT, et al. Alternative strategy to decrease cesarean section: support by Doulas during labor. J Perinat Educ. 2000;9(2):8-13. [pmid: 17273201].
65 Vayssiere C, David E, Meyer N, et al. A French randomized controlled trial of ST-segment analysis in a population with abnormal cardiotocograms during labor. Am J Obstet Gynecol. Sep. 2007;197(3):299 e1-6. [pmid: 17826428].
66 Waldenstrom U, Nilsson CA, Winbladh B. The Stockholm birth centre trial: maternal and infant outcome. Br J Obstet Gynaecol. Apr. 1997;104(4):410-8. [pmid: 9141576].
67 Waldenstrom U, McLachlan H, Forster D, et al. Team midwife care: maternal and infant outcomes. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):257-64. [pmid: 11592538].
68 Windrim R, Seaward PG, Hodnett E, et al. A randomized controlled trial of a bedside partogram in the active management of primiparous labour. J Obstet Gynaecol Can. Jan. 2007;29(1):27-34. [pmid: 17346475].