# Strength of the Evidence Calculator

Table G1 Strength of the evidence calculator

Domain: | Risk of Bias judgment (aggregate quality of studies) | | | Consistency | | | Directness | | | Precision | | Subtotal numeric
Category | Low | Mod | High | Consistent | Inconsistent | NA (single study) | Direct | Indirect | | Precise | Imprecise | Subtotal numeric
Subcategory | Low | Mod | High | Consistent | Inconsistent | NA (single study) | Direct | Surrogate outcome | Indirect comparator | Precise | Imprecise | Subtotal numeric
Numeric rating | 4 | 3 | 2 | 0 | -1 | -0.5 or -1 | 0 | -1 | -1 | 0 | -0.5 or -1 | Subtotal numeric
Study A

Table G2 Interpretation of results

Numeric Score | Strength of Evidence | Interpretation
3.5-4 | High | Highly confident of true effect, further research unlikely to change confidence
2.5-3.5 | Moderate | Moderately confident of true effect, further research may change confidence and may change effect estimate
1-2.5 | Low | Not confident of true effect, further research likely to change confidence and estimate of effect
1-2.5 or NA | Insufficient | Available evidence inadequate for conclusion: too weak, too sparse, too inconsistent