# Quality of the Literature

The Cochrane Risk of Bias Tool for Randomized Controlled Trials

RANDOM SEQUENCE GENERATION Selection bias (biased allocation to interventions) due to inadequate generation of a randomised sequence.
Criteria for a judgment of ‘Low risk’ of bias. | The investigators describe a random component in the sequence generation process such as:; - Referring to a random number table;; - Using a computer random number generator;; - Coin tossing;; - Shuffling cards or envelopes;; - Throwing dice;; - Drawing of lots;; - Minimization*.; *Minimization may be implemented without a random element, and this is considered to be equivalent to being random.
Criteria for the judgment of ‘High risk’ of bias. | The investigators describe a non-random component in the sequence generation process. Usually, the description would involve some systematic, non-random approach, for example:; - Sequence generated by odd or even date of birth;; - Sequence generated by some rule based on date (or day) of admission;; - Sequence generated by some rule based on hospital or clinic record number.; Other non-random approaches happen much less frequently than the systematic approaches mentioned above and tend to be obvious. They usually involve judgement or some method of non-random categorization of participants, for example:; - Allocation by judgement of the clinician;; - Allocation by preference of the participant;; - Allocation based on the results of a laboratory test or a series of tests;; - Allocation by availability of the intervention.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information about the sequence generation process to permit judgement of ‘Low risk’ or ‘High risk’.
ALLOCATION CONCEALMENT Selection bias (biased allocation to interventions) due to inadequate concealment of allocations prior to assignment.
Criteria for a judgment of ‘Low risk’ of bias. | Participants and investigators enrolling participants could not foresee assignment because one of the following, or an equivalent method, was used to conceal allocation:; - Central allocation (including telephone, web-based and pharmacy-controlled randomization);; - Sequentially numbered drug containers of identical appearance;; - Sequentially numbered, opaque, sealed envelopes.
Criteria for the judgment of ‘High risk’ of bias. | Participants or investigators enrolling participants could possibly foresee assignments and thus introduce selection bias, such as allocation based on:; - Using an open random allocation schedule (e.g. a list of random numbers);; - Assignment envelopes were used without appropriate safeguards (e.g. if envelopes were unsealed or non-opaque or not sequentially numbered);; - Alternation or rotation;; - Date of birth;; - Case record number;; - Any other explicitly unconcealed procedure.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. This is usually the case if the method of concealment is not described or not described in sufficient detail to allow a definite judgement – for example if the use of assignment envelopes is described, but it remains unclear whether envelopes were sequentially numbered, opaque and sealed.
SELECTIVE REPORTING Reporting bias due to selective outcome reporting.
Criteria for a judgment of ‘Low risk’ of bias. | Any of the following:; - The study protocol is available and all of the study's pre-specified (primary and secondary) outcomes that are of interest in the review have been reported in the pre-specified way;; - The study protocol is not available but it is clear that the published reports include all expected outcomes, including those that were pre-specified (convincing text of this nature may be uncommon).
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - Not all of the study's pre-specified primary outcomes have been reported;; - One or more primary outcomes is reported using measurements, analysis methods or subsets of the data (e.g. subscales) that were not pre-specified;; - One or more reported primary outcomes were not pre-specified (unless clear justification for their reporting is provided, such as an unexpected adverse effect);; - One or more outcomes of interest in the review are reported incompletely so that they cannot be entered in a meta-analysis;; - The study report fails to include results for a key outcome that would be expected to have been reported for such a study.
Criteria for the judgment of ‘Unclear risk’ of bias. | Insufficient information to permit judgement of ‘Low risk’ or ‘High risk’. It is likely that the majority of studies will fall into this category.
OTHER BIAS Bias due to problems not covered elsewhere in the table.
Criteria for a judgment of ‘Low risk’ of bias. | The study appears to be free of other sources of bias.
Criteria for the judgment of ‘High risk’ of bias. | There is at least one important risk of bias. For example, the study:; - Had a potential source of bias related to the specific study design used; or; - Has been claimed to have been fraudulent; or; - Had some other problem.
Criteria for the judgment of ‘Unclear risk’ of bias. | There may be a risk of bias, but there is either:; - Insufficient information to assess whether an important risk of bias exists; or; - Insufficient rationale or evidence that an identified problem will introduce bias.
BLINDING OF PARTICIPANTS AND PERSONNEL Performance bias due to knowledge of the allocated interventions by participants and personnel during the study.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, but the review authors judge that the outcome is not likely to be influenced by lack of blinding;; - Blinding of participants and key study personnel ensured, and unlikely that the blinding could have been broken.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - No blinding or incomplete blinding, and the outcome is likely to be influenced by lack of blinding;; - Blinding of key study participants and personnel attempted, but likely that the blinding could have been broken, and the outcome is likely to be influenced by lack of blinding.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
BLINDING OF OUTCOME ASSESSMENT Detection bias due to knowledge of the allocated interventions by outcome assessors.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, but the review authors judge that the outcome measurement is not likely to be influenced by lack of blinding;; - Blinding of outcome assessment ensured, and unlikely that the blinding could have been broken.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - No blinding of outcome assessment, and the outcome measurement is likely to be influenced by lack of blinding;; - Blinding of outcome assessment, but likely that the blinding could have been broken, and the outcome measurement is likely to be influenced by lack of blinding.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient information to permit judgment of ‘Low risk’ or ‘High risk’;; - The study did not address this outcome.
INCOMPLETE OUTCOME DATA Attrition bias due to amount, nature or handling of incomplete outcome data.
Criteria for a judgment of ‘Low risk’ of bias. | Any one of the following:; - No missing outcome data;; - Reasons for missing outcome data unlikely to be related to true outcome (for survival data, censoring unlikely to be introducing bias);; - Missing outcome data balanced in numbers across intervention groups, with similar reasons for missing data across groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk not enough to have a clinically relevant impact on the intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes not enough to have a clinically relevant impact on observed effect size;; - Missing data have been imputed using appropriate methods.
Criteria for the judgment of ‘High risk’ of bias. | Any one of the following:; - Reason for missing outcome data likely to be related to true outcome, with either imbalance in numbers or reasons for missing data across intervention groups;; - For dichotomous outcome data, the proportion of missing outcomes compared with observed event risk enough to induce clinically relevant bias in intervention effect estimate;; - For continuous outcome data, plausible effect size (difference in means or standardized difference in means) among missing outcomes enough to induce clinically relevant bias in observed effect size;; - ‘As-treated’ analysis done with substantial departure of the intervention received from that assigned at randomization;; - Potentially inappropriate application of simple imputation.
Criteria for the judgment of ‘Unclear risk’ of bias. | Any one of the following:; - Insufficient reporting of attrition/exclusions to permit judgement of ‘Low risk’ or ‘High risk’ (e.g. number randomized not stated, no reasons for missing data provided);; - The study did not address this outcome.

[underlined: Thresholds for converting the Cochrane Risk of Bias tool to AHRQ standards (good, fair, and poor):]

- Good quality: All criteria met (i.e. low for each domain)
  Using the Cochrane ROB tool, it is possible for a criterion to be met even when the element was technically not part of the method. For instance, a judgment that knowledge of the allocated interventions was adequately prevented can be made even if the study was not blinded, if EPC team members judge that the outcome and the outcome measurement are not likely to be influenced by lack of blinding.
- Fair quality: One criterion not met (i.e. high risk of bias for one domain) or two criteria unclear, and the assessment that this was unlikely to have biased the outcome, and there is no known important limitation that could invalidate the results
- Poor quality: One criterion not met (i.e. high risk of bias for one domain) or two criteria unclear, and the assessment that this was likely to have biased the outcome, and there are important limitations that could invalidate the results
- Poor quality: Two or more criteria listed as high or unclear risk of bias

Newcastle-Ottawa Quality Assessment Form for Cohort Studies

Note: A study can be given a maximum of one star for each numbered item within the Selection and Outcome categories. A maximum of two stars can be given for Comparability.

### Selection

1. Representativeness of the exposed cohort
  a. Truly representative (one star)
  b. Somewhat representative (one star)
  c. Selected group
  d. No description of the derivation of the cohort
2. Selection of the non-exposed cohort
  a. Drawn from the same community as the exposed cohort (one star)
  b. Drawn from a different source
  c. No description of the derivation of the non exposed cohort
3. Ascertainment of exposure
  a. Secure record/institutional documentation of the intervention (e.g., surgical record) (one star)
  b. Structured interview (one star)
  c. Written self report
  d. No description
  e. Other
4. Demonstration that outcome of interest was not present at start of study
  a. Yes (one star)
  b. No

### Comparability

1. Comparability of cohorts on the basis of the design or analysis controlled for confounders
  a. The study controls for vaginal parity and prior cesarean status (one star)
  b. Study controls for other factors (list) _________________________________ (one star)
  c. Cohorts are not comparable on the basis of the design or analysis controlled for confounders
  d. No comparison group^*^
    * Added by Vanderbilt EPC
  e. N/A^*^

### Outcome

1. Assessment of outcome
  a. Independent blind assessment (one star)
  b. Record linkage (one star)
  c. Self report
  d. No description
  e. Other
2. Was follow-up long enough for outcomes to occur
  a. Yes (one star)
  b. No
  Indicate the median duration of follow-up and a brief rationale for the assessment above:____________________
3. Adequacy of follow-up of cohorts
  a. Complete follow up- all subject accounted for (one star)
  b. Subjects lost to follow up unlikely to introduce bias- number lost less than or equal to 20% or description of those lost suggested no different from those followed. (one star)
  c. Follow up rate greater than 80% and no description of those lost
  d. No statement

[underlined: Thresholds for converting the Newcastle-Ottawa scales to AHRQ standards (good, fair, and poor):]

- Good quality: 3 or 4 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain
- Fair quality: 2 stars in selection domain AND 1 or 2 stars in comparability domain AND 2 or 3 stars in outcome/exposure domain
- Poor quality: 0 or 1 star in selection domain OR 0 stars in comparability domain OR 0 or 1 stars in outcome/exposure domain

The Vanderbilt EPC included two additional options in the comparability domain not generally included in the Newcastle-Ottawa scales: “no comparison group” and “not applicable”. This was necessary because the review included single-arm studies for both the effectiveness and harms assessments.

Studies of the effectiveness of strategies to reduce cesarean birth that included only one study arm were marked as “no comparison group”, which equates to receiving no stars and an automatic rating of poor quality.

Cross sectional studies used to identify potential harms and measures of environmental exposure could appropriately have no comparison group, and were marked for comparability as “not applicable.” The quality scores for these studies were downgraded to account for their non-comparative study designs. For example, a study with three or four stars in the selection domain and two or three stars in the outcome/exposure domain, which would normally equate to a “good” quality rating, would be deemed “fair” quality if the comparability domain response was “not applicable”.

Quality Tables

Table E1 Risk of bias of RCTs of strategies to reduce cesarean births

Author, Year | Adequate sequence generation | Allocation concealment | Blinding of (Route of delivery) | Blinding (Maternal morbidity/mortality) | Blinding (Neonatal morbidity/mortality) | Incomplete outcome data (Route of delivery) | Incomplete outcome data (Maternal morbidity/mortality) | Incomplete outcome data (Neonatal morbidity/mortality) | Free of selective reporting | Free of other bias | Quality
World Health Organization, 1994^1^ | + | ? | - | + | + | + | + | + | + | + | Fair
Abdel-Aleem et al., 2005^2^ | + | + | ? | + | + | + | + | + | + | + | Fair
Adamsons et al., 1999^3^ | ? | ? | - | + | + | + | + | + | + | ? | Poor
Ajadi et al., 2006^4^ | + | + | ? | + | + | + | + | + | ? | + | Fair
Althabe et al.,5 | + | + | - | + | + | ? | ? | ? | + | ? | Poor
Asher et al., 2009^6^ | + | + | ? | + | + | + | + | + | + | + | Fair
Barakat et al., 2009^7^ | ? | + | + | + | + | + | + | + | + | - | Fair
Bernitz et al, 2011^8^ | + | + | ? | ? | ? | + | + | + | + | ? | Poor
Bidgood et al., 1987^9^ | + | + | - | + | + | + | + | + | + | + | Fair
Bloom et al., 2006^10^ | + | + | + | + | + | + | + | + | + | + | Good
Bloom et al., 1998^11^ | ? | ? | - | + | + | + | + | + | + | ? | Poor
Campbell et al., 2006^12^ | + | + | ? | + | + | + | + | + | - | + | Poor
Choudhary et al., 2010^13^ | + | + | - | - | - | + | + | + | + | + | Poor
Cohen et al., 1987^14^ | - | - | - | + | + | + | + | + | + | + | Poor
Cox et al., 1999^15^ | + | + | + | + | + | + | + | + | + | + | Good
East et al., 2006^16^ | + | + | + | + | + | ? | + | + | + | + | Fair
Elferink-Stinkens et al., 2004^17^ | ? | ? | + | + | + | + | + | + | + | + | Poor
Frigoletto et al., 1995^18^ | + | + | - | - | ? | + | + | + | + | ? | Poor
Gagnon, 1997^19^ | + | + | ? | + | + | + | + | + | + | + | Poor
Gambling et al., 1998^20^ | + | + | + | + | + | + | + | + | + | - | Fair
Garite et al., 2000^21^ | + | + | - | + | + | + | + | + | + | ? | Fair
Garite et al., 2000^22^ | + | + | + | + | + | + | + | + | + | + | Good
Hamilton et al., 2004^23^ | + | ? | ? | + | + | + | + | + | + | ? | Poor
Harper et al., 2006^24^ | + | + | + | + | + | + | + | + | + | ? | Fair
Harvey et al., 1996^25^ | + | ? | + | + | + | + | + | + | + | + | Fair
Hemminki et al., 1990^26^ | ? | + | - | + | + | + | + | ? | + | ? | Poor
Hinshaw et al., 2008^27^ | + | + | - | + | + | + | + | + | + | + | Poor
Hodnett et al., 2002^28^ | + | + | ? | + | + | + | + | + | + | + | Fair
Hofmeyr et al.,1998^29^ | + | + | - | + | + | + | + | + | + | ? | Poor
Homer et al., 2011^30^ | + | ? | - | - | + | + | + | + | + | ? | Poor
Jalil et al., 2009^31^ | ? | + | - | + | + | + | + | + | + | + | Fair
Janssen et al., 2006^32^ | + | + | - | + | + | + | + | + | + | + | Fair
Karraz, 2003^33^ | ? | ? | - | + | + | + | + | + | + | + | Poor
Kennell et al., 1991^34^ | ? | ? | - | + | + | + | + | + | + | + | Poor
Kuhnert et al., 2004 35 | ? | ? | + | + | + | + | + | + | + | + | Fair
Lavender et al., 1998^36^ | + | + | + | + | + | + | + | + | + | + | Good
Lavender et al., 2006^37^ | + | + | + | + | + | + | + | + | + | + | Good
Lopez-Zeno et al., 1992^38^ | + | + | - | + | + | + | + | + | + | + | Poor
Mahomed et al., 1998^39^ | + | + | ? | + | + | + | + | + | + | + | Fair
Matsuo et al., 2009^40^ | ? | + | - | - | + | + | + | + | + | + | Poor
McGrath and Kennell, 2008^41^ | ? | + | + | + | + | + | + | + | + | - | Poor
McNiven et al., 1998^42^ | ? | + | + | + | + | + | + | + | + | + | Fair
Mehrangiz et al., 2004^43^ | ? | ? | - | + | + | + | + | + | + | ? | Poor
Moodley et al., 1998^44^ | + | + | - | + | + | + | + | + | + | ? | Poor
Nicholson et al., 2008^45^ | + | + | + | + | + | + | + | + | + | - | Fair
Norris et al., 2001^46^ | - | - | ? | + | + | - | + | + | + | + | Poor
Ojala et al., 2006^47^ | + | + | - | + | + | + | + | + | + | + | Fair
Olofsson et al., 1998^48^ | + | + | - | + | + | + | + | + | + | + | Poor
O'Sullivan et al., 2009^49^ | + | + | + | + | + | + | + | + | + | + | Good
Palomäki et al., 2006^50^ | + | ? | + | + | + | + | + | + | + | + | Fair
Pattinson et al., 2003^51^ | + | + | + | + | + | + | + | + | + | + | Good
Phipps et al.,2009^52^ | + | + | - | + | + | + | + | + | + | + | Fair
Rathor et al., 2002^53^ | + | + | - | + | + | + | + | + | + | + | Fair
Regi et al., 2009^54^ | + | + | - | ? | ? | + | + | + | + | - | Poor
Rogers et al., 1997^55^ | + | + | + | + | + | + | + | + | + | + | Good
Sadler et al., 2000^56^ | + | + | ? | ? | ? | + | + | + | + | ? | Poor
Saisto et al., 2001^57^ | ? | + | - | + | + | + | + | ? | + | ? | Poor
Sanchez-Ramos et al., 1996^58^ | + | + | + | + | + | + | + | + | + | + | Good
Scheepers et al., 2002^59^ | + | + | + | + | + | + | + | + | + | - | Fair
Skrablin et al., 2011^60^ | - | - | + | + | + | + | + | + | + | ? | Poor
Somprasit et al., 2005^61^ | + | + | - | + | + | + | + | + | + | + | Poor
Spallicci et al., 2007^62^ | + | + | + | + | + | + | + | + | + | - | Fair
Strong et al., 1990^63^ | + | + | - | + | + | + | + | + | + | + | Poor
Trueba et al., 2000^64^ | ? | ? | - | + | + | + | + | + | + | + | Poor
Vayssiere et al., 2007^65^ | ? | + | ? | + | + | + | + | + | + | + | Fair
Waldenstrom et al., 1997^66^ | + | + | + | - | + | + | + | + | + | + | Fair
Waldenstrom et al., 2001^67^ | ? | + | - | + | + | + | + | + | + | + | Fair
Windrim et al., 2007^68^ | + | + | ? | + | + | + | + | + | + | + | Fair

+=Low risk of bias; -=High risk of bias; ?=Unclear risk of bias

Table E2 Newcastle-Ottawa quality rating systems-level strategies to reduce cesarean births

Author, Year | Selection (0-4) | | | | Comparability | Outcome (0-3) | | | Quality
Author, Year | Representativeness of the exposed cohort | Selection of the non exposed cohort | Ascertainment of exposure | Outcome of interest was not present at start of study | Comparability | Assessment of outcome | Follow-up long enough for outcomes to occur | Adequacy of follow up of cohorts | Quality
Berglund et al., 2010^69^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Bickell et al., 1996^70^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Boylan et al., 1991^71^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Calvo et al., 2009^72^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | No statement | Poor (4+0+2)
Dillon et al., 1992^73^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Gilstrap et al., 1984^74^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Gregory et al., 1999^75^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Iglesias et al., 1991^76^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Kazandjian and Lied, 1998^77^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Kim et al., 2005 78 | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Kiwanuka and Moore, 1993^79^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Langrew et al.,1996^80^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Liang et al., 2004^81^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | No statement | Poor (4+0+2)
Maher et al.,1994^82^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Main et al., 1999^83^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Meyers and Gleicher, 1988, 1993^84-85^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Oleske et al., 1992^86^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Poma, 1998^87^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Porreco, 1990^88^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | No statement | Poor (4+0+2)
Pridjian et al., 1991^89^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Robson et al., 1996^90^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Rust et al., 1993^91^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Sanchez-Ramos et al., 1990^92^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Sloan et al., 2000^93^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Smith et al., 2000^94^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Socol et al., 1993^95^ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | ✯ | Good (4+1+3)
Studnicki et al., 1997^96^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | ✯ | Poor (4+0+3)
Tay et al., 1992^97^ | ✯ | ✯ | ✯ | ✯ | N/A | ✯ | ✯ | No statement | Poor (4+0+2)

N/A=Not applicable

## References

1 World Health Organization partograph in management of labour. World Health Organization Maternal Health and Safe Motherhood Programme. Lancet. Jun. 4. 1994;343(8910):1399-404. [pmid: 7910888].
2 Abdel-Aleem H, Amin AF, Shokry M, et al. Therapeutic amnioinfusion for intrapartum fetal distress using a pediatric feeding tube. Int J Gynaecol Obstet. Aug. 2005;90(2):94-8. [pmid: 15913621].
3 Adamsons K, de la Vega A, Santiago P. Reduction in the cesarean section rate in nulliparous patients after administration of intravenous propranolol. P R Health Sci J. Mar. 1999;18(1):5-8. [pmid: 10343980].
4 Ajadi MA, Kuti O, Orji EO, et al. The effect of amniotomy on the outcome of spontaneous labour in uncomplicated pregnancy. J Obstet Gynaecol. Oct. 2006;26(7):631-4. [pmid: 17071428].
5 Althabe F, Belizan JM, Villar J, et al. Mandatory second opinion to reduce rates of unnecessary caesarean sections in Latin America: a cluster randomised controlled trial. Lancet. Jun. 12. 2004;363(9425):1934-40. [pmid: 15194252].
6 Asher GN, Coeytaux RR, Chen W, et al. Acupuncture to initiate labor (Acumoms 2): a randomized, sham-controlled clinical trial. J Matern Fetal Neonatal Med. Oct. 2009;22(10):843-8. [pmid: 19526433].
7 Barakat R, Ruiz JR, Stirling JR, et al. Type of delivery is not affected by light resistance and toning exercise training during pregnancy: a randomized controlled trial. Am J Obstet Gynecol. Dec. 2009;201(6):590 e1-6. [pmid: 19608151].
8 Bernitz S, Rolland R, Blix E, et al. Is the operative delivery rate in low-risk women dependent on the level of birth care? A randomised controlled trial. BJOG. Oct. 2011;118(11):1357-64. [pmid: 21749629].
9 Bidgood KA, Steer PJ. A randomized control study of oxytocin augmentation of labour. 1. Obstetric outcome. Br J Obstet Gynaecol. Jun. 1987;94(6):512-7. [pmid: 3620398].
10 Bloom SL, Spong CY, Thom E, et al. Fetal pulse oximetry and cesarean delivery. N Engl J Med. Nov. 23. 2006;355(21):2195-202. [pmid: 17124017].
11 Bloom SL, McIntire DD, Kelly MA, et al. Lack of effect of walking on labor and delivery. N Engl J Med. Jul. 9. 1998;339(2):76-9. [pmid: 9654537].
12 Campbell DA, Lake MF, Falk M, et al. A randomized control trial of continuous support in labor by a lay doula. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2006;35(4):456-64. [pmid: 16881989].
13 Choudhary D, Bano I, Ali SM. Does amnioinfusion reduce caesarean section rate in meconium-stained amniotic fluid. Arch Gynecol Obstet. Jul. 2010;282(1):17-22. [pmid: 19685066].
14 Cohen GR, O'Brien WF, Lewis L, et al. A prospective randomized study of the aggressive management of early labor. Am J Obstet Gynecol. Nov. 1987;157(5):1174-7. [pmid: 3688070].
15 Cox J, Cotzias CS, Siakpere O, et al. Does an inflatable obstetric belt facilitate spontaneous vaginal delivery in nulliparae with epidural analgesia?. Br J Obstet Gynaecol. Dec. 1999;106(12):1280-6. [pmid: 10609722].
16 East CE, Brennecke SP, King JF, et al. The effect of intrapartum fetal pulse oximetry, in the presence of a nonreassuring fetal heart rate pattern, on operative delivery rates: a multicenter, randomized, controlled trial (the FOREMOST trial). Am J Obstet Gynecol. Mar. 2006;194(3):606 e1-16. [pmid: 16522387].
17 Elferink-Stinkens PM, Brand R, Amelink-Verburg MP, et al. Randomised clinical trial on the effect of the Dutch obstetric peer review system. Eur J Obstet Gynecol Reprod Biol. Apr. 10. 2002;102(1):21-30. [pmid: 12039085].
18 Frigoletto FD Jr., Lieberman E, Lang JM, et al. A clinical trial of active management of labor. N Engl J Med. Sep. 21. 1995;333(12):745-50. [pmid: 7643880].
19 Gagnon AJ, Waghorn K, Covell C. A randomized trial of one-to-one nurse support of women in labor. Birth. Jun. 1997;24(2):71-7. [pmid: 9271971].
20 Gambling DR, Sharma SK, Ramin SM, et al. A randomized study of combined spinal-epidural analgesia versus intravenous meperidine during labor: impact on cesarean delivery rate. Anesthesiology. Dec. 1998;89(6):1336-44. [pmid: 9856707].
21 Garite TJ, Dildy GA, McNamara H, et al. A multicenter controlled trial of fetal pulse oximetry in the intrapartum management of nonreassuring fetal heart rate patterns. Am J Obstet Gynecol. Nov. 2000;183(5):1049-58. [pmid: 11084540].
22 Garite TJ, Weeks J, Peters-Phair K, et al. A randomized controlled trial of the effect of increased intravenous hydration on the course of labor in nulliparous women. Am J Obstet Gynecol. Dec. 2000;183(6):1544-8. [pmid: 11120525].
23 Hamilton E, Platt R, Gauthier R, et al. The effect of computer-assisted evaluation of labor on cesarean rates. J Healthc Qual. Jan-Feb. 2004;26(1):37-44. [pmid: 14763319].
24 Harper TC, Coeytaux RR, Chen W, et al. A randomized controlled trial of acupuncture for initiation of labor in nulliparous women. J Matern Fetal Neonatal Med. Aug. 2006;19(8):465-70. [pmid: 16966110].
25 Harvey S, Jarrell J, Brant R, et al. A randomized, controlled trial of nurse-midwifery care. Birth. Sep. 1996;23(3):128-35. [pmid: 8924098].
26 Hemminki E, Virta A, Koponen P. A trial on continuous human support during labor; Feasibility, interventions and mothers' satisfaction. J Psychosom Obstet Gynaecol. 1990;11(4):239-50.
27 Hinshaw K, Simpson S, Cummings S, et al. A randomised controlled trial of early versus delayed oxytocin augmentation to treat primary dysfunctional labour in nulliparous women. BJOG. Sep. 2008;115(10):1289-95. discussion 95-6. [pmid: 18715415].
28 Hodnett ED, Lowe NK, Hannah ME, et al. Effectiveness of nurses as providers of birth labor support in North American hospitals: a randomized controlled trial. JAMA. Sep. 18. 2002;288(11):1373-81. [pmid: 12234231].
29 Hofmeyr GJ, Gulmezoglu AM, Buchmann E, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 1. South Africa. Br J Obstet Gynaecol. Mar. 1998;105(3):304-8. [pmid: 9532991].
30 Homer CS, Davis GK, Brodie PM, et al. Collaboration in maternity care: a randomised controlled trial comparing community-based continuity of care with standard hospital care. BJOG. Jan. 2001;108(1):16-22. [pmid: 11212998].
31 Jalil NA, Omar M. Does ropivacaine 0.2% with fentanyl change the labour epidural profile?. Int Med J. 2009;16(2):149-55.
32 Janssen PA, Still DK, Klein MC, et al. Early labor assessment and support at home versus telephone triage: a randomized controlled trial. Obstet Gynecol. Dec. 2006;108(6):1463-9. [pmid: 17138781].
33 Karraz MA. Ambulatory epidural anesthesia and the duration of labor. Int J Gynaecol Obstet. Feb. 2003;80(2):117-22. [pmid: 12566183].
34 Kennell J, Klaus M, McGrath S, et al. Continuous emotional support during labor in a US hospital. A randomized controlled trial. JAMA. May. 1. 1991;265(17):2197-201. [pmid: 2013951].
35 Kuhnert M, Schmidt S. Intrapartum management of nonreassuring fetal heart rate patterns: a randomized controlled trial of fetal pulse oximetry. Am J Obstet Gynecol. Dec. 2004;191(6):1989-95. [pmid: 15592281].
36 Lavender T, Alfirevic Z, Walkinshaw S. Partogram action line study: a randomised trial. Br J Obstet Gynaecol. Sep. 1998;105(9):976-80. [pmid: 9763048].
37 Lavender T, Alfirevic Z, Walkinshaw S. Effect of different partogram action lines on birth outcomes: a randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):295-302. [pmid: 16880298].
38 Lopez-Zeno JA, Peaceman AM, Adashek JA, et al. A controlled trial of a program for the active management of labor. N Engl J Med. Feb. 13. 1992;326(7):450-4. [pmid: 1732771].
39 Mahomed K, Mulambo T, Woelk G, et al. The Collaborative Randomised Amnioinfusion for Meconium Project (CRAMP): 2. Zimbabwe. Br J Obstet Gynaecol. Mar. 1998;105(3):309-13. [pmid: 9532992].
40 Matsuo K, Mudd JV, Kopelman JN, et al. Duration of the second stage of labor while wearing a dental support device: a pilot study. J Obstet Gynaecol Res. Aug. 2009;35(4):672-8. [pmid: 19751326].
41 McGrath SK, Kennell JH. A randomized controlled trial of continuous labor support for middle-class couples: effect on cesarean delivery rates. Birth. Jun. 2008;35(2):92-7. [pmid: 18507579].
42 McNiven PS, Williams JI, Hodnett E, et al. An early labor assessment program: a randomized, controlled trial. Birth. Mar. 1998;25(1):5-10. [pmid: 9534499].
43 Mehrangiz Z, Sogra R, Malihe A. Randomized clinical trial to study the effect of paracervical block on reducing pain, improving APGAR Score and on accelerating the active phase of labor. Internet J Pain, Symptom Control & Palliative Care. 2004;3(1):7p.
44 Moodley J, Matchaba P, Payne AJ. Intrapartum amnioinfusion for meconium-stained liquor in developing countries. Trop Doct. Jan. 1998;28(1):31-4. [pmid: 9481194].
45 Nicholson JM, Parry S, Caughey AB, et al. The impact of the active management of risk in pregnancy at term on birth outcomes: a randomized clinical trial. Am J Obstet Gynecol. May. 2008;198(5):511 e1. 15. [pmid: 18455526].
46 Norris MC, Fogel ST, Conway-Long C. Combined spinal-epidural versus epidural labor analgesia. Anesthesiology. Oct. 2001;95(4):913-20. [pmid: 11605932].
47 Ojala K, Vaarasmaki M, Makikallio K, et al. A comparison of intrapartum automated fetal electrocardiography and conventional cardiotocography--a randomised controlled study. BJOG. Apr. 2006;113(4):419-23. [pmid: 16553653].
48 Olofsson C, Ekblom A, Ekman-Ordeberg G, et al. Obstetric outcome following epidural analgesia with bupivacaine-adrenaline 0.25% or bupivacaine 0.125% with sufentanil--a prospective randomized controlled study in 1000 parturients. Acta Anaesthesiol Scand. Mar. 1998;42(3):284-92. [pmid: 9542554].
49 O'Sullivan G, Liu B, Hart D, et al. Effect of food intake during labour on obstetric outcome: randomised controlled trial. BMJ. 2009;338:b784. [pmid: 19318702].
50 Palomaki O, Uotila J, Tammela O, et al. A double blind, randomized trial on augmentation of labour with a combination of intravenous propranolol and oxytocin versus oxytocin only. Eur J Obstet Gynecol Reprod Biol. Mar. 1. 2006;125(1):44-9. [pmid: 16051416].
51 Pattinson RC, Howarth GR, Mdluli W, et al. Aggressive or expectant management of labour: a randomised clinical trial. BJOG. May. 2003;110(5):457-61. [pmid: 12742329].
52 Phipps H, Charlton S, Dietz HP. Can antenatal education influence how women push in labour?. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):274-8. [pmid: 19566559].
53 Rathor AM, Singh R, Ramji S, et al. Randomised trial of amnioinfusion during labour with meconium stained amniotic fluid. BJOG. Jan. 2002;109(1):17-20. [pmid: 11843370].
54 Regi A, Alexander N, Jose R, et al. Amnioinfusion for relief of recurrent severe and moderate variable decelerations in labor. J Reprod Med. May. 2009;54(5):295-302. [pmid: 19517694].
55 Rogers R, Gilson GJ, Miller AC, et al. Active management of labor: does it make a difference?. Am J Obstet Gynecol. Sep. 1997;177(3):599-605. [pmid: 9322630].
56 Sadler LC, Davison T, McCowan LM. A randomised controlled trial and meta-analysis of active management of labour. BJOG. Jul. 2000;107(7):909-15. [pmid: 10901564].
57 Saisto T, Salmela-Aro K, Nurmi JE, et al. A randomized controlled trial of intervention in fear of childbirth. Obstet Gynecol. Nov. 2001;98(5 Pt 1):820-6. [pmid: 11704175].
58 Sanchez-Ramos L, Quillen MJ, Kaunitz AM. Randomized trial of oxytocin alone and with propranolol in the management of dysfunctional labor. Obstet Gynecol. Oct. 1996;88(4 Pt 1):517-20. [pmid: 8841209].
59 Scheepers HC, Thans MC, de Jong PA, et al. A double-blind, randomised, placebo controlled study on the influence of carbohydrate solution intake during labour. BJOG. Feb. 2002;109(2):178-81. [pmid: 11911101].
60 Skrablin S, Grgic O, Mihaljevic S, et al. Comparison of intermittent and continuous epidural analgesia on delivery and progression of labour. J Obstet Gynaecol. 2011;31(2):134-8. [pmid: 21281028].
61 Somprasit C, Tanprasertkul C, Kamudhamas A. Reducing cesarean delivery rates: an active management labor program in a setting with limited resources. J Med Assoc Thai. Jan. 2005;88(1):20-5. [pmid: 15960212].
62 Spallicci MD, Chiea MA, Singer JM, et al. Use of hyaluronidase for cervical ripening: a randomized trial. Eur J Obstet Gynecol Reprod Biol. Jan. 2007;130(1):46-50. [pmid: 16324780].
63 Strong TH Jr., Hetzler G, Sarno AP, et al. Prophylactic intrapartum amnioinfusion: a randomized clinical trial. Am J Obstet Gynecol. Jun. 1990;162(6):1370-4. discussion 4-5. [pmid: 2193511].
64 Trueba G, Contreras C, Velazco MT, et al. Alternative strategy to decrease cesarean section: support by Doulas during labor. J Perinat Educ. 2000;9(2):8-13. [pmid: 17273201].
65 Vayssiere C, David E, Meyer N, et al. A French randomized controlled trial of ST-segment analysis in a population with abnormal cardiotocograms during labor. Am J Obstet Gynecol. Sep. 2007;197(3):299 e1-6. [pmid: 17826428].
66 Waldenstrom U, Nilsson CA, Winbladh B. The Stockholm birth centre trial: maternal and infant outcome. Br J Obstet Gynaecol. Apr. 1997;104(4):410-8. [pmid: 9141576].
67 Waldenstrom U, McLachlan H, Forster D, et al. Team midwife care: maternal and infant outcomes. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):257-64. [pmid: 11592538].
68 Windrim R, Seaward PG, Hodnett E, et al. A randomized controlled trial of a bedside partogram in the active management of primiparous labour. J Obstet Gynaecol Can. Jan. 2007;29(1):27-34. [pmid: 17346475].
69 Berglund A, Lefevre-Cholay H, Bacci A, et al. Successful implementation of evidence-based routines in Ukrainian maternities. Acta Obstet Gynecol Scand. 2010;89(2):230-7. [pmid: 20121338].
70 Bickell NA, Zdeb MS, Applegate MS, et al. Effect of external peer review on cesarean delivery rates: a statewide program. Obstet Gynecol. May. 1996;87(5 Pt 1):664-7. [pmid: 8677064].
71 Boylan P, Frankowski R, Rountree R, et al. Effect of active management of labor on the incidence of cesarean section for dystocia in nulliparas. Am J Perinatol. Nov. 1991;8(6):373-9. [pmid: 1814299].
72 Calvo A, Campillo C, Juan M, et al. Effectiveness of a multifaceted strategy to improve the appropriateness of cesarean sections. Acta Obstet Gynecol Scand. 2009;88(7):842-5. [pmid: 19488884].
73 Dillon WP, Choate JW, Nusbaum ML, et al. Obstetric care and cesarean birth rates: a program to monitor quality of care. Obstet Gynecol. Nov. 1992;80(5):731-7. [pmid: 1407907].
74 Gilstrap LC 3rd, Hauth JC, Toussaint S. Cesarean section: changing incidence and indications. Obstet Gynecol. Feb. 1984;63(2):205-8. [pmid: 6694814].
75 Gregory KD, Hackmeyer P, Gold L, et al. Using the continuous quality improvement process to safely lower the cesarean section rate. Jt Comm J Qual Improv. Dec. 1999;25(12):619-29. [pmid: 10605652].
76 Iglesias S, Burn R, Saunders LD. Reducing the cesarean section rate in a rural community hospital. CMAJ. Dec. 1. 1991;145(11):1459-64. [pmid: 1959105].
77 Kazandjian VA, Lied TR. Cesarean section rates: effects of participation in a performance measurement project. Jt Comm J Qual Improv. Apr. 1998;24(4):187-96. [pmid: 9589331].
78 Kim CY, Ko SK, Kim KY. Are league tables controlling epidemic of caesarean sections in South Korea?. BJOG. May. 2005;112(5):607-11. [pmid: 15842285].
79 Kiwanuka AI, Moore WM. Influence of audit and feedback on use of caesarean section in a geographically-defined population. Eur J Obstet Gynecol Reprod Biol. Jun. 1993;50(1):59-64. [pmid: 8365537].
80 Lagrew DC Jr., Morgan MA. Decreasing the cesarean section rate in a private hospital: success without mandated clinical changes. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):184-91. [pmid: 8572004].
81 Liang WH, Yuan CC, Hung JH, et al. Effect of peer review and trial of labor on lowering cesarean section rates. J Chin Med Assoc. Jun. 2004;67(6):281-6. [pmid: 15366405].
82 Maher CF, Cave DG, Haran MV. Caesarean section rate reduced. Aust N Z J Obstet Gynaecol. Aug. 1994;34(4):389-92. [pmid: 7848224].
83 Main EK. Reducing cesarean birth rates with data-driven quality improvement activities. Pediatrics. Jan. 1999;103(1 Suppl E):374-83. [pmid: 9917479].
84 Myers SA, Gleicher N. The Mount Sinai cesarean section reduction program: an update after 6 years. Soc Sci Med. Nov. 1993;37(10):1219-22. [pmid: 8272900].
85 Myers SA, Gleicher N. A successful program to lower cesarean-section rates. N Engl J Med. Dec. 8. 1988;319(23):1511-6. [pmid: 3185675].
86 Oleske DM, Glandon GL, Tancredi DJ, et al. Information dissemination and the cesarean birth rate. The Illinois experience. Int J Technol Assess Health Care. Fall. 1992;8(4):708-18. [pmid: 1464490].
87 Poma PA. Effect of departmental policies on cesarean delivery rates: a community hospital experience. Obstet Gynecol. Jun. 1998;91(6):1013-8. [pmid: 9611015].
88 Porreco RP. Meeting the challenge of the rising cesarean birth rate. Obstet Gynecol. Jan. 1990;75(1):133-6. [pmid: 2296410].
89 Pridjian G, Hibbard JU, Moawad AH. Cesarean: changing the trends. Obstet Gynecol. Feb. 1991;77(2):195-200. [pmid: 1988880].
90 Robson MS, Scudamore IW, Walsh SM. Using the medical audit cycle to reduce cesarean section rates. Am J Obstet Gynecol. 1996;174(1):199-205. [pmid: 8572006].
91 Rust OA, Place JC, Melendez D, et al. Lowering the cesarean rate at a small USAF hospital. Mil Med. Jan. 1993;158(1):22-6. [pmid: 8437736].
92 Sanchez-Ramos L, Kaunitz AM, Peterson HB, et al. Reducing cesarean sections at a teaching hospital. Am J Obstet Gynecol. Sep. 1990;163(3):1081-7. discussion 7-8. [pmid: 2403133].
93 Sloan NL, Pinto E, Calle A, et al. Reduction of the cesarean delivery rate in Ecuador. Int J Gynaecol Obstet. Jun. 2000;69(3):229-36. [pmid: 10854864].
94 Smith JE, Fisher DL, Endorf-Olson JJ. Integrating patient satisfaction into performance measurement to meet improvement challenges. Jt Comm J Qual Improv. May. 2000;26(5):277-86. [pmid: 18350772].
95 Socol ML, Garcia PM, Peaceman AM, et al. Reducing cesarean births at a primarily private university hospital. Am J Obstet Gynecol. Jun. 1993;168(6 Pt 1):1748-54. discussion 54-8. [pmid: 8317517].
96 Studnicki J, Remmel R, Campbell R, et al. The impact of legislatively imposed practice guidelines on cesarean section rates: the Florida experience. Am J Med Qual. Spring. 1997;12(1):62-8.
97 Tay SK, Tsakok FH, Ng CS. The use of intradepartmental audit to contain cesarean section rate. Int J Gynaecol Obstet. Oct. 1992;39(2):99-103. [pmid: 1358722].