# Sample Data Abstraction Forms

Abstract Review Form

Full Text Review Form