# Evidence Tables

Evidence Table C1 Strategies To Reduce Cesarean Birth

Evidence Table C2 Strategies To Reduce Cesarean Birth—Systems Interventions