# Excluded Studies

Reasons for exclusion:

- X-1 = Ineligible study design
- X-2 = Not original research
- X-3 = Pregnant women not intending a vaginal birth
- X-4 = Not relevant to strategies to reduce cesarean birth topic
- X-5 = Does not state that intent was to improve/reduce cesarean rates
- X-6 = Does not reflect US contemporary practice
- X-7 = Not published in English
- X-8 = Unable to obtain study
- X-9 = Population was all cesarean

1 Symposium on the self-care concept of nursing. Nurs Clin North Am. Mar. 1980;15(1):129-217. X-1. [pmid: 6899197].
2 Jefferson v. Griffin Spalding County Hospital Authority. South East Report Second Ser. Feb. 3. 1981;274:457-62. X-1, X-2. [pmid: 12041308].
3 NIH consensus development statement on cesarean childbirth. The Cesarean Birth Task Force. Obstet Gynecol. Apr. 1981;57(4):537-45. X-1, X-2. [pmid: 7243111].
4 Illinois hospital given temporary custody of fetus. Am Med News. Feb. 19. 1982;25(7):11. X-1.
5 Mercy Hospital v. Jackson. Atl Report. Apr. 4. 1985;489:1130-4. X-1. [pmid: 11648161].
6 Mercy Hospital v. Jackson. Atl Report. Jun. 30. 1986;510:562-8. X-1. [pmid: 11648170].
7 In re A.C. Atl Report. Nov. 10. 1987;533:611-7. X-1. [pmid: 11648174].
8 Re Baby R. Dom Law Rep. Aug. 5. 1988;53:69-81. X-1. [pmid: 12041067].
9 Three opioids compared for postsurgical pain. Nurses' Drug Alert. 1989;13(9):71-72. X-3.
10 In re A.C. Atl Report. Apr. 26. 1990;573:1235-64. X-1. [pmid: 11648191].
11 Multicenter survey of diabetic pregnancy in France. Gestation and Diabetes in France Study Group. Diabetes Care. Nov. 1991;14(11):994-1000. X-1. [pmid: 1797514].
12 Practice parameters: cesarean birth. Minnesota Clinical Comparison and Assessment Project. QA Rev. Jul. 1991;3(5):6. X-1.
13 Women's health and rights gain media's and medicine's attention. Hosp Ethics. Jan-Feb. 1991;7(1):14-6. X-1. [pmid: 10170641].
14 Court orders caesarean section. Bull Med Ethics. Oct. 1992;(No. 82):3-4. X-1.
15 Re S (Adult: Refusal of Medical Treatment). All Engl Law Rep. Oct. 12. [1992]. 1992;4:671-2. X-1, X-2.
16 From the Centers for Disease Control and Prevention. Rates of cesarean delivery--United States, 1991. JAMA. May. 12. 1993;269(18):2360. X-1, X-2. [pmid: 8479055].
17 Physician-patient relationships frame ethical issues. Hosp Ethics. Nov-Dec. 1993;9(6):13. X-1.
18 A clinical trial of induction of labor versus expectant management in postterm pregnancy. The National Institute of Child Health and Human Development Network of Maternal-Fetal Medicine Units. Am J Obstet Gynecol. Mar. 1994;170(3):716-23. X-4e. [pmid: 7710467].
19 Comparing routine versus delayed amniotomy in spontaneous first labor at term. A multicenter randomized trial. UK Amniotomy Group. Online J Curr Clin Trials. 1994. Apr. 1. Doc No 122:[4148 words; 40 paragraphs]. X-5.
20 Costing caesarean sections: a pilot study. Aust Coll Midwives Inc J. Jun. 1994;7(2):6-10. X-1. [pmid: 8018032].
21 Does anyone know what a caesarean costs?. Aust Coll Midwives Inc J. Jun. 1994;7(2):10-2. X-1. [pmid: 8018028].
22 Forced intervention cases take different lines of argument. Hosp Ethics. Mar-Apr. 1994;10(2):9-10. X-1, X-2.
23 In re Baby Boy Doe. North East Rep Second Ser. Apr. 5. 1994;632:326-35. X-1, X-2. [pmid: 12041260].
24 A multicentre randomised trial of amniotomy in spontaneous first labour at term. The UK Amniotomy Group. Br J Obstet Gynaecol. Apr. 1994;101(4):307-9. X-4e, X-5. [pmid: 8199076].
25 Surgical delivery reduces mother-to-child HIV transmission. RN. 1994;57(10):19-19. X-4b.
26 Court-authorised caesareans: new guidance. Health Care Anal. Sep. 1997;5(3):240-3. X-1. [pmid: 10184767].
27 Enforced caesareans. Bull Med Ethics. Apr. 1997;(127):21-4. X-1, X-2.
28 Fetal monitors offer protection, may reduce need for surgery. OB-GYN Malpractice Prevention. 1997;4(11):81-83. X-2.
29 Institute seeks to close gap between knowledge and delivery in reducing C-section rates. Healthc Demand Dis Manag. Jan. 1997;3(1):12-5. X-2. [pmid: 10174586].
30 Low Birthweight PORT publishes recent findings. AHRQ Research Activities. 1997;(202):6-7. X-2.
31 NY study confirms HMO and FFS Medicaid moms have more complicated, costly births. Public Sect Contract Rep. Mar. 1997;3(3):45-7. X-1.
32 One-fourth of c-sections examined in New York State may be due to defensive medicine. AHRQ Research Activities. 1997;(204):11-11. X-2.
33 Priority area 14: maternal and infant health. Healthy people 2000 review. 1997. 1997:128-135. X-2.
34 Caesareans reduce HIV risk. Health Service Journal. 1998;108(5619):3-3. X-4b.
35 High Court endorses women's right to refuse treatment. Pract Midwife. Jun. 1998;1(6):7. X-1, X-2, X-3, X-4e, X-5. [pmid: 9735814].
36 Nifedipine versus expectant management in mild to moderate hypertension in pregnancy. Gruppo di Studio Ipertensione in Gravidanza. Br J Obstet Gynaecol. Jul. 1998;105(7):718-22. X-4e. [pmid: 9692411].
37 Outreach program slashes Florida health network's rate of cesarean sections. Health Care Cost Reengineering Rep. Sep. 1998;3(9):137-8. X-1. [pmid: 10185344].
38 Therapeutic and other interventions to reduce the risk of mother-to-child transmission of HIV-1 in Europe. The European Collaborative Study. Br J Obstet Gynaecol. Jul. 1998;105(7):704-9. X-1. [pmid: 9692409].
39 Caesarean section does not guarantee satisfaction. Aust Nurs J. Oct. 1999;7(4):31. X-1.
40 CM models cut cesarean rates and preterm births: two hospitals monitor high-risk moms-to-be. Hospital Case Management. 1999;7(11):190. X-1, X-2, X-3, X-5. [pmid: 11184950].
41 Elective caesarean-section versus vaginal delivery in prevention of vertical HIV-1 transmission: a randomised clinical trial. Lancet. Mar. 27. 1999;353(9158):1035-9. X-3, X-4e. [pmid: 10199349].
42 Mother-to-child transmission of human immunodeficiency virus in Italy: temporal trends and determinants of infection. The Italian Collaborative Study on HIV infection in pregnancy. Hum Reprod. Jan. 1999;14(1):242-6. X-1. [pmid: 10374128].
43 Pemberton v. Tallahassee Memorial Regional Center. Wests Fed Suppl. 1999;66:1247-57. X-1, X-2, X-3, X-4e, X-5. [pmid: 11868571].
44 AHRQ says many cesarean sections performed too early in labor. Rep Med Guidel Outcomes Res. Apr. 13. 2000;11(8):8. X-1, X-2, X-3, X-4e, X-5.
45 Data benchmarks. Experts urge open discussion about cesarean section rates. Clin Resour Manag. Sep. 2000;1(9):141-3. 129. X-1, X-2, X-3, X-4, X-5. [pmid: 11186350].
46 The ‘Term Breech Trial’: a multicentre study finds Caesarean section best. International Midwifery. 2000;13(6):10-10. X-4c.
47 ACOG committee opinion: number 265, December 2001. Mode of term single breech delivery. Obstet Gynecol. Dec. 2001;98(6):1189-90. X-1, X-2. [pmid: 11755586].
48 Effects of mode of delivery and infant feeding on the risk of mother-to-child transmission of hepatitis C virus. European Paediatric Hepatitis C Virus Network. BJOG. Apr. 2001;108(4):371-7. X-1. [pmid: 11305543].
49 HIV-infected pregnant women and vertical transmission in Europe since 1986. European collaborative study. AIDS. Apr. 13. 2001;15(6):761-70. X-1. [pmid: 11371691].
50 NCHS dataline. Public Health Reports. 2001;116(4):379-381. X-1.
51 ACOG committee opinion. Mode of term singleton breech delivery. Number 265, December 2001. American College of Obstetricians and Gynecologists. Int J Gynaecol Obstet. Apr. 2002;77(1):65-6. X-1, X-2. [pmid: 12053896].
52 Determinants of mother-to-infant human immunodeficiency virus 1 transmission before and after the introduction of zidovudine prophylaxis. Arch Pediatr Adolesc Med. Sep. 2002;156(9):915-21. X-1. [pmid: 12197800].
53 The Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Int J Gynaecol Obstet. Jul. 2002;78(1):69-77. X-1. [pmid: 12113977].
54 Program note. Using UN process indicators to assess needs in emergency obstetric services: Bhutan, Cameroon and Rajasthan, India. Int J Gynaecol Obstet. Jun. 2002;77(3):277-84. X-1, X-2. [pmid: 12065143].
55 Report says c-section rate increasing. Nursing Spectrum -- Philadelphia Tri -- State Edition. 2002;11(24):28-28. X-1.
56 Report says c-section rate increasing. Nursing Spectrum -- Washington DC & Baltimore Edition. 2002;12(24):29-29. X-1.
57 On-call physician responsibility examined by Indiana court. Miller v. Martig. Hosp Law Newsl. Jan. 2003;20(3):3-6. X-1, X-2, X-3, X-4e, X-5.
58 Program note. Using UN process indicators to assess needs in emergency obstetric services: Niger, Rwanda and Tanzania. Int J Gynaecol Obstet. Oct. 2003;83(1):112-20. X-1, X-2. [pmid: 14511885].
59 Program note: using UN process indicators to assess needs in emergency obstetric services: Morocco, Nicaragua and Sri Lanka. Int J Gynaecol Obstet. Feb. 2003;80(2):222-30. X-1. [pmid: 12566202].
60 A randomised trial of timed delivery for the compromised preterm fetus: short term outcomes and Bayesian interpretation. BJOG. Jan. 2003;110(1):27-32. X-4e, X-5. [pmid: 12504932].
61 U.S. birth rate reaches record low. Medical Letter on the CDC. 2003:13-14. X-1.
62 Female OB/GYNs speak out about health practices. AWHONN Lifelines. Feb-Mar. 2004;8(1):14-8. X-1, X-2. [pmid: 15031881].
63 NICE guidelines aim to stem caesarean rate. RCM Midwives. Jun. 2004;7(6):234. X-1, X-2, X-3, X-4, X-5. [pmid: 15197830].
64 NICE orders curbs on caesareans. Pract Midwife. Jun. 2004;7(6):8. X-1, X-2, X-3.
65 A significant sex--but not elective cesarean section--effect on mother-to-child transmission of hepatitis C virus infection. J Infect Dis. Dec. 1. 2005;192(11):1872-9. X-1. [pmid: 16267757].
66 Task force: screen all pregnant women for HIV. Contraceptive Technology Update. 2005:3-4. X-1, X-2.
67 Term breech delivery in Sweden: mortality relative to fetal presentation and planned mode of delivery. Acta Obstet Gynecol Scand. Jun. 2005;84(6):593-601. X-1. [pmid: 15901273].
68 Abstracts. Obstetrics & Gynecology. 2006;108(5):1293-1296. X-1.
69 Carol Sakala's letter from North America: an uncontrolled experiment: elective delivery predominates in the United States. Birth. Dec. 2006;33(4):332-5. X-1, X-2. [pmid: 17190018].
70 Epidural versus non-epidural or no analgesia in labour. Birth: Issues in Perinatal Care. 2006;33(1):79-79. X-1.
71 From the Centers for Disease Control and Prevention. Rates of cesarean delivery among Puerto Rican women -- Puerto Rico and the US mainland, 1992-2002. JAMA: Journal of the American Medical Association. 2006;295(12):1369-1371. X-1.
72 Living: nutrition know-how. In brief when is it A-OK to choose a C-section?. Health (Time Inc.). 2006;20(8):70-70. X-1.
73 Maternity Coalition campaigns against Birth after Caesarean Trial. Australian Midwifery News. 2006;6(3):15-16. X-1.
74 The mother-to-child HIV transmission epidemic in Europe: evolving in the East and established in the West. AIDS. Jun. 26. 2006;20(10):1419-27. X-1. [pmid: 16791017].
75 News. Neonatal Intensive Care. 2006;19(7):8-12. X-1.
76 News. Birth: Issues in Perinatal Care. 2006;33(1):80-82. X-1.
77 Abstracts. Obstetrics & Gynecology. 2007;109(2 Part 1):446-449. X-1.
78 The CORONIS Trial. International study of caesarean section surgical techniques: a randomised fractional, factorial trial. BMC Pregnancy Childbirth. 2007;7:24. X-1. [pmid: 18336721].
79 Midwifery and childbirth news. Midwifery Today. 2007;(81):60-61. X-1.
80 Midwifery and childbirth news. Midwifery Today. 2007;(82):62-64. X-1.
81 Outcome better with planned cesarean hysterectomy, vs. emergent surgery. Contemporary OB/GYN. 2007;52(10):16-16. X-4b.
82 2008 SNRS abstracts -- M. Southern Online Journal of Nursing Research. 2008;8(4):9-9. X-1.
83 ACORN 13th National Conference: Between the Flags. 21-24 May 2008. Gold Coast, QLD. abstracts. ACORN: the Journal of Perioperative Nursing in Australia. 2008;21(2):35. X-1.
84 Midwifery and childbirth news. Midwifery Today. 2008;(88):62-63. X-1.
85 News. Technic: The Journal of Operating Department Practice. 2008;5(2):6-7. X-1.
86 Chapter 14: caring for the woman experiencing complications during labor and birth. Maternal-child nursing care: optimizing outcomes for mothers, children, and families. 2009:427-466. X-1, X-2.
87 Hot papers in the literature. Journal of Women's Health. (15409996). 2009;18(1):133-137. X-1.
88 Hot papers in the literature. Journal of Women's Health. (15409996). 2009;18(2):275-281. X-1.
89 Hot papers in the literature. Journal of Women's Health. (15409996). 2009;18(4):595-599. X-1.
90 Human resources for health in the low-resource world: collaborative practice and task shifting in maternal and neonatal care. Int J Gynaecol Obstet. Apr. 2009;105(1):74-6. X-1, X-2. [pmid: 19155009].
91 Midwifery and childbirth news. Midwifery Today. 2009;(92):62-62. X-1.
92 News. Neonatal Intensive Care. 2009;22(7):15-20. X-1.
93 Noteworthy professional news. Advances in Neonatal Care (Elsevier Science). 2009;9(2):50-52. X-1.
94 Antibiotic prophylaxis versus no prophylaxis for preventing infection after cesarean section… ©Cochrane Library, reproduced with permission. Journal of Perioperative Practice. 2010;20(5):159-159.
95 Antibiotic prophylaxis versus no prophylaxis for preventing infection after cesarean section… COCochrane Library, reproduced with permission. Journal of Perioperative Practice. 2010;20(5):159-159. X-1, X-2, X-9.
96 Caesarean section surgical techniques: a randomised factorial trial (CAESAR). BJOG. Oct. 2010;117(11):1366-76. X-9. [pmid: 20840692].
97 Clinical digest. Antibiotic prophylaxis reduces infection in caesarean sections. Nursing Standard. 2010;25(13). [16]. X-1, X-9.
98 HIV protection during pregnancy is examined. Contraceptive Technology Update. 2010;31(8):92-93. X-1, X-2, X-3, X-4e, X-5.
99 Hyperglycaemia and Adverse Pregnancy Outcome (HAPO) Study: associations with maternal body mass index. BJOG. Apr. 2010;117(5):575-84. X-1. [pmid: 20089115].
100 Interventions at caesarean section for reducing the risk of aspiration pneumonitis… © Cochrane Library, reproduced with permission. Journal of Perioperative Practice. 2010;20(4):128-128. X-4b.
101 Interventions at caesarean section for reducing the risk of aspiration pneumonitis… CO Cochrane Library, reproduced with permission. Journal of Perioperative Practice. 2010;20(4):128-128. X-1, X-2, X-9.
102 News. Neonatal Intensive Care. 2010. Jan-Feb. 2010;23(1):7. X-1.
103 News. Neonatal Intensive Care. 2010;23(3):14. X-1.
104 Aali BS, Motamedi B. Women's knowledge and attitude towards modes of delivery in Kerman, Islamic Republic of Iran. East Mediterr Health J. Jul. 2005;11(4):663-72. X-1, X-2. [pmid: 16700382].
105 Aarimaa T, Ekblad U, Erkkola R, et al. Effect of antepartum ritodrine on the cardiorespiratory status of the newborn after elective cesarean section. Gynecol Obstet Invest. 1987;23(3):160-6. X-1. [pmid: 3110023].
106 Aaronson D, Harlev A, Sheiner E, et al. Trial of labor after cesarean section in twin pregnancies: maternal and neonatal safety. J Matern Fetal Neonatal Med. Jun. 2010;23(6):550-4. X-1. [pmid: 19658041].
107 Abad-Sarmiento LR, Oliveros-Vistro T. Must anatomy spell destiny for us women?. Philipp J Nurs. Apr-Jun. 1987;57(2):44-7. X-1. [pmid: 3685087].
108 Abbasi S, Gerdes JS, Sehdev HM, et al. Neonatal outcome after exposure to indomethacin in utero: a retrospective case cohort study. Am J Obstet Gynecol. Sep. 2003;189(3):782-5. X-1. [pmid: 14526313].
109 Abbasi S, Hirsch D, Davis J, et al. Effect of single versus multiple courses of antenatal corticosteroids on maternal and neonatal outcome. Am J Obstet Gynecol. May. 2000;182(5):1243-9. X-1. [pmid: 10819866].
110 Abboud TK, Afrasiabi A, Davidson J, et al. Prophylactic oral naltrexone with epidural morphine: effect on adverse reactions and ventilatory responses to carbon dioxide. Anesthesiology. Feb. 1990;72(2):233-7. X-1. [pmid: 2105673].
111 Abboud TK, Curtis J, Earl S, et al. Efficacy of clear antacid prophylaxis in obstetrics. Acta Anaesthesiol Scand. Jun. 1984;28(3):301-4. X-9. [pmid: 6741445].
112 Abboud TK, D'Onofrio L, Reyes A, et al. Isoflurane or halothane for cesarean section: comparative maternal and neonatal effects. Acta Anaesthesiol Scand. Oct. 1989;33(7):578-81. X-9. [pmid: 2816239].
113 Abboud TK, Dror A, Mosaad P, et al. Mini-dose intrathecal morphine for the relief of post-cesarean section pain: safety, efficacy, and ventilatory responses to carbon dioxide. Anesth Analg. Feb. 1988;67(2):137-43. X-9. [pmid: 3277478].
114 Abboud TK, Kim KC, Noueihed R, et al. Epidural bupivacaine, chloroprocaine, or lidocaine for cesarean section--maternal and neonatal effects. Anesth Analg. Oct. 1983;62(10):914-9. X-9. [pmid: 6614524].
115 Abboud TK, Kim SH, Henriksen EH, et al. Comparative maternal and neonatal effects of halothane and enflurane for cesarean section. Acta Anaesthesiol Scand. Oct. 1985;29(7):663-8. X-9. [pmid: 4072589].
116 Abboud TK, Lee K, Zhu J, et al. Prophylactic oral naltrexone with intrathecal morphine for cesarean section: effects on adverse reactions and analgesia. Anesth Analg. Oct. 1990;71(4):367-70. X-9. [pmid: 2205128].
117 Abboud TK, Moore M, Zhu J, et al. Epidural butorphanol or morphine for the relief of post-cesarean section pain: ventilatory responses to carbon dioxide. Anesth Analg. Sep. 1987;66(9):887-93. X-9. [pmid: 3113291].
118 Abboud TK, Sarkis F, Hung TT, et al. Effects of epidural anesthesia during labor on maternal plasma beta-endorphin levels. Anesthesiology. Jul. 1983;59(1):1-5. X-1. [pmid: 6305238].
119 Abboud TK, Zhu J, Gangolly J, et al. Transnasal butorphanol: a new method for pain relief in post-cesarean section pain. Acta Anaesthesiol Scand. Jan. 1991;35(1):14-8. X-9. [pmid: 2006593].
120 Abboud TK, Zhu J, Reyes A, et al. Effect of subarachnoid morphine on the incidence of spinal headache. Reg Anesth. Jan-Feb. 1992;17(1):34-6. X-9. [pmid: 1599892].
121 Abboud TK, Zhu J, Richardson M, et al. Desflurane: a new volatile anesthetic for cesarean section. Maternal and neonatal effects. Acta Anaesthesiol Scand. Aug. 1995;39(6):723-6. X-9. [pmid: 7484023].
122 Abboud TK, Zhu J, Richardson M, et al. Intravenous propofol vs thiamylal-isoflurane for caesarean section, comparative maternal and neonatal effects. Acta Anaesthesiol Scand. Feb. 1995;39(2):205-9. X-9. [pmid: 7793188].
123 Abd Rabbo S. Early oral hydration: a novel regimen for management after elective cesarean section. J Obstet Gynaecol (Tokyo 1995). Dec. 1995;21(6):563-7. X-9. [pmid: 8640466].
124 Abdelgadir M, Elbagir M, Eltom A, et al. Factors affecting perinatal morbidity and mortality in pregnancies complicated by diabetes mellitus in Sudan. Diabetes Res Clin Pract. Apr. 2003;60(1):41-7. X-1. [pmid: 12639764].
125 Abdel-Latif ME, Bajuk B, Oei J, et al. Does rural or urban residence make a difference to neonatal outcome in premature birth? A regional study in Australia. Arch Dis Child Fetal Neonatal Ed. Jul. 2006;91(4):F251-6. X-1. [pmid: 16428354].
126 Abd-El-Maeboud KH, Ibrahim MI, Shalaby DA, et al. Gum chewing stimulates early return of bowel motility after caesarean section. BJOG. Sep. 2009;116(10):1334-9. X-9. [pmid: 19523094].
127 Abdel-Razeq SS, Campbell K, Funai EF, et al. Normative postpartum intraabdominal pressure: potential implications in the diagnosis of abdominal compartment syndrome. Am J Obstet Gynecol. Aug. 2010;203(2):149 e1-4. X-1. [pmid: 20417482].
128 Abdulatif M, Taylouni E. Surgeon-controlled mivacurium administration during elective caesarean section. Can J Anaesth. Feb. 1995;42(2):96-102. X-1. [pmid: 7720168].
129 Abenhaim HA, Benjamin A, Koby RD, et al. Comparison of obstetric outcomes between on-call and patients' own obstetricians. CMAJ. Aug. 14. 2007;177(4):352-6. X-1. [pmid: 17698823].
130 Abenhaim HA, Fraser WD. Impact of pain level on second-stage delivery outcomes among women with epidural analgesia: results from the PEOPLE study. Am J Obstet Gynecol. Nov. 2008;199(5):500 e1-6. X-1, X-4e, X-5. [pmid: 18565489].
131 Abenhaim HA, Morin L, Benjamin A, et al. Effect of instrument preference for operative deliveries on obstetrical and neonatal outcomes. Eur J Obstet Gynecol Reprod Biol. Oct. 2007;134(2):164-8. X-1. [pmid: 17112650].
132 Abiodun MO, Ijaiya MA, Aboyeji PA. Awareness and knowledge of mother-to-child transmission of HIV among pregnant women. J Natl Med Assoc. Jul. 2007;99(7):758-63. X-1. [pmid: 17668641].
133 Abiodun MO, Ijaiya MA, Aboyeji PA, et al. Acceptability of measures aimed at preventing mother-to-child transmission of HIV among pregnant women. J Natl Med Assoc. Apr. 2008;100(4):406-10. X-1. [pmid: 18481479].
134 Abitbol MM, Castillo I, Taylor UB, et al. Vaginal birth after cesarean section: the patient's point of view. Am Fam Physician. Jan. 1993;47(1):129-34. X-1. [pmid: 8418576].
135 Abouleish A, Abouleish E, Camann W. Combined spinal-epidural analgesia in advanced labour. Can J Anaesth. Jul. 1994;41(7):575-8. X-1. [pmid: 8087904].
136 Abouleish E, Abboud T, Lechevalier T, et al. Rocuronium (Org 9426) for caesarean section. Br J Anaesth. Sep. 1994;73(3):336-41. X-1. [pmid: 7946860].
137 Abouleish E, Rawal N, Fallon K, et al. Combined intrathecal morphine and bupivacaine for cesarean section. Anesth Analg. Apr. 1988;67(4):370-4. X-9. [pmid: 3354872].
138 Abouleish E, Wingard LB Jr., de la Vega S, et al. Pancuronium in caesarean section and its placental transfer. Br J Anaesth. May. 1980;52(5):531-6. X-1. [pmid: 7387807].
139 Abouleish EI. Epinephrine improves the quality of spinal hyperbaric bupivacaine for cesarean section. Anesth Analg. May. 1987;66(5):395-400. X-9. [pmid: 3555162].
140 Abouleish EI. Epidural and intrathecal opioids in obstetrics: state of the art. Current Reviews for Nurse Anesthetists. 1992;14(26):210-216. X-1.
141 Abouleish EI, Abboud TK, Bikhazi G, et al. Rapacuronium for modified rapid sequence induction in elective caesarean section: neuromuscular blocking effects and safety compared with succinylcholine, and placental transfer. Br J Anaesth. Dec. 1999;83(6):862-7. X-9. [pmid: 10700783].
142 Abouleish EI, Rashid S, Haque S, et al. Ondansetron versus placebo for the control of nausea and vomiting during Caesarean section under spinal anaesthesia. Anaesthesia. May. 1999;54(5):479-82. X-9. [pmid: 10995148].
143 Abouzeid H, Aggarwal D, De Graaf F. Timing of planned repeated caesarean section: an enigma. J Obstet Gynaecol. Nov. 2007;27(8):798-801. X-1. [pmid: 18097897].
144 Abouzeid H, Thornton JG. Pre-term delivery by Caesarean section ‘en caul’: a case series. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):51-3. X-1. [pmid: 10413226].
145 Abramov Y, Elchalal U, Schenker JG. Obstetric outcome of in vitro fertilized pregnancies complicated by severe ovarian hyperstimulation syndrome: a multicenter study. Fertil Steril. Dec. 1998;70(6):1070-6. X-1. [pmid: 9848297].
146 Abramov Y, Ezra Y, Elchalal U, et al. Markedly elevated levels of inflammatory cytokines in maternal serum and peritoneal washing during arrested labor. Acta Obstet Gynecol Scand. Apr. 2004;83(4):358-63. X-1. [pmid: 15005783].
147 Abramov Y, Sand PK, Botros SM, et al. Risk factors for female anal incontinence: new insight through the Evanston-Northwestern twin sisters study. Obstet Gynecol. Oct. 2005;106(4):726-32. X-1. [pmid: 16199628].
148 Abramovici D, Goldwasser S, Mabie BC, et al. A randomized comparison of oral misoprostol versus Foley catheter and oxytocin for induction of labor at term. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1108-12. X-4d. [pmid: 10561627].
149 Abramovici H, Bornstein J, Ben-David Y, et al. Double-balloon instillation device for second-trimester abortion. Outcome in 340 consecutive cases. J Reprod Med. Jan. 1995;40(1):56-62. X-1. [pmid: 7722978].
150 Abramson D. More than just a scar. Midwifery Today Int Midwife. Spring. 2003;(65):27-9. X-1, X-2, X-3, X-4e, X-5. [pmid: 12710146].
151 Abu Hamad K, Abed Y, Abu Hamad B. Risk factors associated with preterm birth in the Gaza Strip: hospital-based case-control study. East Mediterr Health J. Sep-Oct. 2007;13(5):1132-41. X-1. [pmid: 18290407].
152 Abu-Ghazzeh YM, Barqawi R. An appraisal of computed tomography pelvimetry in patients with previous caesarean section. Mediterr Health J. Mar-May. 2000;6(2-3):260-4. X-1, X-4e, X-5.
153 Abu-Halaweh SA, Massad IM, Abu-Ali HM, et al. Rapid sequence induction and intubation with 1 mg/kg rocuronium bromide in cesarean section, comparison with suxamethonium. Saudi Med J. Sep. 2007;28(9):1393-6. X-1. [pmid: 17768467].
154 Abu-Heija A, al-Chalabi H, el-Iloubani N. Abruptio placentae: risk factors and perinatal outcome. J Obstet Gynaecol Res. Apr. 1998;24(2):141-4. X-1. [pmid: 9631603].
155 Abu-Heija A, Ali AM, Al-Dakheil S. Obstetrics and perinatal outcome of adolescent nulliparous pregnant women. Gynecol Obstet Invest. 2002;53(2):90-2. X-1. [pmid: 11961381].
156 Abu-Heija AT. Vaginal birth after one previous caesarean section: a Jordanian experience. J Obstet Gynaecol (Tokyo 1995). Feb. 1995;21(1):9-12. X-1. [pmid: 8591117].
157 Abu-Heija AT, Ali AM. Induction of labor in grand multiparous women and previous cesarean section: is it safe?. Gynecol Obstet Invest. 2002;53(2):121-4. X-1. [pmid: 11961388].
158 Abu-Heija AT, Jallad MF, Abukteish F. Maternal and perinatal outcome of pregnancies after the age of 45. J Obstet Gynaecol Res. Feb. 2000;26(1):27-30. X-1. [pmid: 10761327].
159 Abushama M, Ahmed B. Cesarean section on request. Saudi Med J. Dec. 2004;25(12):1820-3. X-1, X-2. [pmid: 15711647].
160 Achadi E, Scott S, Pambudi ES, et al. Midwifery provision and uptake of maternity care in Indonesia. Trop Med Int Health. Dec. 2007;12(12):1490-7. X-1. [pmid: 18076557].
161 Acharya G, Al-Sammarai MT, Patel N, et al. A randomized, controlled trial comparing effect of oral misoprostol and intravenous syntocinon on intra-operative blood loss during cesarean section. Acta Obstet Gynecol Scand. Mar. 2001;80(3):245-50. X-9. [pmid: 11207490].
162 Ackerman WE, Juneja MM, Kaczorowski DM, et al. A comparison of the incidence of pruritus following epidural opioid administration in the parturient. Can J Anaesth. Jul. 1989;36(4):388-91. X-9. [pmid: 2569364].
163 Ackermann-Liebrich U, Voegeli T, Gunter-Witt K, et al. Home versus hospital deliveries: follow up study of matched pairs for procedures and outcome. Zurich Study Team. BMJ. Nov. 23. 1996;313(7068):1313-8. X-1. [pmid: 8942694].
164 Adair CD, Sanchez-Ramos L, Whitaker D, et al. Trial of labor in patients with a previous lower uterine vertical cesarean section. Am J Obstet Gynecol. Mar. 1996;174(3):966-70. X-1. [pmid: 8633677].
165 Adair CD, Weeks JW, Barrilleaux S, et al. Oral or vaginal misoprostol administration for induction of labor: a randomized, double-blind trial. Obstet Gynecol. Nov. 1998;92(5):810-3. X-4d. [pmid: 9794674].
166 Adam I, Adam ES, Gerais AS. Randomized trial of ceftriaxone prophylaxis in elective cesarean section. Saudi Med J. Mar. 2005;26(3):500-1. X-3, X-4b, X-5. [pmid: 15806236].
167 Adam I, Hassan OA, Elhassan EM. Oral misoprostol vs. vaginal misoprostol for cervical ripening and labor induction. Int J Gynaecol Obstet. May. 2005;89(2):142-3. X-4d. [pmid: 15847879].
168 Adami J, Glimelius B, Cnattingius S, et al. Maternal and perinatal factors associated with non-Hodgkin's lymphoma among children. Int J Cancer. Mar. 15. 1996;65(6):774-7. X-1. [pmid: 8631590].
169 Adams DJ. Adequacy of labor epidural information for informed consent. Ph.D. 2007:122. X-1.
170 Adams EK, Nishimura B, Merritt RK, et al. Costs of poor birth outcomes among privately insured. J Health Care Finance. Spring. 2003;29(3):11-27. X-1. [pmid: 12635991].
171 Adeleye JA, Ogunseyinde AO. Hysterography after lower-uterine-segment caesarean section. Afr J Med Med Sci. Sep-Dec. 1984;13(3-4):155-60. X-1. [pmid: 6099977].
172 Adeniji OA, Oladokun A, Olayemi O, et al. Pre-induction cervical ripening: transcervical foley catheter versus intravaginal misoprostol. J Obstet Gynaecol. Feb. 2005;25(2):134-9. X-4d. [pmid: 15814391].
173 Adesina OA, Olayemi O. Fetal macrosomia at the University College Hospital, Ibadan: a 3-year review. J Obstet Gynaecol. Jan. 2003;23(1):30-3. X-1. [pmid: 12623478].
174 Adewuya AO, Ologun YA, Ibigbami OS. Post-traumatic stress disorder after childbirth in Nigerian women: prevalence and risk factors. BJOG. Mar. 2006;113(3):284-8. X-1. [pmid: 16487199].
175 Adibi JJ, Hauser R, Williams PL, et al. Maternal urinary metabolites of Di-(2-Ethylhexyl) phthalate in relation to the timing of labor in a US multicenter pregnancy cohort study. Am J Epidemiol. Apr. 15. 2009;169(8):1015-24. X-1. [pmid: 19251754].
176 Adigun TA, Amanor-Boadu SD, Soyannwo OA. Comparison of intravenous ephedrine with phenylephrine for the maintenance of arterial blood pressure during elective caesarean section under spinal anaesthesia. Afr J Med Med Sci. Mar. 2010;39(1):13-20. X-3, X-4b, X-5. [pmid: 20632667].
177 Adinma JI, Agbai AO. Influence of mode of delivery on twin births. Afr J Med Med Sci. Dec. 1996;25(4):377-9. X-1. [pmid: 9532311].
178 Adiyatulin AI, Gulyaeva NV. Effect of natural biocorrector Namivit on free-radical processes in abdominal delivery. Bull Exp Biol Med. Nov. 2002;134(5):457-9. X-1, X-3, X-4b, X-4e, X-5. [pmid: 12802451].
179 Adler G, Duchinski T, Jasinska A, et al. Fibrinogen fractions in the third trimester of pregnancy and in puerperium. Thromb Res. Mar. 15. 2000;97(6):405-10. X-1. [pmid: 10704649].
180 Adler-Levy Y, Lunenfeld E, Levy A. Obstetric outcome of twin pregnancies conceived by in vitro fertilization and ovulation induction compared with those conceived spontaneously. Eur J Obstet Gynecol Reprod Biol. Aug. 2007;133(2):173-8. X-1. [pmid: 17056174].
181 Adsumelli RS, Steinberg ES, Schabel JE, et al. Sequential compression device with thigh-high sleeves supports mean arterial pressure during Caesarean section under spinal anaesthesia. Br J Anaesth. Nov. 2003;91(5):695-8. X-9. [pmid: 14570793].
182 Agardh CD, Aberg A, Norden NE. Glucose levels and insulin secretion during a 75 g glucose challenge test in normal pregnancy. J Intern Med. Nov. 1996;240(5):303-9. X-1. [pmid: 8946813].
183 Agarwal N, Gupta A, Kriplani A, et al. Six hourly vaginal misoprostol versus intracervical dinoprostone for cervical ripening and labor induction. J Obstet Gynaecol Res. Jun. 2003;29(3):147-51. X-4d. [pmid: 12841697].
184 Agarwal R, Loganath A, Roy AC, et al. Effect of T-helper 1 cytokines on secretion of T-helper 2 cytokines by term trophoblast cells in culture. Gynecol Endocrinol. Oct. 2000;14(5):305-10. X-1. [pmid: 11109968].
185 Agostini A, De Guibert F, Salari K, et al. Adverse obstetric outcomes at term after hysteroscopic metroplasty. J Minim Invasive Gynecol. Jul-Aug. 2009;16(4):454-7. X-1. [pmid: 19573822].
186 Agrawal RK, Lui K, Gupta JM. Neonatal hypoglycaemia in infants of diabetic mothers. J Paediatr Child Health. Aug. 2000;36(4):354-6. X-1. [pmid: 10940170].
187 Ahmad I, Afshan G. Knowledge and attitudes of Pakistani women towards anaesthesia techniques for caesarean section. J Pak Med Assoc. Apr. 2011;61(4):359-62. X-1. [pmid: 21465973].
188 Ahmad-Nia S, Delavar B, Eini-Zinab H, et al. Caesarean section in the Islamic Republic of Iran: prevalence and some sociodemographic correlates. East Mediterr Health J. Nov-Dec. 2009;15(6):1389-98. X-1. [pmid: 20218129].
189 Ahmed B, Abu Nahia F, Abushama M. Routine cervical dilatation during elective cesarean section and its influence on maternal morbidity: a randomized controlled study. J Perinat Med. 2005;33(6):510-3. X-1. [pmid: 16318613].
190 Ahmed ET, Mirghani OA, Gerais AS, et al. Ceftriaxone versus ampicillin/cloxacillin as antibiotic prophylaxis in elective caesarean section. East Mediterr Health J. May. 2004;10(3):277-88. X-3, X-4b, X-4e, X-5. [pmid: 16212202].
191 Ahmed R. Magnesium sulphate as an anticonvulsant in the management of eclampsia. J Coll Physicians Surg Pak. Oct. 2004;14(10):605-7. X-1. [pmid: 15456550].
192 Ahmed SM, Khan RM, Bano S, et al. Is spinal anaesthesia safe in pre-eclamptic toxaemia patients?. J Indian Med Assoc. May. 1999;97(5):165-8. X-1. [pmid: 10652883].
193 Ahn HJ, Choi DH, Kim CS. Paraesthesia during the needle-through-needle and the double segment technique for combined spinal epidural anaesthesia. Anaesthesia. Jul. 2006;61(7):634-8. X-9. [pmid: 16792607].
194 Ahsan S, Kitchen N, Jenkins C, et al. Incidence of postdural puncture headache following spinal anaesthesia for lower segment caesarean section with the 25 gauge polymedic spinal needle. J Pak Med Assoc. Dec. 1996;46(12):278-81. X-1, X-3, X-4b, X-4e, X-5. [pmid: 9000830].
195 Ahsinger J. Making a difference in labor and delivery. Fla Nurse. Sep. 2002;50(3):23. X-1, X-2, X-3, X-4e, X-5. [pmid: 12387103].
196 Airas U, Heinonen S. Clinical significance of true umbilical knots: a population-based analysis. Am J Perinatol. Apr. 2002;19(3):127-32. X-1. [pmid: 12012287].
197 Aird IA, Luckas MJ, Buckett WM, et al. Effects of intrapartum hydrotherapy on labour related parameters. Aust N Z J Obstet Gynaecol. May. 1997;37(2):137-42. X-1. [pmid: 9222454].
198 Airey RJ, Farrar D, Duley L. Alternative positions for the baby at birth before clamping the umbilical cord. Cochrane Database of Systematic Reviews. 2010;(10). X-1, X-2.
199 Aisien AO, Towobola OA, Otubu JA, et al. Umbilical cord venous progesterone at term delivery in relation to mode of delivery. Int J Gynaecol Obstet. Oct. 1994;47(1):27-31. X-1. [pmid: 7813748].
200 Aitken MA, Rice G, Brennecke S. Relative abundance of human placental phospholipase A2 messenger RNA in late pregnancy. Prostaglandins. Apr. 1992;43(4):361-70. X-1. [pmid: 1376934].
201 Aitken ME, Warden CR, Critchlow CW. The effect of health maintenance organization vs commercial insurance status on obstetrical management and outcome. Arch Pediatr Adolesc Med. Nov. 1997;151(11):1104-8. X-1. [pmid: 9369871].
202 Akasheh HF, Amarin V. Caesarean sections at Queen Alia Military Hospital, Jordan: a six-year review. East Mediterr Health J. Jan. 2000;6(1):41-5. X-1. [pmid: 11370339].
203 Akerlund M, Bossmar T, Brouard R, et al. Receptor binding of oxytocin and vasopressin antagonists and inhibitory effects on isolated myometrium from preterm and term pregnant women. Br J Obstet Gynaecol. Oct. 1999;106(10):1047-53. X-1. [pmid: 10519430].
204 Akerman N, Saxena S, Wilson R, et al. Effect of intrathecal diamorphine on block height during spinal anaesthesia for Caesarean section with bupivacaine. Br J Anaesth. Jun. 2005;94(6):843-7. X-9. [pmid: 15849209].
205 Akerud A, Dubicke A, Sennstrom M, et al. Differences in heparan sulfate production in cervical fibroblast cultures from women undergoing term and preterm delivery. Acta Obstet Gynecol Scand. 2008;87(11):1220-8. X-1. [pmid: 18949584].
206 Akhtaruzzaman AK, Banik D, Akhtar MF, et al. Prolonged analgesia by adding midazolam and hyperbaric bupivacaine in subarachnoid block for lower uterine caesarian section. Mymensingh Med J. Oct. 2010;19(4):569-75. X-9. [pmid: 20956902].
207 Akin Y, Comert S, Turan C, et al. Macrosomic newborns: a 3-year review. Turk J Pediatr. Jul-Aug. 2010;52(4):378-83. X-1. [pmid: 21043383].
208 Akinola SE, Manne NC, Archibong EI, et al. Teenagers obstetric performance. Saudi Med J. Jul. 2001;22(7):580-4. X-1. [pmid: 11479637].
209 Akoury HA, Brodie G, Caddick R, et al. Active management of labor and operative delivery in nulliparous women. Am J Obstet Gynecol. Feb. 1988;158(2):255-8. X-1. [pmid: 3341403].
210 Akpala CO. An evaluation of the knowledge and practices of trained traditional birth attendants in Bodinga, Sokoto State, Nigeria. J Trop Med Hyg. Feb. 1994;97(1):46-50. X-1. [pmid: 8107173].
211 Akre O, Ekbom A, Hsieh CC, et al. Testicular nonseminoma and seminoma in relation to perinatal characteristics. J Natl Cancer Inst. Jul. 3. 1996;88(13):883-9. X-1. [pmid: 8656440].
212 Akturk G, Kiral N, Barlak A, et al. The choice of anaesthetic technique for caesarean section does not affect plasma beta-endorphin levels in the neonate. Eur J Anaesthesiol. Sep. 1995;12(5):525-7. X-1. [pmid: 8542863].
213 Akwuruoha E, Kamanu C, Onwere S, et al. Grandmultiparity and pregnancy outcome in Aba, Nigeria: a case-control study. Arch Gynecol Obstet. Feb. 2011;283(2):167-72. X-1. [pmid: 19967382].
214 Akyol D, Mungan T, Unsal A, et al. Prelabour rupture of the membranes at term--no advantage of delaying induction for 24 hours. Aust N Z J Obstet Gynaecol. Aug. 1999;39(3):291-5. X-4e. [pmid: 10554936].
215 Al Bunyan M, Abo-Talib Z. Outcome of pregnancies in epileptic women: a study in Saudi Arabia. Seizure. Feb. 1999;8(1):26-9. X-1. [pmid: 10091844].
216 Al Duraihimh H, Ghamdi G, Moussa D, et al. Outcome of 234 pregnancies in 140 renal transplant recipients from five middle eastern countries. Transplantation. Mar. 27. 2008;85(6):840-3. X-1. [pmid: 18360265].
217 Al Ramadhani S, Mohamed LA, Rocke DA, et al. Sternomental distance as the sole predictor of difficult laryngoscopy in obstetric anaesthesia. Br J Anaesth. Sep. 1996;77(3):312-6. X-1. [pmid: 8949801].
218 Al-Abdulhadi O, Biehl D, Ong B, et al. Hyperbaric spinal for elective Cesarean section--ropivacaine vs bupivacaine. Middle East J Anesthesiol. Jun. 2007;19(2):385-96. X-9. [pmid: 17684878].
219 Aladangady N, McHugh S, Aitchison TC, et al. Infants' blood volume in a controlled trial of placental transfusion at preterm delivery. Pediatrics. Jan. 2006;117(1):93-8. X-3, X-4e. [pmid: 16396865].
220 Alahuhta S, Kangas-Saarela T, Hollmen AI, et al. Visceral pain during caesarean section under spinal and epidural anaesthesia with bupivacaine. Acta Anaesthesiol Scand. Feb. 1990;34(2):95-8. X-9. [pmid: 2407045].
221 Alahuhta S, Rasanen J, Jouppila P, et al. The effects of epidural ropivacaine and bupivacaine for cesarean section on uteroplacental and fetal circulation. Anesthesiology. Jul. 1995;83(1):23-32. X-9. [pmid: 7605013].
222 Alahuhta S, Rasanen J, Jouppila R, et al. Effects of extradural bupivacaine with adrenaline for caesarean section on uteroplacental and fetal circulation. Br J Anaesth. Dec. 1991;67(6):678-82. X-1. [pmid: 1768537].
223 Alam M, Raza SJ, Sherali AR, et al. Neonatal complications in infants born to diabetic mothers. J Coll Physicians Surg Pak. Mar. 2006;16(3):212-5. X-1. [pmid: 16542603].
224 Alanis MC, Robinson CJ, Hulsey TC, et al. Early-onset severe preeclampsia: induction of labor vs elective cesarean delivery and neonatal outcomes. Am J Obstet Gynecol. Sep. 2008;199(3):262 e1-6. X-1. [pmid: 18771976].
225 Albers LL, Anderson D, Cragin L, et al. The relationship of ambulation in labor to operative delivery. J Nurse Midwifery. Jan-Feb. 1997;42(1):4-8. X-1. [pmid: 9037929].
226 Albers LL, Savitz DA. Hospital setting for birth and use of medical procedures in low-risk women. J Nurse Midwifery. Nov-Dec. 1991;36(6):327-33. X-1. [pmid: 1757818].
227 Albina ML, Colomina MT, Sanchez DJ, et al. Interactions of caffeine and restraint stress during pregnancy in mice. Exp Biol Med (Maywood). Oct. 2002;227(9):779-85. X-1. [pmid: 12324657].
228 Albrechtsen S, Rasmussen S, Reigstad H, et al. Evaluation of a protocol for selecting fetuses in breech presentation for vaginal delivery or cesarean section. Am J Obstet Gynecol. Sep. 1997;177(3):586-92. X-1. [pmid: 9322628].
229 Alcalay M, Hourvitz A, Reichman B, et al. Prelabour rupture of membranes at term: early induction of labour versus expectant management. Eur J Obstet Gynecol Reprod Biol. Dec. 27. 1996;70(2):129-33. X-3, X-4e, X-5. [pmid: 9119091].
230 Alderson P. Coming home to an empty cot. Nurs Times. Aug. 19-25. 1987;83(33):42-3. X-1. [pmid: 3650894].
231 Alekwe LO, Kuti O, Orji EO, et al. Comparison of ceftriaxone versus triple drug regimen in the prevention of cesarean section infectious morbidities. J Matern Fetal Neonatal Med. Sep. 2008;21(9):638-42. X-9. [pmid: 18828055].
232 Alessandri LM, Stanley FJ, Read AW. A case-control study of intrapartum stillbirths. Br J Obstet Gynaecol. Sep. 1992;99(9):719-23. X-1, X-2. [pmid: 1420008].
233 Alexander JM, Leveno KJ, Hauth J, et al. Fetal injury associated with cesarean delivery. Obstet Gynecol. Oct. 2006;108(4):885-90. X-1, X-2. [pmid: 17012450].
234 Alexander JM, Leveno KJ, Rouse D, et al. Cesarean delivery for the second twin. Obstet Gynecol. Oct. 2008;112(4):748-52. X-1. [pmid: 18827115].
235 Alexander JM, Sharma SK, McIntire DD, et al. Epidural analgesia lengthens the Friedman active phase of labor. Obstet Gynecol. Jul. 2002;100(1):46-50. X-1, X-2. [pmid: 12100802].
236 Alexander JM, Sharma SK, McIntire DD, et al. Intensity of labor pain and cesarean delivery. Anesth Analg. Jun. 2001;92(6):1524-8. X-1. [pmid: 11375838].
237 Alexander S, Boulvain M, Ceysens G, et al. Repeat digital cervical assessment in pregnancy for identifying women at risk of preterm labour. Cochrane Database of Systematic Reviews. 2010;(6). X-1, X-2.
238 Alexander S, Dodds L, Armson BA. Perinatal outcomes in women with asthma during pregnancy. Obstet Gynecol. Sep. 1998;92(3):435-40. X-1. [pmid: 9721785].
239 Alexandersson O, Bixo M, Hogberg U. Evidence-based changes in term breech delivery practice in Sweden. Acta Obstet Gynecol Scand. Jun. 2005;84(6):584-7. X-1. [pmid: 15901271].
240 Al-Fifi S, Al-Binali A, Al-Shahrani M, et al. Congenital anomalies and other perinatal outcomes in ICSI vs. naturally conceived pregnancies: a comparative study. J Assist Reprod Genet. Jul. 2009;26(7):377-81. X-1. [pmid: 19680803].
241 Alfirevic Z, Gyte GM, Dou L. Different classes of antibiotics given to women routinely for preventing infection at caesarean section. Cochrane Database of Systematic Reviews. 2010;(10). X-1.
242 Alfirevic Z, Luckas M, Walkinshaw SA, et al. A randomised comparison between amniotic fluid index and maximum pool depth in the monitoring of post-term pregnancy. Br J Obstet Gynaecol. Feb. 1997;104(2):207-11. X-4e. [pmid: 9070140].
243 Alfirevic Z, Luckas M, Walkinshaw SA, et al. A randomized comparison between amniotic fluid index and maximum pool depth in the monitoring of post-term pregnancy. reprinted from the British Journal of Obstetrics and Gynaecology, February 1997, Vol 104, pp. 207-211, Copyright 1997 Blackwell Science, Oxford. Neonatal Intensive Care. 1997;10(4):30-34. X-4e, X-5.
244 Algovik M, Lagercrantz J, Westgren M, et al. No mutations found in candidate genes for dystocia. Hum Reprod. Oct. 1999;14(10):2451-4. X-1, X-2. [pmid: 10527967].
245 Alhaj AM, Radi EA, Adam I. Epidemiology of preterm birth in Omdurman Maternity hospital, Sudan. J Matern Fetal Neonatal Med. Feb. 2010;23(2):131-4. X-1. [pmid: 19565427].
246 Alhashemi JA, Alotaibi QA, Mashaat MS, et al. Intravenous acetaminophen vs oral ibuprofen in combination with morphine PCIA after Cesarean delivery. Can J Anaesth. Dec. 2006;53(12):1200-6. X-4b, X-4e. [pmid: 17142654].
247 Alhashemi JA, Crosby ET, Grodecki W, et al. Treatment of intrathecal morphine-induced pruritus following caesarean section. Can J Anaesth. Oct. 1997;44(10):1060-5. X-3, X-4b. [pmid: 9350364].
248 Ali AM, Abu-Heija AT. Obstetric and perinatal outcome of women para > or = 5 including one lower segment cesarean section. J Obstet Gynaecol Res. Jun. 2002;28(3):163-5. X-1. [pmid: 12214833].
249 Ali M, Ahmed KM, Kuroiwa C. Emergency obstetric care in Punjab, Pakistan: improvement needed. Eur J Contracept Reprod Health Care. Jun. 2008;13(2):201-7. X-1. [pmid: 18465484].
250 Ali M, Ayaz M, Rizwan H, et al. Emergency obstetric care availability, accessibility and utilization in eight districts in Pakistan's North West Frontier Province. J Ayub Med Coll Abbottabad. Oct-Dec. 2006;18(4):10-5. X-1. [pmid: 17591002].
251 Ali M, Hotta M, Kuroiwa C, et al. Emergency obstetric care in Pakistan: potential for reduced maternal mortality through improved basic EmOC facilities, services, and access. Int J Gynaecol Obstet. Oct. 2005;91(1):105-12. X-1. [pmid: 16098977].
252 Aliefendioglu D, Yurdakok M, Oran O, et al. Neonatal morbidity and mortality associated with maternal HELLP syndrome. Turk J Pediatr. Oct-Dec. 2000;42(4):308-11. X-1. [pmid: 11196748].
253 Al-Inany H, Youssef G, Abd ElMaguid A, et al. Value of subcutaneous drainage system in obese females undergoing cesarean section using pfannenstiel incision. Gynecol Obstet Invest. 2002;53(2):75-8. X-1. [pmid: 11961377].
254 Al-Jufairi ZA, Sandhu AK, Al-Durazi KA. Risk factors of uterine rupture. Saudi Med J. Aug. 2001;22(8):702-4. X-1. [pmid: 11573117].
255 Al-Kadri H, Sabr Y, Al-Saif S, et al. Failed individual and sequential instrumental vaginal delivery: contributing risk factors and maternal-neonatal complications. Acta Obstet Gynecol Scand. Jul. 2003;82(7):642-8. X-1. [pmid: 12790846].
256 Allahbadia GN, Vaidya PR. Squatting position for delivery. J Indian Med Assoc. Jan. 1993;91(1):13-6. X-4e, X-5. [pmid: 8491972].
257 Allaire AD, Fisch J, McMahon MJ. Subcutaneous drain vs. suture in obese women undergoing cesarean delivery. A prospective, randomized trial. J Reprod Med. Apr. 2000;45(4):327-31. X-3, X-4b, X-5. [pmid: 10804490].
258 Allam J, Malhotra S, Hemingway C, et al. Epidural lidocaine-bicarbonate-adrenaline vs levobupivacaine for emergency Caesarean section: a randomised controlled trial. Anaesthesia. Mar. 2008;63(3):243-9. X-4e, X-5. [pmid: 18289229].
259 Allegretti J. Delicate balance: the emerging issue of maternal-fetal conflict. America (NY). Mar. 2. 1991;164(8):238-9. 249. 50. X-1. [pmid: 16144134].
260 Allen JE. C-sections do reduce newborns' herpes risk: a major study finds that a woman's chance of infecting her baby depends on how doctors and nurses manage the delivery. Los Angeles Times -- Southern California Edition (Front Page). 2003:F3-F3. X-1.
261 Allen RW, James MF, Uys PC. Attenuation of the pressor response to tracheal intubation in hypertensive proteinuric pregnant patients by lignocaine, alfentanil and magnesium sulphate. Br J Anaesth. Feb. 1991;66(2):216-23. X-3, X-4b, X-4e. [pmid: 1817624].
262 Allen TK, George RB, White WD, et al. A double-blind, placebo-controlled trial of four fixed rate infusion regimens of phenylephrine for hemodynamic support during spinal anesthesia for cesarean delivery. Anesth Analg. Nov. 2010;111(5):1221-9. X-9. [pmid: 20495139].
263 Allen VM, Jilwah N, Joseph KS, et al. The influence of hospital closures in Nova Scotia on perinatal outcomes. J Obstet Gynaecol Can. Dec. 2004;26(12):1077-85. X-1. [pmid: 15607044].
264 Allen VM, O'Connell CM, Baskett TF. Cumulative economic implications of initial method of delivery. Obstet Gynecol. Sep. 2006;108(3 Pt 1):549-55. X-1. [pmid: 16946214].
265 Allen VM, O'Connell CM, Farrell SA, et al. Economic implications of method of delivery. Am J Obstet Gynecol. Jul. 2005;193(1):192-7. X-1. [pmid: 16021078].
266 Allott HA, Palmer CR. Sweeping the membranes: a valid procedure in stimulating the onset of labour?. Br J Obstet Gynaecol. Oct. 1993;100(10):898-903. X-4e, X-5. [pmid: 8217970].
267 Almeida C, Coutinho E, Moreira D, et al. Myasthenia gravis and pregnancy: anaesthetic management--a series of cases. Eur J Anaesthesiol. Nov. 2010;27(11):985-90. X-1. [pmid: 20733499].
268 Almeida ML, Santana PA, Guimaraes AM, et al. Asthma and pregnancy: repercussions for neonates. J Bras Pneumol. Jun. 2010;36(3):293-300. X-1. [pmid: 20625665].
269 Almstrom H, Axelsson O, Cnattingius S, et al. Comparison of umbilical-artery velocimetry and cardiotocography for surveillance of small-for-gestational-age fetuses. Lancet. Oct. 17. 1992;340(8825):936-40. X-4e. [pmid: 1357349].
270 Almstrom H, Ekman G, Granstrom L. Preinductive cervical ripening with PgE2 gel in term pregnant women with ultrasonically diagnosed intra-uterine growth-retarded fetuses. Acta Obstet Gynecol Scand. 1991;70(7-8):555-9. X-1, X-4d, X-4e. [pmid: 1785270].
271 Almstrom H, Granstrom L, Ekman G. Serial antenatal monitoring compared with labor induction in post-term pregnancies. Acta Obstet Gynecol Scand. Sep. 1995;74(8):599-603. X-1. [pmid: 7660763].
272 Al-Mufti R, McCarthy A, Fisk NM. Survey of obstetricians' personal preference and discretionary practice. Eur J Obstet Gynecol Reprod Biol. May. 1997;73(1):1-4. X-1. [pmid: 9175681].
273 Al-Mulhim AA, Abu-Heija A, Al-Jamma F, et al. Pre-eclampsia: maternal risk factors and perinatal outcome. Fetal Diagn Ther. Jul-Aug. 2003;18(4):275-80. X-1. [pmid: 12835589].
274 Alper BS. Evidence-based medicine. Oral misoprostol and vaginal dinoprostone have similar efficacy and safety. Clinical Advisor for Nurse Practitioners. 2006;9(10):123-123. X-4d.
275 Alper BS. Evidence-based medicine. Prenatal steroids reduce severity of neonatal lung disease but increase rate of cesarean delivery. Clinical Advisor for Nurse Practitioners. 2007;10(1):128-128. X-4e.
276 Alpini D, Corti A, Brusa E, et al. Septal deviation in newborn infants. Int J Pediatr Otorhinolaryngol. Apr. 1986;11(2):103-7. X-3. [pmid: 3744693].
277 Al-Saleh E, Nandakumaran M, Al-Harmi J, et al. Maternal-fetal status of copper, iron, molybdenum, selenium, and zinc in obese pregnant women in late gestation. Biol Trace Elem Res. Nov. 2006;113(2):113-23. X-1. [pmid: 17194914].
278 Al-Saleh E, Nandakumaran M, Al-Rashdan I, et al. Maternal-foetal status of copper, iron, molybdenum, selenium and zinc in obese gestational diabetic pregnancies. Acta Diabetol. Sep. 2007;44(3):106-13. X-1. [pmid: 17721748].
279 Al-Saleh E, Nandakumaran M, Al-Shammari M, et al. Assessment of maternal-fetal status of some essential trace elements in pregnant women in late gestation: relationship with birth weight and placental weight. J Matern Fetal Neonatal Med. Jul. 2004;16(1):9-14. X-1. [pmid: 15370076].
280 Al-Saleh E, Nandakumaran M, Al-Shammari M, et al. Maternal-fetal status of copper, iron, molybdenum, selenium and zinc in patients with gestational diabetes. J Matern Fetal Neonatal Med. Jul. 2004;16(1):15-21. X-1. [pmid: 15370077].
281 Al-Saleh E, Nandakumaran M, Al-Shammari M, et al. Maternal-fetal status of copper, iron, molybdenum, selenium and zinc in insulin-dependent diabetic pregnancies. Arch Gynecol Obstet. Mar. 2005;271(3):212-7. X-1. [pmid: 15175885].
282 Althabe O, Labarrere C, Telenta M. Maternal vascular lesions in placentae of small-for-gestational-age infants. Placenta. May-Jun. 1985;6(3):265-76. X-1. [pmid: 4022955].
283 Althaus JE, Petersen S, Driggers R, et al. Cephalopelvic disproportion is associated with an altered uterine contraction shape in the active phase of labor. Am J Obstet Gynecol. Sep. 2006;195(3):739-42. X-1. [pmid: 16949406].
284 Althaus JE, Petersen SM, Fox HE, et al. Can electronic fetal monitoring identify preterm neonates with cerebral white matter injury?. Obstet Gynecol. Mar. 2005;105(3):458-65. X-1. [pmid: 15738008].
285 Altieri C, Maruotti G, Natale C, et al. In vitro survival of Listeria monocytogenes in human amniotic fluid. Zentralbl Hyg Umweltmed. Sep. 1999;202(5):377-82. X-1. [pmid: 10546327].
286 Alur P, Kodiyanplakkal P, Del Rosario A, et al. Epidemiology of infants of diabetic mothers in indigent Micronesian population-Guam experience. Pac Health Dialog. Sep. 2002;9(2):219-21. X-1. [pmid: 14736104].
287 Alvarez M, Lockwood CJ, Ghidini A, et al. Prophylactic and emergent arterial catheterization for selective embolization in obstetric hemorrhage. Am J Perinatol. Sep-Nov. 1992;9(5-6):441-4. X-1. [pmid: 1418152].
288 Alves B, Sheikh A. Investigating the relationship between affluence and elective caesarean sections. BJOG. Jul. 2005;112(7):994-6. X-1. [pmid: 15958007].
289 Alvino G, Cozzi V, Radaelli T, et al. Maternal and fetal fatty acid profile in normal and intrauterine growth restriction pregnancies with and without preeclampsia. Pediatr Res. Dec. 2008;64(6):615-20. X-1. [pmid: 19034199].
290 Al-Waili NS. Efficacy and safety of repeated postoperative administration of intramuscular diclofenac sodium in the treatment of post-cesarean section pain: a double-blind study. Arch Med Res. Mar-Apr. 2001;32(2):148-54. X-9. [pmid: 11343813].
291 Al-Waili NS, Saloom KY. Effects of topical honey on post-operative wound infections due to gram positive and gram negative bacteria following caesarean sections and hysterectomies. Eur J Med Res. Mar. 26. 1999;4(3):126-30. X-9. [pmid: 10085281].
292 Aly H, Hammad T, Nada A, et al. Maternal obesity, associated complications and risk of prematurity. J Perinatol. Jul. 2010;30(7):447-51. X-1. [pmid: 19693021].
293 Al-Zirqi I, Stray-Pedersen B, Forsen L, et al. Uterine rupture after previous caesarean section. BJOG. Jun. 2010;117(7):809-20. X-1. [pmid: 20236103].
294 Amano K, Saito K, Shoda T, et al. Elective induction of labor at 39 weeks of gestation: a prospective randomized trial. J Obstet Gynaecol Res. Feb. 1999;25(1):33-7. X-4e, X-5. [pmid: 10067011].
295 Amato MP, Portaccio E, Ghezzi A, et al. Pregnancy and fetal outcomes after interferon-beta exposure in multiple sclerosis. Neurology. Nov. 16. 2010;75(20):1794-802. X-1. [pmid: 21079181].
296 Ambrose FP. A retrospective study of the effect of postoperative indomethacin rectal suppositories on the need for narcotic analgesia in patients who had a cesarean delivery while they were under regional anesthesia. Am J Obstet Gynecol. Jun. 2001;184(7):1544-7. discussion 1547-8. X-1. [pmid: 11408878].
297 Ambrus CM, Choi TS, Weintraub DH, et al. Studies on the prevention of respiratory distress syndrome of infants due to hyaline membrane disease with plasminogen. Semin Thromb Hemost. Jul. 1975;2(1):42-51. X-4e. [pmid: 798269].
298 Ameh CA, Bishop S, Kongnyuy E, et al. Challenges to the provision of emergency obstetric care in Iraq. Matern Child Health J. Jan. 2011;15(1):4-11. X-1. [pmid: 19946792].
299 Amer-Wahlin I, Hellsten C, Noren H, et al. Cardiotocography only versus cardiotocography plus ST analysis of fetal electrocardiogram for intrapartum fetal monitoring: a Swedish randomised controlled trial. Lancet. Aug. 18. 2001;358(9281):534-8. X-3, X-4, X-5. [pmid: 11520523].
300 Amin AF, Mohammed MS, Sayed GH, et al. Prophylactic transcervical amnioinfusion in laboring women with oligohydramnios. Int J Gynaecol Obstet. May. 2003;81(2):183-9. X-4e. [pmid: 12706276].
301 Amin-Hanjani S, Corcoran J, Chatwani A. Cold therapy in the management of postoperative cesarean section pain. Am J Obstet Gynecol. Jul. 1992;167(1):108-9. X-9. [pmid: 1442907].
302 Amini SB, Catalano PM, Mann LI. Births to unmarried mothers: trends and obstetric outcomes. Womens Health Issues. Sep-Oct. 1996;6(5):264-72. X-1. [pmid: 8870505].
303 Amir AliAkbari S, Dabiri F, Bakhshori Z, et al. Effects of increased intravenous hydration on the outcome of labor in nulliparous women at Shariati Hospital in Bandar Abbas, 2003. SBMU Faculty of Nursing & Midwifery Quarterly. 2004;14(46):49-49. X-7.
304 Amoa AB, Klufio CA, Arua S, et al. A case-control study of primary caesarean section at the Port Moresby General Hospital, Papua New Guinea, to identify epidemiological predictors of abdominal delivery. P N G Med J. Sep-Dec. 1997;40(3-4):119-26. X-1. [pmid: 10750408].
305 Amon E, Lipshitz J, Sibai BM, et al. Quantitative analysis of amniotic fluid phospholipids in diabetic pregnant women. Obstet Gynecol. Sep. 1986;68(3):373-8. X-1. [pmid: 3737062].
306 Amon E, Shyken JM, Sibai BM. How small is too small and how early is too early? A survey of American obstetricians specializing in high-risk pregnancies. Am J Perinatol. Jan. 1992;9(1):17-21. X-1. [pmid: 1550626].
307 Ananth CV, Joseph Ks K, Smulian JC. Trends in twin neonatal mortality rates in the United States, 1989 through 1999: influence of birth registration and obstetric intervention. Am J Obstet Gynecol. May. 2004;190(5):1313-21. X-1. [pmid: 15167835].
308 Anate M, Akeredolu O. Pregnancy outcome in elderly primigravidae at University of Ilorin Teaching Hospital, Nigeria. East Afr Med J. Aug. 1996;73(8):548-51. X-1. [pmid: 8898473].
309 Ande AB, Ezeanochie MC, Olagbuji BN. Induction of labour: determinants and implications of failure to keep an initial appointment in a developing country. J Obstet Gynaecol. May. 2010;30(4):367-9. X-1. [pmid: 20455719].
310 Anderberg E, Kallen K, Berntorp K. The impact of gestational diabetes mellitus on pregnancy outcome comparing different cut-off criteria for abnormal glucose tolerance. Acta Obstet Gynecol Scand. Dec. 2010;89(12):1532-7. X-1. [pmid: 21050147].
311 Andersch B, Svensson A, Hansson L. Characteristics of hypertension in pregnancy. A retrospective study of 261 consecutive cases. Acta Obstet Gynecol Scand Suppl. 1984;118:33-8. X-1. [pmid: 6587726].
312 Andersen AS, Berthelsen JG, Bergholt T. Venous thromboembolism in pregnancy: prophylaxis and treatment with low molecular weight heparin. Acta Obstet Gynecol Scand. 2010;89(1):15-21. X-1. [pmid: 19916891].
313 Andersen O, Kuhl C. Adipocyte insulin receptor binding and lipogenesis at term in normal pregnancy. Eur J Clin Invest. Dec. 1988;18(6):575-81. X-1. [pmid: 3147184].
314 Andersen WA, Harbert GM Jr. Conservative management of pre-eclamptic and eclamptic patients: a re-evaluation. Am J Obstet Gynecol. Oct. 1. 1977;129(3):260-7. X-1. [pmid: 900196].
315 Anderson GM, Lomas J. Explaining variations in cesarean section rates: patients, facilities or policies?. Can Med Assoc J. Feb. 1. 1985;132(3):253-6. 259. X-1, X-3, X-4e, X-5. [pmid: 3967160].
316 Anderson L, Martin W, Higgins C, et al. The effect of progesterone on myometrial contractility, potassium channels, and tocolytic efficacy. Reprod Sci. Nov. 2009;16(11):1052-61. X-1. [pmid: 19602723].
317 Anderson T. Caesarean section for non-medical reasons at term. Pract Midwife. Sep. 2006;9(8):34-5. X-1. [pmid: 16989416].
318 Andersson T, Lorentzen B, Hogdahl H, et al. Thrombin-inhibitor complexes in the blood during and after delivery. Thromb Res. Apr. 15. 1996;82(2):109-17. X-1. [pmid: 9163064].
319 Andolf E, Thorsell M, Kallen K. Cesarean delivery and risk for postoperative adhesions and intestinal obstruction: a nested case-control study of the Swedish Medical Birth Registry. Am J Obstet Gynecol. Oct. 2010;203(4):406 e1-6. X-1. [pmid: 20875502].
320 Andreasson B, Bock JE, Larsen J. Induction of labor. A double-blind randomized controlled study of prostaglandin E2 vaginal suppositories compared with intranasal oxytocin and with sequential treatment. Acta Obstet Gynecol Scand. 1985;64(2):157-61. X-4d. [pmid: 3885670].
321 Andres RL, Day MC, Larrabee K. Recent cocaine use is not associated with fetal acidemia or other manifestations of intrapartum fetal distress. Am J Perinatol. 2000;17(2):63-7. X-1. [pmid: 11023163].
322 Andrews WW, Hauth JC, Cliver SP, et al. Randomized clinical trial of extended spectrum antibiotic prophylaxis with coverage for Ureaplasma urealyticum to reduce post-cesarean delivery endometritis. Obstet Gynecol. Jun. 2003;101(6):1183-9. X-9. [pmid: 12798523].
323 Andrews WW, Ramin SM, Maberry MC, et al. Effect of type of anesthesia on blood loss at elective repeat cesarean section. Am J Perinatol. May. 1992;9(3):197-200. X-9. [pmid: 1575842].
324 Andrist LC. The implications of objectification theory for women's health: menstrual suppression and “maternal request” cesarean delivery. Health Care Women Int. May. 2008;29(5):551-65. X-1, X-2. [pmid: 18437600].
325 Aneiros F, Vazquez M, Valino C, et al. Does epidural versus combined spinal-epidural analgesia prolong labor and increase the risk of instrumental and cesarean delivery in nulliparous women?. J Clin Anesth. Mar. 2009;21(2):94-7. X-1. [pmid: 19329011].
326 Angeja AC, Washington AE, Vargas JE, et al. Chilean women's preferences regarding mode of delivery: which do they prefer and why?. BJOG. Nov. 2006;113(11):1253-8. X-1. [pmid: 17014679].
327 Angle P, Thompson D, Halpern S, et al. Second stage pushing correlates with headache after unintentional dural puncture in parturients. Can J Anaesth. Sep. 1999;46(9):861-6. X-1. [pmid: 10490155].
328 Angle PJ, Halpern SH, Leighton BL, et al. A randomized controlled trial examining the effect of naproxen on analgesia during the second day after cesarean delivery. Anesth Analg. Sep. 2002;95(3):741-5. table of contents. X-9. [pmid: 12198063].
329 Annapoorna V, Arulkumaran S, Anandakumar C, et al. External cephalic version at term with tocolysis and vibroacoustic stimulation. Int J Gynaecol Obstet. Oct. 1997;59(1):13-8. X-1. [pmid: 9359440].
330 Anoon SS, Rizk DE, Ezimokhai M. Obstetric outcome of excessively overgrown fetuses (> or = 5000 g): a case control study. J Perinat Med. 2003;31(4):295-301. X-1. [pmid: 12951884].
331 Anorlu RI, Orakwe CO, Abudu OO, et al. Uses and misuse of blood transfusion in obstetrics in Lagos, Nigeria. West Afr J Med. Jun. 2003;22(2):124-7. X-1. [pmid: 14529219].
332 Ansaloni L, Brundisini R, Morino G, et al. Prospective, randomized, comparative study of Misgav Ladach versus traditional cesarean section at Nazareth Hospital, Kenya. World J Surg. Sep. 2001;25(9):1164-72. X-9. [pmid: 11571954].
333 Ansari S, Azarkeivan A, Tabaroki A. Pregnancy in patients treated for beta thalassemia major in two centers (Ali Asghar Children's Hospital and Thalassemia Clinic): outcome for mothers and newborn infants. Pediatr Hematol Oncol. Jan-Feb. 2006;23(1):33-7. X-1. [pmid: 16326410].
334 Anteby EY, Kruchkovich J, Kapustian V, et al. Short-term effects of closure versus non-closure of the visceral and parietal peritoneum at cesarean section: a prospective randomized study. J Obstet Gynaecol Res. Dec. 2009;35(6):1026-30. X-9. [pmid: 20144167].
335 Anteby SO, Birkenfeld A, Weinstein D. Post cesarean section urinary tract infections, risk factors and prophylactic antibiotic treatment. Clin Exp Obstet Gynecol. 1984;11(4):161-4. X-1. [pmid: 6499192].
336 Anwar I, Sami M, Akhtar N, et al. Inequity in maternal health-care services: evidence from home-based skilled-birth-attendant programmes in Bangladesh. Bull World Health Organ. Apr. 2008;86(4):252-9. X-1. [pmid: 18438513].
337 Anwari JS, Ahmed F, Mustafa T. An audit of acute pain service in Central, Saudi Arabia. Saudi Med J. Feb. 2005;26(2):298-305. X-1. [pmid: 15770310].
338 Anwari JS, Butt A, Alkhunein S. PCA after subarachnoid block for cesarean section. Middle East J Anesthesiol. Jun. 2004;17(5):913-26. X-1. [pmid: 15449748].
339 Aouad MT, Siddik SS, Jalbout MI, et al. Does pregnancy protect against intrathecal lidocaine-induced transient neurologic symptoms?. Anesth Analg. Feb. 2001;92(2):401-4. X-3, X-4b. [pmid: 11159240].
340 Apantaku O, Chandrasekaran I, Bentick B. Obstetric outcome of singleton pregnancies achieved with in vitro fertilisation and intracytoplasmic sperm injection: experience from a district general hospital. J Obstet Gynaecol. May. 2008;28(4):398-402. X-1. [pmid: 18604672].
341 Appleton B, Targett C, Rasmussen M, et al. Knowledge and attitudes about vaginal birth after Caesarean section in Australian hospitals. VBAC Study Group. Vaginal Birth After Caesarean. Aust N Z J Obstet Gynaecol. May. 2000;40(2):195-9. X-1. [pmid: 10925909].
342 Appleton B, Targett C, Rasmussen M, et al. Vaginal birth after Caesarean section: an Australian multicentre study. VBAC Study Group. Aust N Z J Obstet Gynaecol. Feb. 2000;40(1):87-91. X-1. [pmid: 10870788].
343 Apuzzio JJ, Ganesh VV, Pelosi MA, et al. The effect of prophylactic antibiotics on risk factors for endomyometritis in adolescent patients undergoing cesarean section. J Adolesc Health Care. Jul. 1984;5(3):163-6. X-9. [pmid: 6735830].
344 Apuzzio JJ, Kaminski Z, Gamesh V, et al. Comparative clinical evaluation of ticarcillin plus clavulanic acid versus clindamycin plus gentamicin in treatment of post-cesarean endomyometritis. Am J Med. Nov. 29. 1985;79(5B):164-7. X-9. [pmid: 4073085].
345 Apuzzio JJ, Reyelt C, Pelosi M, et al. Prophylactic antibiotics for cesarean section: comparison of high- and low-risk patients for endomyometritis. Obstet Gynecol. Jun. 1982;59(6):693-8. X-9. [pmid: 7043345].
346 Arai YC, Kato N, Matsura M, et al. Transcutaneous electrical nerve stimulation at the PC-5 and PC-6 acupoints reduced the severity of hypotension after spinal anaesthesia in patients undergoing Caesarean section. Br J Anaesth. Jan. 2008;100(1):78-81. X-9. [pmid: 17959591].
347 Arai YC, Ogata J, Fukunaga K, et al. The effect of intrathecal fentanyl added to hyperbaric bupivacaine on maternal respiratory function during Cesarean section. Acta Anaesthesiol Scand. Mar. 2006;50(3):364-7. X-9. [pmid: 16480472].
348 Arakawa M. Does pregnancy increase the efficacy of lumbar epidural anesthesia?. Int J Obstet Anesth. Apr. 2004;13(2):86-90. X-1. [pmid: 15321410].
349 Arakawa M, Ohe Y. The relationship between the efficacy of epidural anesthesia and the concentration of lidocaine in cerebrospinal fluid. Med Sci Monit. Mar. 2009;15(3):CR95-100. X-9. [pmid: 19247246].
350 Archibong EI. Biophysical profile score in late pregnancy and timing of delivery. Int J Gynaecol Obstet. Feb. 1999;64(2):129-33. X-1. [pmid: 10189020].
351 Arjun G. Caesarean section: evaluation, guidelines and recommendations. Indian J Med Ethics. Jul-Sep. 2008;5(3):117-20. X-1, X-2. [pmid: 18754234].
352 Armstrong C, Damlo S. Practice guideline briefs. American Family Physician. 2007;76(3):444. X-1.
353 Arora R, Swain S, Agrawal A, et al. Impact of mode of delivery on maternal mortality in eclampsia. J Indian Med Assoc. Apr. 1997;95(4):103-4. 106. X-1. [pmid: 9357270].
354 Arpino C, Brescianini S, Ticconi C, et al. Does cesarean section prevent mortality and cerebral ultrasound abnormalities in preterm newborns?. J Matern Fetal Neonatal Med. Feb. 2007;20(2):151-9. X-1. [pmid: 17437214].
355 Arrieta A. Health reform and cesarean sections in the private sector: The experience of Peru. Health Policy. Feb. 2011;99(2):124-30. X-1, X-9. [pmid: 20724019].
356 Artal R, Catanzaro RB, Gavard JA, et al. A lifestyle intervention of weight-gain restriction: diet and exercise in obese women with gestational diabetes mellitus. Appl Physiol Nutr Metab. Jun. 2007;32(3):596-601. X-1. [pmid: 17510701].
357 Arthur D, Payne D. Maternal request for an elective caesarean section. New Zealand College of Midwives Journal. 2005;33:17-20. X-1.
358 Arulkumaran S, Adaikan PG, Anandakumar C, et al. Comparative study of a two dose schedule of PGE2 3 mg pessary and 1700 micrograms film for induction of labour in nulliparae with poor cervical score. Prostaglandins Leukot Essent Fatty Acids. Oct. 1989;38(1):37-41. X-4d. [pmid: 2608700].
359 Arulkumaran S, Gibb DM, Ingemarsson I, et al. Uterine activity during spontaneous labour after previous lower-segment caesarean section. Br J Obstet Gynaecol. Aug. 1989;96(8):933-8. X-1. [pmid: 2775690].
360 Arvela P, Jouppila R, Kauppila A, et al. Placental transfer and hormonal effects of metoclopramide. Eur J Clin Pharmacol. 1983;24(3):345-8. X-1. [pmid: 6407846].
361 Asakura H, Nakai A, Ishikawa G, et al. Prediction of uterine dehiscence by measuring lower uterine segment thickness prior to the onset of labor: evaluation by transvaginal ultrasonography. J Nippon Med Sch. Oct. 2000;67(5):352-6. X-1. [pmid: 11031364].
362 Asantila R, Eklund P, Rosenberg PH. Epidural analgesia with 4 mg of morphine following caesarean section: effect of injected volume. Acta Anaesthesiol Scand. Nov. 1993;37(8):764-7. X-9. [pmid: 8279252].
363 Asbee SM, Jenkins TR, Butler JR, et al. Preventing excessive weight gain during pregnancy through dietary and lifestyle counseling: a randomized controlled trial. Obstet Gynecol. Feb. 2009;113(2 Pt 1):305-12. X-4e, X-5. [pmid: 19155899].
364 Ashfaq F, Shah AA. Effect of amnioinfusion for meconium stained amniotic fluid on perinatal outcome. J Pak Med Assoc. Jun. 2004;54(6):322-5. X-1, X-4e, X-5. [pmid: 15366799].
365 Ashrafunnessa, Khatun SS, Chowdhury SA, et al. Induction of labor by intracervical prostaglandin gel and oxytocin infusion in primigravid women with unfavorable cervix. Bangladesh Med Res Counc Bull. Dec. 1997;23(3):66-71. X-4d, X-5. [pmid: 9621474].
366 Ashton WB, James MF, Janicki P, et al. Attenuation of the pressor response to tracheal intubation by magnesium sulphate with and without alfentanil in hypertensive proteinuric patients undergoing caesarean section. Br J Anaesth. Dec. 1991;67(6):741-7. X-9. [pmid: 1768544].
367 Aslam MF, Gilmour K, Fawdry RD. Who wants a caesarean section? A study of women's personal experience of vaginal and caesarean delivery. J Obstet Gynaecol. Jul. 2003;23(4):364-6. X-1. [pmid: 12881072].
368 Assimakopoulos E, Zafrakas M, Garmiris P, et al. Nuchal cord detected by ultrasound at term is associated with mode of delivery and perinatal outcome. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2005;123(2):188-92. X-1. [pmid: 15941615].
369 Atalla RK, Thompson JR, Oppenheimer CA, et al. Reactive thrombocytosis after caesarean section and vaginal delivery: implications for maternal thromboembolism and its prevention. BJOG. Mar. 2000;107(3):411-4. X-1. [pmid: 10740340].
370 Athukorala C, Rumbold AR, Willson KJ, et al. The risk of adverse pregnancy outcomes in women who are overweight or obese. BMC Pregnancy Childbirth. 2010;10:56. X-1. [pmid: 20849609].
371 Atkinson MW, Guinn D, Owen J, et al. Does magnesium sulfate affect the length of labor induction in women with pregnancy-associated hypertension?. Am J Obstet Gynecol. Oct. 1995;173(4):1219-22. X-3, X-4d, X-4e, X-5. [pmid: 7485324].
372 Atkinson MW, Owen J, Wren A, et al. The effect of manual removal of the placenta on post-cesarean endometritis. Obstet Gynecol. Jan. 1996;87(1):99-102. X-9. [pmid: 8532276].
373 Atkinson RE. An antacid comparison trial. J Int Med Res. Suppl 1. 1978;6:77-82. X-4e. [pmid: 35428].
374 Atkinson SJ, Farias MF. Perceptions of risk during pregnancy amongst urban women in northeast Brazil. Soc Sci Med. Dec. 1995;41(11):1577-86. X-1. [pmid: 8607047].
375 Atrash HK, Hogue CJ, Becerra JW. Birthweight-specific infant mortality risk in cesarean section. Am J Prev Med. Jul-Aug. 1991;7(4):227-31. X-1. [pmid: 1756059].
376 Atterbury JL, Groome LJ, Hoff C. Blood pressure changes in normotensive women readmitted in the postpartum period with severe preeclampsia/eclampsia. J Matern Fetal Med. Jul-Aug. 1996;5(4):201-5. X-1. [pmid: 8796794].
377 Attilakos G, Psaroudakis D, Ash J, et al. Carbetocin versus oxytocin for the prevention of postpartum haemorrhage following caesarean section: the results of a double-blind randomised trial. BJOG. Jul. 2010;117(8):929-36. X-9. [pmid: 20482535].
378 Attilakos G, Sibanda T, Winter C, et al. A randomised controlled trial of a new handheld vacuum extraction device. BJOG. Nov. 2005;112(11):1510-5. X-4e. [pmid: 16225571].
379 Aucott SW, Williams TG, Hertz RH, et al. Rigorous management of insulin-dependent diabetes mellitus during pregnancy. Acta Diabetol. Sep. 1994;31(3):126-9. X-1. [pmid: 7827348].
380 Auerbach KG. The role of the nurse in support of breast feeding. J Adv Nurs. May. 1979;4(3):263-85. X-1, X-2. [pmid: 256572].
381 Aurelius G, Ryde-Blomqvist E. Pregnancy and delivery among immigrants. Scand J Soc Med. 1978;6(1):43-8. X-1. [pmid: 635500].
382 Avery MD, Carr CA, Burkhardt P. Vaginal birth after cesarean section: a pilot study of outcomes in women receiving midwifery care. J Midwifery Womens Health. Mar-Apr. 2004;49(2):113-7. X-1. [pmid: 15010663].
383 Avidan MS, Groves P, Blott M, et al. Low complication rate associated with cesarean section under spinal anesthesia for HIV-1-infected women on antiretroviral therapy. Anesthesiology. Aug. 2002;97(2):320-4. X-1. [pmid: 12151919].
384 Avila WS, Amaral FM, Ramires JA, et al. Influence of pregnancy on clinical course and fetal outcome of women with hypertrophic cardiomyopathy. Arq Bras Cardiol. Apr. 2007;88(4):480-5. X-1. [pmid: 17546281].
385 Awari BH, Al-Habdan I, Sadat-Ali M, et al. Birth associated trauma. Saudi Med J. Jun. 2003;24(6):672-4. X-1. [pmid: 12847602].
386 Awoyinka BS, Ayinde OA, Omigbodun AO. Acceptability of caesarean delivery to antenatal patients in a tertiary health facility in south-west Nigeria. J Obstet Gynaecol. Apr. 2006;26(3):208-10. X-1. [pmid: 16698626].
387 Axelsen SM, Bek KM, Petersen LK. Urodynamic and ultrasound characteristics of incontinence after radical hysterectomy. Neurourol Urodyn. 2007;26(6):794-9. X-1. [pmid: 17487872].
388 Axemo P, Rwamushaija E, Pettersson M, et al. Amniotic fluid antibacterial activity and nutritional parameters in term Mozambican and Swedish pregnant women. Gynecol Obstet Invest. 1996;42(1):24-7. X-1. [pmid: 8840173].
389 Aya AG, Mangin R, Vialles N, et al. Patients with severe preeclampsia experience less hypotension during spinal anesthesia for elective cesarean delivery than healthy parturients: a prospective cohort comparison. Anesth Analg. Sep. 2003;97(3):867-72. X-1. [pmid: 12933418].
390 Aya AG, Vialles N, Tanoubi I, et al. Spinal anesthesia-induced hypotension: a risk comparison between patients with severe preeclampsia and healthy women undergoing preterm cesarean delivery. Anesth Analg. Sep. 2005;101(3):869-75. table of contents. X-1. [pmid: 16116006].
391 Ayangade O. Antibiotic prophylaxis in high-risk obstetrics. J Natl Med Assoc. Nov. 1977;69(11):793-5. X-1. [pmid: 752731].
392 Ayangade O. Long vs short-course antibiotic prophylaxis in cesarean section: a comparative clinical study. J Natl Med Assoc. Jan. 1979;71(1):71-3. X-9. [pmid: 423280].
393 Ayar A, Celik H, Ozcelik O, et al. Homocysteine-induced enhancement of spontaneous contractions of myometrium isolated from pregnant women. Acta Obstet Gynecol Scand. Sep. 2003;82(9):789-93. X-1. [pmid: 12911437].
394 Ayaz A, Shaukat S, Farooq MU, et al. Induction of labor: a comparative study of intravaginal misoprostol and dinoprostone. Taiwan J Obstet Gynecol. Jun. 2010;49(2):151-5. X-1. [pmid: 20708519].
395 Aydin C, Baloglu A, Cetinkaya B, et al. Cardiac troponin levels in pregnant women with severe pre-eclampsia. J Obstet Gynaecol. Oct. 2009;29(7):621-3. X-1. [pmid: 19757267].
396 Aydin GB, Coskun F, Sahin A, et al. Influence of sevoflurane and desflurane on neurological and adaptive capacity scores in newborns. Saudi Med J. Jun. 2008;29(6):841-6. X-3, X-4b, X-4e, X-5. [pmid: 18521462].
397 Aydin Y, Atis A, Ocer F, et al. Association of cervical infection of Chlamydia trachomatis, Ureaplasma urealyticum and Mycoplasma hominis with peritoneum colonisation in pregnancy. J Obstet Gynaecol. 2010;30(8):809-12. X-1. [pmid: 21126118].
398 Ayers JW, Morley GW. Surgical incision for cesarean section. Obstet Gynecol. Nov. 1987;70(5):706-8. X-9. [pmid: 2958727].
399 Ayers S, Collenette A, Hollis B, et al. Feasibility study of a Latest Date of Delivery (LDD) system of managing pregnancy. J Psychosom Obstet Gynaecol. Sep. 2005;26(3):167-71. X-1. [pmid: 16295514].
400 Ayorinde BT, Buczkowski P, Brown J, et al. Evaluation of pre-emptive intramuscular phenylephrine and ephedrine for reduction of spinal anaesthesia-induced hypotension during Caesarean section. Br J Anaesth. Mar. 2001;86(3):372-6. X-9. [pmid: 11573527].
401 Ayres-de-Campos D, Costa-Santos C, Bernardes J. Prediction of neonatal state by computer analysis of fetal heart rate tracings: the antepartum arm of the SisPorto multicentre validation study. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2005;118(1):52-60. X-1. [pmid: 15596273].
402 Aziken M, Omo-Aghoja L, Okonofua F. Perceptions and attitudes of pregnant women towards caesarean section in urban Nigeria. Acta Obstet Gynecol Scand. 2007;86(1):42-7. X-1. [pmid: 17230288].
403 Azizi F, Sadeghipour H, Siahkolah B, et al. Intellectual development of children born of mothers who fasted in Ramadan during pregnancy. Int J Vitam Nutr Res. Sep. 2004;74(5):374-80. X-1. [pmid: 15628676].
404 Azria E, Kane A, Tsatsaris V, et al. Term labor management and outcomes in treated HIV-infected women without contraindications to vaginal delivery and matched controls. Int J Gynaecol Obstet. Nov. 2010;111(2):161-4. X-1. [pmid: 20691445].
405 Azzopardi T, Van Essen P, Cundy PJ, et al. Late diagnosis of developmental dysplasia of the hip: an analysis of risk factors. J Pediatr Orthop B. Jan. 2011;20(1):1-7. X-1. [pmid: 21057331].
406 Baaj JM, Alsatli RA, Majaj HA, et al. Efficacy of ultrasound-guided transversus abdominis plane (TAP) block for postcesarean section delivery analgesia--a double-blind, placebo-controlled, randomized study. Middle East J Anesthesiol. Oct. 2010;20(6):821-6. X-9. [pmid: 21526667].
407 Ba'aqeel HS. Cesarean delivery rates in Saudi Arabia: a ten-year review. Ann Saudi Med. May-Jun. 2009;29(3):179-83. X-1. [pmid: 19448379].
408 Babawale MO, Lovat S, Mayhew TM, et al. Effects of gestational diabetes on junctional adhesion molecules in human term placental vasculature. Diabetologia. Sep. 2000;43(9):1185-96. X-1. [pmid: 11043866].
409 Babay ZA, Al-Nuaim LA, Addar MH, et al. Undiagnosed term breech: management and outcome. Saudi Med J. May. 2000;21(5):478-81. X-1. [pmid: 11500686].
410 Babski-Reeves KL, Tran GM. Efficacy of an assistive intervention for abdominal surgery patients in postoperative care. Disabil Rehabil Assist Technol. Jun. 2006;1(3):191-7. X-1. [pmid: 19260187].
411 Bach V, Carl P, Ravlo O, et al. A randomized comparison between midazolam and thiopental for elective cesarean section anesthesia: III. Placental transfer and elimination in neonates. Anesth Analg. Mar. 1989;68(3):238-42. X-1. [pmid: 2919760].
412 Bachmann-Mennenga B, Veit G, Biscoping J, et al. Epidural ropivacaine 1% with and without sufentanil addition for Caesarean section. Acta Anaesthesiol Scand. Apr. 2005;49(4):525-31. X-9. [pmid: 15777301].
413 Bachmann-Mennenga B, Veit G, Steinicke B, et al. Efficacy of sufentanil addition to ropivacaine epidural anaesthesia for Caesarean section. Acta Anaesthesiol Scand. Apr. 2005;49(4):532-7. X-9. [pmid: 15777302].
414 Backe SK, Kocarev M, Wilson RC, et al. Effect of maternal facial oxygen on neonatal behavioural scores during elective Caesarean section with spinal anaesthesia. Eur J Anaesthesiol. Jan. 2007;24(1):66-70. X-9. [pmid: 16895615].
415 Backe SK, Sheikh Z, Wilson R, et al. Combined epidural/spinal anaesthesia: needle-through-needle or separate spaces?. Eur J Anaesthesiol. Nov. 2004;21(11):854-7. X-3, X-4b, X-5. [pmid: 15717699].
416 Backos M, Rai R, Baxter N, et al. Pregnancy complications in women with recurrent miscarriage associated with antiphospholipid antibodies treated with low dose aspirin and heparin. Br J Obstet Gynaecol. Feb. 1999;106(2):102-7. X-1. [pmid: 10426674].
417 Badawi N, Kurinczuk JJ, Keogh JM, et al. Intrapartum risk factors for newborn encephalopathy: the Western Australian case-control study. BMJ. Dec. 5. 1998;317(7172):1554-8. X-1. [pmid: 9836653].
418 Badawy AM, Khiary M, Sherif LS, et al. Low-molecular weight heparin in patients with recurrent early miscarriages of unknown aetiology. J Obstet Gynaecol. Apr. 2008;28(3):280-4. X-4e. [pmid: 18569468].
419 Bader AM, Tsen LC, Camann WR, et al. Clinical effects and maternal and fetal plasma concentrations of 0.5% epidural levobupivacaine versus bupivacaine for cesarean delivery. Anesthesiology. Jun. 1999;90(6):1596-601. X-9. [pmid: 10360857].
420 Bader D, Riskin A, Paz E, et al. Breathing patterns in term infants delivered by caesarean section. Acta Paediatr. Sep. 2004;93(9):1216-20. X-1. [pmid: 15384887].
421 Baek C, Rutenberg N. Implementing programs for the prevention of mother-to-child HIV transmission in resource-constrained settings: Horizons studies, 1999-2007. Public Health Rep. Mar-Apr. 2010;125(2):293-304. X-1, X-2. [pmid: 20297758].
422 Bagratee JS, Moodley J, Kleinschmidt I, et al. A randomised controlled trial of antibiotic prophylaxis in elective caesarean delivery. BJOG. Feb. 2001;108(2):143-8. X-9. [pmid: 11236113].
423 Bahar AM, Archibong EI, Zaki ZM, et al. Induction of labour using low and high dose regimens of prostaglandin E2 vaginal tablets. East Afr Med J. Jan. 2003;80(1):51-5. X-1. [pmid: 12755242].
424 Bahl R, Strachan B, Murphy DJ. Outcome of subsequent pregnancy three years after previous operative delivery in the second stage of labour: cohort study. BMJ. Feb. 7. 2004;328(7435):311. X-1. [pmid: 14724128].
425 Bahmanyar S, Montgomery SM, Weiss RJ, et al. Maternal smoking during pregnancy, other prenatal and perinatal factors, and the risk of Legg-Calve-Perthes disease. Pediatrics. Aug. 2008;122(2):e459-64. X-1. [pmid: 18625663].
426 Baicker K, Buckles KS, Chandra A. Geographic variation in the appropriate use of cesarean delivery. Health Aff (Millwood). Sep-Oct. 2006;25(5):w355-67. X-1, X-2. [pmid: 16895942].
427 Bailey P, de Bocaletti E, Barrios G, et al. Monitoring utilization and need for obstetric care in the highlands of Guatemala. Int J Gynaecol Obstet. May. 2005;89(2):209-17. X-1. [pmid: 15847896].
428 Bailey PE, Paxton A. Program note. Using UN process indicators to assess needs in emergency obstetric services. Int J Gynaecol Obstet. Mar. 2002;76(3):299-305. discussion 306. X-1, X-2, X-3, X-4e, X-5. [pmid: 11880134].
429 Bailit JL, Landon MB, Lai Y, et al. Maternal-Fetal Medicine Units Network cesarean registry: impact of shift change on cesarean complications. Am J Obstet Gynecol. Feb. 2008;198(2):173 e1-5. X-1. [pmid: 18226616].
430 Bailit JL, Landon MB, Thom E, et al. The MFMU Cesarean Registry: impact of time of day on cesarean complications. Am J Obstet Gynecol. Oct. 2006;195(4):1132-7. X-1. [pmid: 16875648].
431 Bailit JL, Love TE, Dawson NV. Quality of obstetric care and risk-adjusted primary cesarean delivery rates. Am J Obstet Gynecol. Feb. 2006;194(2):402-7. X-1. [pmid: 16458637].
432 Bailit JL, Schulkin J, Dawson NV. Risk-adjusted cesarean rates: what risk factors for cesarean delivery are important to practicing obstetricians?. J Reprod Med. Mar. 2007;52(3):194-8. X-1. [pmid: 17465286].
433 Baka NE, Bayoumeu F, Boutroy MJ, et al. Colostrum morphine concentrations during postcesarean intravenous patient-controlled analgesia. Anesth Analg. Jan. 2002;94(1):184-7. table of contents. X-1. [pmid: 11772825].
434 Baker C, Luce J, Chenoweth C, et al. Comparison of case-finding methodologies for endometritis after cesarean section. Am J Infect Control. Feb. 1995;23(1):27-33. X-1. [pmid: 7762871].
435 Baker PN, Johnson IR. A study of the effect of rotational forceps delivery on fetal acid-base balance. Acta Obstet Gynecol Scand. Nov. 1994;73(10):787-9. X-1. [pmid: 7817730].
436 Baker SG, Lindeman KS. The paired availability design: a proposal for evaluating epidural analgesia during labor. Stat Med. Nov. 15. 1994;13(21):2269-78. X-1, X-2. [pmid: 7846425].
437 Bakhamees H, Hegazy E. Does epidural increase the incidence of cesarean delivery or instrumental labor in Saudi populations?. Middle East J Anesthesiol. Oct. 2007;19(3):693-704. X-1, X-4e, X-5. [pmid: 18044297].
438 Bakke OM, Haram K, Lygre T, et al. Comparison of the placental transfer of thiopental and diazepam in caesarean section. Eur J Clin Pharmacol. 1981;21(3):221-7. X-1. [pmid: 7318882].
439 Bakker JJ, Verhoeven CJ, Janssen PF, et al. Outcomes after internal versus external tocodynamometry for monitoring labor. N Engl J Med. Jan. 28. 2010;362(4):306-13. X-5. [pmid: 20107216].
440 Baksu A, Kalan A, Ozkan A, et al. The effect of placental removal method and site of uterine repair on postcesarean endometritis and operative blood loss. Acta Obstet Gynecol Scand. Mar. 2005;84(3):266-9. X-9. [pmid: 15715535].
441 Balaji P, Dhillon P, Russell IF. Low-dose epidural top up for emergency caesarean delivery: a randomised comparison of levobupivacaine versus lidocaine/epinephrine/fentanyl. Int J Obstet Anesth. Oct. 2009;18(4):335-41. X-9. [pmid: 19733053].
442 Balani J, Hyer SL, Rodin DA, et al. Pregnancy outcomes in women with gestational diabetes treated with metformin or insulin: a case-control study. Diabet Med. Aug. 2009;26(8):798-802. X-1. [pmid: 19709150].
443 Balchin I, Whittaker JC, Lamont RF, et al. Timing of planned cesarean delivery by racial group. Obstet Gynecol. Mar. 2008;111(3):659-66. X-1. [pmid: 18310369].
444 Balcombe LJ. Consent to medical treatment: the law and ethics. Trans Med Soc Lond. 1993;110:34-5. X-1. [pmid: 11660795].
445 Baldwin LM, Hart LG, Lloyd M, et al. Defensive medicine and obstetrics. JAMA. Nov. 22-29. 1995;274(20):1606-10. X-1. [pmid: 7474245].
446 Balki M, Dhumne S, Kasodekar S, et al. Oxytocin-ergometrine co-administration does not reduce blood loss at caesarean delivery for labour arrest. BJOG. Apr. 2008;115(5):579-84. X-9. [pmid: 18333937].
447 Balki M, Dhumne S, Kasodekar S, et al. Blood transfusion for primary postpartum hemorrhage: a tertiary care hospital review. J Obstet Gynaecol Can. Nov. 2008;30(11):1002-7. X-1. [pmid: 19126281].
448 Balki M, Kasodekar S, Dhumne S, et al. Prophylactic [corrected] granisetron does not prevent postdelivery nausea and vomiting during elective cesarean delivery under spinal anesthesia. Anesth Analg. Mar. 2007;104(3):679-83. X-9. [pmid: 17312229].
449 Balki M, Ronayne M, Davies S, et al. Minimum oxytocin dose requirement after cesarean delivery for labor arrest. Obstet Gynecol. Jan. 2006;107(1):45-50. X-9. [pmid: 16394038].
450 Bamigboye AA, Justus HG. Ropivacaine abdominal wound infiltration and peritoneal spraying at cesarean delivery for preemptive analgesia. Int J Gynaecol Obstet. Aug. 2008;102(2):160-4. X-9. [pmid: 18538773].
451 Bandi E, Weeks S, Carli F. Spinal block levels and cardiovascular changes during post-Cesarean transport. Can J Anaesth. Aug. 1999;46(8):736-40. X-1. [pmid: 10451132].
452 Banerjee M, Bhattacharya A, Hughes SM, et al. Efficacy of insulin lispro in pregnancies complicated with pregestational diabetes mellitus. Practical Diabetes International. 2009;26(9):366-370. X-1.
453 Banias BB, Nolan TE, Devoe LD, et al. Maternal coagulation inhibitors and the effects of cesarean delivery. J Reprod Med. Aug. 1992;37(8):741-4. X-1. [pmid: 1432992].
454 Banks E, Meirik O, Farley T, et al. Female genital mutilation and obstetric outcome: WHO collaborative prospective study in six African countries. Lancet. Jun. 3. 2006;367(9525):1835-41. X-1. [pmid: 16753486].
455 Banks S, Pavy T. A portable, disposable device for patient-controlled epidural analgesia following Caesarean section: evaluation by patients and nurses. Aust N Z J Obstet Gynaecol. Nov. 2001;41(4):372-5. X-1. [pmid: 11787908].
456 Bano F, Haider S, Aftab S, et al. Comparison of 25-gauge, Quincke and Whitacre needles for postdural puncture headache in obstetric patients. J Coll Physicians Surg Pak. Nov. 2004;14(11):647-50. X-3, X-4b, X-5. [pmid: 15530271].
457 Bano F, Sabbar S, Zafar S, et al. Intrathecal fentanyl as adjunct to hyperbaric bupivacaine in spinal anesthesia for caesarean section. J Coll Physicians Surg Pak. Feb. 2006;16(2):87-90. X-9. [pmid: 16499796].
458 Bar J, Dvir A, Hod M, et al. Brachial plexus injury and obstetrical risk factors. Int J Gynaecol Obstet. Apr. 2001;73(1):21-5. X-1. [pmid: 11336717].
459 Barak S, Oettinger-Barak O, Machtei EE, et al. Evidence of periopathogenic microorganisms in placentas of women with preeclampsia. J Periodontol. Apr. 2007;78(4):670-6. X-1. [pmid: 17397314].
460 Baraka A, Jabbour S, Tabboush Z, et al. Onset of vecuronium neuromuscular block is more rapid in patients undergoing caesarean section. Can J Anaesth. Feb. 1992;39(2):135-8. X-1. [pmid: 1347489].
461 Baraka A, Khoury PJ, Siddik SS, et al. Efficacy of the self-inflating bulb in differentiating esophageal from tracheal intubation in the parturient undergoing cesarean section. Anesth Analg. Mar. 1997;84(3):533-7. X-9. [pmid: 9052296].
462 Baraka A, Louis F, Noueihid R, et al. Awareness following different techniques of general anaesthesia for caesarean section. Br J Anaesth. Jun. 1989;62(6):645-8. X-9. [pmid: 2502168].
463 Baraka A, Noueihid R, Hajj S. Intrathecal injection of morphine for obstetric analgesia. Anesthesiology. Feb. 1981;54(2):136-40. X-1. [pmid: 7008655].
464 Baraka A, Saab M, Salem MR, et al. Control of gastric acidity by glycopyrrolate premedication in the parturient. Anesth Analg. Sep-Oct. 1977;56(5):642-5. X-9. [pmid: 20823].
465 Baraka A, Siddik S, Assaf B. Supplementation of general anaesthesia with tramadol or fentanyl in parturients undergoing elective caesarean section. Can J Anaesth. Jul. 1998;45(7):631-4. X-9. [pmid: 9717593].
466 Baraka AS, Hanna MT, Jabbour SI, et al. Preoxygenation of pregnant and nonpregnant women in the head-up versus supine position. Anesth Analg. Nov. 1992;75(5):757-9. X-1. [pmid: 1416130].
467 Baraka AS, Sayyid SS, Assaf BA. Thiopental-rocuronium versus ketamine-rocuronium for rapid-sequence intubation in parturients undergoing cesarean section. Anesth Analg. May. 1997;84(5):1104-7. X-9. [pmid: 9141939].
468 Barakat MN, Youssef RM, Al-Lawati JA. Pregnancy outcomes of diabetic women: charting Oman's progress towards the goals of the Saint Vincent Declaration. Ann Saudi Med. Jul-Aug. 2010;30(4):265-70. X-1. [pmid: 20622342].
469 Barbera AF, Pombar X, Perugino G, et al. A new method to assess fetal head descent in labor with transperineal ultrasound. Ultrasound Obstet Gynecol. Mar. 2009;33(3):313-9. X-1. [pmid: 19248000].
470 Barki PA. The midwife and moral dilemma. Midwifery Today Childbirth Educ. Spring. 1997;(41):57-8. X-1. [pmid: 9136427].
471 Barnardo PD, Jenkins JG. Failed tracheal intubation in obstetrics: a 6-year review in a UK region. Anaesthesia. Jul. 2000;55(7):690-4. X-1. [pmid: 10919428].
472 Barnea ER, Lavy G, Fakih H, et al. The role of ACTH in placental steroidogenesis. Placenta. Jul-Aug. 1986;7(4):307-13. X-1. [pmid: 3018717].
473 Barnhart BJ, Carlson CV, Reynolds JW. Adrenal cortical function in the postmature fetus and newborn infant. Pediatr Res. Dec. 1980;14(12):1367-9. X-1. [pmid: 6259578].
474 Barnhart KT, Sammel MD, Gracia CR, et al. Risk factors for ectopic pregnancy in women with symptomatic first-trimester pregnancies. Fertil Steril. Jul. 2006;86(1):36-43. X-1. [pmid: 16730724].
475 Barnsley JM, Vayda E, Lomas J, et al. Cesarean section in Ontario: practice patterns and responses to hypothetical cases. Can J Surg. Apr. 1990;33(2):128-32. X-1. [pmid: 2268812].
476 Baron C, Morgan MA, Garite TJ. The impact of amniotic fluid volume assessed intrapartum on perinatal outcome. Am J Obstet Gynecol. Jul. 1995;173(1):167-74. X-1. [pmid: 7631675].
477 Baron CM, Girling LG, Mathieson AL, et al. Obstetrical and neonatal outcomes in obese parturients. J Matern Fetal Neonatal Med. Aug. 2010;23(8):906-13. X-1. [pmid: 19895351].
478 Barrett HL, Morris J, McElduff A. Watchful waiting: a management protocol for maternal glycaemia in the peripartum period. Aust N Z J Obstet Gynaecol. Apr. 2009;49(2):162-7. X-1. [pmid: 19432604].
479 Barrilleaux PS, Bofill JA, Terrone DA, et al. Cervical ripening and induction of labor with misoprostol, dinoprostone gel, and a Foley catheter: a randomized trial of 3 techniques. Am J Obstet Gynecol. Jun. 2002;186(6):1124-9. X-4d, X-5. [pmid: 12066084].
480 Barros FC, Vaughan JP, Victora CG, et al. Epidemic of caesarean sections in Brazil. Lancet. Jul. 20. 1991;338(8760):167-9. X-1. [pmid: 1677075].
481 Barros FC, Victora CG. Maternal-child health in Pelotas, Rio Grande do Sul State, Brazil: major conclusions from comparisons of the 1982, 1993, and 2004 birth cohorts. Cad Saude Publica. Suppl 3. 2008;24:S461-7. X-1. [pmid: 18797722].
482 Bartha JL, Comino-Delgado R, Garcia-Benasach F, et al. Oral misoprostol and intracervical dinoprostone for cervical ripening and labor induction: a randomized comparison. Obstet Gynecol. Sep. 2000;96(3):465-9. X-4d. [pmid: 10960643].
483 Bartha JL, Romero-Carmona R, Martinez-Del-Fresno P, et al. Bishop score and transvaginal ultrasound for preinduction cervical assessment: a randomized clinical trial. Ultrasound Obstet Gynecol. Feb. 2005;25(2):155-9. X-4d, X-4e. [pmid: 15660437].
484 Barton M. More than just pain relief: a study of postpartum, post-caesarean pain management. Aust Coll Midwives Inc J. Jun. 1996;9(2):14-9. X-3, X-4b, X-5. [pmid: 8716551].
485 Barwolff S, Sohr D, Geffers C, et al. Reduction of surgical site infections after Caesarean delivery using surveillance. J Hosp Infect. Oct. 2006;64(2):156-61. X-1. [pmid: 16899325].
486 Basha SL, Rochon ML, Quinones JN, et al. Randomized controlled trial of wound complication rates of subcuticular suture vs staples for skin closure at cesarean delivery. Am J Obstet Gynecol. Sep. 2010;203(3):285 e1-8. X-9. [pmid: 20816153].
487 Bashiri A, Burstein E, Bar-David J, et al. Face and brow presentation: independent risk factors. J Matern Fetal Neonatal Med. Jun. 2008;21(6):357-60. X-1. [pmid: 18570114].
488 Baskett TF, Allen VM, O'Connell CM, et al. Predictors of respiratory depression at birth in the term infant. BJOG. Jul. 2006;113(7):769-74. X-1. [pmid: 16827759].
489 Bassan H, Feldman HA, Limperopoulos C, et al. Periventricular hemorrhagic infarction: risk factors and neonatal outcome. Pediatr Neurol. Aug. 2006;35(2):85-92. X-1. [pmid: 16876002].
490 Basson E, Odendaal HJ, Grove D. Oxytocin use in South Africa--a review. S Afr Med J. Oct. 2004;94(10):839-45. X-1. [pmid: 15532761].
491 Bastani F, Hidarnia A, Montgomery KS, et al. Does relaxation education in anxious primigravid Iranian women influence adverse pregnancy outcomes?: a randomized controlled trial. J Perinat Neonatal Nurs. Apr-Jun. 2006;20(2):138-46. X-6. [pmid: 16714913].
492 Baston H, Rijnders M, Green JM, et al. Looking back on birth three years later: factors associated with a negative appraisal in England and in the Netherlands. Journal of Reproductive & Infant Psychology. 2008;26(4):323-339. X-1.
493 Bateman C. Rendering unto Caesar?. S Afr Med J. Oct. 2004;94(10):800-2. X-1, X-2. [pmid: 15532747].
494 Battaglia C, Artini PG, Ballestri M, et al. Hemodynamic, hematological and hemorrheological evaluation of post-term pregnancy. Acta Obstet Gynecol Scand. May. 1995;74(5):336-40. X-1. [pmid: 7778423].
495 Bauchat JR, Higgins N, Wojciechowski KG, et al. Low-dose ketamine with multimodal postcesarean delivery analgesia: a randomized controlled trial. Int J Obstet Anesth. Jan. 2011;20(1):3-9. X-9. [pmid: 21224020].
496 Bauer M, Fast C, Haas J, et al. Cystic periventricular leukomalacia in preterm infants: an analysis of obstetric risk factors. Early Hum Dev. Mar. 2009;85(3):163-9. X-1. [pmid: 18783900].
497 Baumert M, Brozek G, Paprotny M, et al. Epidemiology of peri/intraventricular haemorrhage in newborns at term. J Physiol Pharmacol. Sep. Suppl 4. 2008;59:67-75. X-1. [pmid: 18955755].
498 Bawdon RE, Davis LL. Postcesarean section plasma fibronectin levels. Gynecol Obstet Invest. 1988;25(1):38-41. X-1. [pmid: 3343022].
499 Baytur YB, Deveci A, Uyar Y, et al. Mode of delivery and pelvic floor muscle strength and sexual function after childbirth. Int J Gynaecol Obstet. Mar. 2005;88(3):276-80. X-1. [pmid: 15733881].
500 Baytur YB, Serter S, Tarhan S, et al. Pelvic floor function and anatomy after childbirth. J Reprod Med. Jul. 2007;52(7):604-10. X-1. [pmid: 17847758].
501 Bazowska G, Jendryczko A. Concentration of malondialdehyde (MDA) in amniotic fluid and maternal and cord serum in cases of intrauterine growth retardation. Zentralbl Gynakol. 1994;116(6):329-30. X-1. [pmid: 8048286].
502 Beake S, Rose V, Bick D, et al. A qualitative study of the experiences and expectations of women receiving in-patient postnatal care in one English maternity unit. BMC Pregnancy Childbirth. 2010;10:70. X-1. [pmid: 20979605].
503 Beall MH, Spong CY, Ross MG. A randomized controlled trial of prophylactic maneuvers to reduce head-to-body delivery time in patients at risk for shoulder dystocia. Obstet Gynecol. Jul. 2003;102(1):31-5. X-4e, X-5. [pmid: 12850603].
504 Beck P, Lilling MI. Induction of labor with intravenous prostaglandin. Am J Obstet Gynecol. Jul. 1. 1976;125(5):648-54. X-1. [pmid: 937389].
505 Becker S, Solomayer E, Dogan C, et al. Meconium-stained amniotic fluid--perinatal outcome and obstetrical management in a low-risk suburban population. Eur J Obstet Gynecol Reprod Biol. May. 2007;132(1):46-50. X-1. [pmid: 16837118].
506 Becroft DM, Thompson JM, Mitchell EA. Pulmonary interstitial hemosiderin in infancy: a common consequence of normal labor. Pediatr Dev Pathol. Jul-Aug. 2005;8(4):448-52. X-1. [pmid: 16211452].
507 Beeby D, MacIntosh KC, Bailey M, et al. Postoperative analgesia for Caesarean section using epidural methadone. Anaesthesia. Jan. 1984;39(1):61-3. X-9. [pmid: 6696222].
508 Beech BAL. Breech births: Imperial College 10th October, 1998. AIMS Journal. 1998;10(3):24-24. X-2.
509 Behague DP. Beyond the simple economics of cesarean section birthing: women's resistance to social inequality. Cult Med Psychiatry. Dec. 2002;26(4):473-507. X-1. [pmid: 12572770].
510 Behague DP, Victora CG, Barros FC. Consumer demand for caesarean sections in Brazil: informed decision making, patient choice, or social inequality? A population based birth cohort study linking ethnographic and epidemiological methods. BMJ. Apr. 20. 2002;324(7343):942-5. X-1. [pmid: 11964338].
511 Beigi A, Kabiri M, Zarrinkoub F. Cervical ripening with oral misoprostol at term. Int J Gynaecol Obstet. Dec. 2003;83(3):251-5. X-4d. [pmid: 14643034].
512 Beilin Y, Bodian CA, Haddad EM, et al. Practice patterns of anesthesiologists regarding situations in obstetric anesthesia where clinical management is controversial. Anesth Analg. Oct. 1996;83(4):735-41. X-1. [pmid: 8831312].
513 Beilin Y, Guinn NR, Bernstein HH, et al. Local anesthetics and mode of delivery: bupivacaine versus ropivacaine versus levobupivacaine. Anesth Analg. Sep. 2007;105(3):756-63. X-5. [pmid: 17717236].
514 Beilin Y, Mungall D, Hossain S, et al. Labor pain at the time of epidural analgesia and mode of delivery in nulliparous women presenting for an induction of labor. Obstet Gynecol. Oct. 2009;114(4):764-9. X-1. [pmid: 19888033].
515 Beinder E, Mohaupt MG, Schlembach D, et al. Nitric oxide synthase activity and Doppler parameters in the fetoplacental and uteroplacental circulation in preeclampsia. Hypertens Pregnancy. 1999;18(2):115-27. X-1. [pmid: 10476613].
516 Beine K, Fullerton J, Palinkas L, et al. Conceptions of prenatal care among Somali women in San Diego. J Nurse Midwifery. Jul-Aug. 1995;40(4):376-81. X-1. [pmid: 7674057].
517 Bekku S, Mitsuda N, Ogita K, et al. High incidence of respiratory distress syndrome (RDS) in infants born to mothers with placenta previa. J Matern Fetal Med. Mar-Apr. 2000;9(2):110-3. X-1. [pmid: 10902824].
518 Belavy D, Cowlishaw PJ, Howes M, et al. Ultrasound-guided transversus abdominis plane block for analgesia after Caesarean delivery. Br J Anaesth. Nov. 2009;103(5):726-30. X-9. [pmid: 19700776].
519 Belci D, Kos M, Zoricic D, et al. Comparative study of the “Misgav Ladach” and traditional Pfannenstiel surgical techniques for cesarean section. Minerva Ginecol. Jun. 2007;59(3):231-40. X-9. [pmid: 17576402].
520 Belfrage P, Fernstrom I, Hallenberg G. Routine or selective ultrasound examinations in early pregnancy. Obstet Gynecol. May. 1987;69(5):747-50. X-1, X-4e, X-5. [pmid: 3554057].
521 Belfrage P, Gjessing L. The term breech presentation. A retrospective study with regard to the planned mode of delivery. Acta Obstet Gynecol Scand. Jun. 2002;81(6):544-50. X-1. [pmid: 12047309].
522 Belkin A, Levy A, Sheiner E. Perinatal outcomes and complications of pregnancy in women with immune thrombocytopenic purpura. J Matern Fetal Neonatal Med. Nov. 2009;22(11):1081-5. X-1. [pmid: 19900049].
523 Bell JS, Campbell DM, Graham WJ, et al. Can obstetric complications explain the high levels of obstetric interventions and maternity service use among older women? A retrospective analysis of routinely collected data. BJOG. Sep. 2001;108(9):910-8. X-1. [pmid: 11563459].
524 Bellomo G, Narducci PL, Rondoni F, et al. Prognostic value of 24-hour blood pressure in pregnancy. JAMA. Oct. 20. 1999;282(15):1447-52. X-1. [pmid: 10535435].
525 Belzarena SD. Evaluation of intravenous tenoxicam for postoperative cesarean delivery pain relief. Preliminary report. Reg Anesth. Nov-Dec. 1994;19(6):408-11. X-9. [pmid: 7848951].
526 Ben Slama C, Nsiri B, Bouguerra R, et al. Diabetic pregnancy in over 35 years old women. Ann Ist Super Sanita. 1997;33(3):313-6. X-1. [pmid: 9542254].
527 Benachi A, Chailley-Heu B, Barlier-Mur AM, et al. Expression of surfactant proteins and thyroid transcription factor 1 in an ovine model of congenital diaphragmatic hernia. J Pediatr Surg. Oct. 2002;37(10):1393-8. X-1. [pmid: 12378441].
528 Ben-Ami I, Schneider D, Svirsky R, et al. Safety of late second-trimester pregnancy termination by laminaria dilatation and evacuation in patients with previous multiple cesarean sections. Am J Obstet Gynecol. Aug. 2009;201(2):154 e1-5. X-1. [pmid: 19539892].
529 Benaron HB, Tucker BE. The effect of factors beyond clinical control and obstetric management of mature infant survival at the Chicago Maternity Center from 1959 to 1963. Am J Obstet Gynecol. Aug. 15. 1971;110(8):1119-24. X-1. [pmid: 5562727].
530 Benaron HW, Tucker BE. The effect of obstetric management and factors beyond clinical control on maternal mortality rates at the Chicago Maternity Center from 1959 to 1963. Am J Obstet Gynecol. Aug. 15. 1971;110(8):1113-8. X-1. [pmid: 5562726].
531 Ben-Aroya Z, Hallak M, Segal D, et al. Ripening of the uterine cervix in a post-cesarean parturient: prostaglandin E2 versus Foley catheter. J Matern Fetal Neonatal Med. Jul. 2002;12(1):42-5. X-1. [pmid: 12422908].
532 Ben-Aroya Z, Yochai D, Silberstein T, et al. Oxytocin use in grand-multiparous patients: safety and complications. J Matern Fetal Med. Oct. 2001;10(5):328-31. X-1. [pmid: 11730496].
533 Ben-Chetrit E, Ben-Chetrit A, Berkun Y. Pregnancy outcomes in women with familial Mediterranean fever receiving colchicine: is amniocentesis justified?. Arthritis Care Res (Hoboken). Feb. 2010;62(2):143-8. X-1. [pmid: 20191511].
534 Ben-David B, Miller G, Gavriel R, et al. Low-dose bupivacaine-fentanyl spinal anesthesia for cesarean delivery. Reg Anesth Pain Med. May-Jun. 2000;25(3):235-9. X-9. [pmid: 10834776].
535 Bendon RW, Faye-Petersen O, Pavlova Z, et al. Fetal membrane histology in preterm premature rupture of membranes: comparison to controls, and between antibiotic and placebo treatment. The National Institute of Child Health and Human Development Maternal Fetal Medicine Units Network, Bethesda, MD, USA. Pediatr Dev Pathol. Nov-Dec. 1999;2(6):552-8. X-1. [pmid: 10508879].
536 Benedetto C, Marozio L, Prandi G, et al. Short-term maternal and neonatal outcomes by mode of delivery. A case-controlled study. Eur J Obstet Gynecol Reprod Biol. Nov. 2007;135(1):35-40. X-1. [pmid: 17126475].
537 Benedetto MT, De Cicco F, Rossiello F, et al. Oxytocin receptor in human fetal membranes at term and during labor. J Steroid Biochem. Feb. 1990;35(2):205-8. X-1. [pmid: 2155353].
538 Bengtson MB, Solberg IC, Aamodt G, et al. Relationships between inflammatory bowel disease and perinatal factors: both maternal and paternal disease are related to preterm birth of offspring. Inflamm Bowel Dis. May. 2010;16(5):847-55. X-1. [pmid: 19795509].
539 Benhamou D, Labaille T, Bonhomme L, et al. Alkalinization of epidural 0.5% bupivacaine for cesarean section. Reg Anesth. Sep-Oct. 1989;14(5):240-3. X-9. [pmid: 2562096].
540 Benhamou D, Thorin D, Brichant JF, et al. Intrathecal clonidine and fentanyl with hyperbaric bupivacaine improves analgesia during cesarean section. Anesth Analg. Sep. 1998;87(3):609-13. X-9. [pmid: 9728839].
541 Ben-Haroush A, Bardin R, Erman A, et al. Beta2-microglobulin and hypertensive complications in pregnant women at risk. Clin Nephrol. Dec. 2002;58(6):411-6. X-1. [pmid: 12508962].
542 Ben-Haroush A, Glickman H, Yogev Y, et al. Induction of labor in pregnancies with suspected large-for-gestational-age fetuses and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. Oct. 15. 2004;116(2):182-5. X-1. [pmid: 15358461].
543 Ben-Haroush A, Perri T, Bar J, et al. Mode of delivery following successful external cephalic version. Am J Perinatol. Oct. 2002;19(7):355-60. X-1. [pmid: 12442224].
544 Ben-Haroush A, Yogev Y, Bar J, et al. Indicated labor induction with vaginal prostaglandin E2 increases the risk of cesarean section even in multiparous women with no previous cesarean section. J Perinat Med. 2004;32(1):31-6. X-1. [pmid: 15008383].
545 Ben-Haroush A, Yogev Y, Glickman H, et al. Mode of delivery in pregnancies with premature rupture of membranes at or before term following induction of labor with vaginal prostaglandin E2. Am J Perinatol. Jul. 2004;21(5):263-8. X-1. [pmid: 15232758].
546 Ben-Haroush A, Yogev Y, Glickman H, et al. Mode of delivery in pregnant women with hypertensive disorders and unfavorable cervix following induction of labor with vaginal application of prostaglandin E. Acta Obstet Gynecol Scand. Jul. 2005;84(7):665-71. X-1. [pmid: 15954877].
547 Benigno BB, Ford LC, Lawrence WD, et al. A double-blind, controlled comparison of piperacillin and cefoxitin in the prevention of postoperative infection in patients undergoing cesarean section. Surg Gynecol Obstet. Jan. 1986;162(1):1-7. X-9. [pmid: 3079625].
548 Benlabed M, Dreizzen E, Ecoffey C, et al. Neonatal patterns of breathing after cesarean section with or without epidural fentanyl. Anesthesiology. Dec. 1990;73(6):1110-3. X-9. [pmid: 2248390].
549 Bennedsen BE, Mortensen PB, Olesen AV, et al. Obstetric complications in women with schizophrenia. Schizophr Res. Mar. 1. 2001;47(2-3):167-75. X-1. [pmid: 11278134].
550 Bennett B. Pregnant women and the duty to rescue: a feminist response to the fetal rights debate. Law Context. 1991;9:70-91. X-1. [pmid: 11660071].
551 Bennett KA, Butt K, Crane JM, et al. A masked randomized comparison of oral and vaginal administration of misoprostol for labor induction. Obstet Gynecol. Oct. 1998;92(4 Pt 1):481-6. X-4d. [pmid: 9764615].
552 Bennett KA, Butt K, Crane JM, et al. A masked randomized comparison of oral and vaginal administration of misoprostol for labor induction. Obstet Gynecol. Oct. 1998;92(4 Pt 1):481-6. X-4d. [pmid: 9764615].
553 Bennett P, Slater D, Berger L, et al. The expression of phospholipase A2 and lipocortins (annexins) I, II and V in human fetal membranes and placenta in association with labour. Prostaglandins. Aug. 1994;48(2):81-90. X-1. [pmid: 7991777].
554 Bennett PR, Rose MP, Myatt L, et al. Preterm labor: stimulation of arachidonic acid metabolism in human amnion cells by bacterial products. Am J Obstet Gynecol. Mar. 1987;156(3):649-55. X-1. [pmid: 3103451].
555 Ben-Rafael Z, Seidman DS, Recabi K, et al. Uterine anomalies. A retrospective, matched-control study. J Reprod Med. Oct. 1991;36(10):723-7. X-1. [pmid: 1956011].
556 Benrubi GI, Young M, Nuss RC. Intrapartum outcome of term pregnancy after cervical cryotherapy. J Reprod Med. Apr. 1984;29(4):251-4. X-1. [pmid: 6716369].
557 Bensal A, Weintraub AY, Levy A, et al. The significance of peripartum fever in women undergoing vaginal deliveries. Am J Perinatol. Oct. 2008;25(9):567-72. X-1. [pmid: 18756433].
558 Ben-Shlomo I, Alcalay M, Lipitz S, et al. Twin pregnancies complicated by the death of one fetus. J Reprod Med. Jun. 1995;40(6):458-62. X-1. [pmid: 7650661].
559 Benson CB, Chow JS, Chang-Lee W, et al. Outcome of pregnancies in women with uterine leiomyomas identified by sonography in the first trimester. J Clin Ultrasound. Jun. 2001;29(5):261-4. X-1. [pmid: 11486319].
560 Berends N, Teunkens A, Vandermeersch E, et al. A randomized trial comparing low-dose combined spinal-epidural anesthesia and conventional epidural anesthesia for cesarean section in severe preeclampsia. Acta Anaesthesiol Belg. 2005;56(2):155-62. X-9. [pmid: 16013660].
561 Berenson AB, Hammill HA, Martens MG, et al. Bacteriologic findings of post-cesarean endometritis in adolescents. Obstet Gynecol. Apr. 1990;75(4):627-9. X-1. [pmid: 2314783].
562 Berenson AB, Wiemann CM, Wilkinson GS, et al. Perinatal morbidity associated with violence experienced by pregnant women. Am J Obstet Gynecol. Jun. 1994;170(6):1760-6. discussion 1766-9. X-1. [pmid: 8203437].
563 Berg G, Andersson RG, Ryden G. Beta-adrenergic receptors in human myometrium during pregnancy: changes in the number of receptors after beta-mimetic treatment. Am J Obstet Gynecol. Feb. 1. 1985;151(3):392-6. X-1. [pmid: 2982269].
564 Berg M, Adlerberth A, Sultan B, et al. Early random capillary glucose level screening and multidisciplinary antenatal teamwork to improve outcome in gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2007;86(3):283-90. X-1. [pmid: 17364301].
565 Berg S, Engman A, Holmgren S, et al. Increased plasma hyaluronan in severe pre-eclampsia and eclampsia. Scand J Clin Lab Invest. Apr. 2001;61(2):131-7. X-1. [pmid: 11347980].
566 Bergenstrom A, Sherr L. HIV testing and prevention issues for women attending termination assessment clinics. Br J Fam Plann. Apr. 1999;25(1):3-8. X-1. [pmid: 10228241].
567 Berger N, Vaillancourt C, Boksa P. Interactive effects of anoxia and general anesthesia during birth on the degree of CNS and systemic hypoxia produced in neonatal rats. Exp Brain Res. Apr. 2000;131(4):524-31. X-1. [pmid: 10803420].
568 Berger R, Sawodny E, Bachmann G, et al. The prognostic value of magnetic resonance imaging for the management of breech delivery. Eur J Obstet Gynecol Reprod Biol. Jun. 15. 1994;55(2):97-103. X-1. [pmid: 7958156].
569 Bergeron V. The ethics of cesarean section on maternal request: a feminist critique of the American College of Obstetricians and Gynecologists' position on patient-choice surgery. Bioethics. Nov. 2007;21(9):478-87. X-1, X-2. [pmid: 17927624].
570 Bergholt T, Ostberg B, Legarth J, et al. Danish obstetricians' personal preference and general attitude to elective cesarean section on maternal request: a nation-wide postal survey. Acta Obstet Gynecol Scand. Mar. 2004;83(3):262-6. X-1. [pmid: 14995922].
571 Berglund S, Grunewald C, Pettersson H, et al. Risk factors for asphyxia associated with substandard care during labor. Acta Obstet Gynecol Scand. 2010;89(1):39-48. X-1. [pmid: 19961278].
572 Bergsjo P, Bakketeig LS, Eikhom SN. Case-control analysis of post-term induction of labor. Acta Obstet Gynecol Scand. 1982;61(4):317-24. X-1. [pmid: 7148405].
573 Bergstrom H, Bernstein K. Psychic reactions after analgesia with nitrous oxide for caesarean section. Lancet. Sep. 7. 1968;2(7567):541-2. X-1, X-9. [pmid: 4175401].
574 Bergstrom M, Kieler H, Waldenstrom U. Psychoprophylaxis during labor: associations with labor-related outcomes and experience of childbirth. Acta Obstet Gynecol Scand. Jun. 2010;89(6):794-800. X-1. [pmid: 20225989].
575 Berkeley AS, Freedman KS, Hirsch JC, et al. Randomized, comparative trial of imipenem/cilastatin and moxalactam in the treatment of serious obstetric and gynecologic infections. Surg Gynecol Obstet. Mar. 1986;162(3):204-8. X-4e. [pmid: 3513346].
576 Berkeley AS, Hirsch JC, Freedman KS, et al. Cefotaxime for cesarean section prophylaxis in labor. Intravenous administration vs. lavage. J Reprod Med. Mar. 1990;35(3):214-8. X-9. [pmid: 2325029].
577 Berkman H. A discussion of medical malpractice and cesarean section. Spec Law Dig Health Care Law. Apr. 1993;(170):9-30. X-1. [pmid: 10125422].
578 Berkovitch M, Pastuszak A, Gazarian M, et al. Safety of the new quinolones in pregnancy. Obstet Gynecol. Oct. 1994;84(4):535-8. X-1. [pmid: 8090389].
579 Berkowitz RL, Lesser ML, McFarland JG, et al. Antepartum treatment without early cordocentesis for standard-risk alloimmune thrombocytopenia: a randomized controlled trial. Obstet Gynecol. Aug. 2007;110(2 Pt 1):249-55. X-1. [pmid: 17666597].
580 Berkus MD, Ramamurthy RS, O'Connor PS, et al. Cohort study of Silastic obstetric vacuum cup deliveries: II. Unsuccessful vacuum extraction. Obstet Gynecol. Nov. 1986;68(5):662-6. X-1. [pmid: 3763080].
581 Bermeo ME, Fomin VP, Ventolini G, et al. Magnesium sulfate induces translocation of protein kinase C isoenzymes alpha and delta in myometrial cells from pregnant women. Am J Obstet Gynecol. Feb. 2004;190(2):522-7. X-1. [pmid: 14981400].
582 Bernard JM, Le Roux D, Frouin J. Ropivacaine and fentanyl concentrations in patient-controlled epidural analgesia during labor: a volume-range study. Anesth Analg. Dec. 2003;97(6):1800-7. X-4e, X-5. [pmid: 14633563].
583 Berne C, Wibell L, Lindmark G. Ten-year experience of insulin treatment in gestational diabetes. Acta Paediatr Scand Suppl. 1985;320:85-93. X-1. [pmid: 3914817].
584 Bernstein P. Prostaglandin E2 gel for cervical ripening and labour induction: a multicentre placebo-controlled trial. CMAJ. Nov. 15. 1991;145(10):1249-54. X-4d, X-5. [pmid: 1933707].
585 Bettes BA, Coleman VH, Zinberg S, et al. Cesarean delivery on maternal request: obstetrician-gynecologists' knowledge, perception, and practice patterns. Obstet Gynecol. Jan. 2007;109(1):57-66. X-1. [pmid: 17197588].
586 Beverly HM, Clark KM. Is there a difference in fetal oxygenation when varying amounts of oxygen are delivered to the mother during elective cesarean section under spinal or epidural anesthesia?… State of the Science Oral and Poster Sessions: part 2. AANA Journal. 2006;74(6):463-464. X-4b.
587 Bevier WC, Fischer R, Jovanovic L. Treatment of women with an abnormal glucose challenge test (but a normal oral glucose tolerance test) decreases the prevalence of macrosomia. Am J Perinatol. 1999;16(6):269-75. X-1. [pmid: 10586979].
588 Bhagwanjee S, Rocke DA, Rout CC, et al. Prevention of hypotension following spinal anaesthesia for elective caesarean section by wrapping of the legs. Br J Anaesth. Dec. 1990;65(6):819-22. X-9. [pmid: 2265052].
589 Bhalla AK, Sarala G, Dhaliwal L. Pregnancy following infertility. Aust N Z J Obstet Gynaecol. Aug. 1992;32(3):249-51. X-1. [pmid: 1445139].
590 Bhatta MP, Stringer JS, Phanuphak P, et al. Mother-to-child HIV transmission prevention in Thailand: physician zidovudine use and willingness to provide care. Int J STD AIDS. Jun. 2003;14(6):404-10. X-1. [pmid: 12816669].
591 Bhattacharjee N, Ganguly RP, Saha SP. Misoprostol for termination of mid-trimester post-Caesarean pregnancy. Aust N Z J Obstet Gynaecol. Feb. 2007;47(1):23-5. X-1. [pmid: 17261095].
592 Bhattacharya N. Placental umbilical cord blood transfusion: a new method of treatment of patients with diabetes and microalbuminuria in the background of anemia. Clin Exp Obstet Gynecol. 2006;33(3):164-8. X-1. [pmid: 17089581].
593 Bhattacharya N. Transient spontaneous engraftment of CD34 hematopoietic cord blood stem cells as seen in peripheral blood: treatment of leprosy patients with anemia by placental umbilical cord whole blood transfusion. Clin Exp Obstet Gynecol. 2006;33(3):159-63. X-1. [pmid: 17089580].
594 Bhattacharya S, Porter M, Harrild K, et al. Absence of conception after caesarean section: voluntary or involuntary?. BJOG. Mar. 2006;113(3):268-75. X-1. [pmid: 16487197].
595 Bhattarai B, Bhat SY, Upadya M. Comparison of bolus phenylephrine, ephedrine and mephentermine for maintenance of arterial pressure during spinal anesthesia in cesarean section. JNMA J Nepal Med Assoc. Jan-Mar. 2010;49(177):23-8. X-9. [pmid: 21180216].
596 Bhutta ZA, Darmstadt GL, Haws RA, et al. Delivering interventions to reduce the global burden of stillbirths. Neonatal Intensive Care. 2009;22(7):39-43. X-1, X-2.
597 Biale Y, Brawer-Ostrovsky Y, Insler V. Fetal heart rate tracings in fetuses with congenital malformations. J Reprod Med. Jan. 1985;30(1):43-7. X-1. [pmid: 3973859].
598 Bianco A, Stone J, Lynch L, et al. Pregnancy outcome at age 40 and older. Obstet Gynecol. Jun. 1996;87(6):917-22. X-1. [pmid: 8649698].
599 Bick DE, MacArthur C. Attendance, content and relevance of the six week postnatal examination. Midwifery. Jun. 1995;11(2):69-73. X-1. [pmid: 7616861].
600 Bider D, Blankstein J, Tur-Kaspa I. Fertility in anovulatory patients after primary cesarean section. J Reprod Med. Oct. 1998;43(10):869-71. X-1. [pmid: 9800669].
601 Biderman-Madar T, Sheiner E, Levy A, et al. Uterine leiomyoma among women who conceived following fertility treatment. Arch Gynecol Obstet. Sep. 2005;272(3):218-22. X-1. [pmid: 15971053].
602 Biggio JR Jr., Wenstrom KD, Dubard MB, et al. Hydramnios prediction of adverse perinatal outcome. Obstet Gynecol. Nov. 1999;94(5 Pt 1):773-7. X-1. [pmid: 10546727].
603 Bignardi T, Condous G. Transrectal ultrasound-guided surgical evacuation of Cesarean scar ectopic pregnancy. Ultrasound Obstet Gynecol. Apr. 2010;35(4):481-5. X-1. [pmid: 20183866].
604 Bilder D, Pinborough-Zimmerman J, Miller J, et al. Prenatal, perinatal, and neonatal factors associated with autism spectrum disorders. Pediatrics. May. 2009;123(5):1293-300. X-1. [pmid: 19403494].
605 Bilgin T, Kadioglu M, Yildirim V, et al. A randomized trial of intracervical prostaglandin gel and intravenous oxytocin in prelabor rupture of membranes with unripe cervix at term. Clin Exp Obstet Gynecol. 1998;25(1-2):46-8. X-3, X-4e, X-5. [pmid: 9743881].
606 Bimbashi A, Ndoni E, Dokle A, et al. Care during the third stage of labour: obstetricians views and practice in an Albanian maternity hospital. BMC Pregnancy Childbirth. 2010;10:4. X-1. [pmid: 20102601].
607 Binder T, Hajek Z, Zoban P, et al. Conducting labor in women with previous caesarean section in a low gestational week. A prospective case-controlled study. Gynecol Obstet Invest. 2008;66(3):197-202. X-1. [pmid: 18612204].
608 Binsted RJ. Epidural morphine after caesarean section. Anaesth Intensive Care. May. 1983;11(2):130-4. X-9. [pmid: 6869775].
609 Bique C, Bugalho A, Bergstrom S. Labor induction by vaginal misoprostol in grand multiparous women. Acta Obstet Gynecol Scand. Mar. 1999;78(3):198-201. X-1. [pmid: 10078580].
610 Birch L, Culshaw A. Drug error in maternity care: a multiprofessional issue. British Journal of Midwifery. 2003;11(3):173-175. X-1.
611 Birnkrant DJ, Picone C, Markowitz W, et al. Association of transient tachypnea of the newborn and childhood asthma. Pediatr Pulmonol. Oct. 2006;41(10):978-84. X-1. [pmid: 16871596].
612 Biswas R, Sawhney H, Dass R, et al. Histopathological study of placental bed biopsy in placenta previa. Acta Obstet Gynecol Scand. Mar. 1999;78(3):173-9. X-1. [pmid: 10078576].
613 Bivins HA Jr., Cope DA, Newman RB, et al. Randomized trial of intraumbilical vein oxytocin in midtrimester pregnancy losses. Am J Obstet Gynecol. Oct. 1993;169(4):1070-3. X-3, X-4e, X-5. [pmid: 8238122].
614 Bjelic-Radisic V, Pristauz G, Haas J, et al. Neonatal outcome of second twins depending on presentation and mode of delivery. Twin Res Hum Genet. Jun. 2007;10(3):521-7. X-1. [pmid: 17564511].
615 Bjercke S, Dale PO, Tanbo T, et al. Impact of insulin resistance on pregnancy complications and outcome in women with polycystic ovary syndrome. Gynecol Obstet Invest. 2002;54(2):94-8. X-1. [pmid: 12566751].
616 Bjorklund K, Kimaro M, Urassa E, et al. Introduction of the Misgav Ladach caesarean section at an African tertiary centre: a randomised controlled trial. BJOG. Feb. 2000;107(2):209-16. X-9. [pmid: 10688504].
617 Bjornestad E, Iversen OE, Raeder J. Wrapping of the legs versus phenylephrine for reducing hypotension in parturients having epidural anaesthesia for caesarean section: a prospective, randomized and double-blind study. Eur J Anaesthesiol. Oct. 2009;26(10):842-6. X-9. [pmid: 19617841].
618 Bjornestad E, Iversen OL, Raeder J. Similar onset time of 2-chloroprocaine and lidocaine + epinephrine for epidural anesthesia for elective Cesarean section. Acta Anaesthesiol Scand. Mar. 2006;50(3):358-63. X-9. [pmid: 16480471].
619 Bjornestad E, Smedvig JP, Bjerkreim T, et al. Epidural ropivacaine 7.5 mg/ml for elective Caesarean section: a double-blind comparison of efficacy and tolerability with bupivacaine 5 mg/ml. Acta Anaesthesiol Scand. Jul. 1999;43(6):603-8. X-9. [pmid: 10408812].
620 Bjornsdottir S, Cnattingius S, Brandt L, et al. Addison's disease in women is a risk factor for an adverse pregnancy outcome. J Clin Endocrinol Metab. Dec. 2010;95(12):5249-57. X-1. [pmid: 20861125].
621 Bjune K, Stubhaug A, Dodgson MS, et al. Additive analgesic effect of codeine and paracetamol can be detected in strong, but not moderate, pain after Caesarean section. Baseline pain-intensity is a determinant of assay-sensitivity in a postoperative analgesic trial. Acta Anaesthesiol Scand. Apr. 1996;40(4):399-407. X-9. [pmid: 8738682].
622 Black SB, Shinefield HR, France EK, et al. Effectiveness of influenza vaccine during pregnancy in preventing hospitalizations and outpatient visits for respiratory illness in pregnant women and their infants. Am J Perinatol. Aug. 2004;21(6):333-9. X-1. [pmid: 15311370].
623 Blair M, Eliadi C. Preventing premature birth disparities. Minority Nurse. 2009:30-32. X-1, X-4e.
624 Blanchette HA, Nayak S, Erasmus S. Comparison of the safety and efficacy of intravaginal misoprostol (prostaglandin E1) with those of dinoprostone (prostaglandin E2) for cervical ripening and induction of labor in a community hospital. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1551-9. X-1. [pmid: 10368503].
625 Blanco JD, Collins M, Willis D, et al. Prostaglandin E2 gel induction of patients with a prior low transverse cesarean section. Am J Perinatol. Mar. 1992;9(2):80-3. X-1. [pmid: 1590872].
626 Blanco JD, Gibbs RS, Duff P, et al. Randomized comparison of ceftazidime versus clindamycin-tobramycin in the treatment of obstetrical and gynecological infections. Antimicrob Agents Chemother. Oct. 1983;24(4):500-4. X-3, X-4e. [pmid: 6360038].
627 Bland BA, Lawes EG, Duncan PW, et al. Comparison of midazolam and thiopental for rapid sequence anesthetic induction for elective cesarean section. Anesth Analg. Nov. 1987;66(11):1165-8. X-9. [pmid: 3662061].
628 Bland RD, Albertine KH, Carlton DP, et al. Chronic lung injury in preterm lambs: abnormalities of the pulmonary circulation and lung fluid balance. Pediatr Res. Jul. 2000;48(1):64-74. X-1. [pmid: 10879802].
629 Blegen MA, Reiter RC, Goode CJ, et al. Outcomes of hospital-based managed care: a multivariate analysis of cost and quality. Obstet Gynecol. Nov. 1995;86(5):809-14. X-1. [pmid: 7566854].
630 Blickenstaff DC. Defining the boundaries of personal privacy: is there a paternal interest in compelling therapeutic fetal surgery?. Northwest Univ Law Rev. Spring. 1994;88(3):1157-99. X-1, X-2. [pmid: 11656414].
631 Blickstein I, Goldman RD, Kupferminc M. Delivery of breech first twins: a multicenter retrospective study. Obstet Gynecol. Jan. 2000;95(1):37-42. X-1. [pmid: 10636499].
632 Blitt CD, Petty WC, Alberternst EE, et al. Correlation of plasma cholinesterase activity and duration of action of succinylcholine during pregnancy. Anesth Analg. Jan-Feb. 1977;56(1):78-83. X-1. [pmid: 556913].
633 Bloch-Salisbury E, Hall MH, Sharma P, et al. Heritability of apnea of prematurity: a retrospective twin study. Pediatrics. Oct. 2010;126(4):e779-87. X-1. [pmid: 20837586].
634 Blom EA, Jansen PW, Verhulst FC, et al. Perinatal complications increase the risk of postpartum depression. The Generation R Study. BJOG. Oct. 2010;117(11):1390-8. X-1. [pmid: 20682022].
635 Blondel B, Macfarlane A, Gissler M, et al. Preterm birth and multiple pregnancy in European countries participating in the PERISTAT project. BJOG. May. 2006;113(5):528-35. X-1. [pmid: 16637897].
636 Blondel B, Zein A, Ghosn N, et al. Collecting population-based perinatal data efficiently: the example of the Lebanese National Perinatal Survey. Paediatr Perinat Epidemiol. Sep. 2006;20(5):416-24. X-1. [pmid: 16911021].
637 Bloom SL, Leveno KJ, Spong CY, et al. Decision-to-incision times and maternal and infant outcomes. Obstet Gynecol. Jul. 2006;108(1):6-11. X-1. [pmid: 16816049].
638 Blum M. Is the elderly primipara really at high risk?. J Perinat Med. 1979;7(2):108-12. X-1. [pmid: 469694].
639 Blumenthal NJ, Merrell DA, Langer O. Obstetrics in the very young black South African teenager. S Afr Med J. Apr. 3. 1982;61(14):518-20. X-1. [pmid: 7064033].
640 Blumgart CH, Ryall D, Dennison B, et al. Mechanism of extension of spinal anaesthesia by extradural injection of local anaesthetic. Br J Anaesth. Nov. 1992;69(5):457-60. X-9. [pmid: 1467075].
641 Bobadilla JL, Walker GJ. Early neonatal mortality and cesarean delivery in Mexico City. Am J Obstet Gynecol. Jan. 1991;164(1 Pt 1):22-8. X-1. [pmid: 1986611].
642 Boccolini CS, Carvalho ML, Oliveira MI, et al. Factors associated with breastfeeding in the first hour of life. Rev Saude Publica. Feb. 2011;45(1):69-78. X-1. [pmid: 21085886].
643 Boda D, Muranyi L, Eck E. Experiments on placental circulation and transplacental transfer in exteriorized foetuses in hypoxia and after asphyxia in guinea pigs. Z Geburtshilfe Perinatol. Apr. 1976;180(2):112-6. X-1, X-3. [pmid: 947105].
644 Bodelon C, Bernabe-Ortiz A, Schiff MA, et al. Factors associated with peripartum hysterectomy. Obstet Gynecol. Jul. 2009;114(1):115-23. X-1. [pmid: 19546767].
645 Bodmer B, Benjamin A, McLean FH, et al. Has use of cesarean section reduced the risks of delivery in the preterm breech presentation?. Am J Obstet Gynecol. Feb. 1986;154(2):244-50. X-1. [pmid: 3946510].
646 Bodner-Adler B, Bodner K, Kaider A, et al. Risk factors for third-degree perineal tears in vaginal delivery, with an analysis of episiotomy types. J Reprod Med. Aug. 2001;46(8):752-6. X-1. [pmid: 11547651].
647 Bodner-Adler B, Bodner K, Pateisky N, et al. Influence of labor induction on obstetric outcomes in patients with prolonged pregnancy: a comparison between elective labor induction and spontaneous onset of labor beyond term. Wien Klin Wochenschr. Apr. 2005;117(7-8):287-92. X-1. [pmid: 15926620].
648 Boer K, Nellen JF, Patel D, et al. The AmRo study: pregnancy outcome in HIV-1-infected women under effective highly active antiretroviral therapy and a policy of vaginal delivery. BJOG. Feb. 2007;114(2):148-55. X-1. [pmid: 17305888].
649 Boers KE, Vijgen SM, Bijlenga D, et al. Induction versus expectant monitoring for intrauterine growth restriction at term: randomised equivalence trial (DIGITAT). BMJ. 2010;341:c7087. X-4e. [pmid: 21177352].
650 Bofill JA, Rust OA, Perry KG, et al. Operative vaginal delivery: a survey of fellows of ACOG. Obstet Gynecol. Dec. 1996;88(6):1007-10. X-1. [pmid: 8942843].
651 Bofill JA, Vincent RD, Ross EL, et al. Nulliparous active labor, epidural analgesia, and cesarean delivery for dystocia. Am J Obstet Gynecol. Dec. 1997;177(6):1465-70. X-4e, X-5. [pmid: 9423752].
652 Bogg L, Huang K, Long Q, et al. Dramatic increase of Cesarean deliveries in the midst of health reforms in rural China. Soc Sci Med. May. 2010;70(10):1544-9. X-1. [pmid: 20219278].
653 Bogod DG, Rosen M, Rees GA. Maximum FIO2 during caesarean section. Br J Anaesth. Sep. 1988;61(3):255-62. X-9. [pmid: 3140861].
654 Bohra U, Donnelly J, O'Connell MP, et al. Active management of labour revisited: the first 1000 primiparous labours in 2000. J Obstet Gynaecol. Mar. 2003;23(2):118-20. X-1. [pmid: 12745551].
655 Boldt T, Luukkainen P, Fyhrquist F, et al. Birth stress increases adrenomedullin in the newborn. Acta Paediatr. Jan. 1998;87(1):93-4. X-1. [pmid: 9510455].
656 Bolnick JM, Velazquez MD, Gonzalez JL, et al. Randomized trial between two active labor management protocols in the presence of an unfavorable cervix. Am J Obstet Gynecol. Jan. 2004;190(1):124-8. X-4d. [pmid: 14749647].
657 Bonakdar MI, Eckhous AW, Bacher BJ, et al. Major gynecologic and obstetric surgery in Jehovah's Witnesses. Obstet Gynecol. Nov. 1982;60(5):587-90. X-1. [pmid: 7145251].
658 Bondok WM, El-Shehry SH, Fadllallah SM. Trend in cesarean section rate. Saudi Med J. Jan. 2011;32(1):41-5. X-1. [pmid: 21212915].
659 Bonebrake RG, Towers CV, Rumney PJ, et al. Is fluorescence polarization reliable and cost efficient in a fetal lung maturity cascade?. Am J Obstet Gynecol. Oct. 1997;177(4):835-41. X-1, X-3, X-4e. [pmid: 9369829].
660 Bonito M, Gulemi L, Basili R, et al. Myomectomy during the first and second trimester of pregnancy. Clin Exp Obstet Gynecol. 2007;34(3):149-50. X-1, X-2. [pmid: 17937088].
661 Bonomo M, Corica D, Mion E, et al. Evaluating the therapeutic approach in pregnancies complicated by borderline glucose intolerance: a randomized clinical trial. Diabet Med. Nov. 2005;22(11):1536-41. X-4e, X-5. [pmid: 16241919].
662 Bonomo M, Gandini ML, Farina A, et al. Should we treat minor degrees of glucose intolerance in pregnancy?. Ann Ist Super Sanita. 1997;33(3):393-7. X-1. [pmid: 9542269].
663 Boo NY, Lye MS. Factors associated with clinically significant perinatal asphyxia in the Malaysian neonates: a case-control study. J Trop Pediatr. Dec. 1992;38(6):284-9. X-1. [pmid: 1844086].
664 Booth VJ, Nelson KB, Dambrosia JM, et al. What factors influence whether placentas are submitted for pathologic examination?. Am J Obstet Gynecol. Mar. 1997;176(3):567-71. X-1. [pmid: 9077608].
665 Boothby R, Benrubi G, Ferrell E. Comparison of intravenous cefoxitin prophylaxis with intraoperative cefoxitin irrigation for the prevention of post-cesarean-section endometritis. J Reprod Med. Nov. 1984;29(11):830-2. X-9. [pmid: 6520821].
666 Borekci B, Aksoy H, Toker A, et al. Placental tissue cyclo-oxygenase 1 and 2 in pre-eclamptic and normal pregnancy. Int J Gynaecol Obstet. Nov. 2006;95(2):127-31. X-1. [pmid: 16930602].
667 Borello-France D, Burgio KL, Richter HE, et al. Fecal and urinary incontinence in primiparous women. Obstet Gynecol. Oct. 2006;108(4):863-72. X-1. [pmid: 17012447].
668 Borghi J, Bastus S, Belizan M, et al. Costs of publicly provided maternity services in Rosario, Argentina. Salud Publica Mex. Jan-Feb. 2003;45(1):27-34. X-1. [pmid: 12649959].
669 Borruto F, Treisser A, Comparetto C. Utilization of carbetocin for prevention of postpartum hemorrhage after cesarean section: a randomized clinical trial. Arch Gynecol Obstet. Nov. 2009;280(5):707-12. X-9. [pmid: 19229549].
670 Bosch FX, Munoz N, de Sanjose S, et al. Risk factors for cervical cancer in Colombia and Spain. Int J Cancer. Nov. 11. 1992;52(5):750-8. X-1. [pmid: 1330934].
671 Bost BW. Cesarean delivery on demand: what will it cost?. Am J Obstet Gynecol. Jun. 2003;188(6):1418-21. discussion 1421-3. X-1. [pmid: 12824972].
672 Bott J. Clinical. HIV screening issues for midwives. British Journal of Midwifery. 2000;8(2):72-78. X-1, X-2.
673 Boucher M, Horbay GL, Griffin P, et al. Double-blind, randomized comparison of the effect of carbetocin and oxytocin on intraoperative blood loss and uterine tone of patients undergoing cesarean section. J Perinatol. May-Jun. 1998;18(3):202-7. X-9. [pmid: 9659650].
674 Boulvain M, Perneger TV, Othenin-Girard V, et al. Home-based versus hospital-based postnatal care: a randomised trial. BJOG. Aug. 2004;111(8):807-13. X-3, X-4e. [pmid: 15270928].
675 Bourgeois FJ, Harbert GM Jr., Andersen WA, et al. Early versus late tocolytic treatment for preterm premature membrane rupture. Am J Obstet Gynecol. Sep. 1988;159(3):742-8. X-4e, X-5. [pmid: 3421274].
676 Bourgeois FJ, Pinkerton JA, Andersen W, et al. Antibiotic irrigation prophylaxis in the high-risk cesarean section patient. Am J Obstet Gynecol. Sep. 15. 1985;153(2):197-201. X-9. [pmid: 3929609].
677 Bourjeily G, Raker CA, Chalhoub M, et al. Pregnancy and fetal outcomes of symptoms of sleep-disordered breathing. Eur Respir J. Oct. 2010;36(4):849-55. X-1. [pmid: 20525714].
678 Bourlert A. Diclofenac intramuscular single dose to decrease pain in post operative Caesarean section: a double blind randomized controlled trial. J Med Assoc Thai. Jan. 2005;88(1):15-9. X-9. [pmid: 15960211].
679 Bourne TM, deMelo AE, Bastianpillai BA, et al. A survey of how British obstetric anaesthetists test regional anaesthesia before caesarean section. Anaesthesia. Sep. 1997;52(9):901-3. X-1. [pmid: 9349076].
680 Bouvet L, Da-Col X, Chassard D, et al. ED and ED of intrathecal levobupivacaine with opioids for Caesarean delivery. Br J Anaesth. Feb. 2011;106(2):215-20. X-9. [pmid: 21037268].
681 Bouvier-Colle MH, Ould El Joud D, Varnoux N, et al. Evaluation of the quality of care for severe obstetrical haemorrhage in three French regions. BJOG. Sep. 2001;108(9):898-903. X-1. [pmid: 11563457].
682 Bouvier-Colle MH, Varnoux N, Salanave B, et al. Case-control study of risk factors for obstetric patients' admission to intensive care units. Eur J Obstet Gynecol Reprod Biol. Aug. 1997;74(2):173-7. X-1. [pmid: 9306113].
683 Bowden AP, Barrett JH, Fallow W, et al. Women with inflammatory polyarthritis have babies of lower birth weight. J Rheumatol. Feb. 2001;28(2):355-9. X-1. [pmid: 11246676].
684 Bowes WA Jr., Bowes C. Current role of the midforceps operation. Clin Obstet Gynecol. Jun. 1980;23(2):549-57. X-1, X-2. [pmid: 7398165].
685 Boyer SG, Boyer KM. Update on TORCH infections in the newborn infant. Newborn & Infant Nursing Reviews. 2004;4(1):70-80. X-1, X-2.
686 Boyle JG, Gabbe SG. T and J vertical extensions in low transverse cesarean births. Obstet Gynecol. Feb. 1996;87(2):238-43. X-1. [pmid: 8559531].
687 Boyle RK. Herpes simplex labialis after epidural or parenteral morphine: a randomized prospective trial in an Australian obstetric population. Anaesth Intensive Care. Aug. 1995;23(4):433-7. X-9. [pmid: 7485932].
688 Bozkaya H, Mocan H, Usluca H, et al. A retrospective analysis of adolescent pregnancies. Gynecol Obstet Invest. 1996;42(3):146-50. X-4d. [pmid: 8938462].
689 Bozkurt N, Kurdoglu M, Kurdoglu Z, et al. Postoperative pain control after cesarean section: can diclofenac sodium be used instead of meperidine?. J Matern Fetal Neonatal Med. Dec. 2009;22(12):1144-50. X-9. [pmid: 19916712].
690 Brabin L, Verhoeff FH, Kazembe P, et al. Improving antenatal care for pregnant adolescents in southern Malawi. Acta Obstet Gynecol Scand. Apr. 1998;77(4):402-9. X-1. [pmid: 9598948].
691 Brace V, Kernaghan D, Penney G. Learning from adverse clinical outcomes: major obstetric haemorrhage in Scotland, 2003-05. BJOG. Nov. 2007;114(11):1388-96. X-1. [pmid: 17949379].
692 Bracero LA. Ampicillin/sulbactam versus cefotetan for the prevention of infection following cesarean delivery in high-risk patients: a randomized double-blind trial. Gynecol Obstet Invest. 1997;44(1):21-5. X-9. [pmid: 9251949].
693 Bracero LA, Evanco J, Byrne DW. Doppler velocimetry discordancy of the uterine arteries in pregnancies complicated by diabetes. J Ultrasound Med. Jun. 1997;16(6):387-93. X-1. [pmid: 9315182].
694 Bracero LA, Morgan S, Byrne DW. Comparison of visual and computerized interpretation of nonstress test results in a randomized controlled trial. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1254-8. X-4e. [pmid: 10561655].
695 Bracken JN, Dryfhout VL, Goldenhar LM, et al. Preferences and concerns for delivery: an antepartum survey. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1527-31. X-1. [pmid: 18633559].
696 Bradley LA, Canick JA, Palomaki GE, et al. Undetectable maternal serum unconjugated estriol levels in the second trimester: risk of perinatal complications associated with placental sulfatase deficiency. Am J Obstet Gynecol. Mar. 1997;176(3):531-5. X-1. [pmid: 9077601].
697 Braekke K, Harsem NK, Staff AC. Oxidative stress and antioxidant status in fetal circulation in preeclampsia. Pediatr Res. Nov. 2006;60(5):560-4. X-1. [pmid: 16988193].
698 Braekke K, Holthe MR, Harsem NK, et al. Calprotectin, a marker of inflammation, is elevated in the maternal but not in the fetal circulation in preeclampsia. Am J Obstet Gynecol. Jul. 2005;193(1):227-33. X-1. [pmid: 16021084].
699 Braekke K, Ueland PM, Harsem NK, et al. Homocysteine, cysteine, and related metabolites in maternal and fetal plasma in preeclampsia. Pediatr Res. Sep. 2007;62(3):319-24. X-1. [pmid: 17622947].
700 Braekke K, Ueland PM, Harsem NK, et al. Asymmetric dimethylarginine in the maternal and fetal circulation in preeclampsia. Pediatr Res. Oct. 2009;66(4):411-5. X-1. [pmid: 19581842].
701 Braga Ade F, Braga FS, Poterio GM, et al. Sufentanil added to hyperbaric bupivacaine for subarachnoid block in Caesarean section. Eur J Anaesthesiol. Aug. 2003;20(8):631-5. X-9. [pmid: 12932064].
702 Braga Ade F, Frias JA, Braga FS, et al. Epidural block for cesarean section: a comparative study between 0.5% racemic Bupivacaine (S50-R50) and 0.5% enantiomeric excess Bupivacaine (S75-R25) associated with Sufentanil. Rev Bras Anestesiol. May-Jun. 2009;59(3):261-72. X-9. [pmid: 19488539].
703 Braga Ade F, Frias JA, Braga FS, et al. Spinal block with 10 mg of hyperbaric bupivacaine associated with 5 microg of sufentanil for cesarean section. Study of different volumes. Rev Bras Anestesiol. Apr. 2010;60(2):121-9. 69. 73. X-9. [pmid: 20485956].
704 Bragg F, Cromwell DA, Edozien LC, et al. Variation in rates of caesarean section among English NHS trusts after accounting for maternal and clinical risk: cross sectional study. BMJ. 2010;341:c5065. X-1. [pmid: 20926490].
705 Brahams D. Pregnancy following sterilisation: two cases fail. Lancet. Mar. 14. 1987;1(8533):638. X-1, X-2. [pmid: 2881179].
706 Brahams D. Caesarean sections by court order. Lancet. Sep. 21. 1996;348(9030):770. X-1, X-2. [pmid: 8813981].
707 Braig S, Luton D, Sibony O, et al. Acyclovir prophylaxis in late pregnancy prevents recurrent genital herpes and viral shedding. Eur J Obstet Gynecol Reprod Biol. May. 2001;96(1):55-8. X-3, X-4e, X-5. [pmid: 11311761].
708 Bramer S, van Wijk FH, Mol BW, et al. Risk indicators for neonatal early-onset GBS-related disease. A case-control study. J Perinat Med. 1997;25(6):469-75. X-1. [pmid: 9494918].
709 Brancato RM, Church S, Stone PW. In the media: a meta-analysis of passive descent versus immediate pushing in nulliparous women with epidural analgesia in the second stage of labor. Reprinted from Journal of Obstetric, Gynecologic and Neonatal Nursing, 2008, Volume 37, p. 4-12 with permission from Blackwell Publishing, Oxford, UK. Academic Nurse. 2008;25(1):18-18. X-1.
710 Brar HS, Do YS, Tam HB, et al. Uteroplacental unit as a source of elevated circulating prorenin levels in normal pregnancy. Am J Obstet Gynecol. Dec. 1986;155(6):1223-6. X-1. [pmid: 3538876].
711 Brar HS, Platt LD, Paul RH. Fetal umbilical blood flow velocity waveforms using Doppler ultrasonography in patients with late decelerations. Obstet Gynecol. Mar. 1989;73(3 Pt 1):363-6. X-1. [pmid: 2644596].
712 Brashear WT, Zuspan KJ, Lazebnik N, et al. Effect of ranitidine on bupivacaine disposition. Anesth Analg. Mar. 1991;72(3):369-76. X-9. [pmid: 1994765].
713 Braveman P, Egerter S, Edmonston F, et al. Racial/ethnic differences in the likelihood of cesarean delivery, California. Am J Public Health. May. 1995;85(5):625-30. X-1. [pmid: 7733420].
714 Bray JK, Fernando R, Patel NP, et al. Suprasternal Doppler estimation of cardiac output: standard versus sequential combined spinal epidural anesthesia for cesarean delivery. Anesth Analg. Oct. 2006;103(4):959-64. X-9. [pmid: 17000812].
715 Breart G, Mlika-Cabane N, Kaminski M, et al. Evaluation of different policies for the management of labour. Early Hum Dev. Jun-Jul. 1992;29(1-3):309-12. X-1. [pmid: 1396258].
716 Bredfeldt RC, Thomas JM, Massie M. Pregnancy care in family practice: medical student perspectives on specialty and residency selection. Fam Med. Mar. 1994;26(3):145-8. X-1. [pmid: 8026657].
717 Breen TW, Janzen JA. Epidural fentanyl and caesarean section: when should fentanyl be given?. Can J Anaesth. Apr. 1992;39(4):317-22. X-9. [pmid: 1563055].
718 Bremerich DH, Fetsch N, Zwissler BC, et al. Comparison of intrathecal bupivacaine and levobupivacaine combined with opioids for Caesarean section. Curr Med Res Opin. Dec. 2007;23(12):3047-54. X-9. [pmid: 17967219].
719 Bremerich DH, Schlosser RL, L'Allemand N, et al. Mepivacaine for spinal anesthesia in parturients undergoing elective cesarean delivery: maternal and neonatal plasma concentrations and neonatal outcome. Zentralbl Gynakol. Dec. 2003;125(12):518-21. X-1. [pmid: 14755363].
720 Bremme K, Eneroth P. Fetal sex dependent hormone levels in early pregnant women with elevated maternal serum alpha-fetoprotein. Int J Gynaecol Obstet. Dec. 1983;21(6):451-7. X-1. [pmid: 6198221].
721 Brenck F, Hartmann B, Jost A, et al. Examining the influence of maternal bradycardia on neonatal outcome using automated data collection. Int J Obstet Anesth. Jul. 2007;16(3):208-13. X-1. [pmid: 17459694].
722 Brennan DJ, Robson MS, Murphy M, et al. Comparative analysis of international cesarean delivery rates using 10-group classification identifies significant variation in spontaneous labor. Am J Obstet Gynecol. Sep. 2009;201(3):308 e1-8. X-1. [pmid: 19733283].
723 Brennecke SP, Gude NM, Di Iulio JL, et al. Reduction of placental nitric oxide synthase activity in pre-eclampsia. Clin Sci (Lond). Jul. 1997;93(1):51-5. X-1. [pmid: 9279203].
724 Brewster LM, Taherzadeh Z, Volger S, et al. Ethnic differences in resistance artery contractility of normotensive pregnant women. Am J Physiol Heart Circ Physiol. Aug. 2010;299(2):H431-6. X-1. [pmid: 20511407].
725 Breymann C, Zimmermann R, Huch R, et al. Use of recombinant human erythropoietin in combination with parenteral iron in the treatment of postpartum anaemia. Eur J Clin Invest. Feb. 1996;26(2):123-30. X-4e. [pmid: 8904521].
726 Brian DAJI, Agbai AO. Pattern of twin births in Nigerian Igbo women. West Afr J Med. Oct-Dec. 1994;13(4):234-6. X-1. [pmid: 7756191].
727 Briana DD, Boutsikou M, Baka S, et al. Omentin-1 and vaspin are present in the fetus and neonate, and perinatal concentrations are similar in normal and growth-restricted pregnancies. Metabolism. Apr. 2011;60(4):486-90. X-1. [pmid: 20488498].
728 Bricker L, Peden H, Tomlinson AJ, et al. Titrated low-dose vaginal and/or oral misoprostol to induce labour for prelabour membrane rupture: a randomised trial. BJOG. Nov. 2008;115(12):1503-11. X-4d, X-4e. [pmid: 18752586].
729 Bridgeman J. Medical treatment: the mother's rights. Family Law. Sep. 1993;23:534-5. X-1. [pmid: 11657220].
730 Briery CM, Rose CH, Hudson WT, et al. Planned vs emergent cesarean hysterectomy. Am J Obstet Gynecol. Aug. 2007;197(2):154 e1-5. X-1. [pmid: 17689631].
731 Briggs GG, Ambrose P, Nageotte MP. Gentamicin dosing in postpartum women with endometritis. Am J Obstet Gynecol. Feb. 1989;160(2):309-13. X-3, X-4e, X-5. [pmid: 2486180].
732 Briggs ND. Outcome of labour in occipitoposterior positions in an African population. Br J Obstet Gynaecol. Oct. 1989;96(10):1234-6. X-1. [pmid: 2590661].
733 Brill Y, Kingdom J, Thomas J, et al. The management of VBAC at term: a survey of Canadian obstetricians. J Obstet Gynaecol Can. Apr. 2003;25(4):300-10. X-1. [pmid: 12679822].
734 Brink S. C-sections rise but may not be the kindest cut. US News World Rep. Sep. 4. 2000;129(9):63. X-1.
735 Brinton LA, Reeves WC, Brenes MM, et al. Parity as a risk factor for cervical cancer. Am J Epidemiol. Sep. 1989;130(3):486-96. X-1. [pmid: 2763994].
736 Britton JR. Postpartum early hospital discharge and follow-up practices in Canada and the United States. Birth. Sep. 1998;25(3):161-8. X-1. [pmid: 9767218].
737 Brizzi A, Greco F, Malvasi A, et al. Comparison of sequential combined spinal-epidural anesthesia and spinal anesthesia for cesarean section. Minerva Anestesiol. Nov. 2005;71(11):701-9. X-9. [pmid: 16278629].
738 Broberger U, Hansson U, Lagercrantz H, et al. Sympatho-adrenal activity and metabolic adjustment during the first 12 hours after birth in infants of diabetic mothers. Acta Paediatr Scand. Sep. 1984;73(5):620-5. X-1. [pmid: 6541415].
739 Brocklehurst P. Future research needs for venous thrombo-embolic disease in obstetrics and gynaecology. Baillieres Clin Obstet Gynaecol. Sep. 1997;11(3):601-10. X-1, X-2. [pmid: 9488794].
740 Brocklehurst P, Kinghorn G, Carney O, et al. A randomised placebo controlled trial of suppressive acyclovir in late pregnancy in women with recurrent genital herpes infection. Br J Obstet Gynaecol. Mar. 1998;105(3):275-80. X-5. [pmid: 9532986].
741 Brocks V, Philipsen T, Secher NJ. A randomized trial of external cephalic version with tocolysis in late pregnancy. Br J Obstet Gynaecol. Jul. 1984;91(7):653-6. X-4e. [pmid: 6743606].
742 Brock-Utne JG. Reversal of neuromuscular blockade by glycopyrrolate and neostigmine. A study of the effects on lower oesophageal sphincter tone. Anaesthesia. Jul-Aug. 1979;34(7):620-3. X-9. [pmid: 517713].
743 Brock-Utne JG, Buley RJ, Downing JW, et al. Advantages of left over right lateral tilt for caesarean section. S Afr Med J. Sep. 16. 1978;54(12):489-92. X-9. [pmid: 734581].
744 Brock-Utne JG, Rout C, Moodley J, et al. Influence of preoperative gastric aspiration on the volume and pH of gastric contents in obstetric patients undergoing caesarean section. Br J Anaesth. Apr. 1989;62(4):397-401. X-9. [pmid: 2706175].
745 Brodszki J, Morsing E, Malcus P, et al. Early intervention in management of very preterm growth-restricted fetuses: 2-year outcome of infants delivered on fetal indication before 30 gestational weeks. Ultrasound Obstet Gynecol. Sep. 2009;34(3):288-96. X-1. [pmid: 19705404].
746 Brook MG, Taylor GP, Dale A, et al. Management of HIV and pregnancy in England's North Thames Region 1999: a survey of practice in 21 hospitals. HIV Med. Jul. 2000;1(3):143-7. discussion 148. X-1. [pmid: 11737341].
747 Brooks GZ, Donchin Y, Collins JG, et al. Epidural morphine does not affect the duration of action of epidural 2-chloroprocaine following Caesarean section. Can Anaesth Soc J. Nov. 1983;30(6):598-602. X-9. [pmid: 6640396].
748 Brooten D, Knapp H, Borucki L, et al. Early discharge and home care after unplanned cesarean birth: nursing care time. J Obstet Gynecol Neonatal Nurs. Sep. 1996;25(7):595-600. X-1.
749 Brooten D, Naylor M, Brown L, et al. Profile of postdischarge rehospitalizations and acute care visits for seven patient groups. Public Health Nurs. Apr. 1996;13(2):128-34. X-1. [pmid: 8936246].
750 Brooten D, Roncoli M, Finkler S, et al. A randomized trial of early hospital discharge and home follow-up of women having cesarean birth. Obstet Gynecol. Nov. 1994;84(5):832-8. X-9. [pmid: 7936522].
751 Brose WG, Cohen SE. Oxyhemoglobin saturation following cesarean section in patients receiving epidural morphine, PCA, or im meperidine analgesia. Anesthesiology. Jun. 1989;70(6):948-53. X-9. [pmid: 2729636].
752 Brown CE, Stettler RW, Twickler D, et al. Puerperal septic pelvic thrombophlebitis: incidence and response to heparin therapy. Am J Obstet Gynecol. Jul. 1999;181(1):143-8. X-1. [pmid: 10411810].
753 Brown E, Carroll J, Fogarty C, et al. “They get a C-section…they gonna die”: Somali women's fears of obstetrical interventions in the United States. J Transcult Nurs. Jul. 2010;21(3):220-7. X-1. [pmid: 20519725].
754 Brown HS 3rd. Physician demand for leisure: implications for cesarean section rates. J Health Econ. Apr. 1996;15(2):233-42. X-1. [pmid: 10159111].
755 Brown HS 3rd. Lawsuit activity, defensive medicine, and small area variation: the case of Cesarean sections revisited. Health Econ Policy Law. Jul. 2007;2(Pt 3):285-96. X-1. [pmid: 18634651].
756 Brown L. Clinical audit. The tide has turned: audit of water birth. British Journal of Midwifery. 1998;6(4):236-243. X-1.
757 Brown TR, Ehrlich CE, Stehman FB, et al. A clinical evaluation of chlorhexidine gluconate spray as compared with iodophor scrub for preoperative skin preparation. Surg Gynecol Obstet. Apr. 1984;158(4):363-6. X-3, X-4e, X-5. [pmid: 6710300].
758 Brown ZA, Wald A, Morrow RA, et al. Effect of serologic status and cesarean delivery on transmission rates of herpes simplex virus from mother to infant. JAMA. Jan. 8. 2003;289(2):203-9. X-1. [pmid: 12517231].
759 Brownridge P, Frewin DB. A comparative study of techniques of postoperative analgesia following caesarean section and lower abdominal surgery. Anaesth Intensive Care. May. 1985;13(2):123-30. X-9. [pmid: 3893208].
760 Brozanski BS, Jones JG, Krohn MA, et al. Effect of a screening-based prevention policy on prevalence of early-onset group B streptococcal sepsis. Obstet Gynecol. Apr. 2000;95(4):496-501. X-1. [pmid: 10725479].
761 Brubaker K, Garite TJ. The lambda fetal heart rate pattern: an assessment of its significance in the intrapartum period. Obstet Gynecol. Dec. 1988;72(6):881-5. X-1. [pmid: 3186097].
762 Brucato A, Doria A, Frassi M, et al. Pregnancy outcome in 100 women with autoimmune diseases and anti-Ro/SSA antibodies: a prospective controlled study. Lupus. 2002;11(11):716-21. X-1. [pmid: 12475001].
763 Brucker MC. Clinical update. GENESIS. 1999;(2):2. X-2.
764 Brunetti P, Puxeddu A, Calabrese G, et al. Therapeutical application of artificial beta-cell in surgery and obstetrics. Horm Metab Res Suppl. 1979;(8):162-5. X-1, X-2. [pmid: 395074].
765 Brunner L, Hickey ME. Disease management: Lovelace Health Systems episodes of care--a case study. Best Pract Benchmarking Healthc. Nov-Dec. 1997;2(6):254-7. X-1, X-2. [pmid: 9543921].
766 Brunvand L, Shah SS, Bergstrom S, et al. Vitamin D deficiency in pregnancy is not associated with obstructed labor. A study among Pakistani women in Karachi. Acta Obstet Gynecol Scand. Mar. 1998;77(3):303-6. X-1. [pmid: 9539276].
767 Brusati V, Jozwik M, Teng C, et al. Fetal and maternal non-glucose carbohydrates and polyols concentrations in normal human pregnancies at term. Pediatr Res. Oct. 2005;58(4):700-4. X-1. [pmid: 16189196].
768 Brusse I, Duvekot J, Jongerling J, et al. Impaired maternal cognitive functioning after pregnancies complicated by severe preeclampsia: a pilot case-control study. Acta Obstet Gynecol Scand. 2008;87(4):408-12. X-1. [pmid: 18382865].
769 Bryant-Greenwood GD, Yamamoto SY. Control of peripartal collagenolysis in the human chorion-decidua. Am J Obstet Gynecol. Jan. 1995;172(1 Pt 1):63-70. X-1. [pmid: 7847562].
770 Bryanton J, Gagnon AJ, Johnston C, et al. Predictors of women's perceptions of the childbirth experience. J Obstet Gynecol Neonatal Nurs. Jan-Feb. 2008;37(1):24-34. X-1.
771 Bryson GL, Macneil R, Jeyaraj LM, et al. Small dose spinal bupivacaine for Cesarean delivery does not reduce hypotension but accelerates motor recovery. Can J Anaesth. Jul. 2007;54(7):531-7. X-9. [pmid: 17602038].
772 Bsat FA, Warsof S. Extraovular and intraovular uterine contraction monitoring. A comparison. J Reprod Med. Sep. 1992;37(9):813-6. X-4, X-4e, X-5. [pmid: 1453404].
773 Buccellato CA, Stika CS, Frederiksen MC. A randomized trial of misoprostol versus extra-amniotic sodium chloride infusion with oxytocin for induction of labor. Am J Obstet Gynecol. May. 2000;182(5):1039-44. X-4d. [pmid: 10819821].
774 Buchanan SL, Crowther CA, Levett KM, et al. Planned early birth versus expectant management for women with preterm prelabour rupture of membranes prior to 37 weeks' gestation for improving pregnancy outcome. Cochrane Database of Systematic Reviews. 2010;(3). X-1.
775 Buchmiller TL, Shaw KS, Chopourian HL, et al. Effect of transamniotic administration of epidermal growth factor on fetal rabbit small intestinal nutrient transport and disaccharidase development. J Pediatr Surg. Oct. 1993;28(10):1239-44. X-1. [pmid: 8263680].
776 Buckett WM, Chian RC, Holzer H, et al. Obstetric outcomes and congenital abnormalities after in vitro maturation, in vitro fertilization, and intracytoplasmic sperm injection. Obstet Gynecol. Oct. 2007;110(4):885-91. X-1. [pmid: 17906024].
777 Bucknell S, Sikorski K. Putting patient-controlled analgesia to the test. MCN Am J Matern Child Nurs. Jan-Feb. 1989;14(1):37-40. X-1, X-3, X-4e. [pmid: 2494407].
778 Buekens P, Curtis S, Alayon S. Demographic and Health Surveys: caesarean section rates in sub-Saharan Africa. BMJ. Jan. 18. 2003;326(7381):136. X-1, X-2. [pmid: 12531845].
779 Bugg GJ, Atwal GS, Maresh M. Grandmultiparae in a modern setting. BJOG. Mar. 2002;109(3):249-53. X-1. [pmid: 11950178].
780 Buggy DJ, Hall NA, Shah J, et al. Motor block during patient-controlled epidural analgesia with ropivacaine or ropivacaine/fentanyl after intrathecal bupivacaine for caesarean section. Br J Anaesth. Sep. 2000;85(3):468-70. X-9. [pmid: 11103193].
781 Buhimschi CS, Buhimschi IA, Malinow AM, et al. Uterine contractility in women whose fetus is delivered in the occipitoposterior position. Am J Obstet Gynecol. Mar. 2003;188(3):734-9. X-1. [pmid: 12634649].
782 Buhimschi CS, Buhimschi IA, Patel S, et al. Rupture of the uterine scar during term labour: contractility or biochemistry?. BJOG. Jan. 2005;112(1):38-42. X-1. [pmid: 15663395].
783 Buhimschi CS, Buhimschi IA, Yu C, et al. The effect of dystocia and previous cesarean uterine scar on the tensile properties of the lower uterine segment. Am J Obstet Gynecol. Mar. 2006;194(3):873-83. X-1. [pmid: 16522428].
784 Buhimschi CS, Buhimschi IA, Zhao G, et al. Biomechanical properties of the lower uterine segment above and below the reflection of the urinary bladder flap. Obstet Gynecol. Mar. 2007;109(3):691-700. X-9. [pmid: 17329522].
785 Buhimschi IA, Buhimschi CS, Pupkin M, et al. Beneficial impact of term labor: nonenzymatic antioxidant reserve in the human fetus. Am J Obstet Gynecol. Jul. 2003;189(1):181-8. X-1. [pmid: 12861160].
786 Bujold E. Evaluating professional society guidelines on vaginal birth after cesarean. Semin Perinatol. Oct. 2010;34(5):314-7. X-1. [pmid: 20869546].
787 Bujold E, Blackwell SC, Gauthier RJ. Cervical ripening with transcervical foley catheter and the risk of uterine rupture. Obstet Gynecol. Jan. 2004;103(1):18-23. X-1. [pmid: 14704239].
788 Bujold E, Gauthier RJ. Risk of uterine rupture associated with an interdelivery interval between 18 and 24 months. Obstet Gynecol. May. 2010;115(5):1003-6. X-1. [pmid: 20410775].
789 Bujold E, Goyet M, Marcoux S, et al. The role of uterine closure in the risk of uterine rupture. Obstet Gynecol. Jul. 2010;116(1):43-50. X-1. [pmid: 20567166].
790 Buka SL, Goldstein JM, Spartos E, et al. The retrospective measurement of prenatal and perinatal events: accuracy of maternal recall. Schizophr Res. Dec. 1. 2004;71(2-3):417-26. X-1. [pmid: 15474913].
791 Bukar M, Kwari DY, Moruppa JY, et al. Anaesthesia for caesarean delivery: choice of technique among antenatal attendees in North-eastern Nigeria. J Obstet Gynaecol. 2010;30(8):822-5. X-1, X-9. [pmid: 21126121].
792 Buley RJ, Downing W, Brock-Utne JG, et al. Right versus left lateral tilt for Caesarean section. Br J Anaesth. Oct. 1977;49(10):1009-15. X-1. [pmid: 921864].
793 Bulik CM, Sullivan PF, Fear JL, et al. Fertility and reproduction in women with anorexia nervosa: a controlled study. J Clin Psychiatry. Feb. 1999;60(2):130-5. quiz 135-7. X-1. [pmid: 10084645].
794 Bulkmans N, Lyrenas S, Hallberg G, et al. Umbilical cord blood sampling--a tool for delivery quality control?. Acta Obstet Gynecol Scand. May. 1997;76(5):419-22. X-1. [pmid: 9197443].
795 Bullarbo M, Norstrom A, Andersch B, et al. Isosorbide mononitrate induces increased cervical expression of cyclooxygenase-2, but not of cyclooxygenase-1, at term. Eur J Obstet Gynecol Reprod Biol. Feb. 2007;130(2):160-4. X-9. [pmid: 16675095].
796 Bungum TJ, Peaslee DL, Jackson AW, et al. Exercise during pregnancy and type of delivery in nulliparae. J Obstet Gynecol Neonatal Nurs. May-Jun. 2000;29(3):258-64. X-1.
797 Bunin GR, Buckley JD, Boesel CP, et al. Risk factors for astrocytic glioma and primitive neuroectodermal tumor of the brain in young children: a report from the Children's Cancer Group. Cancer Epidemiol Biomarkers Prev. Apr-May. 1994;3(3):197-204. X-1. [pmid: 8019366].
798 Bunting P, McConachie I. Ilioinguinal nerve blockade for analgesia after caesarean section. Br J Anaesth. Dec. 1988;61(6):773-5. X-1, X-9. [pmid: 3207549].
799 Burdan F. Formation of the knee joint after prenatal propyphenazone (isopropylantipyrine) administration. Cells Tissues Organs. 2002;171(2-3):145-51. X-1. [pmid: 12097837].
800 Burgess GE 3rd. Antacids for obstetric patients. Am J Obstet Gynecol. Nov. 15. 1975;123(6):577-9. X-1. [pmid: 1200044].
801 Burgio KL, Borello-France D, Richter HE, et al. Risk factors for fecal and urinary incontinence after childbirth: the childbirth and pelvic symptoms study. Am J Gastroenterol. Sep. 2007;102(9):1998-2004. X-1. [pmid: 17573795].
802 Burgos H, Hsi BL, Yeh CJ, et al. Plasminogen binding by human amniochorion. A possible factor in premature rupture of membranes. Am J Obstet Gynecol. Aug. 15. 1982;143(8):958-63. X-1. [pmid: 6808842].
803 Burke MS, Porreco RP, Day D, et al. Intrauterine resuscitation with tocolysis. An alternate month clinical trial. J Perinatol. Sep. 1989;9(3):296-300. X-1. [pmid: 2681580].
804 Burns CM, Rutherford MA, Boardman JP, et al. Patterns of cerebral injury and neurodevelopmental outcomes after symptomatic neonatal hypoglycemia. Pediatrics. Jul. 2008;122(1):65-74. X-1. [pmid: 18595988].
805 Burns E, Zobbi V, Panzeri D, et al. Aromatherapy in childbirth: a pilot randomised controlled trial. BJOG. Jul. 2007;114(7):838-44. X-4e, X-5. [pmid: 17506789].
806 Burns LR, Chilingerian JA, Wholey DR. The effect of physician practice organization on efficient utilization of hospital resources. Health Serv Res. Dec. 1994;29(5):583-603. X-1. [pmid: 8002351].
807 Burrows J. The parturient woman: can there be room for more than ‘one person with full and equal rights inside a single human skin’?. J Adv Nurs. Mar. 2001;33(5):689-95. X-1, X-2. [pmid: 11298206].
808 Burrows RF, Gan ET, Gallus AS, et al. A randomised double-blind placebo controlled trial of low molecular weight heparin as prophylaxis in preventing venous thrombolic events after caesarean section: a pilot study. BJOG. Aug. 2001;108(8):835-9. X-9. [pmid: 11510709].
809 Burrows WR, Gingo AJ Jr., Rose SM, et al. Safety and efficacy of early postoperative solid food consumption after cesarean section. J Reprod Med. Jun. 1995;40(6):463-7. X-9. [pmid: 7650662].
810 Burt RD, Vaughan TL, Daling JR. Evaluating the risks of cesarean section: low Apgar score in repeat C-section and vaginal deliveries. Am J Public Health. Oct. 1988;78(10):1312-4. X-1. [pmid: 3421386].
811 Buser D, Mora G, Arias F. A randomized comparison between misoprostol and dinoprostone for cervical ripening and labor induction in patients with unfavorable cervices. Obstet Gynecol. Apr. 1997;89(4):581-5. X-4d. [pmid: 9083316].
812 Bush DJ, Lyons G, MacDonald R. Diclofenac for analgesia after caesarean section. Anaesthesia. Dec. 1992;47(12):1075-7. X-9. [pmid: 1489037].
813 Bush MC, Patel S, Lapinski RH, et al. Perinatal outcomes in inflammatory bowel disease. J Matern Fetal Neonatal Med. Apr. 2004;15(4):237-41. X-1. [pmid: 15280131].
814 Busowski JD, Chez RA, Goldfain VM. The effect of a resident night team on cesarean delivery. Am J Perinatol. Apr. 1997;14(4):177-80. X-1. [pmid: 9259923].
815 Butler HM, Laver JC, Shulman A, et al. The use of phenanthroline metal chelates for the control of topical infections due to bacteria, fungi and protozoa. Med J Aust. Aug. 15. 1970;2(7):309-14. X-4e. [pmid: 4248550].
816 Butler J, Abrams B, Parker J, et al. Supportive nurse-midwife care is associated with a reduced incidence of cesarean section. Am J Obstet Gynecol. May. 1993;168(5):1407-13. X-1. [pmid: 8166781].
817 Butt KD, Bennett KA, Crane JM, et al. Randomized comparison of oral misoprostol and oxytocin for labor induction in term prelabor membrane rupture. Obstet Gynecol. Dec. 1999;94(6):994-9. X-4d. [pmid: 10576189].
818 Butt KD, Bennett KA, Crane JM, et al. Randomized comparison of oral misoprostol and oxytocin for labor induction in term prelabor membrane rupture. Obstet Gynecol. Dec. 1999;94(6):994-9. X-4d. [pmid: 10576189].
819 Buttino LT Jr., Garite TJ. Intracervical prostaglandin in postdate pregnancy. A randomized trial. J Reprod Med. Feb. 1990;35(2):155-8. X-4d, X-4e, X-5. [pmid: 2406438].
820 Butts S, Sammel M, Hummel A, et al. Risk factors and clinical features of recurrent ectopic pregnancy: a case control study. Fertil Steril. Dec. 2003;80(6):1340-4. X-1. [pmid: 14667866].
821 Butwick A, Carvalho B. The effect of colloid and crystalloid preloading on thromboelastography prior to Cesarean delivery. Can J Anaesth. Mar. 2007;54(3):190-5. X-9. [pmid: 17331930].
822 Butwick AJ, Coleman L, Cohen SE, et al. Minimum effective bolus dose of oxytocin during elective Caesarean delivery. Br J Anaesth. Mar. 2010;104(3):338-43. X-9. [pmid: 20150347].
823 Butwick AJ, Lipman SS, Carvalho B. Intraoperative forced air-warming during cesarean delivery under spinal anesthesia does not prevent maternal hypothermia. Anesth Analg. Nov. 2007;105(5):1413-9. table of contents. X-9. [pmid: 17959975].
824 Buyukbayrak EE, Kaymaz O, Kars B, et al. Caesarean delivery or vaginal birth: preference of Turkish pregnant women and influencing factors. J Obstet Gynaecol. Feb. 2010;30(2):155-8. X-1. [pmid: 20143975].
825 Bylsma-Howell M, Riggs KW, McMorland GH, et al. Placental transport of metoclopramide: assessment of maternal and neonatal effects. Can Anaesth Soc J. Sep. 1983;30(5):487-92. X-9. [pmid: 6354385].
826 Byrne JP, Crowther CA, Moss JR. A randomised controlled trial comparing birthing centre care with delivery suite care in Adelaide, Australia. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):268-74. X-5. [pmid: 11065032].
827 Cabero L, Cerqueira MJ, del Solar J, et al. Long-term hospitalization and beta-mimetic therapy in the treatment of intrauterine growth retardation of unknown etiology. J Perinat Med. 1988;16(5-6):453-8. X-4e, X-5. [pmid: 3071603].
828 Cade L, Ashley J. Towards optimal analgesia after caesarean section: comparison of epidural and intravenous patient-controlled opioid analgesia. Anaesth Intensive Care. Oct. 1993;21(5):696-9. X-9. [pmid: 8273900].
829 Cade L, Ashley J. Towards optimal analgesia after caesarean section: comparison of epidural and intravenous patient-controlled opioid analgesia. Anaesth Intensive Care. Aug. 1993;21(4):416-9. X-9. [pmid: 7726388].
830 Cade L, Ashley J, Ross AW. Comparison of epidural and intravenous opioid analgesia after elective caesarean section. Anaesth Intensive Care. Feb. 1992;20(1):41-5. X-9. [pmid: 1609940].
831 Cahill AG, Odibo AO, Allsworth JE, et al. Frequent epidural dosing as a marker for impending uterine rupture in patients who attempt vaginal birth after cesarean delivery. Am J Obstet Gynecol. Apr. 2010;202(4):355 e1-5. X-1. [pmid: 20350643].
832 Cahill AG, Stamilio DM, Odibo AO, et al. Racial disparity in the success and complications of vaginal birth after cesarean delivery. Obstet Gynecol. Mar. 2008;111(3):654-8. X-1. [pmid: 18310368].
833 Cahill AG, Stout MJ, Stamilio DM, et al. Risk factors for bladder injury in patients with a prior hysterotomy. Obstet Gynecol. Jul. 2008;112(1):116-20. X-1. [pmid: 18591316].
834 Cahill AG, Tuuli M, Odibo AO, et al. Vaginal birth after caesarean for women with three or more prior caesareans: assessing safety and success. BJOG. Mar. 2010;117(4):422-7. X-1. [pmid: 20374579].
835 Cahill DJ, Clark HS, Martin DH. Cervical ripening: the comparative effectiveness of Lamicel and prostaglandin E2 tablets. Ir J Med Sci. Apr. 1988;157(4):113-4. X-4d, X-5. [pmid: 3164309].
836 Cahill RJ, Tan S, Dougan G, et al. Universal DNA primers amplify bacterial DNA from human fetal membranes and link Fusobacterium nucleatum with prolonged preterm membrane rupture. Mol Hum Reprod. Oct. 2005;11(10):761-6. X-1. [pmid: 16254004].
837 Calder AA, Bonnar J, Sheppard B, et al. Letter: Prostaglandins and pre-eclampsia. Lancet. Jul. 6. 1974;2(7871):49. X-1, X-4e. [pmid: 4134436].
838 Calder AA, Embrey MP, Tait T. Ripening of the cervix with extra-amniotic prostaglandin E2 in viscous gel before induction of labour. Br J Obstet Gynaecol. Apr. 1977;84(4):264-8. X-1, X-4d. [pmid: 857864].
839 Calder AA, Ounsted MK, Moar VA, et al. Increased bilirubin levels in neonates after induction of labour by intravenous prostaglandin E2 or oxytocin. Lancet. Dec. 7. 1974;2(7893):1339-42. X-1. [pmid: 4143308].
840 Calhoun BC, Edgeworth D, Brehm W. External cephalic version at a military teaching hospital: predictors of success. Aust N Z J Obstet Gynaecol. Aug. 1995;35(3):277-9. X-1. [pmid: 8546642].
841 Caliskan E, Bodur H, Ozeren S, et al. Misoprostol 50 microg sublingually versus vaginally for labor induction at term: a randomized study. Gynecol Obstet Invest. 2005;59(3):155-61. X-4d. [pmid: 15640607].
842 Caliskan E, Cakiroglu Y, Corakci A, et al. Reduction in caesarean delivery with fetal heart rate monitoring and intermittent pulse oximetry after induction of labour with misoprostol. J Matern Fetal Neonatal Med. May. 2009;22(5):445-51. X-4e. [pmid: 19530004].
843 Caliskan E, Ozdamar D, Doger E, et al. Prospective case control comparison of fetal intrapartum oxygen saturations during epidural analgesia. Int J Obstet Anesth. Jan. 2010;19(1):77-81. X-1. [pmid: 19945845].
844 Callahan C, Chescheir N, Steiner BD. Safety and efficacy of attempted vaginal birth after cesarean beyond the estimated date of delivery. J Reprod Med. Jul. 1999;44(7):606-10. X-1. [pmid: 10442323].
845 Camann W, Trunfio GV, Kluger R, et al. Automated ST-segment analysis during cesarean delivery: effects of ECG filtering modality. J Clin Anesth. Nov. 1996;8(7):564-7. X-1. [pmid: 8910178].
846 Camann WR, Hartigan PM, Gilbertson LI, et al. Chloroprocaine antagonism of epidural opioid analgesia: a receptor-specific phenomenon?. Anesthesiology. Nov. 1990;73(5):860-3. X-9. [pmid: 2173443].
847 Camann WR, Hurley RH, Gilbertson LI, et al. Epidural nalbuphine for analgesia following caesarean delivery: dose-response and effect of local anaesthetic choice. Can J Anaesth. Sep. 1991;38(6):728-32. X-9. [pmid: 1914055].
848 Camann WR, Loferski BL, Fanciullo GJ, et al. Does epidural administration of butorphanol offer any clinical advantage over the intravenous route? A double-blind, placebo-controlled trial. Anesthesiology. Feb. 1992;76(2):216-20. X-9. [pmid: 1736698].
849 Cammu H, Van Eeckhout E. A randomised controlled trial of early versus delayed use of amniotomy and oxytocin infusion in nulliparous labour. Br J Obstet Gynaecol. Apr. 1996;103(4):313-8. X-5. [pmid: 8605126].
850 Cammu H, Verlaenen H, Perde MP. Premature rupture of membranes at term in nulliparous women: a hazard?. Obstet Gynecol. Oct. 1990;76(4):671-4. X-1. [pmid: 2216201].
851 Camorcia M, Capogna G. Sensory assessment of epidural block for Caesarean section: a systematic comparison of pinprick, cold and touch sensation. Eur J Anaesthesiol. Jul. 2006;23(7):611-7. X-1. [pmid: 16507187].
852 Camorcia M, Capogna G, Columb MO. Estimation of the minimum motor blocking potency ratio for intrathecal bupivacaine and lidocaine. Int J Obstet Anesth. Jul. 2008;17(3):223-7. X-9. [pmid: 18501583].
853 Camorcia M, Capogna G, Lyons G, et al. Epidural test dose with levobupivacaine and ropivacaine: determination of ED(50) motor block after spinal administration. Br J Anaesth. Jun. 2004;92(6):850-3. X-9. [pmid: 15096445].
854 Camorcia M, Capogna G, Lyons G, et al. The relative motor blocking potencies of intrathecal ropivacaine: effects of concentration. Anesth Analg. Jun. 2004;98(6):1779-82. table of contents. X-9. [pmid: 15155346].
855 Campbell DC, Banner R, Crone LA, et al. Addition of epinephrine to intrathecal bupivacaine and sufentanil for ambulatory labor analgesia. Anesthesiology. Mar. 1997;86(3):525-31. X-4e. [pmid: 9066317].
856 Campbell DC, Douglas MJ, Pavy TJ, et al. Comparison of the 25-gauge Whitacre with the 24-gauge Sprotte spinal needle for elective caesarean section: cost implications. Can J Anaesth. Dec. 1993;40(12):1131-5. X-9. [pmid: 8281588].
857 Campero L, Garcia C, Diaz C, et al. “Alone, I wouldn't have known what to do”: a qualitative study on social support during labor and delivery in Mexico. Soc Sci Med. Aug. 1998;47(3):395-403. X-1. [pmid: 9681909].
858 Campero L, Hernandez B, Osborne J, et al. Support from a prenatal instructor during childbirth is associated with reduced rates of caesarean section in a Mexican study. Midwifery. Dec. 2004;20(4):312-23. X-1. [pmid: 15571880].
859 Canales ES, Garrido JT, Zarate A, et al. Effect of ergonovine on prolactin secretion and milk let-down. Obstet Gynecol. Aug. 1976;48(2):228-9. X-1. [pmid: 940657].
860 Canobbio MM, Morris CD, Graham TP, et al. Pregnancy outcomes after atrial repair for transposition of the great arteries. Am J Cardiol. Sep. 1. 2006;98(5):668-72. X-1. [pmid: 16923459].
861 Capik LK. Health beliefs of childbearing women: the choice of epidurals for pain management. Journal of Perinatal Education. 1998;7(3):7-17. X-1.
862 Capogna G, Celleno D. IV clonidine for post-extradural shivering in parturients: a preliminary study. Br J Anaesth. Aug. 1993;71(2):294-5. X. [pmid: 8123410].
863 Capogna G, Celleno D, Costantino P, et al. Alkalinization improves the quality of lidocaine-fentanyl epidural anaesthesia for caesarean section. Can J Anaesth. May. 1993;40(5 Pt 1):425-30. X-9. [pmid: 8390329].
864 Capogna G, Celleno D, Tomassetti M. Maternal analgesia and neonatal effects of epidural sufentanil for cesarean section. Reg Anesth. Nov-Dec. 1989;14(6):282-7. X-9. [pmid: 2577253].
865 Capogna G, Celleno D, Varrassi G, et al. Epidural mepivacaine for cesarean section: effects of a pH-adjusted solution. J Clin Anesth. May-Jun. 1991;3(3):211-4. discussion 214-5. X-9. [pmid: 1652265].
866 Capogna G, Celleno D, Zangrillo A, et al. Addition of clonidine to epidural morphine enhances postoperative analgesia after cesarean delivery. Reg Anesth. Jan-Feb. 1995;20(1):57-61. X-9. [pmid: 7727330].
867 Carayol M, Blondel B, Zeitlin J, et al. Changes in the rates of caesarean delivery before labour for breech presentation at term in France: 1972-2003. Eur J Obstet Gynecol Reprod Biol. May. 2007;132(1):20-6. X-1. [pmid: 16797822].
868 Carbonne B, Langer B, Goffinet F, et al. Multicenter study on the clinical value of fetal pulse oximetry. II. Compared predictive values of pulse oximetry and fetal blood analysis. The French Study Group on Fetal Pulse Oximetry. Am J Obstet Gynecol. Sep. 1997;177(3):593-8. X-1. [pmid: 9322629].
869 Cardoso MM, Carvalho JC, Amaro AR, et al. Small doses of intrathecal morphine combined with systemic diclofenac for postoperative pain control after cesarean delivery. Anesth Analg. Mar. 1998;86(3):538-41. X-9. [pmid: 9495409].
870 Cardozo L, Fysh J, Pearce JM. Prolonged pregnancy: the management debate. Br Med J (Clin Res Ed). Oct. 25. 1986;293(6554):1059-63. X-4e.
871 Cardozo L, Pearce JM. Oxytocin in active-phase abnormalities of labor: a randomized study. Obstet Gynecol. Feb. 1990;75(2):152-7. X-5. [pmid: 2405314].
872 Cardy AH, Barker S, Chesney D, et al. Pedigree analysis and epidemiological features of idiopathic congenital talipes equinovarus in the United Kingdom: a case-control study. BMC Musculoskelet Disord. 2007;8:62. X-1. [pmid: 17610748].
873 Carey TS, Weis K, Homer C. Prepaid versus traditional Medicaid plans: lack of effect on pregnancy outcomes and prenatal care. Health Serv Res. Jun. 1991;26(2):165-81. X-1. [pmid: 2061055].
874 Carlan SJ, Bouldin S, Blust D, et al. Safety and efficacy of misoprostol orally and vaginally: a randomized trial. Obstet Gynecol. Jul. 2001;98(1):107-12. X-4d. [pmid: 11430966].
875 Carlan SJ, Bouldin S, O'Brien WF. Extemporaneous preparation of misoprostol gel for cervical ripening: a randomized trial. Obstet Gynecol. Dec. 1997;90(6):911-5. X-4d. [pmid: 9397101].
876 Carlan SJ, Danna P, Durkee D, et al. Randomized study of pre-induction cervical ripening with sequential use of intravaginal prostaglandin E2 gel. Obstet Gynecol. Apr. 1995;85(4):608-13. X-4d. [pmid: 7898842].
877 Carlan SJ, O'Brien WF, Logan S. Serial intravaginal prostaglandin E2 gel cervical ripening in preterm pregnancies. Prostaglandins. Sep. 1996;52(3):237-46. X-1. [pmid: 8908623].
878 Carley ME, Turner RJ, Scott DE, et al. Obstetric history in women with surgically corrected adult urinary incontinence or pelvic organ prolapse. J Am Assoc Gynecol Laparosc. Feb. 1999;6(1):85-9. X-1. [pmid: 9971858].
879 Carlock LL, Cowan LA, Oneda S, et al. A comparison of effects on reproduction and neonatal development in cynomolgus monkeys given human soluble IL-4R and mice given murine soluble IL-4R. Regul Toxicol Pharmacol. Apr. 2009;53(3):226-34. X-1. [pmid: 19217923].
880 Carlomagno G, Candussi G, Zavino S, et al. Postmaturity: how far is it a clinical entity in its own right?. Clin Exp Obstet Gynecol. 1996;23(1):41-7. X-1. [pmid: 8653934].
881 Carlson B. Changing medical evidence brings shift in C-section stance. Manag Care. Jan. 2003;12(1):32-3. X-1, X-2. [pmid: 12575508].
882 Carlson C, Duff P. Antibiotic prophylaxis for cesarean delivery: is an extended-spectrum agent necessary?. Obstet Gynecol. Sep. 1990;76(3 Pt 1):343-6. X-9. [pmid: 2199866].
883 Carlsson C, Nybell-Lindahl G, Ingemarsson I. Extradural block in patients who have previously undergone caesarean section. Br J Anaesth. Aug. 1980;52(8):827-30. X-1, X-4b. [pmid: 7426260].
884 Carlsson Wallin M, Ekstrom P, Marsal K, et al. Apgar score and perinatal death after one previous caesarean delivery. BJOG. Aug. 2010;117(9):1088-97. X-1. [pmid: 20497412].
885 Carmichael FJ, Rolbin SH, Hew EM. Epidural morphine for analgesia after caesarean section. Can Anaesth Soc J. Jul. 1982;29(4):359-63. X-9. [pmid: 7104806].
886 Caron A, Neuhauser D. The effect of public accountability on hospital performance: trends in rates for cesarean sections and vaginal births after cesarean section in Cleveland, Ohio. Qual Manag Health Care. Winter. 1999;7(2):1-10. X-1. [pmid: 10346457].
887 Carpenter MW, Corrado F, Sung J. Lethal fetal renal anomalies and obstetric outcome. Eur J Obstet Gynecol Reprod Biol. Apr. 2000;89(2):149-52. X-1. [pmid: 10725573].
888 Carpenter MW, Soule D, Yates WT, et al. Practice environment is associated with obstetric decision making regarding abnormal labor. Obstet Gynecol. Oct. 1987;70(4):657-62. X-1. [pmid: 3627632].
889 Carr CA, Burkhardt P, Avery M. Vaginal birth after cesarean birth: a national survey of U.S. midwifery practice. J Midwifery Womens Health. Sep-Oct. 2002;47(5):347-52. X-1. [pmid: 12361346].
890 Carr DB, Larson AM, Schmucker BC, et al. Maternal hemodynamics and pregnancy outcome in women with prior orthotopic liver transplantation. Liver Transpl. Mar. 2000;6(2):213-21. X-1. [pmid: 10719023].
891 Carr MH, Towers CV, Eastenson AR, et al. Prolonged bedrest during pregnancy: does the risk of deep vein thrombosis warrant the use of routine heparin prophylaxis?. J Matern Fetal Med. Sep-Oct. 1997;6(5):264-7. X-1. [pmid: 9360183].
892 Carta G, Iovenitti P, Falciglia K. Recurrent miscarriage associated with antiphospholipid antibodies: prophylactic treatment with low-dose aspirin and fish oil derivates. Clin Exp Obstet Gynecol. 2005;32(1):49-51. X-1, X-3, X-4e, X-5. [pmid: 15864938].
893 Carta Q, Meriggi E, Trossarelli GF, et al. Continuous subcutaneous insulin infusion versus intensive conventional insulin therapy in type I and type II diabetic pregnancy. Diabete Metab. Jun. 1986;12(3):121-9. X-1. [pmid: 3525266].
894 Cartwright DP, Dann WL, Hutchinson A. Placental transfer of alfentanil at caesarean section. Eur J Anaesthesiol. Mar. 1989;6(2):103-9. X-9. [pmid: 2498089].
895 Caruana R, Niculescu RS, Rao RB, et al. Machine learning for sub-population assessment: evaluating the C-section rate of different physician practices. Proc AMIA Symp. 2002:126-30. X-1. [pmid: 12463800].
896 Caruana R, Niculescu RS, Rao RB, et al. Evaluating the C-section rate of different physician practices: using machine learning to model standard practice. AMIA Annu Symp Proc. 2003:135-9. X-1. [pmid: 14728149].
897 Caruso A, De Santis L, Carducci B, et al. The use of prostaglandin E2 for cervical ripening in patients requiring induction of labour. J Int Med Res. May-Jun. 1997;25(3):159-66. X-1. [pmid: 9178148].
898 Carvalho B, Chu L, Fuller A, et al. Valdecoxib for postoperative pain management after cesarean delivery: a randomized, double-blind, placebo-controlled study. Anesth Analg. Sep. 2006;103(3):664-70. X-9. [pmid: 16931678].
899 Carvalho B, Clark DJ, Angst MS. Local and systemic release of cytokines, nerve growth factor, prostaglandin E2, and substance P in incisional wounds and serum following cesarean delivery. J Pain. Jul. 2008;9(7):650-7. X-1. [pmid: 18394968].
900 Carvalho B, Clark DJ, Yeomans DC, et al. Continuous subcutaneous instillation of bupivacaine compared to saline reduces interleukin 10 and increases substance P in surgical wounds after cesarean delivery. Anesth Analg. Dec. 2010;111(6):1452-9. X-9. [pmid: 20861424].
901 Carvalho B, Cohen SE, Giarrusso K, et al. “Ultra-light” patient-controlled epidural analgesia during labor: effects of varying regimens on analgesia and physician workload. Int J Obstet Anesth. Jul. 2005;14(3):223-9. X-5. [pmid: 15935646].
902 Carvalho B, Cohen SE, Lipman SS, et al. Patient preferences for anesthesia outcomes associated with cesarean delivery. Anesth Analg. Oct. 2005;101(4):1182-7. table of contents. X-1. [pmid: 16192541].
903 Carvalho B, Collins J, Drover DR, et al. ED(50) and ED(95) of intrathecal bupivacaine in morbidly obese patients undergoing cesarean delivery. Anesthesiology. Mar. 2011;114(3):529-35. X-9. [pmid: 21307769].
904 Carvalho B, Durbin M, Drover DR, et al. The ED50 and ED95 of intrathecal isobaric bupivacaine with opioids for cesarean delivery. Anesthesiology. Sep. 2005;103(3):606-12. X-9. [pmid: 16129987].
905 Carvalho B, Mercier FJ, Riley ET, et al. Hetastarch co-loading is as effective as preloading for the prevention of hypotension following spinal anesthesia for cesarean delivery. Int J Obstet Anesth. Apr. 2009;18(2):150-5. X-9. [pmid: 19223168].
906 Carvalho B, Riley E, Cohen SE, et al. Single-dose, sustained-release epidural morphine in the management of postoperative pain after elective cesarean delivery: results of a multicenter randomized controlled study. Anesth Analg. Apr. 2005;100(4):1150-8. X-9. [pmid: 15781537].
907 Carvalho B, Roland LM, Chu LF, et al. Single-dose, extended-release epidural morphine (DepoDur) compared to conventional epidural morphine for post-cesarean pain. Anesth Analg. Jul. 2007;105(1):176-83. X-9. [pmid: 17578973].
908 Carvalho B, Saxena A, Butwick A, et al. Vaginal twin delivery: a survey and review of location, anesthesia coverage and interventions. Int J Obstet Anesth. Jul. 2008;17(3):212-6. X-1. [pmid: 17881218].
909 Carvalho JC, Balki M, Kingdom J, et al. Oxytocin requirements at elective cesarean delivery: a dose-finding study. Obstet Gynecol. Nov. 2004;104(5 Pt 1):1005-10. X-9. [pmid: 15516392].
910 Cary AJ. Intervention rates in spontaneous term labour in low risk nulliparous women. Aust N Z J Obstet Gynaecol. Feb. 1990;30(1):46-51. X-1. [pmid: 2346451].
911 Casanegra P, Aviles G, Maturana G, et al. Cardiovascular management of pregnant women with a heart valve prosthesis. Am J Cardiol. Nov. 1975;36(6):802-6. X-1. [pmid: 1199937].
912 Casanova BF, Sammel MD, Macones GA. Cocaine use during pregnancy and the failure of vaginal birth after cesarean. J Reprod Med. Sep. 2005;50(9):663-8. X-1. [pmid: 16363754].
913 Casele HL, Grobman WA. Management of thromboprophylaxis during pregnancy among specialists in maternal-fetal medicine. J Reprod Med. Dec. 2007;52(12):1085-9. X-1. [pmid: 18210898].
914 Casey BM, Lucas MJ, McIntire DD, et al. Pregnancy outcomes in women with gestational diabetes compared with the general obstetric population. Obstet Gynecol. Dec. 1997;90(6):869-73. X-1. [pmid: 9397092].
915 Casey C, Kehoe J, Mylotte MJ. Vaginal prostaglandins for the ripe cervix. Int J Gynaecol Obstet. Jan. 1994;44(1):21-6. X-4d. [pmid: 7907054].
916 Casey WF, Smith CE, Katz JM, et al. Intravenous meperidine for control of shivering during caesarean section under epidural anaesthesia. Can J Anaesth. Mar. 1988;35(2):128-33. X-9. [pmid: 3356050].
917 Caspi B, Ben-Arie A, Appelman Z, et al. Aspiration of simple pelvic cysts during pregnancy. Gynecol Obstet Invest. 2000;49(2):102-5. X-1. [pmid: 10671816].
918 Caspi E, Lifshitz Y. Delivery at 40 years of age and over. Isr J Med Sci. May. 1979;15(5):418-21. X-1. [pmid: 447509].
919 Caspi E, Schreyer P, Weinraub Z, et al. Dexamethasone for prevention of respiratory distress syndrome: multiple perinatal factors. Obstet Gynecol. Jan. 1981;57(1):41-7. X-1, X-4e. [pmid: 6893857].
920 Caspi E, Solomon F, Langer R, et al. Isolation of Mycoplasma from the placenta after cesarean section. Obstet Gynecol. Dec. 1976;48(6):682-4. X-1. [pmid: 995338].
921 Cassell KA, O'Connell CM, Baskett TF. The origins and outcomes of triplet and quadruplet pregnancies in Nova Scotia: 1980 to 2001. Am J Perinatol. Nov. 2004;21(8):439-45. X-1. [pmid: 15580539].
922 Castaman G, Federici AB, Bernardi M, et al. Factor VIII and von Willebrand factor changes after desmopressin and during pregnancy in type 2M von Willebrand disease Vicenza: a prospective study comparing patients with single (R1205H) and double (R1205H-M740I) defect. J Thromb Haemost. Feb. 2006;4(2):357-60. X-1. [pmid: 16420565].
923 Catalano PM, Nizielski SE, Shao J, et al. Downregulated IRS-1 and PPARgamma in obese women with gestational diabetes: relationship to FFA during pregnancy. Am J Physiol Endocrinol Metab. Mar. 2002;282(3):E522-33. X-1. [pmid: 11832353].
924 Catalinotto E. Medically unnecessary Cesarean section. If it's unnecessary, why is it still performed?. Am J Nurs. Jul. 2007;107(7):13. X-1, X-2. [pmid: 17589209].
925 Catanzarite VA. Prophylactic intramyometrial carboprost tromethamine does not substantially reduce blood loss relative to intramyometrial oxytocin at routine cesarean section. Am J Perinatol. Jan. 1990;7(1):39-42. X-9. [pmid: 2403792].
926 Catanzarite VA, Piacquadio KM, Stanco LM, et al. Preventing transmission of AIDS and hepatitis to obstetric-care providers. Contemporary OB/GYN. 1999;44(8):39. X-1, X-2.
927 Catlin AJ. When pregnant women and their physicians disagree on the need for cesarean section: no simple solution. Adv Pract Nurs Q. Fall. 1998;4(2):23-9. X-1, X-2. [pmid: 9874946].
928 Caughey AB, Shipp TD, Repke JT, et al. Trial of labor after cesarean delivery: the effect of previous vaginal delivery. Am J Obstet Gynecol. Oct. 1998;179(4):938-41. X-1. [pmid: 9790374].
929 Caughey AB, Shipp TD, Repke JT, et al. Rate of uterine rupture during a trial of labor in women with one or two prior cesarean deliveries. Am J Obstet Gynecol. Oct. 1999;181(4):872-6. X-1. [pmid: 10521745].
930 Caughey AB, Urato AC, Lee KA, et al. Time of delivery and neonatal morbidity and mortality. Am J Obstet Gynecol. Nov. 2008;199(5):496 e1-5. X-1. [pmid: 18501323].
931 Caukwell S, Joels LA, Kyle PM, et al. Women's attitudes towards management of breech presentation at term. J Obstet Gynaecol. Sep. 2002;22(5):486-8. X-1. [pmid: 12521413].
932 Cebekulu L, Buchmann EJ. Complications associated with cesarean section in the second stage of labor. Int J Gynaecol Obstet. Nov. 2006;95(2):110-4. X-1. [pmid: 16934268].
933 Cebesoy FB, Kutlar I, Dikensoy E, et al. Morgagni hydatids: a new factor in infertility?. Arch Gynecol Obstet. Jun. 2010;281(6):1015-7. X-1. [pmid: 19774388].
934 Cecatti JG, Tedesco RP, Pires HM, et al. Effectiveness and safety of a new vaginal misoprostol product specifically labeled for cervical ripening and labor induction. Acta Obstet Gynecol Scand. 2006;85(6):706-11. X-4d. [pmid: 16752263].
935 Cederblad G, Niklasson A, Rydgren B, et al. Carnitine in maternal and neonatal plasma. Acta Paediatr Scand. Jul. 1985;74(4):500-4. X-1. [pmid: 4024920].
936 Celik C, Acar A, Cicek N, et al. Can myomectomy be performed during pregnancy?. Gynecol Obstet Invest. 2002;53(2):79-83. X-1. [pmid: 11961378].
937 Celik C, Gezginc K, Altintepe L, et al. Results of the pregnancies with HELLP syndrome. Ren Fail. Jul. 2003;25(4):613-8. X-1. [pmid: 12911166].
938 Celik O, Hascalik S, Ozerol E, et al. Cerebrospinal fluid leptin levels in preeclampsia: relation to maternal serum leptin levels. Acta Obstet Gynecol Scand. Jun. 2004;83(6):519-23. X-1. [pmid: 15144331].
939 Celik O, Hascalik S, Turkoz Y, et al. Cerebrospinal fluid nitric oxide level changes in preeclampsia. Eur J Obstet Gynecol Reprod Biol. Dec. 10. 2003;111(2):141-5. X-1. [pmid: 14597241].
940 Celleno D, Capogna G. Spinal buprenorphine for postoperative analgesia after caesarean section. Acta Anaesthesiol Scand. Apr. 1989;33(3):236-8. X-9. [pmid: 2728828].
941 Celleno D, Capogna G, Emanuelli M, et al. Which induction drug for cesarean section? A comparison of thiopental sodium, propofol, and midazolam. J Clin Anesth. Jul-Aug. 1993;5(4):284-8. X-9. [pmid: 8373604].
942 Celleno D, Capogna G, Sebastiani M, et al. Epidural analgesia during and after cesarean delivery. Comparison of five opioids. Reg Anesth. Mar-Apr. 1991;16(2):79-83. X-9. [pmid: 1675119].
943 Celleno D, Capogna G, Tomassetti M, et al. Neurobehavioural effects of propofol on the neonate following elective caesarean section. Br J Anaesth. Jun. 1989;62(6):649-54. X-9. [pmid: 2787664].
944 Cepeda EE, Lee MI, Mehdizadeh B. Decreased incidence of intraventricular hemorrhage in infants of opiate dependent mothers. Acta Paediatr Scand. Jan. 1987;76(1):16-8. X-1. [pmid: 3564994].
945 Cepicky P, Stembera Z, Zeman J, et al. When is it possible to meet the wish of a woman to terminate her labour by caesarean section?. Eur J Obstet Gynecol Reprod Biol. Jan. 30. 1991;38(2):109-12. X-1. [pmid: 1995378].
946 Cernadas M, Smulian JC, Giannina G, et al. Effects of placental delivery method and intraoperative glove changing on postcesarean febrile morbidity. J Matern Fetal Med. Mar-Apr. 1998;7(2):100-4. X-9. [pmid: 9584823].
947 Ceronio CC, Dorfling CS, Nolte AG. The experiences of parents where pregnancy ended in an unplanned caesarean section. Curationis. Dec. 1995;18(4):48-51. X-1. [pmid: 8697538].
948 Cerrato PL. New federal guidelines on group B strep. Contemporary OB/GYN. 2002;47(12):107. X-1, X-2.
949 Cesar JA, Matijasevich A, Santos IS, et al. The use of maternal and child health services in three population-based cohorts in Southern Brazil, 1982-2004. Cad Saude Publica. Suppl 3. 2008;24:S427-36. X-1. [pmid: 18797718].
950 Cesario SK. Re-evaluation of Friedman's labor graph phase II: determining the “normal” length of labor of women receiving epidural anesthesia. Southern Online Journal of Nursing Research. 2008;8(2):1p. X-1.
951 Cesur M, Alici HA, Erdem AF, et al. Spinal anesthesia with sequential administration of plain and hyperbaric bupivacaine provides satisfactory analgesia with hemodynamic stability in cesarean section. Int J Obstet Anesth. Jul. 2008;17(3):217-22. X-9. [pmid: 18499435].
952 Cesur M, Alici HA, Erdem AF, et al. Decreased incidence of headache after unintentional dural puncture in patients with cesarean delivery administered with postoperative epidural analgesia. J Anesth. 2009;23(1):31-5. X-1. [pmid: 19234819].
953 Cetin A, Cetin M. Superficial wound disruption after cesarean delivery: effect of the depth and closure of subcutaneous tissue. Int J Gynaecol Obstet. Apr. 1997;57(1):17-21. X-1. [pmid: 9175664].
954 Cetin I, Hirst K, Corbetta C, et al. Plasma and erythrocyte amino acids in mother and fetus. Biol Neonate. 1991;60(2):83-91. X-1. [pmid: 1932390].
955 Cha LYS, Lau TK, Chiu PY, et al. Levels of cord blood thyroid stimulating hormone after external cephalic version. BJOG. Oct. 2001;108(10):1076-80. X-1. [pmid: 11702840].
956 Chabrier S, Saliba E, Nguyen The Tich S, et al. Obstetrical and neonatal characteristics vary with birthweight in a cohort of 100 term newborns with symptomatic arterial ischemic stroke. Eur J Paediatr Neurol. May. 2010;14(3):206-13. X-1. [pmid: 19541515].
957 Chaillet N, Dube E, Dugas M, et al. Identifying barriers and facilitators towards implementing guidelines to reduce caesarean section rates in Quebec. Bull World Health Organ. Oct. 2007;85(10):791-7. X-1. [pmid: 18038061].
958 Chalk PA. Low dosage buccal oxytocin--a double blind trial in patients with a long induction labour interval. J Obstet Gynaecol Br Commonw. May. 1969;76(5):394-9. X-1. [pmid: 4889951].
959 Chalmers B, Kaczorowski J, Darling E, et al. Cesarean and vaginal birth in canadian women: a comparison of experiences. Birth. Mar. 2010;37(1):44-9. X-1. [pmid: 20402721].
960 Chalmers B, Kaczorowski J, Levitt C, et al. Use of routine interventions in vaginal labor and birth: findings from the Maternity Experiences Survey. Birth. Mar. 2009;36(1):13-25. X-1. [pmid: 19278379].
961 Chalmers B, Meyer D. What women say about their birth experiences: a cross-cultural study. J Psychosom Obstet Gynaecol. Dec. 1994;15(4):211-8. X-1. [pmid: 7881507].
962 Chalmers I, Zlosnik JE, Johns KA, et al. Obstetric practice and outcome of pregnancy in Cardiff residents 1965-73. Br Med J. Mar. 27. 1976;1(6012):735-8. X-1. [pmid: 944066].
963 Chalupczak P, Kolasinska-Kloch W, Jach R, et al. Pregnancy in patients with heart disease. Clin Exp Obstet Gynecol. 2004;31(4):271-3. X-1. [pmid: 15672964].
964 Cham M, Sundby J, Vangen S. Fetal outcome in severe maternal morbidity: too many stillbirths. Acta Obstet Gynecol Scand. 2009;88(3):343-9. X-1. [pmid: 19172420].
965 Chama CM, Morrupa JY. The safety of elective caesarean section for the prevention of mother-to-child transmission of HIV-1. J Obstet Gynaecol. Feb. 2008;28(2):194-7. X-1. [pmid: 18393018].
966 Chamberlain A, White S, Bawdon R, et al. Pharmacokinetics of ampicillin and sulbactam in pregnancy. Am J Obstet Gynecol. Feb. 1993;168(2):667-73. X-9. [pmid: 8438948].
967 Chamberlain M, Karaminia A, Wilton D. Factors affecting pregnant women's participation in a multi-centre randomised controlled trial of fetal occipito-posterior position. Birth Issues. 2003;12(3/4):77-82. X-1.
968 Chambers WA, Mowbray A, Wilson J. Extradural morphine for the relief of pain following caesarean section. Br J Anaesth. Dec. 1983;55(12):1201-3. X-9. [pmid: 6652010].
969 Chambliss LR, Daly C, Medearis AL, et al. The role of selection bias in comparing cesarean birth rates between physician and midwifery management. Obstet Gynecol. Aug. 1992;80(2):161-5. X-1. [pmid: 1635724].
970 Chamchad D, Arkoosh VA, Horrow JC, et al. Using heart rate variability to stratify risk of obstetric patients undergoing spinal anesthesia. Anesth Analg. Dec. 2004;99(6):1818-21. table of contents. X-1. [pmid: 15562079].
971 Chammas MF, Nguyen TM, Vasavada RA, et al. Sequential use of Prepidil and extra-amniotic saline infusion for the induction of labor in nulliparous women with very low Bishop scores. J Matern Fetal Med. Jun. 2001;10(3):193-6. X-1. [pmid: 11444789].
972 Chan A, McCaul KA, Cundy PJ, et al. Perinatal risk factors for developmental dysplasia of the hip. Arch Dis Child Fetal Neonatal Ed. Mar. 1997;76(2):F94-100. X-1. [pmid: 9135287].
973 Chan A, Roder D, Macharper T. Obstetric profiles of immigrant women from non-English speaking countries in South Australia, 1981-1983. Aust N Z J Obstet Gynaecol. May. 1988;28(2):90-5. X-1. [pmid: 3228416].
974 Chan AC, Leung AK, Chin RK, et al. Single dose prophylactic antibiotics in caesarean sections. Aust N Z J Obstet Gynaecol. May. 1989;29(2):107-9. X-1, X-9. [pmid: 2803121].
975 Chan AM, Ng KF, Tong EW, et al. Control of shivering under regional anesthesia in obstetric patients with tramadol. Can J Anaesth. Mar. 1999;46(3):253-8. X-9. [pmid: 10210050].
976 Chan CC, To WW. Antepartum hemorrhage of unknown origin--what is its clinical significance?. Acta Obstet Gynecol Scand. Mar. 1999;78(3):186-90. X-1. [pmid: 10078578].
977 Chan KK, Chan BC, Lam KF, et al. Iron supplement in pregnancy and development of gestational diabetes--a randomised placebo-controlled trial. BJOG. May. 2009;116(6):789-97. discussion 797-8. X-4e, X-5. [pmid: 19432567].
978 Chan LY, Leung TY, Fok WY, et al. High incidence of obstetric interventions after successful external cephalic version. BJOG. Jun. 2002;109(6):627-31. X-1. [pmid: 12118639].
979 Chan VW, Morley-Forster PK, Vosu HA. Temperature changes and shivering after epidural anesthesia for cesarean section. Reg Anesth. Jan-Feb. 1989;14(1):48-52. X-9. [pmid: 2486587].
980 Chan WS, Irwin MG, Tong WN, et al. Prevention of hypotension during spinal anaesthesia for caesarean section: ephedrine infusion versus fluid preload. Anaesthesia. Sep. 1997;52(9):908-13. X-9. [pmid: 9349079].
981 Chan YK, Ng KP. A survey of the current practice of obstetric anaesthesia and analgesia in Malaysia [correction of Malaysis]. J Obstet Gynaecol Res. Apr. 2000;26(2):137-40. X-1. [pmid: 10870307].
982 Chan YL, Wong KL, Lin CF, et al. Views of obstetric patients who refuse regional anesthesia in cesarean section. Acta Anaesthesiol Sin. Jun. 1998;36(2):99-102. X-1. [pmid: 9816720].
983 Chandis V, Williams T. The patient, the doctor, the fetus, and the court-compelled Cesarean: why courts should address the question through a bioethical lens. Med Law. Dec. 2006;25(4):729-46. X-1, X-2. [pmid: 17263038].
984 Chandler JM, Robie PW, Schoolar JC, et al. The effects of methadone on maternal-fetal interactions in the rat. J Pharmacol Exp Ther. Mar. 1975;192(3):549-54. X-1, X-3. [pmid: 1168255].
985 Chandra P, Schiavello HJ, Kluge JE, et al. Manual removal of the placenta and postcesarean endometritis. J Reprod Med. Feb. 2002;47(2):101-6. X-9. [pmid: 11883347].
986 Chandra PC, Schiavello HJ, Ravi B, et al. Pregnancy outcomes in urban teenagers. Int J Gynaecol Obstet. Nov. 2002;79(2):117-22. X-1. [pmid: 12427395].
987 Chang CH, Chang FM. Randomized comparison of misoprostol and dinoprostone for preinduction cervical ripening and labor induction. J Formos Med Assoc. May. 1997;96(5):366-9. X-4d, X-5. [pmid: 9170825].
988 Chang RK, Chen AY, Rodriguez S, et al. Changes in the newborn delivery practice and neonatal outcomes as financing changed in Los Angeles County and Orange County, California. Manag Care Interface. Oct. 2005;18(10):53-7. 62. X-1. [pmid: 16265936].
989 Chang SC, Chen CH. Effects of music therapy on women's physiologic measures, anxiety, and satisfaction during cesarean delivery. Res Nurs Health. Dec. 2005;28(6):453-61. X-9. [pmid: 16287051].
990 Chang WC, Chen SY, Huang SC, et al. Strategy of cervical myomectomy under laparoscopy. Fertil Steril. Dec. 2010;94(7):2710-5. X-1, X-4e. [pmid: 20381037].
991 Chanimov M, Gershfeld S, Cohen ML, et al. Fluid preload before spinal anaesthesia in Caesarean section: the effect on neonatal acid-base status. Eur J Anaesthesiol. Aug. 2006;23(8):676-9. X-9. [pmid: 16438767].
992 Chanprapaph P. Update in pre-eclampsia. J Med Assoc Thai. Oct. Suppl 3. 2004;87:S104-12. X-1. [pmid: 21213502].
993 Chanrachakul B, Hamontri S, Herabutya Y. A randomized comparison of postcesarean pain between closure and nonclosure of peritoneum. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2002;101(1):31-5. X-9. [pmid: 11803097].
994 Chanrachakul B, Herabutya Y. Postterm with favorable cervix: is induction necessary?. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2003;106(2):154-7. X-4e, X-5. [pmid: 12551783].
995 Chanrachakul B, Herabutya Y, Panburana P. Active management of labor: is it suitable for a developing country?. Int J Gynaecol Obstet. Mar. 2001;72(3):229-34. X-1. [pmid: 11226443].
996 Chanrachakul B, Herabutya Y, Punyavachira P. Randomized comparison of glyceryl trinitrate and prostaglandin E2 for cervical ripening at term. Obstet Gynecol. Oct. 2000;96(4):549-53. X-4d, X-5. [pmid: 11004357].
997 Chanrachakul B, Herabutya Y, Punyavachira P. Randomized trial of isosorbide mononitrate versus misoprostol for cervical ripening at term. Int J Gynaecol Obstet. Aug. 2002;78(2):139-45. X-4d. [pmid: 12175715].
998 Chanrachakul B, Herabutya Y, Udomsubpayakul U. Epidemic of cesarean section at the general, private and university hospitals in Thailand. J Obstet Gynaecol Res. Oct. 2000;26(5):357-61. X-1. [pmid: 11147723].
999 Chanrachakul B, Jaovisidha A, Herabutya Y, et al. External cephalic version: first report from Thailand. J Med Assoc Thai. Mar. 1999;82(3):224-8. X-1. [pmid: 10410475].
1000 Chanrachakul B, Matharoo-Ball B, Turner A, et al. Immunolocalization and protein expression of the alpha subunit of the large-conductance calcium-activated potassium channel in human myometrium. Reproduction. Jul. 2003;126(1):43-8. X-1. [pmid: 12814346].
1001 Chantarasorn V, Tannirandorn Y. A comparative study of early postoperative feeding versus conventional feeding for patients undergoing cesarean section; a randomized controlled trial. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S11-6. X-9. [pmid: 17725138].
1002 Chantharojwong P. An efficacy study of ampicillin versus cefazolin prophylaxis in patients undergoing cesarean section. J Med Assoc Thai. Mar. 1993;76(3):165-70. X-1, X-4b. [pmid: 8228713].
1003 Chao AS, Huang JY, Lien R, et al. Pregnancy in women who undergo long-term hemodialysis. Am J Obstet Gynecol. Jul. 2002;187(1):152-6. X-1. [pmid: 12114903].
1004 Chapman DJ, Young S, Ferris AM, et al. Impact of breast pumping on lactogenesis stage II after cesarean delivery: a randomized clinical trial. Pediatrics. Jun. 2001;107(6):E94. X-9. [pmid: 11389292].
1005 Chapman SJ, Owen J, Hauth JC. One-versus two-layer closure of a low transverse cesarean: the next pregnancy. Obstet Gynecol. Jan. 1997;89(1):16-8. X-9. [pmid: 8990429].
1006 Chappuy H, Treluyer JM, Jullien V, et al. Maternal-fetal transfer and amniotic fluid accumulation of nucleoside analogue reverse transcriptase inhibitors in human immunodeficiency virus-infected pregnant women. Antimicrob Agents Chemother. Nov. 2004;48(11):4332-6. X-1. [pmid: 15504861].
1007 Charoenkwan K, Palapinyo C. Early solid food after cesarean section and postoperative ileus. Int J Gynaecol Obstet. Aug. 2005;90(2):144-5. X-9. [pmid: 15913619].
1008 Charuluxananan S, Kyokong O, Somboonviboon W, et al. Nalbuphine versus propofol for treatment of intrathecal morphine-induced pruritus after cesarean delivery. Anesth Analg. Jul. 2001;93(1):162-5. X-9. [pmid: 11429358].
1009 Charuluxananan S, Kyokong O, Somboonviboon W, et al. Nalbuphine versus ondansetron for prevention of intrathecal morphine-induced pruritus after cesarean delivery. Anesth Analg. Jun. 2003;96(6):1789-93. table of contents. X-9. [pmid: 12761013].
1010 Charuluxananan S, Somboonviboon W, Kyokong O, et al. Ondansetron for treatment of intrathecal morphine-induced pruritus after cesarean delivery. Reg Anesth Pain Med. Sep-Oct. 2000;25(5):535-9. X-9. [pmid: 11009242].
1011 Charuluxananan S, Thienthong S, Rungreungvanich M, et al. Cardiac arrest after spinal anesthesia in Thailand: a prospective multicenter registry of 40,271 anesthetics. Anesth Analg. Nov. 2008;107(5):1735-41. X-1. [pmid: 18931240].
1012 Chaturvedi S, Ranadive B. Are we really making motherhood safe? A study of provision of iron supplements and emergency obstetric care in rural Maharashtra. Natl Med J India. Nov-Dec. 2007;20(6):294-6. X-1. [pmid: 18335795].
1013 Chaudhary S, Farrukh R, Dar A, et al. Outcome of labour in nullipara at term with unengaged vertex. J Ayub Med Coll Abbottabad. Jul-Sep. 2009;21(3):131-4. X-1. [pmid: 20929031].
1014 Chaudhuri P, Banerjee GB, Mandal A. Rectally administered misoprostol versus intravenous oxytocin infusion during cesarean delivery to reduce intraoperative and postoperative blood loss. Int J Gynaecol Obstet. Apr. 2010;109(1):25-9. X-9. [pmid: 20070961].
1015 Chauhan SP, Doherty DD, Magann EF, et al. Amniotic fluid index vs single deepest pocket technique during modified biophysical profile: a randomized clinical trial. Am J Obstet Gynecol. Aug. 2004;191(2):661-7. discussion 667-8. X-5, X-6. [pmid: 15343260].
1016 Chauhan SP, Justice L, Sanderson M, et al. Primary cesarean delivery among uncomplicated term nulliparous parturients: the influence of group practice within a community hospital. Am J Perinatol. Feb. 2008;25(2):119-23. X-1. [pmid: 18260043].
1017 Chauhan SP, Magann EF, Bufin L, et al. Umbilical arterial pH < 7.00 in newborns delivered by nonelective cesarean delivery: risk factors and peripartum outcomes. Am J Perinatol. Jul. 2004;21(5):281-7. X-1. [pmid: 15232761].
1018 Chauhan SP, Rutherford SE, Hess LW, et al. Prophylactic intrapartum amnioinfusion for patients with oligohydramnios. A prospective randomized study. J Reprod Med. Sep. 1992;37(9):817-20. X-4e. [pmid: 1453405].
1019 Chauhan SP, Troyer LR, Hendrix NW, et al. Neonatal acidemia with trial of labor among parturients with prior cesarean delivery: a case-control study. J Matern Fetal Med. Sep-Oct. 2000;9(5):278-81. X-1. [pmid: 11132582].
1020 Chauhan SP, Washburne JF, Magann EF, et al. A randomized study to assess the efficacy of the amniotic fluid index as a fetal admission test. Obstet Gynecol. Jul. 1995;86(1):9-13. X-4, X-5. [pmid: 7784029].
1021 Chau-in W, Hintong T, Rodanant O, et al. Anesthesia-related complications of caesarean delivery in Thailand: 16,697 cases from the Thai Anaesthesia Incidents Study. J Med Assoc Thai. Nov. 2010;93(11):1274-83. X-1. [pmid: 21114206].
1022 Chayen MS, Rudick V, Borvine A. Pain control with epidural injection of morphine. Anesthesiology. Oct. 1980;53(4):338-9. X-1. [pmid: 7191684].
1023 Chazotte C, Madden R, Cohen WR. Labor patterns in women with previous cesareans. Obstet Gynecol. Mar. 1990;75(3 Pt 1):350-5. X-1. [pmid: 2304706].
1024 Che Yaakob CA, Dzarr AA, Ismail AA, et al. Anticoagulant therapy for deep vein thrombosis (DVT) in pregnancy. Cochrane Database of Systematic Reviews. 2010;(6). X-1, X-2.
1025 Chelmow D, Andrew DE, Baker ER. Maternal cigarette smoking and placenta previa. Obstet Gynecol. May. 1996;87(5 Pt 1):703-6. X-1. [pmid: 8677070].
1026 Chelmow D, Huang E, Strohbehn K. Closure of the subcutaneous dead space and wound disruption after Cesarean delivery. J Matern Fetal Neonatal Med. Jun. 2002;11(6):403-8. X-9. [pmid: 12389657].
1027 Chelmow D, Kilpatrick SJ, Laros RK Jr. Maternal and neonatal outcomes after prolonged latent phase. Obstet Gynecol. Apr. 1993;81(4):486-91. X-1. [pmid: 8459953].
1028 Chelmow D, Marder AL, Boggess KA. Controversies in ob/gyn. Should patients undergoing low-risk C/S receive antibiotic prophylaxis?. Contemporary OB/GYN. 2006;51(8):57. X-1, X-2, X-3, X-4e, X-5.
1029 Chen BA, Reeves MF, Creinin MD, et al. Misoprostol for treatment of early pregnancy failure in women with previous uterine surgery. Am J Obstet Gynecol. Jun. 2008;198(6):626 e1-5. X-1. [pmid: 18279821].
1030 Chen BA, Reeves MF, Hayes JL, et al. Postplacental or delayed insertion of the levonorgestrel intrauterine device after vaginal delivery: a randomized controlled trial. Obstet Gynecol. Nov. 2010;116(5):1079-87. X-4e, X-5. [pmid: 20966692].
1031 Chen CP, Wang KG, Su TH, et al. Acute pancreatitis in pregnancy. Acta Obstet Gynecol Scand. Sep. 1995;74(8):607-10. X-1. [pmid: 7660765].
1032 Chen FP, Chang SD, Chu KK. Expectant management in severe preeclampsia: does magnesium sulfate prevent the development of eclampsia?. Acta Obstet Gynecol Scand. Mar. 1995;74(3):181-5. X-4e. [pmid: 7900522].
1033 Chen HM, Chang FY, Hsu CT. Effect of acupressure on nausea, vomiting, anxiety and pain among post-cesarean section women in Taiwan. Kaohsiung J Med Sci. Aug. 2005;21(8):341-50. X-1. [pmid: 16158876].
1034 Chen LK, Hsu HW, Lin CJ, et al. Effects of epidural fentanyl on labor pain during the early period of the first stage of induced labor in nulliparous women. J Formos Med Assoc. Jul. 2000;99(7):549-53. X-4e, X-5. [pmid: 10925565].
1035 Chen LK, Huang CH, Jean WH, et al. Effective epidural blood patch volumes for postdural puncture headache in Taiwanese women. J Formos Med Assoc. Feb. 2007;106(2):134-40. X-4e, X-5. [pmid: 17339157].
1036 Chen X, Qian X, Fu F, et al. Intrathecal sufentanil decreases the median effective dose (ED50) of intrathecal hyperbaric ropivacaine for caesarean delivery. Acta Anaesthesiol Scand. Mar. 2010;54(3):284-90. X-9. [pmid: 19650804].
1037 Chen XZ, Chen H, Lou AF, et al. Dose-response study of spinal hyperbaric ropivacaine for cesarean section. J Zhejiang Univ Sci B. Dec. 2006;7(12):992-7. X-9. [pmid: 17111469].
1038 Cheng CR, Su TH, Hung YC, et al. A comparative study of the safety and efficacy of 0.5% levobupivacaine and 0.5% bupivacaine for epidural anesthesia in subjects undergoing elective caesarean section. Acta Anaesthesiol Sin. Mar. 2002;40(1):13-20. X-9. [pmid: 11989042].
1039 Cheng SY, Ming H, Lee JC. Titrated oral compared with vaginal misoprostol for labor induction: a randomized controlled trial. Obstet Gynecol. Jan. 2008;111(1):119-25. X-4d, X-5. [pmid: 18165400].
1040 Cheng YW, Chung JH, Kurbisch-Block I, et al. Gestational weight gain and gestational diabetes mellitus: perinatal outcomes. Obstet Gynecol. Nov. 2008;112(5):1015-22. X-1. [pmid: 18978100].
1041 Cheng YW, Esakoff TF, Block-Kurbisch I, et al. Screening or diagnostic: markedly elevated glucose loading test and perinatal outcomes. J Matern Fetal Neonatal Med. Nov. 2006;19(11):729-34. X-1. [pmid: 17127496].
1042 Cheng YW, Hopkins LM, Caughey AB. How long is too long: Does a prolonged second stage of labor in nulliparous women affect maternal and neonatal outcomes?. Am J Obstet Gynecol. Sep. 2004;191(3):933-8. X-1. [pmid: 15467567].
1043 Cheng YW, Shaffer BL, Bryant AS, et al. Length of the first stage of labor and associated perinatal outcomes in nulliparous women. Obstet Gynecol. Nov. 2010;116(5):1127-35. X-1. [pmid: 20966698].
1044 Cheng YW, Shaffer BL, Caughey AB. Associated factors and outcomes of persistent occiput posterior position: A retrospective cohort study from 1976 to 2001. J Matern Fetal Neonatal Med. Sep. 2006;19(9):563-8. X-1. [pmid: 16966125].
1045 Cheng YW, Shaffer BL, Caughey AB. The association between persistent occiput posterior position and neonatal outcomes. Obstet Gynecol. Apr. 2006;107(4):837-44. X-1. [pmid: 16582120].
1046 Cheong YC, Abdullahi H, Lashen H, et al. Can formal education and training improve the outcome of instrumental delivery?. Eur J Obstet Gynecol Reprod Biol. Apr. 15. 2004;113(2):139-44. X-1. [pmid: 15063949].
1047 Cherian VT, Smith I. Prophylactic ondansetron does not improve patient satisfaction in women using PCA after Caesarean section. Br J Anaesth. Sep. 2001;87(3):502-4. X-9. [pmid: 11517140].
1048 Chertok IR, Shoham-Vardi I, Hallak M. Four-month breastfeeding duration in postcesarean women of different cultures in the Israeli Negev. J Perinat Neonatal Nurs. Apr-Jun. 2004;18(2):145-60. X-1. [pmid: 15214252].
1049 Chervenak FA, McCullough LB. Inadequacies with the ACOG and AAP statements on managing ethical conflict during the intrapartum period. J Clin Ethics. Spring. 1991;2(1):23-4. X-1. [pmid: 11642910].
1050 Chervenak FA, McCullough LB. An ethically justified algorithm for offering, recommending, and performing cesarean delivery and its application in managed care practice. Obstet Gynecol. Feb. 1996;87(2):302-5. X-1. [pmid: 8559543].
1051 Chervenak JL, Divon MY, Hirsch J, et al. Macrosomia in the postdate pregnancy: is routine ultrasonographic screening indicated?. Am J Obstet Gynecol. Sep. 1989;161(3):753-6. X-1. [pmid: 2675605].
1052 Chestnut DH, Choi WW, Isbell TJ. Epidural hydromorphone for postcesarean analgesia. Obstet Gynecol. Jul. 1986;68(1):65-9. X-9. [pmid: 2425315].
1053 Chestnut DH, Dewan DM, Redick LF, et al. Anesthetic management for obstetric hysterectomy: a multi-institutional study. Anesthesiology. Apr. 1989;70(4):607-10. X-1. [pmid: 2648896].
1054 Chestnut DH, Laszewski LJ, Pollack KL, et al. Continuous epidural infusion of 0.0625% bupivacaine-0.0002% fentanyl during the second stage of labor. Anesthesiology. Apr. 1990;72(4):613-8. X-4e, X-5. [pmid: 2321776].
1055 Chestnut DH, McGrath JM, Vincent RD Jr., et al. Does early administration of epidural analgesia affect obstetric outcome in nulliparous women who are in spontaneous labor?. Anesthesiology. Jun. 1994;80(6):1201-8. X-4e, X-5. [pmid: 8010466].
1056 Chestnut DH, Vandewalker GE, Owen CL, et al. The influence of continuous epidural bupivacaine analgesia on the second stage of labor and method of delivery in nulliparous women. Anesthesiology. Jun. 1987;66(6):774-80. X-4e, X-5. [pmid: 3296856].
1057 Chestnut DH, Vincent RD Jr., McGrath JM, et al. Does early administration of epidural analgesia affect obstetric outcome in nulliparous women who are receiving intravenous oxytocin?. Anesthesiology. Jun. 1994;80(6):1193-200. X-5. [pmid: 8010465].
1058 Chetty VK. Stochastic technology, production organization and costs. J Health Econ. Apr. 1998;17(2):187-210. X-1. [pmid: 10180915].
1059 Cheung NF, Mander R, Cheng L, et al. ‘Zuoyuezi’ after caesarean in China: an interview survey. Int J Nurs Stud. Feb. 2006;43(2):193-202. X-1. [pmid: 15967454].
1060 Cheung VY, Constantinescu OC, Ahluwalia BS. Sonographic evaluation of the lower uterine segment in patients with previous cesarean delivery. J Ultrasound Med. Nov. 2004;23(11):1441-7. X-1. [pmid: 15498908].
1061 Chevalier N, Letur H, Lelannou D, et al. Materno-fetal cardiovascular complications in Turner syndrome after oocyte donation: insufficient prepregnancy screening and pregnancy follow-up are associated with poor outcome. J Clin Endocrinol Metab. Feb. 2011;96(2):E260-7. X-1. [pmid: 21147890].
1062 Chew FT, Drew JH, Oats JN, et al. Nonstressed antepartum cardiotocography in patients undergoing elective cesarean section--fetal outcome. Am J Obstet Gynecol. Feb. 1. 1985;151(3):318-21. X-3, X-4e. [pmid: 3970099].
1063 Chhabra S, Bhandari V. Some medico-socio-demographic factors and intra-uterine growth retardation. J Indian Med Assoc. Apr. 1996;94(4):127-30. X-1. [pmid: 8854623].
1064 Chhabra S, Dargan R, Nasare M. Antepartum transabdominal amnioinfusion. Int J Gynaecol Obstet. May. 2007;97(2):95-9. X-1. [pmid: 17379222].
1065 Chi C, Shiltagh N, Kingman CE, et al. Identification and management of women with inherited bleeding disorders: a survey of obstetricians and gynaecologists in the United Kingdom. Haemophilia. Jul. 2006;12(4):405-12. X-1. [pmid: 16834742].
1066 Chia P, Raman S, Tham SW. The pregnancy outcome of acyanotic heart disease. J Obstet Gynaecol Res. Aug. 1998;24(4):267-73. X-1. [pmid: 9798356].
1067 Chia YT, Chua S, Thai AC, et al. Gestational diabetes: obstetric and neonatal outcome in 411 cases. Singapore Med J. Dec. 1996;37(6):591-4. X-1. [pmid: 9104056].
1068 Chia YT, Chua S, Thai AC, et al. Obstetric outcome of pregestational diabetic pregnancies. Singapore Med J. Oct. 1995;36(5):498-500. X-1. [pmid: 8882533].
1069 Chibber R, Al-Sibai MH. Pregnancy following infertility: a concern?. J Obstet Gynaecol. Nov. 2007;27(8):806-9. X-1. [pmid: 18097899].
1070 Chibber RM, Khuranna A, al-Sibai MH, et al. Course and outcome of pregnancy in 54 persistently HIV-1-seronegative sex workers and their infants. J Reprod Med. Dec. 2002;47(12):1016-20. X-1. [pmid: 12516320].
1071 Chibber RM, Usmani MA, Al-Sibai MH. Should HEV infected mothers breast feed?. Arch Gynecol Obstet. Jul. 2004;270(1):15-20. X-1. [pmid: 12698262].
1072 Chien LY, Ko YL. Fatigue during pregnancy predicts caesarean deliveries. J Adv Nurs. Mar. 2004;45(5):487-94. X-1. [pmid: 15009351].
1073 Chigbu B, Onwere S, Aluka C, et al. Factors influencing the use of episiotomy during vaginal delivery in South Eastern Nigeria. East Afr Med J. May. 2008;85(5):240-3. X-1. [pmid: 18814534].
1074 Chigbu CO, Ezenyeaku CC, Ezenkwele E. Obstetricians' opinions and attitudes toward maternal refusal of recommended cesarean delivery in Nigeria. Int J Gynaecol Obstet. Jun. 2009;105(3):248-51. X-1. [pmid: 19232613].
1075 Chigbu CO, Ezenyeaku CC, Ezenkwele EP. Obstetricians' attitudes to caesarean delivery on maternal request in Nigeria. J Obstet Gynaecol. 2010;30(8):813-7. X-1. [pmid: 21126119].
1076 Chigbu CO, Ezeome IV, Iloabachie GC. Cesarean section on request in a developing country. Int J Gynaecol Obstet. Jan. 2007;96(1):54-6. X-1. [pmid: 17187800].
1077 Chigbu CO, Iloabachie GC. The burden of caesarean section refusal in a developing country setting. BJOG. Oct. 2007;114(10):1261-5. X-1. [pmid: 17877678].
1078 Chin KJ, Yeo SW. Bispectral index values at sevoflurane concentrations of 1% and 1.5% in lower segment cesarean delivery. Anesth Analg. Apr. 2004;98(4):1140-4. table of contents. X-1. [pmid: 15041614].
1079 Chinayon P. Clinical management and outcome of eclampsia at Rajavithi Hospital. J Med Assoc Thai. Aug. 1998;81(8):579-85. X-1. [pmid: 9737110].
1080 Chipchase J, Peebles D, Rodeck C. Severe preeclampsia and cerebral blood volume response to postural change. Obstet Gynecol. Jan. 2003;101(1):86-92. X-1. [pmid: 12517651].
1081 Chit Ying L, Levy V, Oi Shan C, et al. A qualitative study of the perceptions of Hong Kong Chinese women during caesarean section under regional anaesthesia. Midwifery. Jun. 2001;17(2):115-22. X-1. [pmid: 11399132].
1082 Chittiphavorn S, Pinjaroen S, Suwanrath C, et al. Clinical practice guideline for cesarean section due to cephalopelvic disproportion. J Med Assoc Thai. Jun. 2006;89(6):735-40. X-1. [pmid: 16850670].
1083 Chivonivoni C, Ehlers VJ, Roos JH. Mothers' attitudes towards using services preventing mother-to-child HIV/AIDS transmission in Zimbabwe: an interview survey. Int J Nurs Stud. Nov. 2008;45(11):1618-24. X-1. [pmid: 18502426].
1084 Cho JH, Jun HS, Lee CN. Hemostatic suturing technique for uterine bleeding during cesarean delivery. Obstet Gynecol. Jul. 2000;96(1):129-131. X-1. [pmid: 10928901].
1085 Cho JY, Kim SJ, Cha KY, et al. Interrupted circular suture: bleeding control during cesarean delivery in placenta previa accreta. Obstet Gynecol. Nov. 1991;78(5 Pt 1):876-9. X-1. [pmid: 1923215].
1086 Choi DH, Ahn HJ, Kim JA. Combined low-dose spinal-epidural anesthesia versus single-shot spinal anesthesia for elective cesarean delivery. Int J Obstet Anesth. Jan. 2006;15(1):13-7. X-9. [pmid: 16256330].
1087 Choi DH, Ahn HJ, Kim MH. Bupivacaine-sparing effect of fentanyl in spinal anesthesia for cesarean delivery. Reg Anesth Pain Med. May-Jun. 2000;25(3):240-5. X-9. [pmid: 10834777].
1088 Choi DH, Park NK, Cho HS, et al. Effects of epidural injection on spinal block during combined spinal and epidural anesthesia for cesarean delivery. Reg Anesth Pain Med. Nov-Dec. 2000;25(6):591-5. X-9. [pmid: 11097665].
1089 Choi DM, Kliffer AP, Douglas MJ. Dextromethorphan and intrathecal morphine for analgesia after Caesarean section under spinal anaesthesia. Br J Anaesth. May. 2003;90(5):653-8. X-9. [pmid: 12697594].
1090 Choi HJ, Little MS, Garber SZ, et al. Pulse oximetry for monitoring during ward analgesia: epidural morphine versus parenteral narcotics. J Clin Monit. Apr. 1989;5(2):87-9. X-9. [pmid: 2723710].
1091 Choi SJ, Oh SY, Kim JH, et al. Increased expression of N-myc downstream-regulated gene 1 (NDRG1) in placentas from pregnancies complicated by intrauterine growth restriction or preeclampsia. Am J Obstet Gynecol. Jan. 2007;196(1):45 e1-7. X-1. [pmid: 17240229].
1092 Chongsuvivatwong V, Bachtiar H, Chowdhury ME, et al. Maternal and fetal mortality and complications associated with cesarean section deliveries in teaching hospitals in Asia. J Obstet Gynaecol Res. Feb. 2010;36(1):45-51. X-1. [pmid: 20178526].
1093 Choolani M, Ratnam SS. Maternal mortality: a global overview. J Indian Med Assoc. Feb. 1995;93(2):36-40. X-1, X-2. [pmid: 7658032].
1094 Chou MM, MacKenzie IZ. A prospective, double-blind, randomized comparison of prophylactic intramyometrial 15-methyl prostaglandin F2 alpha, 125 micrograms, and intravenous oxytocin, 20 units, for the control of blood loss at elective cesarean section. Am J Obstet Gynecol. Nov. 1994;171(5):1356-60. X-9. [pmid: 7977546].
1095 Chou YJ, Huang N, Lin IF, et al. Do physicians and their relatives have a decreased rate of cesarean section? A 4-year population-based study in Taiwan. Birth. Sep. 2006;33(3):195-202. X-1. [pmid: 16948719].
1096 Choudhury AP, Dawson AJ. Trends in indications for caesarean sections over 7 years in a Welsh district general hospital. J Obstet Gynaecol. Nov. 2009;29(8):714-7. X-1. [pmid: 19821664].
1097 Christelis N, Harrad J, Howell PR. A comparison of epidural ropivacaine 0.75% and bupivacaine 0.5% with fentanyl for elective caesarean section. Int J Obstet Anesth. Jul. 2005;14(3):212-8. X-9. [pmid: 15935650].
1098 Christensson K. Fathers can effectively achieve heat conservation in healthy newborn infants. Acta Paediatr. Nov. 1996;85(11):1354-60. X-9. [pmid: 8955466].
1099 Christie JM, Chen GW. Secondary hyperalgesia is not affected by wound infiltration with bupivacaine. Can J Anaesth. Nov. 1993;40(11):1034-7. X-9. [pmid: 8269563].
1100 Chu CC, Shu SS, Lin SM, et al. The effect of intrathecal bupivacaine with combined fentanyl in cesarean section. Acta Anaesthesiol Sin. Sep. 1995;33(3):149-54. X-9. [pmid: 7493145].
1101 Chu KH, Tai CJ, Hsu CS, et al. Women's preference for cesarean delivery and differences between Taiwanese women undergoing different modes of delivery. BMC Health Serv Res. 2010;10:138. X-1. [pmid: 20504354].
1102 Chua S, Arulkumaran S, Kurup A, et al. Does prostaglandin confer significant advantage over oxytocin infusion for nulliparas with pre-labor rupture of membranes at term?. Obstet Gynecol. May. 1991;77(5):664-7. X-3, X-4e, X-5. [pmid: 2014076].
1103 Chua S, Arulkumaran S, Yap C, et al. Premature rupture of membranes in nulliparas at term with unfavorable cervices: a double-blind randomized trial of prostaglandin and placebo. Obstet Gynecol. Oct. 1995;86(4 Pt 1):550-4. X-4d, X-4e. [pmid: 7675378].
1104 Chua S, Kurup A, Arulkumaran S, et al. Augmentation of labor: does internal tocography result in better obstetric outcome than external tocography?. Obstet Gynecol. Aug. 1990;76(2):164-7. X-5. [pmid: 2196493].
1105 Chua S, Wilkins T, Sargent I, et al. Trophoblast deportation in pre-eclamptic pregnancy. Br J Obstet Gynaecol. Oct. 1991;98(10):973-9. X-1. [pmid: 1751443].
1106 Chumpathong S, Santawat U, Saunya P, et al. Comparison of different doses of epidural morphine for pain relief following cesarean section. J Med Assoc Thai. Sep. Suppl 3. 2002;85:S956-62. X-9. [pmid: 12452235].
1107 Chung CJ, Bae SH, Chae KY, et al. Spinal anaesthesia with 0.25% hyperbaric bupivacaine for Caesarean section: effects of volume. Br J Anaesth. Aug. 1996;77(2):145-9. X-9. [pmid: 8881614].
1108 Chung CJ, Choi SR, Yeo KH, et al. Hyperbaric spinal ropivacaine for cesarean delivery: a comparison to hyperbaric bupivacaine. Anesth Analg. Jul. 2001;93(1):157-61. X-9. [pmid: 11429357].
1109 Chung CJ, Kim JS, Park HS, et al. The efficacy of intrathecal neostigmine, intrathecal morphine, and their combination for post-cesarean section analgesia. Anesth Analg. Aug. 1998;87(2):341-6. X-9. [pmid: 9706928].
1110 Chung CJ, Yun SH, Hwang GB, et al. Intrathecal fentanyl added to hyperbaric ropivacaine for cesarean delivery. Reg Anesth Pain Med. Nov-Dec. 2002;27(6):600-3. X-9. [pmid: 12430112].
1111 Chung JH, Garite TJ, Kirk AM, et al. Intrinsic racial differences in the risk of cesarean delivery are not explained by differences in caregivers or hospital site of delivery. Am J Obstet Gynecol. May. 2006;194(5):1323-8. X-1. [pmid: 16647917].
1112 Chung JH, Sinatra RS, Sevarino FB, et al. Subarachnoid meperidine-morphine combination. An effective perioperative analgesic adjunct for cesarean delivery. Reg Anesth. Mar-Apr. 1997;22(2):119-24. X-9. [pmid: 9089852].
1113 Chung TK, Lau TK, Yip AS, et al. Antepartum depressive symptomatology is associated with adverse obstetric and neonatal outcomes. Psychosom Med. Sep-Oct. 2001;63(5):830-4. X-1. [pmid: 11573032].
1114 Cindoglu D, Sayan-Cengiz F. Medicalization discourse and modernity: contested meanings over childbirth in contemporary Turkey. Health Care Women Int. Mar. 2010;31(3):221-43. X-1. [pmid: 20390649].
1115 Cindrova-Davies T, Yung HW, Johns J, et al. Oxidative stress, gene expression, and protein changes induced in the human placenta during labor. Am J Pathol. Oct. 2007;171(4):1168-79. X-1. [pmid: 17823277].
1116 Cinque B, Montesanti MI, Parlati E, et al. Corpus luteum function during the early puerperium. J Endocrinol Invest. Feb. 1985;8(1):1-6. X-1. [pmid: 3989235].
1117 Cirpan T, Akercan F, Terek MC, et al. Evaluation of VEGF in placental bed biopsies from preeclamptic women by immunohistochemistry. Clin Exp Obstet Gynecol. 2007;34(4):228-31. X-1. [pmid: 18225684].
1118 Citkovitz C, Klimenko E, Bolyai M, et al. Effects of acupuncture during labor and delivery in a U.S. hospital setting a case-control pilot study. J Altern Complement Med. May. 2009;15(5):501-5. X-1. [pmid: 19432512].
1119 Claris O, Picaud JC, Brazier JL, et al. Pharmacokinetics of cyclosporin A in 16 newborn infants of renal or cardiac transplant mothers. Dev Pharmacol Ther. 1993;20(3-4):180-5. X-1. [pmid: 7828451].
1120 Clark A, Carr D, Loyd G, et al. The influence of epidural analgesia on cesarean delivery rates: a randomized, prospective clinical trial. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1527-33. X-9. [pmid: 9855591].
1121 Clark M. Maternal exercise and caesarean section. MIDIRS Midwifery Digest. 2005;15(4):530-533. X-1, X-2, X-3, X-4, X-5.
1122 Clark SL, Belfort MA, Dildy GA, et al. Reducing obstetric litigation through alterations in practice patterns. Obstet Gynecol. Dec. 2008;112(6):1279-83. X-1. [pmid: 19037036].
1123 Clark SL, Belfort MA, Hankins GD, et al. Variation in the rates of operative delivery in the United States. Am J Obstet Gynecol. Jun. 2007;196(6):526 e1-5. X-1. [pmid: 17547880].
1124 Clark SL, Koonings PP, Phelan JP. Placenta previa/accreta and prior cesarean section. Obstet Gynecol. Jul. 1985;66(1):89-92. X-1. [pmid: 4011075].
1125 Clark SL, Miller DD, Belfort MA, et al. Neonatal and maternal outcomes associated with elective term delivery. Am J Obstet Gynecol. Feb. 2009;200(2):156 e1-4. X-1. [pmid: 19110225].
1126 Clark SL, Xu W, Porter TF, et al. Institutional influences on the primary cesarean section rate in Utah, 1992 to 1995. Am J Obstet Gynecol. Oct. 1998;179(4):841-5. X-1. [pmid: 9790356].
1127 Clark V, McGrady E, Sugden C, et al. Speed of onset of sensory block for elective extradural caesarean section: choice of agent and temperature of injectate. Br J Anaesth. Feb. 1994;72(2):221-3. X-9. [pmid: 8110578].
1128 Clark VA, Wardall GJ, McGrady EM. Blood ordering practices in obstetric units in the United Kingdom. Anaesthesia. Nov. 1993;48(11):998-1001. X-1. [pmid: 8250200].
1129 Cleary R, Beard RW, Chapple J, et al. The standard primipara as a basis for inter-unit comparisons of maternity care. Br J Obstet Gynaecol. Mar. 1996;103(3):223-9. X-1. [pmid: 8630306].
1130 Cleary-Goldman J, Bettes B, Robinson JN, et al. Postterm pregnancy: practice patterns of contemporary obstetricians and gynecologists. Am J Perinatol. Jan. 2006;23(1):15-20. X-1. [pmid: 16450267].
1131 Cleary-Goldman J, Cornelisse K, Simpson LL, et al. Previous cesarean delivery: understanding and satisfaction with mode of delivery in a subsequent pregnancy in patients participating in a formal vaginal birth after cesarean counseling program. Am J Perinatol. May. 2005;22(4):217-21. X-1. [pmid: 15906216].
1132 Cnattingius R, Hoglund B, Kieler H. Emergency cesarean delivery in induction of labor: an evaluation of risk factors. Acta Obstet Gynecol Scand. May. 2005;84(5):456-62. X-1. [pmid: 15842210].
1133 Cochlin DL. Effects of two ultrasound scanning regimens on the management of pregnancy. Br J Obstet Gynaecol. Sep. 1984;91(9):885-90. X-1. [pmid: 6383460].
1134 Cockell AP, Learmont JG, Smarason AK, et al. Human placental syncytiotrophoblast microvillous membranes impair maternal vascular endothelial function. Br J Obstet Gynaecol. Feb. 1997;104(2):235-40. X-1. [pmid: 9070146].
1135 Cockey CD. On the edge. Teen birthrate falls to record low. AWHONN Lifelines. 2002;6(4):307-307. X-1.
1136 Coetzee EJ, Dommisse J, Anthony J. A randomised controlled trial of intravenous magnesium sulphate versus placebo in the management of women with severe pre-eclampsia. Br J Obstet Gynaecol. Mar. 1998;105(3):300-3. X-4e. [pmid: 9532990].
1137 Coetzee EJ, Jackson WP. Pregnancy in insulin-dependent diabetics. A 5 1/2-year study at Groote Schuur Hospital. S Afr Med J. Aug. 15. 1981;60(7):275-8. X-1. [pmid: 7020109].
1138 Coffin CS, Shaheen AA, Burak KW, et al. Pregnancy outcomes among liver transplant recipients in the United States: a nationwide case-control analysis. Liver Transpl. Jan. 2010;16(1):56-63. X-1. [pmid: 20035524].
1139 Cogliano MS, Graham AC, Clark VA. Supplementary oxygen administration for elective Caesarean section under spinal anaesthesia. Anaesthesia. Jan. 2002;57(1):66-9. X-9. [pmid: 11843746].
1140 Cohain JS. Connecting to birth. Midwifery Today Int Midwife. Fall. 2003;(67):18-9. X-1. [pmid: 14596094].
1141 Cohain JS. Management or care: different outcomes. Midwifery Today Int Midwife. Summer. 2007;(82):19-21. X-1, X-2. [pmid: 17725119].
1142 Cohain JS. Documented causes of unneCesareans. Midwifery Today Int Midwife. Winter. 2009;(92):18-9. 63. X-1, X-2. [pmid: 20092138].
1143 Cohain JS. Nuchal cords are necklaces, not nooses. Midwifery Today Int Midwife. Spring. 2010;(93):46-8. 67. 8. X-1. [pmid: 20397541].
1144 Cohen HR, Green JR, Crombleholme WR. Peripartum cocaine use: estimating risk of adverse pregnancy outcome. Int J Gynaecol Obstet. May. 1991;35(1):51-4. X-1. [pmid: 1680076].
1145 Cohen JR. Patient satisfaction with the prenatal care provider and the risk of cesarean delivery. Am J Obstet Gynecol. Jun. 2005;192(6):2029-32. discussion 2032-4. X-1. [pmid: 15970886].
1146 Cohen NW, LaLeike S. What factors cause unnecessary cesareans?. Midwifery Today Childbirth Educ. Autumn. 1992;(23):16-7. X-1. [pmid: 1339528].
1147 Cohen S, Amar D. Epidural block for obstetrics: comparison of bolus injection of local anesthetic with gravity flow technique. J Clin Anesth. Dec. 1997;9(8):623-8. X-4e. [pmid: 9438889].
1148 Cohen S, Amar D, Pantuck CB, et al. Postcesarean delivery epidural patient-controlled analgesiaFentanyl or sufentanil?. Anesthesiology. Mar. 1993;78(3):486-91. X-9. [pmid: 8457049].
1149 Cohen S, Amar D, Pantuck CB, et al. Adverse effects of epidural 0.03% bupivacaine during analgesia after cesarean section. Anesth Analg. Nov. 1992;75(5):753-6. X-9. [pmid: 1416129].
1150 Cohen S, Amar D, Pantuck CB, et al. Epidural patient-controlled analgesia after cesarean section buprenorphine-0.015% bupivacaine with epinephrine versus fentanyl 0.015% bupivacaine with and without epinephrine. Anesth Analg. Feb. 1992;74(2):226-30. X-9. [pmid: 1731541].
1151 Cohen S, Amar D, Pantuck EJ, et al. Decreased incidence of headache after accidental dural puncture in caesarean delivery patients receiving continuous postoperative intrathecal analgesia. Acta Anaesthesiol Scand. Oct. 1994;38(7):716-8. X-1. [pmid: 7839783].
1152 Cohen S, Lowenwirt I, Pantuck CB, et al. Bupivacaine 0.01% and/or epinephrine 0.5 microg/ml improve epidural fentanyl analgesia after cesarean section. Anesthesiology. Dec. 1998;89(6):1354-61. X-9. [pmid: 9856709].
1153 Cohen S, Pantuck CB, Amar D, et al. The primary action of epidural fentanyl after cesarean delivery is via a spinal mechanism. Anesth Analg. Mar. 2002;94(3):674-9. table of contents. X-9. [pmid: 11867396].
1154 Cohen SB, Goldenberg M, Rabinovici J, et al. Anti-cardiolipin antibodies in fetal blood and amniotic fluid derived from patients with the anti-phospholipid syndrome. Hum Reprod. May. 2000;15(5):1170-2. X-1. [pmid: 10783372].
1155 Cohen SE, Labaille T, Benhamou D, et al. Respiratory effects of epidural sufentanil after cesarean section. Anesth Analg. May. 1992;74(5):677-82. X-9. [pmid: 1533106].
1156 Cohen SE, Ratner EF, Kreitzman TR, et al. Nalbuphine is better than naloxone for treatment of side effects after epidural morphine. Anesth Analg. Nov. 1992;75(5):747-52. X-9. [pmid: 1416128].
1157 Cohen SE, Subak LL, Brose WG, et al. Analgesia after cesarean delivery: patient evaluations and costs of five opioid techniques. Reg Anesth. May-Jun. 1991;16(3):141-9. X-9. [pmid: 1883771].
1158 Cohen SE, Tan S, White PF. Sufentanil analgesia following cesarean section: epidural versus intravenous administration. Anesthesiology. Jan. 1988;68(1):129-34. X-9. [pmid: 2892439].
1159 Cohen SE, Woods WA. The role of epidural morphine in the postcesarean patient: efficacy and effects on bonding. Anesthesiology. Jun. 1983;58(6):500-4. X-9. [pmid: 6344699].
1160 Cohen SL. A function for estriol during human pregnancy--a hypothesis. Clin Biochem. Apr. 1985;18(2):85-7. X-1. [pmid: 4017228].
1161 Cole CP, McMorland GH, Axelson JE, et al. Epidural blockade for cesarean section comparing lidocaine hydrocarbonate and lidocaine hydrochloride. Anesthesiology. Mar. 1985;62(3):348-50. X-9. [pmid: 3977119].
1162 Cole RA, Howie PW, Macnaughton MC. Elective induction of labour. A randomised prospective trial. Lancet. Apr. 5. 1975;1(7910):767-70. X-5. [pmid: 48000].
1163 Coleman TL, Randall H, Graves W, et al. Vaginal birth after cesarean among women with gestational diabetes. Am J Obstet Gynecol. May. 2001;184(6):1104-7. X-1. [pmid: 11349170].
1164 Coleman VH, Erickson K, Schulkin J, et al. Vaginal birth after cesarean delivery: practice patterns of obstetrician-gynecologists. J Reprod Med. Apr. 2005;50(4):261-6. X-1. [pmid: 15916210].
1165 Coleman-Cowger VH, Erickson K, Spong CY, et al. Current practice of cesarean delivery on maternal request following the 2006 state-of-the-science conference. J Reprod Med. Jan-Feb. 2010;55(1-2):25-30. X-1. [pmid: 20337204].
1166 Colker R. Reply to Sarah Burns. Harv Women's Law J. Spring. 1990;13:207-14. X-1, X-2.
1167 Collard TD, Diallo H, Habinsky A, et al. Elective cesarean section: why women choose it and what nurses need to know. Nurs Womens Health. Dec. 2008;12(6):480-8. X-1, X-2. [pmid: 19121053].
1168 Collaris R, Tan PC. Oral nifepidine versus subcutaneous terbutaline tocolysis for external cephalic version: a double-blind randomised trial. BJOG. Jan. 2009;116(1):74-80. discussion 80-1. X-4e. [pmid: 19087079].
1169 Collea JV, Chein C, Quilligan EJ. The randomized management of term frank breech presentation: a study of 208 cases. Am J Obstet Gynecol. May. 15. 1980;137(2):235-44. X-3, X-4c, X-5. [pmid: 7377243].
1170 Collea JV, Rabin SC, Weghorst GR, et al. The randomized management of term frank breech presentation: vaginal delivery vs. cesarean section. Am J Obstet Gynecol. May. 15. 1978;131(2):186-95. X-4c, X-4b. [pmid: 645799].
1171 Collea JV, Rabin SC, Weghorst GR, et al. The randomized management of term frank breech presentation: vaginal delivery vs. cesarean section. Trans Pac Coast Obstet Gynecol Soc. 1978;45:88-97. X-4c, X-4b. [pmid: 715874].
1172 Colletto GM, Segre CA. Lack of effect of maternal body mass index on anthropometric characteristics of newborns in twin gestations. Genet Mol Res. 2005;4(1):47-54. X-1. [pmid: 15841435].
1173 Collier CB, Gatt SP. Epidural catheters for obstetrics. Terminal hole or lateral eyes?. Reg Anesth. Nov-Dec. 1994;19(6):378-85. X-3, X-4e. [pmid: 7848946].
1174 Collin SM, Marshall T, Filippi V. Caesarean section and subsequent fertility in sub-Saharan Africa. BJOG. Mar. 2006;113(3):276-83. X-1. [pmid: 16487198].
1175 Collingham JP, Fuh KC, Caughey AB, et al. Oral misoprostol and vaginal isosorbide mononitrate for labor induction: a randomized controlled trial. Obstet Gynecol. Jul. 2010;116(1):121-6. X-4d, X-5. [pmid: 20567177].
1176 Collins S, Ellaway P, Harrington D, et al. The complications of external cephalic version: results from 805 consecutive attempts. BJOG. May. 2007;114(5):636-8. X-3, X-4c, X-4e, X-5. [pmid: 17355270].
1177 Colman RD, Frank M, Loughnan BA, et al. Use of i.m. ranitidine for the prophylaxis of aspiration pneumonitis in obstetrics. Br J Anaesth. Dec. 1988;61(6):720-9. X-9. [pmid: 3207544].
1178 Colon I, Clawson K, Hunter K, et al. Prospective randomized clinical trial of inpatient cervical ripening with stepwise oral misoprostol vs vaginal misoprostol. Am J Obstet Gynecol. Mar. 2005;192(3):747-52. X-4d. [pmid: 15746667].
1179 Combs CA, Murphy EL, Laros RK Jr. Factors associated with hemorrhage in cesarean deliveries. Obstet Gynecol. Jan. 1991;77(1):77-82. X-1. [pmid: 1984231].
1180 Combs CA, Singh NB, Khoury JC. Elective induction versus spontaneous labor after sonographic diagnosis of fetal macrosomia. Obstet Gynecol. Apr. 1993;81(4):492-6. X-1. [pmid: 8459954].
1181 Comried LA. Cost analysis: initiation of HBMC and first CareMap. Nurs Econ. Jan-Feb. 1996;14(1):34-9. X-1. [pmid: 8700246].
1182 Congreve K, Gardner I, Laxton C, et al. Where is T5? A survey of anaesthetists. Anaesthesia. May. 2006;61(5):453-5. X-1. [pmid: 16674620].
1183 Connell H, Dalgleish JG, Downing JW. General anaesthesia in mothers with severe pre-eclampsia/eclampsia. Br J Anaesth. Nov. 1987;59(11):1375-80. X-1. [pmid: 3689611].
1184 Connelly NR, Dunn SM, Ingold V, et al. The use of fentanyl added to morphine-lidocaine-epinephrine spinal solution in patients undergoing cesarean section. Anesth Analg. May. 1994;78(5):918-20. X-9. [pmid: 8160990].
1185 Connelly NR, Parker RK, Pedersen T, et al. Diluent volume for epidural fentanyl and its effect on analgesia in early labor. Anesth Analg. Jun. 2003;96(6):1799-804. table of contents. X-1, X-4a, X-4e, X-5. [pmid: 12761015].
1186 Connolly C, McLeod GA, Wildsmith JA. Spinal anaesthesia for Caesarean section with bupivacaine 5 mg ml(-1) in glucose 8 or 80 mg ml(-1). Br J Anaesth. Jun. 2001;86(6):805-7. X-9. [pmid: 11573587].
1187 Connolly G, Kennelly S, Conroy R, et al. Teenage pregnancy in the Rotunda Hospital. Ir Med J. Dec. 1998;91(6):209-12. X-1. [pmid: 10069131].
1188 Connolly G, Naidoo C, Conroy RM, et al. A new predictor of cephalopelvic disproportion?. J Obstet Gynaecol. Jan. 2003;23(1):27-9. X-1. [pmid: 12623477].
1189 Connolly G, Razak A, Conroy R, et al. A five year review of scar dehiscence in the Rotunda Hospital Dublin. Ir Med J. Jun. 2001;94(6):176-8. X-1. [pmid: 11495235].
1190 Connolly T. Thromboembolism prophylaxis and cesarean section: a survey of general obstetricians. South Med J. Feb. 2003;96(2):146-8. X-1. [pmid: 12630638].
1191 Connolly TJ, Litman HJ, Tennstedt SL, et al. The effect of mode of delivery, parity, and birth weight on risk of urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2007;18(9):1033-42. X-1. [pmid: 17219253].
1192 Conover WB, Moore TR. Comparison of irrigation and intravenous antibiotic prophylaxis at cesarean section. Obstet Gynecol. Jun. 1984;63(6):787-91. X-9. [pmid: 6374539].
1193 Constantine G, Beevers DG, Reynolds AL, et al. Nifedipine as a second line antihypertensive drug in pregnancy. Br J Obstet Gynaecol. Dec. 1987;94(12):1136-42. X-1. [pmid: 3426985].
1194 Contag SA, Clifton RG, Bloom SL, et al. Neonatal outcomes and operative vaginal delivery versus cesarean delivery. Am J Perinatol. Jun. 2010;27(6):493-9. X-4e, X-5. [pmid: 20099218].
1195 Contreras KR, Kominiarek MA, Zollinger TW. The impact of tobacco smoking on perinatal outcome among patients with gestational diabetes. J Perinatol. May. 2010;30(5):319-23. X-1. [pmid: 19907429].
1196 Contro E, Maroni E, Cera E, et al. Unilaterally increased uterine artery resistance, placental location and pregnancy outcome. Eur J Obstet Gynecol Reprod Biol. Dec. 2010;153(2):143-7. X-1. [pmid: 20667646].
1197 Conturso R, Valsecchi A, De Lalla F. Evaluation of mezlocillin versus placebo as a prophylactic agent in cesarean section. Chemioterapia. Jun. 1987;6(2 Suppl):611-3. X-4b. [pmid: 3334647].
1198 Conway DL, Adkins WB, Schroeder B, et al. Isolated oligohydramnios in the term pregnancy: is it a clinical entity?. J Matern Fetal Med. Jul-Aug. 1998;7(4):197-200. X-1. [pmid: 9730487].
1199 Cook MB, Graubard BI, Rubertone MV, et al. Perinatal factors and the risk of testicular germ cell tumors. Int J Cancer. Jun. 1. 2008;122(11):2600-6. X-1. [pmid: 18324625].
1200 Cook WP, Schultetus RR, Caton D. A comparison of d-tubocurarine pretreatment and no pretreatment in obstetric patients. Anesth Analg. Aug. 1987;66(8):756-60. X-9. [pmid: 3605694].
1201 Coombs DW, Danielson DR, Pageau MG, et al. Epidurally administered morphine for postcesarean analgesia. Surg Gynecol Obstet. Mar. 1982;154(3):385-8. X-9. [pmid: 7038945].
1202 Coonrod DV, Bay RC, Kishi GY. The epidemiology of labor induction: Arizona, 1997. Am J Obstet Gynecol. Jun. 2000;182(6):1355-62. X-1. [pmid: 10871449].
1203 Cooper DW, Carpenter M, Mowbray P, et al. Fetal and maternal effects of phenylephrine and ephedrine during spinal anesthesia for cesarean delivery. Anesthesiology. Dec. 2002;97(6):1582-90. X-9. [pmid: 12459688].
1204 Cooper DW, Garcia E, Mowbray P, et al. Patient-controlled epidural fentanyl following spinal fentanyl at Caesarean section. Anaesthesia. Mar. 2002;57(3):266-70. X-9. [pmid: 11892635].
1205 Cooper DW, Gibb SC, Meek T, et al. Effect of intravenous vasopressor on spread of spinal anaesthesia and fetal acid-base equilibrium. Br J Anaesth. May. 2007;98(5):649-56. X-9. [pmid: 17347185].
1206 Cooper DW, Jeyaraj L, Hynd R, et al. Evidence that intravenous vasopressors can affect rostral spread of spinal anesthesia in pregnancy. Anesthesiology. Jul. 2004;101(1):28-33. X-9. [pmid: 15220768].
1207 Cooper DW, Lindsay SL, Ryall DM, et al. Does intrathecal fentanyl produce acute cross-tolerance to i.v.morphine?. Br J Anaesth. Mar. 1997;78(3):311-3. X-9. [pmid: 9135312].
1208 Cooper DW, Ryall DM, Desira WR. Extradural fentanyl for postoperative analgesia: predominant spinal or systemic action?. Br J Anaesth. Feb. 1995;74(2):184-7. X-9. [pmid: 7696069].
1209 Cooper DW, Ryall DM, McHardy FE, et al. Patient-controlled extradural analgesia with bupivacaine, fentanyl, or a mixture of both, after Caesarean section. Br J Anaesth. May. 1996;76(5):611-5. X-9. [pmid: 8688256].
1210 Cooper DW, Saleh U, Taylor M, et al. Patient-controlled analgesia: epidural fentanyl and i.v. morphine compared after caesarean section. Br J Anaesth. Mar. 1999;82(3):366-70. X-9. [pmid: 10434817].
1211 Cooper ER, Nugent RP, Diaz C, et al. After AIDS clinical trial 076: the changing pattern of zidovudine use during pregnancy, and the subsequent reduction in the vertical transmission of human immunodeficiency virus in a cohort of infected women and their infants. Women and Infants Transmission Study Group. J Infect Dis. Dec. 1996;174(6):1207-11. X-1. [pmid: 8940210].
1212 Cooper GM, MacArthur C, Wilson MJ, et al. Satisfaction, control and pain relief: short- and long-term assessments in a randomised controlled trial of low-dose and traditional epidurals and a non-epidural comparison group. Int J Obstet Anesth. Jan. 2010;19(1):31-7. X-4e, X-5. [pmid: 19945274].
1213 Cooper JC, Sharkey AM, Charnock-Jones DS, et al. VEGF mRNA levels in placentae from pregnancies complicated by pre-eclampsia. Br J Obstet Gynaecol. Dec. 1996;103(12):1191-6. X-1. [pmid: 8968234].
1214 Cooper SC, Flaitz CM, Johnston DA, et al. A natural history of cleidocranial dysplasia. Am J Med Genet. Nov. 15. 2001;104(1):1-6. X-1. [pmid: 11746020].
1215 Coppejans HC, Hendrickx E, Goossens J, et al. The sitting versus right lateral position during combined spinal-epidural anesthesia for cesarean delivery: block characteristics and severity of hypotension. Anesth Analg. Jan. 2006;102(1):243-7. X-9. [pmid: 16368837].
1216 Coppejans HC, Vercauteren MP. Low-dose combined spinal-epidural anesthesia for cesarean delivery: a comparison of three plain local anesthetics. Acta Anaesthesiol Belg. 2006;57(1):39-43. X-9. [pmid: 16617756].
1217 Cordeaux Y, Tattersall M, Charnock-Jones DS, et al. Effects of medroxyprogesterone acetate on gene expression in myometrial explants from pregnant women. J Clin Endocrinol Metab. Dec. 2010;95(12):E437-47. X-1. [pmid: 20843944].
1218 Cordero L, Nankervis CA, Gardner D, et al. The effects of indomethacin tocolysis on the postnatal response of the ductus arteriosus to indomethacin in extremely low birth weight infants. J Perinatol. Jan. 2007;27(1):22-7. X-1. [pmid: 17053778].
1219 Corke BC, Datta S, Ostheimer GW, et al. Spinal anaesthesia for Caesarean section. The influence of hypotension on neonatal outcome. Anaesthesia. Jun. 1982;37(6):658-62. X-1. [pmid: 7091625].
1220 Cornes H, Bartolo DC, Stirrat GM. Changes in anal canal sensation after childbirth. Br J Surg. Jan. 1991;78(1):74-7. X-1. [pmid: 1998871].
1221 Cornet D, Antoine JM, Casanova S, et al. Obstetric evolution of pregnancies obtained from donated oocytes. Fetal Diagn Ther. 1992;7(1):31-5. X-1. [pmid: 1610500].
1222 Coronado GD, Marshall LM, Schwartz SM. Complications in pregnancy, labor, and delivery with uterine leiomyomas: a population-based study. Obstet Gynecol. May. 2000;95(5):764-9. X-1. [pmid: 10775744].
1223 Corrado F, Benedetto AD, Cannata ML, et al. A single abnormal value of the glucose tolerance test is related to increased adverse perinatal outcome. J Matern Fetal Neonatal Med. Jul. 2009;22(7):597-601. X-1. [pmid: 19488948].
1224 Correia-Pinto J, Reis JL, Hutchins GM, et al. In utero meconium exposure increases spinal cord necrosis in a rat model of myelomeningocele. J Pediatr Surg. Mar. 2002;37(3):488-92. X-1. [pmid: 11877673].
1225 Corriveau S, Rousseau E, Berthiaume M, et al. Lipoxygenase and cyclooxygenase inhibitors reveal a complementary role of arachidonic acid derivatives in pregnant human myometrium. Am J Obstet Gynecol. Sep. 2010;203(3):266 e1-7. X-1. [pmid: 20684944].
1226 Costakos DT, Love LA, Kirby RS. The computerized perinatal database: are the data reliable?. Am J Perinatol. Jul. 1998;15(7):453-9. X-1. [pmid: 9759914].
1227 Costello JF, Moore AR, Wieczorek PM, et al. The transversus abdominis plane block, when used as part of a multimodal regimen inclusive of intrathecal morphine, does not improve analgesia after cesarean delivery. Reg Anesth Pain Med. Nov-Dec. 2009;34(6):586-9. X-9. [pmid: 19916252].
1228 Cotter AM, O'Sullivan MJ. Update on managing HIV in pregnancy. Contemporary OB/GYN. 2004;49(11):57. X-4b.
1229 Cotzias CS, Paterson-Brown S, Fisk NM. Obstetricians say yes to maternal request for elective caesarean section: a survey of current opinion. Eur J Obstet Gynecol Reprod Biol. Jul. 2001;97(1):15-6. X-1. [pmid: 11435000].
1230 Coulter CH, Lehrfeld R. When push comes to shove: implementing VBAC practice guidelines. Physician Exec. Jun. 1995;21(6):30-5. X-1. [pmid: 10161334].
1231 Courtney MA, Bader AM, Hartwell B, et al. Perioperative analgesia with subarachnoid sufentanil administration. Reg Anesth. Sep-Oct. 1992;17(5):274-8. X-9. [pmid: 1419940].
1232 Coutinho IC, Ramos de Amorim MM, Katz L, et al. Uterine exteriorization compared with in situ repair at cesarean delivery: a randomized controlled trial. Obstet Gynecol. Mar. 2008;111(3):639-47. X-9. [pmid: 18310366].
1233 Coutinho PR, Cecatti JG, Surita FG, et al. Factors associated with low birth weight in a historical series of deliveries in Campinas, Brazil. Rev Assoc Med Bras. Nov-Dec. 2009;55(6):692-9. X-1. [pmid: 20191223].
1234 Couto RC, Pedrosa TM, Nogueira JM, et al. Post-discharge surveillance and infection rates in obstetric patients. Int J Gynaecol Obstet. Jun. 1998;61(3):227-31. X-1. [pmid: 9688482].
1235 Cowan CM, Kendall JB, Barclay PM, et al. Comparison of intrathecal fentanyl and diamorphine in addition to bupivacaine for caesarean section under spinal anaesthesia. Br J Anaesth. Sep. 2002;89(3):452-8. X-9. [pmid: 12402725].
1236 Cowley E, Thompson JP, Sharpe P, et al. Effects of pre-eclampsia on maternal plasma, cerebrospinal fluid, and umbilical cord urotensin II concentrations: a pilot study. Br J Anaesth. Oct. 2005;95(4):495-9. X-1. [pmid: 16126783].
1237 Crane JM, Delaney T, Butt KD, et al. Predictors of successful labor induction with oral or vaginal misoprostol. J Matern Fetal Neonatal Med. May. 2004;15(5):319-23. X-1. [pmid: 15280123].
1238 Crane JM, Hutchens D. Use of transvaginal ultrasonography to predict preterm birth in women with a history of preterm birth. Ultrasound Obstet Gynecol. Oct. 2008;32(5):640-5. X-1. [pmid: 18816494].
1239 Crane SS, Wojtowycz MA, Dye TD, et al. Association between pre-pregnancy obesity and the risk of cesarean delivery. Obstet Gynecol. Feb. 1997;89(2):213-6. X-1. [pmid: 9015022].
1240 Cranley MS, Hedahl K, Pegg SH. Women's perception of vaginal and cesarean deliveries. Nursing Research. 1983;32(1):10-15. X-1, X-3, X-4e, X-5. [pmid: 6549836].
1241 Craver Pryor E, Mertz HL, Beaver BW, et al. Intrapartum predictors of uterine rupture. Am J Perinatol. May. 2007;24(5):317-21. X-1. [pmid: 17516310].
1242 Crawford JS. Premedication for elective Caesarean section. Anaesthesia. Oct. 1979;34(9):892-7. X-9. [pmid: 43682].
1243 Crawford JS. Experiences with epidural morphine in obstetrics. Anaesthesia. Feb. 1981;36(2):207-9. X-1, X-3, X-4b, X-5. [pmid: 7011087].
1244 Crawford JS, Lewis M, Davies P. Maternal and neonatal responses related to the volatile agent used to maintain anaesthesia at caesarean section. Br J Anaesth. May. 1985;57(5):482-7. X-9. [pmid: 3994881].
1245 Crawford ME, Carl P, Bach V, et al. A randomized comparison between midazolam and thiopental for elective cesarean section anesthesia. I Mothers Anesth Analg. Mar. 1989;68(3):229-33. X-9.
1246 Creatsas G, Pavlatos M, Lolis D, et al. Ampicillin and gemtamicin in the treatment of fetal intrauterine infections. J Perinat Med. 1980;8(1):13-8. X-1. [pmid: 7365666].
1247 Creedy DK, Noy DL. Postdischarge surveillance after cesarean section. Birth. Dec. 2001;28(4):264-9. X-1. [pmid: 11903215].
1248 Critchlow CW, Leet TL, Benedetti TJ, et al. Risk factors and infant outcomes associated with umbilical cord prolapse: a population-based case-control study among births in Washington State. Am J Obstet Gynecol. Feb. 1994;170(2):613-8. X-1. [pmid: 8116723].
1249 Crochetiere CT, Trepanier CA, Cote JJ. Epidural anaesthesia for caesarean section: comparison of two injection techniques. Can J Anaesth. Mar. 1989;36(2):133-6. X-9. [pmid: 2650896].
1250 Crombleholme WR, Green JR, Ohm-Smith M, et al. Cesarean section prophylaxis: comparison of two doses with three doses of mezlocillin. Am J Reprod Immunol Microbiol. Mar. 1987;13(3):71-5. X-9. [pmid: 3300383].
1251 Crombleholme WR, Green JR, Ohm-Smith M, et al. Prophylaxis in caesarean section with cefmetazole and cefoxitin. J Antimicrob Chemother. Apr. Suppl D. 1989;23:97-104. X-9. [pmid: 2722729].
1252 Cromi A, Ghezzi F, Di Naro E, et al. Blunt expansion of the low transverse uterine incision at cesarean delivery: a randomized comparison of 2 techniques. Am J Obstet Gynecol. Sep. 2008;199(3):292 e1-6. X-9. [pmid: 18771988].
1253 Crone LA, Conly JM, Storgard C, et al. Herpes labialis in parturients receiving epidural morphine following cesarean section. Anesthesiology. Aug. 1990;73(2):208-13. X-9. [pmid: 2166452].
1254 Cronje HS, van der Westhuizen A. Coupling of uterine contractions during labor: a pilot study. Int J Gynaecol Obstet. Aug. 1988;27(1):69-72. X-1. [pmid: 2905301].
1255 Cronk M. What happened to the midwife in the case of the woman forced to have a caesarean. Nurs Times. May. 20-26. 1998;94(20):18. X-1, X-2, X-4e. [pmid: 9661457].
1256 Crosby E, Sandler A, Finucane B, et al. Comparison of epidural anaesthesia with ropivacaine 0.5% and bupivacaine 0.5% for caesarean section. Can J Anaesth. Nov. 1998;45(11):1066-71. X-9. [pmid: 10021954].
1257 Crosby ET, Bryson GL, Elliott RD, et al. Epidural sufentanil does not attenuate the central haemodynamic effects of caesarean section performed under epidural anaesthesia. Can J Anaesth. Mar. 1994;41(3):192-7. X-9. [pmid: 8187255].
1258 Crosby ET, Elliott RD. Anaesthesia for caesarean section in a parturient with quintuplet gestation, pulmonary oedema and thrombocytopaenia. Can J Anaesth. Jul. 1988;35(4):417-21. X-1, X-2. [pmid: 3402018].
1259 Crosby ET, Halpern SH. Supplemental maternal oxygen therapy during caesarean section under epidural anaesthesia: a comparison of nasal prongs and facemask. Can J Anaesth. Apr. 1992;39(4):313-6. X-9. [pmid: 1563054].
1260 Crosby ET, Halpern SH, Rolbin SH. Epidural anaesthesia and herpes genitalis. Infection Control Canada. 1990;5(1):10-13. X-1.
1261 Cross LL, Meythaler JM, Tuel SM, et al. Pregnancy, labor and delivery post spinal cord injury. Paraplegia. Dec. 1992;30(12):890-902. X-1, X-2. [pmid: 1287543].
1262 Croughan-Minihane MS, Petitti DB, Gordis L, et al. Morbidity among breech infants according to method of delivery. Obstet Gynecol. May. 1990;75(5):821-5. X-1. [pmid: 2325965].
1263 Crovella S, Bernardon M, Braida L, et al. Italian multicentric pilot study on MBL2 genetic polymorphisms in HIV positive pregnant women and their children. J Matern Fetal Neonatal Med. Apr. 2005;17(4):253-6. X-1. [pmid: 16152689].
1264 Crowhurst JA, Rosen M. General anaesthesia for caesarean section in severe pre-eclampsia. Comparison of the renal and hepatic effects of enflurane and halothane. Br J Anaesth. Jun. 1984;56(6):587-97. X-9. [pmid: 6721970].
1265 Crowther CA. Management and pregnancy outcome in eclampsia at Harare Maternity Hospital. Cent Afr J Med. Jun. 1985;31(6):107-9. X-1, X-4e, X-5. [pmid: 4042145].
1266 Crowther CA. Caesarean delivery for the second twin. Cochrane Database of Systematic Reviews. 1996;(1). X-1, X-2.
1267 Crowther CA, Hiller JE, Moss JR, et al. Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. Jun. 16. 2005;352(24):2477-86. X-4e. [pmid: 15951574].
1268 Crowther ME. Perinatal death: worse obstetric and neonatal outcome in a subsequent pregnancy. J R Army Med Corps. Jun. 1995;141(2):92-7. X-1. [pmid: 7562745].
1269 Cruickshank ME, Flannelly G, Campbell DM, et al. Fertility and pregnancy outcome following large loop excision of the cervical transformation zone. Br J Obstet Gynaecol. Jun. 1995;102(6):467-70. X-1. [pmid: 7632638].
1270 Cruz ML, Cardoso CA, Joao EC, et al. Pregnancy in HIV vertically infected adolescents and young women: a new generation of HIV-exposed infants. AIDS. Nov. 13. 2010;24(17):2727-31. X-1. [pmid: 20827164].
1271 Cruz-Martinez R, Figueras F, Hernandez-Andrade E, et al. Fetal brain Doppler to predict cesarean delivery for nonreassuring fetal status in term small-for-gestational-age fetuses. Obstet Gynecol. Mar. 2011;117(3):618-26. X-1. [pmid: 21343765].
1272 Csitari IK, Pasztuhov A, Laszlo A. The reliability of fetal pulse oximetry: the effect of fetal oxygen saturation below 30% on perinatal outcome. Eur J Obstet Gynecol Reprod Biol. Feb. 2008;136(2):160-4. X-1. [pmid: 17467877].
1273 Cui T, Liu Y, Men X, et al. Bile acid transport correlative protein mRNA expression profile in human placenta with intrahepatic cholestasis of pregnancy. Saudi Med J. Nov. 2009;30(11):1406-10. X-1. [pmid: 19882051].
1274 Culebras X, Gaggero G, Zatloukal J, et al. Advantages of intrathecal nalbuphine, compared with intrathecal morphine, after cesarean delivery: an evaluation of postoperative analgesia and adverse effects. Anesth Analg. Sep. 2000;91(3):601-5. X-9. [pmid: 10960384].
1275 Culver J, Strauss RA, Brody S, et al. A randomized trial comparing vaginal misoprostol versus Foley catheter with concurrent oxytocin for labor induction in nulliparous women. Am J Perinatol. Apr. 2004;21(3):139-46. X-4d. [pmid: 15085496].
1276 Cummiskey KC, Dawood MY. Induction of labor with pulsatile oxytocin. Am J Obstet Gynecol. Dec. 1990;163(6 Pt 1):1868-74. X-4d, X-5. [pmid: 2256497].
1277 Cummiskey KC, Gall SA, Dawood MY. Pulsatile administration of oxytocin for augmentation of labor. Obstet Gynecol. Dec. 1989;74(6):869-72. X-4d, X-4e. [pmid: 2685676].
1278 Cundy T, Slee F, Gamble G, et al. Hypertensive disorders of pregnancy in women with Type 1 and Type 2 diabetes. Diabet Med. Jun. 2002;19(6):482-9. X-1. [pmid: 12060060].
1279 Cunningham FG, Cox K, Hauth JC, et al. Oral prostaglandin E2 for labor induction in high-risk pregnancy. Am J Obstet Gynecol. Aug. 1. 1976;125(7):881-8. X-1, X-3, X-4d, X-4e, X-5. [pmid: 941942].
1280 Cunningham FG, Gilstrap LC 3rd, Kappus SS. Cefamandole for treatment of obstetrical and gynecological infections. Scand J Infect Dis Suppl. suppl 25. 1980:75-82. X-1. [pmid: 7010540].
1281 Cunningham FG, Hauth JC, Strong JD, et al. Infectious morbidity following cesarean section. Comparison of two treatment regimens. Obstet Gynecol. Dec. 1978;52(6):656-61. X-9. [pmid: 733132].
1282 Cunningham ITS, Cushen AM, Healy S, et al. An audit of thromboprophylaxis provision in obstetrics and gynaecology. Health Bulletin. 1998;56(2):561-564. X-1.
1283 Curet LB, Gauger LJ. Cervical ripening with intravaginal prostaglandin E2 gel. Int J Gynaecol Obstet. Mar. 1989;28(3):221-8. X-4d. [pmid: 2564351].
1284 Currier JS, Tosteson TD, Platt R. Cefazolin compared with cefoxitin for cesarean section prophylaxis: the use of a two-stage study design. J Clin Epidemiol. Jul. 1993;46(7):625-30. X-1. [pmid: 8326347].
1285 Curtin SC, Martin JA. Births: preliminary data for 1999. Natl Vital Stat Rep. Aug. 8. 2000;48(14):1-20. X-1.
1286 Curtis SL, Marsden-Williams J, Sullivan C, et al. Current trends in the management of heart disease in pregnancy. Int J Cardiol. Mar. 20. 2009;133(1):62-9. X-1. [pmid: 18242740].
1287 Cuttini M, Habiba M, Nilstun T, et al. Patient refusal of emergency cesarean delivery: a study of obstetricians' attitudes in Europe. Obstet Gynecol. Nov. 2006;108(5):1121-9. X-1. [pmid: 17077233].
1288 Cypryk K, Sobczak M, Pertynska-Marczewska M, et al. Pregnancy complications and perinatal outcome in diabetic women treated with Humalog (insulin lispro) or regular human insulin during pregnancy. Med Sci Monit. Feb. 2004;10(2):PI29-32. X-1, X-4e. [pmid: 14737056].
1289 da Graca Krupa F, Cecatti JG, de Castro Surita FG, et al. Misoprostol versus expectant management in premature rupture of membranes at term. BJOG. Sep. 2005;112(9):1284-90. X-4e. [pmid: 16101609].
1290 Dabelea V, Schultze PM, McDuffie RS Jr. Intrauterine balloon tamponade in the management of postpartum hemorrhage. Am J Perinatol. Jun. 2007;24(6):359-64. X-1. [pmid: 17566947].
1291 Dadkhah F, Kashanian M, Eliasi G. A comparison between the pregnancy outcome in women both with or without threatened abortion. Early Hum Dev. Mar. 2010;86(3):193-6. X-1. [pmid: 20231080].
1292 Dafallah SE, Elhag SM. The role of external cephalic version on the presentation at delivery. Saudi Med J. Mar. 2004;25(3):386-8. X-4c, X-4e, X-5. [pmid: 15048186].
1293 Dahl J, Myhr KM, Daltveit AK, et al. Planned vaginal births in women with multiple sclerosis: delivery and birth outcome. Acta Neurol Scand Suppl. 2006;183:51-4. X-1. [pmid: 16637930].
1294 Dahlgren G, Granath F, Wessel H, et al. Prediction of hypotension during spinal anesthesia for Cesarean section and its relation to the effect of crystalloid or colloid preload. Int J Obstet Anesth. Apr. 2007;16(2):128-34. X-9. [pmid: 17276668].
1295 Dahlgren G, Hultstrand C, Jakobsson J, et al. Intrathecal sufentanil, fentanyl, or placebo added to bupivacaine for cesarean section. Anesth Analg. Dec. 1997;85(6):1288-93. X-9. [pmid: 9390596].
1296 Dahlquist GG, Patterson C, Soltesz G. Perinatal risk factors for childhood type 1 diabetes in Europe. The EURODIAB Substudy 2 Study Group. Diabetes Care. Oct. 1999;22(10):1698-702. X-1. [pmid: 10526738].
1297 Dalby PL, Ramanathan S, Rudy TE, et al. Plasma and saliva substance P levels: the effects of acute pain in pregnant and non-pregnant women. Pain. Feb. 1997;69(3):263-7. X-1. [pmid: 9085300].
1298 Dale E, Mullinax KM, Bryan DH. Exercise during pregnancy: effects on the fetus. Can J Appl Sport Sci. Jun. 1982;7(2):98-103. X-1. [pmid: 7105378].
1299 Daley MD, Sandler AN, Turner KE, et al. A comparison of epidural and intramuscular morphine in patients following cesarean section. Anesthesiology. Feb. 1990;72(2):289-94. X-9. [pmid: 2405743].
1300 Dallenbach P, Boulvain M, Viardot C, et al. Oral misoprostol or vaginal dinoprostone for labor induction: a randomized controlled trial. Am J Obstet Gynecol. Jan. 2003;188(1):162-7. X-4d. [pmid: 12548212].
1301 Dalrymple A, Mahn K, Poston L, et al. Mechanical stretch regulates TRPC expression and calcium entry in human myometrial smooth muscle cells. Mol Hum Reprod. Mar. 2007;13(3):171-9. X-1. [pmid: 17208928].
1302 Dalrymple JL, Gilbert WM, Leiserowitz GS, et al. Pregnancy-associated cervical cancer: obstetric outcomes. J Matern Fetal Neonatal Med. Apr. 2005;17(4):269-76. X-1. [pmid: 16147836].
1303 Daltveit AK, Vollset SE, Skjaerven R, et al. Impact of multiple births and elective deliveries on the trends in low birth weight in Norway, 1967-1995. Am J Epidemiol. Jun. 15. 1999;149(12):1128-33. X-1. [pmid: 10369507].
1304 Danelli G, Fanelli G, Berti M, et al. Spinal ropivacaine or bupivacaine for cesarean delivery: a prospective, randomized, double-blind comparison. Reg Anesth Pain Med. May-Jun. 2004;29(3):221-6. X-9. [pmid: 15138906].
1305 Danelli G, Zangrillo A, Nucera D, et al. The minimum effective dose of 0.5% hyperbaric spinal bupivacaine for cesarean section. Minerva Anestesiol. Jul-Aug. 2001;67(7-8):573-7. X-9. [pmid: 11602876].
1306 Danerek M, Marsal K, Cuttini M, et al. Attitudes of midwives in Sweden toward a woman's refusal of an emergency cesarean section or a cesarean section on request. Birth. Mar. 2011;38(1):71-9. X-1. [pmid: 21332777].
1307 Daneshmand SS, Chmait RH, Moore TR, et al. Preterm premature rupture of membranes: vascular endothelial growth factor and its association with histologic chorioamnionitis. Am J Obstet Gynecol. Nov. 2002;187(5):1131-6. X-1. [pmid: 12439490].
1308 D'Angelo LJ, Sokol RJ. Short- versus long-course prophylactic antibiotic treatment in Cesarean section patients. Obstet Gynecol. May. 1980;55(5):583-6. X-9. [pmid: 6988748].
1309 D'Angelo R, Berkebile BL, Gerancher JC. Prospective examination of epidural catheter insertion. Anesthesiology. Jan. 1996;84(1):88-93. X-4e, X-5. [pmid: 8572359].
1310 Dani C, Reali MF, Bertini G, et al. Risk factors for the development of respiratory distress syndrome and transient tachypnoea in newborn infants. Italian Group of Neonatal Pneumology. Eur Respir J. Jul. 1999;14(1):155-9. X-1. [pmid: 10489844].
1311 Dani C, Reali MF, Oliveto R, et al. Short-term outcome of newborn infants born by a modified procedure of cesarean section. A prospective randomized study. Acta Obstet Gynecol Scand. Oct. 1998;77(9):929-31. X-9. [pmid: 9808382].
1312 Daniel L. Consortium aims to raise standard of health care in Malawi. British Journal of Midwifery. 2006;14(5):259-259. X-1.
1313 Daniel L. Trauma surgeons to teach life-saving procedures to Somali health workers. British Journal of Midwifery. 2010;18(5):319-319. X-1.
1314 Daniel Y, Ochshorn Y, Fait G, et al. Analysis of 104 twin pregnancies conceived with assisted reproductive technologies and 193 spontaneously conceived twin pregnancies. Fertil Steril. Oct. 2000;74(4):683-9. X-1. [pmid: 11020507].
1315 Daniels JA. Court-ordered cesareans: a growing concern for indigent women. Clgh Rev. Feb. 1988;21(9):1064-71. X-1. [pmid: 11649972].
1316 Daniel-Spiegel E, Weiner Z, Ben-Shlomo I, et al. For how long should oxytocin be continued during induction of labour?. BJOG. Apr. 2004;111(4):331-4. X-4d. [pmid: 15008768].
1317 Danielsson AJ, Nachemson AL. Childbearing, curve progression, and sexual function in women 22 years after treatment for adolescent idiopathic scoliosis a case control study. Spine (Phila Pa 1976). Jul. 1. 2001;26(13):1449-56. X-1. [pmid: 11458150].
1318 Danishevski K, Balabanova D, McKee M, et al. Delivering babies in a time of transition in Tula, Russia. Health Policy Plan. May. 2006;21(3):195-205. X-1. [pmid: 16492726].
1319 Dann WL, Hutchinson A, Cartwright DP. Maternal and neonatal responses to alfentanil administered before induction of general anaesthesia for caesarean section. Br J Anaesth. Nov. 1987;59(11):1392-6. X-9. [pmid: 3120764].
1320 Danon D, Ben-Haroush A, Yogev Y, et al. Prostaglandin E2 induction of labor for isolated oligohydramnios in women with unfavorable cervix at term. Fetal Diagn Ther. 2007;22(1):75-9. X-1. [pmid: 17003561].
1321 Dansereau J, Joshi AK, Helewa ME, et al. Double-blind comparison of carbetocin versus oxytocin in prevention of uterine atony after cesarean section. Am J Obstet Gynecol. Mar. 1999;180(3 Pt 1):670-6. X-9. [pmid: 10076146].
1322 Danzer BI, Birnbach DJ, Stein DJ, et al. Does metoclopramide supplement postoperative analgesia using patient-controlled analgesia with morphine in patients undergoing elective cesarean delivery?. Reg Anesth. Sep-Oct. 1997;22(5):424-7. X-9. [pmid: 9338902].
1323 Daponte A, Guidozzi F, Moisuc D, et al. Management of diabetic pregnant patients in a tertiary center in the developing world. Int J Gynaecol Obstet. Feb. 1999;64(2):141-6. X-1. [pmid: 10189022].
1324 Dare FO, Oboro VO. Risk factors of placenta accreta in Ile-Ife, Nigeria. Niger Postgrad Med J. Mar. 2003;10(1):42-5. X-1. [pmid: 12717464].
1325 Darj E, Nordstrom ML. The Misgav Ladach method for cesarean section compared to the Pfannenstiel method. Acta Obstet Gynecol Scand. Jan. 1999;78(1):37-41. X-9. [pmid: 9926890].
1326 Darlow BA, Mogridge N, Horwood LJ, et al. Admission of all gestations to a regional neonatal unit versus controls: neonatal morbidity. J Paediatr Child Health. Apr. 2009;45(4):181-6. X-1. [pmid: 19426376].
1327 Darroca RJ, Buttino L Jr., Miller J, et al. Prostaglandin E2 gel for cervical ripening in patients with an indication for delivery. Obstet Gynecol. Feb. 1996;87(2):228-30. X-4d. [pmid: 8559529].
1328 Das AK, Jana N, Dasgupta S, et al. Intrapartum transcervical amnioinfusion for meconium-stained amniotic fluid. Int J Gynaecol Obstet. Jun. 2007;97(3):182-6. X-1. [pmid: 17368644].
1329 Das BN, Biswas AK. Ligation of internal iliac arteries in pelvic haemorrhage. J Obstet Gynaecol Res. Aug. 1998;24(4):251-4. X-1. [pmid: 9798353].
1330 das Neves JF, Monteiro GA, de Almeida JR, et al. Phenylephrine for blood pressure control in elective cesarean section: therapeutic versus prophylactic doses. Rev Bras Anestesiol. Jul-Aug. 2010;60(4):391-8. X-9. [pmid: 20659611].
1331 Dashe JS, Nathan L, McIntire DD, et al. Correlation between amniotic fluid glucose concentration and amniotic fluid volume in pregnancy complicated by diabetes. Am J Obstet Gynecol. Apr. 2000;182(4):901-4. X-1. [pmid: 10764470].
1332 Dashow EE, Read JA, Coleman FH. Randomized comparison of five irrigation solutions at cesarean section. Obstet Gynecol. Oct. 1986;68(4):473-8. X-9. [pmid: 3748494].
1333 Daskalakis GJ, Mesogitis SA, Papantoniou NE, et al. Misoprostol for second trimester pregnancy termination in women with prior caesarean section. BJOG. Jan. 2005;112(1):97-9. X-1. [pmid: 15663405].
1334 Datta S, Camann W, Bader A, et al. Clinical effects and maternal and fetal plasma concentrations of epidural ropivacaine versus bupivacaine for cesarean section. Anesthesiology. Jun. 1995;82(6):1346-52. X-9. [pmid: 7793647].
1335 Datta S, Kitzmiller JL, Naulty JS, et al. Acid-base status of diabetic mothers and their infants following spinal anesthesia for cesarean section. Anesth Analg. Aug. 1982;61(8):662-5. X-1. [pmid: 7201269].
1336 Datta S, Murphy MT, Carr DB, et al. Maternal and fetal plasma atrial natriuretic peptide concentrations during elective caesarean section. Acta Anaesthesiol Scand. Feb. 1991;35(2):93-6. X-1. [pmid: 1827231].
1337 Davey DA, Macnab M. Oral and intravaginal prostaglandin E2 for cervical ripening and induction of labour. S Afr Med J. May. 19. 1979;55(21):837-42. X-3, X-4d, X-4e, X-5. [pmid: 472913].
1338 David M, Gross MM, Wiemer A, et al. Prior cesarean section--an acceptable risk for vaginal delivery at free-standing midwife-led birth centers? Results of the analysis of vaginal birth after cesarean section (VBAC) in German birth centers. Eur J Obstet Gynecol Reprod Biol. Feb. 2009;142(2):106-10. X-1. [pmid: 19042076].
1339 David M, Halle H, Lichtenegger W, et al. Nitroglycerin to facilitate fetal extraction during cesarean delivery. Obstet Gynecol. Jan. 1998;91(1):119-24. X-9. [pmid: 9464734].
1340 David S, Mamelle N, Riviere O. Estimation of an expected caesarean section rate taking into account the case mix of a maternity hospital. Analysis from the AUDIPOG Sentinelle Network (France). Obstetricians of AUDIPOG. Association of Users of Computerised Files in Perinatalogy, Obstetrics and Gynaecology. BJOG. Sep. 2001;108(9):919-26. X-1. [pmid: 11563460].
1341 Davies GA, Hahn PM, McGrath MM. Vaginal birth after cesarean. Physicians' perceptions and practice. J Reprod Med. Jul. 1996;41(7):515-20. X-1. [pmid: 8829065].
1342 Davies HA, Dalton KJ, Clark JD, et al. Computerized and telemetric management of diabetic pregnancy in Cambridge. J Perinat Med. 1988;16(4):381-9. X-1. [pmid: 3221297].
1343 Davies J, Hey E, Reid W, et al. Prospective regional study of planned home births. Home Birth Study Steering Group. BMJ. Nov. 23. 1996;313(7068):1302-6. X-1. [pmid: 8942691].
1344 Davies JR. Ineffective transcutaneous nerve stimulation following epidural anaesthesia. Anaesthesia. Apr. 1982;37(4):453-4. X-9. [pmid: 6979269].
1345 Davies P, French GW. A randomised trial comparing 5 mL/kg and 10 mL/kg of pentastarch as a volume preload before spinal anaesthesia for elective caesarean section. Int J Obstet Anesth. Oct. 2006;15(4):279-83. X-9. [pmid: 16945514].
1346 Davies SJ, Paech MJ, Welch H, et al. Maternal experience during epidural or combined spinal-epidural anesthesia for cesarean section: a prospective, randomized trial. Anesth Analg. Sep. 1997;85(3):607-13. X-9. [pmid: 9296417].
1347 Davis B, Bond D, Howat P, et al. Maternal and neonatal outcomes following diabetes in pregnancy in Far North Queensland, Australia. Aust N Z J Obstet Gynaecol. Aug. 2009;49(4):393-9. X-1. [pmid: 19694694].
1348 Davis CD. Forced fetal protection creates legal, moral dilemmas. Healthtexas. Jun. 1990;46(1):18-9. X-1.
1349 Davis KM, Esposito MA, Meyer BA. Oral analgesia compared with intravenous patient-controlled analgesia for pain after cesarean delivery: a randomized controlled trial. Am J Obstet Gynecol. Apr. 2006;194(4):967-71. X-9. [pmid: 16580284].
1350 Davis LG, Riedmann GL, Sapiro M, et al. Cesarean section rates in low-risk private patients managed by certified nurse-midwives and obstetricians. J Nurse Midwifery. Mar-Apr. 1994;39(2):91-7. X-1. [pmid: 8027851].
1351 Davis-Floyd R. La partera profesional: articulating identity and cultural space for a new kind of midwife in Mexico. Med Anthropol. 2001;20(2-3):185-243. X-1, X-2. [pmid: 11817855].
1352 Davis-Floyd RE. The role of obstetrical rituals in the resolution of cultural anomaly. Soc Sci Med. 1990;31(2):175-89. X-1, X-2. [pmid: 2389154].
1353 Daviss BA, Johnson KC, Lalonde AB. Evolving evidence since the term breech trial: Canadian response, European dissent, and potential solutions. J Obstet Gynaecol Can. Mar. 2010;32(3):217-24. X-1. [pmid: 20500965].
1354 Dawson A, Cohen D, Candelier C, et al. Domiciliary midwifery support in high-risk pregnancy incorporating telephonic fetal heart rate monitoring: a health technology randomized assessment. J Telemed Telecare. 1999;5(4):220-30. X-4e. [pmid: 10829372].
1355 Dawson TB. Re Baby R: a comment on fetal apprehension. Can J Women Law. 1990;4(1):265-75. X-1. [pmid: 11649295].
1356 Dawson TB. A feminist response to ‘Unborn child abuse: contemplating legal solution. Can J Fam Law. Spring. 1991;9(2):157-76. X-1, X-2. [pmid: 11656495].
1357 De A, Bagga R, Gopalan S. The routine use of oxytocin after oral misoprostol for labour induction in women with an unfavourable cervix is not of benefit. Aust N Z J Obstet Gynaecol. Aug. 2006;46(4):323-9. X-4d. [pmid: 16866794].
1358 de Almeida MF, Guinsburg R, da Costa JO, et al. Non-urgent caesarean delivery increases the need for ventilation at birth in term newborn infants. Arch Dis Child Fetal Neonatal Ed. Sep. 2010;95(5):F326-30. X-1. [pmid: 20584803].
1359 de Almeida MF, Guinsburg R, da Costa JO, et al. Resuscitative procedures at birth in late preterm infants. J Perinatol. Dec. 2007;27(12):761-5. X-1. [pmid: 18034164].
1360 de Aquino MM, Cecatti JG. Misoprostol versus oxytocin for labor induction in term and post-term pregnancy: randomized controlled trial. Sao Paulo Med J. May. 5. 2003;121(3):102-6. X-4d. [pmid: 12920470].
1361 de Boer CN, Thornton JG. Prophylactic short course rectal metronidazole for cesarean section. A double-blind controlled trial of a simple low cost regimen. Int J Gynaecol Obstet. Feb. 1989;28(2):103-7. X-9. [pmid: 2563695].
1362 De Catte L, De Wolf D, Smitz J, et al. Fetal hypothyroidism as a complication of amiodarone treatment for persistent fetal supraventricular tachycardia. Prenat Diagn. Aug. 1994;14(8):762-5. X-1, X-2. [pmid: 7991517].
1363 de Heus R, Mulder EJ, Derks JB, et al. A prospective randomized trial of acute tocolysis in term labour with atosiban or ritodrine. Eur J Obstet Gynecol Reprod Biol. Aug. 2008;139(2):139-45. X-4e, X-5. [pmid: 18316155].
1364 de Jong P. Trial of labor following cesarean section--a study of 212 patients. Int J Gynaecol Obstet. Oct. 1987;25(5):405-11. X-1, X-4b, X-5. [pmid: 2889636].
1365 de la Torre S, Gilson GJ, Flores S, et al. Is high-dose misoprostol able to lower the incidence of cesarean section? A randomized controlled trial. J Matern Fetal Med. Apr. 2001;10(2):85-90. X-4d, X-5. [pmid: 11392598].
1366 de Leon-Casasola OA, Lema MJ, Emrich L, et al. Continuous 2-chloroprocaine infusion versus intermittent bolus injections of bupivacaine or 2-chloroprocaine for epidural anesthesia in cesarean delivery. Reg Anesth. May-Jun. 1991;16(3):154-60. X-9. [pmid: 1883773].
1367 De Meeus JB, D'Halluin G, Bascou V, et al. Prophylactic intrapartum amnioinfusion: a controlled retrospective study of 135 cases. Eur J Obstet Gynecol Reprod Biol. Apr. 1997;72(2):141-8. X-1. [pmid: 9134392].
1368 de Muylder X, de Wals P. Poor acceptance of caesarean section in Zimbabwe. Trop Geogr Med. Jul. 1989;41(3):230-3. X-1. [pmid: 2595801].
1369 De Simone CA, Leighton BL, Norris MC. Spinal anesthesia for cesarean delivery. A comparison of two doses of hyperbaric bupivacaine. Reg Anesth. Mar-Apr. 1995;20(2):90-4. X-9. [pmid: 7605770].
1370 De Sutter P, Bontinck J, Schutysers V, et al. First-trimester bleeding and pregnancy outcome in singletons after assisted reproduction. Hum Reprod. Jul. 2006;21(7):1907-11. X-1. [pmid: 16501033].
1371 De Sutter P, Veldeman L, Kok P, et al. Comparison of outcome of pregnancy after intra-uterine insemination (IUI) and IVF. Hum Reprod. Jun. 2005;20(6):1642-6. X-1. [pmid: 15790611].
1372 de Veciana M, Major CA, Morgan MA, et al. Postprandial versus preprandial blood glucose monitoring in women with gestational diabetes mellitus requiring insulin therapy. N Engl J Med. Nov. 9. 1995;333(19):1237-41. X-3, X-4e. [pmid: 7565999].
1373 de Zegher F, Vanderschueren-Lodeweyckx M, Spitz B, et al. Perinatal growth hormone (GH) physiology: effect of GH-releasing factor on maternal and fetal secretion of pituitary and placental GH. J Clin Endocrinol Metab. Aug. 1990;71(2):520-2. X-9. [pmid: 2143200].
1374 Deaver JE, Cohen WR. An approach to the prediction of neonatal Erb palsy. J Perinat Med. 2009;37(2):150-5. X-1. [pmid: 18976046].
1375 Debby A, Golan A, Sagiv R, et al. Midtrimester abortion in patients with a previous uterine scar. Eur J Obstet Gynecol Reprod Biol. Aug. 15. 2003;109(2):177-80. X-1. [pmid: 12860337].
1376 Debby A, Rotmensch S, Girtler O, et al. Clinical significance of the floating fetal head in nulliparous women in labor. J Reprod Med. Jan. 2003;48(1):37-40. X-1. [pmid: 12611093].
1377 Debillon T, Gras-Leguen C, Verielle V, et al. Intrauterine infection induces programmed cell death in rabbit periventricular white matter. Pediatr Res. Jun. 2000;47(6):736-42. X-1. [pmid: 10832730].
1378 Debley JS, Smith JM, Redding GJ, et al. Childhood asthma hospitalization risk after cesarean delivery in former term and premature infants. Ann Allergy Asthma Immunol. Feb. 2005;94(2):228-33. X-1. [pmid: 15765737].
1379 Decca L, Daldoss C, Fratelli N, et al. Labor course and delivery in epidural analgesia: a case-control study. J Matern Fetal Neonatal Med. Aug. 2004;16(2):115-8. X-1. [pmid: 15512722].
1380 Declercq E, Barger M, Cabral HJ, et al. Maternal outcomes associated with planned primary cesarean births compared with planned vaginal births. Obstet Gynecol. Mar. 2007;109(3):669-77. X-1. [pmid: 17329519].
1381 Declercq E, Chalmers B. Mothers' reports of their maternity experiences in the USA and Canada. Journal of Reproductive & Infant Psychology. 2008;26(4):295-308. X-1.
1382 Dede FS, Guney Y, Dede H, et al. Lipid peroxidation and antioxidant activity in patients in labor with nonreassuring fetal status. Eur J Obstet Gynecol Reprod Biol. Jan. 1. 2006;124(1):27-31. X-1. [pmid: 15950366].
1383 Dede FS, Haberal A, Dede H, et al. Misoprostol for cervical ripening and labor induction in pregnancies with oligohydramnios. Gynecol Obstet Invest. 2004;57(3):139-43. X-1. [pmid: 14707473].
1384 Dedes I, Ziogas V. Circular isthmic-cervical sutures can be an alternative method to control peripartum haemorrhage during caesarean section for placenta praevia accreta. Arch Gynecol Obstet. Dec. 2008;278(6):555-7. X-1. [pmid: 18449555].
1385 Deering MA, Heller J, McGaha K, et al. Patients presenting with birth plans in a military tertiary care hospital: a descriptive study of plans and outcomes. Mil Med. Aug. 2006;171(8):778-80. X-1. [pmid: 16933822].
1386 Deering SH, Carlson N, Stitely M, et al. Perineal body length and lacerations at delivery. J Reprod Med. Apr. 2004;49(4):306-10. X-1. [pmid: 15134158].
1387 Deering SH, Zaret J, McGaha K, et al. Patients presenting with birth plans: a case-control study of delivery outcomes. J Reprod Med. Oct. 2007;52(10):884-7. X-1. [pmid: 17977160].
1388 DeFranco EA, Rampersad R, Atkins KL, et al. Do vaginal birth after cesarean outcomes differ based on hospital setting?. Am J Obstet Gynecol. Oct. 2007;197(4):400 e1-6. X-1. [pmid: 17904977].
1389 Degirmen N, Ozerdogan N, Sayiner D, et al. Effectiveness of foot and hand massage in postcesarean pain control in a group of Turkish pregnant women. Appl Nurs Res. Aug. 2010;23(3):153-8. X-9. [pmid: 20643325].
1390 Dehbashi S, Honarvar M, Fardi FH. Manual removal or spontaneous placental delivery and postcesarean endometritis and bleeding. Int J Gynaecol Obstet. Jul. 2004;86(1):12-5. X-9. [pmid: 15207663].
1391 Dekker GA, Chan A, Luke CG, et al. Risk of uterine rupture in Australian women attempting vaginal birth after one prior caesarean section: a retrospective population-based cohort study. BJOG. Oct. 2010;117(11):1358-65. X-1. [pmid: 20716251].
1392 Del Rosario GR, Lewis T, Irons B, et al. Assessment of risk factors for stillbirth among pregnant women in Jamaica. J Obstet Gynaecol. Oct. 2004;24(7):750-5. X-1. [pmid: 15763780].
1393 Del Valle GO, Combs P, Qualls C, et al. Does closure of Camper fascia reduce the incidence of post-cesarean superficial wound disruption?. Obstet Gynecol. Dec. 1992;80(6):1013-6. X-9. [pmid: 1448244].
1394 Delaney S, Shaffer BL, Cheng YW, et al. Labor induction with a Foley balloon inflated to 30 mL compared with 60 mL: a randomized controlled trial. Obstet Gynecol. Jun. 2010;115(6):1239-45. X-4d, X-5. [pmid: 20502296].
1395 Delaney T, Young DC. Trial of labour compared to elective Caesarean in twin gestations with a previous Caesarean delivery. J Obstet Gynaecol Can. Apr. 2003;25(4):289-92. X-1. [pmid: 12679820].
1396 Dell'Anna E, Chen Y, Loidl F, et al. Short-term effects of perinatal asphyxia studied with Fos-immunocytochemistry and in vivo microdialysis in the rat. Exp Neurol. Feb. 1995;131(2):279-87. X-1. [pmid: 7895827].
1397 Demeter A, Sziller I, Csapo Z, et al. Outcome of pregnancies after cold-knife conization of the uterine cervix during pregnancy. Eur J Gynaecol Oncol. 2002;23(3):207-10. X-1. [pmid: 12094956].
1398 Demiraran Y, Ozdemir I, Kocaman B, et al. Intrathecal sufentanil (1.5 microg) added to hyperbaric bupivacaine (0.5%) for elective cesarean section provides adequate analgesia without need for pruritus therapy. J Anesth. 2006;20(4):274-8. X-9. [pmid: 17072691].
1399 Demirci F, Ozden S, Alpay Z, et al. The effects of vaginal delivery and cesarean section on bladder neck mobility and stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):129-33. X-1. [pmid: 11374511].
1400 Demissie K, Breckenridge MB, Rhoads GG. Infant and maternal outcomes in the pregnancies of asthmatic women. Am J Respir Crit Care Med. Oct. 1998;158(4):1091-5. X-1. [pmid: 9769265].
1401 DeMott RK, Sandmire HF. The Green Bay cesarean section study. I. The physician factor as a determinant of cesarean birth rates. Am J Obstet Gynecol. Jun. 1990;162(6):1593-9. discussion 1599-602. X-1. [pmid: 2360593].
1402 Dempsey MA, Breathnach FM, Geary M, et al. Congenital anomalies: Impact of prenatal diagnosis on mode of delivery. Ir Med J. Mar. 2010;103(3):88-9. X-1. [pmid: 20666076].
1403 Dencker A, Berg M, Bergqvist L, et al. Early versus delayed oxytocin augmentation in nulliparous women with prolonged labour--a randomised controlled trial. BJOG. Mar. 2009;116(4):530-6. X-5. [pmid: 19250364].
1404 Deneux-Tharaux C, Carmona E, Bouvier-Colle MH, et al. Postpartum maternal mortality and cesarean delivery. Obstet Gynecol. Sep. 2006;108(3 Pt 1):541-8. X-1. [pmid: 16946213].
1405 Denguezli W, Hemdane S, Faleh R, et al. Prevalence and risk factors of cesarean section in a population of Tunisian diabetic pregnant women. Tunis Med. Nov. 2007;85(11):935-40. X-1. [pmid: 19166144].
1406 Denguezli W, Trimech A, Haddad A, et al. Efficacy and safety of six hourly vaginal misoprostol versus intracervical dinoprostone: a randomized controlled trial. Arch Gynecol Obstet. Aug. 2007;276(2):119-24. X-4d. [pmid: 17219155].
1407 Denk CE, Kruse LK, Jain NJ. Surveillance of cesarean section deliveries, New Jersey, 1999-2004. Birth. Sep. 2006;33(3):203-9. X-1. [pmid: 16948720].
1408 Dennehy KC, Rosaeg OP, Cicutti NJ, et al. Oxytocin injection after caesarean delivery: intravenous or intramyometrial?. Can J Anaesth. Jul. 1998;45(7):635-9. X-9. [pmid: 9717594].
1409 Dennis AR, Leeson-Payne CG, Hobbs GJ. Analgesia after caesarean section. The use of rectal diclofenac as an adjunct to spinal morphine. Anaesthesia. Apr. 1995;50(4):297-9. X-9. [pmid: 7747843].
1410 DePalma RT, Cunningham FG, Leveno KJ, et al. Continuing investigation of women at high risk for infection following cesarean delivery. Three-dose perioperative antimicrobial therapy. Obstet Gynecol. Jul. 1982;60(1):53-9. X-1. [pmid: 7045755].
1411 Dermitzaki E, Staikou C, Petropoulos G, et al. A randomized study of maternal serum cytokine levels following cesarean section under general or neuraxial anesthesia. Int J Obstet Anesth. Jan. 2009;18(1):33-7. X-9. [pmid: 19026531].
1412 Desai S, Lim Y, Tan CH, et al. A randomised controlled trial of hyperbaric bupivacaine with opioids, injected as either a mixture or sequentially, for spinal anaesthesia for caesarean section. Anaesth Intensive Care. Mar. 2010;38(2):280-4. X-9. [pmid: 20369760].
1413 Desalu I, Afolabi BB. Urgency of surgery and presence of maternal disease influence the choice of anaesthesia for Caesarean section at LUTH. Niger Postgrad Med J. Jun. 2007;14(2):114-7. X-1. [pmid: 17599107].
1414 Desalu I, Kushimo OT. Is ephedrine infusion more effective at preventing hypotension than traditional prehydration during spinal anaesthesia for caesarean section in African parturients?. Int J Obstet Anesth. Oct. 2005;14(4):294-9. X-9. [pmid: 16154346].
1415 DeStephano CC, Flynn PM, Brost BC. Somali prenatal education video use in a United States obstetric clinic: a formative evaluation of acceptability. Patient Educ Couns. Oct. 2010;81(1):137-41. X-1. [pmid: 20071131].
1416 Deter RL, Harrist RB, Hadlock FP, et al. Fetal head and abdominal circumferences: I. Evaluation of measurement errors. J Clin Ultrasound. Oct. 1982;10(8):357-63. X-1. [pmid: 6816815].
1417 Devcic A, Sprung J, Patel S, et al. PDPH in obstetric anesthesia: comparison of 24-gauge Sprotte and 25-gauge Quincke needles and effect of subarachnoid administration of fentanyl. Reg Anesth. Jul-Aug. 1993;18(4):222-5. X-9. [pmid: 8398955].
1418 Devoe LD, Croom CS, Youssef AA, et al. The prediction of “controlled” uterine rupture by the use of intrauterine pressure catheters. Obstet Gynecol. Oct. 1992;80(4):626-9. X-1. [pmid: 1407884].
1419 Dewan DM, Floyd HM, Thistlewood JM, et al. Sodium citrate pretreatment in elective cesarean section patients. Anesth Analg. Jan. 1985;64(1):34-7. X-9. [pmid: 3966649].
1420 Dhar RS, Nagpal J, Bhargava V, et al. Quality of care, maternal attitude and common physician practices across the socio-economic spectrum: a community survey. Arch Gynecol Obstet. Sep. 2010;282(3):245-54. X-1. [pmid: 19727783].
1421 Dhar RS, Nagpal J, Sinha S, et al. Direct cost of maternity-care services in South Delhi: a community survey. J Health Popul Nutr. Jun. 2009;27(3):368-78. X-1. [pmid: 19507752].
1422 Dharan VB, Srinivas SK, Parry S, et al. Pregestational diabetes: a risk factor for vaginal birth after cesarean section failure?. Am J Perinatol. Mar. 2010;27(3):265-70. X-1. [pmid: 19784915].
1423 Dhont M, De Sutter P, Ruyssinck G, et al. Perinatal outcome of pregnancies after assisted reproduction: a case-control study. Am J Obstet Gynecol. Sep. 1999;181(3):688-95. X-1. [pmid: 10486485].
1424 Di Cianni G, Benzi L, Bottone P, et al. Neonatal outcome and obstetric complications in women with gestational diabetes: effects of maternal body mass index. Int J Obes Relat Metab Disord. May. 1996;20(5):445-9. X-1. [pmid: 8696423].
1425 Di Cianni G, Benzi L, Casadidio I, et al. Screening of gestational diabetes in Tuscany: results in 2000 cases. Ann Ist Super Sanita. 1997;33(3):389-91. X-1. [pmid: 9542268].
1426 Di Iulio JL, Gude NM, King RG, et al. Human placental nitric oxide synthase activity is not altered in diabetes. Clin Sci (Lond). Jul. 1999;97(1):123-8. X-1. [pmid: 10369805].
1427 Di Lieto A, Giani U, Campanile M, et al. Prenatal telemedicine: clinical experience with conventional and computerised antepartum telecardiotocography. Eur J Obstet Gynecol Reprod Biol. Jul. 10. 2002;103(2):114-8. X-1. [pmid: 12069731].
1428 Di Orio V. To hell and back. Midwifery Today Childbirth Educ. Autumn. 1994;(31):54. X-1. [pmid: 7920832].
1429 Di Somma AV. In re A.C. Issues Law Med. Fall. 1988;4(2):249-52. X-1. [pmid: 11644331].
1430 Diaferia A, Nicastri PL, Tartagni M, et al. Ursodeoxycholic acid therapy in pregnant women with cholestasis. Int J Gynaecol Obstet. Feb. 1996;52(2):133-40. X-3, X-4e. [pmid: 8855091].
1431 Diamond MP, Entman SS, Salyer SL, et al. Increased risk of endometritis and wound infection after cesarean section in insulin-dependent diabetic women. Am J Obstet Gynecol. Aug. 1986;155(2):297-300. X-1. [pmid: 3740145].
1432 Diani F, Zanconato G, Foschi F, et al. Management of the pregnant immigrant woman in the decade 1992-2001. J Obstet Gynaecol. Nov. 2003;23(6):615-7. X-1. [pmid: 14617461].
1433 Diaz SD, Jones JE, Seryakov M, et al. Uterine rupture and dehiscence: ten-year review and case-control study. South Med J. Apr. 2002;95(4):431-5. X-1. [pmid: 11958242].
1434 Dick W, Traub E, Kraus H, et al. General anaesthesia versus epidural anaesthesia for primary caesarean section--a comparative study. Eur J Anaesthesiol. Jan. 1992;9(1):15-21. X-1. [pmid: 1735394].
1435 Dickason LA, Dinsmoor MJ. Red blood cell transfusion and cesarean section. Am J Obstet Gynecol. Aug. 1992;167(2):327-30. discussion 330-2. X-1. [pmid: 1497033].
1436 Dicker D, Yeshaya A, Feldberg D, et al. Pregnancy outcome in maturity onset diabetes at young age (MODY). Aust N Z J Obstet Gynaecol. May. 1988;28(2):103-6. X-1. [pmid: 3228401].
1437 Dickinson JE, Godfrey M, Evans SF, et al. Factors influencing the selection of analgesia in spontaneously labouring nulliparous women at term. Aust N Z J Obstet Gynaecol. Aug. 1997;37(3):289-93. X-1. [pmid: 9325507].
1438 Dickinson JE, Paech MJ, McDonald SJ, et al. The impact of intrapartum analgesia on labour and delivery outcomes in nulliparous women. Aust N Z J Obstet Gynaecol. Feb. 2002;42(1):59-66. X-4e, X-5. [pmid: 11926643].
1439 Dickson MA, Jenkins J. Extension of epidural blockade for emergency caesarean section. Assessment of a bolus dose of bupivacaine 0.5% 10 ml following an infusion of 0.1% for analgesia in labour. Anaesthesia. Jul. 1994;49(7):636-8. X-1. [pmid: 8042736].
1440 Diejomaoh MF, Al-Shamali IA, Al-Kandari F, et al. The reproductive performance of women at 40 years and over. Eur J Obstet Gynecol Reprod Biol. May. 1. 2006;126(1):33-8. X-1. [pmid: 16154252].
1441 Diejomaoh MF, Gupta M, Farhat R, et al. Intrapartum performance of patients presenting with diabetes mellitus in pregnancy. Med Princ Pract. 2009;18(3):233-8. X-1. [pmid: 19349728].
1442 DiGiuseppe DL, Aron DC, Payne SM, et al. Risk adjusting cesarean delivery rates: a comparison of hospital profiles based on medical record and birth certificate data. Health Serv Res. Oct. 2001;36(5):959-77. X-1. [pmid: 11666112].
1443 Dijkman A, Huisman CM, Smit M, et al. Cardiac arrest in pregnancy: increasing use of perimortem caesarean section due to emergency skills training?. BJOG. Feb. 2010;117(3):282-7. X-1. [pmid: 20078586].
1444 Dilbaz B, Ozturkoglu E, Dilbaz S, et al. Risk factors and perinatal outcomes associated with umbilical cord prolapse. Arch Gynecol Obstet. May. 2006;274(2):104-7. X-1. [pmid: 16538441].
1445 Dildy GA. The future of intrapartum fetal pulse oximetry. Curr Opin Obstet Gynecol. Apr. 2001;13(2):133-6. X-1, X-2. [pmid: 11315866].
1446 Dillon WP, Seigel MS, Lele AS, et al. Evaluation of cefoxitin prophylaxis for cesarean section. Int J Gynaecol Obstet. Apr. 1981;19(2):133-9. X-9. [pmid: 6119244].
1447 Dimond B. Legal issues. Refusal overruled. Mod Midwife. Dec. 1996;6(12):20-2. X-1.
1448 Dimond B. Compulsory caesarean: the ruling of the Court of Appeal. Mod Midwife. Aug. 1997;7(8):20-2. X-1.
1449 Dimond B. The rights of the fetus against the mother. Br J Nurs. Jan. 9-22. 1997;6(1):5. X-1. [pmid: 9015993].
1450 Dimond B. Legal aspects of consent 11: compulsory Caesarean sections. Br J Nurs. Aug 9-Sep 12. 2001;10(15):1002-4. X-1, X-2. [pmid: 11923735].
1451 Dinsbeer H, Tuttle A, Haas A, et al. How do you prevent c-sections?. Midwifery Today Int Midwife. Spring. 2001;(57):8. 69. X-1, X-2, X-3, X-4e, X-5. [pmid: 12596398].
1452 Dinsmoor MJ, Gibbs RS. Previous intra-amniotic infection as a risk factor for subsequent peripartal uterine infections. Obstet Gynecol. Sep. 1989;74(3 Pt 1):299-301. X-1. [pmid: 2761903].
1453 DiPiazza D, Richter HE, Chapman V, et al. Risk factors for anal sphincter tear in multiparas. Obstet Gynecol. Jun. 2006;107(6):1233-7. X-1. [pmid: 16738146].
1454 Diro M, Adra A, Gilles JM, et al. A double-blind randomized trial of two dose regimens of misoprostol for cervical ripening and labor induction. J Matern Fetal Med. May-Jun. 1999;8(3):114-8. X-4d. [pmid: 10338065].
1455 Diro M, Beydoun SN. Segmental epidural analgesia in labor: a matched control study. J Natl Med Assoc. Jul. 1985;77(7):569-73. X-1, X-4e, X-5. [pmid: 4046055].
1456 Disney JA. The context of women's childbirth decisions regarding vaginal birth after cesarean section. Ph.D. 1998:190. X-1.
1457 Dissanayake VH, Samarasinghe HD, Morgan L, et al. Morbidity and mortality associated with pre-eclampsia at two tertiary care hospitals in Sri Lanka. J Obstet Gynaecol Res. Feb. 2007;33(1):56-62. X-1. [pmid: 17212667].
1458 Dixon JB, Dixon ME, O'Brien PE. Pregnancy after Lap-Band surgery: management of the band to achieve healthy weight outcomes. Obes Surg. Feb. 2001;11(1):59-65. X-1. [pmid: 11361170].
1459 diZerega G, Yonekura L, Roy S, et al. A comparison of clindamycin-gentamicin and penicillin-gentamicin in the treatment of post-cesarean section endomyometritis. Am J Obstet Gynecol. Jun. 1. 1979;134(3):238-42. X-9. [pmid: 453256].
1460 Dodd J, Pearce E, Crowther C. Women's experiences and preferences following Caesarean birth. Aust N Z J Obstet Gynaecol. Dec. 2004;44(6):521-4. X-1. [pmid: 15598289].
1461 Dodd JM, Crowther CA, Haslam RR, et al. Timing of birth for women with a twin pregnancy at term: a randomised controlled trial. BMC Pregnancy Childbirth. 2010;10:68. X-9. [pmid: 20973989].
1462 Dodd JM, Crowther CA, Hiller JE, et al. Birth after caesarean study--planned vaginal birth or planned elective repeat caesarean for women at term with a single previous caesarean birth: protocol for a patient preference study and randomised trial. BMC Pregnancy Childbirth. 2007;7:17. X-1, X-3, X-4d, X-5. [pmid: 17697343].
1463 Dodd JM, Crowther CA, Robinson JS. Morning compared with evening induction of labor: a nested randomized controlled trial. A nested randomized controlled trial. Obstet Gynecol. Aug. 2006;108(2):350-60. X-4d, X-5. [pmid: 16880306].
1464 Dodd JM, Crowther CA, Robinson JS. Oral misoprostol for induction of labour at term: randomised controlled trial. BMJ. Mar. 4. 2006;332(7540):509-13. X-4d. [pmid: 16455695].
1465 Doganay M, Tonguc EA, Var T. Effects of method of uterine repair on surgical outcome of cesarean delivery. Int J Gynaecol Obstet. Nov. 2010;111(2):175-8. X-9. [pmid: 20713293].
1466 Doh AS. A clinical study of caesarean section at the University Teaching Hospital (C.H.U.) Yaounde (1982-1989). Cent Afr J Med. Oct. 1991;37(10):326-8. X-1. [pmid: 1813127].
1467 Doi T, Sugimoto K, Puri P. Prenatal retinoic acid up-regulates pulmonary gene expression of COUP-TFII, FOG2, and GATA4 in pulmonary hypoplasia. J Pediatr Surg. Oct. 2009;44(10):1933-7. X-1. [pmid: 19853750].
1468 Dolkart L, Harter M, Snyder M. Four-dimensional ultrasonographic guidance for invasive obstetric procedures. J Ultrasound Med. Sep. 2005;24(9):1261-6. X-1. [pmid: 16123186].
1469 Dombrowski MP, Schatz M. Asthma in pregnancy. Clin Obstet Gynecol. Jun. 2010;53(2):301-10. X-1, X-2. [pmid: 20436305].
1470 Dombrowski MP, Schatz M, Wise R, et al. Asthma during pregnancy. Obstet Gynecol. Jan. 2004;103(1):5-12. X-1. [pmid: 14704237].
1471 Dominguez KL, Lindegren ML, D'Almada PJ, et al. Increasing trend of Cesarean deliveries in HIV-infected women in the United States from 1994 to 2000. J Acquir Immune Defic Syndr. Jun. 1. 2003;33(2):232-8. X-1. [pmid: 12794560].
1472 Dommergues M, Mahieu-Caputo D, Mandelbrot L, et al. Delivery of uncomplicated triplet pregnancies: is the vaginal route safer? A case-control study. Am J Obstet Gynecol. Feb. 1995;172(2 Pt 1):513-7. X-1. [pmid: 7856678].
1473 Donahue D, Brooten D, Roncoli M, et al. Acute care visits and rehospitalization in women and infants after cesarean birth. J Perinatol. Jan-Feb. 1994;14(1):36-40. X-9. [pmid: 8169676].
1474 Donati S, Grandolfo ME, Andreozzi S. Do Italian mothers prefer cesarean delivery?. Birth. Jun. 2003;30(2):89-93. X-1. [pmid: 12752165].
1475 Donchin Y, Davidson JT, Magora F. Epidural morphine for the control of pain after cesarean section. Isr J Med Sci. May. 1981;17(5):331-4. X-9. [pmid: 6894912].
1476 Dong YL, Fang L, Kondapaka S, et al. Involvement of calcitonin gene-related peptide in the modulation of human myometrial contractility during pregnancy. J Clin Invest. Sep. 1999;104(5):559-65. X-1. [pmid: 10487770].
1477 Dongol AS, Shrestha A, Chawla CD. Post partum haemorrhage: prevalence, morbidity and management pattern in Dhulikhel Hospital. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2010;8(30):212-5. X-1. [pmid: 21209538].
1478 Donker RB, Molema G, Faas MM, et al. Absence of in vivo generalized pro-inflammatory endothelial activation in severe, early-onset preeclampsia. J Soc Gynecol Investig. Oct. 2005;12(7):518-28. X-1.
1479 Donnenfeld AE, Otis C, Weiner S. Antibiotic prophylaxis in cesarean section. Comparison of intrauterine lavage and intravenous administration. J Reprod Med. Jan. 1986;31(1):15-8. X-9. [pmid: 3512820].
1480 Donoval BA, Passaro DJ, Klausner JD. The public health imperative for a neonatal herpes simplex virus infection surveillance system. Sex Transm Dis. Mar. 2006;33(3):170-4. X-1, X-2. [pmid: 16505733].
1481 Donovan EF, Lannon C, Bailit J, et al. A statewide initiative to reduce inappropriate scheduled births at 36(0/7)-38(6/7) weeks' gestation. Am J Obstet Gynecol. Mar. 2010;202(3):243 e1-8. X-4e, X-3, X-4b. [pmid: 20207241].
1482 Donowitz LG, Wenzel RP. Endometritis following cesarean section. A controlled study of the increased duration of hospital stay and direct cost of hospitalization. Am J Obstet Gynecol. Jun. 15. 1980;137(4):467-9. X-1. [pmid: 6992580].
1483 Dorea JG, Cruz-Granja AC, Lacayo-Romero ML, et al. Perinatal metabolism of dichlorodiphenyldichloroethylene in Nicaraguan mothers. Environ Res. Jul. 2001;86(3):229-37. X-1. [pmid: 11453673].
1484 Dorenbaum A, Cunningham CK, Gelber RD, et al. Two-dose intrapartum/newborn nevirapine and standard antiretroviral therapy to reduce perinatal HIV transmission: a randomized trial. JAMA. Jul. 10. 2002;288(2):189-98. X-4e, X-5. [pmid: 12095383].
1485 Doret M, Touzet S, Bourdy S, et al. Vaginal birth after two previous c-sections: obstetricians-gynaecologists opinions and practice patterns. J Matern Fetal Neonatal Med. Dec. 2010;23(12):1487-92. X-1. [pmid: 20233132].
1486 d'Orsi E, Carvalho MS, Cruz OG. Similarity between neonatal profile and socioeconomic index: a spatial approach. Cad Saude Publica. May-Jun. 2005;21(3):786-94. X-1. [pmid: 15868036].
1487 D'Orsi E, Chor D, Giffin K, et al. Factors associated with cesarean sections in a public hospital in Rio de Janeiro, Brazil. Cad Saude Publica. Oct. 2006;22(10):2067-78. X-1. [pmid: 16951878].
1488 d'Orsi E, Chor D, Giffin K, et al. Factors associated with vaginal birth after cesarean in a maternity hospital of Rio de Janeiro. Eur J Obstet Gynecol Reprod Biol. Aug. 2001;97(2):152-7. X-1. [pmid: 11451540].
1489 Dottrens M, Rifat K, Morel DR. Comparison of extradural administration of sufentanil, morphine and sufentanil-morphine combination after caesarean section. Br J Anaesth. Jul. 1992;69(1):9-12. X-9. [pmid: 1386224].
1490 Doucette RC, Sharp HT, Alder SC. Challenging generally accepted contraindications to vaginal hysterectomy. Am J Obstet Gynecol. Jun. 2001;184(7):1386-9. discussion 1390-1. X-1. [pmid: 11408857].
1491 Dougherty CJ. The right to begin life with sound body and mind: fetal patients and conflicts with their mothers. Univ Detroit Law Rev. Fall. 1985;63(1-2):89-117. X-1, X-4e. [pmid: 11659281].
1492 Dougherty TB, Baysinger CL, Henenberger JC, et al. Epidural hydromorphone with and without epinephrine for post-operative analgesia after cesarean delivery. Anesth Analg. Mar. 1989;68(3):318-22. X-9. [pmid: 2465709].
1493 Douglas MJ, McMorland GH, Janzen JA. Influence of bupivacaine as an adjuvant to epidural morphine for analgesia after cesarean section. Anesth Analg. Dec. 1988;67(12):1138-41. X-9. [pmid: 3195729].
1494 Downing JW, Brock-Utne JG, Barclay A, et al. WY 16225 (dezocine), a new synthetic opiate agonist-antagonist and potent analgesic: comparison with morphine for relief of pain after lower abdominal surgery. Br J Anaesth. Jan. 1981;53(1):59-64. X-3. [pmid: 7006657].
1495 Downing JW, Buley RJ, Brock-Utne JG, et al. Etomidate for induction of anaesthesia at caesarean section: comparison with thiopentone. Br J Anaesth. Feb. 1979;51(2):135-40. X-9. [pmid: 426990].
1496 Downing JW, Coleman AJ, Mahomedy MC, et al. Lateral table tilt for Caesarean section. Anaesthesia. Nov. 1974;29(6):696-703. X-4b. [pmid: 4429194].
1497 Downing JW, Houlton PC, Barclay A. Extradural analgesia for caesarean section: a comparison with general anaesthesia. Br J Anaesth. Apr. 1979;51(4):367-74. X-1. [pmid: 465260].
1498 Downing JW, Leary WP, White ES. Buprenorphine a new potent long acting synthetic analgesic. Comparison with morphine. Br J Anaesth. Mar. 1977;49(3):251-5. X-9. [pmid: 334206].
1499 Downing JW, Mahomedy MC, Coleman AJ, et al. Anaesthetic induction for Caesarean section. Althesin versus thiopentone. Anaesthesia. Nov. 1974;29(6):689-95. X-4b. [pmid: 4429193].
1500 Downing JW, Mahomedy MC, Jeal DE, et al. Anaesthesia for Caesarean section with ketamine. Anaesthesia. Sep. 1976;31(7):883-92. X-1. [pmid: 9839].
1501 Dowswell T, Mousa HA. Planned home versus hospital care for preterm prelabour rupture of the membranes (PPROM) prior to 37 weeks' gestation. Cochrane Database of Systematic Reviews. 2010;(4). X-1, X-2.
1502 Draisci G, Frassanito L, Pinto R, et al. Safety and effectiveness of coadministration of intrathecal sufentanil and morphine in hyperbaric bupivacaine-based spinal anesthesia for cesarean section. J Opioid Manag. Jul-Aug. 2009;5(4):197-202. X-9. [pmid: 19736899].
1503 Draisci G, Valente A, Suppa E, et al. Remifentanil for cesarean section under general anesthesia: effects on maternal stress hormone secretion and neonatal well-being: a randomized trial. Int J Obstet Anesth. Apr. 2008;17(2):130-6. X-9. [pmid: 18313286].
1504 Draper D, McGregor J, Hall J, et al. Elevated protease activities in human amnion and chorion correlate with preterm premature rupture of membranes. Am J Obstet Gynecol. Nov. 1995;173(5):1506-12. X-1. [pmid: 7503192].
1505 Draper H. Women, forced caesareans and antenatal responsibilities. J Med Ethics. Dec. 1996;22(6):327-33. X-1, X-2. [pmid: 8961116].
1506 Dresner M, Pinder A. Anaesthesia for caesarean section in women with complex cardiac disease: 34 cases using the Braun Spinocath spinal catheter. Int J Obstet Anesth. Apr. 2009;18(2):131-6. X-1. [pmid: 19181514].
1507 Drigotas EE. Forced cesarean sections: do the ends justify the means?. North Carol Law Rev. Nov. 1991;70(1):297-321. X-1. [pmid: 11651652].
1508 Driver RP Jr., D'Angelo R, Eisenach JC. Bolus metoclopramide does not enhance morphine analgesia after cesarean section. Anesth Analg. May. 1996;82(5):1033-5. X-9. [pmid: 8610862].
1509 Drury MI. Diabetes mellitus and pregnancy--the nine month experiment. Postgrad Med J. Suppl 2. 1979;55:36-9. X-1. [pmid: 384384].
1510 Drury MI, Greene AT, Stronge JM. Pregnancy complicated by clinical diabetes mellitus. A study of 600 pregnancies. Obstet Gynecol. May. 1977;49(5):519-22. X-1. [pmid: 850562].
1511 Druzin ML. Packing of lower uterine segment for control of postcesarean bleeding in instances of placenta previa. Surg Gynecol Obstet. Dec. 1989;169(6):543-5. X-1. [pmid: 2814771].
1512 Druzin ML, El-Sayed YY. Cesarean delivery on maternal request: wise use of finite resources? A view from the trenches. Semin Perinatol. Oct. 2006;30(5):305-8. X-1. [pmid: 17011403].
1513 Druzin ML, Lockshin M, Edersheim TG, et al. Second-trimester fetal monitoring and preterm delivery in pregnancies with systemic lupus erythematosus and/or circulating anticoagulant. Am J Obstet Gynecol. Dec. 1987;157(6):1503-10. X-1. [pmid: 3122577].
1514 D'Souza SW, Rivlin E, Cadman J, et al. Children conceived by in vitro fertilisation after fresh embryo transfer. Arch Dis Child Fetal Neonatal Ed. Mar. 1997;76(2):F70-4. X-1. [pmid: 9135283].
1515 Duale C, Frey C, Bolandard F, et al. Epidural versus intrathecal morphine for postoperative analgesia after Caesarean section. Br J Anaesth. Nov. 2003;91(5):690-4. X-9. [pmid: 14570792].
1516 Ducarme G, Revaux A, Rodrigues A, et al. Obstetric outcome following laparoscopic adjustable gastric banding. Int J Gynaecol Obstet. Sep. 2007;98(3):244-7. X-1. [pmid: 17433814].
1517 Duenhoelter JH, Wells CE, Reisch JS, et al. A paired controlled study of vaginal and abdominal delivery of the low birth weight breech fetus. Obstet Gynecol. Sep. 1979;54(3):310-3. X-1. [pmid: 471370].
1518 Duff P, Huff RW, Gibbs RS. Management of premature rupture of membranes and unfavorable cervix in term pregnancy. Obstet Gynecol. May. 1984;63(5):697-702. X-4e. [pmid: 6717874].
1519 Duff P, Keiser JF. A comparative study of two antibiotic regimens for the treatment of operative site infections. Am J Obstet Gynecol. Apr. 15. 1982;142(8):996-1003. X-9. [pmid: 7041654].
1520 Duff P, Park RC. Antibiotic prophylaxis for cesarean section in a military population. Mil Med. Jun. 1980;145(6):377-81. X-4b. [pmid: 6771705].
1521 Duff P, Robertson AW, Read JA. Single-dose cefazolin versus cefonicid for antibiotic prophylaxis in cesarean delivery. Obstet Gynecol. Nov. 1987;70(5):718-21. X-9. [pmid: 3658278].
1522 Duff P, Smith PN, Keiser JF. Antibiotic prophylaxis in low-risk cesarean section. J Reprod Med. Mar. 1982;27(3):133-8. X-9. [pmid: 7086761].
1523 Dufour P, Vinatier D, Vanderstichele S, et al. Intravenous nitroglycerin for internal podalic version of the second twin in transverse lie. Obstet Gynecol. Sep. 1998;92(3):416-9. X-1. [pmid: 9721781].
1524 Dugowson CE, Holland SK. Physicians as patients--the use of obstetric technology in physician families. West J Med. Apr. 1987;146(4):494-6. X-1. [pmid: 3577149].
1525 Duignan NM, Andrews J, Williams JD. Pharmacological studies with lincomycin in late pregnancy. Br Med J. Jul. 14. 1973;3(5871):75-8. X-1. [pmid: 4717846].
1526 Dumas AM, Girard R, Ayzac L, et al. Maternal infection rates after cesarean delivery by Pfannenstiel or Joel-Cohen incision: a multicenter surveillance study. Eur J Obstet Gynecol Reprod Biol. Dec. 2009;147(2):139-43. X-1. [pmid: 19864051].
1527 Duncan JR, Garland M, Myers MM, et al. Prenatal nicotine-exposure alters fetal autonomic activity and medullary neurotransmitter receptors: implications for sudden infant death syndrome. J Appl Physiol. Nov. 2009;107(5):1579-90. X-1. [pmid: 19729586].
1528 Duncan PW, Lawes EG, Bland B, et al. Fresh gas flow requirements using the ADE anaesthetic system during late pregnancy. Br J Anaesth. Mar. 1987;59(3):360-3. X-9. [pmid: 3103662].
1529 Dundee JW, Howe JP, Moore J, et al. Effect of cimetidine on gastric pH in women undergoing elective Caesarean section [proceedings]. Br J Clin Pharmacol. Oct. 1979;8(4):391P-392P. X-3, X-4b.
1530 Dundek LH. Establishment of a Somali doula program at a large metropolitan hospital. J Perinat Neonatal Nurs. Apr-Jun. 2006;20(2):128-37. X-1. [pmid: 16714912].
1531 Dunn DT, Simonds RJ, Bulterys M, et al. Interventions to prevent vertical transmission of HIV-1: effect on viral detection rate in early infant samples. AIDS. Jul. 7. 2000;14(10):1421-8. X-1. [pmid: 10930158].
1532 Dunn PA. Differences in maternal and fetal stress response of women who received moderate or low dose oxytocin for induction of labor. Ph.D. 1998:180. X-4d.
1533 Dunne FP, Brydon P, Smith T, et al. Pre-conception diabetes care in insulin-dependent diabetes mellitus. QJM. Mar. 1999;92(3):175-6. X-1. [pmid: 10326077].
1534 Dupuis O, Silveira R, Dupont C, et al. Comparison of “instrument-associated” and “spontaneous” obstetric depressed skull fractures in a cohort of 68 neonates. Am J Obstet Gynecol. Jan. 2005;192(1):165-70. X-1. [pmid: 15672020].
1535 Durnwald CP, Rouse DJ, Leveno KJ, et al. The Maternal-Fetal Medicine Units Cesarean Registry: safety and efficacy of a trial of labor in preterm pregnancy after a prior cesarean delivery. Am J Obstet Gynecol. Oct. 2006;195(4):1119-26. X-1. [pmid: 17000244].
1536 Durodola A, Kuti O, Orji EO, et al. Rate of increase in oxytocin dose on the outcome of labor induction. Int J Gynaecol Obstet. Aug. 2005;90(2):107-11. X-1. [pmid: 15996667].
1537 Dutton DA, Moir DD, Howie HB, et al. Choice of local anaesthetic drug for extradural caesarean section. Comparison of 0.5% and 0.75% bupivacaine and 1.5% etidocaine. Br J Anaesth. Dec. 1984;56(12):1361-8. X-9. [pmid: 6498044].
1538 Dweck MF, Lynch CM, Spellacy WN. Use of methergine for the prevention of postoperative endometritis in non-elective cesarean section patients. Infect Dis Obstet Gynecol. 2000;8(3-4):151-4. X-9. [pmid: 10968597].
1539 Dwyer R, Fee JP, Moore J. Uptake of halothane and isoflurane by mother and baby during caesarean section. Br J Anaesth. Apr. 1995;74(4):379-83. X-9. [pmid: 7734253].
1540 Dyer C. Colleges say no to forced caesarean sections. BMJ. Jan. 22. 1994;308(6923):224. X-1, X-2. [pmid: 11644510].
1541 Dyer C. Woman can challenge hospital over forced caesarean. BMJ. Jul. 12. 1997;315(7100):78. X-1, X-2. [pmid: 11644954].
1542 Dyer C. Judge misled over call for caesarean operation. BMJ. Feb. 21. 1998;316(7131):574. X-1. [pmid: 11645034].
1543 Dyer C. Trusts face damages after forcing women to have ceasareans. BMJ. May. 16. 1998;316(7143):1480. X-1. [pmid: 11645058].
1544 Dyer RA, Els I, Farbas J, et al. Prospective, randomized trial comparing general with spinal anesthesia for cesarean delivery in preeclamptic patients with a nonreassuring fetal heart trace. Anesthesiology. Sep. 2003;99(3):561-9. discussion 5A-6A. X-3, X-4b, X-5. [pmid: 12960539].
1545 Dyer RA, Farina Z, Joubert IA, et al. Crystalloid preload versus rapid crystalloid administration after induction of spinal anaesthesia (coload) for elective caesarean section. Anaesth Intensive Care. Jun. 2004;32(3):351-7. X-9. [pmid: 15264729].
1546 Dyer RA, Reed AR, van Dyk D, et al. Hemodynamic effects of ephedrine, phenylephrine, and the coadministration of phenylephrine with oxytocin during spinal anesthesia for elective cesarean delivery. Anesthesiology. Oct. 2009;111(4):753-65. X-9. [pmid: 19741494].
1547 Dykowski MD, Ainslie G. Routine antenatal ultrasonography in a base population. Mil Med. Nov. 1990;155(11):549-51. X-1. [pmid: 2126858].
1548 Dyson DC, Ferguson JE 2nd, Hensleigh P. Antepartum external cephalic version under tocolysis. Obstet Gynecol. Jan. 1986;67(1):63-8. X-1. [pmid: 3940340].
1549 Dyson DC, Miller PD, Armstrong MA. Management of prolonged pregnancy: induction of labor versus antepartum fetal testing. Am J Obstet Gynecol. Apr. 1987;156(4):928-34. X-4e. [pmid: 3472467].
1550 East CE, Chan FY, Brennecke SP, et al. Women's evaluations of their experience in a multicenter randomized controlled trial of intrapartum fetal pulse oximetry (The FOREMOST Trial). Birth. Jun. 2006;33(2):101-9. X-1, X-3, X-5. [pmid: 16732774].
1551 East CE, Gascoigne MB, Doran CM, et al. A cost-effectiveness analysis of the intrapartum fetal pulse oximetry multicentre randomised controlled trial (the FOREMOST trial). BJOG. Sep. 2006;113(9):1080-7. X-1, X-3, X-4e, X-5. [pmid: 16956340].
1552 East N, Dube J, Perreault EL. Postpartum pain relief: a randomized comparison of self-administered medication and standard administration. J Obstet Gynaecol Can. Dec. 2007;29(12):975-81. X-4e, X-5. [pmid: 18053382].
1553 Ebeigbe PN, Gharoro EP. Obstetric complications, intervention rates and maternofetal outcome in teenage nullipara in Benin City, Nigeria. Trop Doct. Apr. 2007;37(2):79-83. X-1. [pmid: 17540084].
1554 Eberle RL, Norris MC, Eberle AM, et al. The effect of maternal position on fetal heart rate during epidural or intrathecal labor analgesia. Am J Obstet Gynecol. Jul. 1998;179(1):150-5. X-4e. [pmid: 9704781].
1555 Ebneshahidi A, Mohseni M. The effect of patient-selected music on early postoperative pain, anxiety, and hemodynamic profile in cesarean section surgery. J Altern Complement Med. Sep. 2008;14(7):827-31. X-9. [pmid: 18803492].
1556 Echt M, Begneaud W, Montgomery D. Effect of epidural analgesia on the primary cesarean section and forceps delivery rates. J Reprod Med. Jul. 2000;45(7):557-61. X-1. [pmid: 10948466].
1557 Ecker JL. Once a pregnancy, always a cesarean? Rationale and feasibility of a randomized controlled trial. Am J Obstet Gynecol. Feb. 2004;190(2):314-8. X-1, X-2. [pmid: 14981367].
1558 Eckerlund I, Gerdtham UG. Econometric analysis of variation in cesarean section rates. A cross-sectional study of 59 obstetrical departments in Sweden. Int J Technol Assess Health Care. Fall. 1998;14(4):774-87. X-1. [pmid: 9885466].
1559 Eddleman KA, Lockwood CJ, Berkowitz GS, et al. Clinical significance and sonographic diagnosis of velamentous umbilical cord insertion. Am J Perinatol. Mar. 1992;9(2):123-6. X-1. [pmid: 1590867].
1560 Eden KB, Dolan JG, Perrin NA, et al. Patients were more consistent in randomized trial at prioritizing childbirth preferences using graphic-numeric than verbal formats. J Clin Epidemiol. Apr. 2009;62(4):415-424 e3. X-3, X-4b, X-4e. [pmid: 19008073].
1561 Eden RD, Seifert LS, Winegar A, et al. Perinatal characteristics of uncomplicated postdate pregnancies. Obstet Gynecol. Mar. 1987;69(3 Pt 1):296-9. X-1. [pmid: 3822274].
1562 Eder M, Farina N, Sanabria RR, et al. Normal ocular flora in newborns delivered in two hospital centers in Argentina and Paraguay. Graefes Arch Clin Exp Ophthalmol. Nov. 2005;243(11):1098-107. X-1. [pmid: 15912402].
1563 Edgar JD, Wilson DC, McMillan SA, et al. Predictive value of soluble immunological mediators in neonatal infection. Clin Sci (Lond). Aug. 1994;87(2):165-71. X-1. [pmid: 7924161].
1564 Edirne T, Can M, Kolusari A, et al. Trends, characteristics, and outcomes of adolescent pregnancy in eastern Turkey. Int J Gynaecol Obstet. Aug. 2010;110(2):105-8. X-1. [pmid: 20434724].
1565 Edmunds J. 7 steps toward cesarean prevention. Midwifery Today Int Midwife. Spring. 2001;(57):31-3. X-1, X-2, X-3, X-4e, X-5. [pmid: 12596404].
1566 Edwards C, Witter FR. Preeclampsia, labor duration and mode of delivery. Int J Gynaecol Obstet. Apr. 1997;57(1):39-42. X-1. [pmid: 9175668].
1567 Edwards LE, Dickes WF, Alton IR, et al. Pregnancy in the massively obese: course, outcome, and obesity prognosis of the infant. Am J Obstet Gynecol. Jul. 1. 1978;131(5):479-83. X-1. [pmid: 677188].
1568 Edwards MS. Mifepristone: cervical ripening and induction of labor. Clin Obstet Gynecol. Jun. 1996;39(2):469-73. X-1, X-2. [pmid: 8734011].
1569 Edwards RK, Duff P. Single additional dose postpartum therapy for women with chorioamnionitis. Obstet Gynecol. Nov. 2003;102(5 Pt 1):957-61. X-4e. [pmid: 14672470].
1570 Edwards RK, Madani K, Duff P. Is perioperative hypothermia a risk factor for post-Cesarean infection?. Infect Dis Obstet Gynecol. 2003;11(2):75-80. X-1. [pmid: 14627212].
1571 Effer SB, Moutquin JM, Farine D, et al. Neonatal survival rates in 860 singleton live births at 24 and 25 weeks gestational age. A Canadian multicentre study. BJOG. Jul. 2002;109(7):740-5. X-1. [pmid: 12135208].
1572 Eftekhari N, Doroodian M, Lashkarizadeh R. The effect of sublingual misoprostol versus intravenous oxytocin in reducing bleeding after caesarean section. J Obstet Gynaecol. Oct. 2009;29(7):633-6. X-9. [pmid: 19757270].
1573 Egerman RS, Ramsey RD, Kao LW, et al. Perinatal outcomes in pregnancies managed with antenatal insulin glargine. Am J Perinatol. Sep. 2009;26(8):591-5. X-1. [pmid: 19370512].
1574 Egge T, Schauberger C, Schaper A. Dysfunctional labor after external cephalic version. Obstet Gynecol. May. 1994;83(5 Pt 1):771-3. X-1. [pmid: 8164942].
1575 Eggleston MK Jr., Wax JR, Philput C, et al. Use of surgical pass trays to reduce intraoperative glove perforations. J Matern Fetal Med. Jul-Aug. 1997;6(4):245-7. X-9. [pmid: 9260125].
1576 Eglinton GS, Phelan JP, Yeh S, et al. Outcome of a trial of labor after prior cesarean delivery. J Reprod Med. Jan. 1984;29(1):3-8. X-1. [pmid: 6708017].
1577 Ego A, Subtil D, Grange G, et al. Should parity be d in customised fetal weight standards for identifying small-for-gestational-age babies? Results from a French multicentre study. BJOG. Sep. 2008;115(10):1256-64. X-1. [pmid: 18715411].
1578 Ehigiegba AE, Ande AB, Ojobo SI. Myomectomy during cesarean section. Int J Gynaecol Obstet. Oct. 2001;75(1):21-5. X-1. [pmid: 11597615].
1579 Ehrenberg HM, Dierker L, Milluzzi C, et al. Prevalence of maternal obesity in an urban center. Am J Obstet Gynecol. Nov. 2002;187(5):1189-93. X-1. [pmid: 12439501].
1580 Ehrenreich N. The colonization of the womb. Duke Law J. Dec. 1993;43(3):492-587. X-1, X-2, X-3, X-4e, X-5. [pmid: 10131480].
1581 Eisenach JC, D'Angelo R, Taylor C, et al. An isobolographic study of epidural clonidine and fentanyl after cesarean section. Anesth Analg. Aug. 1994;79(2):285-90. X-9. [pmid: 7639365].
1582 Eisenach JC, Grice SC, Dewan DM. Patient-controlled analgesia following cesarean section: a comparison with epidural and intramuscular narcotics. Anesthesiology. Mar. 1988;68(3):444-8. X-1, X-9. [pmid: 3345002].
1583 Eisenach JC, Schlairet TJ, Dobson CE 2nd, et al. Effect of prior anesthetic solution on epidural morphine analgesia. Anesth Analg. Aug. 1991;73(2):119-23. X-1, X-3, X-4b, X-5. [pmid: 1854026].
1584 Eisenach JC, Thomas JA, Rauck RL, et al. Cystatin C in cerebrospinal fluid is not a diagnostic test for pain in humans. Pain. Feb. 2004;107(3):207-12. X-1. [pmid: 14736582].
1585 Eisenach JC, Tuttle R, Stein A. Is ST segment depression of the electrocardiogram during cesarean section merely due to cardiac sympathetic block?. Anesth Analg. Feb. 1994;78(2):287-92. X-1. [pmid: 8311281].
1586 Eisler G, Hjertberg R, Lagercrantz H. Randomised controlled trial of effect of terbutaline before elective caesarean section on postnatal respiration and glucose homeostasis. Arch Dis Child Fetal Neonatal Ed. Mar. 1999;80(2):F88-92. X-9. [pmid: 10325782].
1587 Ekblad U, Erkkola R, Pirhonen J. Comparison of intravaginal and two intracervical prostaglandin E2 gels in pre-induction of labour. Ann Chir Gynaecol Suppl. 1994;208:64-7. X-4d, X-5. [pmid: 8092777].
1588 Ekblad U, Erkkola R, Uotila P, et al. Ritodrine infusion at term: effects on maternal and fetal prostacyclin, thromboxane and prostaglandin precursor fatty acids. Gynecol Obstet Invest. 1988;25(2):106-12. X-9. [pmid: 3286393].
1589 Ekblad U, Grenman S. Maternal weight, weight gain during pregnancy and pregnancy outcome. Int J Gynaecol Obstet. Dec. 1992;39(4):277-83. X-1. [pmid: 1361460].
1590 Ekblad U, Grenman S, Kaila T. The effect of a short-term ritodrine treatment on the concentration of beta-adrenergic receptors in human myometrium. Ann Chir Gynaecol Suppl. 1987;202:29-31. X-1. [pmid: 2821864].
1591 Ekerhovd E, Bullarbo M, Andersch B, et al. Vaginal administration of the nitric oxide donor isosorbide mononitrate for cervical ripening at term: a randomized controlled study. Am J Obstet Gynecol. Dec. 2003;189(6):1692-7. X-9. [pmid: 14710100].
1592 Ekman G, Granstrom L, Ulmsten U. Induction of labor with intravenous oxytocin or vaginal PGE2 suppositories. A randomized study. Acta Obstet Gynecol Scand. 1986;65(8):857-9. X-4d. [pmid: 3548209].
1593 Ekman G, Ulmsten U, Wingerup L. Intracervical application of PGE2-gel combined with early intravenous infusion of oxytocin for induction of term labor in women with unripe cervix. Arch Gynecol. 1983;234(1):61-5. X-1, X-4d. [pmid: 6660930].
1594 Ekman-Ordeberg G, Uldbjerg N, Ulmsten U. Comparison of intravenous oxytocin and vaginal prostaglandin E2 gel in women with unripe cervixes and premature rupture of the membranes. Obstet Gynecol. Sep. 1985;66(3):307-10. X-4d, X-4e. [pmid: 3860789].
1595 Ekstrom A, Altman D, Wiklund I, et al. Planned cesarean section versus planned vaginal delivery: comparison of lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):459-65. X-1. [pmid: 17896063].
1596 Ekwempu CC, Lawande RV. Postoperative morbidity of eclamptic patients delivered by cesarean section. Int J Gynaecol Obstet. 1980;18(6):468-9. X-1. [pmid: 6111490].
1597 El Khwad M, Stetzer B, Moore RM, et al. Term human fetal membranes have a weak zone overlying the lower uterine pole and cervix before onset of labor. Biol Reprod. Mar. 2005;72(3):720-6. X-1. [pmid: 15548732].
1598 El Maradny E, Kanayama N, Kobayashi H, et al. The role of hyaluronic acid as a mediator and regulator of cervical ripening. Hum Reprod. May. 1997;12(5):1080-8. X-1. [pmid: 9194670].
1599 el-Ashnehi MS, Ibrahim ME, el-Tamamy H, et al. Pregnancy outcome after female infertility in Kuwait. Comparison of medical and surgical treatment. Acta Obstet Gynecol Scand. 1990;69(5):389-92. X-1. [pmid: 2270762].
1600 El-Baradie SM, Mahmoud M, Makhlouf HH. Elevated serum levels of interleukin-15, interleukin-16, and human chorionic gonadotropin in women with preeclampsia. J Obstet Gynaecol Can. Feb. 2009;31(2):142-8. X-1. [pmid: 19327213].
1601 Eldenburg L, Waller WS. Decision-case mix model for analyzing variation in cesarean rates. Med Decis Making. May-Jun. 2001;21(3):170-9. X-1. [pmid: 11386624].
1602 Elhakim M, Abd El-Megid W, Metry A, et al. Analgesic and antacid properties of i.m. tramadol given before Caesarean section under general anaesthesia. Br J Anaesth. Dec. 2005;95(6):811-5. X-9. [pmid: 16227335].
1603 Elhakim M, Fathy A, Amine H, et al. Effect of i.v. tenoxicam during caesarean delivery on platelet activity. Acta Anaesthesiol Scand. May. 2000;44(5):555-9. X-9. [pmid: 10786742].
1604 Elhakim M, Nafie M. I.v. tenoxicam for analgesia during caesarean section. Br J Anaesth. Jun. 1995;74(6):643-6. X-9. [pmid: 7640116].
1605 El-Kak F, Chaaya M, Campbell O, et al. Patterns of antenatal care in low-versus high-risk pregnancies in Lebanon. East Mediterr Health J. May. 2004;10(3):268-76. X-1. [pmid: 16212201].
1606 Elkins TE, Brown D, Barclay M, et al. Maternal-fetal conflict a study of physician concerns in court ordered cesarean sections. J Clin Ethics. Winter. 1990;1(4):316-9. X-1. [pmid: 2131088].
1607 Eller DP, VanDorsten JP. Route of delivery for the breech presentation: a conundrum. Am J Obstet Gynecol. Aug. 1995;173(2):393-6. discussion 396-8. X-1, X-2. [pmid: 7645613].
1608 Ellestad SC, Swamy GK, Sinclair T, et al. Preterm premature rupture of membrane management--inpatient versus outpatient: a retrospective review. Am J Perinatol. Jan. 2008;25(1):69-73. X-1. [pmid: 18075965].
1609 Elliott CL, Brennand JE, Calder AA. The effects of mifepristone on cervical ripening and labor induction in primigravidae. Obstet Gynecol. Nov. 1998;92(5):804-9. X-4d. [pmid: 9794673].
1610 Elliott JP, Flaherty JF. Comparison of lavage or intravenous antibiotics at cesarean section. Obstet Gynecol. Jan. 1986;67(1):29-32. X-9. [pmid: 3510014].
1611 Elliott JP, Freeman RK, Dorchester W. Short versus long course of prophylactic antibiotics. Am J Obstet Gynecol. Aug. 1. 1982;143(7):740-4. X-9. [pmid: 7048929].
1612 Elliott JP, Russell MM, Dickason LA. The labor-adjusted cesarean section rate--a more informative method than the cesarean section “rate” for assessing a practitioner's labor and delivery skills. Am J Obstet Gynecol. Jul. 1997;177(1):139-43. X-1. [pmid: 9240597].
1613 Ellison J, Thomson AJ, Conkie JA, et al. Thromboprophylaxis following caesarean section--a comparison of the antithrombotic properties of three low molecular weight heparins--dalteparin, enoxaparin and tinzaparin. Thromb Haemost. Dec. 2001;86(6):1374-8. X-9. [pmid: 11776302].
1614 el-Mardi AA, el-Qarmalawi MA, Siddik M, et al. A comparison of single prostaglandin E2 vaginal tablet with prostaglandin E2 vaginal pessaries for induction of labor at term. Int J Gynaecol Obstet. Jul. 1991;35(3):221-4. X-4d. [pmid: 1677625].
1615 Elnour AA, El Mugammar IT, Jaber T, et al. Pharmaceutical care of patients with gestational diabetes mellitus. J Eval Clin Pract. Feb. 2008;14(1):131-40. X-4e, X-5. [pmid: 18211656].
1616 Elphick MC, Filshie GM, Hull D. The passage of fat emulsion across the human placenta. Br J Obstet Gynaecol. Aug. 1978;85(8):610-8. X-9. [pmid: 687541].
1617 el-Qarmalawi AM, Elmardi AA, Saddik M, et al. A comparative randomized study of oral prostaglandin E2 (PGE2) tablets and intravenous oxytocin in induction of labor in patients with premature rupture of membranes before 37 weeks of pregnancy. Int J Gynaecol Obstet. Oct. 1990;33(2):115-9. X-4d, X-4e. [pmid: 1976543].
1618 el-Qarmalawi AM, Morsy AH, al-Fadly A, et al. Labetalol vs. methyldopa in the treatment of pregnancy-induced hypertension. Int J Gynaecol Obstet. May. 1995;49(2):125-30. X-3, X-4e, X-5. [pmid: 7649315].
1619 El-Sayed YY, Watkins MM, Fix M, et al. Perinatal outcomes after successful and failed trials of labor after cesarean delivery. Am J Obstet Gynecol. Jun. 2007;196(6):583 e1-5. discussion 583 e5. X-1. [pmid: 17547905].
1620 El-Sherbiny MT, El-Gharieb IH, Gewely HA. Vaginal misoprostol for induction of labor: 25 vs. 50 microg dose regimen. Int J Gynaecol Obstet. Jan. 2001;72(1):25-30. X-4d, X-5. [pmid: 11146073].
1621 Elson JA, Paech MJ. EMLA cream prior to insertion of elective epidurals. Anaesth Intensive Care. Jun. 1995;23(3):339-41. X-9. [pmid: 7573921].
1622 El-Tahan MR, Warda OM, Diab DG, et al. A randomized study of the effects of perioperative i.v. lidocaine on hemodynamic and hormonal responses for cesarean section. J Anesth. 2009;23(2):215-21. X-9. [pmid: 19444560].
1623 El-Tahan MR, Warda OM, Yasseen AM, et al. A randomized study of the effects of preoperative ketorolac on general anaesthesia for caesarean section. Int J Obstet Anesth. Jul. 2007;16(3):214-20. X-9. [pmid: 17459695].
1624 Emanuelli M, Giannubilo SR, Landi B, et al. Placental overexpression of transforming growth factor-beta3 in the HELLP syndrome. Gynecol Obstet Invest. 2008;65(1):1-5. X-1. [pmid: 17671384].
1625 Emanuelli M, Sartini D, Rossi V, et al. Alpha-hemoglobin-stabilizing protein (AHSP) in hemolysis, elevated liver enzyme, and low platelet (HELLP) syndrome, intrauterine growth restriction (IUGR) and fetal death. Cell Stress Chaperones. Spring. 2008;13(1):67-71. X-1. [pmid: 18347943].
1626 Emmer PM, Joosten I, Schut MH, et al. Shift in expression of HLA-G mRNA spliceforms in pregnancies complicated by preeclampsia. J Soc Gynecol Investig. May. 2004;11(4):220-6. X-1.
1627 Emmett CL, Murphy DJ, Patel RR, et al. Decision-making about mode of delivery after previous caesarean section: development and piloting of two computer-based decision aids. Health Expect. Jun. 2007;10(2):161-72. X-1. [pmid: 17524009].
1628 Emmett CL, Shaw AR, Montgomery AA, et al. Women's experience of decision making about mode of delivery after a previous caesarean section: the role of health professionals and information about health risks. BJOG. Dec. 2006;113(12):1438-45. X-1. [pmid: 17081180].
1629 Eneh AU, Fiebai PO, Anya SE, et al. Perinatal outcome among elderly nulliparae at the University of Port Harcourt Teaching Hospital. Niger J Med. Jan-Mar. 2004;13(1):44-7. X-1. [pmid: 15296107].
1630 Engelhardt S, Zieger W, Kassubek J, et al. Tocolytic therapy with fenoterol induces selective down-regulation of beta-adrenergic receptors in human myometrium. J Clin Endocrinol Metab. Apr. 1997;82(4):1235-42. X-1. [pmid: 9100601].
1631 Eniola AO, Bako AU, Selo-Ojeme DO. Risk factors for placenta praevia in southern Nigeria. East Afr Med J. Oct. 2002;79(10):535-8. X-1. [pmid: 12635759].
1632 Ennen CS, Bofill JA, Magann EF, et al. Risk factors for cesarean delivery in preterm, term and post-term patients undergoing induction of labor with an unfavorable cervix. Gynecol Obstet Invest. 2009;67(2):113-7. X-1, X-4e, X-5. [pmid: 18971583].
1633 Enriquez R, Griffin MR, Carroll KN, et al. Effect of maternal asthma and asthma control on pregnancy and perinatal outcomes. J Allergy Clin Immunol. Sep. 2007;120(3):625-30. X-1. [pmid: 17658591].
1634 Entrekin K, Work B, Owen J. Does a high carbohydrate preparatory diet affect the 3-hour oral glucose tolerance test in pregnancy?. J Matern Fetal Med. Mar-Apr. 1998;7(2):68-71. X-1, X-4e, X-5. [pmid: 9584817].
1635 Epstein AJ, Nicholson S. The formation and evolution of physician treatment styles: an application to cesarean sections. J Health Econ. Dec. 2009;28(6):1126-40. X-1. [pmid: 19800141].
1636 Erata YE, Kilic B, Guclu S, et al. Risk factors for pelvic surgery. Arch Gynecol Obstet. Nov. 2002;267(1):14-8. X-1. [pmid: 12410367].
1637 Erb L, Hill G, Houston D. A survey of parents' attitudes toward their cesarean births in Manitoba hospitals. Birth. Summer. 1983;10(2):85-92. X-1, X-9. [pmid: 6552195].
1638 Erdemoglu M, Kale A, Kuyumcuoglu U, et al. Umbilical cord prolapse in the southeast region of Turkey: evaluation of 79 cases. Clin Exp Obstet Gynecol. 2010;37(2):141-3. X-1. [pmid: 21077508].
1639 Erez O, Dukler D, Novack L, et al. Trial of labor and vaginal birth after cesarean section in patients with uterine Mullerian anomalies: a population-based study. Am J Obstet Gynecol. Jun. 2007;196(6):537 e1-11. X-1. [pmid: 17547885].
1640 Erez-Weiss I, Erez O, Shoham-Vardi I, et al. The association between maternal obesity, glucose intolerance and hypertensive disorders of pregnancy in nondiabetic pregnant women. Hypertens Pregnancy. 2005;24(2):125-36. X-1. [pmid: 16036397].
1641 Eriksen NL, Buttino L Jr. Vaginal birth after cesarean: a comparison of maternal and neonatal morbidity to elective repeat cesarean section. Am J Perinatol. Oct. 1989;6(4):375-9. X-1. [pmid: 2789534].
1642 Eriksen NL, Hostetter M, Parisi VM. Prophylactic amnioinfusion in pregnancies complicated by thick meconium. Am J Obstet Gynecol. Oct. 1994;171(4):1026-30. X-4e, X-5. [pmid: 7943066].
1643 Eriksson SL, Frykholm P, Stenlund PM, et al. A comparison of three doses of sufentanil in combination with bupivacaine-adrenaline in continuous epidural analgesia during labour. Acta Anaesthesiol Scand. Sep. 2000;44(8):919-23. X-4d. [pmid: 10981566].
1644 Erkkola R, Lammintausta R, Liukko P. Maternal and fetal plasma renin activity during ritodrine infusion to the mother. Biol Neonate. 1979;35(5-6):268-72. X-1. [pmid: 476199].
1645 Eroglu D, Lembet A, Ozdemir FN, et al. Pregnancy during hemodialysis: perinatal outcome in our cases. Transplant Proc. Jan-Feb. 2004;36(1):53-5. X-1. [pmid: 15013299].
1646 Eroglu D, Oktem M, Yanik F, et al. Labor induction at term: a comparison of the effects of 50 microg and 25 microg vaginal misoprostol. Clin Exp Obstet Gynecol. 2007;34(2):102-5. X-4d. [pmid: 17629164].
1647 Ersdal HL, Verkuyl DA, Bjorklund K, et al. Symphysiotomy in Zimbabwe; postoperative outcome, width of the symphysis joint, and knowledge, attitudes and practice among doctors and midwives. PLoS One. 2008;3(10):e3317. X-1. [pmid: 18846216].
1648 Ertan AK, He JP, Tanriverdi HA, et al. Comparison of perinatal outcome in fetuses with reverse or absent enddiastolic flow in the umbilical artery and/or fetal descending aorta. J Perinat Med. 2003;31(4):307-12. X-1. [pmid: 12951886].
1649 Ertunc D, Tok E, Dilek U, et al. The effect of carbohydrate intolerance on neonatal birth weight in pregnant women without gestational diabetes mellitus. Ann Saudi Med. Jul-Aug. 2004;24(4):280-3. X-1. [pmid: 15387495].
1650 Esakoff TF, Caughey AB, Block-Kurbisch I, et al. Perinatal outcomes in patients with gestational diabetes mellitus by race/ethnicity. J Matern Fetal Neonatal Med. Mar. 2011;24(3):422-6. X-1. [pmid: 20642385].
1651 Escudero F, Contreras H. A comparative trial of labor induction with misoprostol versus oxytocin. Int J Gynaecol Obstet. May. 1997;57(2):139-43. X-4d. [pmid: 9184950].
1652 Escumalha M, Gouveia C, Cunha M, et al. Neonatal morbidity and outcome of live born premature babies after attempted illegal abortion with misoprostol. Pediatr Nurs. May-Jun. 2005;31(3):228-31. X-1. [pmid: 16060589].
1653 Eskandar O, Shet D. Risk factors for 3rd and 4th degree perineal tear. J Obstet Gynaecol. Feb. 2009;29(2):119-22. X-1. [pmid: 19274544].
1654 Eslamian L, Marsoosi V, Pakneeyat Y. Increased intravenous fluid intake and the course of labor in nulliparous women. Int J Gynaecol Obstet. May. 2006;93(2):102-5. X-5. [pmid: 16542657].
1655 Esmaoglu A, Ulgey A, Akin A, et al. Comparison between dexmedetomidine and midazolam for sedation of eclampsia patients in the intensive care unit. J Crit Care. Dec. 2009;24(4):551-5. X-9. [pmid: 19327948].
1656 Espinoza LG. Dissecting women, dissecting law the court ordering of caesarean section operations and the failure of informed consent to protect women of color. Natl Black Law J. 1994;13:211-37. X-1. [pmid: 11660478].
1657 Esposito MA, Menihan CA, Malee MP. Association of interpregnancy interval with uterine scar failure in labor: a case-control study. Am J Obstet Gynecol. Nov. 2000;183(5):1180-3. X-1. [pmid: 11084563].
1658 Essel JK, Opai-Tetteh ET. Macrosomia--maternal and fetal risk factors. S Afr Med J. Jan. 1995;85(1):43-6. X-1. [pmid: 7784919].
1659 Essen B, Johnsdotter S, Hovelius B, et al. Qualitative study of pregnancy and childbirth experiences in Somalian women resident in Sweden. BJOG. Dec. 2000;107(12):1507-12. X-1. [pmid: 11192108].
1660 Estrade S, Schmitz T, Cabrol D, et al. History of cesarean before 32 weeks' gestation and trial of labor: what is the risk of uterine rupture?. Acta Obstet Gynecol Scand. 2009;88(2):149-53. X-1. [pmid: 18951216].
1661 Etchin A, Perl A, Bider D, et al. Prevention of a side effect of epidural morphine by epidural steroid administration in cesarean section. Gynecol Obstet Invest. 1990;29(4):305-6. X-9. [pmid: 2193858].
1662 Euliano TY, Marossero D, Nguyen MT, et al. Spatiotemporal electrohysterography patterns in normal and arrested labor. Am J Obstet Gynecol. Jan. 2009;200(1):54 e1-7. X-1. [pmid: 19121657].
1663 Eure CR, Lindsay MK, Graves WL. Risk of adverse pregnancy outcomes in young adolescent parturients in an inner-city hospital. Am J Obstet Gynecol. May. 2002;186(5):918-20. X-1. [pmid: 12015513].
1664 Evaldson GR, Frederici H, Jullig C, et al. Hospital-associated infections in obstetrics and gynecology. Effects of surveillance. Acta Obstet Gynecol Scand. Jan. 1992;71(1):54-8. X-1. [pmid: 1315099].
1665 Evans LC, Combs CA. Increased maternal morbidity after cesarean delivery before 28 weeks of gestation. Int J Gynaecol Obstet. Mar. 1993;40(3):227-33. X-1. [pmid: 8096474].
1666 Evensen A. Topics in maternity care. Use of amniotomy in spontaneous labor. Evidence-Based Practice. 2008;11(4):8. 2. X-1.
1667 Evensen A, Dresang L. Topics in maternity care. Safety of term external cephalic version. Evidence-Based Practice. 2008;11(1):9-10. X-1.
1668 Evers IM, de Valk HW, Visser GH. Risk of complications of pregnancy in women with type 1 diabetes: nationwide prospective study in the Netherlands. BMJ. Apr. 17. 2004;328(7445):915. X-1. [pmid: 15066886].
1669 Evron S, Glezerman M, Sadan O, et al. Remifentanil: a novel systemic analgesic for labor pain. Anesth Analg. Jan. 2005;100(1):233-8. X-4e. [pmid: 15616083].
1670 Evron S, Samueloff A, Sadovsky E, et al. The effect of phenoxybenzamine on postoperative urinary complications during extradural morphine analgesia. Eur J Anaesthesiol. Mar. 1984;1(1):45-54. X-3, X-4b. [pmid: 6536506].
1671 Evron S, Schenker JG, Olshwang D, et al. Postoperative analgesia by percutaneous electrical stimulation in gynecology and obstetrics. Eur J Obstet Gynecol Reprod Biol. Nov. 1981;12(5):305-13. X-1. [pmid: 6977467].
1672 Ewart MC, Yau G, Gin T, et al. A comparison of the effects of omeprazole and ranitidine on gastric secretion in women undergoing elective caesarean section. Anaesthesia. Jul. 1990;45(7):527-30. X-9. [pmid: 2386275].
1673 Ewert K, Powers B, Robertson S, et al. Controlled-release misoprostol vaginal insert in parous women for labor induction: a randomized controlled trial. Obstet Gynecol. Nov. 2006;108(5):1130-7. X-4d. [pmid: 17077234].
1674 Exacoustos C, Rosati P. Ultrasound diagnosis of uterine myomas and complications in pregnancy. Obstet Gynecol. Jul. 1993;82(1):97-101. X-1. [pmid: 8515934].
1675 Eyster KM, Teixeira F, Zakar T, et al. Protein kinase-C stimulatory activity in human amnion cytosol. J Clin Endocrinol Metab. Feb. 1993;76(2):424-8. X-1. [pmid: 8432785].
1676 Ezechi OC, Kalu BK, Njokanma FO, et al. Uterine incision closure at caesarean section: a randomised comparative study of intraperitoneal closure and closure after temporary exteriorisation. West Afr J Med. Jan-Mar. 2005;24(1):41-3. X-9. [pmid: 15909709].
1677 Ezechi OC, Ndububa VI, Loto OM, et al. Pregnancy, obstetric and neonatal outcome after assisted reproduction in Nigerians. J Matern Fetal Neonatal Med. Apr. 2008;21(4):261-6. X-1. [pmid: 18330823].
1678 Ezimokhai M, Joseph A, Bradley-Watson P. Audit of pregnancies complicated by diabetes from one center five years apart with selective versus universal screening. Ann N Y Acad Sci. Nov. 2006;1084:132-40. X-1, X-4d. [pmid: 17151297].
1679 Ezimokhai M, Rizk DE, Thomas L. Abnormal vascular coiling of the umbilical cord in gestational diabetes mellitus. Arch Physiol Biochem. Jul. 2001;109(3):209-14. X-1. [pmid: 11880923].
1680 Ezra Y, Shveiky D, Ophir E, et al. Intensive management and early delivery reduce antenatal mortality in monoamniotic twin pregnancies. Acta Obstet Gynecol Scand. May. 2005;84(5):432-5. X-1. [pmid: 15842206].
1681 Faas-Fehervary P, Schwarz K, Bauer L, et al. Caesarean section on demand: influence of personal birth experience and working environment on attitude of German gynaecologists. Eur J Obstet Gynecol Reprod Biol. Oct. 1. 2005;122(2):162-6. X-1. [pmid: 16219516].
1682 Faber-Nijholt R, Huisjes HJ, Touwen BC, et al. Neurological follow-up of 281 children born in breech presentation: a controlled study. Br Med J (Clin Res Ed). Jan. 1. 1983;286(6358):9-12. X-1.
1683 Faccenda KA, Simpson AM, Henderson DJ, et al. A comparison of levobupivacaine 0.5% and racemic bupivacaine 0.5% for extradural anesthesia for caesarean section. Reg Anesth Pain Med. Sep-Oct. 2003;28(5):394-400. X-9. [pmid: 14556128].
1684 Facchinetti F, De Pietri R, Giunchi M, et al. Use of meclofenamic acid in gynecology and obstetrics: effects on postsurgical stress. Clin J Pain. Suppl 1. 1991;7:S60-3. X-1. [pmid: 1810523].
1685 Facchinetti F, Venturini P, Verocchi G, et al. Comparison of two preparations of dinoprostone for pre-induction of labour in nulliparous women with very unfavourable cervical condition: a randomised clinical trial. Eur J Obstet Gynecol Reprod Biol. Apr. 1. 2005;119(2):189-93. X-4d. [pmid: 15808378].
1686 Fadda GM, Cherchi PL, D'Antona D, et al. Umbilical artery pulsatility index in pregnancies complicated by insulin-dependent diabetes mellitus without hypertension. Gynecol Obstet Invest. 2001;51(3):173-7. X-1. [pmid: 11306904].
1687 Fadel HE, Hammond SD. Diabetes mellitus and pregnancy: management and results. J Reprod Med. Feb. 1982;27(2):56-66. X-1, X-2. [pmid: 7097664].
1688 Fahdhy M, Chongsuvivatwong V. Evaluation of World Health Organization partograph implementation by midwives for maternity home birth in Medan, Indonesia. Midwifery. Dec. 2005;21(4):301-10. X-1. [pmid: 16076515].
1689 Fait G, Daniel Y, Lessing JB, et al. Can labor with breech presentation be induced?. Gynecol Obstet Invest. 1998;46(3):181-6. X-1. [pmid: 9736800].
1690 Fakeye O. The incidence, sociobiological factors and obstetric complications associated with large infants at Ilorin, Nigeria. Int J Gynaecol Obstet. Dec. 1988;27(3):343-7. X-1. [pmid: 2904895].
1691 Falhammar H, Davis B, Bond D, et al. Maternal and neonatal outcomes in the Torres Strait Islands with a sixfold increase in type 2 diabetes in pregnancy over six years. Aust N Z J Obstet Gynaecol. Apr. 2010;50(2):120-6. X-1. [pmid: 20522066].
1692 Fallis WM, Hamelin K, Symonds J, et al. Maternal and newborn outcomes related to maternal warming during cesarean delivery. J Obstet Gynecol Neonatal Nurs. May-Jun. 2006;35(3):324-31. X-9.
1693 Fan SZ, Susetio L, Wang YP, et al. Low dose of intrathecal hyperbaric bupivacaine combined with epidural lidocaine for cesarean section--a balance block technique. Anesth Analg. Mar. 1994;78(3):474-7. X-9. [pmid: 8109762].
1694 Fanaroff AA, Wright LL, Stevenson DK, et al. Very-low-birth-weight outcomes of the National Institute of Child Health and Human Development Neonatal Research Network, May 1991 through December 1992. Am J Obstet Gynecol. Nov. 1995;173(5):1423-31. X-1. [pmid: 7503180].
1695 Fanning RA, Briggs LP, Carey MF. Epidural analgesia practices for labour: results of a 2005 national survey in Ireland. Eur J Anaesthesiol. Mar. 2009;26(3):235-44. X-1. [pmid: 19237985].
1696 Fanshawe MP. A comparison of patient controlled epidural pethidine versus single dose epidural morphine for analgesia after caesarean section. Anaesth Intensive Care. Dec. 1999;27(6):610-4. X-9. [pmid: 10631415].
1697 Fantini MP, Stivanello E, Frammartino B, et al. Risk adjustment for inter-hospital comparison of primary cesarean section rates: need, validity and parsimony. BMC Health Serv Res. 2006;6:100. X-1. [pmid: 16911770].
1698 Farah LA, Sanchez-Ramos L, Rosa C, et al. Randomized trial of two doses of the prostaglandin E1 analog misoprostol for labor induction. Am J Obstet Gynecol. Aug. 1997;177(2):364-9. discussion 369-71. X-3. [pmid: 9290452].
1699 Faro S, Martens M, Hammill H, et al. Ticarcillin/clavulanic acid versus clindamycin and gentamicin in the treatment of post-cesarean endometritis following antibiotic prophylaxis. Obstet Gynecol. May. 1989;73(5 Pt 1):808-12. X-9. [pmid: 2704510].
1700 Faro S, Martens M, Phillips LE, et al. Ticarcillin disodium/clavulanate potassium versus clindamycin/gentamicin in the treatment of postpartum endometritis. J Reprod Med. Jun. 1988;33(6 Suppl):603-6. X-9. [pmid: 3294407].
1701 Faro S, Martens MG, Hammill HA, et al. Antibiotic prophylaxis: is there a difference?. Am J Obstet Gynecol. Apr. 1990;162(4):900-7. discussion 907-9. X-9. [pmid: 2183617].
1702 Faro S, Sanders CV, Aldridge KE. Use of single-agent antimicrobial therapy in the treatment of polymicrobial female pelvic infections. Obstet Gynecol. Aug. 1982;60(2):232-6. X-1. [pmid: 6760009].
1703 Farr SL, Jamieson DJ, Rivera HV, et al. Risk factors for cesarean delivery among Puerto Rican women. Obstet Gynecol. Jun. 2007;109(6):1351-7. X-1. [pmid: 17540807].
1704 Farrar D, Tuffnell D, Airey R, et al. Care during the third stage of labour: a postal survey of UK midwives and obstetricians. BMC Pregnancy Childbirth. 2010;10:23. X-1. [pmid: 20492659].
1705 Farrell SA, Baskett TF, Farrell KD. The choice of elective cesarean delivery in obstetrics: a voluntary survey of Canadian health care professionals. Int Urogynecol J Pelvic Floor Dysfunct. Sep-Oct. 2005;16(5):378-83. X-1. [pmid: 15976987].
1706 Farshchi A, Ghiasi G. Comparison the analgesic effects of single dose administration of tramadol or piroxicam on postoperative pain after cesarean delivery. Acta Med Iran. May-Jun. 2010;48(3):148-53. X-9. [pmid: 21137649].
1707 Fasciolo A, Pedretti L, Alessandri F, et al. Intrauterine infusion of levobupivacaine vs. placebo associated towound [sic] infiltration in elective caesarean delivery. Internet Journal of Anesthesiology. 2009;20(2):14-14. X-9.
1708 Fassett MJ, Dhillon SH, Williams TR. Effects on perinatal outcome of treating women with 1 elevated glucose tolerance test value. Am J Obstet Gynecol. Jun. 2007;196(6):597 e1-4. discussion 597 e4. X-1. [pmid: 17547912].
1709 Fassoulaki A, Gatzou V, Petropoulos G, et al. Spread of subarachnoid block, intraoperative local anaesthetic requirements and postoperative analgesic requirements in Caesarean section and total abdominal hysterectomy. Br J Anaesth. Nov. 2004;93(5):678-82. X-9. [pmid: 15347609].
1710 Fassoulaki A, Staikou C, Melemeni A, et al. Anaesthesia preference, neuraxial vs general, and outcome after caesarean section. J Obstet Gynaecol. 2010;30(8):818-21. X-9. [pmid: 21126120].
1711 Fasubaa OB, Ezechi OC, Orji EO, et al. Delivery of the impacted head of the fetus at caesarean section after prolonged obstructed labour: a randomised comparative study of two methods. J Obstet Gynaecol. Jul. 2002;22(4):375-8. X-1. [pmid: 12521457].
1712 Fasubaa OB, Ogunniyi SO, Dare FO, et al. Uncomplicated Caesarean section: is prolonged hospital stay necessary?. East Afr Med J. Aug. 2000;77(8):448-51. X-1. [pmid: 12862072].
1713 Fatoye FO, Adeyemi AB, Oladimeji BY. Emotional distress and its correlates among Nigerian women in late pregnancy. J Obstet Gynaecol. Aug. 2004;24(5):504-9. X-1. [pmid: 15369927].
1714 Fatoye FO, Oladimeji BY, Adeyemi AB. Difficult delivery and some selected factors as predictors of early postpartum psychological symptoms among Nigerian women. J Psychosom Res. Mar. 2006;60(3):299-301. X-1. [pmid: 16516663].
1715 Fausett MB, Barth WH Jr., Yoder BA, et al. Oxytocin labor stimulation of twin gestations: effective and efficient. Obstet Gynecol. Aug. 1997;90(2):202-4. X-1. [pmid: 9241293].
1716 Fauveau V. Program Note: Using UN process indicators to assess needs in emergency obstetric services: Gabon, Guinea-Bissau, and The Gambia. Int J Gynaecol Obstet. Mar. 2007;96(3):233-40. X-1. [pmid: 17291505].
1717 Fawcett J. Needs of cesarean birth parents. JOGN Nurs. Sep-Oct. 1981;10(5):372-6. X-9. [pmid: 6912892].
1718 Fawcett J, Aber C, Weiss M. Teaching, practice, and research: an integrative approach benefiting students and faculty. J Prof Nurs. Jan-Feb. 2003;19(1):17-21. X-1. [pmid: 12649815].
1719 Fawcett J, Burritt J. An exploratory study of antenatal preparation for cesarean birth. Journal of Obstetric, Gynecologic, and Neonatal Nursing. 1985;14(3):224-230. X-9.
1720 Fawcett J, Knauth D. The factor structure of the perception of birth scale. Nurs Res. Mar-Apr. 1996;45(2):83-6. X-1. [pmid: 8604369].
1721 Fawcett J, Pollio N, Tully A. Women's perceptions of cesarean and vaginal delivery: another look. Res Nurs Health. Dec. 1992;15(6):439-46. X-1. [pmid: 1448575].
1722 Fawcett J, Pollio N, Tully A. Women's perceptions of cesarean and vaginal delivery: another look. Res Nurs Health. Dec. 1992;15(6):439-46. X-1. [pmid: 1448575].
1723 Fawcett J, Tulman L, Spedden J. Responses to vaginal birth after cesarean section. J Obstet Gynecol Neonatal Nurs. Mar-Apr. 1994;23(3):253-9. X-1.
1724 Fawzy M, Abdel-Hady el S. Midtrimester abortion using vaginal misoprostol for women with three or more prior cesarean deliveries. Int J Gynaecol Obstet. Jul. 2010;110(1):50-2. X-1. [pmid: 20362989].
1725 Faydaci F, Gunaydin B. Different preloading protocols with constant ephedrine infusion in the prevention of hypotension for elective cesarean section under spinal anesthesia. Acta Anaesthesiol Belg. 2011;62(1):5-10. X-9. [pmid: 21612139].
1726 Faye A, Pornprasert S, Mary JY, et al. Characterization of the main placental cytokine profiles from HIV-1-infected pregnant women treated with anti-retroviral drugs in France. Clin Exp Immunol. Sep. 2007;149(3):430-9. X-1. [pmid: 17511776].
1727 Fayed HM, Abid SF, Stevens B. Risk factors in extreme grand multiparity. Int J Gynaecol Obstet. Apr. 1993;41(1):17-22. X-1. [pmid: 8098289].
1728 Fedele D, Lapolla A. A protocol of screening of gestational diabetes mellitus. Ann Ist Super Sanita. 1997;33(3):383-7. X-4e. [pmid: 9542267].
1729 Feingold M, Cetrulo C, Peters M, et al. Mode of delivery in multiple birth of higher order. Acta Genet Med Gemellol (Roma). 1988;37(1):105-9. X-1. [pmid: 3223206].
1730 Feinmann J. How to limit caesareans on demand--too NICE to push?. Lancet. Mar. 2. 2002;359(9308):774. X-1, X-2. [pmid: 11888604].
1731 Feinstein U, Sheiner E, Levy A, et al. Risk factors for arrest of descent during the second stage of labor. Int J Gynaecol Obstet. Apr. 2002;77(1):7-14. X-1. [pmid: 11929650].
1732 Feldberg D, Dicker D, Samuel N, et al. Intrapartum management of insulin-dependent diabetes mellitus (IDDM) gestants. A comparative study of constant intravenous insulin infusion and continuous subcutaneous insulin infusion pump (CSIIP). Acta Obstet Gynecol Scand. 1988;67(4):333-8. X-4e. [pmid: 3051881].
1733 Feldman DM, Borgida AF, Trymbulak WP, et al. Clinical implications of velamentous cord insertion in triplet gestations. Am J Obstet Gynecol. Apr. 2002;186(4):809-11. X-1. [pmid: 11967512].
1734 Fenton PM. Blood transfusion for Caesarean section in Malawi. A study of requirements, amount given and effect on mortality. Anaesthesia. Nov. 1999;54(11):1055-8. X-1. [pmid: 10540094].
1735 Fenton PM, Whitty CJ, Reynolds F. Caesarean section in Malawi: prospective study of early maternal and perinatal mortality. BMJ. Sep. 13. 2003;327(7415):587. X-1. [pmid: 12969922].
1736 Fenwick J, Gamble J, Hauck Y. Believing in birth--choosing VBAC: the childbirth expectations of a self-selected cohort of Australian women. J Clin Nurs. Aug. 2007;16(8):1561-70. X-1. [pmid: 17655545].
1737 Fenwick J, Staff L, Gamble J, et al. Why do women request caesarean section in a normal, healthy first pregnancy?. Midwifery. Aug. 2010;26(4):394-400. X-1. [pmid: 19117644].
1738 Fenwick S, Holloway I, Alexander J. Achieving normality: the key to status passage to motherhood after a caesarean section. Midwifery. Oct. 2009;25(5):554-63. X-1. [pmid: 18191007].
1739 Ferara S. Every birth is unique for the mother, but for the hospital is it worth the price to use custom packs instead of basic packs?. Hosp Mater Manage. Apr. 1996;21(4):14-5. X-1. [pmid: 10155901].
1740 Ferchland A, Rettkowski O, Ponicke K, et al. Effects of uremic plasma on alpha- and beta-adrenoceptor subtypes. Nephron. Sep. 1998;80(1):46-50. X-1. [pmid: 9730702].
1741 Ferguson JE 2nd, Head BH, Frank FH, et al. Misoprostol versus low-dose oxytocin for cervical ripening: a prospective, randomized, double-masked trial. Am J Obstet Gynecol. Aug. 2002;187(2):273-9. discussion 279-80. X-4d. [pmid: 12193911].
1742 Ferguson JE 2nd, Ueland FR, Stevenson DK, et al. Oxytocin-induced labor characteristics and uterine activity after preinduction cervical priming with prostaglandin E2 intracervical gel. Obstet Gynecol. Nov. 1988;72(5):739-45. X-1. [pmid: 3173925].
1743 Fernandez CO, Bloom SL, Smulian JC, et al. A randomized placebo-controlled evaluation of terbutaline for external cephalic version. Obstet Gynecol. Nov. 1997;90(5):775-9. X-4e. [pmid: 9351763].
1744 Fernando R, Jones HM. Comparison of plain and alkalinized local anaesthetic mixtures of lignocaine and bupivacaine for elective extradural caesarean section. Br J Anaesth. Dec. 1991;67(6):699-703. X-9. [pmid: 1662978].
1745 Ferrari AG, Frigerio LG, Candotti G, et al. Can Joel-Cohen incision and single layer reconstruction reduce cesarean section morbidity?. Int J Gynaecol Obstet. Feb. 2001;72(2):135-43. X-9. [pmid: 11166746].
1746 Ferrazzani S, De Santis L, Carducci B, et al. Prostaglandin: cervical ripening in hypertensive pregnancies. Acta Obstet Gynecol Scand. Jun. 2003;82(6):510-5. X-1. [pmid: 12780421].
1747 Ferre F, Breuiller M, Cedard L. Effects of prostaglandins on cyclic nucleotide phosphodiesterase activity in the human term placenta. Prostaglandins. May. 1982;23(5):675-93. X-1. [pmid: 6289380].
1748 Ferre F, Uzan M, Janssens Y, et al. Oral administration of micronized natural progesterone in late human pregnancy. Effects on progesterone and estrogen concentrations in the plasma, placenta, and myometrium. Am J Obstet Gynecol. Jan. 1. 1984;148(1):26-34. X-1. [pmid: 6691378].
1749 Ferre F, Uzan M, Jolivet A, et al. Influence of the oral administration of micronized progesterone on plasma and tissue levels of steroids in human pregnancy. Acta Physiol Hung. 1985;65(4):443-51. X-1. [pmid: 4013776].
1750 Ferrero S, Bentivoglio G. Post-operative complications after caesarean section in HIV-infected women. Arch Gynecol Obstet. Oct. 2003;268(4):268-73. X-1. [pmid: 14504867].
1751 Ferrero S, Pretta S, Nicoletti A, et al. Myasthenia gravis: management issues during pregnancy. Eur J Obstet Gynecol Reprod Biol. Aug. 1. 2005;121(2):129-38. X-1, X-2. [pmid: 16054951].
1752 Festin MR, Laopaiboon M, Pattanittum P, et al. Caesarean section in four South East Asian countries: reasons for, rates, associated care practices and health outcomes. BMC Pregnancy Childbirth. 2009;9:17. X-1. [pmid: 19426513].
1753 Figueras-Aloy J, Jordin Y, Rodraguez-Miguelez JM, et al. Expired nitric oxide in the newborn with high risk of perinatal infection. Am J Perinatol. Apr. 2003;20(3):137-45. X-1. [pmid: 12802713].
1754 Filiz TM, Uludag C, Cinar N, et al. Risk factors for urinary incontinence in Turkish women. A cross-sectional study. Saudi Med J. Nov. 2006;27(11):1688-92. X-4e. [pmid: 17106542].
1755 Filler L, Shipley CF 3rd, Dennis EJ 3rd, et al. Postcesarean endometritis: a brief review and comparison of three antibiotic regimens. J S C Med Assoc. Jun. 1992;88(6):291-5. X-1. [pmid: 1385635].
1756 Filos KS, Goudas LC, Patroni O, et al. Intrathecal clonidine as a sole analgesic for pain relief after cesarean section. Anesthesiology. Aug. 1992;77(2):267-74. X-9. [pmid: 1642346].
1757 Filos KS, Goudas LC, Patroni O, et al. Hemodynamic and analgesic profile after intrathecal clonidine in humans. A dose-response study. Anesthesiology. Sep. 1994;81(3):591-601. discussion 27A-28A. X-9. [pmid: 8092504].
1758 Finegold H, Mandell G, Vallejo M, et al. Does spinal anesthesia cause hearing loss in the obstetric population?. Anesth Analg. Jul. 2002;95(1):198-203. table of contents. X-9. [pmid: 12088968].
1759 Finer JJ. Toward guidelines for compelling cesarean surgery: of rights, responsibility, and decisional authenticity. Minn Law Rev. Dec. 1991;76(2):239-94. X-1, X-8. [pmid: 11659551].
1760 Finkler MD, Wirtschafter DD. Why pay extra for cesarean-section deliveries?. Inquiry. Summer. 1993;30(2):208-15. X-1, X-2. [pmid: 8314609].
1761 Finkler MD, Wirtschafter DD. One health maintenance organization's experience: obstetric costs depend more on staffing patterns than on mode of delivery. J Perinatol. Mar-Apr. 1997;17(2):148-55. X-1. [pmid: 9134516].
1762 Finsen V, Storeheier AH, Aasland OG. Cesarean section: Norwegian women do as obstetricians do--not as obstetricians say. Birth. Jun. 2008;35(2):117-20. X-1. [pmid: 18507582].
1763 Finster M, Pedersen H, Strobel AF, et al. Obstetric anesthesia. Minerva Anestesiol. Oct. 1992;58(10):853-6. X-1, X-4e. [pmid: 1461473].
1764 Fiore S, Newell ML, Thorne C. Higher rates of post-partum complications in HIV-infected than in uninfected women irrespective of mode of delivery. AIDS. Apr. 9. 2004;18(6):933-8. X-1. [pmid: 15060441].
1765 Firouznia K, Ghanaati H, Sanaati M, et al. Pregnancy after uterine artery embolization for symptomatic fibroids: a series of 15 pregnancies. AJR Am J Roentgenol. Jun. 2009;192(6):1588-92. X-1. [pmid: 19457822].
1766 Fiscella K, Meldrum S, Franks P. Post partum discharge against medical advice: who leaves and does it matter?. Matern Child Health J. Sep. 2007;11(5):431-6. X-1. [pmid: 17334926].
1767 Fiscer C. A healthy baby isn't all that matters. Midwifery Today Int Midwife. Autumn. 2008;(87):16-9. X-1, X-2, X-3, X-4e, X-5. [pmid: 18839735].
1768 Fischer A, LaCoursiere DY, Barnard P, et al. Differences between hospitals in cesarean rates for term primigravidas with cephalic presentation. Obstet Gynecol. Apr. 2005;105(4):816-21. X-1. [pmid: 15802411].
1769 Fisher JT, Mortola JP, Smith B, et al. Neonatal pattern of breathing following cesarean section: epidural versus general anesthesia. Anesthesiology. Nov. 1983;59(5):385-9. X-9. [pmid: 6638544].
1770 Fisher JT, Mortola JP, Smith JB, et al. Respiration in newborns: development of the control of breathing. Am Rev Respir Dis. Jun. 1982;125(6):650-7. X-1. [pmid: 7091870].
1771 Fitzsimmons J, Nyberg DA, Cyr DR, et al. Perinatal management of gastroschisis. Obstet Gynecol. Jun. 1988;71(6 Pt 1):910-3. X-1. [pmid: 3285271].
1772 Flaherty JF, Boswell GW, Winkel CA, et al. Pharmacokinetics of cefoxitin in patients at term gestation: lavage versus intravenous administration. Am J Obstet Gynecol. Aug. 1. 1983;146(7):760-6. X-9. [pmid: 6346881].
1773 Flamm B. Cesarean delivery 1970-1995: where have we been and where are we going?. International Journal of Childbirth Education. 1994;9(4):6-7. X-4b.
1774 Flamm BL, Anton D, Goings JR, et al. Prostaglandin E2 for cervical ripening: a multicenter study of patients with prior cesarean delivery. Am J Perinatol. Mar. 1997;14(3):157-60. X-1. [pmid: 9259919].
1775 Flamm BL, Geiger AM. Vaginal birth after cesarean delivery: an admission scoring system. Obstet Gynecol. Dec. 1997;90(6):907-10. X-1. [pmid: 9397100].
1776 Flamm BL, Goings JR. Vaginal birth after cesarean section: is suspected fetal macrosomia a contraindication?. Obstet Gynecol. Nov. 1989;74(5):694-7. X-1. [pmid: 2638575].
1777 Flamm BL, Goings JR, Fuelberth NJ, et al. Oxytocin during labor after previous cesarean section: results of a multicenter study. Obstet Gynecol. Nov. 1987;70(5):709-12. X-1. [pmid: 3309751].
1778 Flamm BL, Goings JR, Liu Y, et al. Elective repeat cesarean delivery versus trial of labor: a prospective multicenter study. Obstet Gynecol. Jun. 1994;83(6):927-32. X-1. [pmid: 8190433].
1779 Flamm BL, Newman LA, Thomas SJ, et al. Vaginal birth after cesarean delivery: results of a 5-year multicenter collaborative study. Obstet Gynecol. Nov. 1990;76(5 Pt 1):750-4. X-1. [pmid: 2216218].
1780 Fleissig A. Are women given enough information by staff during labour and delivery?. Midwifery. Jun. 1993;9(2):70-5. X-1. [pmid: 8332094].
1781 Fleissig A. Prevalence of procedures in childbirth. BMJ. Feb. 20. 1993;306(6876):494-5. X-1, X-3, X-4e, X-5. [pmid: 8448462].
1782 Florio P, Benedetto C, Luisi S, et al. Activin A, inhibin A, inhibin B and parturition: changes of maternal and cord serum levels according to the mode of delivery. Br J Obstet Gynaecol. Oct. 1999;106(10):1061-5. X-1. [pmid: 10519432].
1783 Flynn RJ, Moore J, Collier PS, et al. Effect of intravenous cimetidine on lignocaine disposition during extradural caesarean section. Anaesthesia. Sep. 1989;44(9):739-41. X-9. [pmid: 2802120].
1784 Flynn RJ, Moore J, Collier PS, et al. Single dose oral H2-antagonists do not affect plasma lidocaine levels in the parturient. Acta Anaesthesiol Scand. Oct. 1989;33(7):593-6. X-9. [pmid: 2683547].
1785 Flynn RJ, Moore J, Collier PS, et al. Does pretreatment with cimetidine and ranitidine affect the disposition of bupivacaine?. Br J Anaesth. Jan. 1989;62(1):87-91. X-9. [pmid: 2917116].
1786 Fogel ST, Shyken JM, Leighton BL, et al. Epidural labor analgesia and the incidence of cesarean delivery for dystocia. Anesth Analg. Jul. 1998;87(1):119-23. X-1. [pmid: 9661559].
1787 Fogelson NS, Menard MK, Hulsey T, et al. Neonatal impact of elective repeat cesarean delivery at term: a comment on patient choice cesarean delivery. Am J Obstet Gynecol. May. 2005;192(5):1433-6. X-1. [pmid: 15902129].
1788 Folgero T, Lindal S, Oian P. Skeletal muscle ultrastructure in normal pregnancy and preeclampsia. Gynecol Obstet Invest. 2000;49(2):88-92. X-1. [pmid: 10877616].
1789 Fong J, Gurewitsch ED, Press RA, et al. Prevention of maternal hypotension by epidural administration of ephedrine sulfate during lumbar epidural anesthesia for cesarean section. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):985-90. X-9. [pmid: 8885761].
1790 Fong J, Mack PF, Gurewitsch ED. The effect of lumbar epidural anesthesia on maternal middle cerebral artery blood flow in normal pregnancy: a prospective, randomized, double-blind comparison study. Am J Obstet Gynecol. Nov. 1998;179(5):1237-40. X-9. [pmid: 9822508].
1791 Fonseca SN, Sofia MH, Quintana S, et al. Successful control program to implement the appropriate antibiotic prophylaxis for Cesarean section. Rev Inst Med Trop Sao Paulo. Mar-Apr. 2008;50(2):79-82. X-1. [pmid: 18488085].
1792 Fontaine P, Adam P. Intrathecal narcotics are associated with prolonged second-stage labor and increased oxytocin use. J Fam Pract. Jun. 2000;49(6):515-20. X-1. [pmid: 10923551].
1793 Fontein Y. The comparison of birth outcomes and birth experiences of low-risk women in different sized midwifery practices in the Netherlands. Women Birth. Sep. 2010;23(3):103-10. X-1. [pmid: 20207213].
1794 Foote AJ. External cephalic version from 34 weeks under tocolysis: factors influencing success. J Obstet Gynaecol (Tokyo 1995). Apr. 1995;21(2):127-32. X-1. [pmid: 8556574].
1795 Ford LC. Cost of antibiotic prophylaxis in cesarean section. Drug Intell Clin Pharm. Jul-Aug. 1986;20(7-8):592-3. X-9. [pmid: 3743416].
1796 Forsgren L, Sidenvall R, Blomquist HK, et al. Pre- and perinatal factors in febrile convulsions. Acta Paediatr Scand. Feb. 1991;80(2):218-25. X-1. [pmid: 2035314].
1797 Fortunato SJ, Menon R, Lombardi SJ. Interleukin-10 and transforming growth factor-beta inhibit amniochorion tumor necrosis factor-alpha production by contrasting mechanisms of action: therapeutic implications in prematurity. Am J Obstet Gynecol. Oct. 1997;177(4):803-9. X-1. [pmid: 9369823].
1798 Fortunato SJ, Menon RP, Swan KF, et al. Inflammatory cytokine (interleukins 1, 6 and 8 and tumor necrosis factor-alpha) release from cultured human fetal membranes in response to endotoxic lipopolysaccharide mirrors amniotic fluid concentrations. Am J Obstet Gynecol. Jun. 1996;174(6):1855-61. discussion 1861-2. X-1. [pmid: 8678151].
1799 Fossa SD, Magelssen H, Melve K, et al. Parenthood in survivors after adulthood cancer and perinatal health in their offspring: a preliminary report. J Natl Cancer Inst Monogr. 2005;(34):77-82. X-1. [pmid: 15784830].
1800 Foster WH, Mjekevu T, Olsen G, et al. Low spinal anaesthesia combined with local anaesthesia for caesarean section--an evaluation. S Afr Med J. Jan. 1. 1983;63(1):17-20. X-9. [pmid: 6849145].
1801 Fournier P, Dumont A, Tourigny C, et al. Improved access to comprehensive emergency obstetric care and its effect on institutional maternal mortality in rural Mali. Bull World Health Organ. Jan. 2009;87(1):30-8. X. [pmid: 19197402].
1802 Fovargue S, Miola J. Policing pregnancy: implications of the Attorney General's Reference (No. 3 of 1994). Med Law Rev. Autumn. 1998;6(3):265-96. X-1, X-2. [pmid: 11658019].
1803 Fox S. All-Wales clinical pathway for normal labour: a way to reducing unnecessary intervention?. RCM Midwives. May. 2004;7(5):216-9. X-1. [pmid: 15232958].
1804 Frambach T, Muller T, Freund S, et al. Self-limitation of intravenous tocolysis with beta2-adrenergic agonists is mediated through receptor G protein uncoupling. J Clin Endocrinol Metab. May. 2005;90(5):2882-7. X-1. [pmid: 15728216].
1805 Franchi M, Ghezzi F, Raio L, et al. Joel-Cohen or Pfannenstiel incision at cesarean delivery: does it make a difference?. Acta Obstet Gynecol Scand. Nov. 2002;81(11):1040-6. X-1. [pmid: 12421172].
1806 Francois S, Dresang L. Herpes prophylaxis during pregnancy. Evidence-Based Practice. 2009;12(1):11-12.
1807 Fraser J. Last word. The villains of the piece. Pract Midwife. Jun. 2006;9(6):46. X-1, X-2, X-4e, X-5. [pmid: 16830849].
1808 Fraser J, Bale B. Women should not be able to opt for a caesarean. Nurs Times. Oct. 20-26. 1999;95(42):34. X-1, X-2. [pmid: 10788882].
1809 Fraser W, Maunsell E, Hodnett E, et al. Randomized controlled trial of a prenatal vaginal birth after cesarean section education and support program. Childbirth Alternatives Post-Cesarean Study Group. Am J Obstet Gynecol. Feb. 1997;176(2):419-25. X-4e. [pmid: 9065192].
1810 Fraser W, Usher RH, McLean FH, et al. Temporal variation in rates of cesarean section for dystocia: does “convenience” play a role?. Am J Obstet Gynecol. Feb. 1987;156(2):300-4. X-1. [pmid: 3826164].
1811 Fraser WD, Hofmeyr J, Lede R, et al. Amnioinfusion for the prevention of the meconium aspiration syndrome. N Engl J Med. Sep. 1. 2005;353(9):909-17. X-4e. [pmid: 16135835].
1812 Fraser WD, Marcoux S, Krauss I, et al. Multicenter, randomized, controlled trial of delayed pushing for nulliparous women in the second stage of labor with continuous epidural analgesia. The PEOPLE (Pushing Early or Pushing Late with Epidural) Study Group. Am J Obstet Gynecol. May. 2000;182(5):1165-72. X-4e. [pmid: 10819854].
1813 Fraser WD, Marcoux S, Moutquin JM, et al. Effect of early amniotomy on the risk of dystocia in nulliparous women. The Canadian Early Amniotomy Study Group. N Engl J Med. Apr. 22. 1993;328(16):1145-9. X. [pmid: 8257472].
1814 Fraser WD, Sauve R, Parboosingh IJ, et al. A randomized controlled trial of early amniotomy. Br J Obstet Gynaecol. Jan. 1991;98(1):84-91. X-4a, X-4e, X-5. [pmid: 1998638].
1815 Fredman B, Shapiro A, Zohar E, et al. The analgesic efficacy of patient-controlled ropivacaine instillation after Cesarean delivery. Anesth Analg. Dec. 2000;91(6):1436-40. X-9. [pmid: 11093995].
1816 Freedman RA, Bauer KA, Neuberg DS, et al. Timing of postpartum enoxaparin administration and severe postpartum hemorrhage. Blood Coagul Fibrinolysis. Jan. 2008;19(1):55-9. X-1. [pmid: 18180616].
1817 Freeman K, Oakley L, Pollak A, et al. Association between congenital toxoplasmosis and preterm birth, low birthweight and small for gestational age birth. BJOG. Jan. 2005;112(1):31-7. X-1. [pmid: 15663394].
1818 Freeman RK, Garite TJ, Mondanlou H, et al. Postdate pregnancy: utilization of contraction stress testing for primary fetal surveillance. Am J Obstet Gynecol. May. 15. 1981;140(2):128-35. X-1. [pmid: 7234908].
1819 Freitas PF, Drachler Mde L, Leite JC, et al. Inequalities in cesarean delivery rates by ethnicity and hospital accessibility in Brazil. Int J Gynaecol Obstet. Dec. 2009;107(3):198-201. X-1. [pmid: 19782979].
1820 French GW, White JB, Howell SJ, et al. Comparison of pentastarch and Hartmann's solution for volume preloading in spinal anaesthesia for elective caesarean section. Br J Anaesth. Sep. 1999;83(3):475-7. X-9. [pmid: 10655924].
1821 Frenckner BP, Lally PA, Hintz SR, et al. Prenatal diagnosis of congenital diaphragmatic hernia: how should the babies be delivered?. J Pediatr Surg. Sep. 2007;42(9):1533-8. X-1. [pmid: 17848244].
1822 Freyschuss U, Gentz J, Noack G, et al. Circulatory adaptation in newborn infants of strictly controlled diabetic mothers. Acta Paediatr Scand. Mar. 1982;71(2):209-15. X-1. [pmid: 7136629].
1823 Friedman JE, Ishizuka T, Shao J, et al. Impaired glucose transport and insulin receptor tyrosine phosphorylation in skeletal muscle from obese women with gestational diabetes. Diabetes. Sep. 1999;48(9):1807-14. X-1. [pmid: 10480612].
1824 Fries KS. African American women & unplanned cesarean birth. MCN Am J Matern Child Nurs. Mar-Apr. 2010;35(2):110-5. X-1. [pmid: 20215953].
1825 Frishman GN, Schwartz T, Hogan JW. Closure of Pfannenstiel skin incisions. Staples vs. subcuticular suture. J Reprod Med. Oct. 1997;42(10):627-30. X-9. [pmid: 9350017].
1826 Fritel X, Rollot O, Gerardin P, et al. Chikungunya virus infection during pregnancy, Reunion, France, 2006. Emerg Infect Dis. Mar. 2010;16(3):418-25. X-1. [pmid: 20202416].
1827 Frohlich J. Obesity in pregnancy. MIDIRS Midwifery Digest. 2002;12(1):39-43. X-1, X-2.
1828 Frohn WE, Simmons S, Carlan SJ. Prostaglandin E2 gel versus misoprostol for cervical ripening in patients with premature rupture of membranes after 34 weeks. Obstet Gynecol. Feb. 2002;99(2):206-10. X-4e. [pmid: 11814498].
1829 Frolich MA. Role of the atrial natriuretic factor in obstetric spinal hypotension. Anesthesiology. Aug. 2001;95(2):371-6. X-1. [pmid: 11506108].
1830 Frolich MA, Burchfield DJ, Euliano TY, et al. A single dose of fentanyl and midazolam prior to Cesarean section have no adverse neonatal effects. Can J Anaesth. Jan. 2006;53(1):79-85. X-9. [pmid: 16371613].
1831 Frost J, Shaw A, Montgomery A, et al. Women's views on the use of decision aids for decision making about the method of delivery following a previous caesarean section: qualitative interview study. BJOG. Jun. 2009;116(7):896-905. X-1, X-4b. [pmid: 19385964].
1832 Fuglenes D, Oian P, Gyrd-Hansen D, et al. Norwegian obstetricians' opinions about cesarean section on maternal request: should women pay themselves?. Acta Obstet Gynecol Scand. Dec. 2010;89(12):1582-8. X-1. [pmid: 20925586].
1833 Fujii Y, Numazaki M. Dose-range effects of propofol for reducing emetic symptoms during cesarean delivery. Obstet Gynecol. Jan. 2002;99(1):75-9. X-9. [pmid: 11777514].
1834 Fujii Y, Numazaki M. Randomized, double-blind comparison of subhypnotic-dose propofol alone and combined with dexamethasone for emesis in parturients undergoing cesarean delivery. Clin Ther. Aug. 2004;26(8):1286-91. X-9. [pmid: 15476909].
1835 Fujii Y, Saitoh Y, Tanaka H, et al. Granisetron/dexamethasone combination for reducing nausea and vomiting during and after spinal anesthesia for cesarean section. Anesth Analg. Jun. 1999;88(6):1346-50. X-9. [pmid: 10357343].
1836 Fujii Y, Tanaka H, Toyooka H. Granisetron prevents nausea and vomiting during spinal anaesthesia for caesarean section. Acta Anaesthesiol Scand. Mar. 1998;42(3):312-5. X-9. [pmid: 9542558].
1837 Fujii Y, Tanaka H, Toyooka H. Prevention of nausea and vomiting with granisetron, droperidol and metoclopramide during and after spinal anaesthesia for caesarean section: a randomized, double-blind, placebo-controlled trial. Acta Anaesthesiol Scand. Sep. 1998;42(8):921-5. X-9. [pmid: 9773135].
1838 Fullerton JT, Palinkas L, Cavero C. Nurse-midwifery services in one multi-ethnic, underserved community. J Health Care Poor Underserved. Fall. 1991;2(2):293-306. X-1. [pmid: 1777541].
1839 Fung BK. Continuous epidural analgesia for painless labor does not increase the incidence of cesarean delivery. Acta Anaesthesiol Sin. Jun. 2000;38(2):79-84. X-1. [pmid: 11000670].
1840 Fung BK, Gislefoss AJ, Ho ES. The sedative effect of intravenous injection of low dose midazolam during spinal anesthesia in cesarean section. Ma Zui Xue Za Zhi. Sep. 1992;30(3):159-62. X-9. [pmid: 1302788].
1841 Furuhashi N, Suzuki M, Kono H, et al. Clinical background of preeclampsia in Japanese women. Clin Exp Hypertens B. 1982;1(4):505-10. X-1. [pmid: 7165977].
1842 Fyneface-Ogan S, Mato CN, Anya SE. Epidural anesthesia: views and outcomes of women in labor in a Nigerian hospital. Ann Afr Med. Oct-Dec. 2009;8(4):250-6. X-1. [pmid: 20139548].
1843 Fyneface-Ogan S, Mato CN, Odagme MT. Post-dural puncture headache following caesarean section in Nigerian parturients: A comparison of two spinal needles. Niger Postgrad Med J. Sep. 2006;13(3):200-2. X-9. [pmid: 17066105].
1844 Fyneface-Ogan S, Uzoigwe SA. Caesarean section outcome in eclamptic patients: a comparison of infiltration and general anaesthesia. West Afr J Med. Oct. 2008;27(4):250-4. X-9. [pmid: 19469405].
1845 Gabriele R, Conte M, Izzo L, et al. Cesarean section and hernia repair: simultaneous approach. J Obstet Gynaecol Res. Oct. 2010;36(5):944-9. X-1, X-9. [pmid: 20722982].
1846 Gader AA, Haggaz AE, Adam I. Epidemiology of deep venous thrombosis during pregnancy and puerperium in Sudanese women. Vasc Health Risk Manag. 2009;5(1):85-7. X-1. [pmid: 19436646].
1847 Gaertner I, Burkhardt T, Beinder E. Scar appearance of different skin and subcutaneous tissue closure techniques in caesarean section: a randomized study. Eur J Obstet Gynecol Reprod Biol. May. 2008;138(1):29-33. X-9. [pmid: 17825472].
1848 Gaffud MP, Bansal P, Lawton C, et al. Surgical analgesia for cesarean delivery with epidural bupivacaine and fentanyl. Anesthesiology. Sep. 1986;65(3):331-4. X-4b. [pmid: 3752583].
1849 Gafni A, Goeree R, Myhr TL, et al. Induction of labour versus expectant management for prelabour rupture of the membranes at term: an economic evaluation. TERMPROM Study Group. Term Prelabour Rupture of the Membranes. CMAJ. Dec. 1. 1997;157(11):1519-25. X-1. [pmid: 9400406].
1850 Gaggero G, Meyer O, Van Gessel E, et al. Alkalinization of lidocaine 2% does not influence the quality of epidural anaesthesia for elective caesarean section. Can J Anaesth. Dec. 1995;42(12):1080-4. X-9. [pmid: 8595681].
1851 Gagnon AJ, Meier KM, Waghorn K. Continuity of nursing care and its link to cesarean birth rate. Birth. Mar. 2007;34(1):26-31. X-1. [pmid: 17324175].
1852 Gagnon AJ, Waghorn K. Supportive care by maternity nurses: a work sampling study in an intrapartum unit. Birth. Mar. 1996;23(1):1-6. X-1, X-4e, X-5. [pmid: 8703251].
1853 Gagnon AJ, Waghorn K. One-to-one nurse labor support of nulliparous women stimulated with oxytocin. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 1999;28(4):371-6. X-1.
1854 Gai MY, Wu LF, Su QF, et al. Clinical observation of blood loss reduced by tranexamic acid during and after caesarian section: a multi-center, randomized trial. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2004;112(2):154-7. X-9. [pmid: 14746950].
1855 Gaitini L, Vaida S, Collins G, et al. Awareness detection during caesarean section under general anaesthesia using EEG spectrum analysis. Can J Anaesth. May. 1995;42(5 Pt 1):377-81. X-1. [pmid: 7614642].
1856 Gajewska M, Marianowski L, Wielgos M, et al. The occurrence of genital types of human papillomavirus in normal pregnancy and in pregnant women with pregestational insulin dependent diabetes mellitus. Neuro Endocrinol Lett. Dec. 2005;26(6):766-70. X-1. [pmid: 16380676].
1857 Gajewska M, Wielgos M, Kaminski P, et al. The occurrence of genital types of human papillomavirus in normal pregnancy and in pregnant renal transplant recipients. Neuro Endocrinol Lett. Aug. 2006;27(4):529-34. X-1. [pmid: 16891989].
1858 Gajraj NM, Sharma SK, Souter AJ, et al. A survey of obstetric patients who refuse regional anaesthesia. Anaesthesia. Aug. 1995;50(8):740-1. X-1. [pmid: 7645713].
1859 Galaal KA, Krolikowski A. A randomized controlled study of peritoneal closure at cesarean section. Saudi Med J. Aug. 2000;21(8):759-61. X-9. [pmid: 11423890].
1860 Galask RP, Benigno BB, Cunningham FG, et al. Results of a multicenter comparative study of single-dose cefotetan and multiple-dose cefoxitin as prophylaxis in patients undergoing cesarean section. Am J Surg. May. 31. 1988;155(5A):86-90. X-9. [pmid: 3287975].
1861 Galask RP, Weiner C, Petzold CR. Comparison of single-dose cefmetazole and cefotetan prophylaxis in women undergoing primary caesarean section. J Antimicrob Chemother. Apr. Suppl D. 1989;23:105-8. X-9. [pmid: 2656623].
1862 Galazios G, Papazoglou D, Giagloglou K, et al. Interleukin-6 levels in umbilical artery serum in normal and abnormal pregnancies. Int J Gynaecol Obstet. Aug. 2002;78(2):147-51. X-1. [pmid: 12175716].
1863 Galbraith AA, Egerter SA, Marchi KS, et al. Newborn early discharge revisited: are California newborns receiving recommended postnatal services?. Pediatrics. Feb. 2003;111(2):364-71. X-1. [pmid: 12563065].
1864 Gale R, Slater PE, Zalkinder-Luboshitz I. Neonatal advantage of epidural anesthesia in elective and emergency cesarean sections: a report of 531 cases. Eur J Obstet Gynecol Reprod Biol. Dec. 1986;23(5-6):369-77. X-1. [pmid: 3100356].
1865 Gall S. Therapeutic dilemmas in the treatment of pelvic infections. J Reprod Med. Nov. 1990;35(11 Suppl):1091-4. X-9. [pmid: 2277378].
1866 Gall SA. The efficacy of prophylactic antibiotics in cesarean section. Am J Obstet Gynecol. Jul. 1. 1979;134(5):506-11. X-9. [pmid: 377971].
1867 Gall SA, Hill GB. Single-dose versus multiple-dose piperacillin prophylaxis in primary cesarean operation. Am J Obstet Gynecol. Aug. 1987;157(2):502-6. X-9. [pmid: 3303944].
1868 Gallagher J. The fetus and the law--whose life is it anyway?. Ms. Sep. 1984;13(3):62. 64. 66+. X-1. [pmid: 11655606].
1869 Gallagher J. Prenatal invasions and interventions: what's wrong with fetal rights?. Harv Women's Law J. Spring. 1987;10:9-58. X-1.
1870 Gallery ED, Rowe J, Campbell S. Alteration of in vitro human decidual endothelial cell growth, endothelin-1 and prostaglandin secretion, by growth factors and intracellular calcium. Prostaglandins Leukot Essent Fatty Acids. Jun. 1996;54(6):411-8. X-1. [pmid: 8888352].
1871 Gallery ED, Rowe J, Campbell S, et al. Secretion of prostaglandins and endothelin-1 by decidual endothelial cells from normal and preeclamptic pregnancies: comparison with human umbilical vein endothelial cells. Am J Obstet Gynecol. Nov. 1995;173(5):1557-62. X-1. [pmid: 7503201].
1872 Gallery ED, Rowe J, Schrieber L, et al. Isolation and purification of microvascular endothelium from human decidual tissue in the late phase of pregnancy. Am J Obstet Gynecol. Jul. 1991;165(1):191-6. X-1. [pmid: 1853895].
1873 Galtier-Dereure F, Montpeyroux F, Boulot P, et al. Weight excess before pregnancy: complications and cost. Int J Obes Relat Metab Disord. Jul. 1995;19(7):443-8. X-1. [pmid: 8520632].
1874 Galvez M, Myles TD. Teenage pregnancy in the Texas Panhandle. J Rural Health. Summer. 2005;21(3):259-62. X-1. [pmid: 16092301].
1875 Gamble JA, Creedy DK. Women's preference for a cesarean section: incidence and associated factors. Birth. Jun. 2001;28(2):101-10. X-1. [pmid: 11380381].
1876 Gambling DR, Howell P, Huber C, et al. Epidural butorphanol does not reduce side effects from epidural morphine after cesarean birth. Anesth Analg. Jun. 1994;78(6):1099-104. X-9. [pmid: 8198264].
1877 Gambling DR, Mayson K, McMorland GH, et al. Predictability of spread of epidural anesthesia for cesarean section using incremental doses of lidocaine hydrocarbonate with epinephrine. Reg Anesth. May-Jun. 1989;14(3):133-7. X-1. [pmid: 2486593].
1878 Gambling DR, Sharma SK, White PF, et al. Use of sevoflurane during elective cesarean birth: a comparison with isoflurane and spinal anesthesia. Anesth Analg. Jul. 1995;81(1):90-5. X-9. [pmid: 7598289].
1879 Gandhi SG, Gilbert WM, McElvy SS, et al. Maternal and neonatal outcomes after attempted suicide. Obstet Gynecol. May. 2006;107(5):984-90. X-1. [pmid: 16648400].
1880 Ganesh V, Apuzzio JJ, Dispenziere B, et al. Single-dose trimethoprim-sulfamethoxazole prophylaxis for cesarean section. Am J Obstet Gynecol. May. 1986;154(5):1113-4. X-9. [pmid: 3486596].
1881 Ganzevoort W, Rep A, Bonsel GJ, et al. A randomised controlled trial comparing two temporising management strategies, one with and one without plasma volume expansion, for severe and early onset pre-eclampsia. BJOG. Oct. 2005;112(10):1358-68. X-4e, X-5. [pmid: 16167938].
1882 Gao L, Cong B, Zhang L, et al. Expression of the calcium-activated potassium channel in upper and lower segment human myometrium during pregnancy and parturition. Reprod Biol Endocrinol. 2009;7:27. X-1. [pmid: 19344525].
1883 Gao Y, Barclay L. Availability and quality of emergency obstetric care in Shanxi Province, China. Int J Gynaecol Obstet. Aug. 2010;110(2):181-5. X-1. [pmid: 20570261].
1884 Garbaciak JA Jr., Richter M, Miller S, et al. Maternal weight and pregnancy complications. Am J Obstet Gynecol. May. 15. 1985;152(2):238-45. X-1. [pmid: 4003470].
1885 Garbe E, Suling M, Kloss S, et al. Linkage of mother-baby pairs in the German Pharmacoepidemiological Research Database. Pharmacoepidemiol Drug Saf. Mar. 2011;20(3):258-64. X-1. [pmid: 21351307].
1886 Garbin O, Ohl J, Bettahar-Lebugle K, et al. Hysteroscopic metroplasty in diethylstilboestrol-exposed and hypoplastic uterus: a report on 24 cases. Hum Reprod. Oct. 1998;13(1O):2751-5. X-1. [pmid: 9804225].
1887 Garcia-Patterson A, Corcoy R, Rigla M, et al. Does preconceptional counselling in diabetic women influence perinatal outcome?. Ann Ist Super Sanita. 1997;33(3):333-6. X-1. [pmid: 9542258].
1888 Gardberg M, Stenwall O, Laakkonen E. Recurrent persistent occipito-posterior position in subsequent deliveries. BJOG. Feb. 2004;111(2):170-1. X-1. [pmid: 14723756].
1889 Gardberg M, Tuppurainen M. Dorsoposterior fetal position near term--a sonographic finding worth noting?. Acta Obstet Gynecol Scand. May. 1995;74(5):402-3. X-1. [pmid: 7778438].
1890 Gardella C, Goltra LB, Laschansky E, et al. High-concentration supplemental perioperative oxygen to reduce the incidence of postcesarean surgical site infection: a randomized controlled trial. Obstet Gynecol. Sep. 2008;112(3):545-52. X-9. [pmid: 18757651].
1891 Gareen IF, Morgenstern H, Greenland S, et al. Explaining the association of maternal age with Cesarean delivery for nulliparous and parous women. J Clin Epidemiol. Nov. 2003;56(11):1100-10. X-1. [pmid: 14615001].
1892 Garel M, Lelong N, Kaminski M. Follow-up study of psychological consequences of caesarean childbirth. Early Hum Dev. Mar. 1988;16(2-3):271-82. X-1. [pmid: 3378531].
1893 Garel M, Lelong N, Marchand A, et al. Psychosocial consequences of caesarean childbirth: a four-year follow-up study. Early Hum Dev. Feb. 1990;21(2):105-14. X-1. [pmid: 2318122].
1894 Garenne M, Mbaye K, Bah MD, et al. Risk factors for maternal mortality: a case-control study in Dakar hospitals (Senegal). Afr J Reprod Health. Mar. 1997;1(1):14-24. X-1. [pmid: 10214399].
1895 Garite TJ, Freeman RK, Linzey EM, et al. Prospective randomized study of corticosteroids in the management of premature rupture of the membranes and the premature gestation. Am J Obstet Gynecol. Nov. 1. 1981;141(5):508-15. X-4e. [pmid: 7294077].
1896 Garrett K, Butler A, Cohen WR. Cesarean delivery during second-stage labor: characteristics and diagnostic accuracy. J Matern Fetal Neonatal Med. Jan. 2005;17(1):49-53. X-1. [pmid: 15804787].
1897 Garry D, Figueroa R, Kalish RB, et al. Randomized controlled trial of vaginal misoprostol versus dinoprostone vaginal insert for labor induction. J Matern Fetal Neonatal Med. Apr. 2003;13(4):254-9. X-4d, X-5. [pmid: 12854927].
1898 Gartoulla P, Liabsuetrakul T, Pradhan N. Change in willingness to pay for normal delivery and caesarean section during pregnancy and after delivery in Kathmandu. Trop Med Int Health. Oct. 2010;15(10):1227-34. X-1. [pmid: 20831674].
1899 Garvey WT, Maianu L, Zhu JH, et al. Multiple defects in the adipocyte glucose transport system cause cellular insulin resistance in gestational diabetes. Heterogeneity in the number and a novel abnormality in subcellular localization of GLUT4 glucose transporters. Diabetes. Dec. 1993;42(12):1773-85. X-1. [pmid: 8243823].
1900 Garza M, Piver JS. Obese patients offer big liability risks. OB-GYN Malpractice Prevention. 2004;11(11):81-8. insert 1p. X-1.
1901 Gaspar D, Jordan J. Family medicine in a tertiary care hospital. Obstetrical outcomes and interventions. Can Fam Physician. Apr. 1995;41:601-7. X-1. [pmid: 7787490].
1902 Gass CW. It is the right of every anaesthetist to refuse to participate in a maternal-request caesarean section. Int J Obstet Anesth. Jan. 2006;15(1):33-5. X-1, X-2. [pmid: 16325392].
1903 Gates S, Brocklehurst P, Ayers S, et al. Thromboprophylaxis and pregnancy: two randomized controlled pilot trials that used low-molecular-weight heparin. Am J Obstet Gynecol. Oct. 2004;191(4):1296-303. X-4e, X-5. [pmid: 15507957].
1904 Gathwala G, Narayanan I. Cesarean section and delayed contact: effect on baby's behaviour. Indian Pediatr. Dec. 1990;27(12):1295-9. X-1. [pmid: 2136252].
1905 Gautier P, De Kock M, Huberty L, et al. Comparison of the effects of intrathecal ropivacaine, levobupivacaine, and bupivacaine for Caesarean section. Br J Anaesth. Nov. 2003;91(5):684-9. X-9. [pmid: 14570791].
1906 Gavin NI, Benedict MB, Adams EK. Health service use and outcomes among disabled Medicaid pregnant women. Womens Health Issues. Nov-Dec. 2006;16(6):313-22. X-1. [pmid: 17188214].
1907 Gaymer C, Whalley H, Achten J, et al. Midfoot plantar pressure significantly increases during late gestation. Foot (Edinb). Jun. 2009;19(2):114-6. X-1. [pmid: 20307461].
1908 Gazzolo D, Visser GH, Lituania M, et al. S100B protein cord blood levels and development of fetal behavioral states: a study in normal and small-for-dates fetuses. J Matern Fetal Neonatal Med. Jun. 2002;11(6):378-84. X-1. [pmid: 12389652].
1909 Geary M, Fanagan M, Boylan P. Maternal satisfaction with management in labour and preference for mode of delivery. J Perinat Med. 1997;25(5):433-9. X-1. [pmid: 9438948].
1910 Geddes SM, Thorburn J, Logan RW. Gastric emptying following caesarean section and the effect of epidural fentanyl. Anaesthesia. Dec. 1991;46(12):1016-8. X-9. [pmid: 1781524].
1911 Gedikbasi A, Akyol A, Bingol B, et al. Multiple repeated cesarean deliveries: operative complications in the fourth and fifth surgeries in urgent and elective cases. Taiwan J Obstet Gynecol. Dec. 2010;49(4):425-31. X-1, X-9. [pmid: 21199743].
1912 Geimonen E, Boylston E, Royek A, et al. Elevated connexin-43 expression in term human myometrium correlates with elevated c-Jun expression and is independent of myometrial estrogen receptors. J Clin Endocrinol Metab. Apr. 1998;83(4):1177-85. X-1. [pmid: 9543137].
1913 Geipel A, Ludwig M, Germer U, et al. Uterine artery Doppler velocimetry and the outcome of pregnancies resulting from ICSI. Hum Reprod. Jul. 2001;16(7):1397-402. X-1. [pmid: 11425819].
1914 Gelisen O, Caliskan E, Dilbaz S, et al. Induction of labor with three different techniques at 41 weeks of gestation or spontaneous follow-up until 42 weeks in women with definitely unfavorable cervical scores. Eur J Obstet Gynecol Reprod Biol. Jun. 1. 2005;120(2):164-9. X-4d, X-4e. [pmid: 15925045].
1915 Gelson E, Gatzoulis M, Steer PJ, et al. Tetralogy of Fallot: maternal and neonatal outcomes. BJOG. Feb. 2008;115(3):398-402. X-1. [pmid: 18190378].
1916 Gemer O, Segal S. Incidence and contribution of predisposing factors to transverse lie presentation. Int J Gynaecol Obstet. Mar. 1994;44(3):219-21. X-1. [pmid: 7909759].
1917 Geng ZY, Wang DX, Wu XM. Minimum effective local anesthetic dose of intrathecal hyperbaric ropivacaine and bupivacaine for cesarean section. Chin Med J (Engl). Feb. 2011;124(4):509-13. X-9. [pmid: 21362272].
1918 George PR, Dewart PJ, Elstein M. Short communication: the effect of mode of delivery on contractile function of placental arteries in vitro. Placenta. Dec. 1995;16(8):743-7. X-1. [pmid: 8710804].
1919 George RB, McKeen D, Chaplin AC, et al. Up-down determination of the ED(90) of oxytocin infusions for the prevention of postpartum uterine atony in parturients undergoing Cesarean delivery. Can J Anaesth. Jun. 2010;57(6):578-82. X-9. [pmid: 20238255].
1920 Georgiadis P, Xu H, Chua C, et al. Characterization of acute brain injuries and neurobehavioral profiles in a rabbit model of germinal matrix hemorrhage. Stroke. Dec. 2008;39(12):3378-88. X-1. [pmid: 18845808].
1921 Gerancher JC, Floyd H, Eisenach J. Determination of an effective dose of intrathecal morphine for pain relief after cesarean delivery. Anesth Analg. Feb. 1999;88(2):346-51. X-9. [pmid: 9972754].
1922 Gerhardstein LP, Allswede MT, Sloan CT, et al. Reduction in the rate of cesarean birth with active management of labor and intermediate-dose oxytocin. J Reprod Med. Jan. 1995;40(1):4-8. X-1. [pmid: 7722974].
1923 Gerstenfeld TS, Wing DA. Rectal misoprostol versus intravenous oxytocin for the prevention of postpartum hemorrhage after vaginal delivery. Am J Obstet Gynecol. Oct. 2001;185(4):878-82. X-4e. [pmid: 11641670].
1924 Gerten KA, Coonrod DV, Bay RC, et al. Cesarean delivery and respiratory distress syndrome: does labor make a difference?. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1061-4. X-1. [pmid: 16157112].
1925 Ghetti C, Chan BK, Guise JM. Physicians' responses to patient-requested cesarean delivery. Birth. Dec. 2004;31(4):280-4. X-1. [pmid: 15566340].
1926 Ghezzi F, Massimo F, Raio L, et al. Extra-amniotic Foley catheter and prostaglandin E(2) gel for cervical ripening at term gestation. Eur J Obstet Gynecol Reprod Biol. Aug. 2001;97(2):183-7. X-1. [pmid: 11451546].
1927 Ghidini A, Spong CY, Korker V, et al. Randomized controlled trial of 50 and 100 mcg of misoprostol for induction of labor at term. Arch Gynecol Obstet. Aug. 2001;265(3):128-30. X-4d, X-5. [pmid: 11561740].
1928 Ghnnam WM, Helal AS, Fawzy M, et al. Paraumbilical hernia repair during cesarean delivery. Ann Saudi Med. Mar-Apr. 2009;29(2):115-8. X-1. [pmid: 19318752].
1929 Ghods AA, Soleimani M, Narimani M. Effect of postoperative supplemental oxygen on nausea and vomiting after cesarean birth. J Perianesth Nurs. Jun. 2005;20(3):200-5. X-1. [pmid: 15933967].
1930 Ghoreishi J. Indwelling urinary catheters in cesarean delivery. Int J Gynaecol Obstet. Dec. 2003;83(3):267-70. X-9. [pmid: 14643036].
1931 Ghosh GS, Gudmundsson S. Uterine and umbilical artery Doppler are comparable in predicting perinatal outcome of growth-restricted fetuses. BJOG. Feb. 2009;116(3):424-30. X-1. [pmid: 19187375].
1932 Giacalone PL, Daures JP, Vignal J, et al. Pfannenstiel versus Maylard incision for cesarean delivery: A randomized controlled trial. Obstet Gynecol. May. 2002;99(5 Pt 1):745-50. X-9. [pmid: 11978282].
1933 Giacalone PL, Targosz V, Laffargue F, et al. Cervical ripening with mifepristone before labor induction: a randomized study. Obstet Gynecol. Oct. 1998;92(4 Pt 1):487-92. X-4d, X-4e, X-5. [pmid: 9764616].
1934 Giannubilo SR, Dell'Uomo B, Tranquilli AL. Perinatal outcomes, blood pressure patterns and risk assessment of superimposed preeclampsia in mild chronic hypertensive pregnancy. Eur J Obstet Gynecol Reprod Biol. May. 1. 2006;126(1):63-7. X-1. [pmid: 16137819].
1935 Giannubilo SR, Menegazzi M, Tedeschi E, et al. Doppler analysis and placental nitric oxide synthase expression during fetal growth restriction. J Matern Fetal Neonatal Med. Sep. 2008;21(9):617-22. X-1. [pmid: 18828052].
1936 Gibb DM, Cardozo LD, Studd JW, et al. Prolonged pregnancy: is induction of labour indicated? A prospective study. Br J Obstet Gynaecol. Apr. 1982;89(4):292-5. X-1. [pmid: 7073997].
1937 Gibb W, Riopel L, Collu R, et al. Cyclooxygenase products formed by primary cultures of cells from human chorion laeve: influence of steroids. Can J Physiol Pharmacol. Jun. 1988;66(6):788-93. X-1. [pmid: 3167693].
1938 Gibbs CP, Banner TC. Effectiveness of Bicitra as a preoperative antacid. Anesthesiology. Jul. 1984;61(1):97-9. X-1, X-9. [pmid: 6377975].
1939 Gibbs RS, Blanco JD, Castaneda YS, et al. A double-blind, randomized comparison of clindamycin-gentamicin versus cefamandole for treatment of post-cesarean section endomyometritis. Am J Obstet Gynecol. Oct. 1. 1982;144(3):261-7. X-9. [pmid: 7124839].
1940 Gibbs RS, Blanco JD, Duff P, et al. A double-blind, randomized comparison of moxalactam versus clindamycin-gentamicin in treatment of endomyometritis after cesarean section delivery. Am J Obstet Gynecol. Aug. 1. 1983;146(7):769-72. X-9. [pmid: 6223528].
1941 Gibbs RS, Blanco JD, Lipscomb KA, et al. Aztreonam versus gentamicin, each with clindamycin, in the treatment of endometritis. Obstet Gynecol. Jun. 1985;65(6):825-9. X-9. [pmid: 3889748].
1942 Gibbs RS, Blanco JD, St Clair PJ. A case-control study of wound abscess after cesarean delivery. Obstet Gynecol. Oct. 1983;62(4):498-501. X-1. [pmid: 6888827].
1943 Gibbs RS, Blanco JD, St Clair PJ, et al. Vaginal colonization with resistant aerobic bacteria after antibiotic therapy for endometritis. Am J Obstet Gynecol. Jan. 15. 1982;142(2):130-4. X-1. [pmid: 7055177].
1944 Gibbs RS, DeCherney AH, Schwarz RH. Prophylactic antibiotics in cesarean section: a double-blind study. Am J Obstet Gynecol. Dec. 15. 1972;114(8):1048-53. X-4b. [pmid: 4564355].
1945 Gibbs RS, Hunt JE, Schwarz RH. A follow-up study on prophylactic antibiotics in cesarean section. Am J Obstet Gynecol. Oct. 1. 1973;117(3):419-22. X-4b. [pmid: 4580966].
1946 Gibbs RS, St Clair PJ, Castillo MS, et al. Bacteriologic effects of antibiotic prophylaxis in high-risk cesarean section. Obstet Gynecol. Mar. 1981;57(3):277-82. X-9. [pmid: 7465140].
1947 Gibbs RS, Weinstein AJ. Bacteriologic effects of prophylactic antibiotics in cesarean section. Am J Obstet Gynecol. Sep. 15. 1976;126(2):226-9. X-1. [pmid: 786022].
1948 Gifford DS, Morton SC, Fiske M, et al. Lack of progress in labor as a reason for cesarean. Obstet Gynecol. Apr. 2000;95(4):589-95. X-1. [pmid: 10725495].
1949 Gilbert W, Jandial D, Field N, et al. Birth outcomes in teenage pregnancies. J Matern Fetal Neonatal Med. Nov. 2004;16(5):265-70. X-1. [pmid: 15621541].
1950 Gilbert WM, Nesbitt TS, Danielsen B. Childbearing beyond age 40: pregnancy outcome in 24,032 cases. Obstet Gynecol. Jan. 1999;93(1):9-14. X-1. [pmid: 9916947].
1951 Giles ML, Garland SM, Grover SR, et al. Impact of an education campaign on management in pregnancy of women infected with a blood-borne virus. Med J Aust. Apr. 17. 2006;184(8):389-92. X-1. [pmid: 16618237].
1952 Giles ML, McDonald AM, Elliott EJ, et al. Variable uptake of recommended interventions to reduce mother-to-child transmission of HIV in Australia, 1982-2005. Med J Aust. Aug. 4. 2008;189(3):151-4. X-1. [pmid: 18673102].
1953 Gilkey L. Florida ranks 2nd nationally for C-sections. Midwifery Today Int Midwife. Winter. 2009;(92):6. X-1, X-2, X-3, X-4e, X-5. [pmid: 20092133].
1954 Gillean JR, Coonrod DV, Russ R, et al. Big infants in the neonatal intensive care unit. Am J Obstet Gynecol. Jun. 2005;192(6):1948-53. discussion 1953-5. X-1. [pmid: 15970858].
1955 Gillessen-Kaesbach G, Robinson W, Lohmann D, et al. Genotype-phenotype correlation in a series of 167 deletion and non-deletion patients with Prader-Willi syndrome. Hum Genet. Dec. 1995;96(6):638-43. X-1. [pmid: 8522319].
1956 Gilliam M, Rosenberg D, Davis F. The likelihood of placenta previa with greater number of cesarean deliveries and higher parity. Obstet Gynecol. Jun. 2002;99(6):976-80. X-1. [pmid: 12052584].
1957 Gilson GJ, Izquierdo LA, Chatterjee MS, et al. Prevention of cesarean section Does intracervical dinoprostone work?. West J Med. Aug. 1993;159(2):149-52. X-4d. [pmid: 8212680].
1958 Gilson GJ, Kephart WH, Izquierdo LA, et al. Comparison of absorbable uterine staples and traditional hysterotomy during cesarean delivery. Obstet Gynecol. Mar. 1996;87(3):384-8. X-1. [pmid: 8598960].
1959 Gilson GJ, Russell DJ, Izquierdo LA, et al. A prospective randomized evaluation of a hygroscopic cervical dilator, Dilapan, in the preinduction ripening of patients undergoing induction of labor. Am J Obstet Gynecol. Jul. 1996;175(1):145-9. X-4d. [pmid: 8694040].
1960 Gimenez M, Conget I, Nicolau J, et al. Outcome of pregnancy in women with type 1 diabetes intensively treated with continuous subcutaneous insulin infusion or conventional therapy. A case-control study. Acta Diabetol. Mar. 2007;44(1):34-7. X-1. [pmid: 17357884].
1961 Gimovsky ML, Petrie RH. The intrapartum and neonatal performance of the low-birth-weight vaginal breech delivery. J Reprod Med. Aug. 1982;27(8):451-4. X-1, X-4c, X-5. [pmid: 6890109].
1962 Gimovsky ML, Petrie RH, Todd WD. Neonatal performance of the selected term vaginal breech delivery. Obstet Gynecol. Dec. 1980;56(6):687-91. X-1, X-4c. [pmid: 7443110].
1963 Gin T, Ewart MC, Yau G, et al. Effect of oral omeprazole on intragastric pH and volume in women undergoing elective caesarean section. Br J Anaesth. Nov. 1990;65(5):616-9. X-1. [pmid: 2248836].
1964 Gin T, Gregory MA, Oh TE. The haemodynamic effects of propofol and thiopentone for induction of caesarean section. Anaesth Intensive Care. May. 1990;18(2):175-9. X-1. [pmid: 2368889].
1965 Gin T, Kan AF, Lam KK, et al. Analgesia after caesarean section with intramuscular ketorolac or pethidine. Anaesth Intensive Care. Aug. 1993;21(4):420-3. X-9. [pmid: 8214547].
1966 Gin T, Ngan-Kee WD, Siu YK, et al. Alfentanil given immediately before the induction of anesthesia for elective cesarean delivery. Anesth Analg. May. 2000;90(5):1167-72. X-9. [pmid: 10781473].
1967 Ginosar Y, Mirikatani E, Drover DR, et al. ED50 and ED95 of intrathecal hyperbaric bupivacaine coadministered with opioids for cesarean delivery. Anesthesiology. Mar. 2004;100(3):676-82. X-9. [pmid: 15108985].
1968 Girard B, Vardon D, Creveuil C, et al. Discontinuation of oxytocin in the active phase of labor. Acta Obstet Gynecol Scand. 2009;88(2):172-7. X-1, X-4a. [pmid: 19169930].
1969 Girgin NK, Gurbet A, Turker G, et al. Intrathecal morphine in anesthesia for cesarean delivery: dose-response relationship for combinations of low-dose intrathecal morphine and spinal bupivacaine. J Clin Anesth. May. 2008;20(3):180-5. X-9. [pmid: 18502360].
1970 Givens VA, Lipscomb GH, Meyer NL. A randomized trial of postoperative wound irrigation with local anesthetic for pain after cesarean delivery. Am J Obstet Gynecol. Jun. 2002;186(6):1188-91. X-9. [pmid: 12066096].
1971 Gjerdingen DK, Froberg D. Predictors of health in new mothers. Soc Sci Med. 1991;33(12):1399-407. X-1. [pmid: 1776055].
1972 Glantz JC. Term labor induction compared with expectant management. Obstet Gynecol. Jan. 2010;115(1):70-6. X-1. [pmid: 20027037].
1973 Glantz JC. Rates of labor induction and primary cesarean delivery do not correlate with rates of adverse neonatal outcome in level I hospitals. J Matern Fetal Neonatal Med. Apr. 2011;24(4):636-42. X-1. [pmid: 20836744].
1974 Glasgow TS, Speakman M, Firth S, et al. Clinical and economic outcomes for term infants associated with increasing administration of antibiotics to their mothers. Paediatr Perinat Epidemiol. Jul. 2007;21(4):338-46. X-1. [pmid: 17564591].
1975 Glass BJ. A comparative analysis of the right of a pregnant woman to refuse medical treatment for herself and her viable fetus: the United States and United Kingdom. Indiana Int Comp Law Rev. 2001;11(2):507-41. X-1, X-2, X-4e, X-5. [pmid: 12680376].
1976 Glasson EJ, Bower C, Petterson B, et al. Perinatal factors and the development of autism: a population study. Arch Gen Psychiatry. Jun. 2004;61(6):618-27. X-1. [pmid: 15184241].
1977 Glazener CM, Herbison GP, MacArthur C, et al. New postnatal urinary incontinence: obstetric and other risk factors in primiparae. BJOG. Feb. 2006;113(2):208-17. X-1. [pmid: 16412000].
1978 Gleicher N, Weiner R, Vietzke M. The impact of abnormal autoimmune function on reproduction: maternal and fetal consequences. J Autoimmun. Nov. 2006;27(3):161-5. X-1. [pmid: 17029731].
1979 Glezerman M. Five years to the term breech trial: the rise and fall of a randomized controlled trial. Am J Obstet Gynecol. Jan. 2006;194(1):20-5. X-1. [pmid: 16389006].
1980 Gloeb DJ, O'Sullivan MJ, Efantis J. Human immunodeficiency virus infection in women. I. The effects of human immunodeficiency virus on pregnancy. Am J Obstet Gynecol. Sep. 1988;159(3):756-61. X-1. [pmid: 3421276].
1981 Glosten B, Sessler DI, Faure EA, et al. Central temperature changes are poorly perceived during epidural anesthesia. Anesthesiology. Jul. 1992;77(1):10-6. X-1. [pmid: 1609982].
1982 Gochnour G, Ratcliffe S, Stone MB. The UTAH VBAC Study. Matern Child Health J. Jun. 2005;9(2):181-8. X-1. [pmid: 15965624].
1983 Gocmen A, Gocmen M, Saraoglu M. Early post-operative feeding after caesarean delivery. J Int Med Res. Sep-Oct. 2002;30(5):506-11. X-9. [pmid: 12449520].
1984 Goedert JJ, Duliege AM, Amos CI, et al. High risk of HIV-1 infection for first-born twins. The International Registry of HIV-exposed Twins. Lancet. Dec. 14. 1991;338(8781):1471-5. X-1. [pmid: 1683916].
1985 Goer H. Active management of labor: not the answer to dystocia. Birth. Jun. 1993;20(2):99-101. X-1, X-2. [pmid: 8240616].
1986 Goeree R, Hannah M, Hewson S. Cost-effectiveness of induction of labour versus serial antenatal monitoring in the Canadian Multicentre Postterm Pregnancy Trial. CMAJ. May. 1. 1995;152(9):1445-50. X-1, X-3, X-4e, X-5. [pmid: 7728693].
1987 Goetzl L, Shipp TD, Cohen A, et al. Oxytocin dose and the risk of uterine rupture in trial of labor after cesarean. Obstet Gynecol. Mar. 2001;97(3):381-4. X-1. [pmid: 11239641].
1988 Goffinet F, Carayol M, Foidart JM, et al. Is planned vaginal delivery for breech presentation at term still an option? Results of an observational prospective survey in France and Belgium. Am J Obstet Gynecol. Apr. 2006;194(4):1002-11. X-1. [pmid: 16580289].
1989 Goffinet F, Fraser W, Marcoux S, et al. Early amniotomy increases the frequency of fetal heart rate abnormalities. Amniotomy Study Group. Br J Obstet Gynaecol. May. 1997;104(5):548-53. X-1, X-4e, X-5. [pmid: 9166195].
1990 Goffman D, Madden RC, Harrison EA, et al. Predictors of maternal mortality and near-miss maternal morbidity. J Perinatol. Oct. 2007;27(10):597-601. X-1. [pmid: 17703181].
1991 Gofton EN, Capewell V, Natale R, et al. Obstetrical intervention rates and maternal and neonatal outcomes of women with gestational hypertension. Am J Obstet Gynecol. Oct. 2001;185(4):798-803. X-1. [pmid: 11641654].
1992 Gogarten W, Struemper D, Gramke HF, et al. Assessment of volume preload on uteroplacental blood flow during epidural anaesthesia for Caesarean section. Eur J Anaesthesiol. May. 2005;22(5):359-62. X-1. [pmid: 15918384].
1993 Gogarten W, Van de Velde M, Soetens F, et al. A multicentre trial comparing different concentrations of ropivacaine plus sufentanil with bupivacaine plus sufentanil for patient-controlled epidural analgesia in labour. Eur J Anaesthesiol. Jan. 2004;21(1):38-45. X-4e, X-5. [pmid: 14768922].
1994 Goh JL, Evans SF, Pavy TJ. Patient-controlled epidural analgesia following caesarean delivery: a comparison of pethidine and fentanyl. Anaesth Intensive Care. Feb. 1996;24(1):45-50. X-9. [pmid: 8669654].
1995 Gojnic M, Jeremic K, Boskovic V, et al. Perinatal outcome in multiple pregnancies--spontaneous gestation versus. Clin Exp Obstet Gynecol. 2005;32(1):65-7. X-1. [pmid: 15864943].
1996 Gojnic M, Likic I, Pervulov M, et al. The significance of Doppler flow in early detection of uterine sarcoma in older primigravida pregnancies. Eur J Gynaecol Oncol. 2005;26(3):291-3. X-1. [pmid: 15991529].
1997 Gojnic M, Pervulov M, Petkovic S, et al. Acceleration of fetal maturation by oxytocin-produced uterine contraction in pregnancies complicated with gestational diabetes mellitus: a preliminary report. J Matern Fetal Neonatal Med. Aug. 2004;16(2):111-4. X-1. [pmid: 15512721].
1998 Gojnic M, Pervulov M, Petkovic S, et al. The importance of Doppler ultrasound in delivery planning. Clin Exp Obstet Gynecol. 2004;31(4):282-4. X-1, X-3, X-4e, X-5. [pmid: 15672967].
1999 Gol M, Baloglu A, Aydin C, et al. Does manual removal of the placenta affect operative blood loss during cesarean section?. Eur J Obstet Gynecol Reprod Biol. Jan. 15. 2004;112(1):57-60. X-9. [pmid: 14687740].
2000 Goldberg J, Gopal M, Singhal R, et al. Nighttime call in house vs. out of house: a comparison of obstetric procedure rates. J Reprod Med. Mar. 2004;49(3):143-7. X-1. [pmid: 15098882].
2001 Goldberg RP, Kwon C, Gandhi S, et al. Urinary incontinence among mothers of multiples: the protective effect of cesarean delivery. Am J Obstet Gynecol. Jun. 2003;188(6):1447-50. discussion 1450-3. X-1. [pmid: 12824977].
2002 Goldberg S. Medical choices during pregnancy: whose decision is it anyway?. Rutgers Law Rev. Winter. 1989;41(2):591-623. X-1. [pmid: 11649263].
2003 Goldberger SB, Rosen DJ, Michaeli G, et al. The use of PGE2 for induction of labor in parturients with a previous cesarean section scar. Acta Obstet Gynecol Scand. 1989;68(6):523-6. X-1, X-4b, X-4d, X-5. [pmid: 2520807].
2004 Goldblatt AD. Commentary: no more jurisdiction over Jehovah. J Law Med Ethics. Summer. 1999;27(2):190-3. X-1, X-2. [pmid: 11657466].
2005 Goldbort JG. Women's lived experience of their unexpected birthing process. MCN Am J Matern Child Nurs. Jan-Feb. 2009;34(1):57-62. X-1. [pmid: 19104321].
2006 Goldman G, Pineault R, Bilodeau H, et al. Effects of patient, physician and hospital characteristics on the likelihood of vaginal birth after previous cesarean section in Quebec. CMAJ. Nov. 15. 1990;143(10):1017-24. X-1. [pmid: 2224667].
2007 Goldman G, Pineault R, Potvin L, et al. Factors influencing the practice of vaginal birth after cesarean section. Am J Public Health. Aug. 1993;83(8):1104-8. X-1. [pmid: 8342717].
2008 Goldman GA, Kaplan B, Neri A, et al. The grand multipara. Eur J Obstet Gynecol Reprod Biol. Aug. 1995;61(2):105-9. X-1. [pmid: 7556829].
2009 Goldman JA, Dicker D, Feldberg D, et al. Pregnancy outcome in patients with insulin-dependent diabetes mellitus with preconceptional diabetic control: a comparative study. Am J Obstet Gynecol. Aug. 1986;155(2):293-7. X-1. [pmid: 3740144].
2010 Goldman M, Kitzmiller JL, Abrams B, et al. Obstetric complications with GDM. Effects of maternal weight. Diabetes. Dec. Suppl 2. 1991;40:79-82. X-1. [pmid: 1748271].
2011 Goldner WL, Brown RB, Lundy LE, et al. Nosocomial infections in an obstetric and gynecologic hospital. J Reprod Med. Oct. 1980;25(4):145-9. X-1. [pmid: 7431361].
2012 Gomes UA, Silva AA, Bettiol H, et al. Risk factors for the increasing caesarean section rate in Southeast Brazil: a comparison of two birth cohorts, 1978-1979 and 1994. Int J Epidemiol. Aug. 1999;28(4):687-94. X-1. [pmid: 10480697].
2013 Gomez OL, Carrasquilla G. Factors associated with unjustified Cesarean section in four hospitals in Cali, Colombia. Int J Qual Health Care. Oct. 1999;11(5):385-9. X-1. [pmid: 10561029].
2014 Gonen O, Rosen DJ, Dolfin Z, et al. Induction of labor versus expectant management in macrosomia: a randomized study. Obstet Gynecol. Jun. 1997;89(6):913-7. [pmid: 9170464].
2015 Gonen R, Samberg I, Levinski R, et al. Effect of irrigation or intravenous antibiotic prophylaxis on infectious morbidity at cesarean section. Obstet Gynecol. Apr. 1986;67(4):545-8. X-9. [pmid: 3960427].
2016 Goni S, Sawhney H, Gopalan S. Oxytocin induction of labor: a comparison of 20- and 60-min dose increment levels. Int J Gynaecol Obstet. Jan. 1995;48(1):31-6. X-4d. [pmid: 7698380].
2017 Gonik B. Single- versus three-dose cefotaxime prophylaxis for cesarean section. Obstet Gynecol. Feb. 1985;65(2):189-93. X-9. [pmid: 3881710].
2018 Gonik B, Cotton D, Spillman T, et al. Peripartum colloid osmotic pressure changes: effects of controlled fluid management. Am J Obstet Gynecol. Mar. 15. 1985;151(6):812-5. X-9. [pmid: 3976794].
2019 Gonik B, Feldman S, Pickering LK, et al. Pharmacokinetics of cefoperazone in the parturient. Antimicrob Agents Chemother. Dec. 1986;30(6):874-6. X-1. [pmid: 3813513].
2020 Gonzales GF, Salirrosas A. Pulse oxygen saturation and neurologic assessment in human neonates after vaginal and cesarean delivery. Int J Gynaecol Obstet. Oct. 1998;63(1):63-6. X-1. [pmid: 9849715].
2021 Gonzalez Viejo I, Ferrer Novella C, Pueyo Subias M, et al. Hemorrhagic retinopathy in newborns: frequency, form of presentation, associated factors and significance. Eur J Ophthalmol. Oct-Dec. 1995;5(4):247-50. X-1. [pmid: 8963162].
2022 Gonzalez-Gonzalez NL, Ramirez O, Mozas J, et al. Factors influencing pregnancy outcome in women with type 2 versus type 1 diabetes mellitus. Acta Obstet Gynecol Scand. 2008;87(1):43-9. X-1. [pmid: 18158626].
2023 Gonzalez-Perez GJ, Vega-Lopez MG, Cabrera-Pivaral C, et al. Caesarean sections in Mexico: are there too many?. Health Policy Plan. Mar. 2001;16(1):62-7. X-1. [pmid: 11238432].
2024 Gonzalez-Quintero VH, Istwan NB, Rhea DJ, et al. The impact of glycemic control on neonatal outcome in singleton pregnancies complicated by gestational diabetes. Diabetes Care. Mar. 2007;30(3):467-70. X-1. [pmid: 17327306].
2025 Good MM, Solt I, Acuna JG, et al. Methamphetamine use during pregnancy: maternal and neonatal implications. Obstet Gynecol. Aug. 2010;116(2 Pt 1):330-4. X-1. [pmid: 20664393].
2026 Goodall KE, McVittie C, Magill M. Birth choice following primary Caesarean section: mothers' perceptions of the influence of health professionals on decision-making. Journal of Reproductive & Infant Psychology. 2009;27(1):4-14. X-1.
2027 Goode CJ. Impact of a CareMap and case management on patient satisfaction and staff satisfaction, collaboration, and autonomy. Nurs Econ. Nov-Dec. 1995;13(6):337-48. 361. X-1. [pmid: 8538807].
2028 Gopalani S, Bennett K, Critchlow C. Factors predictive of failed operative vaginal delivery. Am J Obstet Gynecol. Sep. 2004;191(3):896-902. X-1. [pmid: 15467561].
2029 Gordon AJ, Calder AA. Oestradiol applied locally to ripen the unfavourable cervix. Lancet. Dec. 24-31. 1977;2(8052-8053):1319-21. X-1, X-4d. [pmid: 74730].
2030 Gordon NP, Walton D, McAdam E, et al. Effects of providing hospital-based doulas in health maintenance organization hospitals. Obstet Gynecol. Mar. 1999;93(3):422-6. X-5. [pmid: 10074992].
2031 Gordon SC, Gaines SK, Hauber RP. Self-administered versus nurse-administered epidural analgesia after cesarean section. J Obstet Gynecol Neonatal Nurs. Feb. 1994;23(2):99-103. X.
2032 Gordon SF, Russell J. A randomized controlled study comparing ceftizoxime, cefamandole, and cefoxitin in obstetric and gynaecological surgery: a preliminary report. J Antimicrob Chemother. Nov. Suppl C. 1982;10:289-92. X-3, X-4e. [pmid: 6296022].
2033 Gordon-Wright AP, Elder MG. Effect of prostaglandin E2 and its metabolites on lower segment myometrium in vitro. Eur J Obstet Gynecol Reprod Biol. Jun. 1980;10(5):297-302. X-1. [pmid: 7190512].
2034 Goring-Morris J, Russell IF. A randomised comparison of 0.5% bupivacaine with a lidocaine/epinephrine/fentanyl mixture for epidural top-up for emergency caesarean section after “low dose” epidural for labour. Int J Obstet Anesth. Apr. 2006;15(2):109-14. X-9. [pmid: 16488138].
2035 Gorodeski IG, Bahari CM, Holzinger M, et al. Placenta previa with focal accretion. Isr J Med Sci. Feb. 1982;18(2):277-80. X-1. [pmid: 6978326].
2036 Gorton H, Lyons G, Manraj P. Preparation for regional anaesthesia induces changes in thrombelastography. Br J Anaesth. Mar. 2000;84(3):403-4. X-1. [pmid: 10793606].
2037 Gossman GL, Joesch JM, Tanfer K. Trends in maternal request cesarean delivery from 1991 to 2004. Obstet Gynecol. Dec. 2006;108(6):1506-16. X-1. [pmid: 17138787].
2038 Gotoh H, Masuzaki H, Yoshida A, et al. Predicting incomplete uterine rupture with vaginal sonography during the late second trimester in women with prior cesarean. Obstet Gynecol. Apr. 2000;95(4):596-600. X-1. [pmid: 10725496].
2039 Gottlieb SE, Barrett DE. Effects of unanticipated cesarean section on mothers, infants, and their interaction in the first month of life. J Dev Behav Pediatr. Jun. 1986;7(3):180-5. X-1. [pmid: 3722392].
2040 Gottschall DS, Borgida AF, Mihalek JJ, et al. A randomized clinical trial comparing misoprostol with prostaglandin E2 gel for preinduction cervical ripening. Am J Obstet Gynecol. Nov. 1997;177(5):1067-70. X-4d, X-5. [pmid: 9396895].
2041 Gouchon S, Gregori D, Picotto A, et al. Skin-to-skin contact after cesarean delivery: an experimental study. Nurs Res. Mar-Apr. 2010;59(2):78-84. X-9. [pmid: 20179657].
2042 Goudie TA, Winter AW, Ferguson DJ. Lower limb compression using inflatable splints to prevent hypotension during spinal anaesthesia for caesarean section. Acta Anaesthesiol Scand. Oct. 1988;32(7):541-4. X-1. [pmid: 3188824].
2043 Goyert GL, Bottoms SF, Treadwell MC, et al. The physician factor in cesarean birth rates. N Engl J Med. Mar. 16. 1989;320(11):706-9. X-1. [pmid: 2922015].
2044 Grable IA, Garcia PM, Perry D, et al. Group B Streptococcus and preterm premature rupture of membranes: a randomized, double-blind clinical trial of antepartum ampicillin. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):1036-42. X-4e, X-5. [pmid: 8885772].
2045 Grace PJ, McLaughlin M. When consent isn't informed enough: what's the nurse's role when a patient has given consent but doesn't fully understand the risks?. Am J Nurs. Apr. 2005;105(4):79-84. X-1, X-2. [pmid: 15791089].
2046 Graham C, Goldstein A. Epidural analgesia and cardiac output in severe pre-eclamptics. Anaesthesia. Jul. 7. 1980;35(7):709-12. X-1. [pmid: 7435938].
2047 Graham CW, Sutton L, Cozen HJ. Directional spinals in obstetric analgesia. Anaesthesia. Feb. 1978;33(2):192-5. X-1. [pmid: 637277].
2048 Graham EM, Holcroft CJ, Blakemore KJ. Evidence of intrapartum hypoxia-ischemia is not present in the majority of cases of neonatal seizures. J Matern Fetal Neonatal Med. Aug. 2002;12(2):123-6. X-1. [pmid: 12420843].
2049 Graham EM, Holcroft CJ, Rai KK, et al. Neonatal cerebral white matter injury in preterm infants is associated with culture positive infections and only rarely with metabolic acidosis. Am J Obstet Gynecol. Oct. 2004;191(4):1305-10. X-1. [pmid: 15507958].
2050 Graham JM, Blanco JD, Oshiro BT, et al. Single-dose ampicillin prophylaxis does not eradicate enterococcus from the lower genital tract. Obstet Gynecol. Jan. 1993;81(1):115-7. X-9. [pmid: 8416444].
2051 Graham WJ, Hundley V, McCheyne AL, et al. An investigation of women's involvement in the decision to deliver by caesarean section. Br J Obstet Gynaecol. Mar. 1999;106(3):213-20. X-1. [pmid: 10426639].
2052 Gramellini D, Fieni S, Kaihura C, et al. Transabdominal antepartum amnioinfusion. Int J Gynaecol Obstet. Nov. 2003;83(2):171-8. X-1. [pmid: 14550592].
2053 Granger KA, Farquharson RG. Obstetric outcome in antiphospholipid syndrome. Lupus. 1997;6(6):509-13. X-1. [pmid: 9256308].
2054 Granot M, Lowenstein L, Yarnitsky D, et al. Postcesarean section pain prediction by preoperative experimental pain assessment. Anesthesiology. Jun. 2003;98(6):1422-6. X-1. [pmid: 12766652].
2055 Granovsky-Grisaru S, Shaya M, Diamant YZ. The management of labor in women with more than one uterine scar: is a repeat cesarean section really the only “safe” option?. J Perinat Med. 1994;22(1):13-7. X-1. [pmid: 8035290].
2056 Grant GJ, Ramanathan S, Turndorf H. The maternal hemodynamic effects of bupivacaine-epinephrine mixture used for obstetrical anesthesia. Acta Anaesthesiol Scand. Oct. 1990;34(7):543-7. X-1. [pmid: 2244441].
2057 Grant GJ, Susser L, Cascio M, et al. Hemodynamic effects of intrathecal fentanyl in nonlaboring term parturients. J Clin Anesth. Mar. 1996;8(2):99-103. X-9. [pmid: 8695107].
2058 Grant I. Forced obstetrical intervention: a charter analysis. Univ Tor Law J. 1989;39(3):217-57. X-1, X-2. [pmid: 11656008].
2059 Grant JM, Serle E, Mahmood T, et al. Management of prelabour rupture of the membranes in term primigravidae: report of a randomized prospective trial. Br J Obstet Gynaecol. Jul. 1992;99(7):557-62. X-4e. [pmid: 1525095].
2060 Grant R, Sueda A, Kaneshiro B. Expert opinion vs. patient perception of obstetrical outcomes in laboring women with birth plans. J Reprod Med. Jan-Feb. 2010;55(1-2):31-5. X-1. [pmid: 20337205].
2061 Grass JA, Sakima NT, Schmidt R, et al. A randomized, double-blind, dose-response comparison of epidural fentanyl versus sufentanil analgesia after cesarean section. Anesth Analg. Aug. 1997;85(2):365-71. X-9. [pmid: 9249115].
2062 Grau T, Leipold RW, Conradi R, et al. Ultrasound imaging facilitates localization of the epidural space during combined spinal and epidural anesthesia. Reg Anesth Pain Med. Jan-Feb. 2001;26(1):64-7. X-9. [pmid: 11172514].
2063 Grau T, Leipold RW, Conradi R, et al. Efficacy of ultrasound imaging in obstetric epidural anesthesia. J Clin Anesth. May. 2002;14(3):169-75. X-1. [pmid: 12031746].
2064 Grau T, Leipold RW, Fatehi S, et al. Real-time ultrasonic observation of combined spinal-epidural anaesthesia. Eur J Anaesthesiol. Jan. 2004;21(1):25-31. X-9. [pmid: 14768920].
2065 Green JM, Baston HA. Have women become more willing to accept obstetric interventions and does this relate to mode of birth? Data from a prospective study. Birth. Mar. 2007;34(1):6-13. X-1. [pmid: 17324172].
2066 Greenberg BL, Semba RD, Vink PE, et al. Vitamin A deficiency and maternal-infant transmissions of HIV in two metropolitan areas in the United States. AIDS. Mar. 1997;11(3):325-32. X-1. [pmid: 9147424].
2067 Greenberg MB, Cheng YW, Sullivan M, et al. Does length of labor vary by maternal age?. Am J Obstet Gynecol. Oct. 2007;197(4):428 e1-7. X-1. [pmid: 17904990].
2068 Greene PG, Zeichner A, Roberts NL, et al. Preparation for cesarean delivery: a multicomponent analysis of treatment outcome. J Consult Clin Psychol. Aug. 1989;57(4):484-7. X-3, X-4b, X-5. [pmid: 2768607].
2069 Greenland S, Neutra R. Control of confounding in the assessment of medical technology. Int J Epidemiol. Dec. 1980;9(4):361-7. X-1, X-2. [pmid: 7203778].
2070 Greenland S, Neutra R, Staisch KJ. Re: “The relation of electronic fetal monitoring patterns to infant outcome measures in a random sample of term size infants born to high risk mothers”. Am J Epidemiol. May. 1983;117(5):637-9. X-1, X-2. [pmid: 6846321].
2071 Greenough A, Lagercrantz H. Catecholamine abnormalities in transient tachypnoea of the premature newborn. J Perinat Med. 1992;20(3):223-6. X-1. [pmid: 1453297].
2072 Greenwood J. Caesarean sections--are rates too high?. Midwife Health Visit Community Nurse. Sep. 1983;19(9):367. X-1. [pmid: 6556438].
2073 Greer BE, Easterling TR, McLennan DA, et al. Fetal and maternal considerations in the management of stage I-B cervical cancer during pregnancy. Gynecol Oncol. Jul. 1989;34(1):61-5. X-1. [pmid: 2737528].
2074 Gregory KD, Korst LM, Gornbein JA, et al. Using administrative data to identify indications for elective primary cesarean delivery. Health Serv Res. Oct. 2002;37(5):1387-401. X-1. [pmid: 12479502].
2075 Gregory MA, Gin T, Yau G, et al. Propofol infusion anaesthesia for caesarean section. Can J Anaesth. Jul. 1990;37(5):514-20. X-9. [pmid: 2197002].
2076 Gregory R, Scott AR, Mohajer M, et al. Diabetic pregnancy 1977-1990: have we reached a plateau?. J R Coll Physicians Lond. Apr. 1992;26(2):162-6. X-1. [pmid: 1588524].
2077 Greybush M, Singleton C, Atlas RO, et al. Preinduction cervical ripening techniques compared. J Reprod Med. Jan. 2001;46(1):11-7. X-4d, X-5. [pmid: 11209625].
2078 Gribble RK, Meier PR. Effect of epidural analgesia on the primary cesarean rate. Obstet Gynecol. Aug. 1991;78(2):231-4. X-1, X-4e, X-5. [pmid: 2067767].
2079 Griffin ME, Coffey M, Johnson H, et al. Universal vs. risk factor-based screening for gestational diabetes mellitus: detection rates, gestation at diagnosis and outcome. Diabet Med. Jan. 2000;17(1):26-32. X-4e, X-5. [pmid: 10691156].
2080 Griffin RP, Reynolds F. Extradural anaesthesia for caesarean section: a double-blind comparison of 0.5% ropivacaine with 0.5% bupivacaine. Br J Anaesth. May. 1995;74(5):512-6. X-9. [pmid: 7772423].
2081 Griffith MI, Felts JH, James FM, et al. Successful control of pheochromocytoma in pregnancy. JAMA. Jul. 22. 1974;229(4):437-9. X-1. [pmid: 4407194].
2082 Griffith P. Midwives' attitudes: promoting normal birth. Aust J Adv Nurs. Mar-May. 1988;5(3):33-9. X-1. [pmid: 3415774].
2083 Griffiths AN, Avasarala S, Wiener JJ. A prospective observational study of emergency caesarean section rates and the effect of the labour ward experience. J Obstet Gynaecol. Oct. 2005;25(7):666-8. X-1. [pmid: 16263540].
2084 Griffiths J, Demianczuk N, Cordoviz M, et al. Surgical site infection following elective Caesarian section: a case-control study of postdischarge surveillance. J Obstet Gynaecol Can. Apr. 2005;27(4):340-4. X-1. [pmid: 15937607].
2085 Grignaffini A, Cavatorta E, Petrelli M, et al. Fetal distress: role of cardiotocography. Clin Exp Obstet Gynecol. 1994;21(1):49-56. X-1. [pmid: 8020178].
2086 Grignaffini A, Soncini E, Ronzoni E, et al. Meconium-stained amniotic fluid and fetal oxygen saturation measured by pulse oximetry during labour. Acta Biomed. Suppl 1. 2004;75:45-52. X-1. [pmid: 15301290].
2087 Grimpel YI, Kivity V, Cohen A, et al. Effects of calcium, magnesium, low-dose aspirin and low-molecular-weight heparin on the release of PP13 from placental explants. Placenta. Feb. 2011;32(Suppl):S55-64. X-1. [pmid: 21168205].
2088 Grobman WA, Feinglass J, Murthy S. Are the Agency for Healthcare Research and Quality obstetric trauma indicators valid measures of hospital safety?. Am J Obstet Gynecol. Sep. 2006;195(3):868-74. X-1. [pmid: 16949428].
2089 Grobman WA, Lai Y, Landon MB, et al. Development of a nomogram for prediction of vaginal birth after cesarean delivery. Obstet Gynecol. Apr. 2007;109(4):806-12. X-1. [pmid: 17400840].
2090 Grobman WA, Lai Y, Landon MB, et al. Does information available at admission for delivery improve prediction of vaginal birth after cesarean?. Am J Perinatol. Nov. 2009;26(10):693-701. X-1. [pmid: 19813165].
2091 Groom KM, Paterson-Brown S, Fisk NM. Temporal and geographical variation in UK obstetricians' personal preference regarding mode of delivery. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2002;100(2):185-8. X-1. [pmid: 11750962].
2092 Grosch-Woerner I, Puch K, Maier RF, et al. Increased rate of prematurity associated with antenatal antiretroviral therapy in a German/Austrian cohort of HIV-1-infected women. HIV Med. Jan. 2008;9(1):6-13. X-1. [pmid: 18199167].
2093 Grosch-Worner I, Schafer A, Obladen M, et al. An effective and safe protocol involving zidovudine and caesarean section to reduce vertical transmission of HIV-1 infection. AIDS. Dec. 22. 2000;14(18):2903-11. X-1. [pmid: 11153672].
2094 Gross J, Andersson K, Chen Y, et al. Effect of perinatal asphyxia on tyrosine hydroxylase and D2 and D1 dopamine receptor mRNA levels expressed during early postnatal development in rat brain. Brain Res Mol Brain Res. Apr. 4. 2005;134(2):275-81. X-1. [pmid: 15836923].
2095 Grossetti E, Carles G, El Guindi W, et al. Selective prophylactic transfusion in sickle cell disease. Acta Obstet Gynecol Scand. 2009;88(10):1090-4. X-1. [pmid: 19639465].
2096 Grossmann-Kendall F, Filippi V, De Koninck M, et al. Giving birth in maternity hospitals in Benin: testimonies of women. Reprod Health Matters. Nov. 2001;9(18):90-8. X-1. [pmid: 11765405].
2097 Grubb A. Treatment without consent (pregnancy): adult -- Tameside and Glossop Acute Services Trust v. C.H. Med Law Rev. Summer. 1996;4(2):193-8. X-1, X-2. [pmid: 11655136].
2098 Grubb A. Competent adult (pregnant woman): forced treatment and Mental Health Act -- St. George's Healthcare N.H.S. Trust v. S; R. v. Collins and others, ex parte S. Med Law Rev. Autumn. 1998;6(3):356-63. X-1, X-2. [pmid: 11658022].
2099 Grubb DK, Kjos SL, Paul RH. Latent labor with an unknown uterine scar. Obstet Gynecol. Sep. 1996;88(3):351-5. X-4b. [pmid: 8752238].
2100 Gruendhammer M, Brezinka C, Lechleitner M. The number of abnormal plasma glucose values in the oral glucose tolerance test and the feto-maternal outcome of pregnancy. Eur J Obstet Gynecol Reprod Biol. Jun. 10. 2003;108(2):131-6. X-1. [pmid: 12781399].
2101 Grundsell HS, Rizk DE, Kumar RM. Randomized study of non-closure of peritoneum in lower segment cesarean section. Acta Obstet Gynecol Scand. Jan. 1998;77(1):110-5. X-9. [pmid: 9492730].
2102 Grundy H, Anderson RL, Filly RA, et al. Gastroschisis: prenatal diagnosis and management. Fetal Ther. 1987;2(3):144-7. X-1. [pmid: 2977469].
2103 Grunebaum AN, Minkoff H, Schwarz RH, et al. The relationship of maternal antibody levels to post-cesarean section endometritis. Am J Obstet Gynecol. Dec. 15. 1983;147(8):919-22. X-1. [pmid: 6650628].
2104 Grytten J, Skau I, Sorensen R. Do expert patients get better treatment than others? Agency discrimination and statistical discrimination in obstetrics. J Health Econ. Jan. 2011;30(1):163-80. X-1. [pmid: 21095034].
2105 Guarino N, Teramoto H, Shima H, et al. Effect of mechanical ventilation on the pulmonary expression and production of elastin in nitrofen-induced diaphragmatic hernia in rats. J Pediatr Surg. Sep. 2002;37(9):1253-7. X-1. [pmid: 12194112].
2106 Guay J, Gaudreault P, Boulanger A, et al. Lidocaine hydrocarbonate and lidocaine hydrochloride for cesarean section: transplacental passage and neonatal effects. Acta Anaesthesiol Scand. Oct. 1992;36(7):722-7. X-9. [pmid: 1441877].
2107 Gude NM, Stebbing PN, Wang L, et al. Relative abundance of placental pro-atrial natriuretic factor mRNA in normal pregnancy and pre-eclampsia. Gynecol Obstet Invest. 2000;49(2):114-8. X-1. [pmid: 10671819].
2108 Gudmundsson S, Lindblad A, Marsal K. Cord blood gases and absence of end-diastolic blood velocities in the umbilical artery. Early Hum Dev. Dec. 1990;24(3):231-7. X-1. [pmid: 2128931].
2109 Guedj P, Eldor J, Stark M. Immediate postoperative oral hydration after caesarean section. Asia Oceania J Obstet Gynaecol. Jun. 1991;17(2):125-9. X-9. [pmid: 1867580].
2110 Guendelman S, Pearl M, Graham S, et al. Maternity leave in the ninth month of pregnancy and birth outcomes among working women. Womens Health Issues. Jan-Feb. 2009;19(1):30-7. X-1. [pmid: 19111785].
2111 Guest ML, Stamp GE. South Australian rural women's views of their pregnancy, birthing and postnatal care. Rural Remote Health. Jul-Sep. 2009;9(3):1101. X-1. [pmid: 19621980].
2112 Guidetti DA, Divon MY, Langer O. Postdate fetal surveillance: is 41 weeks too early?. Am J Obstet Gynecol. Jul. 1989;161(1):91-3. X-1, X-4e, X-5. [pmid: 2750826].
2113 Guillemette J, Fraser WD. Differences between obstetricians in caesarean section rates and the management of labour. Br J Obstet Gynaecol. Feb. 1992;99(2):105-8. X-1. [pmid: 1554658].
2114 Guillemin J. Increasing incidence and medical ‘necessity’ babies by Cesarean: who chooses, who controls?. Hastings Cent Rep. Jun. 1981;11(3):15-8. X-1. [pmid: 7239890].
2115 Guillon A, Leyre S, Remerand F, et al. Modification of Tp-e and QTc intervals during caesarean section under spinal anaesthesia. Anaesthesia. Apr. 2010;65(4):337-42. X-9. [pmid: 20136804].
2116 Guinn DA, Davies JK, Jones RO, et al. Labor induction in women with an unfavorable Bishop score: randomized controlled trial of intrauterine Foley catheter with concurrent oxytocin infusion versus Foley catheter with extra-amniotic saline infusion with concurrent oxytocin infusion. Am J Obstet Gynecol. Jul. 2004;191(1):225-9. X-4d. [pmid: 15295370].
2117 Guinn DA, Goepfert AR, Christine M, et al. Extra-amniotic saline, laminaria, or prostaglandin E(2) gel for labor induction with unfavorable cervix: a randomized controlled trial. Obstet Gynecol. Jul. 2000;96(1):106-12. X-4d. [pmid: 10862852].
2118 Guittier MJ, Pichon M, Dong H, et al. Moxibustion for breech version: a randomized controlled trial. Obstet Gynecol. Nov. 2009;114(5):1034-40. X-4c, X-5. [pmid: 20168104].
2119 Gulhas N, Erdil FA, Sagir O, et al. Lornoxicam and ondansetron for the prevention of intrathecal fentanyl-induced pruritus. J Anesth. 2007;21(2):159-63. X-9. [pmid: 17458644].
2120 Guller S, Kong L, Wozniak R, et al. Reduction of extracellular matrix protein expression in human amnion epithelial cells by glucocorticoids: a potential role in preterm rupture of the fetal membranes. J Clin Endocrinol Metab. Jul. 1995;80(7):2244-50. X-1. [pmid: 7608287].
2121 Gulmezoglu AM, Langer A, Piaggio G, et al. Cluster randomised trial of an active, multifaceted educational intervention based on the WHO Reproductive Health Library to improve obstetric practices. BJOG. Jan. 2007;114(1):16-23. X-4e, X-5. [pmid: 17010115].
2122 Gulmezoglu AM, Villar J, Ngoc NT, et al. WHO multicentre randomised trial of misoprostol in the management of the third stage of labour. Lancet. Sep. 1. 2001;358(9283):689-95. X-4e, X-5. [pmid: 11551574].
2123 Gunalp S, Bildirici I. The effect of vaginal pH on the efficacy of vaginal misoprostol for induction of labor. Acta Obstet Gynecol Scand. Apr. 2000;79(4):283-5. X-1. [pmid: 10746843].
2124 Gunaratne PS, Wijeyaratne CN, Chandrasiri P, et al. An outbreak of Aspergillus meningitis following spinal anaesthesia for caesarean section in Sri Lanka: a post-tsunami effect?. Ceylon Med J. Dec. 2006;51(4):137-42. X-1. [pmid: 17461323].
2125 Gunaydin B, Tan ED. Intrathecal hyperbaric or isobaric bupivacaine and ropivacaine with fentanyl for elective caesarean section. J Matern Fetal Neonatal Med. Dec. 2010;23(12):1481-6. X-9. [pmid: 20230319].
2126 Gundogan F, Bianchi DW, Scherjon SA, et al. Placental pathology in egg donor pregnancies. Fertil Steril. Feb. 2010;93(2):397-404. X-1. [pmid: 19249031].
2127 Gungorduk K, Asicioglu O, Celikkol O, et al. Does saline irrigation reduce the wound infection in caesarean delivery?. J Obstet Gynaecol. 2010;30(7):662-6. X-9. [pmid: 20925605].
2128 Gungorduk K, Asicioglu O, Celikkol O, et al. Use of additional oxytocin to reduce blood loss at elective caesarean section: A randomised control trial. Aust N Z J Obstet Gynaecol. Feb. 2010;50(1):36-9. X-9. [pmid: 20218995].
2129 Gungorduk K, Asicioglu O, Celikkol O, et al. Iatrogenic bladder injuries during caesarean delivery: a case control study. J Obstet Gynaecol. 2010;30(7):667-70. X-1, X-9. [pmid: 20925606].
2130 Gungorduk K, Yildirim G, Ark C. Is routine cervical dilatation necessary during elective caesarean section? A randomised controlled trial. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):263-7. X-9. [pmid: 19566557].
2131 Gungorduk K, Yildirim G, Dugan N, et al. Peripartum hysterectomy in Turkey: a case-control study. J Obstet Gynaecol. Nov. 2009;29(8):722-8. X-1. [pmid: 19821666].
2132 Gungorduk K, Yildirim G, Gungorduk O, et al. Sustained-release dinoprostone vaginal pessary with concurrent high-dose oxytocin infusion compared to sustained-release dinoprostone vaginal pessary followed 6 h later by high-dose oxytocin infusion for labor induction in women at term with unfavorable cervix: a randomized controlled trial. Gynecol Obstet Invest. 2011;71(1):32-40. X-4d. [pmid: 21160192].
2133 Gunnervik C, Josefsson A, Sydsjo A, et al. Attitudes towards mode of birth among Swedish midwives. Midwifery. Feb. 2010;26(1):38-44. X-1. [pmid: 18632194].
2134 Gunnervik C, Sydsjo G, Sydsjo A, et al. Attitudes towards cesarean section in a nationwide sample of obstetricians and gynecologists. Acta Obstet Gynecol Scand. 2008;87(4):438-44. X-1. [pmid: 18382871].
2135 Gunther A, Smith SJ, Maynard PV, et al. A case-control study of congenital hip dislocation. Public Health. Jan. 1993;107(1):9-18. X-1. [pmid: 8475246].
2136 Gunton JE, McElduff A, Sulway M, et al. Outcome of pregnancies complicated by pregestational diabetes mellitus. Aust N Z J Obstet Gynaecol. Feb. 2000;40(1):38-43. X-1. [pmid: 10870777].
2137 Gunusen I, Karaman S, Ertugrul V, et al. Effects of fluid preload (crystalloid or colloid) compared with crystalloid co-load plus ephedrine infusion on hypotension and neonatal outcome during spinal anaesthesia for caesarean delivery. Anaesth Intensive Care. Jul. 2010;38(4):647-53. X-9. [pmid: 20715726].
2138 Guo Y, Liu J, Meng L, et al. Survey of HBsAg-positive pregnant women and their infants regarding measures to prevent maternal-infantile transmission. BMC Infect Dis. 2010;10:26. X-1. [pmid: 20156338].
2139 Gupta A, Lokhandwala YY, Satoskar PR, et al. Balloon mitral valvotomy in pregnancy: maternal and fetal outcomes. J Am Coll Surg. Oct. 1998;187(4):409-15. X-1. [pmid: 9783788].
2140 Gupta I, Mahajan U, Lata P, et al. Copper intrauterine contraceptive device insertion 6 weeks after caesarean section. Indian J Med Res. Sep. 1985;82:214-6. X-1, X-4e. [pmid: 3908303].
2141 Gupta I, Mahajan U, Sawhney H. Concurrent copper T insertion with medical termination of pregnancy in women with previous caesarean section delivery. Indian J Med Res. May. 1988;87:450-2. X-1, X-3. [pmid: 3169901].
2142 Gupta N, Sood M, Nagesh S. Patterns of various modes of delivery in relation to presence of different risk factors in term pregnant mothers--a case-control study. J Indian Med Assoc. Dec. 1997;95(12):603-5. X-1. [pmid: 9586402].
2143 Gupta P, Elmardi A, Bathula U, et al. Induction of labour in women with one previous caesarean section. J Obstet Gynaecol. 2011;31(2):131-3. X-1. [pmid: 21281027].
2144 Gurbuz A, Karateke A, Yilmaz U, et al. The role of perinatal and intrapartum risk factors in the etiology of cerebral palsy in term deliveries in a Turkish population. J Matern Fetal Neonatal Med. Mar. 2006;19(3):147-55. X-1. [pmid: 16690507].
2145 Gutsche BB. Prophylactic ephedrine preceding spinal analgesia for cesarean section. Anesthesiology. Oct. 1976;45(4):462-5. X-9. [pmid: 788555].
2146 Guzin K, Tomruk S, Tuncay YA, et al. The relation of increased uterine artery blood flow resistance and impaired trophoblast invasion in pre-eclamptic pregnancies. Arch Gynecol Obstet. Oct. 2005;272(4):283-8. X-1. [pmid: 16007505].
2147 Gyamfi C, Juhasz G, Gyamfi P, et al. Increased success of trial of labor after previous vaginal birth after cesarean. Obstet Gynecol. Oct. 2004;104(4):715-9. X-1. [pmid: 15458891].
2148 Gyr TN, Malek A, Mathez-Loic F, et al. Permeation of human chorioamniotic membranes by Escherichia coli in vitro. Am J Obstet Gynecol. Jan. 1994;170(1 Pt 1):223-7. X-1. [pmid: 8296826].
2149 Haas AV. Homebirth after cesarean: the myth & the reality. Midwifery Today Int Midwife. Summer. 2008;(86):44-7. 68. 9. X-1, X-2. [pmid: 18630018].
2150 Haas DM, Ayres AW. Laceration injury at cesarean section. J Matern Fetal Neonatal Med. Mar. 2002;11(3):196-8. X-1. [pmid: 12380677].
2151 Haas DM, Contreras K. Vaginal preparation with antiseptic solution before cesarean section for preventing postoperative infections. Cochrane Database of Systematic Reviews. 2010;(3). X-1, X-2.
2152 Haas DM, Pazouki F, Smith RR, et al. Vaginal cleansing before cesarean delivery to reduce postoperative infectious morbidity: a randomized, controlled trial. Am J Obstet Gynecol. Mar. 2010;202(3):310 e1-6. X-9. [pmid: 20207251].
2153 Haas JS, Udvarhelyi S, Epstein AM. The effect of health coverage for uninsured pregnant women on maternal health and the use of cesarean section. JAMA. Jul. 7. 1993;270(1):61-4. X-5. [pmid: 8510298].
2154 Habek D, Habek JC, Barbir A, et al. Fetal grasping of the umbilical cord and perinatal outcome. Arch Gynecol Obstet. Oct. 2003;268(4):274-7. X-1. [pmid: 14504868].
2155 Habek D, Hodek B, Herman R, et al. Fetal biophysical profile and cerebro-umbilical ratio in assessment of perinatal outcome in growth-restricted fetuses. Fetal Diagn Ther. Jan-Feb. 2003;18(1):12-6. X-1. [pmid: 12566769].
2156 Haberman S, Bracero LA, Byrne DW. Spectral Doppler index mapping of the umbilicoplacental circulation and pregnancy outcome. Gynecol Obstet Invest. 2004;58(1):1-7. X-1. [pmid: 14981345].
2157 Habib AS, Itchon-Ramos N, Phillips-Bute BG, et al. Transcutaneous acupoint electrical stimulation with the ReliefBand for the prevention of nausea and vomiting during and after cesarean delivery under spinal anesthesia. Anesth Analg. Feb. 2006;102(2):581-4. X-9. [pmid: 16428565].
2158 Habib SM, Emam SS, Saber AS. Outpatient cervical ripening with nitric oxide donor isosorbide mononitrate prior to induction of labor. Int J Gynaecol Obstet. Apr. 2008;101(1):57-61. X-4d, X-5. [pmid: 18222450].
2159 Habiba M, Kaminski M, Da Fre M, et al. Caesarean section on request: a comparison of obstetricians' attitudes in eight European countries. BJOG. Jun. 2006;113(6):647-56. X-1. [pmid: 16709207].
2160 Hackethal A, Brueggmann D, Oehmke F, et al. Uterine compression U-sutures in primary postpartum hemorrhage after Cesarean section: fertility preservation with a simple and effective technique. Hum Reprod. Jan. 2008;23(1):74-9. X-1. [pmid: 18024985].
2161 Hadeed AJ, Siegel SR. Maternal cocaine use during pregnancy: effect on the newborn infant. Pediatrics. Aug. 1989;84(2):205-10. X-1. [pmid: 2748245].
2162 Hadfield L, Thomson R. The making of modern motherhood. Pract Midwife. Jul-Aug. 2009;12(7):30-2. X-1, X-2, X-3, X-4e, X-5. [pmid: 19653390].
2163 Haeri AD. Comparison of transverse and vertical skin incisions for Caesarean section. S Afr Med J. Jan. 10. 1976;50(2):33-4. X-3, X-4b, X-5. [pmid: 1251272].
2164 Haeri S, Guichard I, Baker AM, et al. The effect of teenage maternal obesity on perinatal outcomes. Obstet Gynecol. Feb. 2009;113(2 Pt 1):300-4. X-1. [pmid: 19155898].
2165 Haeri S, Masouem S, Baker AM, et al. The effect of excess weight gain in teenage pregnancies. Am J Perinatol. Jan. 2010;27(1):15-8. X-1. [pmid: 19562653].
2166 Hagberg C, Ezri T, Abouleish E. Etiology and incidence of endotracheal intubation following spinal anesthesia for cesarean section. Isr Med Assoc J. Sep. 2001;3(9):653-6. X-1. [pmid: 11574980].
2167 Hage ML, Helms MJ, Dudley A, et al. Acute childbirth morbidity: its measurement using hospital charges. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1853-9. discussion 1859-62. X-1. [pmid: 1615995].
2168 Hager WD, Pauly TH. Fetal tachycardia as an indicator of maternal and neonatal morbidity. Obstet Gynecol. Aug. 1985;66(2):191-4. X-1. [pmid: 4022482].
2169 Hager WD, Rapp RP, Billeter M, et al. Choice of antibiotic in nonelective cesarean section. Antimicrob Agents Chemother. Sep. 1991;35(9):1782-4. X-9. [pmid: 1952848].
2170 Hager WD, Schuchat A, Gibbs R, et al. Prevention of perinatal group B streptococcal infection: current controversies. Obstet Gynecol. Jul. 2000;96(1):141-5. X-1, X-2. [pmid: 10862856].
2171 Hager WD, Williamson MM. Effects of antibiotic prophylaxis on women undergoing nonelective cesarean section in a community hospital. J Reprod Med. Oct. 1983;28(10):687-90. X-9. [pmid: 6361251].
2172 Hagglund L, Christensen KK, Christensen P, et al. Reduced rate of postoperative infections in emergency cesarean section after two doses of cefuroxim perioperatively. A placebo-controlled study. Acta Obstet Gynecol Scand. 1989;68(3):201-4. X-9. [pmid: 2694741].
2173 Hagnevik K, Irestedt L, Lundell B, et al. Cardiac function and sympathoadrenal activity in the newborn after cesarean section under spinal and epidural anesthesia. Acta Anaesthesiol Scand. Apr. 1988;32(3):234-8. X-1. [pmid: 3364148].
2174 Hahn RG, Resby M. Volume kinetics of Ringer's solution and dextran 3% during induction of spinal anaesthesia for caesarean section. Can J Anaesth. May. 1998;45(5 Pt 1):443-51. X-1. [pmid: 9598259].
2175 Haines CJ, Rogers MS, Leung DH. Neonatal outcome and its relationship with maternal age. Aust N Z J Obstet Gynaecol. Aug. 1991;31(3):209-12. X-1. [pmid: 1804079].
2176 Hakansson S, Axemo P, Bremme K, et al. Group B streptococcal carriage in Sweden: a national study on risk factors for mother and infant colonisation. Acta Obstet Gynecol Scand. 2008;87(1):50-8. X-1. [pmid: 18158627].
2177 Hakansson S, Kallen K. Caesarean section increases the risk of hospital care in childhood for asthma and gastroenteritis. Clin Exp Allergy. Jun. 2003;33(6):757-64. X-1. [pmid: 12801309].
2178 Halaska MJ, Pentheroudakis G, Strnad P, et al. Presentation, management and outcome of 32 patients with pregnancy-associated breast cancer: a matched controlled study. Breast J. Sep-Oct. 2009;15(5):461-7. X-1. [pmid: 19624421].
2179 Halder A. A new uterine suture technique to control PPH in congenitally malformed uterus during caesarean section. J Obstet Gynaecol. Jul. 2009;29(5):402-4. X-1. [pmid: 19603317].
2180 Hales KA, Morgan MA, Thurnau GR. Influence of labor and route of delivery on the frequency of respiratory morbidity in term neonates. Int J Gynaecol Obstet. Oct. 1993;43(1):35-40. X-1. [pmid: 7904952].
2181 Halevy S, Liu-Barnett M, Ross PL, et al. Serum thyroid hormones changes in patients undergoing Caesarean section under general or regional anaesthesia. Br J Anaesth. Oct. 1978;50(10):1053-7. X-1. [pmid: 708547].
2182 Haley J, Tuffnell DJ, Johnson N. Randomised controlled trial of cardiotocography versus umbilical artery Doppler in the management of small for gestational age fetuses. Br J Obstet Gynaecol. Apr. 1997;104(4):431-5. X-4e. [pmid: 9141579].
2183 Hall DC, Kaufmann DA. Effects of aerobic and strength conditioning on pregnancy outcomes. Am J Obstet Gynecol. Nov. 1987;157(5):1199-203. X-1. [pmid: 3688075].
2184 Hall DR, Odendaal HJ, Kirsten GF, et al. Expectant management of early onset, severe pre-eclampsia: perinatal outcome. BJOG. Oct. 2000;107(10):1258-64. X-1. [pmid: 11028578].
2185 Hall DR, Odendaal HJ, Smith M. Is the prophylactic administration of magnesium sulphate in women with pre-eclampsia indicated prior to labour?. BJOG. Jul. 2000;107(7):903-8. X-1. [pmid: 10901563].
2186 Hall DR, Odendaal HJ, Steyn DW, et al. Expectant management of early onset, severe pre-eclampsia: maternal outcome. BJOG. Oct. 2000;107(10):1252-7. X-1. [pmid: 11028577].
2187 Hall JE, Ng WS, Smith S. Blood loss during first trimester termination of pregnancy: comparison of two anaesthetic techniques. Br J Anaesth. Feb. 1997;78(2):172-4. X-3, X-4e, X-5. [pmid: 9068336].
2188 Hall ML, Alexander CH. Fetal monitoring in a community hospital: analysis of health maintenance organization, fee-for-service, and clinic populations. Am J Obstet Gynecol. Jun. 1. 1982;143(3):277-85. X-1. [pmid: 7081346].
2189 Hall PA, Bennett A, Wilkes MP, et al. Spinal anaesthesia for caesarean section: comparison of infusions of phenylephrine and ephedrine. Br J Anaesth. Oct. 1994;73(4):471-4. X-9. [pmid: 7999486].
2190 Hall R, Duarte-Gardea M, Harlass F. Oral versus vaginal misoprostol for labor induction. Obstet Gynecol. Jun. 2002;99(6):1044-8. X-4d. [pmid: 12052597].
2191 Hallak M, Bottoms SF. Induction of labor in patients with term premature rupture of membranes. Effect on perinatal outcome. Fetal Diagn Ther. May-Jun. 1999;14(3):138-42. X-1. [pmid: 10364663].
2192 Hallstrom M, Eerola E, Vuento R, et al. Effects of mode of delivery and necrotising enterocolitis on the intestinal microflora in preterm infants. Eur J Clin Microbiol Infect Dis. Jun. 2004;23(6):463-70. X-1. [pmid: 15168141].
2193 Hallworth SP, Fernando R, Bell R, et al. Comparison of intrathecal and epidural diamorphine for elective caesarean section using a combined spinal-epidural technique. Br J Anaesth. Feb. 1999;82(2):228-32. X-9. [pmid: 10364999].
2194 Hallworth SP, Fernando R, Columb MO, et al. The effect of posture and baricity on the spread of intrathecal bupivacaine for elective cesarean delivery. Anesth Analg. Apr. 2005;100(4):1159-65. X-9. [pmid: 15781538].
2195 Halonen P, Sarvela J, Saisto T, et al. Patient-controlled epidural technique improves analgesia for labor but increases cesarean delivery rate compared with the intermittent bolus technique. Acta Anaesthesiol Scand. Jul. 2004;48(6):732-7. X-4e, X-5. [pmid: 15196106].
2196 Halonen PM, Paatero H, Hovorka J, et al. Comparison of two fentanyl doses to improve epidural anaesthesia with 0.5% bupivacaine for caesarean section. Acta Anaesthesiol Scand. Nov. 1993;37(8):774-9. X-9. [pmid: 7848388].
2197 Halperin ME, Moore DC, Hannah WJ. Classical versus low-segment transverse incision for preterm caesarean section: maternal complications and outcome of subsequent pregnancies. Br J Obstet Gynaecol. Oct. 1988;95(10):990-6. X-1. [pmid: 3191053].
2198 Halperin R, Zimmerman A, Langer R, et al. Laminaria dilatation and evacuation for pregnancies with mid-trimester premature rupture of membranes: a retrospective cohort study. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2002;100(2):181-4. X-1. [pmid: 11750961].
2199 Halpern S, Glanc P, Myhr T, et al. Uterine and umbilical blood flow velocity during epidural anaesthesia for caesarean section. Can J Anaesth. Nov. 1994;41(11):1057-62. X-1. [pmid: 7828252].
2200 Halpern SH, Arellano R, Preston R, et al. Epidural morphine vs hydromorphone in post-caesarean section patients. Can J Anaesth. Jun. 1996;43(6):595-8. X-9. [pmid: 8773867].
2201 Halpern SH, Breen TW, Campbell DC, et al. A multicenter, randomized, controlled trial comparing bupivacaine with ropivacaine for labor analgesia. Anesthesiology. Jun. 2003;98(6):1431-5. X-4e. [pmid: 12766654].
2202 Halpern SH, Crosby ET. Supplemental oxygen during caesarean section under epidural anaesthesia: nasal prongs vs face mask. Can J Anaesth. May. 1990;37(4 Pt 2):S137. X-4b. [pmid: 2193734].
2203 Halpern SH, Muir H, Breen TW, et al. A multicenter randomized controlled trial comparing patient-controlled epidural with intravenous analgesia for pain relief in labor. Anesth Analg. Nov. 2004;99(5):1532-8. table of contents. X-4e , X-5, X-6. [pmid: 15502060].
2204 Halvorsen L, Nerum H, Sorlie T, et al. Does counsellor's attitude influence change in a request for a caesarean in women with fear of birth?. Midwifery. Feb. 2010;26(1):45-52. X-1. [pmid: 18621452].
2205 Hamar BD, Saber SB, Cackovic M, et al. Ultrasound evaluation of the uterine scar after cesarean delivery: a randomized controlled trial of one- and two-layer closure. Obstet Gynecol. Oct. 2007;110(4):808-13. X-9. [pmid: 17906013].
2206 Hamar BD, Stiller RJ. Ultrasound clinics. Does U/S have a role in assessing uterine patency?. Contemporary OB/GYN. 2006;51(5):76. X-1, X-2.
2207 Hamdan M, Sidhu K, Sabir N, et al. Serial membrane sweeping at term in planned vaginal birth after cesarean: a randomized controlled trial. Obstet Gynecol. Oct. 2009;114(4):745-51. X-1, X-4b, X-5. [pmid: 19888030].
2208 Hamdorf-Torrens J. A story of homebirth after cesarean. Midwifery Today Int Midwife. Autumn. 2010;(95):30-1. 66. X-4e, X-5. [pmid: 20949790].
2209 Hameed N, Ali MA. Maternal blood loss by expansion of uterine incision at caesarean section--a comparison between sharp and blunt techniques. J Ayub Med Coll Abbottabad. Jul-Sep. 2004;16(3):47-50. X-1. [pmid: 15631372].
2210 Hamilton BE, Martin JA, Sutton PD. Births: preliminary data for 2002. Natl Vital Stat Rep. Jun. 25. 2003;51(11):1-20. X-1, X-2.
2211 Hamilton BE, Martin JA, Sutton PD. Births: preliminary data for 2003. Natl Vital Stat Rep. Nov. 23. 2004;53(9):1-17. X-1, X-2. [pmid: 15622995].
2212 Hamilton BE, Martin JA, Ventura SJ. Births: preliminary data for 2005. Natl Vital Stat Rep. Dec. 28. 2006;55(11):1-18. X-1, X-2.
2213 Hamilton EF, Bujold E, McNamara H, et al. Dystocia among women with symptomatic uterine rupture. Am J Obstet Gynecol. Mar. 2001;184(4):620-4. X-1. [pmid: 11262462].
2214 Hamilton RA, Dornan JC. Neural tube defects--prenatal diagnosis and management. Ulster Med J. Oct. 1992;61(2):127-33. X-1, X-4e, X-5. [pmid: 1481301].
2215 Hamilton WF, Robertson GS, Campbell D. Changes in serum uric acid concentrations after caesarean section using methoxyflurane. Br J Anaesth. Apr. 1975;47(4):508-11. X-1. [pmid: 1138761].
2216 Hammar M, Bostrom K, Borgvall B. Comparison between the influence of methylergometrine and oxytocin on the incidence of retained placenta in the third stage of labour. Gynecol Obstet Invest. 1990;30(2):91-3. X-1. [pmid: 2245955].
2217 Hamrick SE, Olshan AF, Neglia JP, et al. Association of pregnancy history and birth characteristics with neuroblastoma: a report from the Children's Cancer Group and the Pediatric Oncology Group. Paediatr Perinat Epidemiol. Oct. 2001;15(4):328-37. X-1. [pmid: 11703680].
2218 Han DW, Hong SW, Kwon JY, et al. Epidural ondansetron is more effective to prevent postoperative pruritus and nausea than intravenous ondansetron in elective cesarean delivery. Acta Obstet Gynecol Scand. 2007;86(6):683-7. X-1. [pmid: 17520399].
2219 Han TH, Brimacombe J, Lee EJ, et al. The laryngeal mask airway is effective (and probably safe) in selected healthy parturients for elective Cesarean section: a prospective study of 1067 cases. Can J Anaesth. Dec. 2001;48(11):1117-21. X-9. [pmid: 11744589].
2220 Hancock SF. The role of the judge in medical treatment decisions. Albany Law Rev. 1994;57(3):647-54. X-1, X-2. [pmid: 11652858].
2221 Handa VL, Harvey L, Fox HE, et al. Parity and route of delivery: does cesarean delivery reduce bladder symptoms later in life?. Am J Obstet Gynecol. Aug. 2004;191(2):463-9. X-1. [pmid: 15343222].
2222 Haney EI, Reiter JA, MacGregor SN, et al. Optional vaginal delivery rate. An informative indicator of intrapartum care. J Reprod Med. Oct. 1999;44(10):842-8. X-1. [pmid: 10554743].
2223 Hangsleben K, Jones M, Lia-Hoagberg B, et al. Medicaid and non-Medicaid prenatal care by nurse-midwives. Comparison of risk, time, care coordination, and reimbursement. J Nurse Midwifery. Jul-Aug. 1995;40(4):320-7. X-1. [pmid: 7674051].
2224 Hanigsberg JE. Power and procreation: state interference in pregnancy. Ottawa Law Rev. 1991;23(1):35-70. X-1, X-2. [pmid: 11656189].
2225 Hankins GD, Hammond TL, Snyder RR, et al. Transverse lie. Am J Perinatol. Jan. 1990;7(1):66-70. X-1. [pmid: 2131781].
2226 Hankins GD, Rowe J, Quirk JG Jr., et al. Significance of brown and/or green amniotic fluid at the time of second trimester genetic amniocentesis. Obstet Gynecol. Sep. 1984;64(3):353-8. X-1. [pmid: 6205335].
2227 Hannah ME, Hannah WJ, Hellmann J, et al. Induction of labor as compared with serial antenatal monitoring in post-term pregnancy. A randomized controlled trial. The Canadian Multicenter Post-term Pregnancy Trial Group. N Engl J Med. Jun. 11. 1992;326(24):1587-92. X-1, X-4e, X-5. [pmid: 1584259].
2228 Hannah ME, Hannah WJ, Hewson SA, et al. Planned caesarean section versus planned vaginal birth for breech presentation at term: a randomised multicentre trial. Term Breech Trial Collaborative Group. Lancet. Oct. 21. 2000;356(9239):1375-83. X-4c. [pmid: 11052579].
2229 Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. Apr. 10. 2002;287(14):1822-31. X-4c, X-3. [pmid: 11939868].
2230 Hannah ME, Hodnett ED, Willan A, et al. Prelabor rupture of the membranes at term: expectant management at home or in hospital? The TermPROM Study Group. Obstet Gynecol. Oct. 2000;96(4):533-8. X-1, X-2. [pmid: 11004354].
2231 Hannah ME, Huh C, Hewson SA, et al. Postterm pregnancy: putting the merits of a policy of induction of labor into perspective. Birth. Mar. 1996;23(1):13-9. X-1. [pmid: 8703252].
2232 Hannah ME, Ohlsson A, Farine D, et al. Induction of labor compared with expectant management for prelabor rupture of the membranes at term. TERMPROM Study Group. N Engl J Med. Apr. 18. 1996;334(16):1005-10. X-4d, X-4e. [pmid: 8598837].
2233 Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean section versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. Sep. 2004;191(3):917-27. X-1. [pmid: 15467565].
2234 Hannke-Lohmann A, Pildner von Steinburg S, Dehne K, et al. Downregulation of a mitogen-activated protein kinase signaling pathway in the placentas of women with preeclampsia. Obstet Gynecol. Oct. 2000;96(4):582-7. X-1. [pmid: 11004363].
2235 Hansen AR, Allred EN, Leviton A. Predictors of ventriculoperitoneal shunt among babies with intraventricular hemorrhage. J Child Neurol. Sep. 1997;12(6):381-6. X-1. [pmid: 9309522].
2236 Hansen V, Maigaard S, Allen J, et al. Effects of vasoactive intestinal polypeptide and substance P on human intramyometrial arteries and stem villous arteries in term pregnancy. Placenta. Sep-Oct. 1988;9(5):501-6. X-1. [pmid: 2464822].
2237 Hanson U, Persson B. Outcome of pregnancies complicated by type 1 insulin-dependent diabetes in Sweden: acute pregnancy complications, neonatal mortality and morbidity. Am J Perinatol. Jul. 1993;10(4):330-3. X-1. [pmid: 8397576].
2238 Hanson U, Persson B, Stangenberg M. Factors influencing neonatal morbidity in diabetic pregnancy. Diabetes Res. Feb. 1986;3(2):71-6. X-1. [pmid: 3698482].
2239 Hanss R, Bein B, Francksen H, et al. Heart rate variability-guided prophylactic treatment of severe hypotension after subarachnoid block for elective cesarean delivery. Anesthesiology. Apr. 2006;104(4):635-43. X-9. [pmid: 16571956].
2240 Hanss R, Bein B, Ledowski T, et al. Heart rate variability predicts severe hypotension after spinal anesthesia for elective cesarean delivery. Anesthesiology. Jun. 2005;102(6):1086-93. X-1. [pmid: 15915018].
2241 Hanss R, Ohnesorge H, Kaufmann M, et al. Changes in heart rate variability may reflect sympatholysis during spinal anaesthesia. Acta Anaesthesiol Scand. Nov. 2007;51(10):1297-304. X-1. [pmid: 17944631].
2242 Hantoushzadeh S, Rajabzadeh A, Saadati A, et al. Caesarean or normal vaginal delivery: overview of physicians' self-preference and suggestion to patients. Arch Gynecol Obstet. Jul. 2009;280(1):33-7. X-1. [pmid: 19052758].
2243 Hanzal E, Kainz C, Hoffmann G, et al. An analysis of the prediction of cephalopelvic disproportion. Arch Gynecol Obstet. 1993;253(4):161-6. X-1. [pmid: 8161249].
2244 Harger JH, Hsing AW, Tuomala RE, et al. Risk factors for preterm premature rupture of fetal membranes: a multicenter case-control study. Am J Obstet Gynecol. Jul. 1990;163(1 Pt 1):130-7. X-1. [pmid: 2197863].
2245 Harjulehto-Mervaala T, Hovi T, Aro T, et al. Oral poliovirus vaccination and pregnancy complications. Acta Obstet Gynecol Scand. Apr. 1995;74(4):262-5. X-1. [pmid: 7732798].
2246 Harlass FE, Duff P. The duration of labor in primiparas undergoing vaginal birth after cesarean delivery. Obstet Gynecol. Jan. 1990;75(1):45-7. X-1. [pmid: 2296421].
2247 Harle T, Brun JL, Leng JJ. Induction of labor in twin pregnancy after 36 weeks does not increase maternal-fetal morbidity. Int J Gynaecol Obstet. Apr. 2002;77(1):15-21. X-1. [pmid: 11929651].
2248 Harlev A, Levy A, Zaulan Y, et al. Idiopathic bleeding during the second half of pregnancy as a risk factor for adverse perinatal outcome. J Matern Fetal Neonatal Med. May. 2008;21(5):331-5. X-1. [pmid: 18446661].
2249 Harmon D, Ryan M, Kelly A, et al. Acupressure and prevention of nausea and vomiting during and after spinal anaesthesia for caesarean section. Br J Anaesth. Apr. 2000;84(4):463-7. X-9. [pmid: 10823097].
2250 Harnett MJ, O'Rourke N, Walsh M, et al. Transdermal scopolamine for prevention of intrathecal morphine-induced nausea and vomiting after cesarean delivery. Anesth Analg. Sep. 2007;105(3):764-9. X-9. [pmid: 17717237].
2251 Harper DM, Johnson CA, Harper WH, et al. Prenatal predictors of cesarean section due to labor arrest. Arch Gynecol Obstet. 1995;256(2):67-74. X-1. [pmid: 7611821].
2252 Harrigill KM, Miller HS, Haynes DE. The effect of intraabdominal irrigation at cesarean delivery on maternal morbidity: a randomized trial. Obstet Gynecol. Jan. 2003;101(1):80-5. X-9. [pmid: 12517650].
2253 Harrington LC, Miller DA, McClain CJ, et al. Vaginal birth after cesarean in a hospital-based birth center staffed by certified nurse-midwives. J Nurse Midwifery. Jul-Aug. 1997;42(4):304-7. X-1, X-4b. [pmid: 9277061].
2254 Harris DT. Experience in autologous and allogeneic cord blood banking. J Hematother. Apr. 1996;5(2):123-8. X-1. [pmid: 8723787].
2255 Harris JK. Self-care is possible after cesarean delivery. Nurs Clin North Am. Mar. 1980;15(1):191-204. X-1. [pmid: 6899202].
2256 Harris SJ, Farren MD, Janssen PA, et al. Single room maternity care: perinatal outcomes, economic costs,and physician preferences. J Obstet Gynaecol Can. Jul. 2004;26(7):633-40. X-1. [pmid: 15248932].
2257 Harrison DM, Sinatra R, Morgese L, et al. Epidural narcotic and patient-controlled analgesia for post-cesarean section pain relief. Anesthesiology. Mar. 1988;68(3):454-7. X-9. [pmid: 3278653].
2258 Harrison MR, Bressack MA, Churg AM, et al. Correction of congenital diaphragmatic hernia in utero. II. Simulated correction permits fetal lung growth with survival at birth. Surgery. Aug. 1980;88(2):260-8. X-4e. [pmid: 6893089].
2259 Harrison V, Peat G. Red blood cell magnesium and hypoxic-ischaemic encephalopathy. Early Hum Dev. Feb. 20. 1997;47(3):287-96. X-1, X-4e. [pmid: 9088795].
2260 Harsem NK, Staff AC, He L, et al. The decidual suction method: a new way of collecting decidual tissue for functional and morphological studies. Acta Obstet Gynecol Scand. Aug. 2004;83(8):724-30. X-1. [pmid: 15255844].
2261 Hart LG, Dobie SA, Baldwin LM, et al. Rural and urban differences in physician resource use for low-risk obstetrics. Health Serv Res. Oct. 1996;31(4):429-52. X-1. [pmid: 8885857].
2262 Hart MK, Lee KY, Hart RF, et al. Application of attribute control charts to risk-adjusted data for monitoring and improving health care performance. Qual Manag Health Care. Jan-Mar. 2003;12(1):5-19. X-1. [pmid: 12593370].
2263 Harten JM, Boyne I, Hannah P, et al. Effects of a height and weight adjusted dose of local anaesthetic for spinal anaesthesia for elective Caesarean section. Anaesthesia. Apr. 2005;60(4):348-53. X-9. [pmid: 15766337].
2264 Hartert RA Jr., Benrubi G, Thompson RJ, et al. Cefonicid vs. cefoxitin for cesarean section prophylaxis. J Reprod Med. Dec. 1987;32(12):907-10. X-9. [pmid: 3430499].
2265 Bruggemann OM, Parpinelli MA, Osis MJ, et al. Support to woman by a companion of her choice during childbirth: a randomized controlled trial. Reprod Health. 2007;4:5. X-5, X-6. [pmid: 17612408].
2266 Has R, Batukan C, Ermis H, et al. Comparison of 25 and 50 microg vaginally administered misoprostol for preinduction of cervical ripening and labor induction. Gynecol Obstet Invest. 2002;53(1):16-21. X-4d. [pmid: 11803223].
2267 Hasegawa J, Matsuoka R, Ichizuka K, et al. Cord insertion into the lower third of the uterus in the first trimester is associated with placental and umbilical cord abnormalities. Ultrasound Obstet Gynecol. Aug. 2006;28(2):183-6. X-1. [pmid: 16858739].
2268 Hasegawa M, Fujisawa H, Hayashi Y, et al. Autologous amnion graft for repair of myelomeningocele: technical note and clinical implication. J Clin Neurosci. May. 2004;11(4):408-11. X-1. [pmid: 15080958].
2269 Hatjis CG, Kofinas AD, Greelish JP, et al. Interrelationship between atrial natriuretic factor concentrations and acute volume expansion in pregnant and nonpregnant women. Am J Obstet Gynecol. Jul. 1990;163(1 Pt 1):45-50. X-1. [pmid: 2142856].
2270 Hauch MA, Gaiser RR, Hartwell BL, et al. Maternal and fetal colloid osmotic pressure following fluid expansion during cesarean section. Crit Care Med. Mar. 1995;23(3):510-4. X-1. [pmid: 7874903].
2271 Hauch MA, Hartwell BL, Hunt CO, et al. Comparative effects of subarachnoid hyperbaric bupivacaine and tetracaine-procaine for cesarean delivery. Reg Anesth. Mar-Apr. 1990;15(2):81-5. X-1, X-3, X-4b. [pmid: 2265160].
2272 Hauck YL, Fenwick J, Dhaliwal SS, et al. A Western Australian survey of breastfeeding initiation, prevalence and early cessation patterns. Matern Child Health J. Feb. 2011;15(2):260-8. X-1. [pmid: 20077131].
2273 Haugen F, Ranheim T, Harsem NK, et al. Increased plasma levels of adipokines in preeclampsia: relationship to placenta and adipose tissue gene expression. Am J Physiol Endocrinol Metab. Feb. 2006;290(2):E326-33. X-9. [pmid: 16144822].
2274 Haukkamaa M, Nilsson CG, Luukkainen T. Screening, management, and outcome of pregnancy in diabetic mothers. Obstet Gynecol. May. 1980;55(5):596-602. X-1. [pmid: 7366917].
2275 Hauth JC, Ewell MG, Levine RJ, et al. Pregnancy outcomes in healthy nulliparas who developed hypertension. Calcium for Preeclampsia Prevention Study Group. Obstet Gynecol. Jan. 2000;95(1):24-8. X-3, X-4e, X-5. [pmid: 10636496].
2276 Hauth JC, Owen J, Davis RO. Transverse uterine incision closure: one versus two layers. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):1108-11. X-3, X-4b, X-5. [pmid: 1415400].
2277 Haverkamp AD, Orleans M, Langendoerfer S, et al. A controlled trial of the differential effects of intrapartum fetal monitoring. Am J Obstet Gynecol. Jun. 15. 1979;134(4):399-412. X-4e, X-5. [pmid: 453276].
2278 Haverkamp AD, Thompson HE, McFee JG, et al. The evaluation of continuous fetal heart rate monitoring in high-risk pregnancy. Am J Obstet Gynecol. Jun. 1. 1976;125(3):310-20. X-4e, X-5. [pmid: 5895].
2279 Hawkins JL, Hess KR, Kubicek MA, et al. A reevaluation of the association between instrument delivery and epidural analgesia. Reg Anesth. Jan-Feb. 1995;20(1):50-6. X-1. [pmid: 7727329].
2280 Hawkins JL, Johnson TD, Kubicek MA, et al. Vecuronium for rapid-sequence intubation for cesarean section. Anesth Analg. Aug. 1990;71(2):185-90. X-1. [pmid: 1973881].
2281 Hawkins JL, Koonin LM, Palmer SK, et al. Anesthesia-related deaths during obstetric delivery in the United States, 1979-1990. Anesthesiology. Feb. 1997;86(2):277-84. X-1, X-4e. [pmid: 9054245].
2282 Hawkins TL, Lange IR, Gibson PS. Compliance with a perinatal prophylaxis policy for prevention of venous thromboembolism after caesarean section. J Obstet Gynaecol Can. Dec. 2008;30(12):1110-7. X-1. [pmid: 19175962].
2283 Hawrylyshyn PA, Bernstein P, Papsin FR. Short-term antibiotic prophylaxis in high-risk patients following cesarean section. Am J Obstet Gynecol. Feb. 1. 1983;145(3):285-9. X-3, X-4b. [pmid: 6337491].
2284 Hay DA, Gleeson C, Davies C, et al. What information should the multiple birth family receive before, during and after the birth?. Acta Genet Med Gemellol (Roma). 1990;39(2):259-69. X-1. [pmid: 2239111].
2285 Hayashi M, Hoshimoto K, Komine F, et al. Macrophage colony-stimulating factor levels in amniotic fluid before and after the onset of labor do not differ in normal pregnancies. Am J Reprod Immunol. May. 2004;51(5):329-35. X-1, X-4e. [pmid: 15212667].
2286 Hayashi M, Hoshimoto K, Ohkura T. Changes in blood macrophage colony-stimulating factor levels after cesarean section in normotensive pregnancy and preeclampsia. Am J Med Sci. Jul. 2002;324(1):5-9. X-9. [pmid: 12120825].
2287 Hayashi M, Sohma R, Sumioka Y, et al. Granulocyte-macrophage colony-stimulating factor levels in amniotic fluid before the onset of labor and during labor do not differ in normal pregnancies. Am J Reprod Immunol. Jan. 2006;55(1):69-75. X-1, X-4e. [pmid: 16364014].
2288 Hayman RG, Sattar N, Warren AY, et al. Relationship between myometrial resistance artery behavior and circulating lipid composition. Am J Obstet Gynecol. Feb. 1999;180(2 Pt 1):381-6. X-1. [pmid: 9988805].
2289 Haynes SR, Davidson I, Allsop JR, et al. Comparison of epidural methadone with epidural diamorphine for analgesia following caesarean section. Acta Anaesthesiol Scand. May. 1993;37(4):375-80. X-9. [pmid: 8322566].
2290 Haywood JL, Goldenberg RL, Bronstein J, et al. Comparison of perceived and actual rates of survival and freedom from handicap in premature infants. Am J Obstet Gynecol. Aug. 1994;171(2):432-9. X-1. [pmid: 8059823].
2291 Head BB, Owen J, Vincent RD Jr., et al. A randomized trial of intrapartum analgesia in women with severe preeclampsia. Obstet Gynecol. Mar. 2002;99(3):452-7. X-4e, X-5. [pmid: 11864673].
2292 Healy AJ, Malone FD, Sullivan LM, et al. Early access to prenatal care: implications for racial disparity in perinatal mortality. Obstet Gynecol. Mar. 2006;107(3):625-31. X-1. [pmid: 16507934].
2293 Heathcote R, Baird R, Ackland R, et al. Caesarean section surgical site surveillance in a private healthcare setting: a collaboration with the Victorian Hospital Acquired Infection Surveillance System (VICNISS) Coordinating Centre. Healthcare Infection. 2008;13(3):83-87. X-1.
2294 Hebisch G, Grauaug AA, Neumaier-Wagner PM, et al. The relationship between cervical dilatation, interleukin-6 and interleukin-8 during term labor. Acta Obstet Gynecol Scand. Sep. 2001;80(9):840-8. X-9. [pmid: 11531636].
2295 Hecht JL, Onderdonk A, Delaney M, et al. Characterization of chorioamnionitis in 2nd-trimester C-section placentas and correlation with microorganism recovery from subamniotic tissues. Pediatr Dev Pathol. Jan-Feb. 2008;11(1):15-22. X-1, X-9. [pmid: 18237241].
2296 Heck KE, Schoendorf KC, Chavez GF, et al. Does postpartum length of stay affect breastfeeding duration? A population-based study. Birth. Sep. 2003;30(3):153-9. X-1. [pmid: 12911797].
2297 Heckbert SR, Stephens CR, Daling JR. Diabetes in pregnancy: maternal and infant outcome. Paediatr Perinat Epidemiol. Oct. 1988;2(4):314-26. X-1, X-4e, X-5. [pmid: 3244551].
2298 Heddleston LN, Watson WJ. Vaginal birth after cesarean section in a small hospital. Mil Med. May. 1991;156(5):239-40. X-1. [pmid: 2057077].
2299 Heese Hde V, Davey DA, Rorke M, et al. Effect of maternal anaesthesia on oxygenation and acid-base status of the newborn infant. S Afr Med J. Oct. 27. 1973;47(42):1991-9. X-3, X-4b, X-5. [pmid: 4755010].
2300 Hefni MA, Lewis GA. Induction of labour with vaginal prostaglandin E2 pessaries. Br J Obstet Gynaecol. Mar. 1980;87(3):199-202. X-1. [pmid: 7387921].
2301 Hehre FW. Continuous lumbar peridural anesthesia in obstetrics. V. Double-blind comparison of 2 percent lidocaine and 2 percent prilocaine. Anesth Analg. Mar-Apr. 1969;48(2):177-80. X-1, X-4e, X-5. [pmid: 5813065].
2302 Heiberg E, Skurtveit S, Helsing E, et al. Women's experiences of giving birth in Northwest Russia in 2000 and 2002 and in Northern Norway 2000. Acta Obstet Gynecol Scand. 2007;86(3):373-5. X-1. [pmid: 17364316].
2303 Heikkila A, Tuomisto T, Hakkinen SK, et al. Tumor suppressor and growth regulatory genes are overexpressed in severe early-onset preeclampsia--an array study on case-specific human preeclamptic placental tissue. Acta Obstet Gynecol Scand. Jul. 2005;84(7):679-89. X-1. [pmid: 15954879].
2304 Heilbrun ME, Nygaard IE, Lockhart ME, et al. Correlation between levator ani muscle injuries on magnetic resonance imaging and fecal incontinence, pelvic organ prolapse, and urinary incontinence in primiparous women. Am J Obstet Gynecol. May. 2010;202(5):488 e1-6. X-1. [pmid: 20223445].
2305 Heilmann L, Rath W, Pollow K, et al. The rheological changes after cesarean section: The influence of low molecular weight or unfractionated heparin on the rheological properties of blood. Clin Hemorheol Microcirc. 2007;37(3):211-8. X-1, X-9. [pmid: 17726250].
2306 Heimstad R, Skogvoll E, Mattsson LA, et al. Induction of labor or serial antenatal fetal monitoring in postterm pregnancy: a randomized controlled trial. Obstet Gynecol. Mar. 2007;109(3):609-17. X-4e. [pmid: 17329511].
2307 Heinberg EM, Wood RA, Chambers RB. Elective induction of labor in multiparous women. Does it increase the risk of cesarean section?. J Reprod Med. May. 2002;47(5):399-403. X-1. [pmid: 12063879].
2308 Heineck I, Ferreira MB, Schenkel EP. Prescribing practice for antibiotic prophylaxis for cesarean section in a teaching hospital in Brazil. Am J Infect Control. Oct. 2002;30(6):341-5. X-9. [pmid: 12360142].
2309 Heinen L, Peterson E, Pion K, et al. Quality evaluation in a managed care system: comparative data to assess health plan performance. Manag Care Q. Winter. 1993;1(1):62-76. X-5. [pmid: 10130060].
2310 Helbo-Hansen S, Bang U, Garcia RS, et al. Subarachnoid versus epidural bupivacaine 0.5% for caesarean section. Acta Anaesthesiol Scand. Aug. 1988;32(6):473-6. X-9. [pmid: 3176835].
2311 Helfand M, Marton K, Ueland K. Factors involved in the interpretation of fetal monitor tracings. Am J Obstet Gynecol. Mar. 15. 1985;151(6):737-44. X-1. [pmid: 3976782].
2312 Helfand M, Zimmer-Gembeck MJ. Practice variation and the risk of low birth weight in a public prenatal care program. Med Care. Jan. 1997;35(1):16-31. X-1. [pmid: 8998200].
2313 Hellwig JP. Morning sickness treatments. Nursing for Women's Health. 2010;14(6):447-453. X-4e.
2314 Helm DA, Keegan KA Jr., Porto M. Hyperstimulation contraction stress tests: an evaluation of outcome by test pattern. Am J Perinatol. Sep. 1991;8(5):304-7. X-1. [pmid: 1760063].
2315 Helmer H, Hackl T, Schneeberger C, et al. Oxytocin and vasopressin 1a receptor gene expression in the cycling or pregnant human uterus. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1572-8. X-1. [pmid: 9855599].
2316 Helmerhorst FM, Perquin DAM, Donker D, et al. Perinatal outcome of singletons and twins after assisted conception: a systematic review of controlled studies. reprinted from BMJ 2004;328:261. Neonatal Intensive Care. 2005;18(7):30-34. X-4e.
2317 Heluin G, Papiernik E. Spontaneous or systematically induced labor for the termination of twin pregnancies. Acta Genet Med Gemellol (Roma). 1981;30(4):285-8. X-1. [pmid: 7345859].
2318 Heluin G, Papiernik E, Berardi JC, et al. Delivery of twin pregnancy. Acta Genet Med Gemellol (Roma). 1979;28(4):361-2. X-4e. [pmid: 555207].
2319 Hemlin J, Moller B. Extraamniotic saline infusion is promising in preparing the cervix for induction of labor. Acta Obstet Gynecol Scand. Jan. 1998;77(1):45-9. X-4d. [pmid: 9492717].
2320 Hemminki E. Effects of cesarean section on fertility and abortions. J Reprod Med. Jul. 1986;31(7):620-4. X-1. [pmid: 3746793].
2321 Hemminki E. Long term maternal health effects of caesarean section. J Epidemiol Community Health. Mar. 1991;45(1):24-8. X-1. [pmid: 2045740].
2322 Hemminki E, Graubard BI, Hoffman HJ, et al. Cesarean section and subsequent fertility: results from the 1982 National Survey of Family Growth. Fertil Steril. Apr. 1985;43(4):520-8. X-1. [pmid: 3872816].
2323 Hemminki E, Heikkila K, Sevon T, et al. Special features of health services and register based trials - experiences from a randomized trial of childbirth classes. BMC Health Serv Res. 2008;8:126. X-1. [pmid: 18547413].
2324 Hemminki E, Klemetti R, Gissler M. Cesarean section rates among health professionals in Finland, 1990-2006. Acta Obstet Gynecol Scand. 2009;88(10):1138-44. X-1. [pmid: 19707896].
2325 Hemminki E, Merilainen J. Long-term effects of cesarean sections: ectopic pregnancies and placental problems. Am J Obstet Gynecol. May. 1996;174(5):1569-74. X-1. [pmid: 9065131].
2326 Hemminki E, Rimpela U. A randomized comparison of routine versus selective iron supplementation during pregnancy. J Am Coll Nutr. Feb. 1991;10(1):3-10. X-4e, X-5. [pmid: 2010577].
2327 Hemminki E, Simukka R. The timing of hospital admission and progress of labour. Eur J Obstet Gynecol Reprod Biol. Jun. 1986;22(1-2):85-94. X-1. [pmid: 3721051].
2328 Hemminki E, Virta A, Koponen P. A trial on continuous human support during labor; Feasibility, interventions and mothers' satisfaction. J Psychosom Obstet Gynaecol. 1990;11:239-250.
2329 Hemsell DL, Cunningham FG, DePalma RT, et al. Cefotaxime sodium therapy for endomyometritis following cesarean section: dose-finding and comparative studies. Obstet Gynecol. Oct. 1983;62(4):489-97. X-9. [pmid: 6310464].
2330 Hemsell DL, Cunningham FG, Nolan CM, et al. Clinical experience with cefotaxime in obstetric and gynecologic infections. Rev Infect Dis. Sep-Oct. 1982;4(Suppl):S432-8. X-9. [pmid: 6294795].
2331 Henderson SK, Matthew EB, Cohen H, et al. Epidural hydromorphone: a double-blind comparison with intramuscular hydromorphone for postcesarean section analgesia. Anesthesiology. Jun. 1987;66(6):825-30. X-4e. [pmid: 2438965].
2332 Hendler I, Schatz M, Momirova V, et al. Association of obesity with pulmonary and nonpulmonary complications of pregnancy in asthmatic women. Obstet Gynecol. Jul. 2006;108(1):77-82. X-1, X-4e. [pmid: 16816059].
2333 Hendricks SK, Ross B, Colvard MA, et al. Amyl nitrite: use as a smooth muscle relaxant in difficult preterm cesarean section. Am J Perinatol. Jul. 1992;9(4):289-92. X-1. [pmid: 1352684].
2334 Hendrickx AG, Cukierski M, Prahalada S, et al. Evaluation of bendectin embryotoxicity in nonhuman primates: II. Double-blind study in term cynomolgus monkeys. Teratology. Oct. 1985;32(2):191-4. X-1. [pmid: 4049276].
2335 Henne MB, Zhang M, Paroski S, et al. Comparison of obstetric outcomes in recipients of donor oocytes vs. women of advanced maternal age with autologous oocytes. J Reprod Med. Jul. 2007;52(7):585-90. X-1. [pmid: 17847755].
2336 Hennebry MC, Stocks GM, Belavadi P, et al. Effect of i.v. phenylephrine or ephedrine on the ED50 of intrathecal bupivacaine with fentanyl for caesarean section. Br J Anaesth. Jun. 2009;102(6):806-11. X-9. [pmid: 19411667].
2337 Hennessy A, Thornton CE, Makris A, et al. A randomised comparison of hydralazine and mini-bolus diazoxide for hypertensive emergencies in pregnancy: the PIVOT trial. Aust N Z J Obstet Gynaecol. Aug. 2007;47(4):279-85. X. [pmid: 17627681].
2338 Henriksen TB, Sperling L, Hedegaard M, et al. Cesarean section in twin pregnancies in two Danish counties with different cesarean section rates. Acta Obstet Gynecol Scand. Feb. 1994;73(2):123-8. X-1. [pmid: 8116350].
2339 Henry GP, Miller WA. Early amniocentesis. J Reprod Med. May. 1992;37(5):396-402. X-1. [pmid: 1507188].
2340 Henry GR. A controlled trial of surgical induction of labour and amnioscopy in the management of prolonged pregnancy. J Obstet Gynaecol Br Commonw. Sep. 1969;76(9):795-8. X-4d, X-4e. [pmid: 4898652].
2341 Henry JA, Baker RW, Yanowitz TD. The in utero passage of meconium by very low birth weight infants: a marker for adverse outcomes. J Perinatol. Feb. 2006;26(2):125-9. X-1. [pmid: 16407963].
2342 Henry OA, Guaran RL, Petterson CD, et al. Obstetric and birthweight differences between Vietnam-born and Australian-born women. Med J Aust. Mar. 2. 1992;156(5):321-4. X-1. [pmid: 1588863].
2343 Herabutya Y, Chanarachakul B, Punyavachira P. Induction of labor with vaginal misoprostol for second trimester termination of pregnancy in the scarred uterus. Int J Gynaecol Obstet. Dec. 2003;83(3):293-7. X-1. [pmid: 14643040].
2344 Herabutya Y, OP P. The use of low dose 1.5 mg prostaglandin E2 gel for cervical ripening and induction of labor at term with unfavorable cervix. J Med Assoc Thai. Nov. 1995;78(11):590-5. X-1. [pmid: 8576669].
2345 Herabutya Y, OP P, Pokpirom J. A comparison of intravaginal misoprostol and intracervical prostaglandin E2 gel for ripening of unfavorable cervix and labor induction. J Obstet Gynaecol Res. Aug. 1997;23(4):369-74. X-1. [pmid: 9311179].
2346 Herabutya Y, Suchatwatnachai C, OP P. Comparison of intravenous oxytocin with and without vaginal prostaglandin E2 gel in term pregnancy with premature rupture of membranes and unfavorable cervix. J Med Assoc Thai. Feb. 1991;74(2):92-6. X-3, X-4d, X-4e, X-5. [pmid: 1953853].
2347 Heradien MJ, Goosen A, Crotti L, et al. Does pregnancy increase cardiac risk for LQT1 patients with the KCNQ1-A341V mutation?. J Am Coll Cardiol. Oct. 3. 2006;48(7):1410-5. X-1. [pmid: 17010804].
2348 Herbert WN. Cesarean delivery by patient choice: where do things stand?. Obstet Gynecol Surv. Mar. 2007;62(3):153-4. X-1, X-2. [pmid: 17306040].
2349 Herbst A, Ingemarsson I. Intermittent versus continuous electronic monitoring in labour: a randomised study. Br J Obstet Gynaecol. Aug. 1994;101(8):663-8. X-4e, X-5. [pmid: 7947499].
2350 Herbst A, Kallen K. Influence of mode of delivery on neonatal mortality in the second twin, at and before term. BJOG. Nov. 2008;115(12):1512-7. X-1. [pmid: 19035987].
2351 Herbstman CH, Jaffee JB, Tuman KJ, et al. An in vivo evaluation of four spinal needles used for the combined spinal-epidural technique. Anesth Analg. Mar. 1998;86(3):520-2. X-3, X-4e. [pmid: 9495405].
2352 Heres MH, Pel M, Elferink-Stinkens PM, et al. The Dutch obstetric intervention study--variations in practice patterns. Int J Gynaecol Obstet. Aug. 1995;50(2):145-50. X-1, X-4e, X-5. [pmid: 7589749].
2353 Herm FB, Killguss H, Stewart AG. Osteomalacia in Hazara District, Pakistan. Trop Doct. Jan. 2005;35(1):8-10. X-1. [pmid: 15712530].
2354 Herman G, Cohen AW, Talbot GH, et al. Cefoxitin versus clindamycin and gentamicin in the treatment of postcesarean section infections. Obstet Gynecol. Mar. 1986;67(3):371-6. X-9. [pmid: 3511419].
2355 Herman NL, Calicott R, Van Decar TK, et al. Determination of the dose-response relationship for intrathecal sufentanil in laboring patients. Anesth Analg. Jun. 1997;84(6):1256-61. X-4e, X-5. [pmid: 9174303].
2356 Hermus MA, Verhoeven CJ, Mol BW, et al. Comparison of induction of labour and expectant management in postterm pregnancy: a matched cohort study. J Midwifery Womens Health. Sep-Oct. 2009;54(5):351-6. X-1. [pmid: 19720335].
2357 Hernandez-Diaz S, Van Marter LJ, Werler MM, et al. Risk factors for persistent pulmonary hypertension of the newborn. Pediatrics. Aug. 2007;120(2):e272-82. X-1. [pmid: 17671038].
2358 Herrel N, Olevitch L, DuBois DK, et al. Somali refugee women speak out about their needs for care during pregnancy and delivery. J Midwifery Womens Health. Jul-Aug. 2004;49(4):345-9. X-1. [pmid: 15236715].
2359 Herrero-Mercado M, Waliszewski SM, Valencia-Quintana R, et al. Organochlorine pesticide levels in adipose tissue of pregnant women in Veracruz, Mexico. Bull Environ Contam Toxicol. Jun. 2010;84(6):652-6. X-1. [pmid: 20449723].
2360 Herring J. Caesarean sections, phobias and foetal rights. Camb Law J. Nov. 1997;36(3):509-11. X-1, X-2, X-3, X-4, X-5. [pmid: 11657622].
2361 Herse F, Dechend R, Harsem NK, et al. Dysregulation of the circulating and tissue-based renin-angiotensin system in preeclampsia. Hypertension. Mar. 2007;49(3):604-11. X-1. [pmid: 17261642].
2362 Hershey DW, Quilligan EJ. Extraabdominal uterine exteriorization at cesarean section. Obstet Gynecol. Aug. 1978;52(2):189-92. X-9. [pmid: 683658].
2363 Hershkovitz R, Kingdom JC, Geary M, et al. Fetal cerebral blood flow redistribution in late gestation: identification of compromise in small fetuses with normal umbilical artery Doppler. Ultrasound Obstet Gynecol. Mar. 2000;15(3):209-12. X-1. [pmid: 10846776].
2364 Herson VC, Block C, McLaughlin JC, et al. Placental blood sampling: an aid to the diagnosis of neonatal sepsis. J Perinatol. Mar-Apr. 1998;18(2):135-7. X-1. [pmid: 9605305].
2365 Hess PE, Snowman CE, Hahn CJ, et al. Chloroprocaine may not affect epidural morphine for postcesarean delivery analgesia. J Clin Anesth. Feb. 2006;18(1):29-33. X-9. [pmid: 16517329].
2366 Hew EM, Rolbin SH, Cole AF, et al. Obstetrical anaesthesia practice in the University of Toronto affiliated hospitals and some randomly selected community hospitals. Can Anaesth Soc J. Mar. 1981;28(2):158-66. X-1. [pmid: 7248826].
2367 Hewer N, Boschma G, Hall WA. Elective caesarean section as a transformative technological process: players, power and context. J Adv Nurs. Aug. 2009;65(8):1762-71. X-1. [pmid: 19493142].
2368 Hewson B. Ethical triumph, or surgical rape?. Solicit J. Nov. 26. 1993;137(45):1182-3. X-1. [pmid: 11656376].
2369 Hewson B. An upside-down world?. Mod Midwife. May. 1997;7(5):18-9. X-1. [pmid: 9224034].
2370 Hewson B. Whose body is it, anyway?. Nurs Stand. May. 21. 1997;11(35):18. X-1, X-2. [pmid: 9239007].
2371 Hibbard JU, Gilbert S, Landon MB, et al. Trial of labor or repeat cesarean delivery in women with morbid obesity and previous cesarean delivery. Obstet Gynecol. Jul. 2006;108(1):125-33. X-1. [pmid: 16816066].
2372 Hibbard JU, Shashoua A, Adamczyk C, et al. Cervical ripening with prostaglandin gel and hygroscopic dilators. Infect Dis Obstet Gynecol. 1998;6(1):18-24. X-4d, X-5. [pmid: 9678143].
2373 Hickman ME, Rench MA, Ferrieri P, et al. Changing epidemiology of group B streptococcal colonization. Pediatrics. Aug. 1999;104(2 Pt 1):203-9. X-1. [pmid: 10428995].
2374 Hidalgo LA, Chedraui PA, Chavez MJ. Obstetrical and neonatal outcome in young adolescents of low socio-economic status: a case control study. Arch Gynecol Obstet. Mar. 2005;271(3):207-11. X-1. [pmid: 15029506].
2375 Hidar S, Jennane TM, Bouguizane S, et al. The effect of placental removal method at cesarean delivery on perioperative hemorrhage: a randomized clinical trial ISRCTN 49779257. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2004;117(2):179-82. X-9. [pmid: 15541854].
2376 Higgins JR, Papayianni A, Brady HR, et al. Circulating vascular cell adhesion molecule-1 in pre-eclampsia, gestational hypertension, and normal pregnancy: evidence of selective dysregulation of vascular cell adhesion molecule-1 homeostasis in pre-eclampsia. Am J Obstet Gynecol. Aug. 1998;179(2):464-9. X-1. [pmid: 9731854].
2377 Higgins JR, Walshe JJ, Darling MR, et al. Hemostasis in the uteroplacental and peripheral circulations in normotensive and pre-eclamptic pregnancies. Am J Obstet Gynecol. Aug. 1998;179(2):520-6. X-1. [pmid: 9731863].
2378 Higuchi M, Hirano H, Maki M. Effect of human epidermal growth factor on lung surfactant production in fetal rabbit. Tohoku J Exp Med. Sep. 1989;159(1):15-22. X-1, X-2. [pmid: 2815072].
2379 Hiilesmaa V, Suhonen L, Teramo K. Glycaemic control is associated with pre-eclampsia but not with pregnancy-induced hypertension in women with type I diabetes mellitus. Diabetologia. Dec. 2000;43(12):1534-9. X-1. [pmid: 11151763].
2380 Hiilesmaa VK, Bardy A, Teramo K. Obstetric outcome in women with epilepsy. Am J Obstet Gynecol. Jul. 1. 1985;152(5):499-504. X-1. [pmid: 4014343].
2381 Hildingsson I. How much influence do women in Sweden have on caesarean section? A follow-up study of women's preferences in early pregnancy. Midwifery. Mar. 2008;24(1):46-54. X-1. [pmid: 17197058].
2382 Hildingsson I, Radestad I, Lindgren H. Birth preferences that deviate from the norm in Sweden: planned home birth versus planned cesarean section. Birth. Dec. 2010;37(4):288-95. X-1. [pmid: 21083720].
2383 Hill JA, Devoe LD, Bryans CI Jr. Frequency of asymptomatic bacteriuria in preeclampsia. Obstet Gynecol. Apr. 1986;67(4):529-32. X-1. [pmid: 3960425].
2384 Hill JB, Thigpen BD, Bofill JA, et al. A randomized clinical trial comparing vaginal misoprostol versus cervical Foley plus oral misoprostol for cervical ripening and labor induction. Am J Perinatol. Jan. 2009;26(1):33-8. X-4d. [pmid: 18850516].
2385 Hill NC, Hill JG, Sargent JM, et al. Effect of low dose heparin on blood loss at caesarean section. Br Med J (Clin Res Ed). May. 28. 1988;296(6635):1505-6. X-1.
2386 Hillan EM. Maternal-infant attachment following caesarean delivery. Journal of Clinical Nursing. 1992;1(1):33-37. X-1.
2387 Hillemanns P, Hasbargen U, Strauss A, et al. Maternal and neonatal morbidity of emergency caesarean sections with a decision-to-delivery interval under 30 minutes: evidence from 10 years. Arch Gynecol Obstet. Aug. 2003;268(3):136-41. X-1. [pmid: 12883825].
2388 Hilliard GD, Harris RE. Utilization of antibiotics for prevention of symptomatic postpartum infections. Obstet Gynecol. Sep. 1977;50(3):285-7. X-1. [pmid: 896096].
2389 Hillier S, Watts DH, Lee MF, et al. Etiology and treatment of post-cesarean-section endometritis after cephalosporin prophylaxis. J Reprod Med. Mar. 1990;35(3 Suppl):322-8. X-9. [pmid: 2181119].
2390 Hilton J, Allan B, Swaby C, et al. Intravenous nitroglycerin for external cephalic version: a randomized controlled trial. Obstet Gynecol. Sep. 2009;114(3):560-7. X-4e. [pmid: 19701035].
2391 Hin LY, Lau TK, Rogers M, et al. Antepartum and intrapartum prediction of cesarean need: risk scoring in singleton pregnancies. Obstet Gynecol. Aug. 1997;90(2):183-6. X-1, X-4e, X-5. [pmid: 9241289].
2392 Hincz P, Borowski D, Krekora M, et al. Maternal obesity as a perinatal risk factor. Ginekol Pol. May. 2009;80(5):334-7. X-1. [pmid: 19548451].
2393 Hindawi I. Value and pregnancy outcome of external cephalic version. East Mediterr Health J. Jul. 2005;11(4):633-9. X-1. [pmid: 16700378].
2394 Hingson R, Gould JB, Morelock S, et al. Maternal cigarette smoking, psychoactive substance use, and infant Apgar scores. Am J Obstet Gynecol. Dec. 15. 1982;144(8):959-66. X-1. [pmid: 7148928].
2395 Hirabayashi Y, Saitoh K, Fukuda H, et al. Visceral pain during caesarean section: effect of varying dose of spinal amethocaine. Br J Anaesth. Sep. 1995;75(3):266-8. X-9. [pmid: 7547040].
2396 Hiramatsu Y, Masuyama H, Mizutani Y, et al. Heavy-for-date infants: their backgrounds and relationship with gestational diabetes. J Obstet Gynaecol Res. Jun. 2000;26(3):193-8. X-1. [pmid: 10932981].
2397 Hirose M, Hara Y, Hosokawa T, et al. The effect of postoperative analgesia with continuous epidural bupivacaine after cesarean section on the amount of breast feeding and infant weight gain. Anesth Analg. Jun. 1996;82(6):1166-9. X-9. [pmid: 8638785].
2398 Hirose M, Hosokawa T, Tanaka Y. Extradural buprenorphine suppresses breast feeding after caesarean section. Br J Anaesth. Jul. 1997;79(1):120-1. X-1. [pmid: 9301399].
2399 Hirota Y, Sakai M, Nakabayashi M. Changes in plasma coagulation markers with prophylactic treatment of low molecular weight heparin after cesarean section. Semin Thromb Hemost. Jun. 2005;31(3):253-60. X-1. [pmid: 16052393].
2400 Hirsch SS. A family-centered cesarean birth. Midwifery Today Int Midwife. Autumn. 2010;(95):38-9. 67. X-1, X-2. [pmid: 20949794].
2401 Hitschold TP. Doppler flow velocity waveforms of the umbilical arteries correlate with intravillous blood volume. Am J Obstet Gynecol. Aug. 1998;179(2):540-3. X-1, X-3, X-4e, X-5. [pmid: 9731866].
2402 Hizkiyahu R, Levy A, Sheiner E. Pregnancy outcome of patients with schizophrenia. Am J Perinatol. Jan. 2010;27(1):19-23. X-1. [pmid: 19565434].
2403 Hjelm Cluff A, Malmstrom A, Tingaker B, et al. Normal labor associated with changes in uterine heparan sulfate proteoglycan expression and localization. Acta Obstet Gynecol Scand. Mar. 2005;84(3):217-24. X-1. [pmid: 15715528].
2404 Hjertberg R, Faxelius G, Belfrage P. Comparison of outcome of labetalol or hydralazine therapy during hypertension in pregnancy in very low birth weight infants. Acta Obstet Gynecol Scand. Nov. 1993;72(8):611-5. X-3, X-4e, X-5. [pmid: 8259746].
2405 Hjertberg R, Hammarstrom M, Moberger B, et al. Premature rupture of the membranes (PROM) at term in nulliparous women with a ripe cervix. A randomized trial of 12 or 24 hours of expectant management. Acta Obstet Gynecol Scand. Jan. 1996;75(1):48-53. X-4e. [pmid: 8560997].
2406 Ho CM, Hseu SS, Tsai SK, et al. Effect of P-6 acupressure on prevention of nausea and vomiting after epidural morphine for post-cesarean section pain relief. Acta Anaesthesiol Scand. Mar. 1996;40(3):372-5. X-4e. [pmid: 8721471].
2407 Ho CM, Tsai HJ, Chan KH, et al. P6 acupressure does not prevent emesis during spinal anesthesia for cesarean delivery. Anesth Analg. Mar. 2006;102(3):900-3. X-4b. [pmid: 16492848].
2408 Ho Yuen B, Phillips WD, Cannon W, et al. Prolactin, estradiol, and thyroid hormones in umbilical cord blood of neonates with and without hyaline membrane disease: a study of 405 neonates from midpregnancy to term. Am J Obstet Gynecol. Mar. 15. 1982;142(6 Pt 1):698-703. X-1. [pmid: 7065044].
2409 Hobel CJ, Parvez H, Parvez S, et al. Enzymes for epinephrine synthesis and metabolism in the myometrium, endometrium, red blood cells, and plasma of pregnant human subjects. Am J Obstet Gynecol. Dec. 15. 1981;141(8):1009-18. X-1. [pmid: 7315912].
2410 Hobson JA, Slade P, Wrench IJ, et al. Preoperative anxiety and postoperative satisfaction in women undergoing elective caesarean section. Int J Obstet Anesth. Jan. 2006;15(1):18-23. X-1, X-9. [pmid: 16256338].
2411 Hod M, Bar J, Peled Y, et al. Antepartum management protocol. Timing and mode of delivery in gestational diabetes. Diabetes Care. Aug. Suppl 2. 1998;21:B113-7. X-1, X-4e, X-5. [pmid: 9704237].
2412 Hodgkinson R, Glassenberg R, Joyce TH 3rd, et al. Comparison of cimetidine (Tagamet) with antacid for safety and effectiveness in reducing gastric acidity before elective cesarean section. Anesthesiology. Aug. 1983;59(2):86-90. X-9. [pmid: 6869899].
2413 Hodjati H, Kazerooni T. Location of the appendix in the gravid patient: a re-evaluation of the established concept. Int J Gynaecol Obstet. Jun. 2003;81(3):245-7. X-1. [pmid: 12767564].
2414 Hodnett ED, Gates S, Hofmeyr GJ, et al. Continuous support for women during childbirth. Cochrane Database Syst Rev. 2011;2:CD003766. X-1, X-2, X-3, X-4, X-5. [pmid: 21328263].
2415 Hodnett ED, Hannah ME, Hewson S, et al. Mothers' views of their childbirth experiences 2 years after planned Caesarean versus planned vaginal birth for breech presentation at term, in the international randomized Term Breech Trial. J Obstet Gynaecol Can. Mar. 2005;27(3):224-31. X-1. [pmid: 15937595].
2416 Hodnett ED, Osborn RW. Effects of continuous intrapartum professional support on childbirth outcomes. Res Nurs Health. Oct. 1989;12(5):289-97. X-4e, X-5. [pmid: 2798949].
2417 Hodnett ED, Osborn RW. A randomized trial of the effects of monitrice support during labor: mothers' views two to four weeks postpartum. Birth. Dec. 1989;16(4):177-83. discussion 183-4. X-4e, X-5. [pmid: 2610781].
2418 Hoffman DI, Abboud TK, Haase HR, et al. Plasma beta-endorphin concentrations prior to and during pregnancy, in labor, and after delivery. Am J Obstet Gynecol. Nov. 1. 1984;150(5 Pt 1):492-6. X-1. [pmid: 6093536].
2419 Hofmeyr GJ. Effect of external cephalic version in late pregnancy on breech presentation and caesarean section rate: a controlled trial. Br J Obstet Gynaecol. May. 1983;90(5):392-9. X-3, X-4c, X-4d, X-5. [pmid: 6342657].
2420 Hofmeyr GJ. Amnioinfusion for potential or suspected umbilical cord compression in labour. Cochrane Database of Systematic Reviews. 1998;(1). X-1, X-2.
2421 Hofmeyr GJ. Amnioinfusion for preterm rupture of membranes. Cochrane Database of Systematic Reviews. 1998;(1). X-1, X-2.
2422 Hofmeyr GJ, Alfirevic Z, Matonhodze B, et al. Titrated oral misoprostol solution for induction of labour: a multi-centre, randomised trial. BJOG. Sep. 2001;108(9):952-9. X-4d. [pmid: 11563466].
2423 Hofmeyr GJ, Kulier R. External cephalic version for breech presentation at term. Cochrane Database of Systematic Reviews. 1996;(1). X-1, X-2.
2424 Hofmeyr GJ, Kulier R. Operative versus conservative management for ‘fetal distress’ in labour. Cochrane Database of Systematic Reviews. 1998;(2). X-1, X-2.
2425 Hofmeyr GJ, Shweni PM. Symphysiotomy for feto-pelvic disproportion. Cochrane Database of Systematic Reviews. 2010;(10). X-1, X-2.
2426 Hogberg U, Lynoe N, Wulff M. Cesarean by choice? Empirical study of public attitudes. Acta Obstet Gynecol Scand. 2008;87(12):1301-8. X-1. [pmid: 18972235].
2427 Hogg B, Hauth JC, Caritis SN, et al. Safety of labor epidural anesthesia for women with severe hypertensive disease. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1096-101. X-1. [pmid: 10561625].
2428 Hogle KL, Kilburn L, Hewson S, et al. Impact of the international term breech trial on clinical practice and concerns: a survey of centre collaborators. J Obstet Gynaecol Can. Jan. 2003;25(1):14-6. X-1. [pmid: 12548320].
2429 Hohlagschwandtner M, Chalubinski K, Nather A, et al. Continuous vs interrupted sutures for single-layer closure of uterine incision at cesarean section. Arch Gynecol Obstet. Apr. 2003;268(1):26-8. X-1. [pmid: 12673471].
2430 Hohlagschwandtner M, Ruecklinger E, Husslein P, et al. Is the formation of a bladder flap at cesarean necessary? A randomized trial. Obstet Gynecol. Dec. 2001;98(6):1089-92. X-9. [pmid: 11755558].
2431 Hohlfeld P. Cesarean section on request: a case for common sense. Gynakol Geburtshilfliche Rundsch. 2002;42(1):19-21. X-1, X-2. [pmid: 12037414].
2432 Hojberg KE, Aagaard J, Laursen H, et al. Closure versus non-closure of peritoneum at cesarean section--evaluation of pain. A randomized study. Acta Obstet Gynecol Scand. Aug. 1998;77(7):741-5. X-9. [pmid: 9740522].
2433 Holdcroft A, Morgan M, Gordon H, et al. Althesin as an induction agent for Caesarean section. Br J Anaesth. Nov. 1975;47(11):1213-7. X-9. [pmid: 1218150].
2434 Holdcroft A, Robinson MJ, Gordon H, et al. Comparison of effect of two induction doses of methohexitone on infants delivered by elective caesarean section. Br Med J. Jun. 1. 1974;2(5917):472-5. X-1. [pmid: 4834097].
2435 Holden KR, Titus MO, Van Tassel P. Cranial magnetic resonance imaging examination of normal term neonates: a pilot study. J Child Neurol. Nov. 1999;14(11):708-10. X-1. [pmid: 10593546].
2436 Holdsworth JD. Relationship between stomach contents and analgesia in labour. Br J Anaesth. Nov. 1978;50(11):1145-8. X-1. [pmid: 718785].
2437 Holdsworth-Carson SJ, Permezel M, Riley C, et al. Peroxisome proliferator-activated receptors and retinoid X receptor-alpha in term human gestational tissues: tissue specific and labour-associated changes. Placenta. Feb. 2009;30(2):176-86. X-1. [pmid: 19070893].
2438 Holland ML, Holland ES. Survey of Connecticut Nurse-Midwives. J Midwifery Womens Health. Mar-Apr. 2007;52(2):106-15. X-1. [pmid: 17336816].
2439 Hollander P, Maeder EC Jr. Diabetes in pregnancy. No longer a barrier to successful outcome. Postgrad Med. Feb. 1. 1985;77(2):137-41. 144. 6. X-1, X-2. [pmid: 3881750].
2440 Hollinger JL. Transcutaneous electrical nerve stimulation after cesarean birth. Phys Ther. Jan. 1986;66(1):36-8. X-1. [pmid: 3484553].
2441 Hollmen AI, Eskelinen P, Tolonen U, et al. Effects of anaesthesia for caesarean section on the computerized EEG of the neonate. Eur J Anaesthesiol. Mar. 1985;2(1):39-51. X-1. [pmid: 4018040].
2442 Hollmen AI, Jouppila R, Albright GA, et al. Intervillous blood flow during caesarean section with prophylactic ephedrine and epidural anaesthesia. Acta Anaesthesiol Scand. Aug. 1984;28(4):396-400. X-1. [pmid: 6435379].
2443 Holmes P, Oppenheimer LW, Gravelle A, et al. The effect of variable heart rate decelerations on intraventricular hemorrhage and other perinatal outcomes in preterm infants. J Matern Fetal Med. Aug. 2001;10(4):264-8. X-1. [pmid: 11531153].
2444 Holmes R, Montemagno R, Jones J, et al. Fetal and maternal plasma insulin-like growth factors and binding proteins in pregnancies with appropriate or retarded fetal growth. Early Hum Dev. Jul. 24. 1997;49(1):7-17. X-1. [pmid: 9179534].
2445 Holmlund U, Wahamaa H, Bachmayer N, et al. The novel inflammatory cytokine high mobility group box protein 1 (HMGB1) is expressed by human term placenta. Immunology. Nov. 2007;122(3):430-7. X-1. [pmid: 17617154].
2446 Holub Z, Lukac J, Kliment L, et al. Pregnancy outcomes and deliveries following laparoscopic transsection of uterine vessels: a pilot study. Eur J Obstet Gynecol Reprod Biol. Apr. 1. 2006;125(2):165-70. X-1. [pmid: 16054287].
2447 Holub Z, Mara M, Kuzel D, et al. Pregnancy outcomes after uterine artery occlusion: prospective multicentric study. Fertil Steril. Nov. 2008;90(5):1886-91. X-1, X-4e, X-5. [pmid: 18155701].
2448 Holzer D. Honouring traditional midwifery, valuing the knowledge: a Mexico conference. International Midwifery. 2004;17(2):18-19. X-1, X-2.
2449 Homer CS, Davis GK, Brodie PM. What do women feel about community-based antenatal care?. Aust N Z J Public Health. Dec. 2000;24(6):590-5. X-4e, X-5. [pmid: 11215006].
2450 Homer CS, Davis GK, Cooke M, et al. Women's experiences of continuity of midwifery care in a randomised controlled trial in Australia. Midwifery. Jun. 2002;18(2):102-12. X-4e, X-5. [pmid: 12139908].
2451 Homer CS, Kurinczuk JJ, Spark P, et al. A novel use of a classification system to audit severe maternal morbidity. Midwifery. Oct. 2010;26(5):532-6. X-1. [pmid: 20691518].
2452 Homer CS, Matha DV, Jordan LG, et al. Community-based continuity of midwifery care versus standard hospital care: a cost analysis. Aust Health Rev. 2001;24(1):85-93. X-1. [pmid: 11357746].
2453 Homko CJ, Sivan E, Nyirjesy P, et al. The interrelationship between ethnicity and gestational diabetes in fetal macrosomia. Diabetes Care. Nov. 1995;18(11):1442-5. X-1. [pmid: 8722067].
2454 Homko CJ, Sivan E, Reece EA. The impact of self-monitoring of blood glucose on self-efficacy and pregnancy outcomes in women with diet-controlled gestational diabetes. Diabetes Educ. May-Jun. 2002;28(3):435-43. X-4e. [pmid: 12073958].
2455 Honarmand A, Safavi MR. Prediction of difficult laryngoscopy in obstetric patients scheduled for Caesarean delivery. Eur J Anaesthesiol. Sep. 2008;25(9):714-20. X-1. [pmid: 18471331].
2456 Hong JY, Jee YS, Jeong HJ, et al. Effects of epidural fentanyl on speed and quality of block for emergency cesarean section in extending continuous epidural labor analgesia using ropivacaine and fentanyl. J Korean Med Sci. Feb. 2010;25(2):287-92. X-9. [pmid: 20119585].
2457 Hong JY, Lee IH. Comparison of the effects of intrathecal morphine and pethidine on shivering after Caesarean delivery under combined-spinal epidural anaesthesia. Anaesthesia. Dec. 2005;60(12):1168-72. X-9. [pmid: 16288613].
2458 Hong JY, Park JW, Oh JI. Comparison of preoperative gastric contents and serum gastrin concentrations in pregnant and nonpregnant women. J Clin Anesth. Sep. 2005;17(6):451-5. X-1. [pmid: 16171666].
2459 Hong X. Factors related to the high cesarean section rate and their effects on the “price transparency policy” in Beijing, China. Tohoku J Exp Med. Jul. 2007;212(3):283-98. X-1. [pmid: 17592216].
2460 Hongo T, Kitamura A, Yokozuka M, et al. An epidural initial dose is unnecessary in combined spinal epidural anesthesia for Caesarean section. J Nippon Med Sch. Apr. 2006;73(2):70-4. X-9. [pmid: 16641530].
2461 Hood DD, Dewan DM. Anesthetic and obstetric outcome in morbidly obese parturients. Anesthesiology. Dec. 1993;79(6):1210-8. X-1. [pmid: 8267196].
2462 Hood DD, Dewan DM, James FM 3rd, et al. The use of nitroglycerin in preventing the hypertensive response to tracheal intubation in severe preeclampsia. Anesthesiology. Sep. 1985;63(3):329-32. X-9. [pmid: 3927785].
2463 Hooi LS, Rozina G, Shaariah MY, et al. Pregnancy in patients with renal transplants in Malaysia. Med J Malaysia. Mar. 2003;58(1):27-36. X-1. [pmid: 14556324].
2464 Hopkins K. Are Brazilian women really choosing to deliver by cesarean?. Soc Sci Med. Sep. 2000;51(5):725-40. X-1. [pmid: 10975232].
2465 Hopkins L, Smaill FM. Antibiotic prophylaxis regimens and drugs for cesarean section. Cochrane Database of Systematic Reviews. 1999;(2). X-1, X-2.
2466 Hopkins LM, Caughey AB, Brown JS, et al. Concordance of chart abstraction and patient recall of intrapartum variables up to 53 years later. Am J Obstet Gynecol. Mar. 2007;196(3):233 e1-6. X-1. [pmid: 17346533].
2467 Hopkinson JM, Samaan AK, Russell IF, et al. A comparative multicentre trial of spinal needles for caesarean section. Anaesthesia. Oct. 1997;52(10):1005-11. X-9. [pmid: 9370847].
2468 Hopp H, Vollert W, Ragosch V, et al. Indication and results of insulin therapy for gestational diabetes mellitus. J Perinat Med. 1996;24(5):521-30. X-4e, X-5. [pmid: 8950733].
2469 Horn EP, Schroeder F, Gottschalk A, et al. Active warming during cesarean delivery. Anesth Analg. Feb. 2002;94(2):409-14. table of contents. X-9. [pmid: 11812709].
2470 Hornick HL. Mama vs. fetus. Med Trial Tech Q. 1993;39(4):536-69. X-1. [pmid: 11659785].
2471 Horstman DJ, Riley ET, Carvalho B. A randomized trial of maximum cephalad sensory blockade with single-shot spinal compared with combined spinal-epidural techniques for cesarean delivery. Anesth Analg. Jan. 2009;108(1):240-5. X-9. [pmid: 19095857].
2472 Horta ML, Horta BL. Inhibition of epidural morphine-induced pruritus by intravenous droperidol. Reg Anesth. Mar-Apr. 1993;18(2):118-20. X-9. [pmid: 8489978].
2473 Horta ML, Morejon LC, da Cruz AW, et al. Study of the prophylactic effect of droperidol, alizapride, propofol and promethazine on spinal morphine-induced pruritus. Br J Anaesth. Jun. 2006;96(6):796-800. X-9. [pmid: 16597655].
2474 Horta ML, Ramos L, Goncalves Zda R, et al. Inhibition of epidural morphine-induced pruritus by intravenous droperidol. The effect of increasing the doses of morphine and of droperidol. Reg Anesth. Jul-Aug. 1996;21(4):312-7. X-9. [pmid: 8837189].
2475 Horta ML, Ramos L, Goncalves ZR. The inhibition of epidural morphine-induced pruritus by epidural droperidol. Anesth Analg. Mar. 2000;90(3):638-41. X-9. [pmid: 10702450].
2476 Hoskins IA, Ordorica SA, Frieden FJ, et al. Performance of cesarean section using absorbable staples. Surg Gynecol Obstet. Feb. 1991;172(2):108-12. X-9. [pmid: 1846451].
2477 Hossain N, Khan N, Sultana SS. Abruptio placenta and adverse pregnancy outcome. J Pak Med Assoc. Jun. 2010;60(6):443-6. X-1. [pmid: 20527640].
2478 Hossein-Nezhad A, Maghbooli Z, Vassigh AR, et al. Prevalence of gestational diabetes mellitus and pregnancy outcomes in Iranian women. Taiwan J Obstet Gynecol. Sep. 2007;46(3):236-41. X-1. [pmid: 17962102].
2479 Hou S. Pregnancy and birth control in CAPD patients. Adv Perit Dial. 1993;9:173-6. X-1. [pmid: 8105917].
2480 Houghton DJ. Use of lorazepam as a premedicant for caesarean section. An evaluation of its effects on the mother and the neonate. Br J Anaesth. Aug. 1983;55(8):767-71. X-9. [pmid: 6136289].
2481 Houlton PC, Downing JW, Buley RJ, et al. Anaesthetic induction of caesarean section with thiopentone, methohexitone and ketamine. S Afr Med J. Nov. 11. 1978;54(20):818-20. X-1, X-3, X-4b. [pmid: 33455].
2482 Hounshell JB, Schrager S. Topics in maternity care. Evidence-based uses of amnioinfusion. Evidence-Based Practice. 2007;10(9):8-9. X-1.
2483 Hounton S, Chapman G, Menten J, et al. Accessibility and utilisation of delivery care within a Skilled Care Initiative in rural Burkina Faso. Trop Med Int Health. Jul. Suppl 1. 2008;13:44-52. X-1. [pmid: 18578811].
2484 Hourvitz A, Alcalay M, Korach J, et al. A prospective study of high- versus low-dose oxytocin for induction of labor. Acta Obstet Gynecol Scand. Aug. 1996;75(7):636-41. X-4d. [pmid: 8822656].
2485 Houston MC, Raynor BD. Postoperative morbidity in the morbidly obese parturient woman: supraumbilical and low transverse abdominal approaches. Am J Obstet Gynecol. May. 2000;182(5):1033-5. X-1. [pmid: 10819819].
2486 How HY, Harris BJ, Pietrantoni M, et al. Is vaginal delivery preferable to elective cesarean delivery in fetuses with a known ventral wall defect?. Am J Obstet Gynecol. Jun. 2000;182(6):1527-34. X-1. [pmid: 10871475].
2487 How HY, Hughes SA, Vogel RL, et al. Oral terbutaline in the outpatient management of preterm labor. Am J Obstet Gynecol. Nov. 1995;173(5):1518-22. X-4e. [pmid: 7503194].
2488 How HY, Leaseburge L, Khoury JC, et al. A comparison of various routes and dosages of misoprostol for cervical ripening and the induction of labor. Am J Obstet Gynecol. Oct. 2001;185(4):911-5. X-4d. [pmid: 11641677].
2489 Howard CR, Howard FM, Lanphear B, et al. Randomized clinical trial of pacifier use and bottle-feeding or cupfeeding and their effect on breastfeeding. Pediatrics. Mar. 2003;111(3):511-8. X-3, X-4e. [pmid: 12612229].
2490 Howard RJ, Tuck SM, Pearson TC. Pregnancy in sickle cell disease in the UK: results of a multicentre survey of the effect of prophylactic blood transfusion on maternal and fetal outcome. Br J Obstet Gynaecol. Dec. 1995;102(12):947-51. X-1. [pmid: 8652484].
2491 Howden NL, Weber AM, Meyn LA. Episiotomy use among residents and faculty compared with private practitioners. Obstet Gynecol. Jan. 2004;103(1):114-8. X-1. [pmid: 14704254].
2492 Howe RS, Sayegh RA, Durinzi KL, et al. Perinatal outcome of singleton pregnancies conceived by in vitro fertilization: a controlled study. J Perinatol. Sep. 1990;10(3):261-6. X-1. [pmid: 2213266].
2493 Howell EM, Dubay L, Kenney G, et al. The impact of Medicaid managed care on pregnant women in Ohio: a cohort analysis. Health Serv Res. Aug. 2004;39(4 Pt 1):825-46. X-4b, X-4e. [pmid: 15230930].
2494 Howell P, Davies W, Wrigley M, et al. Comparison of four local extradural anaesthetic solutions for elective caesarean section. Br J Anaesth. Nov. 1990;65(5):648-53. X-9. [pmid: 2248843].
2495 Howell PR, Gambling DR, Pavy T, et al. Patient-controlled analgesia following caesarean section under general anaesthesia: a comparison of fentanyl with morphine. Can J Anaesth. Jan. 1995;42(1):41-5. X-9. [pmid: 7889583].
2496 Howorka K, Pumprla J, Gabriel M, et al. Normalization of pregnancy outcome in pregestational diabetes through functional insulin treatment and modular out-patient education adapted for pregnancy. Diabet Med. Dec. 2001;18(12):965-72. X-1. [pmid: 11903395].
2497 Hoy J, Venn A, Halliday J, et al. Perinatal and obstetric outcomes of donor insemination using cryopreserved semen in Victoria, Australia. Hum Reprod. Jul. 1999;14(7):1760-4. X-1. [pmid: 10402384].
2498 Hsu CD, Meaddough E, Basherra H, et al. Increased apoptosis in human amnion is associated with labor at term. Am J Reprod Immunol. May. 2000;43(5):255-8. X-1. [pmid: 10872603].
2499 Hsu HW, Cheng YJ, Chen LK, et al. Differential analgesic effect of tenoxicam on the wound pain and uterine cramping pain after cesarean section. Clin J Pain. Jan-Feb. 2003;19(1):55-8. X-9. [pmid: 12514457].
2500 Hsu KH, Liao PJ, Hwang CJ. Factors affecting Taiwanese women's choice of Cesarean section. Soc Sci Med. Jan. 2008;66(1):201-9. X-1. [pmid: 17869398].
2501 Huam SH, Lim JM, Raman S. Single-dose antibiotic prophylaxis in women undergoing elective caesarean section. Med J Malaysia. Mar. 1997;52(1):3-7. X-9. [pmid: 10968046].
2502 Huang CJ, Fan YC, Tsai PS. Differential impacts of modes of anaesthesia on the risk of stroke among preeclamptic women who undergo Caesarean delivery: a population-based study. Br J Anaesth. Dec. 2010;105(6):818-26. X-1. [pmid: 20926478].
2503 Huang YC, Tsai SK, Huang CH, et al. Intravenous tenoxicam reduces uterine cramps after Cesarean delivery. Can J Anaesth. Apr. 2002;49(4):384-7. X-9. [pmid: 11927478].
2504 Huddle K, England M, Nagar A. Outcome of pregnancy in diabetic women in Soweto, South Africa 1983-1992. Diabet Med. Apr. 1993;10(3):290-4. X-1. [pmid: 8485965].
2505 Huddle KR. Audit of the outcome of pregnancy in diabetic women in Soweto, South Africa, 1992 - 2002. S Afr Med J. Oct. 2005;95(10):789-94. X-1. [pmid: 16341334].
2506 Huddle KR, Myer IG, Diamond TH, et al. Diabetes in pregnancy. The use of home blood glucose monitoring and intensive monitoring to ensure favourable perinatal outcome. S Afr Med J. Apr. 4. 1987;71(7):429-31. X-1. [pmid: 3551132].
2507 Hudic I, Fatusic Z, Sinanovic O, et al. Etiological risk factors for brachial plexus palsy. J Matern Fetal Neonatal Med. Oct. 2006;19(10):655-61. X-1. [pmid: 17118741].
2508 Hueston WJ. Site-to-site variation in the factors affecting cesarean section rates. Arch Fam Med. Apr. 1995;4(4):346-51. X-1. [pmid: 7711922].
2509 Hueston WJ, Applegate JA, Mansfield CJ, et al. Practice variations between family physicians and obstetricians in the management of low-risk pregnancies. J Fam Pract. Apr. 1995;40(4):345-51. X-1. [pmid: 7699347].
2510 Hueston WJ, Lewis-Stevenson S. Provider distribution and variations in statewide cesarean section rates. J Community Health. Feb. 2001;26(1):1-10. X-1. [pmid: 11297186].
2511 Hueston WJ, McClaflin RR, Claire E. Variations in cesarean delivery for fetal distress. J Fam Pract. Nov. 1996;43(5):461-7. X-1. [pmid: 8917145].
2512 Hueston WJ, Sutton A. Managed care market share and cesarean section rates in the United States: is there a link?. Am J Manag Care. Nov. 2000;6(11):1202-8. X-1. [pmid: 11185845].
2513 Huffnagle HJ, Norris MC, Leighton BL, et al. Ilioinguinal iliohypogastric nerve blocks--before or after cesarean delivery under spinal anesthesia?. Anesth Analg. Jan. 1996;82(1):8-12. X-9. [pmid: 8712430].
2514 Hug I, Chattopadhyay C, Mitra GR, et al. Maternal expectations and birth-related experiences: a survey of pregnant women of mixed parity from Calcutta, India. Int J Obstet Anesth. Apr. 2008;17(2):112-7. X-1. [pmid: 18295472].
2515 Hughes JC, Harmer M. A new gas jet method for the assessment of sensory block after spinal anaesthesia. Anaesthesia. Feb. 1998;53(2):197-200. X-1. [pmid: 9534649].
2516 Hughey MJ. Routine ultrasound for detection and management of the small-for-gestational-age fetus. Obstet Gynecol. Jul. 1984;64(1):101-7. X-1. [pmid: 6738932].
2517 Hughey MJ, LaPata RE, McElin TW, et al. The effect of fetal monitoring on the incidence of cesarean section. Obstet Gynecol. May. 1977;49(5):513-8. X-1. [pmid: 850561].
2518 Hughey MJ, McElin TW, Young T. Maternal and fetal outcome of Lamaze-prepared patients. Obstet Gynecol. Jun. 1978;51(6):643-7. X-1. [pmid: 662240].
2519 Hui CK, Huang CH, Lin CJ, et al. A randomised double-blind controlled study evaluating the hypothermic effect of 150 microg morphine during spinal anaesthesia for Caesarean section. Anaesthesia. Jan. 2006;61(1):29-31. X-9. [pmid: 16409339].
2520 Huissoud C, Dupont C, Canoui-Poitrine F, et al. Decision-to-delivery interval for emergency caesareans in the Aurore perinatal network. Eur J Obstet Gynecol Reprod Biol. Apr. 2010;149(2):159-64. X-1. [pmid: 20079963].
2521 Hullfish KL, Fenner DE, Sorser SA, et al. Postpartum depression, urge urinary incontinence, and overactive bladder syndrome: is there an association?. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2007;18(10):1121-6. X-1. [pmid: 17308861].
2522 Hultman CM, Sparen P, Cnattingius S. Perinatal risk factors for infantile autism. Epidemiology. Jul. 2002;13(4):417-23. X-1. [pmid: 12094096].
2523 Hung S, Morrison DR, Whittington LA, et al. Prepartum work, job characteristics, and risk of cesarean delivery. Birth. Mar. 2002;29(1):10-7. X-1. [pmid: 11843785].
2524 Hung TH, Chen SF, Liou JD, et al. Bax, Bak and mitochondrial oxidants are involved in hypoxia-reoxygenation-induced apoptosis in human placenta. Placenta. Jul. 2008;29(7):565-83. X-1. [pmid: 18472157].
2525 Hunger C, Kulker R, Kitundu H, et al. Assessing unmet obstetric need in Mtwara Region, Tanzania. Trop Med Int Health. Oct. 2007;12(10):1239-47. X-1. [pmid: 17956507].
2526 Hunt CO, Naulty JS, Bader AM, et al. Perioperative analgesia with subarachnoid fentanyl-bupivacaine for cesarean delivery. Anesthesiology. Oct. 1989;71(4):535-40. X-9. [pmid: 2679237].
2527 Hunter DJ, Enkin MW, Sargeant EJ, et al. The outcome of prolonged labor as defined by partography and the use of oxytocin: a descriptive study. Am J Obstet Gynecol. Jan. 15. 1983;145(2):189-92. X-1. [pmid: 6849352].
2528 Hunter IW, Cato E, Ritchie JW. Induction of labor using high-dose or low-dose prostaglandin vaginal pessaries. Obstet Gynecol. Mar. 1984;63(3):418-20. X-4d. [pmid: 6366660].
2529 Huntoon M, Eisenach JC, Boese P. Epidural clonidine after cesarean section. Appropriate dose and effect of prior local anesthetic. Anesthesiology. Feb. 1992;76(2):187-93. X-9. [pmid: 1736694].
2530 Huovinen K, Lehtovirta P, Forss M, et al. Changes in placental intervillous blood flow measured by the 133xenon method during lumbar epidural block for elective caesarean section. Acta Anaesthesiol Scand. Dec. 1979;23(6):529-33. X-9. [pmid: 545989].
2531 Huria A, Gupta P, Kumar D, et al. Vitamin C and vitamin E supplementation in pregnant women at risk for pre eclampsia: a randomized controlled trial. Internet Journal of Health. 2010;10(2):10. X-1.
2532 Husain F, Busby C, Shaw S, et al. Use of anaesthetic rooms in obstetric anaesthesia; a postal survey of obstetric anaesthetists and departments in the United Kingdom. Int J Obstet Anesth. Jan. 2005;14(1):14-21. X-1. [pmid: 15627533].
2533 Husaini SW, Russell IF. Intrathecal diamorphine compared with morphine for postoperative analgesia after caesarean section under spinal anaesthesia. Br J Anaesth. Aug. 1998;81(2):135-9. X-9. [pmid: 9813510].
2534 Husemeyer RP, Davenport HT. Prophylaxis for Mendelson's syndrome before elective caesarean section. A comparison of cimetidine and magnesium trisilicate mixture regimens. Br J Obstet Gynaecol. Jul. 1980;87(7):565-70. X-9. [pmid: 7426509].
2535 Huskins WC, Ba-Thike K, Festin MR, et al. An international survey of practice variation in the use of antibiotic prophylaxis in cesarean section. Int J Gynaecol Obstet. May. 2001;73(2):141-5. X-1. [pmid: 11336733].
2536 Hutchings G, Gevaert T, Deprest J, et al. The effect of extracellular adenosine triphosphate on the spontaneous contractility of human myometrial strips. Eur J Obstet Gynecol Reprod Biol. Apr. 2009;143(2):79-83. X-1. [pmid: 19185969].
2537 Hutchins CJ. Delivery of the growth-retarded infant. Obstet Gynecol. Dec. 1980;56(6):683-6. X-1. [pmid: 7443109].
2538 Hutchon DJ, Geirsson R, Patel NB. A double-blind controlled trial of PGE2 gel in cervical ripening. Int J Gynaecol Obstet. May-Jun. 1980;17(6):604-7. X-4d. [pmid: 6106583].
2539 Hutton EK, Hannah ME, Barrett J. Use of external cephalic version for breech pregnancy and mode of delivery for breech and twin pregnancy: a survey of Canadian practitioners. J Obstet Gynaecol Can. Oct. 2002;24(10):804-10. X-1. [pmid: 12399807].
2540 Hutton EK, Hannah ME, Ross SJ, et al. The Early External Cephalic Version (ECV) 2 Trial: an international multicentre randomised controlled trial of timing of ECV for breech pregnancies. BJOG. Apr. 2011;118(5):564-77. X-4c. [pmid: 21291506].
2541 Hutton EK, Kaufman K, Hodnett E, et al. External cephalic version beginning at 34 weeks' gestation versus 37 weeks' gestation: a randomized multicenter trial. Am J Obstet Gynecol. Jul. 2003;189(1):245-54. X-4c, X-4e. [pmid: 12861170].
2542 Hvidman L, Foldspang A, Mommsen S, et al. Postpartum urinary incontinence. Acta Obstet Gynecol Scand. Jun. 2003;82(6):556-63. X-1. [pmid: 12780427].
2543 Hwang JJ, Ho ST, Wang JJ, et al. The incidence of post dural puncture headache in Taiwanese patients undergoing cesarean section. Acta Anaesthesiol Sin. Mar. 1997;35(1):1-6. X-1. [pmid: 9212474].
2544 Hwang JL, Lin YH, Tsai YL. In vitro maturation and fertilization of immature oocytes: a comparative study of fertilization techniques. J Assist Reprod Genet. Jan. 2000;17(1):39-43. X-1, X-3, X-4b. [pmid: 10754782].
2545 Hwu YM, Chen CP, Chen HS, et al. Parallel vertical compression sutures: a technique to control bleeding from placenta praevia or accreta during caesarean section. BJOG. Oct. 2005;112(10):1420-3. X-1. [pmid: 16167948].
2546 Hyams R. Who gets to choose? Responses to the foetal/maternal conflict. E Law. Dec. 1995;2(3):E7. X-1, X-2. [pmid: 16969923].
2547 Hye MA, Masud KM, Banik D, et al. Intrathecal neostigmine for postoperatrive analgesia in caesarean section. Mymensingh Med J. Oct. 2010;19(4):586-93. X-9. [pmid: 20956904].
2548 Ibara S, Tokunaga M, Ikenoue T, et al. Histologic observation of the ductus arteriosus in premature infants with intrauterine growth retardation. J Perinatol. Sep-Oct. 1994;14(5):411-6. X-1. [pmid: 7830159].
2549 Idogun ES, Imarengiaye CO, Momoh SM. Extracellular calcium and magnesium in preeclampsia and eclampsia. Afr J Reprod Health. Aug. 2007;11(2):89-94. X-1. [pmid: 20690291].
2550 Idris I, Srinivasan R, Simm A, et al. Maternal hypothyroidism in early and late gestation: effects on neonatal and obstetric outcome. Clin Endocrinol (Oxf). Nov. 2005;63(5):560-5. X-1. [pmid: 16268809].
2551 Idris N, Wong SF, Thomae M, et al. Influence of polyhydramnios on perinatal outcome in pregestational diabetic pregnancies. Ultrasound Obstet Gynecol. Sep. 2010;36(3):338-43. X-1. [pmid: 20503236].
2552 Iffy L, Bilenki I, Apuzzio JJ, et al. The role of obstetric factors in perinatal mortality trends. Int J Gynaecol Obstet. Apr. 1986;24(2):85-95. X-1. [pmid: 2874086].
2553 Ifnan F, Jameel MB. Ripening of cervix for induction of labour by hydrostatic sweeping of membrane versus Foley's catheter ballooning alone. J Coll Physicians Surg Pak. May. 2006;16(5):347-50. X-4d, X-5. [pmid: 16756780].
2554 Iglesias S, Burn R, Saunders LD. Reducing the cesarean section rate in a rural community hospital. CMAJ. Dec. 1. 1991;145(11):1459-64. [pmid: 1959105].
2555 Igwegbe AO, Ilika AL. Knowledge and perceptions of HIV/AIDS and mother to child transmission among antenatal mothers at Nnamdi Azikiwe University Teaching hospital, Nnewi. Niger J Clin Pract. Dec. 2005;8(2):97-101. X-1. [pmid: 16477862].
2556 Iijima S, Arai H, Ozawa Y, et al. Clinical patterns in extremely preterm (22 to 24 weeks of gestation) infants in relation to survival time and prognosis. Am J Perinatol. Jun. 2009;26(6):399-406. X-1. [pmid: 19263334].
2557 Ikeako LC, Nwajiaku L. Grandmultiparity: experience at Awka, Nigeria. Niger J Clin Pract. Sep. 2010;13(3):301-5. X-1. [pmid: 20857790].
2558 Ikemoto LC. Furthering the inquiry: race, class, and culture in the forced medical treatment of pregnant women. Tenn Law Rev. Spring. 1992;59(3):487-517. X-1, X-2. [pmid: 11652636].
2559 Ikenoue T, Iito J, Matsuda Y, et al. Effects of ranitidine on maternal gastric juice and neonates when administered prior to caesarean section. Aliment Pharmacol Ther. Jun. 1991;5(3):315-8. X-1. [pmid: 1888830].
2560 Illia R, Solana C, Oliveri P, et al. Evidence of fetal pulmonary aspiration of intra-amniotic administered surfactant in animal experiment. J Perinat Med. 2004;32(4):354-8. X-1. [pmid: 15346823].
2561 Imajima T, Shono T, Kai H, et al. The biological effect of phthalate esters on transabdominal migration of the testis in fetal rats in comparison with the antiandrogen flutamide. Pediatr Surg Int. Mar. 2001;17(2-3):164-6. X-1. [pmid: 11315278].
2562 Imarengiaye CO, Ande AB. Risk factors for blood transfusion during c-section in a tertiary hospital in Nigeria. Med Sci Monit. Jun. 2006;12(6):CR269-72. X-1. [pmid: 16733486].
2563 Imarengiaye CO, Edomwonyi NP. Evaluation of 25-gauge Quincke and 24-gauge Gertie Marx needles for spinal anaesthesia for caesarean section. East Afr Med J. Jul. 2002;79(7):379-81. X-9. [pmid: 12638834].
2564 Imig JR, Perkins RP. Extraperitoneal cesarean section: a new need for old skills. A preliminary report. Am J Obstet Gynecol. May. 1. 1976;125(1):51-4. X-9. [pmid: 1275013].
2565 Impey L, MacQuillan K, Robson M. Epidural analgesia need not increase operative delivery rates. Am J Obstet Gynecol. Feb. 2000;182(2):358-63. X-1. [pmid: 10694337].
2566 Impey L, Pandit M. Tocolysis for repeat external cephalic version in breech presentation at term: a randomised, double-blinded, placebo-controlled trial. BJOG. May. 2005;112(5):627-31. X-4c. [pmid: 15842288].
2567 Impey L, Reynolds M, MacQuillan K, et al. Admission cardiotocography: a randomised controlled trial. Lancet. Feb. 8. 2003;361(9356):465-70. X-4e, X-5. [pmid: 12583945].
2568 Inglis A, Daniel M, McGrady E. Maternal position during induction of spinal anaesthesia for caesarean section. A comparison of right lateral and sitting positions. Anaesthesia. Apr. 1995;50(4):363-5. X-9. [pmid: 7747861].
2569 Inthawiwat S, Rattanachaiyanont M, Leerasiri P, et al. Increasing trend of illicit drug abuse in Thai parturient at Siriraj Hospital. J Med Assoc Thai. Oct. 2002;85(10):1081-8. X-1. [pmid: 12501899].
2570 Ioscovich A, Elstein Y, Halpern S, et al. Anesthesia for obstetric patients with Gaucher disease: survey and review. Int J Obstet Anesth. Oct. 2004;13(4):244-50. X-1. [pmid: 15477054].
2571 Irion O, Boulvain M. Induction of labour for suspected fetal macrosomia. Cochrane Database of Systematic Reviews. 1998;(2). X-1, X-2.
2572 Irion O, Luzuy F, Beguin F. Nonclosure of the visceral and parietal peritoneum at caesarean section: a randomised controlled trial. Br J Obstet Gynaecol. Jul. 1996;103(7):690-4. X-9. [pmid: 8688397].
2573 Irion O, Pedrazzoli J, Mermillod B. A randomized trial comparing vaginal and cervical prostaglandin gel for cervical ripening and labor induction. Obstet Gynecol. Jan. 1998;91(1):65-71. X-4e. [pmid: 9464723].
2574 Irwin S, Jordan B. Knowledge, practice, and power: court-ordered cesarean sections. Med Anthropol Q. Sep. 1987;1(3):319-34. X-1, X-2, X-9. [pmid: 11659066].
2575 Isaacs JD, Magann EF, Martin RW, et al. Obstetric challenges of massive obesity complicating pregnancy. J Perinatol. Jan-Feb. 1994;14(1):10-4. X-1. [pmid: 8169671].
2576 Ishii S, Endo M. Blunt-edged, notched scalpel for cesarean incision. Obstet Gynecol. Sep. 1999;94(3):469-70. X-1. [pmid: 10472879].
2577 Islam MT, Hossain MM, Islam MA, et al. Improvement of coverage and utilization of EmOC services in southwestern Bangladesh. Int J Gynaecol Obstet. Dec. 2005;91(3):298-305. discussion 283-4. X-1. [pmid: 16226760].
2578 Ismail MA, Nelson KE, Larson P, et al. Selective effect of cefoxitin prophylaxis on post-cesarean-section microbial flora. J Reprod Med. Feb. 1990;35(2):168-74. X-9. [pmid: 2406439].
2579 Ithnin F, Lim Y, Sia AT, et al. Combined spinal epidural causes higher level of block than equivalent single-shot spinal anesthesia in elective cesarean patients. Anesth Analg. Feb. 2006;102(2):577-80. X-9. [pmid: 16428564].
2580 Itoo BA, Al-Hawsawi ZM, Khan AH. Hypoxic ischemic encephalopathy. Incidence and risk factors in North Western Saudi Arabia. Saudi Med J. Feb. 2003;24(2):147-53. X-1. [pmid: 12682677].
2581 Itskovitz J, Paldi E, Katz M. The effect of prophylactic antibiotics on febrile morbidity following cesarean section. Obstet Gynecol. Feb. 1979;53(2):162-5. X-9. [pmid: 418968].
2582 Ittichaikulthol W, Sriswasdi S, Prachanpanich N, et al. Bispectral index in assessment of 3% and 4.5% desflurane in 50% N2O for caesarean section. J Med Assoc Thai. Aug. 2007;90(8):1546-50. X-9. [pmid: 17926983].
2583 Iwama H, Ohmizo H, Furuta S, et al. Spinal anesthesia hypotension in elective cesarean section in parturients wearing extra-strong compression stockings. Arch Gynecol Obstet. Dec. 2002;267(2):85-9. X-1. [pmid: 12439553].
2584 Iwata A, Murayama Y, Itakura A, et al. Limitations of internal iliac artery ligation for the reduction of intraoperative hemorrhage during cesarean hysterectomy in cases of placenta previa accreta. J Obstet Gynaecol Res. Apr. 2010;36(2):254-9. X-1. [pmid: 20492374].
2585 Jackson DJ, Lang JM, Ecker J, et al. Impact of collaborative management and early admission in labor on method of delivery. J Obstet Gynecol Neonatal Nurs. Mar-Apr. 2003;32(2):147-57. discussion 158-60. X-1.
2586 Jackson GM, Sharp HT, Varner MW. Cervical ripening before induction of labor: a randomized trial of prostaglandin E2 gel versus low-dose oxytocin. Am J Obstet Gynecol. Oct. 1994;171(4):1092-6. X-4d. [pmid: 7943077].
2587 Jackson KW Jr., Allbert JR, Schemmer GK, et al. A randomized controlled trial comparing oxytocin administration before and after placental delivery in the prevention of postpartum hemorrhage. Am J Obstet Gynecol. Oct. 2001;185(4):873-7. X-3, X-4a, X-4e. [pmid: 11641669].
2588 Jackson R, Reid JA, Thorburn J. Volume preloading is not essential to prevent spinal-induced hypotension at caesarean section. Br J Anaesth. Sep. 1995;75(3):262-5. X-9. [pmid: 7547039].
2589 Jacob J, Pfenninger J. Cesarean deliveries: when is a pediatrician necessary?. Obstet Gynecol. Feb. 1997;89(2):217-20. X-1. [pmid: 9015023].
2590 Jacobsen AF, Skjeldestad FE, Sandset PM. Ante- and postnatal risk factors of venous thrombosis: a hospital-based case-control study. J Thromb Haemost. Jun. 2008;6(6):905-12. X-1. [pmid: 18363820].
2591 Jacobsen AF, Skjeldestad FE, Sandset PM. Incidence and risk patterns of venous thromboembolism in pregnancy and puerperium--a register-based case-control study. Am J Obstet Gynecol. Feb. 2008;198(2):233 e1-7. X-1. [pmid: 17997389].
2592 Jacobsen BS, Munro BH, Brooten DA. Comparison of original and revised scoring systems for the Multiple Affect Adjective Check List. Nurs Res. Jan-Feb. 1996;45(1):57-60. X-1. [pmid: 8570425].
2593 Jacobson GF, Ramos GA, Ching JY, et al. Comparison of glyburide and insulin for the management of gestational diabetes in a large managed care organization. Am J Obstet Gynecol. Jul. 2005;193(1):118-24. X-1. [pmid: 16021069].
2594 Jacobson JD, Cousins L. A population-based study of maternal and perinatal outcome in patients with gestational diabetes. Am J Obstet Gynecol. Oct. 1989;161(4):981-6. X-1. [pmid: 2801849].
2595 Jacquemyn Y, Ahankour F, Martens G. Flemish obstetricians' personal preference regarding mode of delivery and attitude towards caesarean section on demand. Eur J Obstet Gynecol Reprod Biol. Dec. 10. 2003;111(2):164-6. X-1. [pmid: 14597245].
2596 Jaffe R, Altaras M, Cohen I, et al. Single-dose mezlocillin prophylaxis in emergency cesarean section. Clin Ther. 1985;7(4):507-11. X-9. [pmid: 4016830].
2597 Jaffe R, Altaras M, Loebel R, et al. Single-versus multiple-dose mezlocillin prophylaxis in emergency cesarean section. Chemotherapy. 1986;32(2):173-7. X-9. [pmid: 3698726].
2598 Jaffe R, Loebel R, Altaras M, et al. Perioperative mezlocillin prophylaxis in cesarean section. Clin Ther. 1984;6(4):467-74. X-9. [pmid: 6380723].
2599 Jagani N, Schulman H, Fleischer A, et al. Role of prostaglandin-induced cervical changes in labor induction. Obstet Gynecol. Feb. 1984;63(2):225-9. X-4d. [pmid: 6582419].
2600 Jahromi BN, Daneshvar A. Pregnancy outcome of parturients below 16 years of age. Saudi Med J. Sep. 2005;26(9):1417-9. X-1. [pmid: 16155660].
2601 Jahromi BN, Husseini Z. Pregnancy outcome at maternal age 40 and older. Taiwan J Obstet Gynecol. Sep. 2008;47(3):318-21. X-1. [pmid: 18935996].
2602 Jain K, Grover VK, Mahajan R, et al. Effect of varying doses of fentanyl with low dose spinal bupivacaine for caesarean delivery in patients with pregnancy-induced hypertension. Int J Obstet Anesth. Oct. 2004;13(4):215-20. X-9. [pmid: 15477049].
2603 Jain L, Ferre C, Vidyasagar D. Cesarean delivery of the breech very-low-birth-weight infant: does it make a difference?. J Matern Fetal Med. Jan-Feb. 1998;7(1):28-31. X-1. [pmid: 9502667].
2604 Jain S, Arya VK, Gopalan S, et al. Analgesic efficacy of intramuscular opioids versus epidural analgesia in labor. Int J Gynaecol Obstet. Oct. 2003;83(1):19-27. X-4e. [pmid: 14511868].
2605 Jain S, Mulligama C, Tagwira V, et al. Labour outcome of women with successful external cephalic version: a prospective study. J Obstet Gynaecol. Jan. 2010;30(1):13-6. X-1. [pmid: 20121496].
2606 Jakobi P, Weiner Z, Solt I, et al. Oral analgesia in the treatment of post-cesarean pain. Eur J Obstet Gynecol Reprod Biol. Nov. 2000;93(1):61-4. X-1. [pmid: 11000506].
2607 Jakobi P, Weissman A, Sigler E, et al. Post-cesarean section febrile morbidity. Antibiotic prophylaxis in low-risk patients. J Reprod Med. Sep. 1994;39(9):707-10. X-9. [pmid: 7807484].
2608 Jakobi P, Weissman A, Zimmer EZ, et al. Single-dose cefazolin prophylaxis for cesarean section. Am J Obstet Gynecol. May. 1988;158(5):1049-52. X-9. [pmid: 3130756].
2609 Jamal A, Choobak N, Tabassomi F. Intrapartum maternal glucose infusion and fetal acid-base status. Int J Gynaecol Obstet. Jun. 2007;97(3):187-9. X-4e. [pmid: 17368645].
2610 Jamal A, Kalantari R. High and low dose oxytocin in augmentation of labor. Int J Gynaecol Obstet. Oct. 2004;87(1):6-8. X-4d, X-4e, X-5. [pmid: 15464768].
2611 James C, George SS, Gaunekar N, et al. Management of prolonged pregnancy: a randomized trial of induction of labour and antepartum foetal monitoring. Natl Med J India. Sep-Oct. 2001;14(5):270-3. X-4e, X-5. [pmid: 11767219].
2612 James KS, McGrady E, Patrick A. Combined spinal-extradural anaesthesia for preterm and term caesarean section: is there a difference in local anaesthetic requirements?. Br J Anaesth. May. 1997;78(5):498-501. X-1. [pmid: 9175961].
2613 James KS, Stott SM, McGrady EM, et al. Spinal anaesthesia for Caesarean section: effect of Sprotte needle orientation. Br J Anaesth. Aug. 1996;77(2):150-2. X-9. [pmid: 8881615].
2614 James M, Hunt K, Burr R, et al. A decision analytical cost analysis of offering ECV in a UK district general hospital. BMC Health Serv Res. 2001;1(1):6. X-1. [pmid: 11472641].
2615 James MF. Use of magnesium sulphate in the anaesthetic management of phaeochromocytoma: a review of 17 anaesthetics. Br J Anaesth. Jun. 1989;62(6):616-23. X-1. [pmid: 2751917].
2616 James MF, Cork RC, Dennett JE. Succinylcholine pretreatment with magnesium sulfate. Anesth Analg. Apr. 1986;65(4):373-6. X-3, X-4e, X-5. [pmid: 3513667].
2617 Jamisse L, Songane F, Libombo A, et al. Reducing maternal mortality in Mozambique: challenges, failures, successes and lessons learned. Int J Gynaecol Obstet. May. 2004;85(2):203-12. X-1. [pmid: 15099795].
2618 Jan GS, Tong WN, Chan AM, et al. Recovery from mivacurium block with or without anticholinesterase following continuous infusion in obstetric patients. Anaesth Intensive Care. Oct. 1996;24(5):585-9. X-3, X-4e, X-5. [pmid: 8909671].
2619 Jana N, Vasishta K, Saha SC, et al. Effect of bronchial asthma on the course of pregnancy, labour and perinatal outcome. J Obstet Gynaecol (Tokyo 1995). Jun. 1995;21(3):227-32. X-1. [pmid: 8590358].
2620 Janakiraman V, Ecker J, Kaimal AJ. Comparing the second stage in induced and spontaneous labor. Obstet Gynecol. Sep. 2010;116(3):606-11. X-1. [pmid: 20733442].
2621 Jang HC, Cho NH, Min YK, et al. Increased macrosomia and perinatal morbidity independent of maternal obesity and advanced age in Korean women with GDM. Diabetes Care. Oct. 1997;20(10):1582-8. X-1. [pmid: 9314639].
2622 Jannet D, Carbonne B, Sebban E, et al. Nicardipine versus metoprolol in the treatment of hypertension during pregnancy: a randomized comparative trial. Obstet Gynecol. Sep. 1994;84(3):354-9. X-4e, X-5. [pmid: 8058230].
2623 Janowitz B, Higgins JE, Clopton DC, et al. Access to postpartum sterilization in southeast Brazil. Med Care. May. 1982;20(5):526-34. X-1. [pmid: 7098591].
2624 Janssen PA, Ryan EM, Etches DJ, et al. Outcomes of planned hospital birth attended by midwives compared with physicians in British Columbia. Birth. Jun. 2007;34(2):140-7. X-1. [pmid: 17542818].
2625 Jansson T, Scholtbach V, Powell TL. Placental transport of leucine and lysine is reduced in intrauterine growth restriction. Pediatr Res. Oct. 1998;44(4):532-7. X-1. [pmid: 9773842].
2626 Jaques AM, Amor DJ, Baker HW, et al. Adverse obstetric and perinatal outcomes in subfertile women conceiving without assisted reproductive technologies. Fertil Steril. Dec. 2010;94(7):2674-9. X-1. [pmid: 20381039].
2627 Jardim O, Sobral E, Branco EC, et al. Delivery in diabetic pregnancy. Ann Ist Super Sanita. 1997;33(3):329-32. X-1. [pmid: 9542257].
2628 Jarvenpaa J, Vuoristo JT, Santaniemi M, et al. Adiponectin induced placental cell apoptosis could be mediated via the ADIPOR1-receptor in pre-eclampsia with IUGR. J Perinat Med. 2009;37(3):257-62. X-1. [pmid: 19196212].
2629 Jauniaux E, Burton GJ. Villous histomorphometry and placental bed biopsy investigation in Type I diabetic pregnancies. Placenta. Apr-May. 2006;27(4-5):468-74. X-1. [pmid: 16009423].
2630 Jauniaux E, Moscoso JG, Vanesse M, et al. Perfusion fixation for placental morphologic investigation. Hum Pathol. May. 1991;22(5):442-9. X-1. [pmid: 2032694].
2631 Jauniaux E, Ramsay B, Peellaerts C, et al. Perinatal features of pregnancies complicated by nuchal cord. Am J Perinatol. Jul. 1995;12(4):255-8. X-1. [pmid: 7575829].
2632 Javed I, Bhutta S, Shoaib T. Role of partogram in preventing prolonged labour. J Pak Med Assoc. Aug. 2007;57(8):408-11. X-1, X-4, X-5. [pmid: 17902525].
2633 Jeffcoate TN, Miller J, Roos RF, et al. Puerperal thromboembolism in relation to the inhibition of lactation by oestrogen therapy. Br Med J. Oct. 5. 1968;4(5622):19-25. X-1. [pmid: 5677208].
2634 Jehan I, McClure EM, Salat S, et al. Stillbirths in an urban community in Pakistan. Am J Obstet Gynecol. Sep. 2007;197(3):257 e1-8. X-1. [pmid: 17826410].
2635 Jelsema RD, Wittingen JA, Vander Kolk KJ. Continuous, nonlocking, single-layer repair of the low transverse uterine incision. J Reprod Med. May. 1993;38(5):393-6. X-1. [pmid: 8320678].
2636 Jenkins JG, Khan MM. Anaesthesia for Caesarean section: a survey in a UK region from 1992 to 2002. Anaesthesia. Nov. 2003;58(11):1114-8. X-1. [pmid: 14616600].
2637 Jenkins TM, Mackey SF, Benzoni EM, et al. Non-obstetric surgery during gestation: risk factors for lower birthweight. Aust N Z J Obstet Gynaecol. Feb. 2003;43(1):27-31. X-1. [pmid: 12755343].
2638 Jensen DM, Damm P, Moelsted-Pedersen L, et al. Outcomes in type 1 diabetic pregnancies: a nationwide, population-based study. Diabetes Care. Dec. 2004;27(12):2819-23. X-1. [pmid: 15562191].
2639 Jensen DM, Korsholm L, Ovesen P, et al. Adverse pregnancy outcome in women with mild glucose intolerance: is there a clinically meaningful threshold value for glucose?. Acta Obstet Gynecol Scand. 2008;87(1):59-62. X-1. [pmid: 18158628].
2640 Jensen DM, Sorensen B, Feilberg-Jorgensen N, et al. Maternal and perinatal outcomes in 143 Danish women with gestational diabetes mellitus and 143 controls with a similar risk profile. Diabet Med. Apr. 2000;17(4):281-6. X-1. [pmid: 10821294].
2641 Jensen K. Evidence supports the obvious. Midwifery Today Int Midwife. Autumn. 2004;(71):23. X-1, X-2, X-3, X-4, X-5. [pmid: 15536930].
2642 Jeon Y, Hwang J, Kang J, et al. Effects of epidural naloxone on pruritus induced by epidural morphine: a randomized controlled trial. Int J Obstet Anesth. Jan. 2005;14(1):22-5. X-3, X-4b, X-4e. [pmid: 15627534].
2643 Jerbi M, Hidar S, Zardi H, et al. Previous cesarean scar exploration following vaginal delivery and hemorrhagic morbidity. Int J Gynaecol Obstet. Feb. 2006;92(2):135-6. X-4b, X-4e. [pmid: 16378610].
2644 Jervell J, Moe N, Skjaeraasen J, et al. Diabetes mellitus and pregnancy--management and results at Rikshospitalet, Oslo, 1970-1977. Diabetologia. Mar. 1979;16(3):151-5. X-1. [pmid: 428684].
2645 Jiang CJ, Liu CC, Wu TJ, et al. Mini-dose intrathecal morphine for post-cesarean section analgesia. Ma Zui Xue Za Zhi. Dec. 1991;29(4):683-9. X-9. [pmid: 1800872].
2646 Jimenez E, Marin ML, Martin R, et al. Is meconium from healthy newborns actually sterile?. Res Microbiol. Apr. 2008;159(3):187-93. X-1. [pmid: 18281199].
2647 Jimenez Torres M, Campoy Folgoso C, Canabate Reche F, et al. Organochlorine pesticides in serum and adipose tissue of pregnant women in Southern Spain giving birth by cesarean section. Sci Total Environ. Dec. 15. 2006;372(1):32-8. X-9. [pmid: 16904732].
2648 Jin Z, Guan X, Gao H, et al. The change in sex hormone binding globulin and the influence by gestational diabetes mellitus in fetal period. Gynecol Endocrinol. Oct. 2009;25(10):647-52. X-1. [pmid: 19557594].
2649 Jingheng H, Yindi X, Yongxin J, et al. Evaluation of a health education programme in China to increase breast-feeding rates. Health Promotion International. 1994;9(2):95-98. X-1.
2650 Jirecek S, Tringler B, Knofler M, et al. Redistribution of corticotropin-releasing hormone receptor R2 using fluorescence immunohistochemistry in fetal membranes of women delivering preterm or at term. Wien Klin Wochenschr. Dec. 30. 2002;114(23-24):1008-12. X-1, X-3, X-4b, X-4e, X-5. [pmid: 12635470].
2651 Jirsova S, Mardesic T, Muller P, et al. Multi-fetal pregnancy reduction does not influence perinatal results in twin pregnancies. Twin Res. Dec. 2001;4(6):422-5. X-1. [pmid: 11780932].
2652 Jivraj S, Anstie B, Cheong YC, et al. Obstetric and neonatal outcome in women with a history of recurrent miscarriage: a cohort study. Hum Reprod. Jan. 2001;16(1):102-106. X-1. [pmid: 11139545].
2653 Jivraj S, Nazzal Z, Davies P, et al. Obstetric outcome of teenage pregnancies from 2002 to 2008: the Sheffield experience. J Obstet Gynaecol. Apr. 2010;30(3):253-6. X-1. [pmid: 20373925].
2654 Johannesen P, Pedersen EB, Rasmussen AB. Arginine vasopressin in amniotic fluid, arterial and venous cord plasma and maternal venous plasma. Gynecol Obstet Invest. 1985;19(4):192-5. X-1. [pmid: 4029752].
2655 Johanson RB, El-Timini S, Rigby C, et al. Caesarean section by choice could fulfil the inverse care law. Eur J Obstet Gynecol Reprod Biol. Jul. 2001;97(1):20-2. X-1, X-2. [pmid: 11435002].
2656 Johansson M, Radestad I, Rubertsson C, et al. Few fathers-to-be prefer caesarean section for the birth of their baby. BJOG. May. 2010;117(6):761-4. X-1. [pmid: 20175875].
2657 Johns K, Olynik C, Mase R, et al. Gestational diabetes mellitus outcome in 394 patients. J Obstet Gynaecol Can. Feb. 2006;28(2):122-7. X-1. [pmid: 16643713].
2658 Johnsen D. A new threat to pregnant women's autonomy. Hastings Cent Rep. Aug-Sep. 1987;17(4):33-40. X-2. [pmid: 3667248].
2659 Johnson A, Young D, Reilly J. Caesarean section surgical site infection surveillance. J Hosp Infect. Sep. 2006;64(1):30-5. X-1. [pmid: 16822582].
2660 Johnson C, Oriol N, Feinstein D, et al. Onset of action between bupivacaine 0.5% and bupivacaine 0.5% plus fentanyl 75 mcg. J Clin Anesth. 1989;1(6):440-3. X-9. [pmid: 2696506].
2661 Johnson C, Ransil BJ, Oriol N. Comparison of onset time between 0.5% bupivacaine and 3% 2-chloroprocaine with and without 75 micrograms fentanyl. Reg Anesth. Jul-Aug. 1991;16(4):228-31. X-1, X-2. [pmid: 1911500].
2662 Johnson D, Jin Y. Low-volume obstetrics. Characteristics of family physicians' practices in Alberta. Can Fam Physician. Jul. 2002;48:1208-15. X-1. [pmid: 12166011].
2663 Johnson EB, Reed SD, Hitti J, et al. Increased risk of adverse pregnancy outcome among Somali immigrants in Washington state. Am J Obstet Gynecol. Aug. 2005;193(2):475-82. X-1. [pmid: 16098873].
2664 Johnson JM. Minnesota's “crack baby” law: weapon of war or link in a chain?. Law Inequal. Jul. 1990;8(3):485-531. X-1. [pmid: 11651347].
2665 Johnson JM, Lange IR, Harman CR, et al. Biophysical profile scoring in the management of the diabetic pregnancy. Obstet Gynecol. Dec. 1988;72(6):841-6. X-1. [pmid: 3054650].
2666 Johnson KC, Daviss BA. Outcomes of planned home births with certified professional midwives: large prospective study in North America. BMJ. Jun. 18. 2005;330(7505):1416. X-1. [pmid: 15961814].
2667 Johnson N, Ansell D. Variation in caesarean and instrumental delivery rates in New Zealand hospitals. Aust N Z J Obstet Gynaecol. Feb. 1995;35(1):6-11. X-1. [pmid: 7772003].
2668 Johnson N, Lilford R, Guthrie K, et al. Randomised trial comparing a policy of early with selective amniotomy in uncomplicated labour at term. Br J Obstet Gynaecol. Mar. 1997;104(3):340-6. X-5. [pmid: 9091013].
2669 Johnson RF, Mitchell CM, Giles WB, et al. The in vivo control of prostaglandin H synthase-2 messenger ribonucleic acid expression in the human amnion at parturition. J Clin Endocrinol Metab. Jun. 2002;87(6):2816-23. X-1. [pmid: 12050256].
2670 Johnson RF, Mitchell CM, Giles WB, et al. The control of prostaglandin endoperoxide H-Synthase-2 expression in the human chorion laeve at term. J Soc Gynecol Investig. May. 2003;10(4):222-30. X-1.
2671 Johnson SA. Ethical dilemma: a patient refuses a life-saving cesarean. MCN Am J Matern Child Nurs. May-Jun. 1992;17(3):121-5. X-1, X-2. [pmid: 1625536].
2672 Johnson SR, Kolberg BH, Varner MW, et al. Maternal obesity and pregnancy. Surg Gynecol Obstet. May. 1987;164(5):431-7. X-1. [pmid: 3576419].
2673 Johnston JR, McCaughey W, Moore J, et al. Cimetidine as an oral antacid before elective Caesarean section. Anaesthesia. Jan. 1982;37(1):26-32. X-9. [pmid: 7081645].
2674 Johnston JR, Moore J, McCaughey W, et al. Use of cimetidine as an oral antacid in obstetric anesthesia. Anesth Analg. Aug. 1983;62(8):720-6. X-1. [pmid: 6346954].
2675 Johnstone FD, Prescott R, Hoskins P, et al. The effect of introduction of umbilical Doppler recordings to obstetric practice. Br J Obstet Gynaecol. Aug. 1993;100(8):733-41. X-4e. [pmid: 8399011].
2676 Johnstone FD, Steel JM, Haddad NG, et al. Doppler umbilical artery flow velocity waveforms in diabetic pregnancy. Br J Obstet Gynaecol. Feb. 1992;99(2):135-40. X-1. [pmid: 1554666].
2677 Jolly J, Walker J, Bhabra K. Subsequent obstetric performance related to primary mode of delivery. Br J Obstet Gynaecol. Mar. 1999;106(3):227-32. X-1, X-3, X-4e, X-5. [pmid: 10426641].
2678 Jones GD, Poston L. The role of endogenous nitric oxide synthesis in contractility of term or preterm human myometrium. Br J Obstet Gynaecol. Feb. 1997;104(2):241-5. X-1. [pmid: 9070147].
2679 Jones MM, Longmire S, Cotton DB, et al. Influence of crystalloid versus colloid infusion on peripartum colloid osmotic pressure changes. Obstet Gynecol. Nov. 1986;68(5):659-61. X-9. [pmid: 3763079].
2680 Jonsson ER, Elfaghi I, Rydhstrom H, et al. Modified Ritgen's maneuver for anal sphincter injury at delivery: a randomized controlled trial. Obstet Gynecol. Aug. 2008;112(2 Pt 1):212-7. X-4e, X-5. [pmid: 18669713].
2681 Jonsson M, Hanson U, Lidell C, et al. ST depression at caesarean section and the relation to oxytocin dose. A randomised controlled trial. BJOG. Jan. 2010;117(1):76-83. X-9. [pmid: 19781043].
2682 Jordan HS, Straus JH, Bailit MH. Reporting and using health plan performance information in Massachusetts. Jt Comm J Qual Improv. Apr. 1995;21(4):167-77. X-1. [pmid: 7780531].
2683 Jordan JM, Gaspar D. Family practice obstetrics in a teaching hospital. Does a tertiary care environment make a difference?. Can Fam Physician. Apr. 1995;41:610-5. X-1. [pmid: 7787491].
2684 Jordan S, Emery S, Bradshaw C, et al. The impact of intrapartum analgesia on infant feeding. BJOG. Jul. 2005;112(7):927-34. X-1. [pmid: 15957994].
2685 Joseph GF Jr., Stedman CM, Robichaux AG. Vaginal birth after cesarean section: the impact of patient resistance to a trial of labor. Am J Obstet Gynecol. Jun. 1991;164(6 Pt 1):1441-4. discussion 1444-7. X-1. [pmid: 2048590].
2686 Joseph KS, Dodds L, Allen AC, et al. Socioeconomic status and receipt of obstetric services in Canada. Obstet Gynecol. Mar. 2006;107(3):641-50. X-1. [pmid: 16507936].
2687 Joseph KS, Young DC, Dodds L, et al. Changes in maternal characteristics and obstetric practice and recent increases in primary cesarean delivery. Obstet Gynecol. Oct. 2003;102(4):791-800. X-1. [pmid: 14551010].
2688 Joshi VM, Otiv SR, Majumder R, et al. Internal iliac artery ligation for arresting postpartum haemorrhage. BJOG. Mar. 2007;114(3):356-61. X-1. [pmid: 17261120].
2689 Jouppila P, Kuikka J, Jouppila R, et al. Effect of induction of general anesthesia for cesarean section on intervillous blood flow. Acta Obstet Gynecol Scand. 1979;58(3):249-53. X-1. [pmid: 484216].
2690 Jouppila R, Jouppila P, Kuikka J, et al. Placental blood flow during caesarean section under lumbar extradural analgesia. Br J Anaesth. Mar. 1978;50(3):275-9. X-1. [pmid: 638000].
2691 Jouppila R, Kauppila A, Tuimala R, et al. Maternal, fetal and neonatal effects of beta-adrenergic stimulation in connection with cesarean section. Acta Obstet Gynecol Scand. 1980;59(6):489-93. X-1. [pmid: 6109424].
2692 Jovanovic L. The role of continuous glucose monitoring in gestational diabetes mellitus. Diabetes Technol Ther. Suppl 1. 2000;2:S67-71. X-1, X-2. [pmid: 11469635].
2693 Jovanovic-Peterson L, Bevier W, Peterson CM. The Santa Barbara County Health Care Services program: birth weight change concomitant with screening for and treatment of glucose-intolerance of pregnancy: a potential cost-effective intervention?. Am J Perinatol. Apr. 1997;14(4):221-8. X-4e, X-5. [pmid: 9259932].
2694 Ju H, Chadha Y, Donovan T, et al. Fetal macrosomia and pregnancy outcomes. Aust N Z J Obstet Gynaecol. Oct. 2009;49(5):504-9. X-1. [pmid: 19780734].
2695 Ju H, Rumbold AR, Willson KJ, et al. Borderline gestational diabetes mellitus and pregnancy outcomes. BMC Pregnancy Childbirth. 2008;8:31. X-4e, X-5. [pmid: 18664297].
2696 Juarez I, Silva-Gomez AB, Peralta F, et al. Anoxia at birth induced hyperresponsiveness to amphetamine and stress in postpubertal rats. Brain Res. Dec. 5. 2003;992(2):281-7. X-1. [pmid: 14625067].
2697 Judson KMM. The normal majority: a critical analysis of childbearing practice and the professional status and contribution of nurse midwives in California. PH.D. 1995:188. X-1.
2698 Jundt K, Scheer I, Schiessl B, et al. Incontinence, bladder neck mobility, and sphincter ruptures in primiparous women. Eur J Med Res. Jun. 28. 2010;15(6):246-52. X-1. [pmid: 20696633].
2699 Juneja MM, Ackerman WE 3rd, Bellinger K. Epidural morphine pruritus reduction with hydroxyzine in parturients. J Ky Med Assoc. Jul. 1991;89(7):319-21. X-9. [pmid: 1919305].
2700 Kaandorp G, Bosch JL, Duvekot JJ, et al. The effectiveness and cost-effectiveness of Breech Version Acumoxa compared to standard care to correct breech presentation. 13th Annual Symposium on Complementary Health Care. 12th-14th December, 2006. University of Exeter, UK. Focus on Alternative & Complementary Therapies. 2006;11:5-5. X-4c.
2701 Kabir AA, Pridjian G, Steinmann WC, et al. Racial differences in cesareans: an analysis of U.S. 2001 National Inpatient Sample Data. Obstet Gynecol. Apr. 2005;105(4):710-8. X-1. [pmid: 15802395].
2702 Kabir AA, Steinmann WC, Myers L, et al. Unnecessary cesarean delivery in Louisiana: an analysis of birth certificate data. Am J Obstet Gynecol. Jan. 2004;190(1):10-9. discussion 3A. X-1. [pmid: 14749628].
2703 Kacmar J, Bhimani L, Boyd M, et al. Route of delivery as a risk factor for emergent peripartum hysterectomy: a case-control study. Obstet Gynecol. Jul. 2003;102(1):141-5. X-1. [pmid: 12850620].
2704 Kadanali S, Kucukozkan T, Zor N, et al. Comparison of labor induction with misoprostol vs. oxytocin/prostaglandin E2 in term pregnancy. Int J Gynaecol Obstet. Nov. 1996;55(2):99-104. X-4d. [pmid: 8960988].
2705 Kadar N, Tapp A, Wong A. The influence of nipple stimulation at term on the duration of pregnancy. J Perinatol. Jun. 1990;10(2):164-6. X-4e, X-5. [pmid: 2193123].
2706 Kadiki OA, Reddy MR, Sahli MA, et al. Outcome of pregnant diabetic patients in Benghazi (Libya) from 1984 to 1991. Diabetes Res Clin Pract. Jul. 1993;21(1):39-42. X-1. [pmid: 8253020].
2707 Kadir RA, Khan A, Wilcock F, et al. Is inferior dissection of the rectus sheath necessary during Pfannenstiel incision for lower segment Caesarean section? A randomised controlled trial. Eur J Obstet Gynecol Reprod Biol. Sep-Oct. 2006;128(1-2):262-6. X-9. [pmid: 16621227].
2708 Kaemmerer H, Bauer U, Stein JI, et al. Pregnancy in congenital cardiac disease: an increasing challenge for cardiologists and obstetricians -- a prospective multicenter study. Z Kardiol. Jan. 2003;92(1):16-23. X-1. [pmid: 12545297].
2709 Kaestner R, Dubay L, Kenney G. Managed care and infant health: an evaluation of Medicaid in the US. Soc Sci Med. Apr. 2005;60(8):1815-33. X-1, X-4e, X-5. [pmid: 15686812].
2710 Kafali H, Duvan CI, Gozdemir E, et al. Influence of gum chewing on postoperative bowel activity after cesarean section. Gynecol Obstet Invest. 2010;69(2):84-7. X-9. [pmid: 19940484].
2711 Kafle SK. Intrathecal meperidine for elective caesarean section: a comparison with lidocaine. Can J Anaesth. Aug. 1993;40(8):718-21. X-9. [pmid: 8403155].
2712 Kaimal AJ, Zlatnik MG, Cheng YW, et al. Effect of a change in policy regarding the timing of prophylactic antibiotics on the rate of postcesarean delivery surgical-site infections. Am J Obstet Gynecol. Sep. 2008;199(3):310 e1-5. X-1. [pmid: 18771995].
2713 Kakuya F, Shirai M, Takase M, et al. Relationship between erythropoietin levels both in cord serum and amniotic fluid at birth and abnormal fetal heart rate records. Pediatr Int. Aug. 2002;44(4):414-9. X-1. [pmid: 12139568].
2714 Kale A, Kuyumcuoglu U, Guzel A. Is pregnancy over 45 with very high parity related with adverse maternal and fetal outcomes?. Clin Exp Obstet Gynecol. 2009;36(2):120-2. X-1. [pmid: 19688957].
2715 Kalhan SC, D'Angelo LJ, Savin SM, et al. Glucose production in pregnant women at term gestation. Sources of glucose for human fetus. J Clin Invest. Mar. 1979;63(3):388-94. X-1. [pmid: 429559].
2716 Kalish RB, McCullough LB, Chervenak FA. Decision-making about caesarean delivery. Lancet. Mar. 18. 2006;367(9514):883-5. X-1, X-2. [pmid: 16546524].
2717 Kallen B. Case control study of hypospadias, based on registry information. Teratology. Jul. 1988;38(1):45-50. X-1. [pmid: 3175939].
2718 Kallen B, Finnstrom O, Nygren KG, et al. In vitro fertilisation in Sweden: obstetric characteristics, maternal morbidity and mortality. BJOG. Nov. 2005;112(11):1529-35. X-1. [pmid: 16225574].
2719 Kamal P, Dixon-Woods M, Kurinczuk JJ, et al. Factors influencing repeat caesarean section: qualitative exploratory study of obstetricians' and midwives' accounts. BJOG. Aug. 2005;112(8):1054-60. X-1. [pmid: 16045517].
2720 Kamata S, Hasegawa T, Ishikawa S, et al. Prenatal diagnosis of congenital diaphragmatic hernia and perinatal care: assessment of lung hypoplasia. Early Hum Dev. Jun-Jul. 1992;29(1-3):375-9. X-1. [pmid: 1396271].
2721 Kampe S, Tausch B, Paul M, et al. Epidural block with ropivacaine and bupivacaine for elective caesarean section: maternal cardiovascular parameters, comfort and neonatal well-being. Curr Med Res Opin. Jan. 2004;20(1):7-12. X-9. [pmid: 14741065].
2722 Kampikaho A, Irwig LM. Risk factors for maternal mortality in five Kampala hospitals, 1980-1986. Int J Epidemiol. Dec. 1990;19(4):1116-8. X-1. [pmid: 2083999].
2723 Kan RE, Hughes SC, Rosen MA, et al. Intravenous remifentanil: placental transfer, maternal and neonatal effects. Anesthesiology. Jun. 1998;88(6):1467-74. X-1, X-9. [pmid: 9637638].
2724 Kanazi GE, Aouad MT, Abdallah FW, et al. The analgesic efficacy of subarachnoid morphine in comparison with ultrasound-guided transversus abdominis plane block after cesarean delivery: a randomized controlled trial. Anesth Analg. Aug. 2010;111(2):475-81. X-9. [pmid: 20488929].
2725 Kang FC, Tsai YC, Chang PJ, et al. Subarachnoid fentanyl with diluted small-dose bupivacaine for cesarean section delivery. Acta Anaesthesiol Sin. Dec. 1998;36(4):207-14. X-9. [pmid: 10399516].
2726 Kang YG, Abouleish E, Caritis S. Prophylactic intravenous ephedrine infusion during spinal anesthesia for cesarean section. Anesth Analg. Oct. 1982;61(10):839-42. X-9. [pmid: 7125249].
2727 Kangas-Saarela T, Hollmen AI, Tolonen U, et al. Does ephedrine influence newborn neurobehavioural responses and spectral EEG when used to prevent maternal hypotension during caesarean section?. Acta Anaesthesiol Scand. Jan. 1990;34(1):8-16. X-1, X-9. [pmid: 2309548].
2728 Kansal A, Mohta M, Sethi AK, et al. Randomised trial of intravenous infusion of ephedrine or mephentermine for management of hypotension during spinal anaesthesia for Caesarean section. Anaesthesia. Jan. 2005;60(1):28-34. X-9. [pmid: 15601269].
2729 Kanto J, Erkkola R, Aaltonen L, et al. Epidural morphine as postoperative analgesic following cesarean section under epidural analgesia. Int J Clin Pharmacol Ther Toxicol. Jan. 1985;23(1):43-4. X-9. [pmid: 3988391].
2730 Kanto J, Scheinin M. Biochemical assessment of preoperative stress: a study with diazepam and measurement of monoamine metabolites and catecholamines in cerebrospinal fluid and plasma. Br J Anaesth. May. 1991;66(5):587-90. X-9. [pmid: 1709566].
2731 Kanto J, Scheinin M. Diazepam and atropine as premedicants: no discrimination by monoamine metabolite and catecholamine measurements in cerebrospinal fluid and plasma. Acta Anaesthesiol Scand. Jan. 1992;36(1):80-3. X-9. [pmid: 1371633].
2732 Kantor T, Cavaliere MB, Hopper M, et al. A double-blind parallel comparison of ketoprofen, codeine, and placebo in patients with moderate to severe postpartum pain. J Clin Pharmacol. May-Jun. 1984;24(5-6):228-34. X-3, X-4e. [pmid: 6747019].
2733 Kappel B, Eriksen G, Hansen KB, et al. Short stature in Scandinavian women. An obstetrical risk factor. Acta Obstet Gynecol Scand. 1987;66(2):153-8. X-1. [pmid: 3618140].
2734 Karaer A, Avsar FA, Batioglu S. Risk factors for ectopic pregnancy: a case-control study. Aust N Z J Obstet Gynaecol. Dec. 2006;46(6):521-7. X-1. [pmid: 17116058].
2735 Karaman S, Akercan F, Akarsu T, et al. Comparison of the maternal and neonatal effects of epidural block and of combined spinal-epidural block for Cesarean section. Eur J Obstet Gynecol Reprod Biol. Jul. 1. 2005;121(1):18-23. X-9. [pmid: 15989982].
2736 Karaman S, Akercan F, Aldemir O, et al. The maternal and neonatal effects of the volatile anaesthetic agents desflurane and sevoflurane in caesarean section: a prospective, randomized clinical study. J Int Med Res. Mar-Apr. 2006;34(2):183-92. X-9. [pmid: 16749414].
2737 Karaman S, Kocabas S, Uyar M, et al. The effects of sufentanil or morphine added to hyperbaric bupivacaine in spinal anaesthesia for caesarean section. Eur J Anaesthesiol. Apr. 2006;23(4):285-91. X-9. [pmid: 16438758].
2738 Karambelkar DJ, Ramanathan S. 2-Chloroprocaine antagonism of epidural morphine analgesia. Acta Anaesthesiol Scand. Jun. 1997;41(6):774-8. X-9. [pmid: 9241341].
2739 Karcaaltincaba D, Akdag D, Kandemir O, et al. Is there any relation between development of persistent non-reassuring fetal heart rate pattern and acutely increased uterine artery vascular flow resistance during dinoprostone use in prolonged pregnancies?. Acta Obstet Gynecol Scand. 2009;88(8):894-900. X-1. [pmid: 19562559].
2740 Karhunen M, Koskela O, Teisala K, et al. Prophylaxis and treatment of anaerobic infections following caesarean section with tinidazole. Chemotherapy. 1985;31(3):228-36. X-1, X-9. [pmid: 3996091].
2741 Kariminia A, Saunders DM, Chamberlain M. Risk factors for strong regret and subsequent IVF request after having tubal ligation. Aust N Z J Obstet Gynaecol. Nov. 2002;42(5):526-9. X-1. [pmid: 12495101].
2742 Karinen J, Makarainen L, Alahuhta S, et al. Single bolus compared with a fractionated dose injection technique of bupivacaine for extradural Caesarean section: effect on uteroplacental and fetal haemodynamic state. Br J Anaesth. Aug. 1996;77(2):140-4. X-9. [pmid: 8881613].
2743 Karinen J, Rasanen J, Alahuhta S, et al. Effect of crystalloid and colloid preloading on uteroplacental and maternal haemodynamic state during spinal anaesthesia for caesarean section. Br J Anaesth. Nov. 1995;75(5):531-5. X-9. [pmid: 7577275].
2744 Karinen J, Rasanen J, Paavilainen T, et al. Uteroplacental and fetal haemodynamics and cardiac function of the fetus and newborn after crystalloid and colloid preloading for extradural caesarean section anaesthesia. Br J Anaesth. Dec. 1994;73(6):751-7. X-9. [pmid: 7880658].
2745 Kariniemi V, Aula P. Heart rate patterns in trisomic fetuses. J Perinat Med. 1982;10(5):242-6. X-1. [pmid: 6217310].
2746 Karjane NW, Brock EL, Walsh SW. Induction of labor using a foley balloon, with and without extra-amniotic saline infusion. Obstet Gynecol. Feb. 2006;107(2 Pt 1):234-9. X-4d. [pmid: 16449106].
2747 Karkanis SG, Caloia D, Salenieks ME, et al. Randomized controlled trial of rectal misoprostol versus oxytocin in third stage management. J Obstet Gynaecol Can. Feb. 2002;24(2):149-54. X-3, X-4e, X-5. [pmid: 12196880].
2748 Karlstrom A, Engstrom-Olofsson R, Nystedt A, et al. Swedish caregivers' attitudes towards caesarean section on maternal request. Women Birth. Jun. 2009;22(2):57-63. X-1. [pmid: 19195958].
2749 Karmon A, Levy A, Holcberg G, et al. Decreased perinatal mortality among women with diet-controlled gestational diabetes mellitus. Int J Gynaecol Obstet. Mar. 2009;104(3):199-202. X-1. [pmid: 19189868].
2750 Karpel JP, Wait JL. Asthma in women, part 1: clinical course and outcome in pregnancy: what to expect when asthma control is good -- and when it isn't. Journal of Critical Illness. 1999;14(11):599-606. X-1, X-2.
2751 Karsdorp VH, Dekker GA, Bast A, et al. Maternal and fetal plasma concentrations of endothelin, lipidhydroperoxides, glutathione peroxidase and fibronectin in relation to abnormal umbilical artery velocimetry. Eur J Obstet Gynecol Reprod Biol. Sep. 1998;80(1):39-44. X-1. [pmid: 9758257].
2752 Karsdorp VH, van Vugt JM, Jakobs C, et al. Amino acids, glucose and lactate concentrations in umbilical cord blood in relation to umbilical artery flow patterns. Eur J Obstet Gynecol Reprod Biol. Nov. 1994;57(2):117-22. X-1. [pmid: 7859903].
2753 Karsdorp VH, van Vugt JM, van Geijn HP, et al. Clinical significance of absent or reversed end diastolic velocity waveforms in umbilical artery. Lancet. Dec. 17. 1994;344(8938):1664-8. X-1. [pmid: 7996959].
2754 Karuparthy VR, Downing JW, Husain FJ, et al. Incidence of venous air embolism during cesarean section is unchanged by the use of a 5 to 10 degree head-up tilt. Anesth Analg. Nov. 1989;69(5):620-3. X-9. [pmid: 2679231].
2755 Kasai KE, Nomura RM, Benute GR, et al. Women's opinions about mode of birth in Brazil: a qualitative study in a public teaching hospital. Midwifery. Jun. 2010;26(3):319-26. X-1. [pmid: 18842327].
2756 Kashanian M, Akbarian A, Baradaran H, et al. Effect of membrane sweeping at term pregnancy on duration of pregnancy and labor induction: a randomized trial. Gynecol Obstet Invest. 2006;62(1):41-4. X-4d, X-5. [pmid: 16534210].
2757 Kashanian M, Akbarian AR, Baradaran H, et al. Pregnancy outcome following a previous spontaneous abortion (miscarriage). Gynecol Obstet Invest. 2006;61(3):167-70. X-1. [pmid: 16428886].
2758 Kashanian M, Akbarian AR, Fekrat M. Cervical ripening and induction of labor with intravaginal misoprostol and Foley catheter cervical traction. Int J Gynaecol Obstet. Jan. 2006;92(1):79-80. X-4d. [pmid: 16246342].
2759 Kashanian M, Fekrat M, Naghghash S, et al. Evaluation of the effect of extra-amniotic normal saline infusion alone or in combination with dexamethasone for the induction of labor. J Obstet Gynaecol Res. Feb. 2008;34(1):47-50. X-4d. [pmid: 18226128].
2760 Kashanian M, Fekrat M, Zarrin Z, et al. A comparison between the effect of oxytocin only and oxytocin plus propranolol on the labor (a double blind randomized trial). J Obstet Gynaecol Res. Jun. 2008;34(3):354-8. X-4d. [pmid: 18588611].
2761 Kashanian M, Javadi F, Haghighi MM. Effect of continuous support during labor on duration of labor and rate of cesarean delivery. Int J Gynaecol Obstet. Jun. 2010;109(3):198-200. X-6. [pmid: 20152972].
2762 Kassanos D, Botsis D, Rizos D, et al. Tissue polypeptide specific antigen (TPS) throughout normal pregnancy. Anticancer Res. May-Jun. 2000;20(3B):2129-31. X-1. [pmid: 10928165].
2763 Kassis A, Mazor M, Leiberman JR, et al. Management of post-date pregnancy: a case control study. Isr J Med Sci. Feb. 1991;27(2):82-6. X-1. [pmid: 2004889].
2764 Kasule J, Chimbira TH, Brown IM. Controlled trial of external cephalic version. Br J Obstet Gynaecol. Jan. 1985;92(1):14-8. X-4e, X-4c. [pmid: 3881122].
2765 Katafigioti A, Paraskeva A, Petropoulos G, et al. Pregnancy at term does not alter the responses to a mechanical and an electrical stimulus after skin EMLA application. Middle East J Anesthesiol. Jun. 2009;20(2):251-5. X-1. [pmid: 19583074].
2766 Kattwinkel J, Robinson M, Bloom BT, et al. Technique for intrapartum administration of surfactant without requirement for an endotracheal tube. J Perinatol. Jun. 2004;24(6):360-5. X-1. [pmid: 15085166].
2767 Katz O, Levy A, Wiznitzer A, et al. Pregnancy and perinatal outcome in epileptic women: a population-based study. J Matern Fetal Neonatal Med. Jan. 2006;19(1):21-5. X-1. [pmid: 16492586].
2768 Katz Z, Yemini M, Lancet M, et al. Non-aggressive management of post-date pregnancies. Eur J Obstet Gynecol Reprod Biol. Jun. 1983;15(2):71-9. X-4d, X-4e, X-5. [pmid: 6347741].
2769 Kaufman KE, Bailit JL, Grobman W. Elective induction: an analysis of economic and health consequences. Am J Obstet Gynecol. Oct. 2002;187(4):858-63. X-1. [pmid: 12388964].
2770 Kaufmann T, Liu D. Should cesareans be performed only on the basis of medical need?. Nurs Times. Sep. 20-26. 2001;97(38):17. X-1, X-2, X-3, X-4, X-5. [pmid: 11935846].
2771 Kaul B, Vallejo MC, Ramanathan S, et al. Induction of labor with oxytocin increases cesarean section rate as compared with oxytocin for augmentation of spontaneous labor in nulliparous parturients controlled for lumbar epidural analgesia. J Clin Anesth. Sep. 2004;16(6):411-4. X-1. [pmid: 15567643].
2772 Kauppila O, Gronroos M, Aro P, et al. Management of low birth weight breech delivery: should cesarean section be routine?. Obstet Gynecol. Mar. 1981;57(3):289-94. X-1. [pmid: 7465142].
2773 Kavak ZN, Basgul A, Ceyhan N. Short-term outcome of newborn infants: spinal versus general anesthesia for elective cesarean section. A prospective randomized study. Eur J Obstet Gynecol Reprod Biol. Dec. 10. 2001;100(1):50-4. X-9. [pmid: 11728657].
2774 Kavee EH, Bernstein J, Zakowski MI, et al. The hypothermic action of epidural and subarachnoid morphine in parturients. Reg Anesth. Nov-Dec. 1991;16(6):325-8. X-1. [pmid: 1772816].
2775 Kawamata K, Neki R, Yamanaka K, et al. Risks and pregnancy outcome in women with prosthetic mechanical heart valve replacement. Circ J. Feb. 2007;71(2):211-3. X-1. [pmid: 17251669].
2776 Kaya FN, Sahin S, Owen MD, et al. Epidural neostigmine produces analgesia but also sedation in women after cesarean delivery. Anesthesiology. Feb. 2004;100(2):381-5. X-9. [pmid: 14739815].
2777 Kaya T, Buyukkocak U, Basar H, et al. Comparison of epidural ropivacaine 0.2% and ropivacaine 0.2% in combination with sufentanil 0.75 microg mL-1 for postcaesarean analgesia. Agri. Oct. 2008;20(4):30-7. X-9. [pmid: 19117154].
2778 Kaya T, Cetin A, Cetin M, et al. Effects of endothelin-1 and calcium channel blockers on contractions in human myometrium. A study on myometrial strips from normal and diabetic pregnant women. J Reprod Med. Feb. 1999;44(2):115-21. X-1. [pmid: 10853442].
2779 Kayabasoglu F, Guzin K, Aydogdu S, et al. Emergency peripartum hysterectomy in a tertiary Istanbul hospital. Arch Gynecol Obstet. Sep. 2008;278(3):251-6. X-1. [pmid: 18193245].
2780 Kaye D. Risk factors for preterm premature rupture of membranes at Mulago Hospital, Kampala. East Afr Med J. Feb. 2001;78(2):65-9. X-1. [pmid: 11682948].
2781 Kaye D. Antenatal and intrapartum risk factors for birth asphyxia among emergency obstetric referrals in Mulago Hospital, Kampala, Uganda. East Afr Med J. Mar. 2003;80(3):140-3. X-1. [pmid: 12762429].
2782 Kaye SA, Robison LL, Smithson WA, et al. Maternal reproductive history and birth characteristics in childhood acute lymphoblastic leukemia. Cancer. Sep. 15. 1991;68(6):1351-5. X-1. [pmid: 1873786].
2783 Kayihura V, Osman NB, Bugalho A, et al. Choice of antibiotics for infection prophylaxis in emergency cesarean sections in low-income countries: a cost-benefit study in Mozambique. Acta Obstet Gynecol Scand. Jul. 2003;82(7):636-41. X-9. [pmid: 12790845].
2784 Kaymak O, Ustunyurt E, Okyay RE, et al. Myomectomy during cesarean section. Int J Gynaecol Obstet. May. 2005;89(2):90-3. X-1. [pmid: 15847868].
2785 Kazandjian VA, Chaulk CP, Ogunbo S, et al. Does a Cesarean section delivery always cost more than a vaginal delivery?. J Eval Clin Pract. Feb. 2007;13(1):16-20. X-1. [pmid: 17286718].
2786 Kazandjian VA, Summer SJ. Evaluating the appropriateness of care: a study of cesarean section rates. QRB Qual Rev Bull. Jul. 1989;15(7):206-14. X-1. [pmid: 2771383].
2787 Kazzi GM, Bottoms SF, Rosen MG. Efficacy and safety of Laminaria digitata for preinduction ripening of the cervix. Obstet Gynecol. Oct. 1982;60(4):440-3. X-1. [pmid: 7121931].
2788 Keane D, James D. Prophylactic antibiotics at caesarean section do not reduce costs. Health Trends. 1993;25(3):84-7. X-1. [pmid: 10131868].
2789 Keane HE, Thornton JG. A trial of cetrimide/chlorhexidine or tap water for perineal cleaning. British Journal of Midwifery. 1998;6(1):34-37. X-4e.
2790 Keelan JA, Zhou RL, Mitchell MD. Activin A exerts both pro- and anti-inflammatory effects on human term gestational tissues. Placenta. Jan. 2000;21(1):38-43. X-1. [pmid: 10692249].
2791 Keeler EB, Brodie M. Economic incentives in the choice between vaginal delivery and cesarean section. Milbank Q. 1993;71(3):365-404. X-1. [pmid: 8413067].
2792 Keeler EB, Fok T. Equalizing physician fees had little effect on cesarean rates. Med Care Res Rev. Dec. 1996;53(4):465-71. X-9. [pmid: 10162961].
2793 Keeri-Szanto M. The mode of action of promethazine in potentiating narcotic drugs. Br J Anaesth. Dec. 1974;46(12):918-24. X-9. [pmid: 4157318].
2794 Keeton K, Zikmund-Fisher BJ, Ubel PA, et al. The accuracy of predicting parity as a prerequisite for cesarean delivery on maternal request. Obstet Gynecol. Aug. 2008;112(2 Pt 1):285-9. X-1. [pmid: 18669724].
2795 Keijzer G, Lemay G, Toms C, et al. Tricks of the trade. Midwifery Today. 2005;(76):7-7. X-2.
2796 Keirse MJ, de Koning Gans HJ. Randomized comparison of the effects of endocervical and vaginal prostaglandin E2 gel in women with various degrees of cervical ripeness. Dutch Collaborative Prostaglandin Trialists' Group. Am J Obstet Gynecol. Dec. 1995;173(6):1859-64. X-4d, X-4e, X-5. [pmid: 8610776].
2797 Keirse MJN. The Term Breech Trial and its aftermath. Birth Issues. 2007;15(3-4):114-118. X-1.
2798 Keith RD, Beckley S, Garibaldi JM, et al. A multicentre comparative study of 17 experts and an intelligent computer system for managing labour using the cardiotocogram. Br J Obstet Gynaecol. Sep. 1995;102(9):688-700. X-1. [pmid: 7547758].
2799 Kellum RB, Roberts WE, Harris JB, et al. Effect of intrauterine antibiotic lavage after cesarean birth on postoperative morbidity. J Reprod Med. Jul. 1985;30(7):527-9. X-9. [pmid: 4032389].
2800 Kelly K. Childbirth: what it's really like. American Baby. 2003;65(11):122. X-1.
2801 Kelly KM, Madden DA, Arcarese JS, et al. The utilization and efficacy of pelvimetry. Am J Roentgenol Radium Ther Nucl Med. Sep. 1975;125(1):66-74. X-1.
2802 Kelly MC, Carabine UA, Mirakhur RK. Intrathecal diamorphine for analgesia after caesarean section. A dose finding study and assessment of side-effects. Anaesthesia. Mar. 1998;53(3):231-7. X-9. [pmid: 9613267].
2803 Kelly MC, Fitzpatrick KT, Hill DA. Respiratory effects of spinal anaesthesia for caesarean section. Anaesthesia. Dec. 1996;51(12):1120-2. X-1. [pmid: 9038445].
2804 Kelly RW, Leask R, Calder AA. Choriodecidual production of interleukin-8 and mechanism of parturition. Lancet. Mar. 28. 1992;339(8796):776-7. X-1. [pmid: 1347804].
2805 Kelly VM, Nelson LM, Chakravarty EF. Obstetric outcomes in women with multiple sclerosis and epilepsy. Neurology. Dec. 1. 2009;73(22):1831-6. X-1. [pmid: 19923552].
2806 Kelso IM, Parsons RJ, Lawrence GF, et al. An assessment of continuous fetal heart rate monitoring in labor. A randomized trial. Am J Obstet Gynecol. Jul. 1. 1978;131(5):526-32. X-4e, X-5. [pmid: 677195].
2807 Kemp B, Rath W, Winkler M, et al. Is cervical dilatation during parturition at term associated with apoptosis?. J Perinat Med. 2005;33(2):137-43. X-1. [pmid: 15843264].
2808 Kendell RE, McInneny K, Juszczak E, et al. Obstetric complications and schizophrenia. Two case-control studies based on structured obstetric records. Br J Psychiatry. Jun. 2000;176:516-22. X-1. [pmid: 10974955].
2809 Kendrick WD, Woods AM, Daly MY, et al. Naloxone versus nalbuphine infusion for prophylaxis of epidural morphine-induced pruritus. Anesth Analg. Mar. 1996;82(3):641-7. X-9. [pmid: 8623975].
2810 Kenepp NB, Kumar S, Shelley WC, et al. Fetal and neonatal hazards of maternal hydration with 5% dextrose before caesarean section. Lancet. May. 22. 1982;1(8282):1150-2. X-9. [pmid: 6122939].
2811 Kennaway DJ, Goble FC, Stamp GE. Factors influencing the development of melatonin rhythmicity in humans. J Clin Endocrinol Metab. Apr. 1996;81(4):1525-32. X-1. [pmid: 8636362].
2812 Kennedy I. Consent: adult, refusal of consent, capacity: Re M.B. (Medical Treatment). Med Law Rev. Autumn. 1997;5(3):317-25. X-1, X-2. [pmid: 11657492].
2813 Kennedy JH, Stewart P, Barlow DH, et al. Induction of labour: a comparison of a single prostaglandin E2 vaginal tablet with amniotomy and intravenous oxytocin. Br J Obstet Gynaecol. Sep. 1982;89(9):704-7. X-4d. [pmid: 7052115].
2814 Kenton K, Brincat C, Mutone M, et al. Repeat cesarean section and primary elective cesarean section: recently trained obstetrician-gynecologist practice patterns and opinions. Am J Obstet Gynecol. Jun. 2005;192(6):1872-5. discussion 1875-6. X-1. [pmid: 15970836].
2815 Kenyon AP, Piercy CN, Girling J, et al. Obstetric cholestasis, outcome with active management: a series of 70 cases. BJOG. Mar. 2002;109(3):282-8. X-1. [pmid: 11950183].
2816 Keogh E, Hughes S, Ellery D, et al. Psychosocial influences on women's experience of planned elective cesarean section. Psychosom Med. Jan-Feb. 2006;68(1):167-74. X-1. [pmid: 16449428].
2817 Kernaghan D, Penney GC, Pearson DWM. Pregnancy-related care and outcomes for women with Type 1 diabetes in Scotland: a five-year population-based audit cycle. Clinical Governance: An International Journal. 2006;11(2):114-127. X-1.
2818 Kerr-Wilson RH, McNally S. Bladder drainage for caesarean section under epidural analgesia. Br J Obstet Gynaecol. Jan. 1986;93(1):28-30. X-9. [pmid: 3942703].
2819 Kershaw K, Jolly J, Bhabra K, et al. Randomised controlled trial of community debriefing following operative delivery. BJOG. Nov. 2005;112(11):1504-9. X-3, X-4e. [pmid: 16225570].
2820 Kessler I, Lancet M, Borenstein R, et al. The obstetrical management of patients with immunologic thrombocytopenic purpura. Int J Gynaecol Obstet. Feb. 1982;20(1):23-8. X-1. [pmid: 6126403].
2821 Kessler I, Lancet M, Borenstein R, et al. The problem of the older primipara. Obstet Gynecol. Aug. 1980;56(2):165-9. X-1. [pmid: 7190255].
2822 Kessler I, Shoham Z, Lancet M, et al. Complications associated with genital colonization in pregnancies with and without cerclage. Int J Gynaecol Obstet. Dec. 1988;27(3):359-63. X-1. [pmid: 2904898].
2823 Kestila KK, Ekblad UU, Ronnemaa T. Continuous glucose monitoring versus self-monitoring of blood glucose in the treatment of gestational diabetes mellitus. Diabetes Res Clin Pract. Aug. 2007;77(2):174-9. X-4e, X-5. [pmid: 17234297].
2824 Kestin IG, Madden AP, Mulvein JT, et al. Comparison of incremental spinal anesthesia using a 32-gauge catheter with extradural anaesthesia for elective caesarean section. Br J Anaesth. Feb. 1991;66(2):232-6. X-9. [pmid: 1817627].
2825 Ketler SK. The rebirth of informed consent: a cultural analysis of the Informed Consent Doctrine after Schreiber v. Physicians Insurance Co. of Wisconsin. Northwest Univ Law Rev. Spring. 2001;95(3):1029-56. X-1, X-2. [pmid: 12778922].
2826 Khan A, Zaman S. Costs of vaginal delivery and Caesarean section at a tertiary level public hospital in Islamabad, Pakistan. BMC Pregnancy Childbirth. 2010;10:2. X-1. [pmid: 20085662].
2827 Khan KS, Hashmi FA, Rizvi JH. Are nondiabetic women with abnormal glucose screening test at increased risk of pre-eclampsia, macrosomia and caesarian birth?. J Pak Med Assoc. Jul. 1995;45(7):176-9. X-1. [pmid: 8523639].
2828 Khan KS, Khan BF, Rasul S, et al. The safety of epidural analgesia in labour and its effect on delivery--a case control study in Pakistani women. J Pak Med Assoc. Jun. 1993;43(6):115-7. X-1. [pmid: 8411613].
2829 Khan R, Burgoyne L, O'Connell M, et al. Antenatal management of the expectant mother and extreme preterm infant at the limits of viability. Ir Med J. Oct. 2010;103(9):266-9. X-1. [pmid: 21186749].
2830 Khan ZH, Zanjani AP, Makarem J, et al. Antishivering effects of two different doses of intrathecal meperidine in caesarean section: a prospective randomised blinded study. Eur J Anaesthesiol. Mar. 2011;28(3):202-6. X-9. [pmid: 21325901].
2831 Khandelwal M, Lynch L, Lockwood CJ, et al. Maternal serum levels of alpha-fetoprotein and fetal fibronectin as markers of labor in the third trimester. Am J Perinatol. May. 1995;12(3):161-3. X-1. [pmid: 7541997].
2832 Khang YH, Yun SC, Jo MW, et al. Public release of institutional Cesarean section rates in South Korea: which women were aware of the information?. Health Policy. Apr. 2008;86(1):10-6. X-1. [pmid: 17964680].
2833 Khatree MH, Mokgokong ET. The significance of meconium staining of the liquor amnii during labour. S Afr Med J. Dec. 15. 1979;56(25):1099-101. X-1. [pmid: 550443].
2834 Khatun N, Latif SA, Uddin MM. Pregnancy associated complications of mothers with gestational diabetes mellitus. Mymensingh Med J. Jul. 2005;14(2):196-8. X-1. [pmid: 16056211].
2835 Khaw KS, Ngan Kee WD, Chu CY, et al. Effects of different inspired oxygen fractions on lipid peroxidation during general anaesthesia for elective Caesarean section. Br J Anaesth. Sep. 2010;105(3):355-60. X-9. [pmid: 20576633].
2836 Khaw KS, Ngan Kee WD, Lee A, et al. Supplementary oxygen for elective Caesarean section under spinal anaesthesia: useful in prolonged uterine incision-to-delivery interval?. Br J Anaesth. Apr. 2004;92(4):518-22. X-9. [pmid: 15013959].
2837 Khaw KS, Ngan Kee WD, Wong EL, et al. Spinal ropivacaine for cesarean section: a dose-finding study. Anesthesiology. Dec. 2001;95(6):1346-50. X-9. [pmid: 11748390].
2838 Khaw KS, Ngan Kee WD, Wong M, et al. Spinal ropivacaine for cesarean delivery: a comparison of hyperbaric and plain solutions. Anesth Analg. Mar. 2002;94(3):680-5. table of contents. X-9. [pmid: 11867397].
2839 Khaw KS, Wang CC, Ngan Kee WD, et al. Effects of high inspired oxygen fraction during elective caesarean section under spinal anaesthesia on maternal and fetal oxygenation and lipid peroxidation. Br J Anaesth. Jan. 2002;88(1):18-23. X-9. [pmid: 11883375].
2840 Khaw KS, Wang CC, Ngan Kee WD, et al. Supplementary oxygen for emergency Caesarean section under regional anaesthesia. Br J Anaesth. Jan. 2009;102(1):90-6. X-9. [pmid: 19011261].
2841 Khawaja M, Choueiry N, Jurdi R. Hospital-based caesarean section in the Arab region: an overview. East Mediterr Health J. Mar-Apr. 2009;15(2):458-69. X-1. [pmid: 19554995].
2842 Khawaja NP, Yousaf T, Tayyeb R. Analysis of caesarean delivery at a tertiary care hospital in Pakistan. J Obstet Gynaecol. Feb. 2004;24(2):139-41. X-1. [pmid: 14766448].
2843 Khonjandi M, Tsai M, Tyson JE. Gestational diabetes: the dilemma of delivery. Obstet Gynecol. Jan. 1974;43(1):1-6. X-1. [pmid: 4587642].
2844 Khor LJ, Jeskins G, Cooper GM, et al. National obstetric anaesthetic practice in the UK 1997/1998. Anaesthesia. Dec. 2000;55(12):1168-72. X-1. [pmid: 11121925].
2845 Khosla AH, Sangwan K, Ahuja SD. Prophylactic amnioinfusion during labor complicated by meconium. Aust N Z J Obstet Gynaecol. Aug. 1997;37(3):294-6. X-1. [pmid: 9325508].
2846 Khunpradit S, Patumanond J, Tawichasri C. Risk indicators for cesarean section due to cephalopelvic disproportion in Lamphun hospital. J Med Assoc Thai. Oct. Suppl 2. 2005;88:S63-8. X-1. [pmid: 17722319].
2847 Khunpradit S, Patumanond J, Tawichasri C. Validation of risk scoring scheme for cesarean delivery due to cephalopelvic disproportion in Lamphun Hospital. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S163-8. X-1. [pmid: 17726817].
2848 Khunpradit S, Patumanond J, Tawichasri C. Development of risk scoring scheme for prediction of cesarean delivery due to cephalopelvic disproportion in Lamphun Hospital, Thailand. J Obstet Gynaecol Res. Aug. 2007;33(4):445-51. X-1. [pmid: 17688610].
2849 Khunpradit S, Tavender E, Lumbiganon P, et al. Non-clinical interventions for reducing unnecessary caesarean section (Review). Cochrane Database of Systematic Reviews [Review]. 2011. 2011;(6). X-1, X-2.
2850 Kianmanesh Rad NA, Vandenbussche FP, Le Cessie S, et al. A risk model approach to the prediction of fetal acidemia. J Perinat Med. 1998;26(4):270-7. X-1. [pmid: 9846301].
2851 Kidd LC, Patel NB, Smith R. Non-stress antenatal cardiotocography--a prospective randomized clinical trial. Br J Obstet Gynaecol. Nov. 1985;92(11):1156-9. X-1, X-4e. [pmid: 3904818].
2852 Kieback DG, Zahradnik HP, Quaas L, et al. Clinical evaluation of endocervical prostaglandin E2-triacetin-gel for preinduction cervical softening in pregnant women at term. Prostaglandins. Jul. 1986;32(1):81-5. X-4d, X-5. [pmid: 3532209].
2853 Kiely JL. Mode of delivery and neonatal death in 17,587 infants presenting by the breech. Br J Obstet Gynaecol. Sep. 1991;98(9):898-904. X-1. [pmid: 1911609].
2854 Kikutani T, Oshima M, Sugimoto K, et al. Effects of intravenous infusion rate of oxytocin on thoracic epidural pressure in parturients undregoing elective cesarean section. J Nippon Med Sch. Dec. 2003;70(6):475-9. X-9. [pmid: 14685287].
2855 Kikutani T, Shimada Y. Effects of methylergometrine and oxytocin on thoracic epidural pressure during cesarean section. J Obstet Gynaecol Res. Jun. 2003;29(3):180-5. X-9. [pmid: 12841703].
2856 Kilarski WM, Fu X, Roomans GM, et al. In vitro effect of Hepes buffer on maintaining the number of gap junction plaques in human myometrium at term. Folia Histochem Cytobiol. 1995;33(3):151-5. X-1. [pmid: 8612866].
2857 Kilby MD, Afford S, Li XF, et al. Localisation of hepatocyte growth factor and its receptor (c-met) protein and mRNA in human term placenta. Growth Factors. 1996;13(1-2):133-9. X-1. [pmid: 8804995].
2858 Kilby MD, Neary RH, Mackness MI, et al. Fetal and maternal lipoprotein metabolism in human pregnancy complicated by type I diabetes mellitus. J Clin Endocrinol Metab. May. 1998;83(5):1736-41. X-1, X-3, X-4b. [pmid: 9589684].
2859 Killie MK, Kjeldsen-Kragh J, Husebekk A, et al. Cost-effectiveness of antenatal screening for neonatal alloimmune thrombocytopenia. BJOG. May. 2007;114(5):588-95. X-1. [pmid: 17355359].
2860 Kim C, Brawarsky P, Jackson RA, et al. Changes in health status experienced by women with gestational diabetes and pregnancy-induced hypertensive disorders. J Womens Health (Larchmt). Oct. 2005;14(8):729-36. X-1. [pmid: 16232105].
2861 Kim JH, Min KT, Ahn EK, et al. The infusion rate of mivacurium or atracurium for cesarean section compared with gynecological procedures. Yonsei Med J. Aug. 1999;40(4):371-6. X-1. [pmid: 10487141].
2862 Kim LH, Cheng YW, Delaney S, et al. Is preeclampsia associated with an increased risk of cesarean delivery if labor is induced?. J Matern Fetal Neonatal Med. May. 2010;23(5):383-8. X-1. [pmid: 19951010].
2863 Kimberlin DF, Hauth JC, Goldenberg RL, et al. The effect of maternal magnesium sulfate treatment on neonatal morbidity in < or = 1000-gram infants. Am J Perinatol. 1998;15(11):635-41. X-1. [pmid: 10064205].
2864 Kimberlin DF, Hauth JC, Owen J, et al. Indicated versus spontaneous preterm delivery: An evaluation of neonatal morbidity among infants weighing </=1000 grams at birth. Am J Obstet Gynecol. Mar. 1999;180(3 Pt 1):683-9. X-1. [pmid: 10076148].
2865 King D. Birth and delivery rates for 2004. International Journal of Childbirth Education. 2006;21(4):30-31. X-1.
2866 King DE, Lahiri K. Socioeconomic factors and the odds of vaginal birth after cesarean delivery. JAMA. Aug. 17. 1994;272(7):524-9. X-1. [pmid: 8046806].
2867 King H, Ashley S, Brathwaite D, et al. Adequacy of general anesthesia for cesarean section. Anesth Analg. Jul. 1993;77(1):84-8. X-1, X-9. [pmid: 8317753].
2868 King HH, Tettambel MA, Lockwood MD, et al. Osteopathic manipulative treatment in prenatal care: a retrospective case control design study. J Am Osteopath Assoc. Dec. 2003;103(12):577-82. X-1. [pmid: 14740980].
2869 King HK, Wood L, Steffens Z, et al. Spinal anesthesia for cesarean section: isobaric versus hyperbaric solution. Acta Anaesthesiol Sin. Jun. 1999;37(2):61-4. X-9. [pmid: 10410404].
2870 King JF. Guest commentary. The Term Breech Trial. Birth Issues. 2000;9(4):113-113. X-1.
2871 King KJ, Douglas MJ, Unger W, et al. Five unit bolus oxytocin at cesarean delivery in women at risk of atony: a randomized, double-blind, controlled trial. Anesth Analg. Dec. 2010;111(6):1460-6. X-9. [pmid: 20889945].
2872 King MJ, Bowden MI, Cooper GM. Epidural fentanyl and 0.5% bupivacaine for elective caesarean section. Anaesthesia. Apr. 1990;45(4):285-8. X-9. [pmid: 2337211].
2873 King TA, Jackson GL, Josey AS, et al. The effect of profound umbilical artery acidemia in term neonates admitted to a newborn nursery. J Pediatr. Apr. 1998;132(4):624-9. X-1. [pmid: 9580760].
2874 Kingdom JC, McQueen J, Connell JM, et al. Fetal angiotensin II levels and vascular (type I) angiotensin receptors in pregnancies complicated by intrauterine growth retardation. Br J Obstet Gynaecol. May. 1993;100(5):476-82. X-1. [pmid: 8518250].
2875 Kingdon C, Lavender T. Cochrane reviews with no trials: pointless or pragmatic?. British Journal of Midwifery. 2008;16(1):8-11. X-1, X-2.
2876 Kingdon C, Neilson J, Singleton V, et al. Choice and birth method: mixed-method study of caesarean delivery for maternal request. BJOG. Jun. 2009;116(7):886-95. X-1. [pmid: 19385961].
2877 Kinsella SM, Walton B, Sashidharan R, et al. Category-1 caesarean section: a survey of anaesthetic and peri-operative management in the UK. Anaesthesia. Apr. 2010;65(4):362-8. X-1. [pmid: 20402875].
2878 Kinsley M. Planning for baby's birth day. Nursing Spectrum -- New York & New Jersey Edition. 2007;19A(9):NJ/NY4-5. X-1, X-2.
2879 Kiondo P, Wandabwa J, Doyle P. Risk factors for placenta praevia presenting with severe vaginal bleeding in Mulago hospital, Kampala, Uganda. Afr Health Sci. Mar. 2008;8(1):44-9. X-1. [pmid: 19357732].
2880 Kiran TS, Chui YK, Bethel J, et al. Is gestational age an independent variable affecting uterine scar rupture rates?. Eur J Obstet Gynecol Reprod Biol. May. 1. 2006;126(1):68-71. X-1. [pmid: 16221523].
2881 Kirby AE. Classification of advanced practice nursing functions using the Nursing Intervention Classification taxonomy. PH.D. 1996:237. X-1, X-2.
2882 Kirkinen P, Jouppila P, Herva R. Fatal fetal abnormalities. Route of delivery and effect of the development of antepartum diagnostics in the last 13 years. J Reprod Med. Jul. 1992;37(7):645-8. X-1. [pmid: 1522572].
2883 Kirkman S. The burden of proof. Pract Midwife. Jun. 2004;7(6):4-5. X-1, X-2, X-3, X-4, X-5. [pmid: 15222195].
2884 Kirz DS, Dorchester W, Freeman RK. Advanced maternal age: the mature gravida. Am J Obstet Gynecol. May. 1. 1985;152(1):7-12. X-1. [pmid: 3993714].
2885 Kitzinger S, Green JM, Chalmers B, et al. Why do women go along with this stuff?. Birth. Jun. 2006;33(2):154-8. X-1, X-2. [pmid: 16732782].
2886 Kitzmiller JL, Elixhauser A, Carr S, et al. Assessment of costs and benefits of management of gestational diabetes mellitus. Diabetes Care. Aug. Suppl 2. 1998;21:B123-30. X-1. [pmid: 9704239].
2887 Kjaer K, Comerford M, Kondilis L, et al. Oral sodium citrate increases nausea amongst elective Cesarean delivery patients. Can J Anaesth. Aug. 2006;53(8):776-80. X-9. [pmid: 16873344].
2888 Kjaer K, Hagen C, Sando SH, et al. Infertility and pregnancy outcome in an unselected group of women with insulin-dependent diabetes mellitus. Am J Obstet Gynecol. May. 1992;166(5):1412-8. X-1. [pmid: 1595796].
2889 Kjaergaard H, Olsen J, Ottesen B, et al. Incidence and outcomes of dystocia in the active phase of labor in term nulliparous women with spontaneous labor onset. Acta Obstet Gynecol Scand. 2009;88(4):402-7. X-1. [pmid: 19330572].
2890 Kjaergaard H, Olsen J, Ottesen B, et al. Obstetric risk indicators for labour dystocia in nulliparous women: a multi-centre cohort study. BMC Pregnancy Childbirth. 2008;8:45. X-1. [pmid: 18837972].
2891 Kjeldsen-Kragh J, Killie MK, Tomter G, et al. A screening and intervention program aimed to reduce mortality and serious morbidity associated with severe neonatal alloimmune thrombocytopenia. Blood. Aug. 1. 2007;110(3):833-9. X-1. [pmid: 17429009].
2892 Kjos SL, Berkowitz KM, Kung B. Prospective delivery of reliably dated term infants of diabetic mothers without determination of fetal lung maturity: comparison to historical control. J Matern Fetal Neonatal Med. Dec. 2002;12(6):433-7. X-1. [pmid: 12683657].
2893 Kjos SL, Henry OA, Montoro M, et al. Insulin-requiring diabetes in pregnancy: a randomized trial of active induction of labor and expectant management. Am J Obstet Gynecol. Sep. 1993;169(3):611-5. X-4e. [pmid: 8372870].
2894 Kjos SL, Schaefer-Graf U, Sardesi S, et al. A randomized controlled trial using glycemic plus fetal ultrasound parameters versus glycemic parameters to determine insulin therapy in gestational diabetes with fasting hyperglycemia. Diabetes Care. Nov. 2001;24(11):1904-10. X-4b, X-4e, X-5. [pmid: 11679455].
2895 Klamt JG, Garcia LV, Prado WA. Analgesic and adverse effects of a low dose of intrathecally administered hyperbaric neostigmine alone or combined with morphine in patients submitted to spinal anaesthesia: pilot studies. Anaesthesia. Jan. 1999;54(1):27-31. X-1, X-9. [pmid: 10209366].
2896 Klaus MH, Kennell JH, Robertson SS, et al. Effects of social support during parturition on maternal and infant morbidity. Br Med J (Clin Res Ed). Sep. 6. 1986;293(6547):585-7. X-6.
2897 Klauser CK, Christensen EE, Chauhan SP, et al. Use of fetal pulse oximetry among high-risk women in labor: a randomized clinical trial. Am J Obstet Gynecol. Jun. 2005;192(6):1810-7. discussion 1817-9. X-4e. [pmid: 15970816].
2898 Klebe JG, Espersen T, Allen J. Diabetes mellitus and pregnancy. A seven-year material of pregnant diabetics, where control during pregnancy was based on a centralized ambulant regime. Acta Obstet Gynecol Scand. 1986;65(3):235-40. X-1. [pmid: 3739629].
2899 Kleiblova P, Dostalova I, Bartlova M, et al. Expression of adipokines and estrogen receptors in adipose tissue and placenta of patients with gestational diabetes mellitus. Mol Cell Endocrinol. Jan. 15. 2010;314(1):150-6. X-9. [pmid: 19682537].
2900 Klein AH, Hobel CJ, Sack J, et al. Effect of intraamniotic fluid thyroxine injection on fetal serum and amniotic fluid iodothyronine concentrations. J Clin Endocrinol Metab. Nov. 1978;47(5):1034-7. X-1, X-9. [pmid: 263334].
2901 Klein B, Faridi A, Amo-Takyi BK, et al. Neonatal platelet activation in preeclampsia. Clin Appl Thromb Hemost. Jan. 2001;7(1):29-32. X-1. [pmid: 11190901].
2902 Klein CJ, Dyck PJ, Friedenberg SM, et al. Inflammation and neuropathic attacks in hereditary brachial plexus neuropathy. J Neurol Neurosurg Psychiatry. Jul. 2002;73(1):45-50. X-1. [pmid: 12082044].
2903 Klein M. The active management of labor: whose agenda?. Birth. Jun. 1993;20(2):97-9. X-1, X-2. [pmid: 8240615].
2904 Klein M, Papageorgiou A, Westreich R, et al. Care in a birth room versus a conventional setting: a controlled trial. Can Med Assoc J. Dec. 15. 1984;131(12):1461-6. X-1, X-4e, X-5. [pmid: 6388776].
2905 Klein MC, Gauthier RJ, Robbins JM, et al. Relationship of episiotomy to perineal trauma and morbidity, sexual dysfunction, and pelvic floor relaxation. Am J Obstet Gynecol. Sep. 1994;171(3):591-8. X-1, X-3, X-4e, X-5. [pmid: 8092203].
2906 Klein MC, Grzybowski S, Harris S, et al. Epidural analgesia use as a marker for physician approach to birth: implications for maternal and newborn outcomes. Birth. Dec. 2001;28(4):243-8. X-1. [pmid: 11903212].
2907 Klein MC, Kaczorowski J, Firoz T, et al. A comparison of urinary and sexual outcomes in women experiencing vaginal and Caesarean births. J Obstet Gynaecol Can. Apr. 2005;27(4):332-9. X-1. [pmid: 15937606].
2908 Klein MC, Kaczorowski J, Hall WA, et al. The attitudes of Canadian maternity care practitioners towards labour and birth: many differences but important similarities. J Obstet Gynaecol Can. Sep. 2009;31(9):827-40. X-1. [pmid: 19941707].
2909 Klein MC, Kaczorowski J, Robbins JM, et al. Physicians' beliefs and behaviour during a randomized controlled trial of episiotomy: consequences for women in their care. CMAJ. Sep. 15. 1995;153(6):769-79. X-1. [pmid: 7664230].
2910 Klein MC, Kelly A, Kaczorowski J, et al. The effect of family physician timing of maternal admission on procedures in labour and maternal and infant morbidity. J Obstet Gynaecol Can. Jul. 2004;26(7):641-5. X-1. [pmid: 15248933].
2911 Klein MC, Sakala C, Simkin P, et al. Why do women go along with this stuff?. Birth. Sep. 2006;33(3):245-50. X-1, X-2, X-3, X-4e, X-5. [pmid: 16948725].
2912 Klein VR, McDowl J. Should pregnant women be able to choose elective cesarean as a birth option?. MCN Am J Matern Child Nurs. Sep-Oct. 2010;35(5):252-3. X-1, X-2. [pmid: 20706094].
2913 Klerman LV, Ramey SL, Goldenberg RL, et al. A randomized trial of augmented prenatal care for multiple-risk, Medicaid-eligible African American women. Am J Public Health. Jan. 2001;91(1):105-11. X-4e, X-5. [pmid: 11189800].
2914 Kline GA, Edwards A. Antepartum and intra-partum insulin management of type 1 and type 2 diabetic women: Impact on clinically significant neonatal hypoglycemia. Diabetes Res Clin Pract. Aug. 2007;77(2):223-30. X-1. [pmid: 17126946].
2915 Klonoff-Cohen HS, Srinivasan IP, Edelstein SL. Prenatal and intrapartum events and sudden infant death syndrome. Paediatr Perinat Epidemiol. Jan. 2002;16(1):82-9. X-1. [pmid: 11856458].
2916 Klufio CA, Amoa AB, Kariwiga G, et al. A case-control study of meconium staining of amniotic fluid in labour at Port Moresby General Hospital to determine associated risk factors and perinatal outcome. P N G Med J. Dec. 1996;39(4):297-309. X-1. [pmid: 10214088].
2917 Kmietowicz Z. NICE advises against caesarean section on demand. BMJ. May. 1. 2004;328(7447):1031. X-1, X-2. [pmid: 15117770].
2918 Knauth DR, Barbosa RM, Hopkins K. Between personal wishes and medical “prescription”: mode of delivery and post-partum sterilisation among women with HIV in Brazil. Reprod Health Matters. Nov. 2003;11(22):113-21. X-1. [pmid: 14708402].
2919 Knight M. Antenatal pulmonary embolism: risk factors, management and outcomes. BJOG. Mar. 2008;115(4):453-61. X-1. [pmid: 18201281].
2920 Knight M, Kurinczuk JJ, Spark P, et al. Cesarean delivery and peripartum hysterectomy. Obstet Gynecol. Jan. 2008;111(1):97-105. X-1. [pmid: 18165397].
2921 Knight M, Nelson-Piercy C, Kurinczuk JJ, et al. A prospective national study of acute fatty liver of pregnancy in the UK. Gut. Jul. 2008;57(7):951-6. X-1. [pmid: 18332072].
2922 Knight M, Tuffnell D, Brocklehurst P, et al. Incidence and risk factors for amniotic-fluid embolism. Obstet Gynecol. May. 2010;115(5):910-7. X-1. [pmid: 20410762].
2923 Knight RL, Rice GE, Permezel M. Are alterations in plasma protease concentrations during labor associated with poor obstetric outcomes?. Am J Obstet Gynecol. Jul. 2005;193(1):283-8. X-1. [pmid: 16021091].
2924 Knox EG. Control of haemolytic disease of the newborn. Br J Prev Soc Med. Sep. 1976;30(3):163-9. X-1, X-3, X-4e, X-5. [pmid: 824003].
2925 Ko JS, Kim CS, Cho HS, et al. A randomized trial of crystalloid versus colloid solution for prevention of hypotension during spinal or low-dose combined spinal-epidural anesthesia for elective cesarean delivery. Int J Obstet Anesth. Jan. 2007;16(1):8-12. X-1, X-9. [pmid: 17125995].
2926 Ko PC, Liang CC, Chang SD, et al. A randomized controlled trial of antenatal pelvic floor exercises to prevent and treat urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2011;22(1):17-22. X-4e.
2927 Kobayashi H, Sun GW, Terao T. Urinary trypsin inhibitor down-regulates hyaluronic acid fragment-induced prostanoid release in cultured human amnion cells by inhibiting cyclo-oxygenase-2 expression. Mol Hum Reprod. Jul. 1999;5(7):662-7. X-1. [pmid: 10381822].
2928 Kocarev M, Watkins E, McLure H, et al. Sensory testing of spinal anaesthesia for caesarean section: differential block and variability. Int J Obstet Anesth. Jul. 2010;19(3):261-5. X-1, X-9. [pmid: 20627691].
2929 Kocher M, Krcova V, Cerna M, et al. Retrievable Gunther Tulip Vena Cava Filter in the prevention of pulmonary embolism in patients with acute deep venous thrombosis in perinatal period. Eur J Radiol. Apr. 2009;70(1):165-9. X-1. [pmid: 18242910].
2930 Kocylowski RD, Dubiel M, Gudmundsson S, et al. Biochemical tissue-specific injury markers of the heart and brain in postpartum cord blood. Am J Obstet Gynecol. Mar. 2009;200(3):273 e1-273 e25. X-1. [pmid: 19167692].
2931 Koelewijn JM, de Haas M, Vrijkotte TG, et al. Risk factors for RhD immunisation despite antenatal and postnatal anti-D prophylaxis. BJOG. Sep. 2009;116(10):1307-14. X-1. [pmid: 19538414].
2932 Koelewijn JM, Vrijkotte TG, de Haas M, et al. Risk factors for the presence of non-rhesus D red blood cell antibodies in pregnancy. BJOG. Apr. 2009;116(5):655-64. X-1. [pmid: 19210505].
2933 Koerber JP, Roberts GE, Whitaker R, et al. Variation in rapid sequence induction techniques: current practice in Wales. Anaesthesia. Jan. 2009;64(1):54-9. X-1. [pmid: 19087008].
2934 Kohler F, Sorensen JF, Helbo-Hansen HS. Effect of delayed supine positioning after induction of spinal anaesthesia for caesarean section. Acta Anaesthesiol Scand. Apr. 2002;46(4):441-6. X-9. [pmid: 11952447].
2935 Koifman A, Levy A, Zaulan Y, et al. The clinical significance of bleeding during the second trimester of pregnancy. Arch Gynecol Obstet. Jul. 2008;278(1):47-51. X-1. [pmid: 18066562].
2936 Koigi-Kamau R, Leting PK, Kiarie JN. Perceptions and practices of vaginal birth after Caesarean section among privately practicing obstetricians in Kenya. East Afr Med J. Dec. 2005;82(12):631-6. X-1. [pmid: 16619707].
2937 Koike T, Minakami H, Kosuge S, et al. Uterine leiomyoma in pregnancy: its influence on obstetric performance. J Obstet Gynaecol Res. Oct. 1999;25(5):309-13. X-1. [pmid: 10533324].
2938 Kok J, Tan KH, Koh S, et al. Antenatal use of a novel vaginal birth training device by term primiparous women in Singapore. Singapore Med J. Jul. 2004;45(7):318-23. X-1. [pmid: 15221047].
2939 Kok M, Bais JM, van Lith JM, et al. Nifedipine as a uterine relaxant for external cephalic version: a randomized controlled trial. Obstet Gynecol. Aug. 2008;112(2 Pt 1):271-6. X-4e. [pmid: 18669722].
2940 Kok M, Gravendeel L, Opmeer BC, et al. Expectant parents' preferences for mode of delivery and trade-offs of outcomes for breech presentation. Patient Educ Couns. Aug. 2008;72(2):305-10. X-1. [pmid: 18534810].
2941 Koken G, Cosar E, Sahin FK, et al. Attitudes towards mode of delivery and cesarean on demand in Turkey. Int J Gynaecol Obstet. Dec. 2007;99(3):233-5. X-1. [pmid: 17673239].
2942 Koklanaris N, Bonnano C, Seubert D, et al. Does raising the glucose challenge test threshold impact birthweight in Asian gravidas?. J Perinat Med. 2007;35(2):100-3. X-1. [pmid: 17302513].
2943 Kol IO, Kaygusuz K, Gursoy S, et al. The effects of intravenous ephedrine during spinal anesthesia for cesarean delivery: a randomized controlled trial. J Korean Med Sci. Oct. 2009;24(5):883-8. X-9. [pmid: 19794988].
2944 Kolas T, Oian P, Skjeldestad FE. Risks for peroperative excessive blood loss in cesarean delivery. Acta Obstet Gynecol Scand. May. 2010;89(5):658-63. X-1, X-9. [pmid: 20218934].
2945 Kolas T, Saugstad OD, Daltveit AK, et al. Planned cesarean versus planned vaginal delivery at term: comparison of newborn infant outcomes. Am J Obstet Gynecol. Dec. 2006;195(6):1538-43. X-1. [pmid: 16846577].
2946 Kolatat T, Somboonnanonda A, Lertakyamanee J, et al. Effects of general and regional anesthesia on the neonate (a prospective, randomized trial). J Med Assoc Thai. Jan. 1999;82(1):40-5. X-9. [pmid: 10087737].
2947 Kolawole IK, Fawole AA. Postoperative pain management following caesarean section in University of Ilorin Teaching Hospital (UITH), Ilorin, Nigeria. West Afr J Med. Dec. 2003;22(4):305-9. X-1, X-9. [pmid: 15008293].
2948 Kolder VE, Gallagher J, Parsons MT. Court-ordered obstetrical interventions. N Engl J Med. May. 7. 1987;316(19):1192-6. X-1. [pmid: 3574370].
2949 Kolderup L, McLean L, Grullon K, et al. Misoprostol is more efficacious for labor induction than prostaglandin E2, but is it associated with more risk?. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1543-50. X-4d. [pmid: 10368502].
2950 Kolderup LB, Laros RK Jr., Musci TJ. Incidence of persistent birth injury in macrosomic infants: association with mode of delivery. Am J Obstet Gynecol. Jul. 1997;177(1):37-41. X-1. [pmid: 9240580].
2951 Kolip P. Attitudes to cesarean delivery: the view of cesarean section mothers. Gesundheitswesen. Aug-Sep. 2008;70(8-9):e22-8. X-1. [pmid: 18785093].
2952 Kollee LA, Cuttini M, Delmas D, et al. Obstetric interventions for babies born before 28 weeks of gestation in Europe: results of the MOSAIC study. BJOG. Oct. 2009;116(11):1481-91. X-1. [pmid: 19583715].
2953 Kominiarek MA, Angelopoulos SM, Shapiro NL, et al. Low-molecular-weight heparin in pregnancy: peripartum bleeding complications. J Perinatol. Jun. 2007;27(6):329-34. X-1. [pmid: 17443203].
2954 Komoto Y, Shimoya K, Shimizu T, et al. Prospective study of non-closure or closure of the peritoneum at cesarean delivery in 124 women: Impact of prior peritoneal closure at primary cesarean on the interval time between first cesarean section and the next pregnancy and significant adhesion at second cesarean. J Obstet Gynaecol Res. Aug. 2006;32(4):396-402. X-9. [pmid: 16882265].
2955 Kongnyuy EJ, Leigh B, van den Broek N. Effect of audit and feedback on the availability, utilisation and quality of emergency obstetric care in three districts in Malawi. Women Birth. Dec. 2008;21(4):149-55. X-1, X-3, X-4e, X-5. [pmid: 18842471].
2956 Kongnyuy EJ, Mlava G, van den Broek N. A criterion based audit of the management of obstructed labour in Malawi. Arch Gynecol Obstet. May. 2009;279(5):649-54. X-1, X-3, X-4e, X-5. [pmid: 18779971].
2957 Kongnyuy EJ, Mlava G, van den Broek N. Facility-based maternal death review in three districts in the central region of Malawi: an analysis of causes and characteristics of maternal deaths. Womens Health Issues. Jan-Feb. 2009;19(1):14-20. X-1. [pmid: 19111783].
2958 Kongnyuy EJ, Nana PN, Fomulu N, et al. Adverse perinatal outcomes of adolescent pregnancies in Cameroon. Matern Child Health J. Mar. 2008;12(2):149-54. X-1. [pmid: 17562148].
2959 Konje JC, Palmer A, Watson A, et al. Early teenage pregnancies in Hull. Br J Obstet Gynaecol. Dec. 1992;99(12):969-73. X-1. [pmid: 1477018].
2960 Kono H, Lin YC, Yamaguchi M, et al. Effects of progesterone and gossypol on monoamine oxidase activity in human term placental explant. Tohoku J Exp Med. Jan. 1991;163(1):39-45. X-1. [pmid: 2048118].
2961 Koopmans CM, Bijlenga D, Aarnoudse JG, et al. Induction of labour versus expectant monitoring in women with pregnancy induced hypertension or mild preeclampsia at term: the HYPITAT trial. BMC Pregnancy Childbirth. 2007;7:14. X-4e, X-5. [pmid: 17662114].
2962 Kopic D, Sedensky M, Owen M. The impact of a teaching program on obstetric anesthesia practices in Croatia. Int J Obstet Anesth. Jan. 2009;18(1):4-9. X-1. [pmid: 18691873].
2963 Kornelsen J, Grzybowski S. Safety and community: the maternity care needs of rural parturient women. J Obstet Gynaecol Can. Jun. 2005;27(6):554-61. X-1. [pmid: 16100632].
2964 Kornelsen J, Grzybowski S, Iglesias S. Is rural maternity care sustainable without general practitioner surgeons?. Can J Rural Med. Summer. 2006;11(3):218-20. X-1, X-2. [pmid: 16914080].
2965 Kornelsen J, Hutton E, Munro S. Influences on decision making among primiparous women choosing elective caesarean section in the absence of medical indications: findings from a qualitative investigation. J Obstet Gynaecol Can. Oct. 2010;32(10):962-9. X-1. [pmid: 21176305].
2966 Koroukian SM, Bush D, Rimm AA. Comparison of cesarean section rates in fee-for-service versus managed care patients in the Ohio Medicaid population, 1992-1997. Am J Manag Care. Feb. 2001;7(2):134-42. X-1. [pmid: 11216331].
2967 Koroukian SM, Trisel B, Rimm AA. Estimating the proportion of unnecessary Cesarean sections in Ohio using birth certificate data. J Clin Epidemiol. Dec. 1998;51(12):1327-34. X-1. [pmid: 10086827].
2968 Koszalka MF Jr., Haverkamp AD, Orleans M, et al. The effects of internal electronic fetal heart rate monitoring on maternal and infant infections in high-risk pregnancies. J Reprod Med. Oct. 1982;27(10):661-5. X-4e. [pmid: 7175837].
2969 Kotake Y, Matsumoto M, Morisaki H, et al. Combination of intrathecal and intravenous fentanyl for cesarean delivery. J Anesth. 2003;17(4):277-80. X-9. [pmid: 14625718].
2970 Kotani N, Kushikata T, Hashimoto H, et al. Rebound perioperative hyperkalemia in six patients after cessation of ritodrine for premature labor. Anesth Analg. Sep. 2001;93(3):709-11. X-1. [pmid: 11524345].
2971 Kotelko DM, Rottman RL, Wright WC, et al. Transdermal scopolamine decreases nausea and vomiting following cesarean section in patients receiving epidural morphine. Anesthesiology. Nov. 1989;71(5):675-8. X-1, X-9. [pmid: 2817461].
2972 Kovavisarach E, Atthakorn M. Early versus delayed oral feeding after cesarean delivery. Int J Gynaecol Obstet. Jul. 2005;90(1):31-4. X-9. [pmid: 15923005].
2973 Kovavisarach E, Chairaj S, Tosang K, et al. Outcome of teenage pregnancy in Rajavithi Hospital. J Med Assoc Thai. Jan. 2010;93(1):1-8. X-1. [pmid: 20196404].
2974 Kovavisarach E, Jirasettasiri P. Randomised controlled trial of perineal shaving versus hair cutting in parturients on admission in labor. J Med Assoc Thai. Sep. 2005;88(9):1167-71. X-4e, X-5. [pmid: 16536100].
2975 Kovavisarach E, Sringamvong W. Enema versus no-enema in pregnant women on admission in labor: a randomized controlled trial. J Med Assoc Thai. Dec. 2005;88(12):1763-7. X-4e, X-5. [pmid: 16518971].
2976 Kovavisarach E, Vanitchanon P. Perforation in single- and double-gloving methods for cesarean section. Int J Gynaecol Obstet. Dec. 1999;67(3):157-61. X-9. [pmid: 10659898].
2977 Kowalewski M, Mujinja P, Jahn A. Can mothers afford maternal health care costs? User costs of maternity services in rural Tanzania. Afr J Reprod Health. Apr. 2002;6(1):65-73. X-1. [pmid: 12476730].
2978 Kowalska A, Niemiec T, El Midaoui A, et al. Effect of antiretroviral therapy on pregnancy outcome in HIV-1 positive women. Med Wieku Rozwoj. Oct-Dec. 2003;7(4 Pt 1):459-68. X-1, X-4e. [pmid: 15010556].
2979 Kozak LJ, Weeks JD. U.S. trends in obstetric procedures, 1990-2000. Birth. Sep. 2002;29(3):157-61. X-1. [pmid: 12153645].
2980 Kozinszky Z, Orvos H, Zoboki T, et al. Risk factors for cesarean section of primiparous women aged over 35 years. Acta Obstet Gynecol Scand. Apr. 2002;81(4):313-6. X-1. [pmid: 11952460].
2981 Kozinszky Z, Zadori J, Orvos H, et al. Obstetric and neonatal risk of pregnancies after assisted reproductive technology: a matched control study. Acta Obstet Gynecol Scand. Sep. 2003;82(9):850-6. X-1. [pmid: 12911448].
2982 Kozinszky Z, Zadori J, Orvos H, et al. Risk of cesarean section in singleton pregnancies after assisted reproductive techniques. J Reprod Med. Mar. 2003;48(3):160-4. X-1. [pmid: 12698772].
2983 Kramer RL, Gilson GJ, Morrison DS, et al. A randomized trial of misoprostol and oxytocin for induction of labor: safety and efficacy. Obstet Gynecol. Mar. 1997;89(3):387-91. X-4d. [pmid: 9052591].
2984 Kramer RL, Van Someren JK, Qualls CR, et al. Postoperative management of cesarean patients: the effect of immediate feeding on the incidence of ileus. Obstet Gynecol. Jul. 1996;88(1):29-32. X-9. [pmid: 8684757].
2985 Kraus PA, Hassan S. The young ‘elderly’ primipara revisited. Aust N Z J Obstet Gynaecol. Nov. 2001;41(4):450-2. X-1. [pmid: 11787925].
2986 Krauss DJ. Regulating women's bodies: the adverse effect of fetal rights theory on childbirth decisions and women of color. Harv Civ Rights-Civil Lib Law Rev. 1991;26(2):523-47. X-1, X-2. [pmid: 11652068].
2987 Kravitz RL, Krackhardt D, Melnikow J, et al. Networked for change? Identifying obstetric opinion leaders and assessing their opinions on caesarean delivery. Soc Sci Med. Dec. 2003;57(12):2423-34. X-1. [pmid: 14572848].
2988 Krebs L, Langhoff-Roos J. Breech delivery at term in Denmark, 1982-92: a population-based case-control study. Paediatr Perinat Epidemiol. Oct. 1999;13(4):431-41. X-1. [pmid: 10563362].
2989 Krebs L, Langhoff-Roos J, Bodker B. Are intrapartum and neonatal deaths in breech delivery at term potentially avoidable?--a blinded controlled audit. J Perinat Med. 2002;30(3):220-4. X-1. [pmid: 12122903].
2990 Krebs L, Topp M, Langhoff-Roos J. The relation of breech presentation at term to cerebral palsy. Br J Obstet Gynaecol. Sep. 1999;106(9):943-7. X-1. [pmid: 10492106].
2991 Kreutner AK, Del Bene VE, Delamar D, et al. Perioperative cephalosporin prophylaxis in cesarean section: effect on endometritis in the high-risk patient. Am J Obstet Gynecol. Aug. 15. 1979;134(8):925-35. X-9. [pmid: 380347].
2992 Kreutner AK, del Bene VE, Delamar D, et al. Perioperative antibiotic prophylaxis is cesarean section. Obstet Gynecol. Sep. 1978;52(3):279-84. X-9. [pmid: 360120].
2993 Krishnan L, Gunasekaran N, Bhaskaranand N. Anesthesia for caesarean section and immediate neonatal outcome. Indian J Pediatr. Mar-Apr. 1995;62(2):219-23. X-1, X-9. [pmid: 10829871].
2994 Krishnan L, Gunasekaran N, Bhaskaranand N. Neonatal effects of anesthesia for caesarean section. Indian J Pediatr. Jan-Feb. 1995;62(1):109-13. X-1. [pmid: 10829852].
2995 Krissel J, Dick WF, Leyser KH, et al. Thiopentone, thiopentone/ketamine, and ketamine for induction of anaesthesia in caesarean section. Eur J Anaesthesiol. Mar. 1994;11(2):115-22. X-9. [pmid: 8174531].
2996 Kristensen GB, Beiter EC, Mather O. Single-dose cefuroxime prophylaxis in non-elective cesarean section. Acta Obstet Gynecol Scand. 1990;69(6):497-500. X-9. [pmid: 2126657].
2997 Kristoffersen M, Sande HA, Sande OS. Ripening of the cervix with prostaglandin E2-gel. A randomized study with a new ready-to-use compound of triacetin-prostaglandin-E2-gel. Int J Gynaecol Obstet. Aug. 1986;24(4):297-300. X-4d, X-5. [pmid: 2878839].
2998 Kritchevsky SB, Braun BI, Gross PA, et al. Definition and adjustment of Cesarean section rates and assessments of hospital performance. Int J Qual Health Care. Aug. 1999;11(4):283-91. X-1. [pmid: 10501598].
2999 Krohn MA, Hitti J. Characteristics of women with clinical intra-amniotic infection who deliver preterm compared with term. Am J Epidemiol. Jan. 15. 1998;147(2):111-6. X-1. [pmid: 9456999].
3000 Kroll L, Twohey L, Daubeney PE, et al. Risk factors at delivery and the need for skilled resuscitation. Eur J Obstet Gynecol Reprod Biol. Jun. 30. 1994;55(3):175-7. X-1. [pmid: 7958161].
3001 Krukowski JA, Hood DD, Eisenach JC, et al. Intrathecal neostigmine for post-cesarean section analgesia: dose response. Anesth Analg. Jun. 1997;84(6):1269-75. X-9. [pmid: 9174305].
3002 Ksykiewicz-Dorota A, Adamska-Kuzmicka I. Method of Patient Classification System in obstetric staff scheduling. III. Demand for direct nursing in the delivery room among mothers who deliver by Caesarean section. Ann Univ Mariae Curie Sklodowska Med. 2001;56:307-11. X-1. [pmid: 11977331].
3003 Kucukguclu S, Unlugenc H, Gunenc F, et al. The influence of epidural volume extension on spinal block with hyperbaric or plain bupivacaine for Caesarean delivery. Eur J Anaesthesiol. Apr. 2008;25(4):307-13. X-9. [pmid: 17888192].
3004 Kuhn L, Stein ZA, Thomas PA, et al. Maternal-infant HIV transmission and circumstances of delivery. Am J Public Health. Jul. 1994;84(7):1110-5. X-1. [pmid: 8017534].
3005 Kuhnert BR, Zuspan KJ, Kuhnert PM, et al. Lack of influence of cimetidine on bupivacaine levels during parturition. Anesth Analg. Oct. 1987;66(10):986-90. X-9. [pmid: 3631597].
3006 Kuitunen M, Kukkonen K, Juntunen-Backman K, et al. Probiotics prevent IgE-associated allergy until age 5 years in cesarean-delivered children but not in the total cohort. J Allergy Clin Immunol. Feb. 2009;123(2):335-41. X-1. [pmid: 19135235].
3007 Kukulu K, Demirok H. Effects of epidural anesthesia on labor progress. Pain Manag Nurs. Mar. 2008;9(1):10-6. X-1. [pmid: 18313585].
3008 Kulas T, Habek D, Karsa M, et al. Modified Misgav Ladach method for cesarean section: clinical experience. Gynecol Obstet Invest. 2008;65(4):222-6. X-1. [pmid: 18196903].
3009 Kulier R, Gulmezoglu AM, Hofmeyr GJ, et al. Betamimetics in fetal distress: randomised controlled trial. J Perinat Med. 1997;25(1):97-100. X-9. [pmid: 9085210].
3010 Kulkarni R, Soucie JM, Lusher J, et al. Sites of initial bleeding episodes, mode of delivery and age of diagnosis in babies with haemophilia diagnosed before the age of 2 years: a report from The Centers for Disease Control and Prevention's (CDC) Universal Data Collection (UDC) project. Haemophilia. Nov. 2009;15(6):1281-90. X-1. [pmid: 19637999].
3011 Kumar A, Bala I, Bhukal I, et al. Spinal anaesthesia with lidocaine 2% for caesarean section. Can J Anaesth. Nov. 1992;39(9):915-9. X-9. [pmid: 1451219].
3012 Kumar A, Meena M, Begum N, et al. Latent celiac disease in reproductive performance of women. Fertil Steril. Mar. 1. 2011;95(3):922-7. X-1. [pmid: 21106194].
3013 Kumar N, Batra YK, Bala I, et al. Nifedipine attenuates the hypertensive response to tracheal intubation in pregnancy-induced hypertension. Can J Anaesth. Apr. 1993;40(4):329-33. X-9. [pmid: 8485793].
3014 Kumar RM, Khuranna A. Pregnancy outcome in women with beta-thalassemia major and HIV infection. Eur J Obstet Gynecol Reprod Biol. Apr. 1998;77(2):163-9. X-1. [pmid: 9578273].
3015 Kumari AS. Pregnancy outcome in women with morbid obesity. Int J Gynaecol Obstet. May. 2001;73(2):101-7. X-1. [pmid: 11336728].
3016 Kumari S, Sharma M, Yadav M, et al. Trends in neonatal outcome with low Apgar scores. Indian J Pediatr. May-Jun. 1993;60(3):415-22. X-1. [pmid: 8253491].
3017 Kundodyiwa TW, Alfirevic Z, Weeks AD. Low-dose oral misoprostol for induction of labor: a systematic review. Obstet Gynecol. Feb. 2009;113(2 Pt 1):374-83. X-1, X-2. [pmid: 19155909].
3018 Kundra P, Khanna S, Habeebullah S, et al. Manual displacement of the uterus during Caesarean section. Anaesthesia. May. 2007;62(5):460-5. X-9. [pmid: 17448057].
3019 Kunt C, Kanat-Pektas M, Gungor AN, et al. Randomized trial of vaginal prostaglandin E2 versus oxytocin for labor induction in term premature rupture of membranes. Taiwan J Obstet Gynecol. Mar. 2010;49(1):57-61. X-4d, X-5. [pmid: 20466294].
3020 Kuntz TB, Christensen RD, Stegner J, et al. Fas and Fas ligand expression in maternal blood and in umbilical cord blood in preeclampsia. Pediatr Res. Dec. 2001;50(6):743-9. X-1. [pmid: 11726734].
3021 Kuo HH, Yang JM, Wang KG. Preeclampsia in multiple pregnancy. Zhonghua Yi Xue Za Zhi (Taipei). May. 1995;55(5):392-6. X-1. [pmid: 7641125].
3022 Kuo SC, Lin KC, Hsu CH, et al. Evaluation of the effects of a birth plan on Taiwanese women's childbirth experiences, control and expectations fulfilment: a randomised controlled trial. Int J Nurs Stud. Jul. 2010;47(7):806-14. X-4a, X-5. [pmid: 20036361].
3023 Kupek E. Beyond logistic regression: structural equations modelling for binary variables and its application to investigating unobserved confounders. BMC Med Res Methodol. 2006;6:13. X-1. [pmid: 16539711].
3024 Kupferminc MJ, Tamura RK, Wigton TR, et al. Placenta accreta is associated with elevated maternal serum alpha-fetoprotein. Obstet Gynecol. Aug. 1993;82(2):266-9. X-1. [pmid: 7687756].
3025 Kuppuvelumani P, Jaradi H, Delilkan A. Abdominal nerve blockade for postoperative analgesia after caesarean section. Asia Oceania J Obstet Gynaecol. Jun. 1993;19(2):165-9. X-9. [pmid: 8379864].
3026 Kurahashi N, Kasai S, Shibata T, et al. Parental and neonatal risk factors for cryptorchidism. Med Sci Monit. Jun. 2005;11(6):CR274-283. X-1. [pmid: 15917718].
3027 Kurdi AM, Mesleh RA, Al-Hakeem MM, et al. Multiple pregnancy and preterm labor. Saudi Med J. May. 2004;25(5):632-7. X-1. [pmid: 15138532].
3028 Kurki T, Laatikainen T, Salminen-Lappalainen K, et al. Maternal plasma corticotrophin-releasing hormone--elevated in preterm labour but unaffected by indomethacin or nylidrin. Br J Obstet Gynaecol. Jul. 1991;98(7):685-91. X-1. [pmid: 1883793].
3029 Kurkinen-Raty M, Koivisto M, Jouppila P. Preterm delivery for maternal or fetal indications: maternal morbidity, neonatal outcome and late sequelae in infants. BJOG. May. 2000;107(5):648-55. X-1. [pmid: 10826581].
3030 Kutteh WH. Antiphospholipid antibody-associated recurrent pregnancy loss: treatment with heparin and low-dose aspirin is superior to low-dose aspirin alone. Am J Obstet Gynecol. May. 1996;174(5):1584-9. X-4e, X-5. [pmid: 9065133].
3031 Kvale JK. Maternal and neonatal outcomes associated with selected intrapartum interventions. PH.D. 1994:222. X-1.
3032 Kvetny J, Poulsen HF. Incidence of gestational hypertension in gestational diabetes mellitus. Arch Gynecol Obstet. Jan. 2003;267(3):153-7. X-1. [pmid: 12552326].
3033 Kwawukume EY. Caesarean myomectomy. Afr J Reprod Health. Dec. 2002;6(3):38-43. X-1. [pmid: 12685407].
3034 Kwee A, Bots ML, Visser GH, et al. Uterine rupture and its complications in the Netherlands: a prospective study. Eur J Obstet Gynecol Reprod Biol. Sep-Oct. 2006;128(1-2):257-61. X-1. [pmid: 16530918].
3035 Kwee A, Bots ML, Visser GH, et al. Obstetric management and outcome of pregnancy in women with a history of caesarean section in the Netherlands. Eur J Obstet Gynecol Reprod Biol. Jun. 2007;132(2):171-6. X-1. [pmid: 16904813].
3036 Kwee A, Cohlen BJ, Kanhai HH, et al. Caesarean section on request: a survey in The Netherlands. Eur J Obstet Gynecol Reprod Biol. Apr. 15. 2004;113(2):186-90. X-1. [pmid: 15063958].
3037 Kwon JS, Davies GA, Mackenzie VP. A comparison of oral and vaginal misoprostol for induction of labour at term: a randomised trial. BJOG. Jan. 2001;108(1):23-6. X-4d. [pmid: 11212999].
3038 Kyokong O, Charuluxananan S, Pothimamaka S, et al. Hypotension in spinal anesthesia for cesarean section: a comparison of 0.5% hyperbaric bupivacaine and 5% hyperbaric lidocaine. J Med Assoc Thai. Jun. Suppl 1. 2001;84:S256-62. X-9. [pmid: 11529341].
3039 Laatikainen T, Ikonen E. Fetal prognosis in obstetric hepatosis. Ann Chir Gynaecol Fenn. 1975;64(3):155-64. X-1. [pmid: 1217841].
3040 Ladfors L, Mattsson LA, Eriksson M, et al. A randomised trial of two expectant managements of prelabour rupture of the membranes at 34 to 42 weeks. Br J Obstet Gynaecol. Aug. 1996;103(8):755-62. X-4e. [pmid: 8760703].
3041 Ladfors L, Tessin I, Mattsson LA, et al. Risk factors for neonatal sepsis in offspring of women with prelabor rupture of the membranes at 34-42 weeks. J Perinat Med. 1998;26(2):94-101. X-1, X-4e. [pmid: 9650129].
3042 Lafayette RA, Malik T, Druzin M, et al. The dynamics of glomerular filtration after Caesarean section. J Am Soc Nephrol. Jul. 1999;10(7):1561-5. X-1. [pmid: 10405212].
3043 Lagrew DC Jr., Adashek JA. Lowering the cesarean section rate in a private hospital: comparison of individual physicians' rates, risk factors, and outcomes. Am J Obstet Gynecol. Jun. 1998;178(6):1207-14. X-1. [pmid: 9662303].
3044 Lagrew DC, Bush MC, McKeown AM, et al. Emergent (crash) cesarean delivery: indications and outcomes. Am J Obstet Gynecol. Jun. 2006;194(6):1638-43. discussion 1643. X-1. [pmid: 16731082].
3045 Lagrew DC Jr., Morgan MA, Nakamoto K, et al. Advanced maternal age: perinatal outcome when controlling for physician selection. J Perinatol. Jul-Aug. 1996;16(4):256-60. X-1. [pmid: 8866293].
3046 Lai ML, Lin KC, Li HY, et al. Effects of delayed pushing during the second stage of labor on postpartum fatigue and birth outcomes in nulliparous women. J Nurs Res. Mar. 2009;17(1):62-72. X-1. [pmid: 19352230].
3047 Laishley RS, Morgan BM. A single dose epidural technique for caesarean section. A comparison between 0.5% bupivacaine plain and 0.5% bupivacaine with adrenaline. Anaesthesia. Feb. 1988;43(2):100-3. X-9. [pmid: 3354801].
3048 Laishley RS, Morgan BM, Reynolds F. Effect of adrenaline on extradural anaesthesia and plasma bupivacaine concentrations during caesarean section. Br J Anaesth. Feb. 1988;60(2):180-6. X-9. [pmid: 3345279].
3049 Lal K, Tsomo P. Comparative study of single layer and conventional closure of uterine incision in cesarean section. Int J Gynaecol Obstet. Dec. 1988;27(3):349-52. X-9. [pmid: 2904896].
3050 Lam DT, Ngan Kee WD, Khaw KS. Extension of epidural blockade in labour for emergency Caesarean section using 2% lidocaine with epinephrine and fentanyl, with or without alkalinisation. Anaesthesia. Aug. 2001;56(8):790-4. X-9. [pmid: 11493247].
3051 Lam FY, Broome IJ, Matthews PJ. A comparison of postoperative analgesia following spinal or epidural anaesthesia for caesarean section. Anaesthesia. Jan. 1994;49(1):65-7. X-9. [pmid: 8311216].
3052 Lambalk CB, van Hooff M. Natural versus induced twinning and pregnancy outcome: a Dutch nationwide survey of primiparous dizygotic twin deliveries. Fertil Steril. Apr. 2001;75(4):731-6. X-1. [pmid: 11287027].
3053 Lambert JS, Nogueira SA, Abreu T, et al. A pilot study to evaluate the safety and feasibility of the administration of AZT/3TC fixed dose combination to HIV infected pregnant women and their infants in Rio de Janeiro, Brazil. Sex Transm Infect. Dec. 2003;79(6):448-52. X-1. [pmid: 14663118].
3054 Lamont RF, Morgan DJ, Logue M, et al. A prospective randomised trial to compare the efficacy and safety of hemabate and syntometrine for the prevention of primary postpartum haemorrhage. Prostaglandins Other Lipid Mediat. Oct. 2001;66(3):203-10. X-1, X-2, X-3, X-4e, X-5. [pmid: 11577783].
3055 Lamont RF, Pinney D, Rodgers P, et al. Continuous versus intermittent epidural analgesia. A randomised trial to observe obstetric outcome. Anaesthesia. Nov. 1989;44(11):893-6. X-4e. [pmid: 2688475].
3056 Lamont RF, Taylor-Robinson D, Newman M, et al. Spontaneous early preterm labour associated with abnormal genital bacterial colonization. Br J Obstet Gynaecol. Aug. 1986;93(8):804-10. X-1. [pmid: 3741809].
3057 Lanari M, Adorni F, Silvestri M, et al. The multicenter Italian birth cohort study on incidence and determinants of lower respiratory tract infection hospitalization in infants at 33 weeks GA or more: preliminary results. Early Hum Dev. Mar. Suppl 1. 2011;87:S43-6. X-4e. [pmid: 21277122].
3058 Land R, Parry E, Rane A, et al. Personal preferences of obstetricians towards childbirth. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):249-52. X-1. [pmid: 11592537].
3059 Landau R, Kraft JC, Flint LY, et al. An experimental paradigm for the prediction of Post-Operative Pain (PPOP). J Vis Exp. 2010;(35). X-1, X-2.
3060 Landau R, Schiffer E, Morales M, et al. The dose-sparing effect of clonidine added to ropivacaine for labor epidural analgesia. Anesth Analg. Sep. 2002;95(3):728-34. table of contents. X-4e, X-5. [pmid: 12198061].
3061 Landon MB, Gabbe SG. Antepartum fetal surveillance in gestational diabetes mellitus. Diabetes. Jun. Suppl 2. 1985;34:50-4. X-1. [pmid: 3888742].
3062 Landon MB, Gabbe SG. Glucose monitoring and insulin administration in the pregnant diabetic patient. Clin Obstet Gynecol. Sep. 1985;28(3):496-506. X-1, X-2. [pmid: 3902303].
3063 Landon MB, Gabbe SG, Sachs L. Management of diabetes mellitus and pregnancy: a survey of obstetricians and maternal-fetal specialists. Obstet Gynecol. Apr. 1990;75(4):635-40. X-1. [pmid: 2179778].
3064 Landon MB, Hauth JC, Leveno KJ, et al. Maternal and perinatal outcomes associated with a trial of labor after prior cesarean delivery. N Engl J Med. Dec. 16. 2004;351(25):2581-9. X-1. [pmid: 15598960].
3065 Landon MB, Leindecker S, Spong CY, et al. The MFMU Cesarean Registry: factors affecting the success of trial of labor after previous cesarean delivery. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1016-23. X-1. [pmid: 16157104].
3066 Landon MB, Spong CY, Thom E, et al. A multicenter, randomized trial of treatment for mild gestational diabetes. N Engl J Med. Oct. 1. 2009;361(14):1339-48. X-1. [pmid: 19797280].
3067 Landon MB, Spong CY, Thom E, et al. Risk of uterine rupture with a trial of labor in women with multiple and single prior cesarean delivery. Obstet Gynecol. Jul. 2006;108(1):12-20. X-1. [pmid: 16816050].
3068 Landon MJ, Creagh-Barry P, McArthur S, et al. Influence of vitamin B12 status on the inactivation of methionine synthase by nitrous oxide. Br J Anaesth. Jul. 1992;69(1):81-6. X-1. [pmid: 1637609].
3069 Landry DP, Bennett FM, Oriol NE. Analysis of heart rate dynamics as a measure of autonomic tone in obstetrical patients undergoing epidural or spinal anesthesia. Reg Anesth. May-Jun. 1994;19(3):189-95. X-1. [pmid: 7999654].
3070 Lane S, Evans P, Arfeen Z, et al. A comparison of intrathecal fentanyl and diamorphine as adjuncts in spinal anaesthesia for Caesarean section. Anaesthesia. May. 2005;60(5):453-7. X-9. [pmid: 15819765].
3071 Lang CT, King JC. Maternal mortality in the United States. Best Pract Res Clin Obstet Gynaecol. Jun. 2008;22(3):517-31. X-1, X-2. [pmid: 18182328].
3072 Lange AP, Secher NJ, Nielsen FH, et al. Stimulation of labor in cases of premature rupture of the membranes at or near term. A consecutive randomized study of prostaglandin E2-tablets and intravenous oxytocin. Acta Obstet Gynecol Scand. 1981;60(2):207-10. X-4e. [pmid: 7018166].
3073 Lange IR, Collister C, Johnson J, et al. The effect of vaginal prostaglandin E2 pessaries on induction of labor. Am J Obstet Gynecol. Mar. 1. 1984;148(5):621-5. X-4d, X-4e, X-5. [pmid: 6584028].
3074 Langenveld J, Buttinger A, van der Post J, et al. Recurrence risk and prediction of a delivery under 34 weeks of gestation after a history of a severe hypertensive disorder. BJOG. Apr. 2011;118(5):589-95. X-1. [pmid: 21291508].
3075 Langer A, Campero L, Garcia C, et al. Effects of psychosocial support during labour and childbirth on breastfeeding, medical interventions, and mothers' wellbeing in a Mexican public hospital: a randomised clinical trial. Br J Obstet Gynaecol. Oct. 1998;105(10):1056-63. X-5. [pmid: 9800927].
3076 Langer M, Czermak B, Ringler M. Couple relationship, birth preparation and pregnancy outcome: a prospective controlled study. J Perinat Med. 1990;18(3):201-8. X-1, X-4e, X-5. [pmid: 2384843].
3077 Langer O, Mazze R. The relationship between large-for-gestational-age infants and glycemic control in women with gestational diabetes. Am J Obstet Gynecol. Dec. 1988;159(6):1478-83. X-1. [pmid: 3207126].
3078 Langer O, Rodriguez DA, Xenakis EM, et al. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. Apr. 1994;170(4):1036-46. discussion 1046-7. X-1. [pmid: 8166187].
3079 Langer O, Yogev Y, Xenakis EM, et al. Overweight and obese in gestational diabetes: the impact on pregnancy outcome. Am J Obstet Gynecol. Jun. 2005;192(6):1768-76. X-1. [pmid: 15970805].
3080 Langesaeter E, Rosseland LA, Stubhaug A. Continuous invasive blood pressure and cardiac output monitoring during cesarean delivery: a randomized, double-blind comparison of low-dose versus high-dose spinal anesthesia with intravenous phenylephrine or placebo infusion. Anesthesiology. Nov. 2008;109(5):856-63. X-9. [pmid: 18946298].
3081 Langesaeter E, Rosseland LA, Stubhaug A. Haemodynamic effects of repeated doses of oxytocin during Caesarean delivery in healthy parturients. Br J Anaesth. Aug. 2009;103(2):260-2. X-1. [pmid: 19502285].
3082 Langhoff-Roos J, Lindmark G. Obstetric interventions and perinatal asphyxia in growth retarded term infants. Acta Obstet Gynecol Scand Suppl. 1997;165:39-43. X-1. [pmid: 9219455].
3083 Langslow A. The dangers of refusing a blood transfusion. Aust Nurs J. May. 1998;5(10):38-9. X-1. [pmid: 10639954].
3084 Lao TT, Halpern SH, Crosby ET, et al. Uterine incision and maternal blood loss in preterm caesarean section. Arch Gynecol Obstet. 1993;252(3):113-7. X-1. [pmid: 8503702].
3085 Lao TT, Ho LF. Obstetric outcome of teenage pregnancies. Hum Reprod. Nov. 1998;13(11):3228-32. X-1. [pmid: 9853885].
3086 Lao TT, Huengsburg M. Labour and delivery in mothers with asthma. Eur J Obstet Gynecol Reprod Biol. May-Jun. 1990;35(2-3):183-90. X-1. [pmid: 2335253].
3087 Lapaire O, Irion O, Koch-Holch A, et al. Increased peri- and post-elective cesarean section morbidity in women infected with human immunodeficiency virus-1: a case-controlled multicenter study. Arch Gynecol Obstet. Jun. 2006;274(3):165-9. X-1. [pmid: 16715290].
3088 Lapaire O, Schneider MC, Stotz M, et al. Oral misoprostol vs. intravenous oxytocin in reducing blood loss after emergency cesarean delivery. Int J Gynaecol Obstet. Oct. 2006;95(1):2-7. X-3, X-4e. [pmid: 16934269].
3089 Lapolla A, Dalfra MG, Bonomo M, et al. Gestational diabetes mellitus in Italy: a multicenter study. Eur J Obstet Gynecol Reprod Biol. Aug. 2009;145(2):149-53. X-1. [pmid: 19467766].
3090 Lapolla A, Marangon M, Dalfra MG, et al. Pregnancy outcome in morbidly obese women before and after laparoscopic gastric banding. Obes Surg. Sep. 2010;20(9):1251-7. X-1. [pmid: 20524157].
3091 LaPorta RF, Arthur GR, Datta S. Phenylephrine in treating maternal hypotension due to spinal anaesthesia for caesarean delivery: effects on neonatal catecholamine concentrations, acid base status and Apgar scores. Acta Anaesthesiol Scand. Oct. 1995;39(7):901-5. X-9. [pmid: 8848889].
3092 LaPorta-Krum L, Mueller A, Jorg M, et al. Effects of Pregnancy and Delivery on Pelvic Floor Muscles: MRI Comparisons of Vaginal and Caesarean Birth Versus Nulliparous Controls. Journal of Women's Health Physical Therapy. 2011. Jan-Apr. 2011;35(1):20-20. X-1.
3093 Lappas M, Permezel M, Rice GE. Leptin and adiponectin stimulate the release of proinflammatory cytokines and prostaglandins from human placenta and maternal adipose tissue via nuclear factor-kappaB, peroxisomal proliferator-activated receptor-gamma and extracellularly regulated kinase 1/2. Endocrinology. Aug. 2005;146(8):3334-42. X-1. [pmid: 15905315].
3094 Lappas M, Yee K, Permezel M, et al. Release and regulation of leptin, resistin and adiponectin from human placenta, fetal membranes, and maternal adipose tissue and skeletal muscle from normal and gestational diabetes mellitus-complicated pregnancies. J Endocrinol. Sep. 2005;186(3):457-65. X-1. [pmid: 16135665].
3095 Larmon JE, Magann EF, Dickerson GA, et al. Outpatient cervical ripening with prostaglandin E2 and estradiol. J Matern Fetal Neonatal Med. Feb. 2002;11(2):113-7. X-4d, X-5. [pmid: 12375540].
3096 LaRosa JA, Saywell RM Jr., Zollinger TW, et al. The incidence of adynamic ileus in postcesarean patients. Patient-controlled analgesia versus intramuscular analgesia. J Reprod Med. Apr. 1993;38(4):293-300. X-1. [pmid: 8501738].
3097 Larque E, Demmelmair H, Berger B, et al. In vivo investigation of the placental transfer of (13)C-labeled fatty acids in humans. J Lipid Res. Jan. 2003;44(1):49-55. X-1. [pmid: 12518022].
3098 Larson JD, Rayburn WF, Crosby S, et al. Multiple nuchal cord entanglements and intrapartum complications. Am J Obstet Gynecol. Oct. 1995;173(4):1228-31. X-1. [pmid: 7485326].
3099 Larsson C, Kallen K, Andolf E. Cesarean section and risk of pelvic organ prolapse: a nested case-control study. Am J Obstet Gynecol. Mar. 2009;200(3):243 e1-4. X-1. [pmid: 19254581].
3100 LaSala AP, Berkeley AS. Primary cesarean section and subsequent fertility. Am J Obstet Gynecol. Aug. 1987;157(2):379-83. X-1. [pmid: 3618689].
3101 Lashen H, Fear K, Sturdee D. Trends in the management of the breech presentation at term; experience in a District General hospital over a 10-year period. Acta Obstet Gynecol Scand. Dec. 2002;81(12):1116-22. X-1. [pmid: 12519107].
3102 Lasley DS, Eblen A, Yancey MK, et al. The effect of placental removal method on the incidence of postcesarean infections. Am J Obstet Gynecol. Jun. 1997;176(6):1250-4. X-9. [pmid: 9215181].
3103 Latham SR, Norwitz ER. Ethics and “cesarean delivery on maternal demand”. Semin Perinatol. Dec. 2009;33(6):405-9. X-1, X-2. [pmid: 19914526].
3104 Latto IP, Waldron BA. Anaesthesia for Caesarean section. Analysis of blood concentrations of halothane using 0.2% or 0.65% halothane with 50% nitrous oxide in oxygen. Br J Anaesth. Apr. 1977;49(4):371-8. X-9. [pmid: 889651].
3105 Lattuada D, Colleoni F, Martinelli A, et al. Higher mitochondrial DNA content in human IUGR placenta. Placenta. Dec. 2008;29(12):1029-33. X-1. [pmid: 19007984].
3106 Lau LC, Adaikan PG, Arulkumaran S, et al. Oxytocics reverse the tocolytic effect of glyceryl trinitrate on the human uterus. BJOG. Feb. 2001;108(2):164-8. X-1. [pmid: 11236116].
3107 Lau TK, Wong SH, Li CY. A study of patients' acceptance towards vaginal birth after caesarean section. Aust N Z J Obstet Gynaecol. May. 1996;36(2):155-8. X-1. [pmid: 8798303].
3108 Laudenbach V, Mercier FJ, Roze JC, et al. Anaesthesia mode for caesarean section and mortality in very preterm infants: an epidemiologic study in the EPIPAGE cohort. Int J Obstet Anesth. Apr. 2009;18(2):142-9. X-1. [pmid: 19195873].
3109 Laughon SK, Wolfe HM, Visco AG. Prior cesarean and the risk for placenta previa on second-trimester ultrasonography. Obstet Gynecol. May. 2005;105(5 Pt 1):962-5. X-1. [pmid: 15863531].
3110 Lavand'homme PM, Roelants F, Waterloos H, et al. An evaluation of the postoperative antihyperalgesic and analgesic effects of intrathecal clonidine administered during elective cesarean delivery. Anesth Analg. Sep. 2008;107(3):948-55. X-9. [pmid: 18713912].
3111 Lavand'homme PM, Roelants F, Waterloos H, et al. Postoperative analgesic effects of continuous wound infiltration with diclofenac after elective cesarean delivery. Anesthesiology. Jun. 2007;106(6):1220-5. X-9. [pmid: 17525598].
3112 Lavender T, Kingdon C. Primigravid women's views of being approached to participate in a hypothetical term cephalic trial of planned vaginal birth versus planned cesarean birth. Birth. Sep. 2009;36(3):213-9. X-1. [pmid: 19747268].
3113 Lavender T, Kingdon C, Hart A, et al. Birth method: trial and error?. Pract Midwife. Oct. 2006;9(9):12-6. X-1, X-4b. [pmid: 17069081].
3114 Lavender T, Kingdon C, Hart A, et al. Could a randomised trial answer the controversy relating to elective caesarean section? National survey of consultant obstetricians and heads of midwifery. BMJ. Sep. 3. 2005;331(7515):490-1. X-1. [pmid: 16115829].
3115 Lavender T, Walkinshaw S. Open dialogue. A conflict of outcomes. British Journal of Midwifery. 1998;6(4):209-209. X-2.
3116 Lavender T, Wallymahmed AH, Walkinshaw SA. Managing labor using partograms with different action lines: a prospective study of women's views. Birth. Jun. 1999;26(2):89-96. X-1, X-4e, X-5. [pmid: 10687572].
3117 Lavery JP, Huang KC, Koontz WL, et al. Mezlocillin prophylaxis against infection after cesarean section: a comparison of techniques. South Med J. Oct. 1986;79(10):1248-51. X-9. [pmid: 3764522].
3118 Lavery JP, Marcell CC, Walker R. An association between ureaplasma urealyticum and endomyometritis after cesarean section. J Ky Med Assoc. Jul. 1985;83(7):359-62. X-3, X-4e. [pmid: 3894550].
3119 Lavies NG, Meiklejohn BH, May AE, et al. Hypertensive and catecholamine response to tracheal intubation in patients with pregnancy-induced hypertension. Br J Anaesth. Oct. 1989;63(4):429-34. X-1. [pmid: 2818920].
3120 Lavin JP Jr., Lovelace DR, Miodovnik M, et al. Clinical experience with one hundred seven diabetic pregnancies. Am J Obstet Gynecol. Dec. 1. 1983;147(7):742-52. X-1. [pmid: 6650594].
3121 Law AC, Lam KK, Irwin MG. The effect of right versus left lateral decubitus positions on induction of spinal anesthesia for cesarean delivery. Anesth Analg. Dec. 2003;97(6):1795-9. X-9. [pmid: 14633562].
3122 Law LW, Pang MW, Chung TK, et al. Randomised trial of assigned mode of delivery after a previous cesarean section--impact on maternal psychological dynamics. J Matern Fetal Neonatal Med. Oct. 2010;23(10):1106-13. X-5. [pmid: 20088723].
3123 Law YY, Lam KY. A randomized controlled trial comparing midwife-managed care and obstetrician-managed care for women assessed to be at low risk in the initial intrapartum period. J Obstet Gynaecol Res. Apr. 1999;25(2):107-12. X-4e, X-5. [pmid: 10379125].
3124 Lawes EG, Duncan PW, Bland B, et al. The cricoid yoke--a device for providing consistent and reproducible cricoid pressure. Br J Anaesth. Aug. 1986;58(8):925-31. X-9. [pmid: 3730239].
3125 Lawes EG, Newman B, Campbell MJ, et al. Maternal inspired oxygen concentration and neonatal status for caesarean section under general anaesthesia. Comparison of effects of 33% or 50% oxygen in nitrous oxide. Br J Anaesth. Sep. 1988;61(3):250-4. X-9. [pmid: 3140860].
3126 Lawhorn CD, McNitt JD, Fibuch EE, et al. Epidural morphine with butorphanol for postoperative analgesia after cesarean delivery. Anesth Analg. Jan. 1991;72(1):53-7. X-9. [pmid: 1984377].
3127 Lawoyin TO. A prospective study on some factors which influence the delivery of large babies. J Trop Med Hyg. Dec. 1993;96(6):352-6. X-1. [pmid: 8254713].
3128 Lawrie TA, de Jager M, Hofmeyr GJ. High cesarean section rates for pregnant medical practitioners in South Africa. Int J Gynaecol Obstet. Jan. 2001;72(1):71-3. X-1, X-4e, X-5. [pmid: 11146080].
3129 Lawrie TA, Hofmeyr GJ, De Jager M, et al. A double-blind randomised placebo controlled trial of postnatal norethisterone enanthate: the effect on postnatal depression and serum hormones. Br J Obstet Gynaecol. Oct. 1998;105(10):1082-90. X-3, X-4e. [pmid: 9800931].
3130 Laye MR, Dellinger EH. Timing of scheduled cesarean delivery in patients on a teaching versus private service: adherence to American College of Obstetricians and Gynecologists guidelines and neonatal outcomes. Am J Obstet Gynecol. Aug. 2006;195(2):577-82. discussion 582-4. X-1. [pmid: 16777051].
3131 Lazar P, Gueguen S, Dreyfus J, et al. Multicentred controlled trial of cervical cerclage in women at moderate risk of preterm delivery. Br J Obstet Gynaecol. Aug. 1984;91(8):731-5. X-4e, X-5. [pmid: 6380565].
3132 Lazer S, Biale Y, Mazor M, et al. Complications associated with the macrosomic fetus. J Reprod Med. Jun. 1986;31(6):501-5. X-1. [pmid: 3735262].
3133 Lazor LZ, Philipson EH, Ingardia CJ, et al. A randomized comparison of 15- and 40-minute dosing protocols for labor augmentation and induction. Obstet Gynecol. Dec. 1993;82(6):1009-12. X-5. [pmid: 8233251].
3134 Le Guen H, Roy D, Branger B, et al. Comparison of fentanyl and sufentanil in combination with bupivacaine for patient-controlled epidural analgesia during labor. J Clin Anesth. Mar. 2001;13(2):98-102. X-4e, X-5. [pmid: 11331168].
3135 Le Ray C, Carayol M, Breart G, et al. Elective induction of labor: failure to follow guidelines and risk of cesarean delivery. Acta Obstet Gynecol Scand. 2007;86(6):657-65. X-1. [pmid: 17520395].
3136 Le Ray C, Serres P, Schmitz T, et al. Manual rotation in occiput posterior or transverse positions: risk factors and consequences on the cesarean delivery rate. Obstet Gynecol. Oct. 2007;110(4):873-9. X-1. [pmid: 17906022].
3137 le Roux PA, Olarogun JO, Penny J, et al. Oral and vaginal misoprostol compared with dinoprostone for induction of labor: a randomized controlled trial. Obstet Gynecol. Feb. 2002;99(2):201-5. X-4d, X-5. [pmid: 11814497].
3138 Leach CL, Fuhrman BP, Morin FC 3rd, et al. Perfluorocarbon-associated gas exchange (partial liquid ventilation) in respiratory distress syndrome: a prospective, randomized, controlled study. Crit Care Med. Sep. 1993;21(9):1270-8. X-3, X-4, X-5. [pmid: 8370289].
3139 Leach JD. C-sections, breastfeeding and bugs for your baby: what the doctor probably won't tell you. Midwifery Today Int Midwife. Autumn. 2006;(79):12-3. X-1, X-2. [pmid: 17024888].
3140 Leach L, Sproule V. Meeting the challenge of cesarean births. JOGN Nurs. May-Jun. 1984;13(3):191-5. X-1, X-2. [pmid: 6563205].
3141 Learmont JG, Poston L. Nitric oxide is involved in flow-induced dilation of isolated human small fetoplacental arteries. Am J Obstet Gynecol. Feb. 1996;174(2):583-8. X-1. [pmid: 8623789].
3142 Leavine BA. Court-ordered cesareans: can a pregnant woman refuse?. Houst Law Rev. Spring. 1992;29(1):185-218. X-1. [pmid: 11656666].
3143 Leavitt BG, Huff DL, Bell LA, et al. Placental drainage of fetal blood at cesarean delivery and feto maternal transfusion: a randomized controlled trial. Obstet Gynecol. Sep. 2007;110(3):608-11. X-9. [pmid: 17766607].
3144 Lebel DE, Levy A, Holcberg G, et al. Symphysiolysis as an independent risk factor for cesarean delivery. J Matern Fetal Neonatal Med. May. 2010;23(5):417-20. X-1. [pmid: 20199196].
3145 Leclair MD, El-Ghoneimi A, Audry G, et al. The outcome of prenatally diagnosed renal tumors. J Urol. Jan. 2005;173(1):186-9. X-1. [pmid: 15592071].
3146 Ledger WJ. Hospital infections: gynecologic, obstetric, and perinatal infections. Ann Intern Med. Nov. 1978;89(5 Pt 2 Suppl):774-6. X-1, X-2. [pmid: 717952].
3147 Ledowski T, Paech MJ, Browning R, et al. An observational study of skin conductance monitoring as a means of predicting hypotension from spinal anaesthesia for caesarean delivery. Int J Obstet Anesth. Jul. 2010;19(3):282-6. X-1. [pmid: 20605437].
3148 Lee A, McKeown D, Wilson J. Evaluation of the efficacy of elastic compression stockings in prevention of hypotension during epidural anaesthesia for elective caesarean section. Acta Anaesthesiol Scand. Apr. 1987;31(3):193-5. X-3, X-4b. [pmid: 3577640].
3149 Lee AH, Fung WK, Fu B. Analyzing hospital length of stay: mean or median regression?. Med Care. May. 2003;41(5):681-6. X-1. [pmid: 12719692].
3150 Lee B. Normal birth--is it possible in the 21st century?. RCM Midwives. Sep. 2004;7(9):396-8. X-1, X-2, X-3, X-4e, X-5. [pmid: 15739738].
3151 Lee BB, Ngan Kee WD, Ng FF, et al. Epidural infusions of ropivacaine and bupivacaine for labor analgesia: a randomized, double-blind study of obstetric outcome. Anesth Analg. Apr. 2004;98(4):1145-52. table of contents. X-4e, X-5. [pmid: 15041615].
3152 Lee CH, Huang N, Chang HJ, et al. The immediate effects of the severe acute respiratory syndrome (SARS) epidemic on childbirth in Taiwan. BMC Public Health. Apr. 4. 2005;5:30. X-1. [pmid: 15804368].
3153 Lee DH, Kwon IC. Magnesium sulphate has beneficial effects as an adjuvant during general anaesthesia for Caesarean section. Br J Anaesth. Dec. 2009;103(6):861-6. X-9. [pmid: 19783538].
3154 Lee G. Worst case scenario. Supporting women who refuse a caesarean section. Pract Midwife. Jul-Aug. 1998;1(7-8):28-9. X-1, X-2, X-3, X-4e, X-5.
3155 Lee J, Croen LA, Backstrand KH, et al. Maternal and infant characteristics associated with perinatal arterial stroke in the infant. JAMA. Feb. 9. 2005;293(6):723-9. X-1. [pmid: 15701914].
3156 Lee KA, Gay CL. Sleep in late pregnancy predicts length of labor and type of delivery. Am J Obstet Gynecol. Dec. 2004;191(6):2041-6. X-1. [pmid: 15592289].
3157 Lee KY, McGreevey C. Using comparison charts to assess performance measurement data. Jt Comm J Qual Improv. Mar. 2002;28(3):129-38. X-1. [pmid: 11902028].
3158 Lee LH, Irwin MG, Lim J, et al. The effect of celecoxib on intrathecal morphine-induced pruritus in patients undergoing Caesarean section. Anaesthesia. Sep. 2004;59(9):876-80. X-9. [pmid: 15310350].
3159 Lee LY, Holroyd E, Ng CY. Exploring factors influencing Chinese women's decision to have elective caesarean surgery. Midwifery. Dec. 2001;17(4):314-22. X-1. [pmid: 11749064].
3160 Lee MJ, Conner EL, Charafeddine L, et al. A critical birth weight and other determinants of survival for infants with severe intrauterine growth restriction. Ann N Y Acad Sci. Sep. 2001;943:326-39. X-1. [pmid: 11594552].
3161 Lee SD, Lo KJ, Tsai YT, et al. Role of caesarean section in prevention of mother-infant transmission of hepatitis B virus. Lancet. Oct. 8. 1988;2(8615):833-4. X-1. [pmid: 2902274].
3162 Lee SI, Khang YH, Lee MS. Women's attitudes toward mode of delivery in South Korea--a society with high cesarean section rates. Birth. Jun. 2004;31(2):108-16. X-1. [pmid: 15153130].
3163 Lee SS, Lao TT. Cord blood thyrotrophin and foetal presentation at delivery in singleton pregnancies. Gynecol Obstet Invest. 1997;43(2):94-7. X-1. [pmid: 9067714].
3164 LeFevre ML, Bain RP, Ewigman BG, et al. A randomized trial of prenatal ultrasonographic screening: impact on maternal management and outcome. RADIUS (Routine Antenatal Diagnostic Imaging with Ultrasound) Study Group. Am J Obstet Gynecol. Sep. 1993;169(3):483-9. X-5. [pmid: 8372849].
3165 Legarth J, Guldbaek E, Scher NJ. The efficiency of prostaglandin E2 vaginal suppositories versus intracervical prostaglandin gel for induction of labor in patients with unfavorable inducibility prospects. Eur J Obstet Gynecol Reprod Biol. Feb. 1988;27(2):93-8. X-4d, X-5. [pmid: 3277875].
3166 Lehavi A, Abecasis P, Weissman A, et al. Subarachnoid block with hyperbaric bupivacaine and morphine may shorten PACU stay after cesarean delivery. J Perianesth Nurs. Dec. 2010;25(6):371-9. X-9. [pmid: 21126667].
3167 Lehmann S, Bordahl PE, Rasmussen SA, et al. Norwegian midwives and doctors have increased cesarean section rates. Acta Obstet Gynecol Scand. 2007;86(9):1087-9. X-1. [pmid: 17712649].
3168 Leigh B, Mwale TG, Lazaro D, et al. Emergency obstetric care: how do we stand in Malawi?. Int J Gynaecol Obstet. Apr. 2008;101(1):107-11. X-1. [pmid: 18291400].
3169 Leighton BL, Halpern SH, Wilson DB. Lumbar sympathetic blocks speed early and second stage induced labor in nulliparous women. Anesthesiology. Apr. 1999;90(4):1039-46. X-4d. [pmid: 10201675].
3170 Leiserowitz GS, Xing G, Cress R, et al. Adnexal masses in pregnancy: how often are they malignant?. Gynecol Oncol. May. 2006;101(2):315-21. X-1. [pmid: 16310839].
3171 Lejeune VN, Chaplet VM, Carbonne B, et al. Precarity and pregnancy in Paris. Eur J Obstet Gynecol Reprod Biol. Mar. 1999;83(1):27-30. X-1. [pmid: 10221606].
3172 Lelaidier C, Baton C, Benifla JL, et al. Mifepristone for labour induction after previous caesarean section. Br J Obstet Gynaecol. Jun. 1994;101(6):501-3. X-4b, X-4e. [pmid: 8018638].
3173 Lenaway DD. Evaluation of a public-private certified nurse-midwife maternity program for indigent women. PH.D. 1995:77. X-1.
3174 Lenihan JP Jr. Relationship of antepartum pelvic examinations to premature rupture of the membranes. Obstet Gynecol. Jan. 1984;63(1):33-7. X-1. [pmid: 6691015].
3175 Lenke RR, Hatch EI Jr. Fetal gastroschisis: a preliminary report advocating the use of cesarean section. Obstet Gynecol. Mar. 1986;67(3):395-8. X-1. [pmid: 2935763].
3176 Lennox CE, Kwast BE. The partograph in community obstetrics. Trop Doct. Apr. 1995;25(2):56-63. X-2. [pmid: 7778195].
3177 Lennox CE, Kwast BE, Farley TM. Breech labor on the WHO partograph. Int J Gynaecol Obstet. Aug. 1998;62(2):117-27. X-4c. [pmid: 9749882].
3178 Lennox-King SM, O'Farrell SM, Bettelheim KA, et al. Escherichia coli isolated from babies delivered by caesarean section and their environment. Infection. 1976;4(3):139-45. X-1. [pmid: 789250].
3179 Leo S, Sng BL, Lim Y, et al. A randomized comparison of low doses of hyperbaric bupivacaine in combined spinal-epidural anesthesia for cesarean delivery. Anesth Analg. Nov. 2009;109(5):1600-5. X-9. [pmid: 19843797].
3180 Leone T, Padmadas SS, Matthews Z. Community factors affecting rising caesarean section rates in developing countries: an analysis of six countries. Soc Sci Med. Oct. 2008;67(8):1236-46. X-1. [pmid: 18657345].
3181 Lepercq J, Le Meaux JP, Agman A, et al. Factors associated with cesarean delivery in nulliparous women with type 1 diabetes. Obstet Gynecol. May. 2010;115(5):1014-20. X-1. [pmid: 20410777].
3182 Lepisto A, Sarna S, Tiitinen A, et al. Female fertility and childbirth after ileal pouch-anal anastomosis for ulcerative colitis. Br J Surg. Apr. 2007;94(4):478-82. X-1. [pmid: 17310506].
3183 Leppaniemi AK. Obstetrics and the general surgeon. Surg Gynecol Obstet. Apr. 1993;176(4):365-7. X-1. [pmid: 8460413].
3184 Leppert PC, Namerow PB, Barker D. Pregnancy outcomes among adolescent and older women receiving comprehensive prenatal care. J Adolesc Health Care. Mar. 1986;7(2):112-7. X-1. [pmid: 3957748].
3185 Lerchl A, Reinhard SC. Where are the Sunday babies? II. Declining weekend birth rates in Switzerland. Naturwissenschaften. Feb. 2008;95(2):161-4. X-1. [pmid: 17891531].
3186 Leroy F, Puissant F, Barlow P, et al. Guidelines for the prevention of multiple pregnancy in treatment by in vitro fertilization. Acta Genet Med Gemellol (Roma). 1990;39(3):371-8. X-1. [pmid: 2085073].
3187 Lertakyamanee J, Chinachoti T, Tritrakarn T, et al. Comparison of general and regional anesthesia for cesarean section: success rate, blood loss and satisfaction from a randomized trial. J Med Assoc Thai. Jul. 1999;82(7):672-80. X-9. [pmid: 10511769].
3188 Lescale KB, Inglis SR, Eddleman KA, et al. Conflicts between physicians and patients in non-elective cesarean delivery: incidence and the adequacy of informed consent. Am J Perinatol. Apr. 1996;13(3):171-6. X-1. [pmid: 8688110].
3189 Lesser P, Bembridge M, Lyons G, et al. An evaluation of a 30-gauge needle for spinal anaesthesia for caesarean section. Anaesthesia. Sep. 1990;45(9):767-8. X-1. [pmid: 2240540].
3190 Leszczynska-Gorzelak B, Kaminski K, Szymula D, et al. Serum level of endothelin-1 and -2 in pregnancies complicated by EPH gestosis. Gynecol Obstet Invest. 1997;43(1):37-40. X-1. [pmid: 9015697].
3191 Leung AS, Farmer RM, Leung EK, et al. Risk factors associated with uterine rupture during trial of labor after cesarean delivery: a case-control study. Am J Obstet Gynecol. May. 1993;168(5):1358-63. X-1. [pmid: 8498412].
3192 Leung DT, Henning PA, Wagner EC, et al. Inadequacy of plasma acyclovir levels at delivery in patients with genital herpes receiving oral acyclovir suppressive therapy in late pregnancy. J Obstet Gynaecol Can. Dec. 2009;31(12):1137-43. X-1. [pmid: 20085679].
3193 Leung GM, Lam TH, Thach TQ, et al. Rates of cesarean births in Hong Kong: 1987-1999. Birth. Sep. 2001;28(3):166-72. X-1. [pmid: 11552964].
3194 Leung PS, Tsai SJ, Wallukat G, et al. The upregulation of angiotensin II receptor AT(1) in human preeclamptic placenta. Mol Cell Endocrinol. Nov. 26. 2001;184(1-2):95-102. X-1. [pmid: 11694345].
3195 Leung TY, Lau TK, Lo KW, et al. A survey of pregnant women's attitude towards breech delivery and external cephalic version. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):253-9. X-1. [pmid: 11065030].
3196 Leushuis E, Tromp M, Ravelli AC, et al. Indicators for intervention during the expulsive second-stage arrest of labour. BJOG. Dec. 2009;116(13):1773-81. X-1. [pmid: 19832827].
3197 Leveno KJ, Alexander JM, McIntire DD, et al. Does magnesium sulfate given for prevention of eclampsia affect the outcome of labor?. Am J Obstet Gynecol. Apr. 1998;178(4):707-12. X-4e, X-5. [pmid: 9579432].
3198 Leveno KJ, Cunningham FG, Nelson S, et al. A prospective comparison of selective and universal electronic fetal monitoring in 34,995 pregnancies. N Engl J Med. Sep. 4. 1986;315(10):615-9. X-1. [pmid: 3736600].
3199 Leveno KJ, Quirk JG Jr., Cunningham FG, et al. Perioperative antimicrobials at cesarean section: lavage versus three intravenous doses. Am J Obstet Gynecol. Jun. 15. 1984;149(4):463-4. X-3, X-4b. [pmid: 6731524].
3200 Levey KA, Arslan AA, Funai EF. Extra-amniotic saline infusion increases cesarean risk versus other induction methods and spontaneous labor. Am J Perinatol. Oct. 2006;23(7):435-8. X-1. [pmid: 17001554].
3201 Levin DK, Gorchels C, Andersen R. Reduction of post-cesarean section infectious morbidity by means of antibiotic irrigation. Am J Obstet Gynecol. Oct. 1. 1983;147(3):273-7. X-9. [pmid: 6353923].
3202 Levine AB, Kuhlman K, Bonn J. Placenta accreta: comparison of cases managed with and without pelvic artery balloon catheters. J Matern Fetal Med. Jul-Aug. 1999;8(4):173-6. X-1. [pmid: 10406301].
3203 Levine C. A verdict against doctors in a Jehovah's Witness case. Hastings Cent Rep. Jun. 1984;14(3):2-3. X-1.
3204 Levine D, Callen PW, Pender SG, et al. Chorioamniotic separation after second-trimester genetic amniocentesis: importance and frequency. Radiology. Oct. 1998;209(1):175-81. X-1. [pmid: 9769829].
3205 Levine EM. The constitutionality of court-ordered cesarean surgery: a threshold question. Albany Law J Sci Technol. 1994;4(2):229-309. X-1, X-2. [pmid: 12091921].
3206 Levine RJ, Ewell MG, Hauth JC, et al. Should the definition of preeclampsia a rise in diastolic blood pressure of >/=15 mm Hg to a level <90 mm Hg in association with proteinuria?. Am J Obstet Gynecol. Oct. 2000;183(4):787-92. X-1. [pmid: 11035314].
3207 Levy A, Fraser D, Katz M, et al. Maternal anemia during pregnancy is an independent risk factor for low birthweight and preterm delivery. Eur J Obstet Gynecol Reprod Biol. Oct. 1. 2005;122(2):182-6. X-1. [pmid: 16219519].
3208 Levy A, Wiznitzer A, Holcberg G, et al. Family history of diabetes mellitus as an independent risk factor for macrosomia and cesarean delivery. J Matern Fetal Neonatal Med. Feb. 2010;23(2):148-52. X-1. [pmid: 19637110].
3209 Levy DR. The maternal-fetal conflict: the right of a woman to refuse a Cesarean section versus the state's interest in saving the life of the fetus. Spec Law Dig Health Care Law. May. 2007;(337):9-36. X-1, X-2, X-3, X-4, X-5. [pmid: 17694896].
3210 Levy JK. Jehovah's Witnesses, pregnancy, and blood transfusions: a paradigm for the autonomy rights of all pregnant women. J Law Med Ethics. Summer. 1999;27(2):171-89. X-1, X-2, X-3, X-4, X-5. [pmid: 11657465].
3211 Levy R, Ferber A, Ben-Arie A, et al. A randomised comparison of early versus late amniotomy following cervical ripening with a Foley catheter. BJOG. Feb. 2002;109(2):168-72. X-4d. [pmid: 11888099].
3212 Levy R, Vaisbuch E, Furman B, et al. Induction of labor with oral misoprostol for premature rupture of membranes at term in women with unfavorable cervix: a randomized, double-blind, placebo-controlled trial. J Perinat Med. 2007;35(2):126-9. X-4d, X-4e, X-5. [pmid: 17343543].
3213 Lew E, Yeo SW, Thomas E. Combined spinal-epidural anesthesia using epidural volume extension leads to faster motor recovery after elective cesarean delivery: a prospective, randomized, double-blind study. Anesth Analg. Mar. 2004;98(3):810-4. table of contents. X-9. [pmid: 14980942].
3214 Lewis D, Tolosa JE, Kaufmann M, et al. Elective cesarean delivery and long-term motor function or ambulation status in infants with meningomyelocele. Obstet Gynecol. Mar. 2004;103(3):469-73. X-1. [pmid: 14990408].
3215 Lewis DF, Otterson WN, Dunnihoo DR. Antibiotic prophylactic uterine lavage in cesarean section: a double-blind comparison of saline, ticarcillin, and cefoxitin irrigation in indigent patients. South Med J. Mar. 1990;83(3):274-6. X-9. [pmid: 2315771].
3216 Lewis M, Crawford JS. Can one risk fasting the obstetric patient for less than 4 hours?. Br J Anaesth. Mar. 1987;59(3):312-4. X-1. [pmid: 3828179].
3217 Lewis NL, Ritchie EL, Downer JP, et al. Left lateral vs. supine, wedged position for development of block after combined spinal-epidural anaesthesia for Caesarean section. Anaesthesia. Sep. 2004;59(9):894-8. X-9. [pmid: 15310354].
3218 Li H, Du J, Jin L, et al. Myomectomy during cesarean section. Acta Obstet Gynecol Scand. 2009;88(2):183-6. X-1. [pmid: 19093235].
3219 Li M, Zou L, Zhu J. Study on modification of the Misgav Ladach method for cesarean section. J Tongji Med Univ. 2001;21(1):75-7. X-9. [pmid: 11523256].
3220 Li T, Rhoads GG, Smulian J, et al. Physician cesarean delivery rates and risk-adjusted perinatal outcomes. Obstet Gynecol. Jun. 2003;101(6):1204-12. X-1. [pmid: 12798526].
3221 Li TC, MacLeod I, Singhal V, et al. The obstetric and neonatal outcome of pregnancy in women with a previous history of infertility: a prospective study. Br J Obstet Gynaecol. Nov. 1991;98(11):1087-92. X-1. [pmid: 1760419].
3222 Liabsuetrakul T, Chongsuvivatwong V, Lumbiganon P, et al. Obstetricians' attitudes, subjective norms, perceived controls, and intentions on antibiotic prophylaxis in caesarean section. Soc Sci Med. Nov. 2003;57(9):1665-74. X-1. [pmid: 12948575].
3223 Liabsuetrakul T, Islam M. Evidence on antibiotic prophylaxis for cesarean section alone is not sufficient to change the practices of doctors in a teaching hospital. J Obstet Gynaecol Res. Jun. 2005;31(3):202-9. X-1. [pmid: 15916655].
3224 Liabsuetrakul T, Lumbiganon P, Chongsuvivatwong V. Prophylactic antibiotic prescription for cesarean section. Int J Qual Health Care. Dec. 2002;14(6):503-8. X-1. [pmid: 12515336].
3225 Liabsuetrakul T, Lumbiganon P, Chongsuvivatwong V, et al. Current status of prophylactic use of antimicrobial agents for cesarean section in Thailand. J Obstet Gynaecol Res. Oct. 2002;28(5):262-8. X-1. [pmid: 12428696].
3226 Liabsuetrakul T, Peeyananjarassri K, Tassee S, et al. Emergency obstetric care in the southernmost provinces of Thailand. Int J Qual Health Care. Aug. 2007;19(4):250-6. X-1. [pmid: 17575277].
3227 Liamputtong P, Watson LF. The meanings and experiences of cesarean birth among Cambodian, Lao and Vietnamese immigrant women in Australia. Women Health. 2006;43(3):63-82. X-1. [pmid: 17194678].
3228 Liao W, Xie J, Zhong J, et al. Therapeutic effect of human umbilical cord multipotent mesenchymal stromal cells in a rat model of stroke. Transplantation. Feb. 15. 2009;87(3):350-9. X-1. [pmid: 19202439].
3229 Libombo A, Folgosa E, Bergstrom S. A case-control study on post-caesarean endometritis-myometritis in Mozambique. Gynecol Obstet Invest. 1995;39(3):180-5. X-1. [pmid: 7789913].
3230 Lie B, Juul J. Effect of epidural vs. general anesthesia on breastfeeding. Acta Obstet Gynecol Scand. 1988;67(3):207-9. X-1. [pmid: 3176938].
3231 Lieberman E, Cohen A, Lang J, et al. Maternal intrapartum temperature elevation as a risk factor for cesarean delivery and assisted vaginal delivery. Am J Public Health. Apr. 1999;89(4):506-10. X-1. [pmid: 10191792].
3232 Lieberman E, Lang JM, Cohen A, et al. Association of epidural analgesia with cesarean delivery in nulliparas. Obstet Gynecol. Dec. 1996;88(6):993-1000. X-1. [pmid: 8942841].
3233 Lieberman E, Lang JM, Cohen AP, et al. The association of fetal sex with the rate of cesarean section. Am J Obstet Gynecol. Mar. 1997;176(3):667-71. X-1. [pmid: 9077626].
3234 Liebman-Cohen EH. The effects of a nursing case management model on patient length of stay and variables related to cost of care delivery within an acute care setting. ED.D. 1990:210. X-1.
3235 Lien JM, Morgan MA, Garite TJ, et al. Antepartum cervical ripening: applying prostaglandin E2 gel in conjunction with scheduled nonstress tests in postdate pregnancies. Am J Obstet Gynecol. Aug. 1998;179(2):453-8. X-1. [pmid: 9731852].
3236 Liepert DJ, Douglas MJ, McMorland GH, et al. Comparison of lidocaine CO2, two per cent lidocaine hydrochloride and pH adjusted lidocaine hydrochloride for caesarean section anesthesia. Can J Anaesth. Apr. 1990;37(3):333-6. X-9. [pmid: 2182205].
3237 Lilliecreutz C, Sydsjo G, Josefsson A. Obstetric and perinatal outcomes among women with blood- and injection phobia during pregnancy. J Affect Disord. Mar. 2011;129(1-3):289-95. X-1. [pmid: 20825998].
3238 Lim FT, van Winsen L, Willemze R, et al. Influence of delivery on numbers of leukocytes, leukocyte subpopulations, and hematopoietic progenitor cells in human umbilical cord blood. Blood Cells. 1994;20(2-3):547-58. discussion 558-9. X-1. [pmid: 7749120].
3239 Lim NL, Lo WK, Chong JL, et al. Single dose diclofenac suppository reduces post-Cesarean PCEA requirements. Can J Anaesth. Apr. 2001;48(4):383-6. X-9. [pmid: 11339782].
3240 Lim SK, Elegbe EO. The use of single dose of sodium citrate as a prophylaxis against acid aspiration syndrome in obstetric patients undergoing caesarean section. Med J Malaysia. Dec. 1991;46(4):349-55. X-1. [pmid: 1840444].
3241 Lim Y, Jha S, Sia AT, et al. Morphine for post-caesarean section analgesia: intrathecal, epidural or intravenous?. Singapore Med J. Aug. 2005;46(8):392-6. X-1. [pmid: 16049608].
3242 Lim Y, Teoh W, Sia AT. Combined spinal epidural does not cause a higher sensory block than single shot spinal technique for cesarean delivery in laboring women. Anesth Analg. Dec. 2006;103(6):1540-2. X-9. [pmid: 17122236].
3243 Lin A, Kupferminc M, Dooley SL. A randomized trial of extra-amniotic saline infusion versus laminaria for cervical ripening. Obstet Gynecol. Oct. 1995;86(4 Pt 1):545-9. X-4d, X-5. [pmid: 7675377].
3244 Lin BC, Lin PC, Lai YY, et al. The maternal and fetal effects of the addition of sufentanil to 0.5% spinal bupivacaine for cesarean delivery. Acta Anaesthesiol Sin. Sep. 1998;36(3):143-8. X-9. [pmid: 9874862].
3245 Lin C, Wang S, Hsu Y, et al. Risk for respiratory distress syndrome in preterm infants born to mothers complicated by placenta previa. Early Hum Dev. Jan. 2001;60(3):215-24. X-1. [pmid: 11146240].
3246 Lin CH, Kuo SC, Lin KC, et al. Evaluating effects of a prenatal breastfeeding education programme on women with caesarean delivery in Taiwan. J Clin Nurs. Nov. 2008;17(21):2838-45. X-1. [pmid: 18624780].
3247 Lin CH, Lin SY, Yang YH, et al. Extremely preterm cesarean delivery “en caul”. Taiwan J Obstet Gynecol. Sep. 2010;49(3):254-9. X-1, X-9. [pmid: 21056307].
3248 Lin CJ, Huang CL, Hsu HW, et al. Prophylaxis against acid aspiration in regional anesthesia for elective cesarean section: a comparison between oral single-dose ranitidine, famotidine and omeprazole assessed with fiberoptic gastric aspiration. Acta Anaesthesiol Sin. Dec. 1996;34(4):179-84. X-9. [pmid: 9084544].
3249 Lin CS, Lin TY, Huang CH, et al. Prevention of hypotension after spinal anesthesia for cesarean section: dextran 40 versus lactated Ringer's solution. Acta Anaesthesiol Sin. Jun. 1999;37(2):55-9. X-9. [pmid: 10410403].
3250 Lin HC, Sheen TC, Tang CH, et al. Association between maternal age and the likelihood of a cesarean section: a population-based multivariate logistic regression analysis. Acta Obstet Gynecol Scand. Dec. 2004;83(12):1178-83. X-1. [pmid: 15548152].
3251 Lin HC, Xirasagar S. Institutional factors in cesarean delivery rates: policy and research implications. Obstet Gynecol. Jan. 2004;103(1):128-36. X-1. [pmid: 14704256].
3252 Lin HC, Xirasagar S, Tung YC. Impact of a cultural belief about ghost month on delivery mode in Taiwan. J Epidemiol Community Health. Jun. 2006;60(6):522-6. X-1. [pmid: 16698984].
3253 Lin JY, Lee WL, Wang PH, et al. Uterine artery occlusion and myomectomy for treatment of pregnant women with uterine leiomyomas who are undergoing cesarean section. J Obstet Gynaecol Res. Apr. 2010;36(2):284-90. X-1. [pmid: 20492378].
3254 Lin MG, Reid KJ, Treaster MR, et al. Transcervical Foley catheter with and without extraamniotic saline infusion for labor induction: a randomized controlled trial. Obstet Gynecol. Sep. 2007;110(3):558-65. X-4d, X-5. [pmid: 17766600].
3255 Lind B, Hoel TM. Alleviation of labor pain in Norway. An interview investigation in 1969 and 1986. Acta Obstet Gynecol Scand. 1989;68(2):125-9. X-1. [pmid: 2589040].
3256 Lindblad A, Bernow J, Vernersson E, et al. Effects of extradural anaesthesia on human fetal blood flow in utero. Comparison of three local anaesthetic solutions. Br J Anaesth. Oct. 1987;59(10):1265-72. X-9. [pmid: 3676055].
3257 Lindgren HE, Radestad IJ, Christensson K, et al. Outcome of planned home births compared to hospital births in Sweden between 1992 and 2004. A population-based register study. Acta Obstet Gynecol Scand. 2008;87(7):751-9. X-1. [pmid: 18607818].
3258 Lindholm ES, Norman M, Kilander CP, et al. Weight control program for obese pregnant women. Acta Obstet Gynecol Scand. Jun. 2010;89(6):840-3. X-1, X-3, X-4e. [pmid: 19961277].
3259 Lindoff C, Rybo G, Astedt B. Treatment with tranexamic acid during pregnancy, and the risk of thrombo-embolic complications. Thromb Haemost. Aug. 2. 1993;70(2):238-40. X-1. [pmid: 8236125].
3260 Lindow SW, Hendricks MS, Thompson JW, et al. Effects of morphine administration on the fetal production of oxytocin in labour. Clin Sci (Lond). Jul. 1998;95(1):91-5. X-1. [pmid: 9662490].
3261 Lindsay MK, Graves W, Klein L. The relationship of one abnormal glucose tolerance test value and pregnancy complications. Obstet Gynecol. Jan. 1989;73(1):103-6. X-1. [pmid: 2909030].
3262 Linhart Y, Bashiri A, Maymon E, et al. Congenital anomalies are an independent risk factor for neonatal morbidity and perinatal mortality in preterm birth. Eur J Obstet Gynecol Reprod Biol. May. 2000;90(1):43-9. X-1. [pmid: 10767509].
3263 Linton A, Peterson MR. Effect of managed care enrollment on primary and repeat cesarean rates among U.S. Department of Defense health care beneficiaries in military and civilian hospitals worldwide, 1999-2002. Birth. Dec. 2004;31(4):254-64. X-1. [pmid: 15566337].
3264 Lirk P, Kleber N, Mitterschiffthaler G, et al. Pulmonary effects of bupivacaine, ropivacaine, and levobupivacaine in parturients undergoing spinal anaesthesia for elective caesarean delivery: a randomised controlled study. Int J Obstet Anesth. Jul. 2010;19(3):287-92. X-9. [pmid: 20605441].
3265 Lishner M, Zemlickis D, Degendorfer P, et al. Maternal and foetal outcome following Hodgkin's disease in pregnancy. Br J Cancer. Jan. 1992;65(1):114-7. X-1. [pmid: 1733434].
3266 Litchfield JS, Pronk CR, Nezat GG, et al. Efficacy of prophylactic administration of intramuscular promethazine in a parturient population scheduled for cesarean section with intrathecal analgesia. AANA Journal. 2007;75(5):369-369. X-4b.
3267 Lithgow DM, Blecher J. A controlled trial of glifanan and omnopon in postoperative pain. S Afr Med J. Feb. 20. 1971;45(8):203-5. X-4e. [pmid: 4928687].
3268 Little MP, Jarvelin MR, Neasham DE, et al. Factors associated with fall in neonatal intubation rates in the United Kingdom--prospective study. BJOG. Feb. 2007;114(2):156-64. X-1. [pmid: 17305903].
3269 Liu A, Wen SW, Bottomley J, et al. Utilization of health care services of pregnant women complicated by preeclampsia in Ontario. Hypertens Pregnancy. Feb. 2009;28(1):76-84. X-1. [pmid: 19165672].
3270 Liu LL, Clemens CJ, Shay DK, et al. The safety of newborn early discharge. The Washington State experience. JAMA. Jul. 23-30. 1997;278(4):293-8. X-1. [pmid: 9228434].
3271 Liu S, Wen SW, Demissie K, et al. Maternal asthma and pregnancy outcomes: a retrospective cohort study. Am J Obstet Gynecol. Jan. 2001;184(2):90-6. X-1. [pmid: 11174486].
3272 Liu T, Liu Q, Wang YX, et al. Use of amniocytes for prenatal diagnosis of 22q11.2 microdeletion syndrome: a feasibility study. Chin Med J (Engl). Feb. 20. 2010;123(4):438-42. X-1. [pmid: 20193483].
3273 Liu WH, Luxton MC. The effect of prophylactic fentanyl on shivering in elective caesarean section under epidural analgesia. Anaesthesia. May. 1991;46(5):344-8. X-9. [pmid: 2035777].
3274 Liu WM, Wang PH, Tang WL, et al. Uterine artery ligation for treatment of pregnant women with uterine leiomyomas who are undergoing cesarean section. Fertil Steril. Aug. 2006;86(2):423-8. X-1. [pmid: 16762346].
3275 Liu YF, Chen KB, Lin HL, et al. Comparison of the effect of epidural and intravenous patient-controlled analgesia on bowel activity after cesarean section: a retrospective study of 726 Chinese patients. Acta Anaesthesiol Taiwan. Mar. 2009;47(1):22-7. X-1. [pmid: 19318296].
3276 Lloyd H, Munby J, Brown SP. Medical treatment--refusal of medical treatment--adult--refusal on religions grounds: Re S (refusal of medical treatment). New Law J. Oct. 23. 1992;142(6573):1450-1. X-1. [pmid: 16184670].
3277 Lo JC. Patients' attitudes vs. physicians' determination: implications for cesarean sections. Soc Sci Med. Jul. 2003;57(1):91-6. X-1. [pmid: 12753818].
3278 Lo JY, Alexander JM, McIntire DD, et al. Ruptured membranes at term: randomized, double-blind trial of oral misoprostol for labor induction. Obstet Gynecol. Apr. 2003;101(4):685-9. X-4d, X-4e, X-5. [pmid: 12681871].
3279 Lo KW, Rogers M. A controlled trial of amnioinfusion: the prevention of meconium aspiration in labour. Aust N Z J Obstet Gynaecol. Feb. 1993;33(1):51-4. X-1, X-4e. [pmid: 8498939].
3280 Lo T, Candido G, Janssen P. Diastasis of the Recti abdominis in pregnancy: risk factors and treatment. Physiotherapy Canada. 1999. Winter. 1999;51(1):32. X-1.
3281 Localio AR, Lawthers AG, Bengtson JM, et al. Relationship between malpractice claims and cesarean delivery. JAMA. Jan. 20. 1993;269(3):366-73. X-1. [pmid: 8418343].
3282 Locatelli A, Incerti M, Paterlini G, et al. Antepartum and intrapartum risk factors for neonatal encephalopathy at term. Am J Perinatol. Sep. 2010;27(8):649-54. X-1. [pmid: 20225171].
3283 Locatelli A, Regalia AL, Ghidini A, et al. Risks of induction of labour in women with a uterine scar from previous low transverse caesarean section. BJOG. Dec. 2004;111(12):1394-9. X-1. [pmid: 15663125].
3284 Locke NJ. Mother v. her unborn child: where should Texas draw the line?. Houst Law Rev. May. 1987;24(3):549-76. X-1. [pmid: 11649225].
3285 Lockington PF, Fa'aea P. Subcutaneous naloxone for the prevention of intrathecal morphine induced pruritus in elective Caesarean delivery. Anaesthesia. Jul. 2007;62(7):672-6. X-9. [pmid: 17567342].
3286 Locks Gde F, Almeida MC, Pereira AA. Use of the ultrasound to determine the level of lumbar puncture in pregnant women. Rev Bras Anestesiol. Feb. 2010;60(1):13-9. X-1. [pmid: 20169259].
3287 Locksmith GJ, Gei AF, Rowe TF, et al. Teaching the Laufe-Piper forceps technique at cesarean delivery. J Reprod Med. May. 2001;46(5):457-61. X-1. [pmid: 11396372].
3288 Lockwood GF, Newman RL. Estriol determination in random urine samples. Obstet Gynecol. Mar. 1974;43(3):343-6. X-1, X-3, X-4e. [pmid: 4814451].
3289 Lodhi SK, Khanum Z, Watoo TH. Placenta previa: the role of ultrasound in assessment during third trimester. J Pak Med Assoc. Feb. 2004;54(2):81-3. X-1. [pmid: 15134208].
3290 Loftus JR, Holbrook RH, Cohen SE. Fetal heart rate after epidural lidocaine and bupivacaine for elective cesarean section. Anesthesiology. Sep. 1991;75(3):406-12. X-9. [pmid: 1888047].
3291 Loidl CF, Herrera-Marschitz M, Andersson K, et al. Long-term effects of perinatal asphyxia on basal ganglia neurotransmitter systems studied with microdialysis in rat. Neurosci Lett. Jul. 4. 1994;175(1-2):9-12. X-1. [pmid: 7970219].
3292 Loke GP, Chan EH, Sia AT. The effect of 10 degrees head-up tilt in the right lateral position on the systemic blood pressure after subarachnoid block for Caesarean section. Anaesthesia. Feb. 2002;57(2):169-72. X-9. [pmid: 11871954].
3293 Lokugamage AU, Paine M, Bassaw-Balroop K, et al. Active management of the third stage at caesarean section: a randomised controlled trial of misoprostol versus syntocinon. Aust N Z J Obstet Gynaecol. Nov. 2001;41(4):411-4. X-9. [pmid: 11787915].
3294 Lomas J, Enkin M, Anderson GM, et al. Opinion leaders vs audit and feedback to implement practice guidelines. Delivery after previous cesarean section. JAMA. May. 1. 1991;265(17):2202-7. X-4b, X-4e, X-5. [pmid: 2013952].
3295 Lone F, Sultan AH, Thakar R, et al. Risk factors and management patterns for emergency obstetric hysterectomy over 2 decades. Int J Gynaecol Obstet. Apr. 2010;109(1):12-5. X-1. [pmid: 19951818].
3296 Long J, Yue Y. Patient controlled intravenous analgesia with tramadol for labor pain relief. Chin Med J (Engl). Nov. 2003;116(11):1752-5. X-4e, X-5. [pmid: 14642152].
3297 Long Q, Zhang Y, Raven J, et al. Giving birth at a health-care facility in rural China: is it affordable for the poor?. Bull World Health Organ. Feb. 1. 2011;89(2):144-52. X-1. [pmid: 21346926].
3298 Long WH, Rudd EG, Dillon MB. Intrauterine irrigation with cefamandole nafate solution at cesarean section: a preliminary report. Am J Obstet Gynecol. Dec. 1. 1980;138(7 Pt 1):755-8. X-9. [pmid: 7446607].
3299 Longaker MT, Golbus MS, Filly RA, et al. Maternal outcome after open fetal surgery. A review of the first 17 human cases. JAMA. Feb. 13. 1991;265(6):737-41. X-1. [pmid: 1990189].
3300 Lonky NM, Worthen N, Ross MG. Prediction of cesarean section scars with ultrasound imaging during pregnancy. J Ultrasound Med. Jan. 1989;8(1):15-9. X-1. [pmid: 2644438].
3301 Loong RL, Rogers MS, Chang AM. A controlled trial on wound drainage in caesarean section. Aust N Z J Obstet Gynaecol. Nov. 1988;28(4):266-9. X-9. [pmid: 3074776].
3302 Lopez-Escobar G, Fortney JA, Riano-Gamboa G, et al. Maternity record: initial report on a national experience (Colombia). Int J Gynaecol Obstet. 1978 Jul-1979 Aug. 17(1):40-6. X-1. [pmid: 39836].
3303 Lopez-Escobar G, Riano-Gamboa G, Fortney J, et al. Breech presentations in a sample of Colombian hospitals. Int J Gynaecol Obstet. Nov-Dec. 1979;17(3):284-9. X-1. [pmid: 42588].
3304 Lorenzo AV. The preterm rabbit: a model for the study of acute and chronic effects of premature birth. Pediatr Res. Feb. 1985;19(2):201-5. X-1. [pmid: 3982879].
3305 Losty PD, Connell MG, Freese R, et al. Cardiovascular malformations in experimental congenital diaphragmatic hernia. J Pediatr Surg. Aug. 1999;34(8):1203-7. X-1. [pmid: 10466596].
3306 Lotgering FK, Gaugler-Senden IP, Lotgering SF, et al. Outcome after transabdominal cervicoisthmic cerclage. Obstet Gynecol. Apr. 2006;107(4):779-84. X-1. [pmid: 16582112].
3307 Loto O, Onile TG. Placenta praevia at the Obafemi Awolowo University Teaching Hospitals Complex, Ile-Ife. A ten year analysis. Niger J Clin Pract. Jun. 2008;11(2):130-3. X-1. [pmid: 18817052].
3308 Loto OM, Adewuya AO, Ajenifuja OK, et al. The effect of caesarean section on self-esteem amongst primiparous women in South-Western Nigeria: a case-control study. J Matern Fetal Neonatal Med. Sep. 2009;22(9):765-9. X-1. [pmid: 19544153].
3309 Loubert C, O'Brien PJ, Fernando R, et al. Epidural volume extension in combined spinal epidural anaesthesia for elective caesarean section: a randomised controlled trial. Anaesthesia. May. 2011;66(5):341-7. X-9. [pmid: 21418045].
3310 Loughnan BA, Carli F, Romney M, et al. Randomized controlled comparison of epidural bupivacaine versus pethidine for analgesia in labour. Br J Anaesth. Jun. 2000;84(6):715-9. X-4e, X-5. [pmid: 10895743].
3311 Loughrey JP, Walsh F, Gardiner J. Prophylactic intravenous bolus ephedrine for elective Caesarean section under spinal anaesthesia. Eur J Anaesthesiol. Jan. 2002;19(1):63-8. X-9. [pmid: 11915786].
3312 Loughrey JP, Yao N, Datta S, et al. Hemodynamic effects of spinal anesthesia and simultaneous intravenous bolus of combined phenylephrine and ephedrine versus ephedrine for cesarean delivery. Int J Obstet Anesth. Jan. 2005;14(1):43-7. X-9. [pmid: 15627538].
3313 Louie B, Guy J, Quinn M, et al. Reducing surgical length of stay: quantifying the impact. Healthc Manage Forum. Winter. 1995;8(4):29-35. X-1. [pmid: 10156483].
3314 Louie TJ, Binns BA, Baskett TF, et al. Cefotaxime, cefazolin, or ampicillin prophylaxis of febrile morbidity in emergency cesarean sections. Clin Ther. Suppl A. 1982;5:83-96. X-9. [pmid: 6293721].
3315 Louis J, Buhari MA, Allen D, et al. Postpartum morbidity associated with advanced HIV disease. Infect Dis Obstet Gynecol. 2006;2006:79512. X-1. [pmid: 17485809].
3316 Louis JM, Auckley D, Sokol RJ, et al. Maternal and neonatal morbidities associated with obstructive sleep apnea complicating pregnancy. Am J Obstet Gynecol. Mar. 2010;202(3):261 e1-5. X-1. [pmid: 20005507].
3317 Louis JM, Ehrenberg HM, Collin MF, et al. Perinatal intervention and neonatal outcomes near the limit of viability. Am J Obstet Gynecol. Oct. 2004;191(4):1398-402. X-1. [pmid: 15507972].
3318 Lourens R, Paterson-Brown S. Ergometrine given during caesarean section and incidence of delayed postpartum haemorrhage due to uterine atony. J Obstet Gynaecol. Nov. 2007;27(8):795-7. X-9. [pmid: 18097896].
3319 Love ER, Bhattacharya S, Smith NC. Effect of interpregnancy interval on outcomes of pregnancy after miscarriage: retrospective analysis of hospital episode statistics in Scotland. BMJ. 2010;341:c3967. X-1. [pmid: 20688842].
3320 Loverro G, Greco P, Vimercati A, et al. Maternal complications associated with cesarean section. J Perinat Med. 2001;29(4):322-6. X-1. [pmid: 11565201].
3321 Lowder JL, Shackelford DP, Holbert D, et al. A randomized, controlled trial to compare ketorolac tromethamine versus placebo after cesarean section to reduce pain and narcotic usage. Am J Obstet Gynecol. Dec. 2003;189(6):1559-62. discussion 1562. X-9. [pmid: 14710063].
3322 Lowe N. A mother's intuition: Nicola's story. Pract Midwife. Dec. 2010;13(11):32-3. X-1, X-2. [pmid: 21218708].
3323 Lowson SM, Brown J, Wilkins CJ. Influence of the lumbar interspace chosen for injection on the spread of hyperbaric 0.5% bupivacaine. Br J Anaesth. Apr. 1991;66(4):465-8. X-9. [pmid: 2025473].
3324 Lubarsky SL, Schiff E, Friedman SA, et al. Obstetric characteristics among nulliparas under age 15. Obstet Gynecol. Sep. 1994;84(3):365-8. X-1. [pmid: 8058232].
3325 Lubke GH, Kerssens C, Gershon RY, et al. Memory formation during general anesthesia for emergency cesarean sections. Anesthesiology. Apr. 2000;92(4):1029-34. X-1. [pmid: 10754622].
3326 Lucas DN, Borra PJ, Yentis SM. Epidural top-up solutions for emergency caesarean section: a comparison of preparation times. Br J Anaesth. Apr. 2000;84(4):494-6. X-1. [pmid: 10823102].
3327 Lucas DN, Ciccone GK, Yentis SM. Extending low-dose epidural analgesia for emergency Caesarean section. A comparison of three solutions. Anaesthesia. Dec. 1999;54(12):1173-7. X-9. [pmid: 10594415].
3328 Lucas DN, Yentis SM, Kinsella SM, et al. Urgency of caesarean section: a new classification. J R Soc Med. Jul. 2000;93(7):346-50. X-1, X-2. [pmid: 10928020].
3329 Lucas MJ, Sharma SK, McIntire DD, et al. A randomized trial of labor analgesia in women with pregnancy-induced hypertension. Am J Obstet Gynecol. Oct. 2001;185(4):970-5. X-3, X-4e, X-5. [pmid: 11641687].
3330 Luckas M, Buckett W, Alfirevic Z. Comparison of outcomes in uncomplicated term and post-term pregnancy following spontaneous labor. J Perinat Med. 1998;26(6):475-9. X-1. [pmid: 10224605].
3331 Ludvigsson JF, Ludvigsson J. Inflammatory bowel disease in mother or father and neonatal outcome. Acta Paediatr. 2002;91(2):145-51. X-1. [pmid: 11952000].
3332 Luewan S, Srisupundit K, Tongsong T. Outcomes of pregnancies complicated by beta-thalassemia/hemoglobin E disease. Int J Gynaecol Obstet. Mar. 2009;104(3):203-5. X-1. [pmid: 19084837].
3333 Lufkin EG, Nelson RL, Hill LM, et al. An analysis of diabetic pregnancies at Mayo Clinic, 1950-79. Diabetes Care. Nov-Dec. 1984;7(6):539-47. X-1. [pmid: 6439531].
3334 Luisi S, Petraglia F, Benedetto C, et al. Serum allopregnanolone levels in pregnant women: changes during pregnancy, at delivery, and in hypertensive patients. J Clin Endocrinol Metab. Jul. 2000;85(7):2429-33. X-1. [pmid: 10902789].
3335 Lukacz ES, Lawrence JM, Contreras R, et al. Parity, mode of delivery, and pelvic floor disorders. Obstet Gynecol. Jun. 2006;107(6):1253-60. X-1. [pmid: 16738149].
3336 Lukasse M, Vangen S, Oian P, et al. Childhood abuse and caesarean section among primiparous women in the Norwegian Mother and Child Cohort Study. BJOG. Aug. 2010;117(9):1153-7. X-1. [pmid: 20528868].
3337 Lukasse M, Vangen S, Oian P, et al. Fear of childbirth, women's preference for cesarean section and childhood abuse: a longitudinal study. Acta Obstet Gynecol Scand. Jan. 2011;90(1):33-40. X-1. [pmid: 21275913].
3338 Luke B, Brown MB. Maternal morbidity and infant death in twin vs triplet and quadruplet pregnancies. Am J Obstet Gynecol. Apr. 2008;198(4):401 e1-10. X-1. [pmid: 18177828].
3339 Lumbiganon P, Laopaiboon M, Gulmezoglu AM, et al. Method of delivery and pregnancy outcomes in Asia: the WHO global survey on maternal and perinatal health 2007-08. Lancet. Feb. 6. 2010;375(9713):490-9. X-1. [pmid: 20071021].
3340 Lumley J. Any room left for disagreement about assisting breech births at term?. Lancet. 2000;356(9239):1368-1369. X-1.
3341 Lumley J, Lester A, Renou P, et al. A failed RCT to determine the best method of delivery for very low birth weight infants. Control Clin Trials. Jun. 1985;6(2):120-7. X-3, X-4e, X-5. [pmid: 4006485].
3342 Lundin-Schiller S, Mitchell MD. Renin increases human amnion cell prostaglandin E2 biosynthesis. J Clin Endocrinol Metab. Aug. 1991;73(2):436-40. X-1. [pmid: 1856269].
3343 Luo Y, He GP. Pregnant women's awareness and knowledge of mother-to-child transmission of HIV in South Central China. Acta Obstet Gynecol Scand. 2008;87(8):831-6. X-1. [pmid: 18607833].
3344 Lurie S, Eldar I, Glezerman M, et al. Pregnancy outcome after stillbirth. J Reprod Med. Apr. 2007;52(4):289-92. X-1. [pmid: 17506368].
3345 Lurie S, Feinstein M, Mamet Y. Assessment of a newer technique for cesarean section. Arch Gynecol Obstet. Aug. 2002;266(4):195-7. X-1. [pmid: 12192477].
3346 Lurie S, Matzkel A, Weissman A, et al. Outcome of pregnancy in class A1 and A2 gestational diabetic patients delivered beyond 40 weeks' gestation. Am J Perinatol. Sep-Nov. 1992;9(5-6):484-8. X-1. [pmid: 1418162].
3347 Lurie S, Sadan O, Ben Aroya Z, et al. Atosiban treatment for uterine hyperactivity during active labor: a pilot study. J Perinat Med. 2004;32(2):137-9. X-1. [pmid: 15085889].
3348 Lussos SA, Bader AM, Thornhill ML, et al. The antiemetic efficacy and safety of prophylactic metoclopramide for elective cesarean delivery during spinal anesthesia. Reg Anesth. May-Jun. 1992;17(3):126-30. X-9. [pmid: 1606094].
3349 Luterkort M, Marsal K. Umbilical cord acid-base state and Apgar score in term breech neonates. Acta Obstet Gynecol Scand. 1987;66(1):57-60. X-1. [pmid: 3300136].
3350 Luthy DA, Malmgren JA, Zingheim RW. Cesarean delivery after elective induction in nulliparous women: the physician effect. Am J Obstet Gynecol. Nov. 2004;191(5):1511-5. X-1. [pmid: 15547518].
3351 Luthy DA, Malmgren JA, Zingheim RW, et al. Physician contribution to a cesarean delivery risk model. Am J Obstet Gynecol. Jun. 2003;188(6):1579-85. discussion 1585-7. X-1. [pmid: 12824996].
3352 Luthy DA, Shy KK, van Belle G, et al. A randomized trial of electronic fetal monitoring in preterm labor. Obstet Gynecol. May. 1987;69(5):687-95. X-4e, X-5. [pmid: 3554055].
3353 Luttkus AK, Friedmann W, Thomas S, et al. The safety of fetal pulse oximetry in parturients requiring fetal scalp blood sampling. Obstet Gynecol. Oct. 1997;90(4 Pt 1):533-7. X-1. [pmid: 9380311].
3354 Lyall EG, Stainsby C, Taylor GP, et al. Review of uptake of interventions to reduce mother to child transmission of HIV by women aware of their HIV status. BMJ. Jan. 24. 1998;316(7127):268-70. X-1. [pmid: 9472507].
3355 Lydon-Rochelle MT, Holt VL, Nelson JC, et al. Accuracy of reporting maternal in-hospital diagnoses and intrapartum procedures in Washington State linked birth records. Paediatr Perinat Epidemiol. Nov. 2005;19(6):460-71. X-1. [pmid: 16269074].
3356 Lyell DJ, Pullen K, Fuh K, et al. Daily compared with 8-hour gentamicin for the treatment of intrapartum chorioamnionitis: a randomized controlled trial. Obstet Gynecol. Feb. 2010;115(2 Pt 1):344-9. X-3, X-4e, X-5. [pmid: 20093909].
3357 Lygidakis NA, Dimou G, Marinou D. Molar-incisor-hypomineralisation (MIH). A retrospective clinical study in Greek children. II. Possible medical aetiological factors. Eur Arch Paediatr Dent. Dec. 2008;9(4):207-17. X-1. [pmid: 19054474].
3358 Lykkesfeldt G, Osler M. Induction of labor with oral prostaglandin E2 and buccal demoxytocin without amniotomy. Acta Obstet Gynecol Scand. 1981;60(4):429-30. X-4d. [pmid: 7282312].
3359 Lyndrup J, Nickelsen C, Weber T, et al. Induction of labour by balloon catheter with extra-amniotic saline infusion (BCEAS): a randomised comparison with PGE2 vaginal pessaries. Eur J Obstet Gynecol Reprod Biol. Mar. 15. 1994;53(3):189-97. X-4d. [pmid: 8200466].
3360 Lyndrup J, Weber T, Legarth J, et al. Prediction of mode of delivery and ‘DisFIL score’ following induction of labor by local PGE2. Eur J Obstet Gynecol Reprod Biol. Nov. 1993;52(1):11-9. X-1. [pmid: 8119469].
3361 Lyons G, Macdonald R, Mikl B. Combined epidural/spinal anaesthesia for caesarean section. Through the needle or in separate spaces?. Anaesthesia. Mar. 1992;47(3):199-201. X-9. [pmid: 1566985].
3362 Lyrenas S, Clason I, Ulmsten U. In vivo controlled release of PGE2 from a vaginal insert (0.8 mm, 10 mg) during induction of labour. BJOG. Feb. 2001;108(2):169-78. X-1. [pmid: 11236117].
3363 Lyrenas S, Nyberg F, Lindberg B, et al. Cerebrospinal fluid activity of dynorphin-converting enzyme at term pregnancy. Obstet Gynecol. Jul. 1988;72(1):54-8. X-1. [pmid: 2898124].
3364 Ma X, Huang C, Lou S, et al. The clinical outcomes of late preterm infants: a multi-center survey of Zhejiang, China. J Perinat Med. 2009;37(6):695-9. X-1. [pmid: 19591555].
3365 Maak B, Frenzel J. The influence of perinatal risk factors on the incidence of atypical coagulation factor VII during the first days of life. Eur J Pediatr. Aug. 12. 1977;125(4):259-64. X-1. [pmid: 891570].
3366 Maayan-Metzger A, Mazkereth R, Shani A, et al. Risk factors for maternal intrapartum fever and short-term neonatal outcome. Fetal Pediatr Pathol. May-Jun. 2006;25(3):169-77. X-1. [pmid: 17060193].
3367 Maayan-Metzger A, Naor N, Sirota L. Comparative outcome study between triplet and singleton preterm newborns. Acta Paediatr. 2002;91(11):1208-11. X-1. [pmid: 12463320].
3368 Maberry MC, Gilstrap LC 3rd, Bawdon R, et al. Anaerobic coverage for intra-amnionic infection: maternal and perinatal impact. Am J Perinatol. Sep. 1991;8(5):338-41. X-4e. [pmid: 1760067].
3369 Maberry MC, Ramin SM, Gilstrap LC 3rd, et al. Intrapartum asphyxia in pregnancies complicated by intra-amniotic infection. Obstet Gynecol. Sep. 1990;76(3 Pt 1):351-4. X-1. [pmid: 2381612].
3370 Mabie WC, Barton JR, Wasserstrum N, et al. Clinical observations in asthma in pregnancy. Journal of Maternal-Fetal Medicine. 1992. Jan-Feb. 1992;1(1):45-50. X-4e.
3371 Mabina MH, Pitsoe SB, Moodley J. The effect of traditional herbal medicines on pregnancy outcome. The King Edward VIII Hospital experience. S Afr Med J. Aug. 1997;87(8):1008-10. X-1. [pmid: 9323410].
3372 Macario A, Scibetta WC, Navarro J, et al. Analgesia for labor pain: a cost model. Anesthesiology. Mar. 2000;92(3):841-50. X-1. [pmid: 10719963].
3373 MacArthur C. More evidence against the routine use of epidurals. commentary on: Thorp JA, Hu DH, Albin RM, McNitt J, Meyer BA, Cohen GR, Yeast JD. The effect of intrapartum epidural analgesia on nulliparous labor: A randomized, controlled, prospective trial. Am J Obstet Gynecol 1993;169:851-858. Birth: Issues in Perinatal Care. 1994;21(3):172-174. X-2.
3374 Macarthur C, Glazener C, Lancashire R, et al. Faecal incontinence and mode of first and subsequent delivery: a six-year longitudinal study. BJOG. Aug. 2005;112(8):1075-82. X-1. [pmid: 16045521].
3375 MacArthur C, Glazener CM, Wilson PD, et al. Obstetric practice and faecal incontinence three months after delivery. BJOG. Jul. 2001;108(7):678-83. X-1. [pmid: 11467690].
3376 MacArthur C, Glazener CM, Wilson PD, et al. Persistent urinary incontinence and delivery mode history: a six-year longitudinal study. BJOG. Feb. 2006;113(2):218-24. X-1. [pmid: 16412001].
3377 MacDonald C, Pinion SB, MacLeod UM. Scottish female obstetricians' views on elective caesarean section and personal choice for delivery. J Obstet Gynaecol. Nov. 2002;22(6):586-9. X-1. [pmid: 12554241].
3378 MacDonald D, Grant A, Sheridan-Pereira M, et al. The Dublin randomized controlled trial of intrapartum fetal heart rate monitoring. Am J Obstet Gynecol. Jul. 1. 1985;152(5):524-39. X-4e, X-5. [pmid: 3893132].
3379 Macer J, Buchanan D, Yonekura ML. Induction of labor with prostaglandin E2 vaginal suppositories. Obstet Gynecol. May. 1984;63(5):664-8. X-4d, X-5. [pmid: 6585734].
3380 Macer JA, Macer CL, Chan LS. Elective induction versus spontaneous labor: a retrospective study of complications and outcome. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1690-6. discussion 1696-7. X-1. [pmid: 1615976].
3381 Macfie AG, Magides AD, Richmond MN, et al. Gastric emptying in pregnancy. Br J Anaesth. Jul. 1991;67(1):54-7. X-1. [pmid: 1859760].
3382 MacGregor RR, Graziani AL, Samuels P. Randomized, double-blind study of cefotetan and cefoxitin in post-cesarean section endometritis. Am J Obstet Gynecol. Jul. 1992;167(1):139-43. X-9. [pmid: 1442917].
3383 MacGregor SN, Banzhaf WC, Silver RK, et al. A prospective, randomized evaluation of intrapartum amnioinfusion. Fetal acid-base status and cesarean delivery. J Reprod Med. Jan. 1991;36(1):69-73. X-4e. [pmid: 2008006].
3384 MacKenzie IZ, Bradley S, Embrey MP. A simpler approach to labor induction using lipid-based prostaglandin E2 vaginal suppository. Am J Obstet Gynecol. Sep. 15. 1981;141(2):158-62. X-1, X-4d, X-5. [pmid: 6945046].
3385 MacKenzie IZ, Burns E. Randomised trial of one versus two doses of prostaglandin E2 for induction of labour: 1. Clinical outcome. Br J Obstet Gynaecol. Sep. 1997;104(9):1062-7. X-4d. [pmid: 9307536].
3386 MacKenzie IZ, Magill P, Burns E. Randomised trial of one versus two doses of prostaglandin E2 for induction of labour: 2. Analysis of cost. Br J Obstet Gynaecol. Sep. 1997;104(9):1068-72. X-4d, X-4e. [pmid: 9307537].
3387 MacLennan AH, Taylor AW, Wilson DH, et al. The prevalence of pelvic floor disorders and their relationship to gender, age, parity and mode of delivery. BJOG. Dec. 2000;107(12):1460-70. X-1. [pmid: 11192101].
3388 Macleod M, Murphy DJ. Operative vaginal delivery and the use of episiotomy--a survey of practice in the United Kingdom and Ireland. Eur J Obstet Gynecol Reprod Biol. Feb. 2008;136(2):178-83. X-1. [pmid: 17459568].
3389 Macones GA, Cahill AG, Stamilio DM, et al. Can uterine rupture in patients attempting vaginal birth after cesarean delivery be predicted?. Am J Obstet Gynecol. Oct. 2006;195(4):1148-52. X-1. [pmid: 17000247].
3390 Macones GA, Hausman N, Edelstein R, et al. Predicting outcomes of trials of labor in women attempting vaginal birth after cesarean delivery: a comparison of multivariate methods with neural networks. Am J Obstet Gynecol. Feb. 2001;184(3):409-13. X-1. [pmid: 11228495].
3391 Macones GA, Peipert J, Nelson DB, et al. Maternal complications with vaginal birth after cesarean delivery: a multicenter study. Am J Obstet Gynecol. Nov. 2005;193(5):1656-62. X-1. [pmid: 16260206].
3392 Macones GA, Sehdev HM, Parry S, et al. The association between maternal cocaine use and placenta previa. Am J Obstet Gynecol. Nov. 1997;177(5):1097-100. X-1. [pmid: 9396901].
3393 Macrae DJ, Munishankrappa S, Burrow LM, et al. Double-blind comparison of the efficacy of extradural diamorphine, extradural phenoperidine and i.m. diamorphine following caesarean section. Br J Anaesth. Mar. 1987;59(3):354-9. X-9. [pmid: 3828185].
3394 Macri CJ, Schrimmer DB, Greenspoon JS, et al. Amnioinfusion does not affect the length of labor. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):1134-6. X-1. [pmid: 1415405].
3395 Macri CJ, Schrimmer DB, Leung A, et al. Prophylactic amnioinfusion improves outcome of pregnancy complicated by thick meconium and oligohydramnios. Am J Obstet Gynecol. Jul. 1992;167(1):117-21. X-4e, X-5. [pmid: 1442910].
3396 Madaan M, Trivedi SS. Intrapartum electronic fetal monitoring vs. intermittent auscultation in postcesarean pregnancies. Int J Gynaecol Obstet. Aug. 2006;94(2):123-5. X-4b. [pmid: 16828100].
3397 Madazli R, Somunkiran A, Calay Z, et al. Histomorphology of the placenta and the placental bed of growth restricted foetuses and correlation with the Doppler velocimetries of the uterine and umbilical arteries. Placenta. May. 2003;24(5):510-6. X-1. [pmid: 12744927].
3398 Madi BC, Sandall J, Bennett R, et al. Effects of female relative support in labor: a randomized controlled trial. Birth. Mar. 1999;26(1):4-8. X-6. [pmid: 10352048].
3399 Madi-Jebara S, Ghosn A, Sleilaty G, et al. Prevention of hypotension after spinal anesthesia for cesarean section: 6% hydroxyethyl starch 130/0.4 (Voluven) versus lactated Ringer's solution. J Med Liban. Oct-Dec. 2008;56(4):203-7. X-9. [pmid: 19115593].
3400 Magalhaes E, Goveia CS, de Araujo Ladeira LC, et al. Ephedrine versus phenylephrine: prevention of hypotension during spinal block for cesarean section and effects on the fetus. Rev Bras Anestesiol. Jan-Feb. 2009;59(1):11-20. X-9. [pmid: 19374211].
3401 Magann EF, Chauhan SP, Bufkin L, et al. Intra-operative haemorrhage by blunt versus sharp expansion of the uterine incision at caesarean delivery: a randomised clinical trial. BJOG. Apr. 2002;109(4):448-52. X-9. [pmid: 12013167].
3402 Magann EF, Chauhan SP, Martin JN Jr., et al. Does uterine wiping influence the rate of post-Cesarean endometritis?. J Matern Fetal Med. Oct. 2001;10(5):318-22. X-9. [pmid: 11730494].
3403 Magann EF, Chauhan SP, Rodts-Palenik S, et al. Subcutaneous stitch closure versus subcutaneous drain to prevent wound disruption after cesarean delivery: a randomized clinical trial. Am J Obstet Gynecol. Jun. 2002;186(6):1119-23. X-9. [pmid: 12066083].
3404 Magann EF, Cleveland RS, Dockery JR, et al. Acute tocolysis for fetal distress: terbutaline versus magnesium sulphate. Aust N Z J Obstet Gynaecol. Nov. 1993;33(4):362-4. X-3, X-4b, X-5. [pmid: 8179541].
3405 Magann EF, Dodson MK, Allbert JR, et al. Blood loss at time of cesarean section by method of placental removal and exteriorization versus in situ repair of the uterine incision. Surg Gynecol Obstet. Oct. 1993;177(4):389-92. X-9. [pmid: 8211584].
3406 Magann EF, Dodson MK, Ray MA, et al. Preoperative skin preparation and intraoperative pelvic irrigation: impact on post-cesarean endometritis and wound infection. Obstet Gynecol. Jun. 1993;81(6):922-5. X-9. [pmid: 8497357].
3407 Magann EF, Doherty DA, Field K, et al. Biophysical profile with amniotic fluid volume assessments. Obstet Gynecol. Jul. 2004;104(1):5-10. X-4e, X-5. [pmid: 15228994].
3408 Magann EF, Kinsella MJ, Chauhan SP, et al. Does an amniotic fluid index of </=5 cm necessitate delivery in high-risk pregnancies? A case-control study. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1354-9. X-1. [pmid: 10368471].
3409 Magann EF, Nolan TE. Pregnancy outcome in an active-duty population. Obstet Gynecol. Sep. 1991;78(3 Pt 1):391-3. X-1. [pmid: 1876371].
3410 Magann EF, Perry KG Jr., Dockery JR Jr., et al. Cervical ripening before medical induction of labor: a comparison of prostaglandin E2, estradiol, and oxytocin. Am J Obstet Gynecol. Jun. 1995;172(6):1702-6. discussion 1704-8. X-4d, X-4e. [pmid: 7778622].
3411 Magann EF, Washburne JF, Harris RL, et al. Infectious morbidity, operative blood loss, and length of the operative procedure after cesarean delivery by method of placental removal and site of uterine repair. J Am Coll Surg. Dec. 1995;181(6):517-20. X-9. [pmid: 7582225].
3412 Magann EF, Winchester MI, Carter DP, et al. Factors adversely affecting pregnancy outcome in the military. Am J Perinatol. Nov. 1995;12(6):462-6. X-1. [pmid: 8579664].
3413 Maghoma J, Buchmann EJ. Maternal and fetal risks associated with prolonged latent phase of labour. J Obstet Gynaecol. Jan. 2002;22(1):16-9. X-1. [pmid: 12521720].
3414 Magill-Cuerden J. Training: the best way to operate?. Pract Midwife. Oct. 2006;9(9):18-20. X-1, X-2. [pmid: 17069082].
3415 Magnani E, Corosu R, Mancino P, et al. Postoperative analgesia after cesarean section by continued administration of levobupivacaine with the On-Q Painbuster system over the fascia vs ketorolac + morphine i.v. Clin Exp Obstet Gynecol. 2006;33(4):223-5. X-9. [pmid: 17211970].
3416 Magos AL, Noble MC, Wong Ten, Yuen A, et al. Controlled study comparing vaginal prostaglandin E2 pessaries with intravenous oxytocin for the stimulation of labour after spontaneous rupture of the membranes. Br J Obstet Gynaecol. Aug. 1983;90(8):726-31. X-4d, X-4e, X-5. [pmid: 6576807].
3417 Magriples U, Kershaw TS, Rising SS, et al. The effects of obesity and weight gain in young women on obstetric outcomes. Am J Perinatol. May. 2009;26(5):365-71. X-1. [pmid: 19085680].
3418 Magtibay PM, Ramin KD, Harris DY, et al. Misoprostol as a labor induction agent. J Matern Fetal Med. Jan-Feb. 1998;7(1):15-8. X-4d, X-5. [pmid: 9502664].
3419 Maguire A, Sanchez E, Fortuny C, et al. Potential risk factors for vertical HIV-1 transmission in Catalonia, Spain: the protective role of cesarean section. The Working Group on HIV-1 Vertical Transmission in Catalonia. AIDS. Dec. 1997;11(15):1851-7. X-1. [pmid: 9412704].
3420 Mah MW, Pyper AM, Oni GA, et al. Impact of antibiotic prophylaxis on wound infection after cesarean section in a situation of expected higher risk. Am J Infect Control. Apr. 2001;29(2):85-8. X-1. [pmid: 11287874].
3421 Mahadevan U, Sandborn WJ, Li DK, et al. Pregnancy outcomes in women with inflammatory bowel disease: a large community-based study from Northern California. Gastroenterology. Oct. 2007;133(4):1106-12. X-1. [pmid: 17764676].
3422 Mahmood TA. A prospective comparative study on the use of prostaglandin E2 gel (2 mg) and prostaglandin E2 tablet (3 mg) for the induction of labour in primigravid women with unfavorable cervices. Eur J Obstet Gynecol Reprod Biol. Nov. 1989;33(2):169-75. X-4d. [pmid: 2684698].
3423 Mahmood TA, Dick MJ. A randomized trial of management of pre-labor rupture of membranes at term in multiparous women using vaginal prostaglandin gel. Obstet Gynecol. Jan. 1995;85(1):71-4. X-3, X-4e, X-5. [pmid: 7800329].
3424 Mahmood TA, Dick MJ, Smith NC, et al. Role of prostaglandin in the management of prelabour rupture of the membranes at term. Br J Obstet Gynaecol. Feb. 1992;99(2):112-7. X-4e, X-5. [pmid: 1554660].
3425 Mahomed K. A double-blind randomized controlled trial on the use of prophylactic antibiotics in patients undergoing elective caesarean section. Br J Obstet Gynaecol. Jul. 1988;95(7):689-92. X-9. [pmid: 3046651].
3426 Mahomed K, Nyoni R, Mlambo T, et al. Intrapartum foetal heart rate monitoring--continuous electronic versus intermittent Doppler--a randomised controlled trial. Cent Afr J Med. Dec. 1992;38(12):458-62. X-4e, X-5. [pmid: 1340797].
3427 Mahomed K, Nyoni R, Mulambo T, et al. Randomised controlled trial of intrapartum fetal heart rate monitoring. BMJ. Feb. 19. 1994;308(6927):497-500. X-4e. [pmid: 8136665].
3428 Mahomed K, Seeras R, Coulson R. External cephalic version at term. A randomized controlled trial using tocolysis. Br J Obstet Gynaecol. Jan. 1991;98(1):8-13. X-4c, X-5. [pmid: 1998637].
3429 Mahomedy MC, Downing JW, Jeal DE, et al. Ketamine for anaesthetic induction at Caesarean section. S Afr Med J. May. 22. 1976;50(22):846-8. X-1. [pmid: 935971].
3430 Mahomedy MC, Downing JW, Jeal DE, et al. Propanidid for anaesthetic induction at Caesarean section. S Afr Med J. Aug. 2. 1975;49(33):1358-60. X-1. [pmid: 239456].
3431 Mahomedy MC, Downing JW, Jeal DE, et al. Anaesthetic induction for Caesarean section with propanidid. Anaesthesia. Mar. 1976;31(2):205-11. X-1. [pmid: 7151].
3432 Mahomedy MC, Downing JW, Mahomedy YH. Alfathesin for anaesthetic induction at caesarean section. S Afr Med J. Jun. 28. 1975;49(27):1095-6. X-1. [pmid: 239451].
3433 Mahomedy YH, Downing JW, Coleman AJ, et al. Ketamine and the obstetric patient. S Afr Med J. Apr. 13. 1974;48(17):734-6. X-1, X-3, X-4b, X-5. [pmid: 4824138].
3434 Mahoney SF, Malcoe LH. Cesarean delivery in Native American women: are low rates explained by practices common to the Indian health service?. Birth. Sep. 2005;32(3):170-8. X-1. [pmid: 16128970].
3435 Mahony R, Walsh C, Foley ME, et al. Outcome of second delivery after prior macrosomic infant in women with normal glucose tolerance. Obstet Gynecol. Apr. 2006;107(4):857-62. X-1. [pmid: 16582123].
3436 Mahowald M. Beyond abortion: refusal of caesarean section. Bioethics. Apr. 1989;3(2):106-21. X-1. [pmid: 11649241].
3437 Maigaard S, Forman A, Andersson KE. Relaxant and contractile effects of some amines and prostanoids in myometrial and vascular smooth muscle within the human uteroplacental unit. Acta Physiol Scand. Sep. 1986;128(1):33-40. X-1. [pmid: 3766173].
3438 Maine D, Akalin MZ, Chakraborty J, et al. Why did maternal mortality decline in Matlab?. Stud Fam Plann. Jul-Aug. 1996;27(4):179-87. X-1. [pmid: 8875731].
3439 Maiques V, Garcia-Tejedor A, Diago V, et al. Perioperative cesarean delivery morbidity among HIV-infected women under highly active antiretroviral treatment: a case-control study. Eur J Obstet Gynecol Reprod Biol. Nov. 2010;153(1):27-31. X-1, X-9. [pmid: 20675036].
3440 Maiques-Montesinos V, Cervera-Sanchez J, Bellver-Pradas J, et al. Post-cesarean section morbidity in HIV-positive women. Acta Obstet Gynecol Scand. Oct. 1999;78(9):789-92. X-1. [pmid: 10535342].
3441 Majoko F, Zwizwai M, Lindmark G, et al. Labor induction with vaginal misoprostol and extra-amniotic prostaglandin F2alpha gel. Int J Gynaecol Obstet. Feb. 2002;76(2):127-33. X-4d. [pmid: 11818106].
3442 Majoko F, Zwizwai M, Nystrom L, et al. Vaginal misoprostol for induction of labour: a more effective agent than prostaglandin F2 alpha gel and prostaglandin E2 pessary. Cent Afr J Med. Nov-Dec. 2002;48(11-12):123-8. X-4d, X-5. [pmid: 14562597].
3443 Major CA, Henry MJ, De Veciana M, et al. The effects of carbohydrate restriction in patients with diet-controlled gestational diabetes. Obstet Gynecol. Apr. 1998;91(4):600-4. X-1. [pmid: 9540949].
3444 Makedos G, Papanicolaou A, Hitoglou A, et al. Homocysteine, folic acid and B12 serum levels in pregnancy complicated with preeclampsia. Arch Gynecol Obstet. Feb. 2007;275(2):121-4. X-1. [pmid: 16941105].
3445 Makhseed MA, Ahmed MA, Musini VM. Impaired gestational glucose tolerance. Its effect on placental pathology. Saudi Med J. Sep. 2004;25(9):1241-4. X-1. [pmid: 15448775].
3446 Makila UM, Viinikka L, Ylikorkala O. Evidence that prostacyclin deficiency is a specific feature in preeclampsia. Am J Obstet Gynecol. Mar. 15. 1984;148(6):772-4. X-1. [pmid: 6367477].
3447 Makkonen N, Heinonen S, Hongisto T, et al. Normalization of vasoactive changes in preeclampsia precedes clinical recovery. Hypertens Pregnancy. 2002;21(1):51-64. X-1. [pmid: 12044343].
3448 Malamitsi-Puchner A, Economou E, Sevastiadou S, et al. Endothelin 1-21 plasma levels on the first and fourth postpartum day in normal full-term neonates. Dev Pharmacol Ther. 1993;20(3-4):195-8. X-1. [pmid: 7828453].
3449 Malhotra M, Sharma JB, Tripathii R, et al. Maternal and fetal outcome in valvular heart disease. Int J Gynaecol Obstet. Jan. 2004;84(1):11-6. X-1. [pmid: 14698824].
3450 Malhotra N, Khanna S, Pasrija S, et al. Early oral hydration and its impact on bowel activity after elective caesarean section--our experience. Eur J Obstet Gynecol Reprod Biol. May. 1. 2005;120(1):53-6. X-1. [pmid: 15866086].
3451 Malhotra S, Yentis SM. Extending low-dose epidural analgesia in labour for emergency Caesarean section - a comparison of levobupivacaine with or without fentanyl. Anaesthesia. Jul. 2007;62(7):667-71. X-9. [pmid: 17567341].
3452 Malik HZ, Khawaja NP, Zahid B, et al. Sublingual versus oral misoprostol for induction of labour in prelabour rupture of membranes at term. J Coll Physicians Surg Pak. Apr. 2010;20(4):242-5. X-4d. [pmid: 20392399].
3453 Malleeswaran S, Panda N, Mathew P, et al. A randomised study of magnesium sulphate as an adjuvant to intrathecal bupivacaine in patients with mild preeclampsia undergoing caesarean section. Int J Obstet Anesth. Apr. 2010;19(2):161-6. X-9. [pmid: 20171080].
3454 Malomo OO, Kuti O, Orji EO, et al. A randomised controlled study of non-closure of peritoneum at caesarean section in a Nigerian population. J Obstet Gynaecol. Jul. 2006;26(5):429-32. X-9. [pmid: 16846869].
3455 Malone FD, Craigo SD, Chelmow D, et al. Outcome of twin gestations complicated by a single anomalous fetus. Obstet Gynecol. Jul. 1996;88(1):1-5. X-1. [pmid: 8684738].
3456 Maltau JM, Andersen HT. Continuous epidural anaesthesia with a low frequency of instrumental deliveries. Acta Obstet Gynecol Scand. 1975;54(5):401-6. X-1. [pmid: 1202900].
3457 Malvasi A, Tinelli A, Brizzi A, et al. Long-term epidural analgesia treatment in pre-eclamptic women: a preliminary trial. J Obstet Gynaecol. Feb. 2009;29(2):114-8. X-1. [pmid: 19274543].
3458 Malvasi A, Tinelli A, Farine D, et al. Effects of visceral peritoneal closure on scar formation at cesarean delivery. Int J Gynaecol Obstet. May. 2009;105(2):131-5. X-9. [pmid: 19232595].
3459 Malvasi A, Tinelli A, Guido M, et al. Should the visceral peritoneum at the bladder flap closed at cesarean sections? A post-partum sonographic and clinical assessment. J Matern Fetal Neonatal Med. Jul. 2010;23(7):662-9. X-1. [pmid: 20540660].
3460 Malvasi A, Tinelli A, Stark M, et al. Low-dose sequential combined spinal-epidural anaesthesia in elective Stark caesarean section: a preliminary cohort study. Eur Rev Med Pharmacol Sci. Mar. 2010;14(3):215-21. X-9. [pmid: 20391961].
3461 Malzoni M, Rotond M, Perone C, et al. Fertility after laparoscopic myomectomy of large uterine myomas: operative technique and preliminary results. Eur J Gynaecol Oncol. 2003;24(1):79-82. X-1. [pmid: 12691325].
3462 Maman E, Lunenfeld E, Levy A, et al. Obstetric outcome of singleton pregnancies conceived by in vitro fertilization and ovulation induction compared with those conceived spontaneously. Fertil Steril. Aug. 1998;70(2):240-5. X-1. [pmid: 9696214].
3463 Mancuso A, De Vivo A, Fanara G. Cesarean section on demand: are there differences related to obstetricians' gender?. J Matern Fetal Neonatal Med. May. 2006;19(5):309-10. X-1. [pmid: 16753772].
3464 Mancuso A, De Vivo A, Fanara G, et al. Caesarean section on request: are there loco-regional factors influencing maternal choice? An Italian experience. J Obstet Gynaecol. May. 2008;28(4):382-5. X-1. [pmid: 18604668].
3465 Mancuso A, De Vivo A, Fanara G, et al. Women's preference on mode of delivery in Southern Italy. Acta Obstet Gynecol Scand. 2006;85(6):694-9. X-1. [pmid: 16752261].
3466 Mancuso A, De Vivo A, Giacobbe A, et al. General versus spinal anaesthesia for elective caesarean sections: effects on neonatal short-term outcome. A prospective randomised study. J Matern Fetal Neonatal Med. Oct. 2010;23(10):1114-8. X-9. [pmid: 20088721].
3467 Mancuso A, Settineri S, Fanara G, et al. Confidential survey on cesarean section on request: obstetricians' personal experience in Sicily. Acta Obstet Gynecol Scand. 2006;85(5):623-4. X-1. [pmid: 16752245].
3468 Mancuso S, Ferrazzani S, De Carolis S, et al. Term and postterm low-risk pregnancies: management schemes for the reduction of high rates of cesarean section. Minerva Ginecol. Mar. 1996;48(3):95-8. X-1. [pmid: 8684694].
3469 Mandelbrot L, Dommergues M, Dumez Y. Prepartum transabdominal amnio-infusion for severe oligohydramnios. Acta Obstet Gynecol Scand. Feb. 1992;71(2):124-5. X-1. [pmid: 1316039].
3470 Mandelbrot L, Mayaux MJ, Bongain A, et al. Obstetric factors and mother-to-child transmission of human immunodeficiency virus type 1: the French perinatal cohorts. SEROGEST French Pediatric HIV Infection Study Group. Am J Obstet Gynecol. Sep. 1996;175(3 Pt 1):661-7. X-1. [pmid: 8828431].
3471 Mandelbrot L, Verspyck E, Dommergues M, et al. Transabdominal amnioinfusion for the management of nonlaboring postdates with severe oligohydramnios. Fetal Diagn Ther. Nov-Dec. 1993;8(6):412-7. X-1. [pmid: 8286032].
3472 Mando C, Tabano S, Colapietro P, et al. Transferrin receptor gene and protein expression and localization in human IUGR and normal term placentas. Placenta. Jan. 2011;32(1):44-50. X-1, X-9. [pmid: 21036394].
3473 Mangione S, Giarratano A. The role of antithrombin III in critical patients in obstetrics. Minerva Anestesiol. May. 2002;68(5):449-53. X-1. [pmid: 12029262].
3474 Mankowitz E, Downing JW, Brock-Utne JG, et al. Total intravenous anaesthesia using low-dose ketamine infusion for caesarean section. A comparison with a standard inhalation anaesthetic technique. S Afr Med J. Feb. 18. 1984;65(7):246-50. X-9. [pmid: 6420904].
3475 Manner RL. Court-ordered surgery for the protection of a viable fetus: Jefferson v. Griffin Spalding County Hospital Authority, 247 Ga. 86, 274 S.E.2d 457 (1981). West New Engl Law Rev. Summer. 1982;5(1):125-48. X-1.
3476 Manner T, Kanto J, Salonen M. Use of simple tests to determine the residual effects of the analgesic component of balanced anaesthesia. Br J Anaesth. Aug. 1987;59(8):978-82. X-9. [pmid: 3651280].
3477 Mano Y, Shibata K, Sumigama S, et al. Tocilizumab inhibits interleukin-6-mediated matrix metalloproteinase-2 and -9 secretions from human amnion cells in preterm premature rupture of membranes. Gynecol Obstet Invest. 2009;68(3):145-53. X-1. [pmid: 19628948].
3478 Mansfield PK. Re-evaluating the medical risks of late childbearing. Women Health. Summer. 1986;11(2):37-60. X-1. [pmid: 3751081].
3479 Manthata AL, Hall DR, Steyn PS, et al. The attitudes of two groups of South African women towards mode of delivery. Int J Gynaecol Obstet. Jan. 2006;92(1):87-91. X-1. [pmid: 16266706].
3480 Manullang TR, Viscomi CM, Pace NL. Intrathecal fentanyl is superior to intravenous ondansetron for the prevention of perioperative nausea during cesarean delivery with spinal anesthesia. Anesth Analg. May. 2000;90(5):1162-6. X-9. [pmid: 10781472].
3481 Many A, Helpman L, Vilnai Y, et al. Neonatal respiratory morbidity after elective cesarean section. J Matern Fetal Neonatal Med. Feb. 2006;19(2):75-8. X-1. [pmid: 16581601].
3482 Manyonda IT, Shaw DE, Drife JO. The effect of delayed pushing in the second stage of labor with continuous lumbar epidural analgesia. Acta Obstet Gynecol Scand. 1990;69(4):291-5. X-1. [pmid: 2244459].
3483 Manzai M, Liggins GC. Inhibitory effects of dispersed human amnion cells on production rates of prostaglandin E and F by endometrial cells. Prostaglandins. Sep. 1984;28(3):297-307. X-1. [pmid: 6440211].
3484 Manzanares S, Carrillo MP, Gonzalez-Peran E, et al. Isolated oligohydramnios in term pregnancy as an indication for induction of labor. J Matern Fetal Neonatal Med. Mar. 2007;20(3):221-4. X-1. [pmid: 17437223].
3485 Marchiano D, Elkousy M, Stevens E, et al. Diet-controlled gestational diabetes mellitus does not influence the success rates for vaginal birth after cesarean delivery. Am J Obstet Gynecol. Mar. 2004;190(3):790-6. X-1. [pmid: 15042016].
3486 Marchisio S, Ferraccioli K, Barbieri A, et al. Care pathways in obstetrics: the effectiveness in reducing the incidence of episiotomy in childbirth. J Nurs Manag. Oct. 2006;14(7):538-43. X-1, X-4e, X-5. [pmid: 17004964].
3487 Marco AP, Greenwald MK, Higgins MS. A preliminary study of 24-hour post-cesarean patient controlled analgesia: postoperative pain reports and morphine requests/utilization are greater in abstaining smokers than non-smokers. Med Sci Monit. Jun. 2005;11(6):CR255-261. X-1. [pmid: 15917715].
3488 Marinoni E, Korebrits C, Di Iorio R, et al. Effect of betamethasone in vivo on placental corticotropin-releasing hormone in human pregnancy. Am J Obstet Gynecol. Apr. 1998;178(4):770-8. X-1. [pmid: 9579442].
3489 Marinoni E, Santoro M, Vitagliano MP, et al. Intravaginal gemeprost and second-trimester pregnancy termination in the scarred uterus. Int J Gynaecol Obstet. Apr. 2007;97(1):35-9. X-1. [pmid: 17320086].
3490 Marinoni E, Zacharopoulou C, Di Rocco A, et al. Effect of betamethasone in vivo on placental adrenomedullin in human pregnancy. J Soc Gynecol Investig. Sep. 2006;13(6):418-24. X-1.
3491 Marks C, Fethers K, Mindel A. Management of women with recurrent genital herpes in pregnancy in Australia. Sex Transm Infect. Feb. 1999;75(1):55-7. X-1. [pmid: 10448344].
3492 Marquette GP, Boucher M, Theriault D, et al. Does the use of a tocolytic agent affect the success rate of external cephalic version?. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):859-61. X-4c, X-4e, X-5. [pmid: 8885736].
3493 Marshall VA. Management of premature rupture of membranes at or near term. J Nurse Midwifery. May-Jun. 1993;38(3):140-5. X-1. [pmid: 8331424].
3494 Martens MG, Faro S, Hammill HA, et al. Sulbactam/ampicillin versus metronidazole/gentamicin in the treatment of post-cesarean section endometritis. Diagn Microbiol Infect Dis. Jul-Aug. 1989;12(4 Suppl):189S-194S. X-9. [pmid: 2686919].
3495 Martens PJ, Derksen S, Gupta S. Predictors of hospital readmission of Manitoba newborns within six weeks postbirth discharge: a population-based study. Pediatrics. Sep. 2004;114(3):708-13. X-1. [pmid: 15342843].
3496 Martin JA, Hamilton BE, Ventura SJ. Births: preliminary data for 2000. Natl Vital Stat Rep. Jul. 24. 2001;49(5):1-20. X-1.
3497 Martin JA, Menacker F. Expanded health data from the new birth certificate, 2004. Natl Vital Stat Rep. Apr. 19. 2007;55(12):1-22. X-1.
3498 Martin JA, Park MM, Sutton PD. Births: preliminary data for 2001. Natl Vital Stat Rep. Jun. 6. 2002;50(10):1-20. X-1.
3499 Martin JA, Smith BL, Mathews TJ, et al. Births and deaths: preliminary data for 1998. Natl Vital Stat Rep. Oct. 5. 1999;47(25):1-45. X-1.
3500 Martin LF, Finigan KM, Nolan TE. Pregnancy after adjustable gastric banding. Obstet Gynecol. Jun. 2000;95(6 Pt 1):927-30. X-1. [pmid: 10831994].
3501 Martin S, Coleman M. Judicial intervention in pregnancy. McGill Law J. Aug. 1995;40(4):947-91. X-1. [pmid: 11654475].
3502 Martin TC, Clarke A. A case control study of the prevalence of perinatal complications associated with fetal macrosomia in Antigua and Barbuda. West Indian Med J. Sep. 2003;52(3):231-4. X-1. [pmid: 14649106].
3503 Marucci M, Diele C, Bruno F, et al. Subarachnoid anaesthesia in caesarean delivery: effects on alertness. Minerva Anestesiol. Nov. 2003;69(11):809-19. 819. 24. X-9. [pmid: 14735021].
3504 Marut JS, Mercer RT. The cesarean birth experience: implications for nursing. Birth Defects Orig Artic Ser. 1981;17(6):129-52. X-1. [pmid: 7326369].
3505 Marvin KW, Eykholt RL, Keelan JA, et al. The 15-deoxy-delta(12,14)-prostaglandin J(2)receptor, peroxisome proliferator activated receptor-gamma (PPARgamma) is expressed in human gestational tissues and is functionally active in JEG3 choriocarcinoma cells. Placenta. May. 2000;21(4):436-40. X-1. [pmid: 10833383].
3506 Marwick C. Mother accused of murder after refusing caesarean section. BMJ. Mar. 20. 2004;328(7441):663. X-1, X-2. [pmid: 15206080].
3507 Maschi S, Clavenna A, Campi R, et al. Neonatal outcome following pregnancy exposure to antidepressants: a prospective controlled cohort study. BJOG. Jan. 2008;115(2):283-9. X-1. [pmid: 17903222].
3508 Mashiach R, Hod M, Kaplan B, et al. External cephalic version at term using broad criteria: effect on mode of delivery. Clin Exp Obstet Gynecol. 1995;22(4):279-84. X-1. [pmid: 8777779].
3509 Mashini IS, Fadel HE, Nelson GH, et al. Indications for and timing of delivery in diabetic pregnancies. Am J Obstet Gynecol. Dec. 1. 1985;153(7):759-66. X-1. [pmid: 4073140].
3510 Maslovitz S, Many A, Landsberg JA, et al. The safety of low molecular weight heparin therapy during labor. J Matern Fetal Neonatal Med. Jan. 2005;17(1):39-43. X-1. [pmid: 15804785].
3511 Maslovitz S, Shenhav M, Levin I, et al. Outcome of induced deliveries in growth-restricted fetuses: second thoughts about the vaginal option. Arch Gynecol Obstet. Feb. 2009;279(2):139-43. X-1. [pmid: 18506461].
3512 Mason PR, Katzenstein DA, Chimbira TH, et al. Vaginal flora of women admitted to hospital with signs of sepsis following normal delivery, cesarean section or abortion. The Puerperal Sepsis Study Group. Cent Afr J Med. Mar. 1989;35(3):344-51. X-1. [pmid: 2789104].
3513 Massad M, Fahl M, Slim M, et al. Thrombosed Bjork-Shiley standard disc mitral valve prosthesis. J Cardiovasc Surg (Torino). Nov-Dec. 1989;30(6):976-80. X-1.
3514 Masse E, Drolet P, Girard M. Direction of injection does not affect the spread of spinal bupivacaine in parturients. Can J Anaesth. Aug. 1997;44(8):816-9. X-9. [pmid: 9260008].
3515 Mastrobattista JM, Hollier LM, Yeomans ER, et al. Effects of nuchal cord on birthweight and immediate neonatal outcomes. Am J Perinatol. Feb. 2005;22(2):83-5. X-1. [pmid: 15731986].
3516 Matalon S, Sheiner E, Levy A, et al. Relationship of treated maternal hypothyroidism and perinatal outcome. J Reprod Med. Jan. 2006;51(1):59-63. X-1. [pmid: 16482779].
3517 Matar HE, Almerie MQ, Alsabbagh M, et al. Policies for care during the third stage of labour: a survey of maternity units in Syria. BMC Pregnancy Childbirth. 2010;10:32. X-1. [pmid: 20569439].
3518 Mathai M, Ambersheth S, George A. Comparison of two transverse abdominal incisions for cesarean delivery. Int J Gynaecol Obstet. Jul. 2002;78(1):47-9. X-9. [pmid: 12113971].
3519 Mathelier AC. A comparison of postoperative morbidity following prophylactic antibiotic administration by combined irrigation and intravenous route or by intravenous route alone during cesarean section. J Perinat Med. 1992;20(3):177-82. X-9. [pmid: 1453290].
3520 Mathelier AC. Radiopelvimetry after cesarean section. J Reprod Med. Jun. 1996;41(6):427-30. X-1. [pmid: 8799919].
3521 Mathew M, Saquib S, Rizvi SG. Polyhydramnios. Risk factors and outcome. Saudi Med J. Feb. 2008;29(2):256-60. X-1. [pmid: 18246237].
3522 Mathieu D. Respecting liberty and preventing harm: limits of state intervention in prenatal choice. Harv J Law Public Policy. Winter. 1985;8(1):19-55. X-1. [pmid: 11655781].
3523 Mathru M, Rao TL, Kartha RK, et al. Intravenous albumin administration for prevention of spinal hypotension during cesarean section. Anesth Analg. Sep. 1980;59(9):655-8. X-9. [pmid: 7191222].
3524 Matijevic R. Outcome of post-term pregnancy: a matched-pair case-control study. Croat Med J. Dec. 1998;39(4):430-4. X-1. [pmid: 9841946].
3525 Matonhodze BB, Hofmeyr GJ, Levin J. Labour induction at term--a randomised trial comparing Foley catheter plus titrated oral misoprostol solution, titrated oral misoprostol solution alone, and dinoprostone. S Afr Med J. May. 2003;93(5):375-9. X-4d, X-5. [pmid: 12830603].
3526 Matorras R, Tacuri C, Nieto A, et al. Lack of benefits of left tilt in emergent cesarean sections: a randomized study of cardiotocography, cord acid-base status and other parameters of the mother and the fetus. J Perinat Med. 1998;26(4):284-92. X-9. [pmid: 9846303].
3527 Matouskova A, Dottori O, Forssman L, et al. An improved method of epidural analgesia with reduced instrumental delivery rate. Acta Obstet Gynecol Scand. 1975;54(3):231-5. X-1, X-4, X-5. [pmid: 1163215].
3528 Matouskova A, Hanson B, Elmen H. Continuous mini-infusion of bupivacaine into the epidural space during labor. Part III: A clinical study of 225 patients. Acta Obstet Gynecol Scand Suppl. 1979;83:43-52. [pmid: 287310].
3529 Matsota PK, Markantonis SL, Fousteri MZ, et al. Excretion of ropivacaine in breast milk during patient-controlled epidural analgesia after cesarean delivery. Reg Anesth Pain Med. Mar-Apr. 2009;34(2):126-9. X-1, X-9. [pmid: 19282712].
3530 Matsubara S, Ohkuchi A, Kikkawa M, et al. Blood loss in low-lying placenta: placental edge to cervical internal os distance of less vs. more than 2 cm. J Perinat Med. 2008;36(6):507-12. X-1. [pmid: 18673083].
3531 Matteson KA, Lievense SP, Catanzaro B, et al. Intrapartum group B streptococci prophylaxis in patients reporting a penicillin allergy. Obstet Gynecol. Feb. 2008;111(2 Pt 1):356-64. X-1. [pmid: 18238973].
3532 Matthews P, Dann WL, Cartwright DP, et al. Inspired oxygen concentration during general anaesthesia for caesarean section. Eur J Anaesthesiol. Jul. 1989;6(4):295-301. X-9. [pmid: 2759066].
3533 Matthias MS. Problematic integration in pregnancy and childbirth: contrasting approaches to uncertainty and desire in obstetric and midwifery care. Health Commun. Jan. 2009;24(1):60-70. X-1. [pmid: 19204859].
3534 Mauldin JG, Mauldin PD, Feng TI, et al. Determining the clinical efficacy and cost savings of successful external cephalic version. Am J Obstet Gynecol. Dec. 1996;175(6):1639-44. X-1. [pmid: 8987953].
3535 Mavalankar D, Singh A, Patel SR, et al. Saving mothers and newborns through an innovative partnership with private sector obstetricians: Chiranjeevi scheme of Gujarat, India. Int J Gynaecol Obstet. Dec. 2009;107(3):271-6. X-1. [pmid: 19846090].
3536 Mavalankar DV. Policy and management constraints on access to and use of life-saving emergency obstetric care in India. J Am Med Womens Assoc. Summer. 2002;57(3):165-6. 168. X-1. [pmid: 12146609].
3537 Mavalankar DV, Trivedi CR, Gray RH. Levels and risk factors for perinatal mortality in Ahmedabad, India. Bull World Health Organ. 1991;69(4):435-42. X-1. [pmid: 1934237].
3538 Mayberry JF, Weterman IT. European survey of fertility and pregnancy in women with Crohn's disease: a case control study by European collaborative group. Gut. Jul. 1986;27(7):821-5. X-1. [pmid: 3732892].
3539 Mayberry L. Nursing implications of the 2006 NIH State of the Science Conference Statement: Cesarean Delivery on Maternal Request. MCN Am J Matern Child Nurs. Sep-Oct. 2006;31(5):286-9. X-1. [pmid: 17013066].
3540 Mayer A, Erez O, Novack L, et al. Chronic hypertension is an independent risk factor for preeclampsia and preterm delivery in women with rheumatologic diseases: a population-based study. Eur J Obstet Gynecol Reprod Biol. Aug. 2007;133(2):157-63. X-1. [pmid: 17010499].
3541 Mayer DC, Quance D, Weeks SK. Headache after spinal anesthesia for cesarean section: a comparison of the 27-gauge Quincke and 24-gauge Sprotte needles. Anesth Analg. Sep. 1992;75(3):377-80. X-9. [pmid: 1510258].
3542 Mayhew TM, Sorensen FB, Klebe JG, et al. The effects of mode of delivery and sex of newborn on placental morphology in control and diabetic pregnancies. J Anat. Dec. 1993;183(Pt 3):545-52. X-1. [pmid: 8300431].
3543 Maymo JL, Perez Perez A, Sanchez-Margalet V, et al. Up-regulation of placental leptin by human chorionic gonadotropin. Endocrinology. Jan. 2009;150(1):304-13. X-1. [pmid: 18787032].
3544 Mayo TW. Medical decision making during a surrogate pregnancy. Houst Law Rev. May. 1988;25(3):599-644. X-1, X-2. [pmid: 11649257].
3545 Mazhar SB, Imran R, Alam K. Trial of extra amniotic saline infusion with oxytocin versus prostaglandin E2 pessary for induction of labor. J Coll Physicians Surg Pak. Jun. 2003;13(6):317-20. X-4d, X-5. [pmid: 12814527].
3546 Mazhar SB, Peerzada A, Mahmud G. Maternal and perinatal complications in multiple versus singleton pregnancies: a prospective two years study. J Pak Med Assoc. Apr. 2002;52(4):143-7. X-1. [pmid: 12174477].
3547 Mazor M, Furman B, Wiznitzer A, et al. Maternal and perinatal outcome of patients with preterm labor and meconium-stained amniotic fluid. Obstet Gynecol. Nov. 1995;86(5):830-3. X-1. [pmid: 7566858].
3548 Mazor M, Leiberman JR, Dreval D, et al. Management and outcome of vertex-breech and vertex-vertex presentation in twin gestation: a comparative study. Eur J Obstet Gynecol Reprod Biol. Jun. 1986;22(1-2):69-75. X-1. [pmid: 3721049].
3549 Mazor-Dray E, Levy A, Schlaeffer F, et al. Maternal urinary tract infection: is it independently associated with adverse pregnancy outcome?. J Matern Fetal Neonatal Med. Feb. 2009;22(2):124-8. X-1. [pmid: 19085630].
3550 Mazouni C, Provensal M, Porcu G, et al. Termination of pregnancy in patients with previous cesarean section. Contraception. Mar. 2006;73(3):244-8. X-1. [pmid: 16472563].
3551 Mazza F, Kitchens J, Kerr S, et al. Clinical excellence series. Eliminating birth trauma at Ascension Health. Joint Commission Journal on Quality & Patient Safety. 2007;33(1):15-24. X-3, X-4e, X-5. [pmid: 17283938].
3552 Mc Gurgan P, Coulter-Smith S, PJ OD. A national confidential survey of obstetrician's personal preferences regarding mode of delivery. Eur J Obstet Gynecol Reprod Biol. Jul. 2001;97(1):17-9. X-1. [pmid: 11435001].
3553 McAndrew CR, Harms P. Paraesthesiae during needle-through-needle combined spinal epidural versus single-shot spinal for elective caesarean section. Anaesth Intensive Care. Oct. 2003;31(5):514-7. X-9. [pmid: 14601273].
3554 McAra-Couper J, Jones M, Smythe E. Rising rates of intervention in childbirth. British Journal of Midwifery. 2010;18(3):160-169. X-1.
3555 McAuley DM, Moore J, McCaughey W, et al. Ranitidine as an antacid before elective Caesarean section. Anaesthesia. Feb. 1983;38(2):108-14. X-1, X-9. [pmid: 6131624].
3556 McAuliffe FM, Foley M, Firth R, et al. Outcome of diabetic pregnancy with spontaneous labour after 38 weeks. Ir J Med Sci. Jul-Sep. 1999;168(3):160-3. X-1. [pmid: 10540779].
3557 McBride S. The effect of induction of labor on the odds of primary Cesarean delivery. Ph.D. 2005:391. X-1.
3558 McBride WG, Black BP, Brown CJ, et al. Method of delivery and developmental outcome at five years of age. Med J Aust. Apr. 21. 1979;1(8):301-4. X-1. [pmid: 449802].
3559 McCabe CJ, Goldie SJ, Fisman DN. The cost-effectiveness of directly observed highly-active antiretroviral therapy in the third trimester in HIV-infected pregnant women. PLoS One. 2010;5(4):e10154. X-1, X-4e. [pmid: 20405011].
3560 McCaul JFt, Rogers LW, Perry KG Jr., et al. Premature rupture of membranes at term with an unfavorable cervix: comparison of expectant management, vaginal prostaglandin, and oxytocin induction. South Med J. Dec. 1997;90(12):1229-33. X-4d, X-4e. [pmid: 9404911].
3561 McClain CS. Why women choose trial of labor or repeat cesarean section. J Fam Pract. Sep. 1985;21(3):210-6. X-1. [pmid: 4031794].
3562 McClellan MS, Cabianca WA. Effects of early mother-infant contact following cesarean birth. Obstet Gynecol. Jul. 1980;56(1):52-5. X-9. [pmid: 7383488].
3563 McCloskey L, Petitti DB, Hobel CJ. Variations in the use of cesarean delivery for dystocia: lessons about the source of care. Med Care. Feb. 1992;30(2):126-35. X-1. [pmid: 1736018].
3564 McClure EM, Wright LL, Goldenberg RL, et al. The global network: a prospective study of stillbirths in developing countries. Am J Obstet Gynecol. Sep. 2007;197(3):247 e1-5. X-1. [pmid: 17826406].
3565 McCowan L, Jackson P. The prophylactic use of metronidazole in caesarean section. N Z Med J. Aug. 27. 1980;92(666):153-5. X-9. [pmid: 7001295].
3566 McCurdy CM Jr., Magann EF, McCurdy CJ, et al. The effect of placental management at cesarean delivery on operative blood loss. Am J Obstet Gynecol. Nov. 1992;167(5):1363-7. X-9. [pmid: 1442991].
3567 McDonald C, Curtis H, de Ruiter A, et al. National review of maternity care for women with HIV infection. HIV Med. Jul. 2006;7(5):275-80. X-1. [pmid: 16945070].
3568 McDonnell JG, Curley G, Carney J, et al. The analgesic efficacy of transversus abdominis plane block after cesarean delivery: a randomized controlled trial. Anesth Analg. Jan. 2008;106(1):186-91. table of contents. X-9. [pmid: 18165577].
3569 McDonnell M, Henderson-Smart DJ. Delayed umbilical cord clamping in preterm infants: a feasibility study. J Paediatr Child Health. Aug. 1997;33(4):308-10. X-3, X-4e. [pmid: 9323618].
3570 McDonnell NJ, Paech MJ, Browning RM, et al. A randomised comparison of regular oral oxycodone and intrathecal morphine for post-caesarean analgesia. Int J Obstet Anesth. Jan. 2010;19(1):16-23. X-9. [pmid: 19700304].
3571 McDuffie RS Jr., Beck A, Bischoff K, et al. Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial. JAMA. Mar. 20. 1996;275(11):847-51. X-5. [pmid: 8596222].
3572 McDuffie RS Jr., Nelson GE, Osborn CL, et al. Effect of routine weekly cervical examinations at term on premature rupture of the membranes: a randomized controlled trial. Obstet Gynecol. Feb. 1992;79(2):219-22. X-5. [pmid: 1731288].
3573 McElvy SS, Miodovnik M, Myatt L, et al. Is human myometrial sampling at the time of cesarean delivery safe?. Am J Obstet Gynecol. Dec. 2000;183(6):1583-6. X-1. [pmid: 11120532].
3574 McFarland LV, Raskin M, Daling JR, et al. Erb/Duchenne's palsy: a consequence of fetal macrosomia and method of delivery. Obstet Gynecol. Dec. 1986;68(6):784-8. X-1. [pmid: 3785790].
3575 McGill J, Shetty A. Mifepristone and misoprostol in the induction of labor at term. Int J Gynaecol Obstet. Feb. 2007;96(2):80-4. X-1. [pmid: 17274998].
3576 McGladdery SL, Aparicio S, Verrier-Jones K, et al. Outcome of pregnancy in an Oxford-Cardiff cohort of women with previous bacteriuria. Q J Med. Jul. 1992;83(303):533-9. X-1. [pmid: 1484930].
3577 McGrath P, Phillips E. Bioethics and birth: insights on risk decision-making for an elective caesarean after a prior caesarean delivery. Monash Bioeth Rev. Sep. 2009;28(3):22 1-19. X-1. [pmid: 20131527].
3578 McGrath P, Ray-Barruel G. The easy option? Australian findings on mothers' perception of elective Caesarean as a birth choice after a prior Caesarean section. Int J Nurs Pract. Aug. 2009;15(4):271-9. X-1. [pmid: 19703043].
3579 McGregor JA, Christiansen FB. Treatment of obstetric and gynecologic infections, with an emphasis on beta-lactamase-producing organisms. J Reprod Med. Jun. 1988;33(6 Suppl):591-4. X-1. [pmid: 3294404].
3580 McGregor JA, French JI, Makowski E. Single-dose cefotetan versus multidose cefoxitin for prophylaxis in cesarean section in high-risk patients. Am J Obstet Gynecol. Apr. 1986;154(4):955-60. X-1. [pmid: 3515951].
3581 McGrory CH, Groshek MA, Sollinger HW, et al. Pregnancy outcomes in female pancreas-kidney recipients. Transplant Proc. Feb-Mar. 1999;31(1-2):652-3. X-1, X-4e. [pmid: 10083282].
3582 McGuinness BJ, Trivedi AN. Maternal height as a risk factor for Caesarean section due to failure to progress in labour. Aust N Z J Obstet Gynaecol. May. 1999;39(2):152-4. X-1. [pmid: 10755767].
3583 McGuinness GA, Merkow AJ, Kennedy RL, et al. Epidural anesthesia with bupivacaine for Cesarean section: neonatal blood levels and neurobehavioral responses. Anesthesiology. Oct. 1978;49(4):270-3. X-3, X-4b. [pmid: 697082].
3584 McHugh GA. Protection of the rights of pregnant women in prisons and detention facilities. New Engl J Prison Law. Summer. 1980;6(2):231-63. X-1.
3585 McKelvey A, Ashe R, McKenna D, et al. Caesarean section in the second stage of labour: a retrospective review of obstetric setting and morbidity. J Obstet Gynaecol. Apr. 2010;30(3):264-7. X-1. [pmid: 20373928].
3586 McKilligin HR. Deliveries in teenagers at a Newfoundland general hospital. Can Med Assoc J. May. 20. 1978;118(10):1252-4. X-1. [pmid: 647544].
3587 McKinney PA, Parslow R, Gurney K, et al. Antenatal risk factors for childhood diabetes mellitus; a case-control study of medical record data in Yorkshire, UK. Diabetologia. Aug. 1997;40(8):933-9. X-1, X-4e. [pmid: 9267988].
3588 McKinney PA, Parslow R, Gurney KA, et al. Perinatal and neonatal determinants of childhood type 1 diabetes. A case-control study in Yorkshire, U.K. Diabetes Care. Jun. 1999;22(6):928-32. X-1. [pmid: 10372244].
3589 McKinnie V, Swift SE, Wang W, et al. The effect of pregnancy and mode of delivery on the prevalence of urinary and fecal incontinence. Am J Obstet Gynecol. Aug. 2005;193(2):512-7. discussion 517-8. X-1. [pmid: 16098879].
3590 McLaren RA, Chauhan SP, Gross TL. Intrapartum factors in early-onset group B streptococcal sepsis in term neonates: a case-control study. Am J Obstet Gynecol. Jun. 1996;174(6):1934-7. discussion 1937-40. X-1, X-4e, X-5. [pmid: 8678161].
3591 McLaughlin CC, Baptiste MS, Schymura MJ, et al. Perinatal risk factors for neuroblastoma. Cancer Causes Control. Apr. 2009;20(3):289-301. X-1. [pmid: 18941915].
3592 McLaughlin GB, Cheng YW, Caughey AB. Women with one elevated 3-hour glucose tolerance test value: are they at risk for adverse perinatal outcomes?. Am J Obstet Gynecol. May. 2006;194(5):e16-9. X-1. [pmid: 16647890].
3593 McLaughlin RA. Associations among health literacy levels and health outcomes in pregnant women with pregestational and gestational diabetes in an urban setting. Ph.D. 2009:129. X-1.
3594 McLaws ML, Murphy C, Whitby M. Standardising surveillance of nosocomial infections: the HISS program. Hospital Infection Standardised Surveillance. J Qual Clin Pract. Mar. 2000;20(1):6-11. X-1. [pmid: 10821448].
3595 McLean MT. Personal autonomy versus active management of labor. Midwifery Today Childbirth Educ. Summer. 1994;(30):18. X-1. [pmid: 7920795].
3596 McLean MT. Marion's message. Cesarean on maternal request. Midwifery Today Int Midwife. Winter. 2006;(80):10. 66. X-1.
3597 McLean SA, Ramsey J. Human rights, reproductive freedom, medicine and the law. Med Law Int. 2002;5(4):239-58. X-1. [pmid: 14983883].
3598 McLennan MT, Alten B, Melick C, et al. Patients' satisfaction with and attitudes toward vaginal delivery. J Reprod Med. Oct. 2005;50(10):740-4. X-1. [pmid: 16320554].
3599 McLennan MT, Melick CF, Alten B, et al. Patients' knowledge of potential pelvic floor changes associated with pregnancy and delivery. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):22-6. X-1. [pmid: 16003482].
3600 McLeod L, Barrett J, Hewson S, et al. Women's views regarding participation in a proposed randomized controlled trial of twin delivery. J Obstet Gynaecol Can. Jun. 2004;26(6):575-9. X-1. [pmid: 15193203].
3601 McLintic AJ, Danskin FH, Reid JA, et al. Effect of adrenaline on extradural anaesthesia, plasma lignocaine concentrations and the feto-placental unit during elective caesarean section. Br J Anaesth. Dec. 1991;67(6):683-9. X-9. [pmid: 1768538].
3602 McLoughlin G. Does caesarean delivery prevent anal incontinence?. Nursing Times. 2011;107(17):23-23. X-1, X-2. [pmid: 21614956].
3603 McMahon MJ, Li R, Schenck AP, et al. Previous cesarean birth. A risk factor for placenta previa?. J Reprod Med. Jul. 1997;42(7):409-12. X-1. [pmid: 9252931].
3604 McMorland GH, Douglas MJ, Axelson JE, et al. The effect of pH adjustment of bupivacaine on onset and duration of epidural anaesthesia for caesarean section. Can J Anaesth. Sep. 1988;35(5):457-61. X-9. [pmid: 3048753].
3605 McMorland GH, Douglas MJ, Kim JH, et al. Epidural sufentanil for post-caesarean section analgesia: lack of benefit of epinephrine. Can J Anaesth. May. 1990;37(4 Pt 1):432-7. X-1, X-9. [pmid: 1971198].
3606 McMorrow RC, Ni Mhuircheartaigh RJ, Ahmed KA, et al. Comparison of transversus abdominis plane block vs spinal morphine for pain relief after Caesarean section. Br J Anaesth. May. 2011;106(5):706-12. X-9. [pmid: 21498494].
3607 McQeen J, Kingdom JC, Connell JM, et al. Fetal endothelin levels and placental vascular endothelin receptors in intrauterine growth retardation. Obstet Gynecol. Dec. 1993;82(6):992-8. X-1. [pmid: 8233278].
3608 Mead M, Bogaerts A, Reyns M. Midwives' perception of the intrapartum risk of healthy nulliparae in spontaneous labour, in The Flanders, Belgium. Midwifery. Dec. 2007;23(4):361-71. X-1. [pmid: 17126968].
3609 Meakin S. Education to save midwifery. MIDIRS Midwifery Digest. 2003;13(2):157-160. X-1, X-2.
3610 Mebazaa MS, Ouerghi S, Ben Meftah R, et al. Reduction of bupivacaine dose in spinal anaesthesia for caesarean section may improve maternal satisfaction by reducing incidence of low blood pressure episodes. Middle East J Anesthesiol. Jun. 2010;20(5):673-8. X-9. [pmid: 20803855].
3611 Mecklem DW, Humphrey MD, Hicks RW. Efficacy of bupivacaine delivered by wound catheter for post-Caesarean section analgesia. Aust N Z J Obstet Gynaecol. Nov. 1995;35(4):416-21. X-9. [pmid: 8717568].
3612 Meda N, Hounton S, De Brouwere V, et al. From evaluating a Skilled Care Initiative in rural Burkina Faso to policy implications for safe motherhood in Africa. Trop Med Int Health. Jul. Suppl 1. 2008;13:68-72. X-1. [pmid: 18578814].
3613 Meehan FP, Moolgaoker AS, Stallworthy J. Vaginal delivery under caudal analgesia after caesarean section and other major uterine surgery. Br Med J. Jun. 24. 1972;2(5816):740-2. X-1. [pmid: 5036881].
3614 Mehdizadeh A, Roosta F, Chaichian S, et al. Evaluation of the impact of birth preparation courses on the health of the mother and the newborn. Am J Perinatol. Jan. 2005;22(1):7-9. X-6. [pmid: 15668838].
3615 Mehta S, Nuamah I, Kalhan S. Altered diastolic function in asymptomatic infants of mothers with gestational diabetes. Diabetes. Dec. Suppl 2. 1991;40:56-60. X-1. [pmid: 1748266].
3616 Meikle SF, Bissell ME, Freedman WL, et al. A retrospective review of the efficacy and safety of prostaglandin E2 with premature rupture of the membranes at term. Obstet Gynecol. Jul. 1992;80(1):76-9. X-1. [pmid: 1603502].
3617 Meikle SF, Steiner CA, Zhang J, et al. A national estimate of the elective primary cesarean delivery rate. Obstet Gynecol. Apr. 2005;105(4):751-6. X-1. [pmid: 15802401].
3618 Meininger D, Byhahn C, Kessler P, et al. Intrathecal fentanyl, sufentanil, or placebo combined with hyperbaric mepivacaine 2% for parturients undergoing elective cesarean delivery. Anesth Analg. Mar. 2003;96(3):852-8. table of contents. X-9. [pmid: 12598273].
3619 Mekbib T, Kassaye E, Getachew A, et al. The FIGO Save the Mothers Initiative: the Ethiopia-Sweden collaboration. Int J Gynaecol Obstet. Apr. 2003;81(1):93-102. X-1. [pmid: 12676407].
3620 Melamed N, Ben-Haroush A, Chen R, et al. Pregnancy outcome and mode of delivery after a previous operative vaginal delivery. Obstet Gynecol. Oct. 2009;114(4):757-63. X-1. [pmid: 19888032].
3621 Melamed N, Klinger G, Tenenbaum-Gavish K, et al. Short-term neonatal outcome in low-risk, spontaneous, singleton, late preterm deliveries. Obstet Gynecol. Aug. 2009;114(2 Pt 1):253-60. X-1. [pmid: 19622985].
3622 Melamed N, Yogev Y, Hadar E, et al. Preinduction cervical ripening with prostaglandin E2 at preterm. Acta Obstet Gynecol Scand. 2008;87(1):63-7. X-1. [pmid: 18158629].
3623 Melamed N, Yogev Y, Meizner I, et al. Sonographic prediction of fetal macrosomia: the consequences of false diagnosis. J Ultrasound Med. Feb. 2010;29(2):225-30. X-1. [pmid: 20103792].
3624 Melia RJ, Morgan M, Wolfe CD, et al. Consumers' views of the maternity services: implications for change and quality assurance. J Public Health Med. May. 1991;13(2):120-6. X-1. [pmid: 1854521].
3625 Melis F, Vandenbrouke JP, Buller HR, et al. Estimates of risk of venous thrombosis during pregnancy and puerperium are not influenced by diagnostic suspicion and referral basis. Am J Obstet Gynecol. Sep. 2004;191(3):825-9. X-1. [pmid: 15467549].
3626 Melzer K, Schutz Y, Soehnchen N, et al. Effects of recommended levels of physical activity on pregnancy outcomes. Am J Obstet Gynecol. Mar. 2010;202(3):266 e1-6. X-1. [pmid: 20022583].
3627 Menacker F, Declercq E, Macdorman MF. Cesarean delivery: background, trends, and epidemiology. Semin Perinatol. Oct. 2006;30(5):235-41. X-1. [pmid: 17011392].
3628 Menada Valenzano M, Lijoi D, Mistrangelo E, et al. Vaginal ultrasonographic and hysterosonographic evaluation of the low transverse incision after caesarean section: correlation with gynaecological symptoms. Gynecol Obstet Invest. 2006;61(4):216-22. X-1. [pmid: 16479140].
3629 Mendez R, Eisenach JC, Kashtan K. Epidural clonidine analgesia after cesarean section. Anesthesiology. Nov. 1990;73(5):848-52. X-9. [pmid: 2240674].
3630 Mendonca C, Griffiths J, Ateleanu B, et al. Hypotension following combined spinal-epidural anaesthesia for Caesarean section. Left lateral position vs. tilted supine position. Anaesthesia. May. 2003;58(5):428-31. X-9. [pmid: 12693997].
3631 Menezes Succi RC. Mother-to-child transmission of HIV in Brazil during the years 2000 and 2001: results of a multi-centric study. Cad Saude Publica. Suppl 3. 2007;23:S379-89. X-1. [pmid: 17992344].
3632 Ment LR, Oh W, Ehrenkranz RA, et al. Antenatal steroids, delivery mode, and intraventricular hemorrhage in preterm infants. Am J Obstet Gynecol. Mar. 1995;172(3):795-800. X-3, X-4e. [pmid: 7892866].
3633 Menticoglou SM. Differences among obstetricians in caesarean section rates. Aust N Z J Obstet Gynaecol. Nov. 1997;37(4):387-92. X-1. [pmid: 9429698].
3634 Mercer B, Pilgrim P, Sibai B. Labor induction with continuous low-dose oxytocin infusion: a randomized trial. Obstet Gynecol. May. 1991;77(5):659-63. X-4d. [pmid: 2014075].
3635 Mercer BM, Gilbert S, Landon MB, et al. Labor outcomes with increasing number of prior vaginal births after cesarean delivery. Obstet Gynecol. Feb. 2008;111(2 Pt 1):285-91. X-1. [pmid: 18238964].
3636 Mercer RT, Stainton MC. Perceptions of the birth experience: a cross-cultural comparison. Health Care Women Int. 1984;5(1-3):29-47. X-1. [pmid: 6565701].
3637 Mercier FJ, Riley ET, Frederickson WL, et al. Phenylephrine added to prophylactic ephedrine infusion during spinal anesthesia for elective cesarean section. Anesthesiology. Sep. 2001;95(3):668-74. X-9. [pmid: 11575540].
3638 Merrill DC, Goodwin P, Burson JM, et al. The optimal route of delivery for fetal meningomyelocele. Am J Obstet Gynecol. Jul. 1998;179(1):235-40. X-1. [pmid: 9704793].
3639 Merrill DC, Zlatnik FJ. Randomized, double-masked comparison of oxytocin dosage in induction and augmentation of labor. Obstet Gynecol. Sep. 1999;94(3):455-63. X-4d, X-5. [pmid: 10472877].
3640 Merz W, Van de Vondel P, Strunk H, et al. Diagnosis, treatment and application of color Doppler in conservative management of abnormally adherent placenta. Ultraschall Med. Dec. 2009;30(6):571-6. X-1. [pmid: 18773385].
3641 Mesleh RA, Al-Aql AS, Kurdi AM. Teenage pregnancy. Saudi Med J. Oct. 2001;22(10):864-7. X-1. [pmid: 11744943].
3642 Mesleh RA, Asiri F, Al-Naim MF. Cesarean section in the primigravid. Saudi Med J. Oct. 2000;21(10):957-9. X-1. [pmid: 11369962].
3643 Messinis I, Malamitsi-Puchner A, Hadjigeorgiou E, et al. Perinatal complications in elderly primigravidas. Padiatr Padol. 1982;17(3):597-602. X-1, X-4e. [pmid: 7110739].
3644 Metsala J, Kilkkinen A, Kaila M, et al. Perinatal factors and the risk of asthma in childhood--a population-based register study in Finland. Am J Epidemiol. Jul. 15. 2008;168(2):170-8. X-1. [pmid: 18511427].
3645 Metsala J, Lundqvist A, Kaila M, et al. Maternal and perinatal characteristics and the risk of cow's milk allergy in infants up to 2 years of age: a case-control study nested in the Finnish population. Am J Epidemiol. Jun. 15. 2010;171(12):1310-6. X-1. [pmid: 20472571].
3646 Metzger BE, Lowe LP, Dyer AR, et al. Hyperglycemia and adverse pregnancy outcomes. N Engl J Med. May. 8. 2008;358(19):1991-2002. X-1. [pmid: 18463375].
3647 Meydanli MM, Caliskan E, Burak F, et al. Labor induction post-term with 25 micrograms vs. 50 micrograms of intravaginal misoprostol. Int J Gynaecol Obstet. Jun. 2003;81(3):249-55. X-4d. [pmid: 12767565].
3648 Meyer KC. Forced medical treatment in pregnancy: resolving the conflicting rights of mother and fetus. Med Staff Couns. Winter. 1990;4(1):53-8. X-1, X-2. [pmid: 10104769].
3649 Meyer M, Paranya G, Keefer Norris A, et al. Intrapartum and postpartum analgesia for women maintained on buprenorphine during pregnancy. Eur J Pain. Oct. 2010;14(9):939-43. X-1. [pmid: 20444630].
3650 Meyer M, Pflum J, Howard D. Outpatient misoprostol compared with dinoprostone gel for preinduction cervical ripening: a randomized controlled trial. Obstet Gynecol. Mar. 2005;105(3):466-72. X-4d. [pmid: 15738009].
3651 Meyer M, Wagner K, Benvenuto A, et al. Intrapartum and postpartum analgesia for women maintained on methadone during pregnancy. Obstet Gynecol. Aug. 2007;110(2 Pt 1):261-6. X-1. [pmid: 17666599].
3652 Meyer NL, Hosier KV, Scott K, et al. Cefazolin versus cefazolin plus metronidazole for antibiotic prophylaxis at cesarean section. South Med J. Oct. 2003;96(10):992-5. X-9. [pmid: 14570343].
3653 Michaels WH, Thompson HO, Boutt A, et al. Ultrasound diagnosis of defects in the scarred lower uterine segment during pregnancy. Obstet Gynecol. Jan. 1988;71(1):112-20. X-1. [pmid: 3275907].
3654 Michalowski S. Court-authorised caesarean sections--the end of a trend?. Mod Law Rev. Jan. 1999;62(1):115-27. X-1, X-2, X-3, X-4, X-5. [pmid: 12741389].
3655 Michlin R, Oettinger M, Odeh M, et al. Maternal obesity and pregnancy outcome. Isr Med Assoc J. Jan. 2000;2(1):10-3. X-1. [pmid: 10892363].
3656 Middelburg KJ, Haadsma ML, Heineman MJ, et al. Ovarian hyperstimulation and the in vitro fertilization procedure do not influence early neuromotor development; a history of subfertility does. Fertil Steril. Feb. 2010;93(2):544-53. X-1. [pmid: 19361794].
3657 Middleton P, Crowther CA, Simmonds L, et al. Different intensities of glycaemic control for pregnant women with pre-existing diabetes. Cochrane Database of Systematic Reviews. 2010;(9). X-1, X-2.
3658 Mikki N, Abu-Rmeileh NM, Wick L, et al. Caesarean delivery rates, determinants and indications in Makassed Hospital, Jerusalem 1993 and 2002. East Mediterr Health J. Jul-Aug. 2009;15(4):868-79. X-1. [pmid: 20187538].
3659 Mikulandra F, Perisa M, Merlak I, et al. The grand multipara--an obstetric problem?. Zentralbl Gynakol. 1992;114(10):491-6. X-1. [pmid: 1414065].
3660 Mikulandra F, Perisa M, Merlak I, et al. Pregnancy and delivery in women aged 35 years and over. Zentralbl Gynakol. 1993;115(4):171-6. X-1. [pmid: 8503236].
3661 Mikulandra F, Perisa M, Stojnic E. When is fetal macrosomia (> or = 4500 g) an indication for caesarean section?. Zentralbl Gynakol. 1996;118(8):441-7. X-1. [pmid: 8794545].
3662 Mikuni I, Hirai H, Toyama Y, et al. Efficacy of intrathecal morphine with epidural ropivacaine infusion for postcesarean analgesia. J Clin Anesth. Jun. 2010;22(4):268-73. X-9. [pmid: 20522357].
3663 Miles AL, Monga M, Waller DK, et al. Risk factors for symptomatic uterine rupture during a trial of labor: the 1990s. Am J Perinatol. 2000;17(7):385-9. X-1. [pmid: 12141526].
3664 Miletic T, Aberle N, Mikulandra F, et al. Perinatal outcome of pregnancies in women aged 40 and over. Coll Antropol. Jun. 2002;26(1):251-8. X-1. [pmid: 12137307].
3665 Millar JS, Winston T, McCauley D, et al. Quality improvement efforts in prenatal care for Oklahoma Medicaid managed care patients: 1995-1998. J Okla State Med Assoc. Jan. 2002;95(1):28-33. X-1. [pmid: 11799801].
3666 Miller ES, Partezana J, Montgomery RL. Vaginal birth after cesarean: a 5-year experience in a family practice residency program. J Am Board Fam Pract. Sep-Oct. 1995;8(5):357-60. X-1. [pmid: 7484222].
3667 Miller FH. Maternal-fetal ethical dilemmas: a guideline for physicians. Semin Anesth. Sep. 1991;10(3):157-62. X-1. [pmid: 11651353].
3668 Miller J, Thornton E, Gittens C. Influences of mode of birth and personality. British Journal of Midwifery. 2002;10(11):692-697. X-1.
3669 Miller L. Two patients or one? Problems of consent in obstetrics. Med Law Int. 1993;1(1):97-112. X-1. [pmid: 11659741].
3670 Miller LA. Legal issues in neonatal nursing. Neonatal Netw. Nov-Dec. 2003;22(6):67-8. X-1. [pmid: 14700183].
3671 Miller MK. Refusal to undergo a cesarean section: a woman's right or a criminal act?. Health Matrix Clevel. Summer. 2005;15(2):383-400. X-9. [pmid: 16238288].
3672 Miller TD, Davis G. Use of the Atad catheter for the induction of labour in women who have had a previous Caesarean section--a case series. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):325-7. X-1. [pmid: 16029302].
3673 Milliez JM, Jannet D, Touboul C, et al. Maturation of the uterine cervix by repeated intracervical instillation of prostaglandin E2. Am J Obstet Gynecol. Sep. 1991;165(3):523-8. X-1. [pmid: 1892176].
3674 Milliez JM, Jannet D, Touboul C, et al. Two different regimens of preinduction ripening of the uterine cervix with prostaglandin E2: a randomized clinical study. Eur J Obstet Gynecol Reprod Biol. Aug. 1993;50(3):163-8. X-4d. [pmid: 8262291].
3675 Milne J, Gafni A, Lu D, et al. Developing and pre-testing a decision board to facilitate informed choice about delivery approach in uncomplicated pregnancy. BMC Pregnancy Childbirth. 2009;9:50. X-1. [pmid: 19874628].
3676 Milner AR, Bogod DG, Harwood RJ. Intrathecal administration of morphine for elective Caesarean section. A comparison between 0.1 mg and 0.2 mg. Anaesthesia. Sep. 1996;51(9):871-3. X-9. [pmid: 8882255].
3677 Milsom I, Ladfors L, Thiringer K, et al. Influence of maternal, obstetric and fetal risk factors on the prevalence of birth asphyxia at term in a Swedish urban population. Acta Obstet Gynecol Scand. Oct. 2002;81(10):909-17. X-1. [pmid: 12366480].
3678 Milwidsky A, Gutman A. Glycogen metabolism of normal human myometrium and leiomyoma--possible hormonal control. Gynecol Obstet Invest. 1983;15(3):147-52. X-1. [pmid: 6403415].
3679 Mimouni F, Miodovnik M, Rosenn B, et al. Birth trauma in insulin-dependent diabetic pregnancies. Am J Perinatol. May. 1992;9(3):205-8. X-1. [pmid: 1575844].
3680 Mimouni F, Miodovnik M, Whitsett JA, et al. Respiratory distress syndrome in infants of diabetic mothers in the 1980s: no direct adverse effect of maternal diabetes with modern management. Obstet Gynecol. Feb. 1987;69(2):191-5. X-1. [pmid: 3808504].
3681 Minaretzis D, Tsionu C, Papageorgiou I, et al. Intracervical prostaglandin E2 gel for cervical ripening and labor induction: what is the appropriate dose?. Gynecol Obstet Invest. 1993;35(1):34-7. X-1, X-4d. [pmid: 8449431].
3682 Minchom P, Niswander K, Chalmers I, et al. Antecedents and outcome of very early neonatal seizures in infants born at or after term. Br J Obstet Gynaecol. May. 1987;94(5):431-9. X-1. [pmid: 3580326].
3683 Minerbi-Codish I, Fraser D, Avnun L, et al. Influence of asthma in pregnancy on labor and the newborn. Respiration. 1998;65(2):130-5. X-9. [pmid: 9580925].
3684 Minior VK, Divon MY. Fetal growth restriction at term: myth or reality?. Obstet Gynecol. Jul. 1998;92(1):57-60. X-1. [pmid: 9649093].
3685 Minkoff H. The ethics of cesarean section by choice. Semin Perinatol. Oct. 2006;30(5):309-12. X-1, X-2. [pmid: 17011404].
3686 Minkoff H, Ecker J. Is there a doctor in the house? Standards of physician availability for laboring women. Obstet Gynecol. Sep. 2010;116(3):723-7. X-1, X-2. [pmid: 20733458].
3687 Minkoff HL, Schwarz RH. The rising cesarean section rate: can it safely be reversed?. Obstet Gynecol. Aug. 1980;56(2):135-43. X-1. [pmid: 7393501].
3688 Mino M, Puertas A, Herruzo AJ, et al. Amnioinfusion in labor induction of term pregnancies with premature rupture of the membranes and low amniotic fluid. Int J Gynaecol Obstet. May. 1998;61(2):135-40. X-1. [pmid: 9639217].
3689 Mino M, Puertas A, Miranda JA, et al. Amnioinfusion in term labor with low amniotic fluid due to rupture of membranes: a new indication. Eur J Obstet Gynecol Reprod Biol. Jan. 1999;82(1):29-34. X-4d, X-4e. [pmid: 10192481].
3690 Mints M, Jansson M, Sadeghi B, et al. Endometrial endothelial cells are derived from donor stem cells in a bone marrow transplant recipient. Hum Reprod. Jan. 2008;23(1):139-43. X-1. [pmid: 17981818].
3691 Mintz G, Niz J, Gutierrez G, et al. Prospective study of pregnancy in systemic lupus erythematosus. Results of a multidisciplinary approach. J Rheumatol. Aug. 1986;13(4):732-9. X-1. [pmid: 3772921].
3692 Miodovnik M, Mimouni F, Tsang RC, et al. Management of the insulin-dependent diabetic during labor and delivery. Influences on neonatal outcome. Am J Perinatol. Apr. 1987;4(2):106-14. X-1. [pmid: 3551973].
3693 Miovech SM, Knapp H, Borucki L, et al. Major concerns of women after cesarean delivery. J Obstet Gynecol Neonatal Nurs. Jan. 1994;23(1):53-9. X-1.
3694 Mirakhur RK, Badve AV. Pregnancy and anaethetic practice in India. Anaesthesia. Jan. 1975;30(1):18-22. X-1. [pmid: 1115337].
3695 Miranda AE, Trindade CR, Nunes RH, et al. Factors associated with prenatal care and seeking assistance in public hospitals in Vitoria, Espirito Santo, Brazil. Women Health. May. 2010;50(3):229-40. X-1. [pmid: 20512743].
3696 Miranda AF, Kyi W, Sivalingam N. Propofol and methohexitone for elective caesarean--a comparative study. Med J Malaysia. Dec. 1992;47(4):280-6. X-9. [pmid: 1303480].
3697 Mires G, Williams F, Howie P. Randomised controlled trial of cardiotocography versus Doppler auscultation of fetal heart at admission in labour in low risk obstetric population. BMJ. Jun. 16. 2001;322(7300):1457-60. discussion 1460-2. X-5. [pmid: 11408301].
3698 Mirghani HM, Hamud OA. The effect of maternal diet restriction on pregnancy outcome. Am J Perinatol. Jan. 2006;23(1):21-4. X-1. [pmid: 16450268].
3699 Mirghani OA, Saeed OK. A simplified management of diabetic pregnant woman. Saudi Med J. Apr. 2000;21(4):335-9. X-1. [pmid: 11533813].
3700 Miser WF. Outcome of infants born with nuchal cords. J Fam Pract. Apr. 1992;34(4):441-5. X-1. [pmid: 1556538].
3701 Miser WF, Blount BW, LeClair BM, et al. The practice of obstetrics by Army family physicians. J Am Board Fam Pract. May-Jun. 1996;9(3):174-81. X-1. [pmid: 8743230].
3702 Mishra US, Ramanathan M. Delivery-related complications and determinants of caesarean section rates in India. Health Policy Plan. Mar. 2002;17(1):90-8. X-1. [pmid: 11861590].
3703 Misra A. Impact of the HealthChoice program on cesarean section and vaginal birth after C-section deliveries: a retrospective analysis. Matern Child Health J. Mar. 2008;12(2):266-74. X-1. [pmid: 17549614].
3704 Mitchell CM, Johnson RF, Giles WB, et al. Prostaglandin H synthase-2 gene regulation in the amnion at labour: histone acetylation and nuclear factor kappa B binding to the promoter in vivo. Mol Hum Reprod. Jan. 2008;14(1):53-9. X-1. [pmid: 18204072].
3705 Mitchell K. The effect of the labour electronic fetal monitoring admission test on operative delivery in low-risk women: a randomised controlled trial. Evidence Based Midwifery. 2008;6(1):18-26. X-5.
3706 Mitler LK, Rizzo JA, Horwitz SM. Physician gender and cesarean sections. J Clin Epidemiol. Oct. 2000;53(10):1030-5. X-1. [pmid: 11027936].
3707 Mitra SC, Ganesh V, Apuzzio JJ. Effect of maternal cocaine abuse on renal arterial flow and urine output of the fetus. Am J Obstet Gynecol. Dec. 1994;171(6):1556-9. X-1. [pmid: 7802067].
3708 Mitt P, Lang K, Peri A, et al. Surgical-site infections following cesarean section in an Estonian university hospital: postdischarge surveillance and analysis of risk factors. Infect Control Hosp Epidemiol. May. 2005;26(5):449-54. X-1, X-9. [pmid: 15954482].
3709 Mitty HA, Sterling KM, Alvarez M, et al. Obstetric hemorrhage: prophylactic and emergency arterial catheterization and embolotherapy. Radiology. Jul. 1993;188(1):183-7. X-1. [pmid: 8511294].
3710 Miura K, Miura S, Yamasaki K, et al. Increased level of cell-free placental mRNA in a subgroup of placenta previa that needs hysterectomy. Prenat Diagn. Sep. 2008;28(9):805-9. X-1. [pmid: 18646248].
3711 Miyabe M, Sato S. The effect of head-down tilt position on arterial blood pressure after spinal anesthesia for cesarean delivery. Reg Anesth. May-Jun. 1997;22(3):239-42. X-9. [pmid: 9168215].
3712 Miyazaki FS, Taylor NA. Saline amnioinfusion for relief of variable or prolonged decelerations. A preliminary report. Am J Obstet Gynecol. Jul. 15. 1983;146(6):670-8. X-1, X-4e, X-5. [pmid: 6869437].
3713 Mockler JC, Murphy DJ, Wallace EM. An Australian and New Zealand survey of practice of the use of oxytocin at elective caesarean section. Aust N Z J Obstet Gynaecol. Feb. 2010;50(1):30-5. X-1. [pmid: 20218994].
3714 Mocumbi P, Amaral E. Reproductive rights and HIV/AIDS. Best Pract Res Clin Obstet Gynaecol. Jun. 2006;20(3):381-93. X-1. [pmid: 16564225].
3715 Modanlou HD, Dorchester WL, Thorosian A, et al. Antenatal versus neonatal transport to a regional perinatal center: a comparison between matched pairs. Obstet Gynecol. Jun. 1979;53(6):725-9. X-1. [pmid: 450342].
3716 Modanlou HD, Dorchester WL, Thorosian A, et al. Macrosomia--maternal, fetal, and neonatal implications. Obstet Gynecol. Apr. 1980;55(4):420-4. X-1. [pmid: 7366896].
3717 Moen MD, Besinger RE, Tomich PG, et al. Effect of amnioinfusion on the incidence of postpartum endometritis in patients undergoing cesarean delivery. J Reprod Med. May. 1995;40(5):383-6. X-1, X-9. [pmid: 7608881].
3718 Moffat MA, Bell JS, Porter MA, et al. Decision making about mode of delivery among pregnant women who have previously had a caesarean section: A qualitative study. BJOG. Jan. 2007;114(1):86-93. X-1. [pmid: 17233863].
3719 Moftaquir-Handaj A, Barbe F, Barbarino-Monnier P, et al. Circulating chromogranin A and catecholamines in human fetuses at uneventful birth. Pediatr Res. Jan. 1995;37(1):101-5. X-1. [pmid: 7700724].
3720 Mohamed Ismail NA, Ibrahim M, Mohd Naim N, et al. Nifedipine versus terbutaline for tocolysis in external cephalic version. Int J Gynaecol Obstet. Sep. 2008;102(3):263-6. X-4c. [pmid: 18554601].
3721 Mohta M, Agarwal D, Gupta LK, et al. Comparison of potency of ephedrine and mephentermine for prevention of post-spinal hypotension in caesarean section. Anaesth Intensive Care. May. 2008;36(3):360-4. X-9. [pmid: 18564796].
3722 Mohta M, Janani SS, Sethi AK, et al. Comparison of phenylephrine hydrochloride and mephentermine sulphate for prevention of post spinal hypotension. Anaesthesia. Dec. 2010;65(12):1200-5. X-1, X-9. [pmid: 21182601].
3723 Moini A, Riazi K, Ebrahimi A, et al. Caesarean section rates in teaching hospitals of Tehran: 1999-2003. East Mediterr Health J. Mar-Apr. 2007;13(2):457-60. X-1. [pmid: 17684866].
3724 Moir CR, Ramsey PS, Ogburn PL, et al. A prospective trial of elective preterm delivery for fetal gastroschisis. Am J Perinatol. Jul. 2004;21(5):289-94. X-1. [pmid: 15232762].
3725 Moir DD. Anaesthesia for Caesarean section. An evaluation of a method using low concentrations of halothane and 50 per cent of oxygen. Br J Anaesth. Feb. 1970;42(2):136-42. [pmid: 5440528].
3726 Moise KJ Jr., Saade G, Knudsen L, et al. Ultrasound-guided cardiac blood sampling of the rabbit fetus. Fetal Diagn Ther. Sep-Oct. 1994;9(5):331-6. X-1. [pmid: 7818782].
3727 Mokgokong ET, Crichton D. Extraperitoneal lower segment caesarean section for infected cases. A reappraisal. S Afr Med J. Apr. 17. 1974;48(18):788-90. X-9. [pmid: 4596724].
3728 Mokmeli S, Khazemikho N, Niromanesh S, et al. The application of low-level laser therapy after cesarean section does not compromise blood prolactin levels and lactation status. Photomed Laser Surg. Jun. 2009;27(3):509-12. X-9. [pmid: 19405857].
3729 Mokriski BK, Malinow AM. Neonatal acid-base status following general anesthesia for emergency abdominal delivery with halothane or isoflurane. J Clin Anesth. Mar-Apr. 1992;4(2):97-100. X-3, X-4b, X-4e, X-5. [pmid: 1562344].
3730 Mola G, Rageau O. Augmentation of labour by a standard protocol in Papua New Guinea. Asia Oceania J Obstet Gynaecol. Sep. 1990;16(3):219-24. X-1. [pmid: 2088245].
3731 Molkenboer JF, Debie S, Roumen FJ, et al. Maternal health outcomes two years after term breech delivery. J Matern Fetal Neonatal Med. Apr. 2007;20(4):319-24. X-1. [pmid: 17437240].
3732 Molkenboer JF, Debie S, Roumen FJ, et al. Mothers' views of their childbirth experience two years after term breech delivery. J Psychosom Obstet Gynaecol. Mar. 2008;29(1):39-44. X-1. [pmid: 17852657].
3733 Molkenboer JF, Reijners EP, Nijhuis JG, et al. Moderate neonatal morbidity after vaginal term breech delivery. J Matern Fetal Neonatal Med. Dec. 2004;16(6):357-61. X-4c, X-5. [pmid: 15621556].
3734 Molkenboer JF, Vencken PM, Sonnemans LG, et al. Conservative management in breech deliveries leads to similar results compared with cephalic deliveries. J Matern Fetal Neonatal Med. Aug. 2007;20(8):599-603. X-1. [pmid: 17674277].
3735 Mollberg M, Hagberg H, Bager B, et al. High birthweight and shoulder dystocia: the strongest risk factors for obstetrical brachial plexus palsy in a Swedish population-based study. Acta Obstet Gynecol Scand. Jul. 2005;84(7):654-9. X-1. [pmid: 15954875].
3736 Moller M, Thomsen AC, Sorensen J, et al. Oxytocin- or low-dose prostaglandin F2 alpha-infusion for stimulation of labor after primary rupture of membranes. A prospective, randomized trial. Acta Obstet Gynecol Scand. 1987;66(2):103-6. X-4d, X-4e, X-5. [pmid: 3303813].
3737 Mollica G, Pittini L, Minganti E, et al. Elective uterine myomectomy in pregnant women. Clin Exp Obstet Gynecol. 1996;23(3):168-72. X-1. [pmid: 8894327].
3738 Monari F, Di Mario S, Facchinetti F, et al. Obstetricians' and midwives' attitudes toward cesarean section. Birth. Jun. 2008;35(2):129-35. X-1. [pmid: 18507584].
3739 Monincx WM, Birnie E, Zondervan HA, et al. Maternal health, antenatal and at 8 weeks after delivery, in home versus in-hospital fetal monitoring in high-risk pregnancies. Eur J Obstet Gynecol Reprod Biol. Feb. 2001;94(2):197-204. X-3, X-4e, X-5. [pmid: 11165725].
3740 Monir-Bishty E, Pierce SJ, Kupittayanant S, et al. The effects of metabolic inhibition on intracellular calcium and contractility of human myometrium. BJOG. Dec. 2003;110(12):1050-6. X-1. [pmid: 14664875].
3741 Montgomery AA, Emmett CL, Fahey T, et al. Two decision aids for mode of delivery among women with previous caesarean section: randomised controlled trial. BMJ. Jun. 23. 2007;334(7607):1305. X-4b. [pmid: 17540908].
3742 Montgomery J. Deciding for others. Bull Med Ethics. May. 1999;(No. 148):18-20. X-1, X-2.
3743 Moodley J, Gouws E. A comparative study of the use of epoprostenol and dihydralazine in severe hypertension in pregnancy. Br J Obstet Gynaecol. Sep. 1992;99(9):727-30. X-4e, X-5. [pmid: 1420010].
3744 Moodley J, Venkatachalam S, Songca P. Misoprostol for cervical ripening at and near term--a comparative study. S Afr Med J. May. 2003;93(5):371-4. X-4d. [pmid: 12830602].
3745 Moodley J, Zeeman DJ. Prophylactic and antimicrobial therapy using lincomycin in patients undergoing emergency caesarean section. S Afr Med J. Jun. 13. 1981;59(25):911-3. X-9. [pmid: 7015540].
3746 Moon S. C-section rebirth. Procedure making strong comeback after a decade. Mod Healthc. Jul. 8. 2002;32(27):18. X-1, X-9. [pmid: 12141168].
3747 Moore A, Costello J, Wieczorek P, et al. Gabapentin improves postcesarean delivery pain management: a randomized, placebo-controlled trial. Anesth Analg. Jan. 2011;112(1):167-73. X-9. [pmid: 21081764].
3748 Moore CH, Wilhite A, Pan PH, et al. The addition of epinephrine to subarachnoid administered hyperbaric bupivacaine with fentanyl for cesarean delivery: the effect on onset time. Reg Anesth. Jul-Aug. 1992;17(4):202-4. X-9. [pmid: 1515385].
3749 Moore J, Bill KM, Flynn RJ, et al. A comparison between propofol and thiopentone as induction agents in obstetric anaesthesia. Anaesthesia. Sep. 1989;44(9):753-7. X-1, X-9. [pmid: 2802123].
3750 Moore LE, Briery CM, Clokey D, et al. Metformin and insulin in the management of gestational diabetes mellitus: preliminary results of a comparison. J Reprod Med. Nov. 2007;52(11):1011-5. X-4e, X-5. [pmid: 18161398].
3751 Moore MP, Redman CW. Case-control study of severe pre-eclampsia of early onset. Br Med J (Clin Res Ed). Aug. 27. 1983;287(6392):580-3. X-1.
3752 Moore TR, Origel W, Key TC, et al. The perinatal and economic impact of prenatal care in a low-socioeconomic population. Am J Obstet Gynecol. Jan. 1986;154(1):29-33. X-1. [pmid: 3946500].
3753 Morales M, Ceysens G, Jastrow N, et al. Spontaneous delivery or manual removal of the placenta during caesarean section: a randomised controlled trial. BJOG. Sep. 2004;111(9):908-12. X-9. [pmid: 15327603].
3754 Morales WJ, Lazar AJ. Expectant management of rupture of membranes at term. South Med J. Aug. 1986;79(8):955-8. X-4e, X-5. [pmid: 3526572].
3755 Moran DH, Perillo M, LaPorta RF, et al. Phenylephrine in the prevention of hypotension following spinal anesthesia for cesarean delivery. J Clin Anesth. Jul-Aug. 1991;3(4):301-5. X-9. [pmid: 1910798].
3756 Morgan MA, Berkowitz KM, Thomas SJ, et al. Abruptio placentae: perinatal outcome in normotensive and hypertensive patients. Am J Obstet Gynecol. Jun. 1994;170(6):1595-9. X-1. [pmid: 8203415].
3757 Morgan MA, Goldenberg RL, Schulkin J. Obstetrician-gynecologists' practices regarding preterm birth at the limit of viability. J Matern Fetal Neonatal Med. Feb. 2008;21(2):115-21. X-1. [pmid: 18240080].
3758 Morgan PJ, Halpern S, Lam-McCulloch J. Comparison of maternal satisfaction between epidural and spinal anesthesia for elective Cesarean section. Can J Anaesth. Oct. 2000;47(10):956-61. X-9. [pmid: 11032269].
3759 Morgan PJ, Mehta S, Kapala DM. Nalbuphine pretreatment in cesarean section patients receiving epidural morphine. Reg Anesth. Mar-Apr. 1991;16(2):84-8. X-9. [pmid: 2043531].
3760 Morganstern PS. Court-ordered caesarean sections: round II. Healthspan. Jun. 1990;7(6):10-1. X-9. [pmid: 10105176].
3761 Morhason-Bello IO, Adedokun BO, Ojengbede OA, et al. Assessment of the effect of psychosocial support during childbirth in Ibadan, south-west Nigeria: a randomised controlled trial. Aust N Z J Obstet Gynaecol. Apr. 2009;49(2):145-50. X-6. [pmid: 19432601].
3762 Mori M, Davies TW, Tsukamoto T, et al. Maternal and other factors of cryptorchidism--a case-control study in Japan. Kurume Med J. 1992;39(2):53-60. X-1. [pmid: 1357225].
3763 Moriarty KT, Onwuzurike B, Jones JJ, et al. The 30 minutes decision-to-delivery interval for ‘urgent’ caesarean sections: an elusive target. J Obstet Gynaecol. Nov. 2006;26(8):736-9. X-1. [pmid: 17130018].
3764 Morikawa M, Yamada T, Shimada S, et al. Pregnancy-induced antithrombin deficiency. J Perinat Med. Jul. 2010;38(4):379-85. X-1. [pmid: 20443661].
3765 Morkved S, Bo K. Effect of postpartum pelvic floor muscle training in prevention and treatment of urinary incontinence: a one-year follow up. BJOG. Aug. 2000;107(8):1022-8. X-1, X-3, X-4e. [pmid: 10955436].
3766 Morley R, Moore VM, Dwyer T, et al. Association between erythropoietin in cord blood of twins and size at birth: does it relate to gestational factors or to factors during labor or delivery?. Pediatr Res. May. 2005;57(5 Pt 1):680-4. X-1. [pmid: 15718359].
3767 Moro M, Andrews M. Prophylactic antibiotics in cesarean section. Obstet Gynecol. Nov. 1974;44(5):688-92. X-9. [pmid: 4608263].
3768 Moro M, Perez-Rodriguez J, Figueras-Aloy J, et al. Predischarge morbidities in extremely and very low-birth-weight infants in Spanish neonatal units. Am J Perinatol. May. 2009;26(5):335-43. X-1. [pmid: 19090453].
3769 Moroni GA, Cossu MM, Barbarani V. Vertical transmission of hepatitis B. Boll Ist Sieroter Milan. Jan. 31. 1979;57(6):779-85. X-1. [pmid: 552825].
3770 Morris A. Life and death decisions: “Die, my dear doctor? That's the last thing I shall do!. Eur J Health Law. Mar. 1996;3(1):9-28. X-1. [pmid: 11654851].
3771 Morris C, Sullivan MH, Elder MG. Transfer and metabolism of platelet-activating factor by fetal membranes, amnion and chorio-decidua. Br J Obstet Gynaecol. Nov. 1992;99(11):895-8. X-1, X-9. [pmid: 1450138].
3772 Morris JA Jr., Rosenbower TJ, Jurkovich GJ, et al. Infant survival after cesarean section for trauma. Ann Surg. May. 1996;223(5):481-8. discussion 488-91. X-1, X-9. [pmid: 8651739].
3773 Morris JM, Thompson K, Smithey J, et al. The usefulness of ultrasound assessment of amniotic fluid in predicting adverse outcome in prolonged pregnancy: a prospective blinded observational study. BJOG. Nov. 2003;110(11):989-94. X-1. [pmid: 14592583].
3774 Morrison JC, Coxwell WL, Kennedy BS, et al. The use of prophylactic antibiotics in patients undergoing cesarean section. Surg Gynecol Obstet. Mar. 1973;136(3):425-8. X-9. [pmid: 4688806].
3775 Morrow RJ, Rolbin SH, Ritchie JW, et al. Epidural anaesthesia and blood flow velocity in mother and fetus. Can J Anaesth. Sep. 1989;36(5):519-22. X-1, X-9. [pmid: 2676221].
3776 Morton CP, Bloomfield S, Magnusson A, et al. Ropivacaine 0.75% for extradural anaesthesia in elective caesarean section: an open clinical and pharmacokinetic study in mother and neonate. Br J Anaesth. Jul. 1997;79(1):3-8. X-1. [pmid: 9301380].
3777 Moschini V, Marra G, Dabrowska D. Complications of epidural and combined spinal-epidural analgesia in labour. Minerva Anestesiol. Jan-Feb. 2006;72(1-2):47-58. X-1. [pmid: 16407806].
3778 Moses J, Doherty DA, Magann EF, et al. A randomized clinical trial of the intrapartum assessment of amniotic fluid volume: amniotic fluid index versus the single deepest pocket technique. Am J Obstet Gynecol. Jun. 2004;190(6):1564-9. discussion 1569-70. X-5, X-6. [pmid: 15284736].
3779 Moses RG, Knights SJ, Lucas EM, et al. Gestational diabetes: is a higher cesarean section rate inevitable?. Diabetes Care. Jan. 2000;23(1):15-7. X-1. [pmid: 10857961].
3780 Moss JR, Crowther CA, Hiller JE, et al. Costs and consequences of treatment for mild gestational diabetes mellitus - evaluation from the ACHOIS randomised trial. BMC Pregnancy Childbirth. 2007;7:27. X-1, X-3, X-4e, X-5. [pmid: 17963528].
3781 Most O, Langer O. GDM women in good glycemic control: which meal-related measure enhances fetal well-being?. J Perinat Med. 2007;35(6):481-5. X-1. [pmid: 18052834].
3782 Mould TA, Chong S, Spencer JA, et al. Women's involvement with the decision preceding their caesarean section and their degree of satisfaction. Br J Obstet Gynaecol. Nov. 1996;103(11):1074-7. X-1, X-9. [pmid: 8916991].
3783 Mousa WF, Al-Metwalli RR, Mostafa M. Epidural analgesia during labor--0.5% lidocaine with fentanyl vs. 0.08% ropivacaine with fentanyl. Middle East J Anesthesiol. Feb. 2010;20(4):521-7. X-4e, X-5. [pmid: 20394248].
3784 Mouzinho A, Rosenfeld CR, Sanchez PJ, et al. Effect of maternal hypertension on neonatal neutropenia and risk of nosocomial infection. Pediatrics. Sep. 1992;90(3):430-5. X-1. [pmid: 1518702].
3785 Moya F, Mena P, Heusser F, et al. Response of the maternal, fetal, and neonatal pituitary-thyroid axis to thyrotropin-releasing hormone. Pediatr Res. Oct. 1986;20(10):982-6. X-9. [pmid: 3095783].
3786 Moya FR, Reece EA, Hobbins JC. Fetal-neonatal uremia in advanced maternal diabetes. Clin Pediatr (Phila). Apr. 1984;23(4):229-31. X-1. [pmid: 6697631].
3787 Moynihan AT, Smith TJ, Morrison JJ. The relaxant effect of nifedipine in human uterine smooth muscle and the BK(Ca) channel. Am J Obstet Gynecol. Feb. 2008;198(2):237 e1-8. X-1, X-9. [pmid: 18226634].
3788 Mozurkewich E, Horrocks J, Daley S, et al. The MisoPROM study: a multicenter randomized comparison of oral misoprostol and oxytocin for premature rupture of membranes at term. Am J Obstet Gynecol. Oct. 2003;189(4):1026-30. X-3, X-4d, X-4e, X-5. [pmid: 14586349].
3789 Mridha MK, Anwar I, Koblinsky M. Public-sector maternal health programmes and services for rural Bangladesh. J Health Popul Nutr. Apr. 2009;27(2):124-38. X-1. [pmid: 19489411].
3790 Mu SC, Lin CH, Sung TC, et al. Neurodevelopmental outcome of very-low-birth-weight infants with chorioamnionitis. Acta Paediatr Taiwan. Jul-Aug. 2007;48(4):207-12. X-1. [pmid: 18265542].
3791 Mugford M, Kingston J, Chalmers I. Reducing the incidence of infection after caesarean section: implications of prophylaxis with antibiotics for hospital resources. BMJ. Oct. 21. 1989;299(6706):1003-6. X-9. [pmid: 2511938].
3792 Mukasa FM. Comparison of pregnancy and labour in teenagers and primigravidas aged 21-25 years in Transkei. S Afr Med J. Apr. 18. 1992;81(8):421-3. X-1. [pmid: 1566217].
3793 Mukherjee S, Sood M. Towards a safer motherhood. J Indian Med Assoc. Mar. 1995;93(3):98-100. 89. X-1, X-4d, X-5. [pmid: 8522824].
3794 Mulayim B, Celik NY, Kaya S, et al. Early oral hydration after cesarean delivery performed under regional anesthesia. Int J Gynaecol Obstet. Jun. 2008;101(3):273-6. X-9. [pmid: 18279877].
3795 Muller PR, Stubbs TM, Laurent SL. A prospective randomized clinical trial comparing two oxytocin induction protocols. Am J Obstet Gynecol. Aug. 1992;167(2):373-80. discussion 380-1. X-4d, X-5. [pmid: 1497039].
3796 Mulvihill SJ, Stone MM, Debas HT, et al. The role of amniotic fluid in fetal nutrition. J Pediatr Surg. Dec. 1985;20(6):668-72. X-1, X-3. [pmid: 4087096].
3797 Mundle WR, Young DC. Vaginal misoprostol for induction of labor: a randomized controlled trial. Obstet Gynecol. Oct. 1996;88(4 Pt 1):521-5. X-4d, X-5. [pmid: 8841210].
3798 Mungen E, Tutuncu L, Muhcu M, et al. Pregnancy outcome following second-trimester amniocentesis: a case-control study. Am J Perinatol. Jan. 2006;23(1):25-30. X-1. [pmid: 16450269].
3799 Munkhaugen J, Lydersen S, Romundstad PR, et al. Kidney function and future risk for adverse pregnancy outcomes: a population-based study from HUNT II, Norway. Nephrol Dial Transplant. Dec. 2009;24(12):3744-50. X-1. [pmid: 19578097].
3800 Munn MB, Owen J, Vincent R, et al. Comparison of two oxytocin regimens to prevent uterine atony at cesarean delivery: a randomized controlled trial. Obstet Gynecol. Sep. 2001;98(3):386-90. X-9. [pmid: 11530117].
3801 Munn MB, Rouse DJ, Owen J. Intraoperative hypothermia and post-cesarean wound infection. Obstet Gynecol. Apr. 1998;91(4):582-4. X-1, X-9. [pmid: 9540945].
3802 Munoz FM, Greisinger AJ, Wehmanen OA, et al. Safety of influenza vaccination during pregnancy. Am J Obstet Gynecol. Apr. 2005;192(4):1098-106. X-1. [pmid: 15846187].
3803 Munro BH, Jacobsen BS, Brooten DA. Re-examination of the psychometric characteristics of the La Monica-Oberst Patient Satisfaction Scale. Res Nurs Health. Apr. 1994;17(2):119-25. X-1. [pmid: 8127992].
3804 Murphy AJ, Jalland M, Pepperell RJ, et al. Use of vaginal prostaglandin gel before induction of labour. Aust N Z J Obstet Gynaecol. May. 1980;20(2):84-6. X-1, X-5. [pmid: 6932208].
3805 Murphy DF, Nally B, Gardiner J, et al. Effect of metoclopramide on gastric emptying before elective and emergency caesarean section. Br J Anaesth. Oct. 1984;56(10):1113-6. X-1. [pmid: 6477792].
3806 Murphy DJ, Carey M, Montgomery AA, et al. Study protocol. ECSSIT - Elective Caesarean Section Syntocinon Infusion Trial. A multi-centre randomised controlled trial of oxytocin (Syntocinon) 5 IU bolus and placebo infusion versus oxytocin 5 IU bolus and 40 IU infusion for the control of blood loss at elective caesarean section. BMC Pregnancy Childbirth. 2009;9:36. X-9. [pmid: 19703279].
3807 Murphy DJ, Liebling RE. Cohort study of maternal views on future mode of delivery after operative delivery in the second stage of labor. Am J Obstet Gynecol. Feb. 2003;188(2):542-8. X-1. [pmid: 12592269].
3808 Murphy DJ, Liebling RE, Patel R, et al. Cohort study of operative delivery in the second stage of labour and standard of obstetric care. BJOG. Jun. 2003;110(6):610-5. X-1. [pmid: 12798481].
3809 Murphy DJ, MacGregor H, Munishankar B, et al. A randomised controlled trial of oxytocin 5IU and placebo infusion versus oxytocin 5IU and 30IU infusion for the control of blood loss at elective caesarean section--pilot study. ISRCTN 40302163. Eur J Obstet Gynecol Reprod Biol. Jan. 2009;142(1):30-3. X-9. [pmid: 18977579].
3810 Murphy DJ, Pope C, Frost J, et al. Women's views on the impact of operative delivery in the second stage of labour: qualitative interview study. BMJ. Nov. 15. 2003;327(7424):1132. X-1. [pmid: 14615336].
3811 Murphy JD, Henderson K, Bowden MI, et al. Bupivacaine versus bupivacaine plus fentanyl for epidural analgesia: effect on maternal satisfaction. BMJ. Mar. 9. 1991;302(6776):564-7. X-5. [pmid: 2021719].
3812 Murphy JF. The relentless rise in caesarean sections. Ir Med J. Jul-Aug. 2001;94(7):196. X-1. [pmid: 11693205].
3813 Murphy JR, Haverkamp AD, Langendoerfer S, et al. The relation of electronic fetal monitoring patterns to infant outcome measures in a random sample of term size infants born to high risk mothers. Am J Epidemiol. Oct. 1981;114(4):539-47. X-1, X-4e, X-5. [pmid: 7304584].
3814 Murphy KW, Hanretty KP, Inglis GC. Fetal catecholamine responses to vibroacoustic stimulation. Am J Obstet Gynecol. Dec. 1993;169(6):1571-7. X-3, X-4b, X-5. [pmid: 8267064].
3815 Murphy MC, Harvey SM. Choice of a childbirth method after cesarean. Women Health. 1989;15(2):67-85. X-1. [pmid: 2781811].
3816 Murray AM, Morgan M, Whitwam JG. Crystalloid versus colloid for circulatory preload for epidural caesarean section. Anaesthesia. Jun. 1989;44(6):463-6. X-9. [pmid: 2474257].
3817 Murray HG, Buonocore A, Hawley J. A randomized trial of two preparations of vaginal prostaglandin for pre-induction cervical ripening. Obstet Gynecol. Dec. 1995;86(6):880-5. X-4d, X-5. [pmid: 7501332].
3818 Murta EF, de Souza FH, de Souza MA, et al. High-grade cervical squamous intraepithelial lesion during pregnancy. Tumori. May-Jun. 2002;88(3):246-50. X-1. [pmid: 12195765].
3819 Murtha AP, Kaplan AL, Paglia MJ, et al. Evaluation of a novel technique for wound closure using a barbed suture. Plast Reconstr Surg. May. 2006;117(6):1769-80. X-9. [pmid: 16651950].
3820 Musk GC, Polglase GR, Bunnell JB, et al. High positive end-expiratory pressure during high-frequency jet ventilation improves oxygenation and ventilation in preterm lambs. Pediatr Res. Apr. 2011;69(4):319-24. X-1. [pmid: 21178822].
3821 Mutabingwa TK, Malle LN, Verhave JP, et al. Malaria chemosuppression during pregnancy. IV. Its effects on the newborn's passive malaria immunity. Trop Geogr Med. 1993;45(4):150-6. X-1, X-4e. [pmid: 8236464].
3822 Mutihir JT, Nyiputen YA. The unbooked patient: a lingering obstetric pathology in Jos, Nigeria. J Obstet Gynaecol. Oct. 2007;27(7):695-8. X-1. [pmid: 17999295].
3823 Mutlu Meydanli M, Caliskan E, Haberal A. Prediction of adverse outcome associated with vaginal misoprostol for labor induction. Eur J Obstet Gynecol Reprod Biol. Oct. 10. 2003;110(2):143-8. X-1. [pmid: 12969573].
3824 Muzlifah KB, Choy YC. Comparison between preloading with 10 ml/kg and 20 ml/kg of Ringer's lactate in preventing hypotension during spinal anaesthesia for caesarean section. Med J Malaysia. Jun. 2009;64(2):114-7. X-9. [pmid: 20058569].
3825 Mychaliska GB, Bealer JF, Graf JL, et al. Operating on placental support: the ex utero intrapartum treatment procedure. J Pediatr Surg. Feb. 1997;32(2):227-30. discussion 230-1. X-1. [pmid: 9044127].
3826 Myers JE, Hart S, Armstrong S, et al. Evidence for multiple circulating factors in preeclampsia. Am J Obstet Gynecol. Mar. 2007;196(3):266 e1-6. X-1. [pmid: 17346549].
3827 Myers SA, Gleicher N. A successful program to lower cesarean-section rates. N Engl J Med. Dec. 8. 1988;319(23):1511-6. [pmid: 3185675].
3828 Myles T. Vaginal birth of twins after a previous Cesarean section. J Matern Fetal Med. Jun. 2001;10(3):171-4. X-1. [pmid: 11444785].
3829 Myles TD. Is there an obstetric July phenomenon?. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1080-4. X-1. [pmid: 14672490].
3830 Myles TD, Santolaya-Forgas J. Normal ultrasonic evaluation of amniotic fluid in low-risk patients at term. J Reprod Med. Aug. 2002;47(8):621-4. X-1. [pmid: 12216427].
3831 Nabhan AF. Long-term outcomes of two different surgical techniques for cesarean. Int J Gynaecol Obstet. Jan. 2008;100(1):69-75. X-9. [pmid: 17904561].
3832 Nabhan AF, El-Din LB, Rabie AH, et al. Impact of intrapartum factors on oxidative stress in newborns. J Matern Fetal Neonatal Med. Oct. 2009;22(10):867-72. X-3, X-4e, X-5. [pmid: 19488955].
3833 Nachshon I, Denno D. Birth stress and lateral preferences. Cortex. Mar. 1987;23(1):45-58. X-1. [pmid: 3568705].
3834 Nachum Z, Ben-Shlomo I, Weiner E, et al. Twice daily versus four times daily insulin dose regimens for diabetes in pregnancy: randomised controlled trial. BMJ. Nov. 6. 1999;319(7219):1223-7. X-4e, X-5. [pmid: 10550081].
3835 Naef RW 3rd, Chauhan SP, Chevalier SP, et al. Prediction of hemorrhage at cesarean delivery. Obstet Gynecol. Jun. 1994;83(6):923-6. X-1. [pmid: 8190432].
3836 Naef RW 3rd, Ray MA, Chauhan SP, et al. Trial of labor after cesarean delivery with a lower-segment, vertical uterine incision: is it safe?. Am J Obstet Gynecol. Jun. 1995;172(6):1666-73. discussion 1673-4. X-1. [pmid: 7778619].
3837 Nafisi S. Influence of uterine exteriorization versus in situ repair on post-Cesarean maternal pain: a randomized trial. Int J Obstet Anesth. Apr. 2007;16(2):135-8. X-9. [pmid: 17276669].
3838 Nagele F, Karas H, Spitzer D, et al. Closure or nonclosure of the visceral peritoneum at cesarean delivery. Am J Obstet Gynecol. Apr. 1996;174(4):1366-70. X-9. [pmid: 8623871].
3839 Nageotte MP, Bertucci L, Towers CV, et al. Prophylactic amnioinfusion in pregnancies complicated by oligohydramnios: a prospective study. Obstet Gynecol. May. 1991;77(5):677-80. X-3, X-4e, X-5. [pmid: 2014078].
3840 Nageotte MP, Freeman RK, Garite TJ, et al. Prophylactic intrapartum amnioinfusion in patients with preterm premature rupture of membranes. Am J Obstet Gynecol. Nov. 1. 1985;153(5):557-62. X-1, X-4e, X-5. [pmid: 3904456].
3841 Nageotte MP, Larson D, Rumney PJ, et al. Epidural analgesia compared with combined spinal-epidural analgesia during labor in nulliparous women. N Engl J Med. Dec. 11. 1997;337(24):1715-9. X-5. [pmid: 9392696].
3842 Nageotte MP, Towers CV, Asrat T, et al. Perinatal outcome with the modified biophysical profile. Am J Obstet Gynecol. Jun. 1994;170(6):1672-6. X-5. [pmid: 8203424].
3843 Nageotte MP, Towers CV, Asrat T, et al. The value of a negative antepartum test: contraction stress test and modified biophysical profile. Obstet Gynecol. Aug. 1994;84(2):231-4. X-4e. [pmid: 8041536].
3844 Nager CW, Key TC, Moore TR. Cervical ripening and labor outcome with preinduction intracervical prostaglandin E2 (Prepidil) gel. J Perinatol. Summer. 1987;7(3):189-93. X-1. [pmid: 3504454].
3845 Naguib AH, Morsi HM, Borg TF, et al. Vaginal misoprostol for second-trimester pregnancy termination after one previous cesarean delivery. Int J Gynaecol Obstet. Jan. 2010;108(1):48-51. X-1. [pmid: 19781700].
3846 Nagy G. Management of gestational diabetes. Zentralbl Gynakol. 1993;115(4):147-53. X-1. [pmid: 8503231].
3847 Nagy S, Bush M, Stone J, et al. Clinical significance of subchorionic and retroplacental hematomas detected in the first trimester of pregnancy. Obstet Gynecol. Jul. 2003;102(1):94-100. X-1. [pmid: 12850613].
3848 Nahar S, Costello A. The hidden cost of ‘free’ maternity care in Dhaka, Bangladesh. Health Policy Plan. Dec. 1998;13(4):417-22. X-1. [pmid: 10346033].
3849 Nakayama M, Yamamoto J, Ichinose H, et al. Effects of volume and concentration of lidocaine on epidural anaesthesia in pregnant females. Eur J Anaesthesiol. Nov. 2002;19(11):808-11. X-9. [pmid: 12442930].
3850 Naki MM, Api O, Celik H, et al. Comparative study of Misgav-Ladach and Pfannenstiel-Kerr cesarean techniques: a randomized controlled trial. J Matern Fetal Neonatal Med. Feb. 2011;24(2):239-44. X-9. [pmid: 20712425].
3851 Namba Y, Smith JB, Fox GS, et al. Plasma cortisol concentrations during Caesarean section. Br J Anaesth. Oct. 1980;52(10):1027-32. X-1. [pmid: 7437211].
3852 Narchi P, Benhamou D, Hamza J, et al. Ventilatory effects of epidural clonidine during the first 3 hours after caesarean section. Acta Anaesthesiol Scand. Nov. 1992;36(8):791-5. X-9. [pmid: 1466216].
3853 Nasir A, Korejo R, Noorani KJ. Child birth in squatting position. J Pak Med Assoc. Jan. 2007;57(1):19-22. X-4e, X-5. [pmid: 17319414].
3854 Nasr AM, ElBigawy AF, Abdelamid AE, et al. Evaluation of the use vs nonuse of urinary catheterization during cesarean delivery: a prospective, multicenter, randomized controlled trial. J Perinatol. Jun. 2009;29(6):416-21. X-3, X-4b, X-5. [pmid: 19212327].
3855 Nasrat H, Fageeh W, Abalkhail B, et al. Determinants of pregnancy outcome in patients with gestational diabetes. Int J Gynaecol Obstet. May. 1996;53(2):117-23. X-1. [pmid: 8735291].
3856 Nassar AH, Awwad J, Khalil AM, et al. A randomised comparison of patient satisfaction with vaginal and sublingual misoprostol for induction of labour at term. BJOG. Oct. 2007;114(10):1215-21. X-4d, X-5. [pmid: 17877674].
3857 Nassar AH, Fayyumy R, Saab W, et al. Grandmultiparas in modern obstetrics. Am J Perinatol. Aug. 2006;23(6):345-9. X-1. [pmid: 16841276].
3858 Nassar AH, Usta IM, Rechdan JB, et al. Pregnancy outcome in spontaneous twins versus twins who were conceived through in vitro fertilization. Am J Obstet Gynecol. Aug. 2003;189(2):513-8. X-1. [pmid: 14520227].
3859 Nassar N, Roberts CL, Raynes-Greenow CH, et al. Development and pilot-testing of a decision aid for women with a breech-presenting baby. Midwifery. Mar. 2007;23(1):38-47. X-1. [pmid: 16843575].
3860 Natale A, Davidson T, Geiger MJ, et al. Implantable cardioverter-defibrillators and pregnancy: a safe combination?. Circulation. Nov. 4. 1997;96(9):2808-12. X-1. [pmid: 9386142].
3861 Natale R, Milne JK, Campbell MK, et al. Management of premature rupture of membranes at term: randomized trial. Am J Obstet Gynecol. Oct. 1994;171(4):936-9. X-4e. [pmid: 7943104].
3862 Naulty JS, Datta S, Ostheimer GW, et al. Epidural fentanyl for postcesarean delivery pain management. Anesthesiology. Dec. 1985;63(6):694-8. X-9. [pmid: 2865914].
3863 Naumann RW, Hauth JC, Owen J, et al. Subcutaneous tissue approximation in relation to wound disruption after cesarean delivery in obese women. Obstet Gynecol. Mar. 1995;85(3):412-6. X-9. [pmid: 7862382].
3864 Navaneethakrishnan R, Anderson A, Holding S, et al. A randomised controlled trial of placental cord drainage to reduce feto-maternal transfusion. Eur J Obstet Gynecol Reprod Biol. Mar. 2010;149(1):27-30. X-3, X-4e, X-5. [pmid: 20018421].
3865 Navot D, Mor-Yosef S, Granat M, et al. Antepartum fetal heart rate pattern associated with major congenital malformations. Obstet Gynecol. Mar. 1984;63(3):414-7. X-1, X-4e. [pmid: 6700867].
3866 Nayar R, Sahajanand H. Does anesthetic induction for Cesarean section with a combination of ketamine and thiopentone confer any benefits over thiopentone or ketamine alone? A prospective randomized study. Minerva Anestesiol. Apr. 2009;75(4):185-90. X-9. [pmid: 18946429].
3867 Naylor CD, Sermer M, Chen E, et al. Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. JAMA. Apr. 17. 1996;275(15):1165-70. X-1. [pmid: 8609683].
3868 Naz T, Mehr un N, Hassan L. Eclampsia--management and outcome with magnesium sulphate as the anticonvulsant. J Coll Physicians Surg Pak. Oct. 2005;15(10):624-7. X-1. [pmid: 19810301].
3869 Ndiweni Q, Buchmann EJ. Unbooked mothers and their babies--what causes the poor outcomes?. S Afr Med J. Feb. 195. 1998;88(2 Suppl):192-6. 199. X-1. [pmid: 9542486].
3870 Neary RH, Kilby MD, Kumpatula P, et al. Fetal and maternal lipoprotein metabolism in human pregnancy. Clin Sci (Lond). Mar. 1995;88(3):311-8. X-1. [pmid: 7736700].
3871 Neau JP, Marion P, Mathis S, et al. Restless legs syndrome and pregnancy: follow-up of pregnant women before and after delivery. Eur Neurol. 2010;64(6):361-6. X-1, X-4e. [pmid: 21088424].
3872 Needleman J, Minnick AF. Anesthesia provider model, hospital resources, and maternal outcomes. Health Serv Res. Apr. 2009;44(2 Pt 1):464-82. X-1. [pmid: 19178582].
3873 Neilson DR Jr., Prins RP, Bolton RN, et al. A comparison of prostaglandin E2 gel and prostaglandin F2 alpha gel for preinduction cervical ripening. Am J Obstet Gynecol. Jul. 1. 1983;146(5):526-32. X-4e. [pmid: 6344644].
3874 Neldam S, Osler M, Hansen PK, et al. Intrapartum fetal heart rate monitoring in a combined low- and high-risk population: a controlled clinical trial. Eur J Obstet Gynecol Reprod Biol. Oct. 1986;23(1-2):1-11. X-4e, X-5. [pmid: 3536631].
3875 Nelson CR, Parkes JR. Placental localisation using the Doppler portable ultrasonic apparatus. S Afr Med J. Nov. 30. 1974;48(58):2393-5. X-1, X-4e. [pmid: 4432198].
3876 Nelson EA, Taylor BJ. International child care practices study: methods and study population. Early Hum Dev. Jun. 1999;55(2):149-68. X-1. [pmid: 10390090].
3877 Nelson KB, Dambrosia JM, Ting TY, et al. Uncertain value of electronic fetal monitoring in predicting cerebral palsy. N Engl J Med. Mar. 7. 1996;334(10):613-8. X-1. [pmid: 8592523].
3878 Nelson LD, Grobman WA. Obstetric morbidity associated with amniotic sheets. Ultrasound Obstet Gynecol. Sep. 2010;36(3):324-7. X-1. [pmid: 20131329].
3879 Nelson LJ. Compulsory treatment of pregnant women. Clin Ethics Rep. May. 1987;1(5):1-8. X-1, X-2.
3880 Nelson LJ, Buggy BP, Weil CJ. Forced medical treatment of pregnant women: “compelling each to live as seems good to the rest. Hastings Law J. May. 1986;37(5):703-63. X-1, X-2. [pmid: 11655855].
3881 Nelson RL, Furner SE, Westercamp M, et al. Cesarean delivery for the prevention of anal incontinence. Cochrane Database of Systematic Reviews. 2010;(2). X-1.
3882 Nelson SH, Suresh MS. Lack of reactivity of uterine arteries from patients with obstetric hemorrhage. Am J Obstet Gynecol. May. 1992;166(5):1436-43. X-1. [pmid: 1317676].
3883 Nelson WL, O'Brien JM. The uterine sandwich for persistent uterine atony: combining the B-Lynch compression suture and an intrauterine Bakri balloon. Am J Obstet Gynecol. May. 2007;196(5):e9-10. X-1, X-9. [pmid: 17466689].
3884 Nemunaitis-Keller J, Gill P. Limitations of the obstetric group B Streptococcus protocol. J Reprod Med. Feb. 2003;48(2):107-11. X-1. [pmid: 12621794].
3885 Neri I, Airola G, Contu G, et al. Acupuncture plus moxibustion to resolve breech presentation: a randomized controlled study. J Matern Fetal Neonatal Med. Apr. 2004;15(4):247-52. X-4d, X-4c. [pmid: 15280133].
3886 Nerum H, Halvorsen L, Oian P, et al. Birth outcomes in primiparous women who were raped as adults: a matched controlled study. BJOG. Feb. 2010;117(3):288-94. X-1. [pmid: 20015304].
3887 Nerum H, Halvorsen L, Sorlie T, et al. Maternal request for cesarean section due to fear of birth: can it be changed through crisis-oriented counseling?. Birth. Sep. 2006;33(3):221-8. X-1. [pmid: 16948722].
3888 Neuhoff D, Burke MS, Porreco RP. Cesarean birth for failed progress in labor. Obstet Gynecol. Jun. 1989;73(6):915-20. X-1. [pmid: 2726112].
3889 Neuman M, Langer R, Bachar R, et al. Penicillin-tetracycline prophylaxis in cesarean delivery: prospective and randomized comparison of short and long term therapy. J Perinat Med. 1990;18(2):145-8. X-9. [pmid: 2366136].
3890 Neumann PG, Valladares L. The emergence of maternal-fetal conflict policies. Health Care Law Newsl. Dec. 1991;6(12):3-7. X-1. [pmid: 10183596].
3891 Neutra RR, Greenland S, Friedman EA. The relationship between electronic fetal monitoring and Apgar score. Am J Obstet Gynecol. Jun. 15. 1981;140(4):440-5. X-1. [pmid: 7246661].
3892 Newburn M. Caesarean sections performed without consent. Mod Midwife. Nov. 1996;6(11):9. X-9. [pmid: 9052148].
3893 Newell ML, Dunn DT, Peckham CS, et al. Vertical transmission of HIV-1: maternal immune status and obstetric factors. The European Collaborative Study. AIDS. Dec. 1996;10(14):1675-81. X-1, X-3, X-4e, X-5. [pmid: 8970688].
3894 Newell ML, Huang S, Fiore S, et al. Characteristics and management of HIV-1-infected pregnant women enrolled in a randomised trial: differences between Europe and the USA. BMC Infect Dis. 2007;7:60. X-1. [pmid: 17584491].
3895 Newell ML, Parazzini F, Mandelbrot L, et al. A randomised trial of mode of delivery in women infected with the human immunodeficiency virus. Br J Obstet Gynaecol. Mar. 1998;105(3):281-5. X-2, X-4e. [pmid: 9532987].
3896 Newnham JP, O'Dea MR, Reid KP, et al. Doppler flow velocity waveform analysis in high risk pregnancies: a randomized controlled trial. Br J Obstet Gynaecol. Oct. 1991;98(10):956-63. X-4e, X-5. [pmid: 1751442].
3897 Newton ER, Barss V, Cetrulo CL. The epidemiology and clinical history of asymptomatic midtrimester placenta previa. Am J Obstet Gynecol. Mar. 15. 1984;148(6):743-8. X-1. [pmid: 6702943].
3898 Newton ER, Higgins CS. Factors associated with hospital-specific cesarean birth rates. J Reprod Med. Jun. 1989;34(6):407-11. X-1. [pmid: 2738872].
3899 Newton J, Round L, Curson R. The outcome of pregnancy in previously infertile women. Acta Eur Fertil. Sep. 1978;9(3):161-7. X-1. [pmid: 756109].
3900 Ng CS, Lim LS, Chng KP, et al. Combined team management of diabetes mellitus in pregnancy. Ann Acad Med Singapore. Apr. 1985;14(2):297-302. X-1, X-4e, X-5. [pmid: 4037689].
3901 Ng EK, Leung TN, Tsui NB, et al. The concentration of circulating corticotropin-releasing hormone mRNA in maternal plasma is increased in preeclampsia. Clin Chem. May. 2003;49(5):727-31. X-1. [pmid: 12709362].
3902 Ng NK, Sivalingam N. The role of prophylactic antibiotics in caesarean section--a randomised trial. Med J Malaysia. Dec. 1992;47(4):273-9. X-9. [pmid: 1303479].
3903 Ng PC, So KW, Leung TF, et al. Infection control for SARS in a tertiary neonatal centre. Arch Dis Child Fetal Neonatal Ed. Sep. 2003;88(5):F405-9. X-1. [pmid: 12937045].
3904 Ng SK, Olog A, Spinks AB, et al. Risk factors and obstetric complications of large for gestational age births with adjustments for community effects: results from a new cohort study. BMC Public Health. 2010;10:460. X-1. [pmid: 20687966].
3905 Ng YT, Chen C, Chuah EC, et al. The evaluation of subarachnoid administration of fentanyl for surgery and postoperative analgesia in patients undergoing cesarean section. Ma Zui Xue Za Zhi. Dec. 1990;28(4):438-42. X-9. [pmid: 2097485].
3906 Ngamprasertwong P, Udomtecha D, Charuluxananan S, et al. Levobupivacaine versus racemic bupivacaine for extradural anesthesia for cesarean delivery. J Med Assoc Thai. Nov. 2005;88(11):1563-8. X-9. [pmid: 16471103].
3907 Ngan Kee WD, Khaw KS, Lau TK, et al. Randomised double-blinded comparison of phenylephrine vs ephedrine for maintaining blood pressure during spinal anaesthesia for non-elective Caesarean section*. Anaesthesia. Dec. 2008;63(12):1319-26. X-9. [pmid: 19032300].
3908 Ngan Kee WD, Khaw KS, Lee BB, et al. A dose-response study of prophylactic intravenous ephedrine for the prevention of hypotension during spinal anesthesia for cesarean delivery. Anesth Analg. Jun. 2000;90(6):1390-5. X-9. [pmid: 10825326].
3909 Ngan Kee WD, Khaw KS, Lee BB, et al. Randomized controlled study of colloid preload before spinal anaesthesia for caesarean section. Br J Anaesth. Nov. 2001;87(5):772-4. X-9. [pmid: 11878530].
3910 Ngan Kee WD, Khaw KS, Lee BB, et al. The limitations of ropivacaine with epinephrine as an epidural test dose in parturients. Anesth Analg. Jun. 2001;92(6):1529-31. X-4e. [pmid: 11375839].
3911 Ngan Kee WD, Khaw KS, Lee BB, et al. Metaraminol infusion for maintenance of arterial blood pressure during spinal anesthesia for cesarean delivery: the effect of a crystalloid bolus. Anesth Analg. Sep. 2001;93(3):703-8. X-9. [pmid: 11524344].
3912 Ngan Kee WD, Khaw KS, Ma KC, et al. Randomized, double-blind comparison of different inspired oxygen fractions during general anaesthesia for Caesarean section. Br J Anaesth. Oct. 2002;89(4):556-61. X-9. [pmid: 12393355].
3913 Ngan Kee WD, Khaw KS, Ma KC, et al. Maternal and neonatal effects of remifentanil at induction of general anesthesia for cesarean delivery: a randomized, double-blind, controlled trial. Anesthesiology. Jan. 2006;104(1):14-20. X-9. [pmid: 16394684].
3914 Ngan Kee WD, Khaw KS, Ma ML. Patient-controlled epidural analgesia after caesarean section using meperidine. Can J Anaesth. Jul. 1997;44(7):702-6. X-9. [pmid: 9232297].
3915 Ngan Kee WD, Khaw KS, Ma ML, et al. Postoperative analgesic requirement after cesarean section: a comparison of anesthetic induction with ketamine or thiopental. Anesth Analg. Dec. 1997;85(6):1294-8. X-9. [pmid: 9390597].
3916 Ngan Kee WD, Khaw KS, Ng FF. Comparison of phenylephrine infusion regimens for maintaining maternal blood pressure during spinal anaesthesia for Caesarean section. Br J Anaesth. Apr. 2004;92(4):469-74. X-9. [pmid: 14977792].
3917 Ngan Kee WD, Khaw KS, Ng FF. Prevention of hypotension during spinal anesthesia for cesarean delivery: an effective technique using combination phenylephrine infusion and crystalloid cohydration. Anesthesiology. Oct. 2005;103(4):744-50. X-9. [pmid: 16192766].
3918 Ngan Kee WD, Khaw KS, Ng FF, et al. A prospective comparison of vasopressor requirement and hemodynamic changes during spinal anesthesia for cesarean delivery in patients with multiple gestation versus singleton pregnancy. Anesth Analg. Feb. 2007;104(2):407-11. X-9. [pmid: 17242099].
3919 Ngan Kee WD, Khaw KS, Ng FF, et al. Prophylactic phenylephrine infusion for preventing hypotension during spinal anesthesia for cesarean delivery. Anesth Analg. Mar. 2004;98(3):815-21. table of contents. X-9. [pmid: 14980943].
3920 Ngan Kee WD, Khaw KS, Tan PE, et al. Placental transfer and fetal metabolic effects of phenylephrine and ephedrine during spinal anesthesia for cesarean delivery. Anesthesiology. Sep. 2009;111(3):506-12. X-9. [pmid: 19672175].
3921 Ngan Kee WD, Lam KK, Chen PP, et al. Epidural meperidine after cesarean section. A dose-response study. Anesthesiology. Aug. 1996;85(2):289-94. X-9. [pmid: 8712444].
3922 Ngan Kee WD, Lam KK, Chen PP, et al. Comparison of patient-controlled epidural analgesia with patient-controlled intravenous analgesia using pethidine or fentanyl. Anaesth Intensive Care. Apr. 1997;25(2):126-32. X-9. [pmid: 9127653].
3923 Ngan Kee WD, Lam KK, Chen PP, et al. Epidural meperidine after cesarean section: the effect of diluent volume. Anesth Analg. Aug. 1997;85(2):380-4. X-9. [pmid: 9249117].
3924 Ngan Kee WD, Lam KK, Twyford C, et al. Evaluation of a disposable device for patient-controlled epidural analgesia after caesarean section. Anaesth Intensive Care. Feb. 1996;24(1):51-5. X-1, X-9. [pmid: 8669655].
3925 Ngan Kee WD, Lau TK, Khaw KS, et al. Comparison of metaraminol and ephedrine infusions for maintaining arterial pressure during spinal anesthesia for elective cesarean section. Anesthesiology. Aug. 2001;95(2):307-13. X-9. [pmid: 11506099].
3926 Ngan Kee WD, Lee A, Khaw KS, et al. A randomized double-blinded comparison of phenylephrine and ephedrine infusion combinations to maintain blood pressure during spinal anesthesia for cesarean delivery: the effects on fetal acid-base status and hemodynamic control. Anesth Analg. Oct. 2008;107(4):1295-302. X-9. [pmid: 18806043].
3927 Ngan Kee WD, Ma ML, Gin T. Patient-controlled epidural analgesia after caesarean section using a disposable device. Aust N Z J Obstet Gynaecol. Aug. 1997;37(3):304-7. X-9. [pmid: 9325511].
3928 Ngan Kee WD, Ma ML, Khaw KS. Addition of adrenaline to pethidine for epidural analgesia after caesarean section. Anaesthesia. Sep. 1997;52(9):853-7. X-9. [pmid: 9349065].
3929 Ngan Kee WD, Tam YH, Khaw KS, et al. Closed-loop feedback computer-controlled infusion of phenylephrine for maintaining blood pressure during spinal anaesthesia for caesarean section: a preliminary descriptive study. Anaesthesia. Dec. 2007;62(12):1251-6. X-9. [pmid: 17991262].
3930 Ngiam SK, Chong JL. The addition of intrathecal sufentanil and fentanyl to bupivacaine for caesarean section. Singapore Med J. Jul. 1998;39(7):290-4. X-9. [pmid: 9885688].
3931 Ngo C, Kayem G, Habibi A, et al. Pregnancy in sickle cell disease: maternal and fetal outcomes in a population receiving prophylactic partial exchange transfusions. Eur J Obstet Gynecol Reprod Biol. Oct. 2010;152(2):138-42. X-1. [pmid: 20846778].
3932 Ngu A, Quinn MA. Vaginal delivery following caesarean section. Aust N Z J Obstet Gynaecol. Feb. 1985;25(1):41-3. X-1. [pmid: 3899089].
3933 Nguyen T, Slater P, Cyna AM. Open vs specific questioning during anaesthetic follow-up after Caesarean section. Anaesthesia. Feb. 2009;64(2):156-60. X-1, X-9. [pmid: 19143693].
3934 Ni HY, Daling JR, Chu J, et al. Previous abdominal surgery and tubal pregnancy. Obstet Gynecol. Jun. 1990;75(6):919-22. X-1. [pmid: 2342736].
3935 Nice C, Feeney A, Godwin P, et al. A prospective audit of wound infection rates after caesarean section in five West Yorkshire hospitals. J Hosp Infect. May. 1996;33(1):55-61. X-1, X-9. [pmid: 8738202].
3936 Nicholas AD, Tipton RH, Wheatley CJ, et al. Obstetric practice and epidural analgesia. J Obstet Gynaecol Br Commonw. May. 1970;77(5):457-61. X-1. [pmid: 4913513].
3937 Nichols CM, Nam M, Ramakrishnan V, et al. Anal sphincter defects and bowel symptoms in women with and without recognized anal sphincter trauma. Am J Obstet Gynecol. May. 2006;194(5):1450-4. X-1. [pmid: 16579932].
3938 Nicholson JM, Caughey AB, Stenson MH, et al. The active management of risk in multiparous pregnancy at term: association between a higher preventive labor induction rate and improved birth outcomes. Am J Obstet Gynecol. Mar. 2009;200(3):250 e1-250 e13. X-1. [pmid: 19254584].
3939 Nicholson JM, Cronholm P, Kellar LC, et al. The association between increased use of labor induction and reduced rate of cesarean delivery. J Womens Health (Larchmt). Nov. 2009;18(11):1747-58. X-1. [pmid: 19951208].
3940 Nicholson JM, Kellar LC, Cronholm PF, et al. Active management of risk in pregnancy at term in an urban population: an association between a higher induction of labor rate and a lower cesarean delivery rate. Am J Obstet Gynecol. Nov. 2004;191(5):1516-28. X-1. [pmid: 15547519].
3941 Nicholson JM, Stenson MH, Kellar LC, et al. Active management of risk in nulliparous pregnancy at term: association between a higher preventive labor induction rate and improved birth outcomes. Am J Obstet Gynecol. Mar. 2009;200(3):254 e1-254 e13. X-1. [pmid: 19168168].
3942 Nicholson JM, Yeager DL, Macones G. A preventive approach to obstetric care in a rural hospital: association between higher rates of preventive labor induction and lower rates of cesarean delivery. Ann Fam Med. Jul-Aug. 2007;5(4):310-9. X-1. [pmid: 17664497].
3943 Nicholson WK, Witter F, Powe NR. Effect of hospital setting and volume on clinical outcomes in women with gestational and type 2 diabetes mellitus. J Womens Health (Larchmt). Oct. 2009;18(10):1567-76. X-1. [pmid: 19764843].
3944 Nielsen PE, Erickson JR, Abouleish EI, et al. Fetal heart rate changes after intrathecal sufentanil or epidural bupivacaine for labor analgesia: incidence and clinical significance. Anesth Analg. Oct. 1996;83(4):742-6. X-1. [pmid: 8831313].
3945 Nielsen PE, Goldman MB, Mann S, et al. Effects of teamwork training on adverse outcomes and process of care in labor and delivery: a randomized controlled trial. Obstet Gynecol. Jan. 2007;109(1):48-55. X-4e, X-5. [pmid: 17197587].
3946 Nielsen PE, Howard BC, Hill CC, et al. Comparison of elective induction of labor with favorable Bishop scores versus expectant management: a randomized clinical trial. J Matern Fetal Neonatal Med. Jul. 2005;18(1):59-64. X-4e, X-5. [pmid: 16105793].
3947 Nielsen PE, Thomson BA, Jackson RB, et al. Standard obstetric record charting system: evaluation of a new electronic medical record. Obstet Gynecol. Dec. 2000;96(6):1003-8. X-1. [pmid: 11084193].
3948 Nielsen TF, Hokegard KH, Moldin PG. X-ray pelvimetry and trial of labor after previous cesarean section. A prospective study. Acta Obstet Gynecol Scand. 1985;64(6):485-90. X-1. [pmid: 4061065].
3949 Nigam A, Madan M, Puri M, et al. Labour induction with 25 micrograms versus 50 micrograms intravaginal misoprostol in full term pregnancies. Trop Doct. Jan. 2010;40(1):53-5. X-4d. [pmid: 20008056].
3950 Nigam A, Singh VK, Dubay P, et al. Misoprostol vs. oxytocin for induction of labor at term. Int J Gynaecol Obstet. Sep. 2004;86(3):398-400. X-4d. [pmid: 15325864].
3951 Nilses C, Nystrom L, Munjanja S, et al. Self-reported reproductive outcome and implications in relation to use of care in women in rural Zimbabwe. Acta Obstet Gynecol Scand. Jun. 2002;81(6):508-15. X-1. [pmid: 12047303].
3952 Nilsson L, Reinheimer T, Steinwall M, et al. FE 200 440: a selective oxytocin antagonist on the term-pregnant human uterus. BJOG. Nov. 2003;110(11):1025-8. X-9. [pmid: 14592588].
3953 Nilstun T, Habiba M, Lingman G, et al. Cesarean delivery on maternal request: can the ethical problem be solved by the principlist approach?. BMC Med Ethics. 2008;9:11. X. [pmid: 18559083].
3954 Niruthisard S, Somboonviboon W, Thaithumyanon P, et al. Maternal and neonatal effects of single-dose epidural anesthesia with lidocaine and morphine for cesarean delivery. J Med Assoc Thai. Feb. 1998;81(2):103-9. X-1, X-9. [pmid: 9529839].
3955 Nishikawa K, Yokoyama N, Saito S, et al. Comparison of effects of rapid colloid loading before and after spinal anesthesia on maternal hemodynamics and neonatal outcomes in cesarean section. J Clin Monit Comput. Apr. 2007;21(2):125-9. X-9. [pmid: 17265094].
3956 Nkyekyer K. Twin and singleton births in Ghana--a case-control study. Twin Res. Aug. 2002;5(4):265-9. X-1. [pmid: 12217231].
3957 Noah ML, DeCoster JM, Fraser TJ, et al. Preinduction cervical softening with endocervical PGE2 gel. A multi-center trial. Acta Obstet Gynecol Scand. 1987;66(1):3-7. X-4d, X-5. [pmid: 3300135].
3958 Noah MM, Norton ME, Sandberg P, et al. Short-term maternal outcomes that are associated with the EXIT procedure, as compared with cesarean delivery. Am J Obstet Gynecol. Apr. 2002;186(4):773-7. X-1, X-9. [pmid: 11967506].
3959 Nobile CG, Raffaele G, Altomare C, et al. Influence of maternal and social factors as predictors of low birth weight in Italy. BMC Public Health. 2007;7:192. X-1. [pmid: 17683559].
3960 Noble DW, Morrison LM, Brockway MS, et al. Adrenaline, fentanyl or adrenaline and fentanyl as adjuncts to bupivacaine for extradural anaesthesia in elective caesarean section. Br J Anaesth. Jun. 1991;66(6):645-50. X-9. [pmid: 2064878].
3961 Nohr EA, Timpson NJ, Andersen CS, et al. Severe obesity in young women and reproductive health: the Danish National Birth Cohort. PLoS One. 2009;4(12):e8444. X-1. [pmid: 20041193].
3962 Nolan A, Lawrence C. A pilot study of a nursing intervention protocol to minimize maternal-infant separation after Cesarean birth. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 2009;38(4):430-42. X-3, X-4b.
3963 Nor Azlin, MI Haliza H, Mahdy ZA, et al. Tocolysis in term breech external cephalic version. Int J Gynaecol Obstet. Jan. 2005;88(1):5-8. X-4c, X-4e. [pmid: 15617697].
3964 Nordberg EM. Incidence and estimated need of caesarean section, inguinal hernia repair, and operation for strangulated hernia in rural Africa. Br Med J (Clin Res Ed). Jul. 14. 1984;289(6437):92-3. X-1.
3965 Nordlander E, Hanson U, Persson B. Factors influencing neonatal morbidity in gestational diabetic pregnancy. Br J Obstet Gynaecol. Jun. 1989;96(6):671-8. X-1. [pmid: 2679865].
3966 Norjavaara E, de Verdier MG. Normal pregnancy outcomes in a population-based study including 2,968 pregnant women exposed to budesonide. J Allergy Clin Immunol. Apr. 2003;111(4):736-42. X-1. [pmid: 12704351].
3967 Norris LA, Higgins JR, Darling MR, et al. Nitric oxide in the uteroplacental, fetoplacental, and peripheral circulations in preeclampsia. Obstet Gynecol. Jun. 1999;93(6):958-63. X-1, X-9. [pmid: 10362162].
3968 Norris MC, Dewan DM. Effect of gravity on the spread of extradural anaesthesia for caesarean section. Br J Anaesth. Mar. 1987;59(3):338-41. X-1, X-9. [pmid: 3828183].
3969 Norris TE, Reese JW, Pirani MJ, et al. Are rural family physicians comfortable performing cesarean sections?. J Fam Pract. Nov. 1996;43(5):455-60. X-1. [pmid: 8917144].
3970 Nortcliffe SA, Shah J, Buggy DJ. Prevention of postoperative nausea and vomiting after spinal morphine for Caesarean section: comparison of cyclizine, dexamethasone and placebo. Br J Anaesth. May. 2003;90(5):665-70. X-9. [pmid: 12697596].
3971 Norton AC, Davis AG, Spicer RJ. Lignocaine 2% with adrenaline for epidural caesarean section. A comparison with 0.5% bupivacaine. Anaesthesia. Oct. 1988;43(10):844-9. X-9. [pmid: 3059842].
3972 Novaes Junior M, Biancalana MM, Garcia SA, et al. Elevation of cord blood TSH concentration in newborn infants of mothers exposed to acute povidone iodine during delivery. J Endocrinol Invest. Nov. 1994;17(10):805-8. X-1, X-3, X-4b, X-4e, X-5. [pmid: 7699215].
3973 Novikova N, Hofmeyr GJ. Tranexamic acid for preventing postpartum haemorrhage. Cochrane Database of Systematic Reviews. 2010;(7). X-1, X-2.
3974 Novikova N, Hofmeyr GJ, Essilfie-Appiah G. Prophylactic versus therapeutic amnioinfusion for oligohydramnios in labour. Cochrane Database of Systematic Reviews. 1996;(1). X-1, X-2.
3975 Noyan Ashraf MA, Sadeghi A, Azarbakht Z, et al. Evaluation of intravenous hydrocortisone in reducing headache after spinal anesthesia: a double blind controlled clinical study [corrected]. Middle East J Anesthesiol. Jun. 2007;19(2):415-22. X-9. [pmid: 17684881].
3976 Noyes N, Berkeley AS, Freedman K, et al. Incidence of postpartum endomyometritis following single-dose antibiotic prophylaxis with either ampicillin/sulbactam, cefazolin, or cefotetan in high-risk cesarean section patients. Infect Dis Obstet Gynecol. 1998;6(5):220-3. X-9. [pmid: 9894177].
3977 Nuamah MA, Yura S, Sagawa N, et al. Significant increase in maternal plasma leptin concentration in induced delivery: a possible contribution of pro-inflammatory cytokines to placental leptin secretion. Endocr J. Apr. 2004;51(2):177-87. X-1, X-3, X-4e, X-5. [pmid: 15118268].
3978 Numazaki M, Fujii Y. Subhypnotic dose of propofol for the prevention of nausea and vomiting during spinal anaesthesia for caesarean section. Anaesth Intensive Care. Jun. 2000;28(3):262-5. X-9. [pmid: 10853206].
3979 Numazaki M, Fujii Y. Reduction of emetic symptoms during cesarean delivery with antiemetics: propofol at subhypnotic dose versus traditional antiemetics. J Clin Anesth. Sep. 2003;15(6):423-7. X-9. [pmid: 14652118].
3980 Nunes F, Rodrigues R, Meirinho M. Randomized comparison between intravaginal misoprostol and dinoprostone for cervical ripening and induction of labor. Am J Obstet Gynecol. Sep. 1999;181(3):626-9. X-4d. [pmid: 10486474].
3981 Nunes FP, Campos AP, Pedroso SR, et al. Intravaginal glyceryl trinitrate and dinoprostone for cervical ripening and induction of labor. Am J Obstet Gynecol. Apr. 2006;194(4):1022-6. X-4d. [pmid: 16580291].
3982 Nuthalapaty FS, Ramsey PS, Biggio JR, et al. High-dose vaginal misoprostol versus concentrated oxytocin plus low-dose vaginal misoprostol for midtrimester labor induction: a randomized trial. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1065-70. X-4d. [pmid: 16157113].
3983 Nuutila M, Halmesmaki E, Hiilesmaa V, et al. Women's anticipations of and experiences with induction of labor. Acta Obstet Gynecol Scand. Sep. 1999;78(8):704-9. X-1. [pmid: 10468063].
3984 Nuutila M, Kajanoja P. Local administration of prostaglandin E2 for cervical ripening and labor induction: the appropriate route and dose. Acta Obstet Gynecol Scand. Feb. 1996;75(2):135-8. X-4d, X-5. [pmid: 8604599].
3985 Nwogu-Ikojo EE, Okafor II, Ezegwui HU. Multiple antenatal bookings among pregnant women in Enugu, Nigeria. J Obstet Gynaecol. Apr. 2010;30(3):244-7. X-1. [pmid: 20373923].
3986 Nwosu UC, Wallach EE, Boggs TR, et al. Possible adrenocortical insufficiency in postmature neonates. Am J Obstet Gynecol. Aug. 15. 1975;122(8):969-74. X-4e. [pmid: 1155534].
3987 Nygaard IE, Rao SS, Dawson JD. Anal incontinence after anal sphincter disruption: a 30-year retrospective cohort study. Obstet Gynecol. Jun. 1997;89(6):896-901. X-1. [pmid: 9170461].
3988 Nystedt A, Hogberg U, Lundman B. The negative birth experience of prolonged labour: a case-referent study. J Clin Nurs. May. 2005;14(5):579-86. X-1. [pmid: 15840072].
3989 Nystedt A, Hogberg U, Lundman B. Some Swedish women's experiences of prolonged labour. Midwifery. Mar. 2006;22(1):56-65. X-1. [pmid: 16488810].
3990 Oates RK, Harvey D. Failure of hypothermia as treatment for asphyxiated newborn rabbits. Arch Dis Child. Jul. 1976;51(7):512-6. X-1, X-3. [pmid: 989263].
3991 Oats JN, Beischer NA. The persistence of abnormal glucose tolerance after delivery. Obstet Gynecol. Mar. 1990;75(3 Pt 1):397-401. X-1. [pmid: 2304711].
3992 Oats JN, Vasey DP, Waldron BA. Effects of ketamine on the pregnant uterus. Br J Anaesth. Dec. 1979;51(12):1163-6. X-1, X-3, X-4b, X-4e. [pmid: 526384].
3993 Obade CC. In re A.C. reversed: judicial recognition of the rights of pregnant women. J Clin Ethics. Fall. 1990;1(3):251. X-1, X-4e. [pmid: 2132021].
3994 Obata-Yasuoka M, Hamada H, Watanabe H, et al. Midtrimester termination of pregnancy using gemeprost in combination with laminaria in women who have previously undergone cesarean section. J Obstet Gynaecol Res. Oct. 2009;35(5):901-5. X-1. [pmid: 20149039].
3995 Oberman M. Mothers and doctors' orders: unmasking the doctor's fiduciary role in maternal-fetal conflicts. Northwest Univ Law Rev. Winter. 2000;94(2):451-501. X-1. [pmid: 12455556].
3996 Oboro V, Adewunmi A, Ande A, et al. Morbidity associated with failed vaginal birth after cesarean section. Acta Obstet Gynecol Scand. Sep. 2010;89(9):1229-32. X-1. [pmid: 20804350].
3997 Oboro VO, Dare FO. Pregnancy outcome in nulliparous women aged 35 or older. West Afr J Med. Jan-Mar. 2006;25(1):65-8. X-1. [pmid: 16722362].
3998 Oboro VO, Isawumi AI, Akinola SE, et al. Factors predicting failure of labour induction. Niger Postgrad Med J. Jun. 2007;14(2):137-9. X-1. [pmid: 17599113].
3999 O'Brien D, Babiker E, O'Sullivan O, et al. Prediction of peripartum hysterectomy and end organ dysfunction in major obstetric haemorrhage. Eur J Obstet Gynecol Reprod Biol. Dec. 2010;153(2):165-9. X-1. [pmid: 20810201].
4000 Obst TE, Nauenberg E, Buck GM. Maternal health insurance coverage as a determinant of obstetrical anesthesia care. J Health Care Poor Underserved. May. 2001;12(2):177-91. X-1, X-9. [pmid: 11370186].
4001 Ochedalski T, Lachowicz A. Maternal and fetal hypothalamo-pituitary-adrenal axis: different response depends upon the mode of parturition. Neuro Endocrinol Lett. Aug. 2004;25(4):278-82. X-1. [pmid: 15361817].
4002 Ochi H, Kusanagi Y, Katayama T, et al. Clinical significance of normalization of uterine artery pulsatility index with maternal heart rate for the evaluation of uterine circulation in pregnancy-induced hypertension. Ultrasound Obstet Gynecol. May. 2003;21(5):459-63. X-1, X-4e, X-5. [pmid: 12768557].
4003 Ochsenbein-Imhof N, Huch A, Huch R, et al. No benefit from post-caesarean wound drainage. Swiss Med Wkly. May. 5. 2001;131(17-18):246-50. X-9. [pmid: 11420821].
4004 Ochsenbein-Kolble N, Demartines N, Ochsenbein-Imhof N, et al. Cesarean section and simultaneous hernia repair. Arch Surg. Aug. 2004;139(8):893-5. X-1. [pmid: 15302700].
4005 Ochsenkuhn R, Strowitzki T, Gurtner M, et al. Pregnancy complications, obstetric risks, and neonatal outcome in singleton and twin pregnancies after GIFT and IVF. Arch Gynecol Obstet. Oct. 2003;268(4):256-61. X-1. [pmid: 12904987].
4006 O'Connor DJ, Scher LA, Gargiulo NJ 3rd, et al. Incidence and characteristics of venous thromboembolic disease during pregnancy and the postnatal period: a contemporary series. Ann Vasc Surg. Jan. 2011;25(1):9-14. X-1. [pmid: 20800436].
4007 Odegaard I, Stray-Pedersen B, Hallberg K, et al. Maternal and fetal morbidity in pregnancies of Norwegian and Swedish women with cystic fibrosis. Acta Obstet Gynecol Scand. Aug. 2002;81(8):698-705. X-1. [pmid: 12174152].
4008 Odeh M, Tarazova L, Wolfson M, et al. Evidence that women with a history of cesarean section can deliver twins safely. Acta Obstet Gynecol Scand. Aug. 1997;76(7):663-6. X-1. [pmid: 9292641].
4009 Odem RR, Work BA Jr., Dawood MY. Pulsatile oxytocin for induction of labor: a randomized prospective controlled study. J Perinat Med. 1988;16(1):31-7. X-4d, X-5. [pmid: 3404378].
4010 Odendaal HJ. The fetal and labor outcome of 102 positive contraction stress tests. Obstet Gynecol. Nov. 1979;54(5):591-6. X-1. [pmid: 503388].
4011 Odendaal HJ, Pattinson RC, Bam R, et al. Aggressive or expectant management for patients with severe preeclampsia between 28-34 weeks' gestation: a randomized controlled trial. Obstet Gynecol. Dec. 1990;76(6):1070-5. X-4e, X-5. [pmid: 2234715].
4012 Odero W, Otieno-Nyunya B. Major obstetric interventions among encamped refugees and the local population in Turkana District, Kenya. East Afr Med J. Dec. 2001;78(12):666-72. X-1, X-3. [pmid: 12199450].
4013 Odibo AO, Cahill AG, Stamilio DM, et al. Predicting placental abruption and previa in women with a previous cesarean delivery. Am J Perinatol. May. 2007;24(5):299-305. X-1. [pmid: 17514600].
4014 O'Driscoll K, Jackson RJ, Gallagher JT. Prevention of prolonged labour. Br Med J. May. 24. 1969;2(5655):477-80. X-1. [pmid: 5771578].
4015 O'Driscoll K, Stronge JM. Active management of labor. Br Med J. Sep. 15. 1973;3(5880):590. X-1, X-2, X-3, X-4e, X-5. [pmid: 4726933].
4016 Odum CU, Pipkins FB. The influence of mode of delivery, obstetric analgesia and anaesthesia on the response of isolated human chorionic plate arteries to angiotensin II. West Afr J Med. Jan-Mar. 1989;8(1):1-9. X-1. [pmid: 2486765].
4017 Offen WW, Gruber CM Jr. Dose response to fenoprofen calcium using placebo and codeine as controls. J Med. 1985;16(4):439-52. X-3, X-4e, X-5. [pmid: 3913726].
4018 Ofir D, Levy A, Wiznitzer A, et al. Familial Mediterranean fever during pregnancy: an independent risk factor for preterm delivery. Eur J Obstet Gynecol Reprod Biol. Dec. 2008;141(2):115-8. X-1. [pmid: 18771840].
4019 Ogaji DS, Ikpeme BM, Oyo-Ita AE, et al. Awareness and acceptability of strategies for preventing mother to child transmission of HIV among antenatal clients in Calabar, Nigeria. Niger J Med. Jan-Mar. 2008;17(1):29-32. X-1. [pmid: 18390128].
4020 Ognissanti F, Bucciero A, Conturso R, et al. A comparison of mezlocillin and cefotetan in cesarean section prophylaxis: a prospective, randomized study. Preliminary results. J Chemother. Jul. 1989;1(4 Suppl):1030-2. X-9. [pmid: 16312758].
4021 O'Grady JP, Veille JC, Holland RL, et al. External cephalic version: a clinical experience. J Perinat Med. 1986;14(3):189-96. X-1. [pmid: 3537268].
4022 Ogun CO, Kirgiz EN, Duman A, et al. Comparison of intrathecal isobaric bupivacaine-morphine and ropivacaine-morphine for Caesarean delivery. Br J Anaesth. May. 2003;90(5):659-64. X-9. [pmid: 12697595].
4023 Oguz S, Sener B, Ozcan S, et al. Nonfreeing of the lower leaf of the rectus sheath at caesarean section: a randomized controlled trial. Aust N Z J Obstet Gynaecol. Aug. 1998;38(3):317-8. X-9. [pmid: 9761162].
4024 Oh SY, Kim CJ, Park I, et al. Progesterone receptor isoform (A/B) ratio of human fetal membranes increases during term parturition. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1156-60. X-1. [pmid: 16157129].
4025 Oh SY, Song SE, Seo ES, et al. The expression of connective tissue growth factor in pregnancies complicated by severe preeclampsia or fetal growth restriction. Placenta. Nov. 2009;30(11):981-7. X-1. [pmid: 19762080].
4026 O'Hana HP, Levy A, Rozen A, et al. The effect of epidural analgesia on labor progress and outcome in nulliparous women. J Matern Fetal Neonatal Med. Aug. 2008;21(8):517-21. X-1. [pmid: 18609353].
4027 Ohel G, Gonen R, Vaida S, et al. Early versus late initiation of epidural analgesia in labor: does it increase the risk of cesarean section? A randomized trial. Am J Obstet Gynecol. Mar. 2006;194(3):600-5. X-5. [pmid: 16522386].
4028 Ohel G, Rahav D, Rothbart H, et al. Randomised trial of outpatient induction of labor with vaginal PGE2 at 40-41 weeks of gestation versus expectant management. Arch Gynecol Obstet. 1996;258(3):109-12. X-4e, X-5. [pmid: 8781697].
4029 Ohel G, Younis JS, Lang N, et al. Double-layer closure of uterine incision with visceral and parietal peritoneal closure: are they obligatory steps of routine cesarean sections?. J Matern Fetal Med. Nov-Dec. 1996;5(6):366-9. X-9. [pmid: 8972417].
4030 Ohel I, Levy A, Mazor M, et al. Refusal of treatment in obstetrics - A maternal-fetal conflict. J Matern Fetal Neonatal Med. Jul. 2009;22(7):612-5. X-1. [pmid: 19479647].
4031 O'Herlihy C, Klein M, Goer H. Roundtable discussion. Active management of labor: benefits and risks… part 1. Birth: Issues in Perinatal Care. 1993;20(2):95-101. X-1, X-2.
4032 O'Herlihy C, Macdonald HN. Influence of preinduction prostaglandin E2 vaginal gel on cervical ripening and labor. Obstet Gynecol. Dec. 1979;54(6):708-10. X-1. [pmid: 514556].
4033 Ohlsson A. Treatments of preterm premature rupture of the membranes: a meta-analysis. Am J Obstet Gynecol. Apr. 1989;160(4):890-906. X-1, X-2. [pmid: 2653041].
4034 Ohlsson G, Buchhave P, Leandersson U, et al. Warm tub bathing during labor: maternal and neonatal effects. Acta Obstet Gynecol Scand. Apr. 2001;80(4):311-4. X-4e, X-5. [pmid: 11264604].
4035 Ojala JR. A Lamentation of birth. Midwifery Today Int Midwife. Spring. 2007;(81):34-5. X-1. [pmid: 17447696].
4036 Ojofeitimi EO, Elegbe I, Babafemi J. Diet restriction by pregnant women in Nigeria. Int J Gynaecol Obstet. Apr. 1982;20(2):99-103. X-1. [pmid: 6125444].
4037 Okasha AS, Motaweh MM, Bali A. Cimetidine - antacid combination as premedication for elective Caesarean section. Can Anaesth Soc J. Nov. 1983;30(6):593-7. X-9. [pmid: 6640395].
4038 O'Keefe D, O'Herlihy C, Gross Y, et al. Patient-controlled analgesia using a miniature electrochemically driven infusion pump. Br J Anaesth. Dec. 1994;73(6):843-6. X-1. [pmid: 7880679].
4039 Okonofua FE, Olatunbosun OA. Cesarean versus vaginal delivery in abruptio placentae associated with live fetuses. Int J Gynaecol Obstet. Dec. 1985;23(6):471-4. X-1, X-3, X-4e. [pmid: 2868941].
4040 Okoye BO, Losty PD, Fisher MJ, et al. Antenatal glucocorticoid therapy suppresses angiotensin-converting enzyme activity in rats with nitrofen-induced congenital diaphragmatic hernia. J Pediatr Surg. Feb. 1998;33(2):286-91. X-1. [pmid: 9498404].
4041 Okoye BO, Losty PD, Lloyd DA, et al. Effect of prenatal glucocorticoids on pulmonary vascular muscularisation in nitrofen-induced congenital diaphragmatic hernia. J Pediatr Surg. Jan. 1998;33(1):76-80. X-1. [pmid: 9473105].
4042 Okudaira S, Suzuki S. Influence of spinal hypotension on fetal oxidative status during elective cesarean section in uncomplicated pregnancies. Arch Gynecol Obstet. Apr. 2005;271(4):292-5. X-1, X-9. [pmid: 14740229].
4043 Ola ER, Imosemi OD, Abudu OO. Vaginal birth after one previous Caesarean section--evaluation of predictive factors. Afr J Med Med Sci. Mar-Jun. 2001;30(1-2):61-6. X-1. [pmid: 14510153].
4044 Oladapo OT, Ayoola-Sotubo O, Daniel OJ, et al. Tertiary hospital staff and caesarean section risk. J Obstet Gynaecol. May. 2006;26(4):325-8. X-1. [pmid: 16753682].
4045 Oladapo OT, Sotunsa JO, Sule-Odu AO. The rise in caesarean birth rate in Sagamu, Nigeria: reflection of changes in obstetric practice. J Obstet Gynaecol. Jun. 2004;24(4):377-81. X-1. [pmid: 15203575].
4046 Oladipo A, Syed A. The views of obstetricians in the south-west of England on the use of prostaglandins and syntocinon in VBAC. J Obstet Gynaecol. Feb. 2008;28(2):177-82. X-1. [pmid: 18393014].
4047 Oladokun A, Okewole AI, Adewole IF, et al. Evaluation of cases of eclampsia in the University College Hospital, Ibadan over a 10 year period. West Afr J Med. Jul-Sep. 2000;19(3):192-4. X-1. [pmid: 11126082].
4048 Olah KS, Vince GS, Neilson JP, et al. Interleukin-6, interferon-gamma, interleukin-8, and granulocyte-macrophage colony stimulating factor levels in human amniotic fluid at term. J Reprod Immunol. Nov. 1996;32(1):89-98. X-1. [pmid: 8953522].
4049 Olatunbosun A, Ravichander A, Turnell RW, et al. The influence of patient preferences and physician practices on cesarean delivery. Clin Exp Obstet Gynecol. 2002;29(1):19-21. X-1. [pmid: 12013083].
4050 Olayemi O, Adeniji RA, Udoh ES, et al. Determinants of pain perception in labour among parturients at the University College Hospital, Ibadan. J Obstet Gynaecol. Feb. 2005;25(2):128-30. X-1. [pmid: 15814389].
4051 Olden AJ, Jordan ET, Sakima NT, et al. Patients' versus nurses' assessments of pain and sedation after cesarean section. J Obstet Gynecol Neonatal Nurs. Feb. 1995;24(2):137-41. X-9.
4052 O'Leary JA. Vaginal delivery of the term breech. A preliminary report. Obstet Gynecol. Mar. 1979;53(3):341-3. X-1. [pmid: 424106].
4053 O'Leary JA. Uterine artery ligation in the control of postcesarean hemorrhage. J Reprod Med. Mar. 1995;40(3):189-93. X-1. [pmid: 7776302].
4054 O'Leary JA, Mullins JH Jr., Andrinopoulos GC. Ampicillin vs. ampicillin-gentamicin prophylaxis in high-risk primary cesarean section. J Reprod Med. Jan. 1986;31(1):27-30. X-9. [pmid: 3950878].
4055 O'Leary JA, O'Leary JL. Uterine artery ligation for control of postcesarean hemorrhage. Surg Forum. 1968;19:409-10. X-4e. [pmid: 5305052].
4056 O'Leary JL, O'Leary JA. Uterine artery ligation for control of postcesarean section hemorrhage. Obstet Gynecol. Jun. 1974;43(6):849-53. X-9, X-4e. [pmid: 4597790].
4057 Oleen MA, Mariano JP. Controlling refractory atonic postpartum hemorrhage with Hemabate sterile solution. Am J Obstet Gynecol. Jan. 1990;162(1):205-8. X-1. [pmid: 2405676].
4058 Oleske DM, Branca ML, Schmidt JB, et al. A comparison of capitated and fee-for-service Medicaid reimbursement methods on pregnancy outcomes. Health Serv Res. Apr. 1998;33(1):55-73. X-1, X-4e, X-5. [pmid: 9566177].
4059 Oleske DM, Linn ES, Nachman KL, et al. Cesarean and VBAC delivery rates in Medicaid managed care, Medicaid fee-for-service, and private managed care. Birth. Jun. 1998;25(2):125-7. X-9. [pmid: 9668747].
4060 Olmos PR, Araya-Del-Pino AP, Gonzalez-Carvello CA, et al. Near-optimal glycemic control in Chilean women with pregestational type-2 diabetes: persistent macrosomia relates to maternal pre-pregnancy overweight. Diabetes Res Clin Pract. Jul. 2009;85(1):53-60. X-1. [pmid: 19446354].
4061 Olofsson C, Ekblom A, Ekman-Ordeberg G, et al. Increased cerebrospinal fluid concentration of aspartate but decreased concentration of nitric oxide breakdown products in women experiencing visceral pain during active labour. Neuroreport. Mar. 3. 1997;8(4):995-8. X-1. [pmid: 9141079].
4062 Olofsson C, Ekblom A, Skoldefors E, et al. Anesthetic quality during cesarean section following subarachnoid or epidural administration of bupivacaine with or without fentanyl. Acta Anaesthesiol Scand. Mar. 1997;41(3):332-8. X-9. [pmid: 9113175].
4063 Olofsson CI, Legeby MH, Nygards EB, et al. Diclofenac in the treatment of pain after caesarean delivery. An opioid-saving strategy. Eur J Obstet Gynecol Reprod Biol. Feb. 2000;88(2):143-6. X-9. [pmid: 10690672].
4064 Olofsson P, Ingemarsson I, Solum T. Fetal distress during labour in diabetic pregnancy. Br J Obstet Gynaecol. Oct. 1986;93(10):1067-71. X-1. [pmid: 3790466].
4065 Olofsson P, Laurini RN, Marsal K. A high uterine artery pulsatility index reflects a defective development of placental bed spiral arteries in pregnancies complicated by hypertension and fetal growth retardation. Eur J Obstet Gynecol Reprod Biol. May. 1993;49(3):161-8. X-1. [pmid: 8405630].
4066 Olsen MA, Butler AM, Willers DM, et al. Risk factors for surgical site infection after low transverse cesarean section. Infect Control Hosp Epidemiol. Jun. 2008;29(6):477-84. discussion 485-6. X-1. [pmid: 18510455].
4067 Olsen MA, Butler AM, Willers DM, et al. Risk factors for endometritis after low transverse cesarean delivery. Infect Control Hosp Epidemiol. Jan. 2010;31(1):69-77. X-1. [pmid: 19951198].
4068 Olsen MA, Butler AM, Willers DM, et al. Comparison of costs of surgical site infection and endometritis after cesarean delivery using claims and medical record data. Infect Control Hosp Epidemiol. Aug. 2010;31(8):872-5. X-1. [pmid: 20583923].
4069 Olsen MA, Butler AM, Willers DM, et al. Attributable costs of surgical site infection and endometritis after low transverse cesarean delivery. Infect Control Hosp Epidemiol. Mar. 2010;31(3):276-82. X-1. [pmid: 20102279].
4070 Olusanya BO, Afe AJ, Onyia NO. Infants with HIV-infected mothers in a universal newborn hearing screening programme in Lagos, Nigeria. Acta Paediatr. Aug. 2009;98(8):1288-93. X-1. [pmid: 19519758].
4071 Olusanya BO, Afe AJ, Solanke OA. Are risk factors for stillbirths in low-income countries associated with sensorineural hearing loss in survivors?. J Matern Fetal Neonatal Med. Jul. 2009;22(7):576-83. X-1. [pmid: 19488940].
4072 Olusanya BO, Solanke OA. Predictors of term stillbirths in an inner-city maternity hospital in Lagos, Nigeria. Acta Obstet Gynecol Scand. 2009;88(11):1243-51. X-1. [pmid: 19900141].
4073 O'Mahony F, Hofmeyr GJ, Menon V. Choice of instruments for assisted vaginal delivery. Cochrane Database of Systematic Reviews. 2010;(11). X-1, X-2.
4074 Omole-Ohonsi A, Ashimi A, Adeleke S. Spontaneous pre-labour rupture of membranes at term: immediate versus delayed induction of labour. West Afr J Med. May. 2009;28(3):156-60. X-1, X-4d, X-4e, X-5. [pmid: 20306730].
4075 Omole-Ohonsi A, Attah RA. Obstetric outcome of teenage pregnancy in Kano, North-Western Nigeria. West Afr J Med. Sep-Oct. 2010;29(5):318-22. X-1. [pmid: 21089018].
4076 Omu AE, al-Othman S, al-Qattan F, et al. A comparative study of obstetric outcome of patients with pregnancy induced hypertension: economic considerations. Acta Obstet Gynecol Scand. May. 1996;75(5):443-8. X-1. [pmid: 8677768].
4077 Onah HE. Formal education does not improve the acceptance of cesarean section among pregnant Nigerian women. Int J Gynaecol Obstet. Mar. 2002;76(3):321-3. X-1. [pmid: 11880141].
4078 Onah HE, Nkwo PO. Caesarean section or symphysiotomy for obstructed labour for developing countries? Need to ascertain women's preferences. J Obstet Gynaecol. Nov. 2003;23(6):594-5. X-1, X-2. [pmid: 14617456].
4079 Onah HE, Ugona MC. Preferences for cesarean section or symphysiotomy for obstructed labor among Nigerian women. Int J Gynaecol Obstet. Jan. 2004;84(1):79-81. X-1. [pmid: 14698836].
4080 Onderdonk AB, Delaney ML, DuBois AM, et al. Detection of bacteria in placental tissues obtained from extremely low gestational age neonates. Am J Obstet Gynecol. Jan. 2008;198(1):110 e1-7. X-1. [pmid: 18166321].
4081 Onen A, Ark HC. Fetal thoracic aorta doppler in cases with intrauterine growth restriction. Clin Exp Obstet Gynecol. 2001;28(3):168-70. X-1. [pmid: 11530865].
4082 Ong JP, Edwards GJ, Allison MC. Mode of delivery and risk of fecal incontinence in women with or without inflammatory bowel disease: questionnaire survey. Inflamm Bowel Dis. Nov. 2007;13(11):1391-4. X-1. [pmid: 17576117].
4083 Onile TG, Kuti O, Orji EO, et al. A prospective randomized clinical trial of urethral catheter removal following elective cesarean delivery. Int J Gynaecol Obstet. Sep. 2008;102(3):267-70. X-9. [pmid: 18602634].
4084 Onuigbo WI, Chukudebelu WO. Appendices removed at cesarean section: histopathology. Dis Colon Rectum. Oct. 1981;24(7):507-9. X-1. [pmid: 7297358].
4085 Onwuhafua PI, Oguntayo A. Perinatal mortality associated with eclampsia in Kaduna, Northern Nigeria. Niger J Med. Oct-Dec. 2006;15(4):397-400. X-1. [pmid: 17111724].
4086 Onyiriuka AN. High birth weight babies: incidence and foetal outcome in a mission hospital in Benin City, Nigeria. Niger J Clin Pract. Dec. 2006;9(2):114-9. X-1. [pmid: 17319341].
4087 Onyiriuka AN. Twin delivery: comparison of incidence and foetal outcome in two health institutions in Benin City, Nigeria. Nig Q J Hosp Med. Jan-Mar. 2009;19(1):1-5. X-1. [pmid: 20830979].
4088 Onyiriuka AN, Okolo AA. Neonatal morbidity pattern in infants born in Benin City to Nigerian mothers with hypertensive disorders in pregnancy. Niger J Clin Pract. Dec. 2007;10(4):294-9. X-1. [pmid: 18293638].
4089 Opara PI, Jaja T, Onubogu UC. Morbidity and mortality amongst infants of diabetic mothers admitted into a special care baby unit in Port Harcourt Nigeria. Ital J Pediatr. 2010;36(1):77. X-1, X-4e. [pmid: 21138582].
4090 Opoien HK, Valbo A, Grinde-Andersen A, et al. Post-cesarean surgical site infections according to CDC standards: rates and risk factors. A prospective cohort study. Acta Obstet Gynecol Scand. 2007;86(9):1097-102. X-1, X-9. [pmid: 17712651].
4091 Oppenheimer LW, Bland ES, Dabrowski A, et al. Uterine contraction pattern as a predictor of the mode of delivery. J Perinatol. Mar. 2002;22(2):149-53. X-1. [pmid: 11896521].
4092 Oppenheimer LW, Labrecque M, Wells G, et al. Prostaglandin E vaginal gel to treat dystocia in spontaneous labour: a multicentre randomised placebo-controlled trial. BJOG. May. 2005;112(5):612-8. X-5, X-6. [pmid: 15842286].
4093 Orach CG, Dubourg D, De Brouwere V. Costs and coverage of reproductive health interventions in three rural refugee-affected districts, Uganda. Trop Med Int Health. Mar. 2007;12(3):459-69. X-1. [pmid: 17313517].
4094 Oral E, Cagdas A, Gezer A, et al. Perinatal and maternal outcomes of fetal macrosomia. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2001;99(2):167-71. X-1. [pmid: 11788165].
4095 O'Reilly-Green CP, Divon MY. Predictive value of amniotic fluid index for oligohydramnios in patients with prolonged pregnancies. J Matern Fetal Med. Jul-Aug. 1996;5(4):218-26. X-1. [pmid: 8796797].
4096 Orji EO, Ndububa VI. Obstetric performance of women aged over forty years. East Afr Med J. Mar. 2004;81(3):139-41. X-1. [pmid: 15293972].
4097 Orji EO, Ogunlola IO, Onwudiegwu U. Brought-in maternal deaths in south-west Nigeria. J Obstet Gynaecol. Jul. 2002;22(4):385-8. X-1. [pmid: 12521460].
4098 Orji EO, Olabode TO, Kuti O, et al. A randomised controlled trial of early initiation of oral feeding after cesarean section. J Matern Fetal Neonatal Med. Jan. 2009;22(1):65-71. X-9. [pmid: 19165681].
4099 Orji EO, Olaleye AO, Loto OM, et al. A randomised controlled trial of uterine exteriorisation and non-exteriorisation at caesarean section. Aust N Z J Obstet Gynaecol. Dec. 2008;48(6):570-4. X-9. [pmid: 19133045].
4100 Orji EO, Shittu AS, Makinde ON, et al. Effect of prolonged birth spacing on maternal and perinatal outcome. East Afr Med J. Aug. 2004;81(8):388-91. X-1. [pmid: 15622931].
4101 Ormezzano X, Francois TP, Viaud JY, et al. Aspiration pneumonitis prophylaxis in obstetric anaesthesia: comparison of effervescent cimetidine-sodium citrate mixture and sodium citrate. Br J Anaesth. Apr. 1990;64(4):503-6. X-9. [pmid: 2334627].
4102 Oron G, Hirsch R, Ben-Haroush A, et al. Pregnancy outcome in women with heart disease undergoing induction of labour. BJOG. Jul. 2004;111(7):669-75. X-1. [pmid: 15198756].
4103 Ortega-Senovilla H, Alvino G, Taricco E, et al. Enhanced circulating retinol and non-esterified fatty acids in pregnancies complicated with intrauterine growth restriction. Clin Sci (Lond). Mar. 2010;118(5):351-8. X-1. [pmid: 19656084].
4104 Osathanondh R, Chopra IJ, Tulchinsky D. Effects of dexamethasone on fetal and maternal thyroxine, triiodothyronine, reverse triiodothyronine, and thyrotropin levels. J Clin Endocrinol Metab. Dec. 1978;47(6):1236-9. X-1. [pmid: 263347].
4105 Oscarsson ME, Amer-Wahlin I, Rydhstroem H, et al. Outcome in obstetric care related to oxytocin use. A population-based study. Acta Obstet Gynecol Scand. 2006;85(9):1094-8. X-1. [pmid: 16929414].
4106 Oshiro BT, Henry E, Wilson J, et al. Decreasing elective deliveries before 39 weeks of gestation in an integrated health care system. Obstet Gynecol. Apr. 2009;113(4):804-11. X-1. [pmid: 19305323].
4107 Osis MJ, Cecatti JG, de Padua KS, et al. Brazilian doctors' perspective on the second opinion strategy before a C-section. Rev Saude Publica. Apr. 2006;40(2):233-9. X-1. [pmid: 16583033].
4108 Osis MJ, Padua KS, Duarte GA, et al. The opinion of Brazilian women regarding vaginal labor and cesarean section. Int J Gynaecol Obstet. Nov. Suppl 1. 2001;75:S59-66. X-1. [pmid: 11742644].
4109 Osmers RG, Adelmann-Grill BC, Rath W, et al. Biochemical events in cervical ripening dilatation during pregnancy and parturition. J Obstet Gynaecol (Tokyo 1995). Apr. 1995;21(2):185-94. X-1. [pmid: 8556580].
4110 Ostlund I, Hanson U, Bjorklund A, et al. Maternal and fetal outcomes if gestational impaired glucose tolerance is not treated. Diabetes Care. Jul. 2003;26(7):2107-11. X-1, X-4e. [pmid: 12832321].
4111 O'Sullivan CJ, Allen NM, O'Loughlin AJ, et al. Thrombin and PAR1-activating peptide: effects on human uterine contractility in vitro. Am J Obstet Gynecol. Apr. 2004;190(4):1098-105. X-1. [pmid: 15118649].
4112 O'Sullivan G, Sear JW, Bullingham RE, et al. The effect of magnesium trisilicate mixture, metoclopramide and ranitidine on gastric pH, volume and serum gastrin. Anaesthesia. Mar. 1985;40(3):246-53. X-9. [pmid: 2986474].
4113 O'Sullivan GM, Smith M, Morgan B, et al. H2 antagonists and bupivacaine clearance. Anaesthesia. Feb. 1988;43(2):93-5. X-9. [pmid: 2895594].
4114 Otamiri G, Berg G, Ledin T, et al. Delayed neurological adaptation in infants delivered by elective cesarean section and the relation to catecholamine levels. Early Hum Dev. Jul. 1991;26(1):51-60. X-1. [pmid: 1914988].
4115 Otamiri G, Berg G, Ledin T, et al. Influence of elective cesarean section and breech delivery on neonatal neurological condition. Early Hum Dev. Jun. 1990;23(1):53-66. X-1. [pmid: 2209475].
4116 Otley H. Fear of childbirth: Understanding the causes, impact and treatment. British Journal of Midwifery. 2011;19(4):215-220. X-1.
4117 Ott WJ, Mora G, Arias F, et al. Comparison of the modified biophysical profile to a “new” biophysical profile incorporating the middle cerebral artery to umbilical artery velocity flow systolic/diastolic ratio. Am J Obstet Gynecol. Jun. 1998;178(6):1346-53. X-4e, X-5. [pmid: 9662321].
4118 Ottervanger HP, Keirse MJ, Smit W, et al. Controlled comparison of induction versus expectant care for prelabor rupture of the membranes at term. J Perinat Med. 1996;24(3):237-42. X-4e. [pmid: 8827572].
4119 Ottinger WS, Menard MK, Brost BC. A randomized clinical trial of prostaglandin E2 intracervical gel and a slow release vaginal pessary for preinduction cervical ripening. Am J Obstet Gynecol. Aug. 1998;179(2):349-53. X-4d, X-5. [pmid: 9731837].
4120 Ottolini SR. Through the looking glass. Ann Emerg Med. Dec. 2009;54(6):841-2. X-1, X-2. [pmid: 19942070].
4121 Otubu JA, Kumi GO, Ezem BU. Pregnancy and delivery after successful repair of vesicovaginal fistula. Int J Gynaecol Obstet. Apr. 1982;20(2):163-6. X-1. [pmid: 6125440].
4122 Ou SX, Han D, Severson RK, et al. Birth characteristics, maternal reproductive history, hormone use during pregnancy, and risk of childhood acute lymphocytic leukemia by immunophenotype (United States). Cancer Causes Control. Feb. 2002;13(1):15-25. X-1. [pmid: 11899114].
4123 Ouellette A. New medical technology: a chance to reexamine court-ordered medical procedures during pregnancy. Albany Law Rev. 1994;57(3):927-60. X-1. [pmid: 11652868].
4124 Ouerghi S, Bougacha MA, Frikha N, et al. Combined use of crystalloid preload and low dose spinal anesthesia for preventing hypotension in spinal anesthesia for cesarean delivery: a randomized controlled trial. Middle East J Anesthesiol. Jun. 2010;20(5):667-72. X-9. [pmid: 20803854].
4125 Ouzounian JG, Masaki DI, Abboud TK, et al. Systemic vascular resistance index determined by thoracic electrical bioimpedance predicts the risk for maternal hypotension during regional anesthesia for cesarean delivery. Am J Obstet Gynecol. Mar. 1996;174(3):1019-25. X-9. [pmid: 8633629].
4126 Oweis AI. Relationships among the situational variables of perceived stress of the childbirth experience, perceived length and perceived difficulty of labor, selected personal variables, perceived nursing support and postpartum depression in primiparous Jordanian women living in Jordan. D.N.Sc. 2001:181. X-1.
4127 Owen J, Groome LJ, Hauth JC. Randomized trial of prophylactic antibiotic therapy after preterm amnion rupture. Am J Obstet Gynecol. Oct. 1993;169(4):976-81. X-4e, X-5. [pmid: 8238160].
4128 Owen J, Henson BV, Hauth JC. A prospective randomized study of saline solution amnioinfusion. Am J Obstet Gynecol. May. 1990;162(5):1146-9. X-4e, X-5. [pmid: 2187344].
4129 Owens LA, O'Sullivan EP, Kirwan B, et al. ATLANTIC DIP: the impact of obesity on pregnancy outcome in glucose-tolerant women. Diabetes Care. Mar. 2010;33(3):577-9. X-1, X-4e. [pmid: 20067952].
4130 Owens M, Bhullar A, Carlan SJ, et al. Effect of fundal pressure on maternal to fetal microtransfusion at the time of cesarean delivery. J Obstet Gynaecol Res. Jun. 2003;29(3):152-6. X-9. [pmid: 12841698].
4131 Owolabi AT, Dare FO, Fasubaa OB, et al. Risk factors for retained placenta in southwestern Nigeria. Singapore Med J. Jul. 2008;49(7):532-7. X-1. [pmid: 18695860].
4132 Owolabi AT, Kuti O, Ogunlola IO. Randomised trial of intravaginal misoprostol and intracervical Foley catheter for cervical ripening and induction of labour. J Obstet Gynaecol. Aug. 2005;25(6):565-8. X-4d. [pmid: 16234141].
4133 Oyarzun E, Gomez R, Rioseco A, et al. Antibiotic treatment in preterm labor and intact membranes: a randomized, double-blinded, placebo-controlled trial. J Matern Fetal Med. May-Jun. 1998;7(3):105-10. X-4e, X-5. [pmid: 9642605].
4134 Oyelese Y, Catanzarite V, Prefumo F, et al. Vasa previa: the impact of prenatal diagnosis on outcomes. Obstet Gynecol. May. 2004;103(5 Pt 1):937-42. X-1. [pmid: 15121568].
4135 Oyston J. Obstetrical anaesthesia in Ontario. Can J Anaesth. Dec. 1995;42(12):1117-25. X-1. [pmid: 8595688].
4136 Ozalp E, Tanir HM, Sener T. Dinoprostone vaginal insert versus intravenous oxytocin to reduce postpartum blood loss following vaginal or cesarean delivery. Clin Exp Obstet Gynecol. 2010;37(1):53-5. X-3, X-4b, X-4d, X-5. [pmid: 20420283].
4137 Ozarda Ilcol Y, Uncu G, Ulus IH. Free and phospholipid-bound choline concentrations in serum during pregnancy, after delivery and in newborns. Arch Physiol Biochem. Dec. 2002;110(5):393-9. X-1. [pmid: 12530624].
4138 Ozcakar ZB, Sahin F, Beyazova U, et al. Physical and mental development of Turkish twins. Pediatr Int. Dec. 2003;45(6):712-8. X-1. [pmid: 14651547].
4139 Ozkan S, Caliskan E, Doger E, et al. Comparative efficacy and safety of vaginal misoprostol versus dinoprostone vaginal insert in labor induction at term: a randomized trial. Arch Gynecol Obstet. Jul. 2009;280(1):19-24. X-4d. [pmid: 19034471].
4140 Ozsoy M, Ozsoy D. Induction of labor with 50 and 100 microg of misoprostol: comparison of maternal and fetal outcomes. Eur J Obstet Gynecol Reprod Biol. Mar. 15. 2004;113(1):41-4. X-4d, X-5. [pmid: 15036709].
4141 Ozturk A, Demirci F, Yavuz T, et al. Antenatal and delivery risk factors and prevalence of cerebral palsy in Duzce (Turkey). Brain Dev. Jan. 2007;29(1):39-42. X-1. [pmid: 16824718].
4142 Ozumba BC, Obi SN, Oli JM. Diabetes mellitus in pregnancy in an African population. Int J Gynaecol Obstet. Feb. 2004;84(2):114-9. X-1. [pmid: 14871512].
4143 Ozumbia BC, Ibe AI. Eclampsia in Enugu, eastern Nigeria. Acta Obstet Gynecol Scand. Apr. 1993;72(3):189-92. X-1. [pmid: 8385854].
4144 Pabinger I, Kyrle PA, Heistinger M, et al. The risk of thromboembolism in asymptomatic patients with protein C and protein S deficiency: a prospective cohort study. Thromb Haemost. Apr. 1994;71(4):441-5. X-1. [pmid: 8052960].
4145 Pacheco LD, Rosen MP, Gei AF, et al. Management of uterine hyperstimulation with concomitant use of oxytocin and terbutaline. Am J Perinatol. Aug. 2006;23(6):377-80. X-4e, X-5. [pmid: 16847795].
4146 Padilla SL, Spence MR, Beauchamp PJ. Single-dose ampicillin for cesarean section prophylaxis. Obstet Gynecol. Apr. 1983;61(4):463-6. X-9. [pmid: 6828277].
4147 Padmadas SS, Kumar S, Nair SB, et al. Caesarean section delivery in Kerala, India: evidence from a National Family Health Survey. Soc Sci Med. Aug. 2000;51(4):511-21. X-1. [pmid: 10868667].
4148 Paech MJ. Epidural anaesthesia for caesarean section: a comparison of 0.5% bupivacaine and 2% lignocaine both with adrenaline. Anaesth Intensive Care. May. 1988;16(2):187-96. X-9. [pmid: 3394912].
4149 Paech MJ. Epidural pethidine or fentanyl during caesarean section: a double-blind comparison. Anaesth Intensive Care. May. 1989;17(2):157-65. X-9. [pmid: 2719235].
4150 Paech MJ, Evans SF. Prospective clinical evaluation of two combined spinal-epidural kits. Anaesth Intensive Care. Oct. 1995;23(5):600-4. X-1. [pmid: 8787262].
4151 Paech MJ, Moore JS, Evans SF. Meperidine for patient-controlled analgesia after cesarean section. Intravenous versus epidural administration. Anesthesiology. Jun. 1994;80(6):1268-76. X-9. [pmid: 8010473].
4152 Paech MJ, Pavy TJ, Orlikowski CE, et al. Postcesarean analgesia with spinal morphine, clonidine, or their combination. Anesth Analg. May. 2004;98(5):1460-6. table of contents. X-9. [pmid: 15105231].
4153 Paech MJ, Westmore MD, Speirs HM. A double-blind comparison of epidural bupivacaine and bupivacaine-fentanyl for caesarean section. Anaesth Intensive Care. Feb. 1990;18(1):22-30. X-9. [pmid: 2186658].
4154 Pafumi C, Farina M, Bandiera S, et al. Differences in umbilical cord blood units collected during cesarean section, before or after the delivery of the placenta. Gynecol Obstet Invest. 2002;54(2):73-7. X-1. [pmid: 12566747].
4155 Pafumi C, Milone G, Maggi I, et al. Umbilical cord blood collection in Cesarean section: a comparison before and after placental delivery. Arch Gynecol Obstet. Aug. 2002;266(4):193-4. X-9. [pmid: 12192476].
4156 Page L. Fruitful labours. Nurs Stand. Jun 25-Jul 1. 2003;17(41):104. X-1, X-2. [pmid: 12861805].
4157 Page L, Beake S, Vail A, et al. Clinical outcomes of one-to-one midwifery practice. British Journal of Midwifery. 2001;9(11):700-706. X-1.
4158 Pahari K, Ghosh A. Study of pregnancy outcome over a period of five years in a postgraduate institute of west Bengal. J Indian Med Assoc. Jun. 1997;95(6):172-4. X-1. [pmid: 9420393].
4159 Paine MA, Scioscia M, Gumaa KA, et al. P-type inositol phosphoglycans in serum and amniotic fluid in active pre-eclampsia. J Reprod Immunol. Apr. 2006;69(2):165-79. X-1. [pmid: 16384607].
4160 Pak SC, Song CH, So GY, et al. Extrauterine incubation of fetal goats applying the extracorporeal membrane oxygenation via umbilical artery and vein. J Korean Med Sci. Oct. 2002;17(5):663-8. X-1. [pmid: 12378020].
4161 Pakenham S, Chamberlain SM, Smith GN. Women's views on elective primary caesarean section. J Obstet Gynaecol Can. Dec. 2006;28(12):1089-94. X-1. [pmid: 17169232].
4162 Pal M, Biswas AK, Bhattacharya SM. B-Lynch Brace Suturing in primary post-partum hemorrhage during cesarean section. J Obstet Gynaecol Res. Oct. 2003;29(5):317-20. X-1. [pmid: 14641702].
4163 Palacios Jaraquemada JM, Pesaresi M, Nassif JC, et al. Anterior placenta percreta: surgical approach, hemostasis and uterine repair. Acta Obstet Gynecol Scand. Aug. 2004;83(8):738-44. X-1. [pmid: 15255846].
4164 Palacios QT, Jones MM, Hawkins JL, et al. Post-caesarean section analgesia: a comparison of epidural butorphanol and morphine. Can J Anaesth. Jan. 1991;38(1):24-30. X-9. [pmid: 1989736].
4165 Palacios-Jaraquemada JM. Diagnosis and management of placenta accreta. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22(6):1133-48. X-1, X-2. [pmid: 18815074].
4166 Palahniuk RJ, Cumming M. Serum cholinesterase activity following the use of methoxyflurane in obstetrics. Anesthesiology. Dec. 1977;47(6):520-2. X-4e. [pmid: 337857].
4167 Palencia R, Gafni A, Hannah ME, et al. The costs of planned cesarean versus planned vaginal birth in the Term Breech Trial. CMAJ. Apr. 11. 2006;174(8):1109-13. X-1. [pmid: 16606959].
4168 Pallasmaa N, Ekblad U, Aitokallio-Tallberg A, et al. Cesarean delivery in Finland: maternal complications and obstetric risk factors. Acta Obstet Gynecol Scand. Jul. 2010;89(7):896-902. X-1, X-9. [pmid: 20583935].
4169 Palmer AW, Waugaman WR, Conklin KA, et al. Does the administration of oral Bicitra before elective cesarean section affect the incidence of nausea and vomiting in the parturient?. Nurse Anesth. Sep. 1991;2(3):126-33. X-9. [pmid: 1888787].
4170 Palmer CM, Emerson S, Volgoropolous D, et al. Dose-response relationship of intrathecal morphine for postcesarean analgesia. Anesthesiology. Feb. 1999;90(2):437-44. X-9. [pmid: 9952150].
4171 Palmer CM, Nogami WM, Van Maren G, et al. Postcesarean epidural morphine: a dose-response study. Anesth Analg. Apr. 2000;90(4):887-91. X-9. [pmid: 10735794].
4172 Palmer CM, Voulgaropoulos D, Alves D. Subarachnoid fentanyl augments lidocaine spinal anesthesia for cesarean delivery. Reg Anesth. Sep-Oct. 1995;20(5):389-94. X-9. [pmid: 8519715].
4173 Palomba S, Falbo A, Russo T, et al. Pregnancy in women with polycystic ovary syndrome: the effect of different phenotypes and features on obstetric and neonatal outcomes. Fertil Steril. Oct. 2010;94(5):1805-11. X-1. [pmid: 20004377].
4174 Palta M, Sadek M, Gabbert D, et al. The relation of maternal complications to outcomes in very low birthweight infants in an era of changing neonatal care. Am J Perinatol. Feb. 1996;13(2):109-14. X-1. [pmid: 8672182].
4175 Pan MH, Wei TT, Shieh BS. Comparative analgesic enhancement of alfentanil, fentanyl, and sufentanil to spinal tetracaine anesthesia for cesarean delivery. Acta Anaesthesiol Sin. Sep. 1994;32(3):171-6. X-9. [pmid: 7921862].
4176 Pan PH, James CF. Anesthetic-postoperative morphine regimens for cesarean section and postoperative oxygen saturation monitored by a telemetric pulse oximetry network for 24 continuous hours. J Clin Anesth. Mar-Apr. 1994;6(2):124-8. X-9. [pmid: 8204230].
4177 Pan PH, Moore CH. Intraoperative antiemetic efficacy of prophylactic ondansetron versus droperidol for cesarean section patients under epidural anesthesia. Anesth Analg. Nov. 1996;83(5):982-6. X-9. [pmid: 8895272].
4178 Pan PH, Moore CH. Comparing the efficacy of prophylactic metoclopramide, ondansetron, and placebo in cesarean section patients given epidural anesthesia. J Clin Anesth. Sep. 2001;13(6):430-5. X-9. [pmid: 11578887].
4179 Pan PM, Huang CT, Wei TT, et al. Enhancement of analgesic effect of intrathecal neostigmine and clonidine on bupivacaine spinal anesthesia. Reg Anesth Pain Med. Jan-Feb. 1998;23(1):49-56. X-9. [pmid: 9552778].
4180 Panburana P, Phaupradit W, Tantisirin O, et al. Maternal complications after Caesarean section in HIV-infected pregnant women. Aust N Z J Obstet Gynaecol. Apr. 2003;43(2):160-3. X-9. [pmid: 14712975].
4181 Panburana P, Sirinavin S, Phuapradit W, et al. Elective cesarean delivery plus short-course lamivudine and zidovudine for the prevention of mother-to-child transmission of human immunodeficiency virus type 1. Am J Obstet Gynecol. Mar. 2004;190(3):803-8. X-9. [pmid: 15042018].
4182 Panchal S, Arria AM, Harris AP. Intensive care utilization during hospital admission for delivery: prevalence, risk factors, and outcomes in a statewide population. Anesthesiology. Jun. 2000;92(6):1537-44. X-1. [pmid: 10839902].
4183 Pandian RU. Dydrogesterone in threatened miscarriage: a Malaysian experience. Maturitas. Dec. Suppl 1. 2009;65:S47-50. X-4e. [pmid: 20005647].
4184 Pandian Z, Bhattacharya S, Templeton A. Review of unexplained infertility and obstetric outcome: a 10 year review. Hum Reprod. Dec. 2001;16(12):2593-7. X-1. [pmid: 11726580].
4185 Pandis GK, Papageorghiou AT, Otigbah CM, et al. Randomized study of vaginal misoprostol (PGE(1)) and dinoprostone gel (PGE(2)) for induction of labor at term. Ultrasound Obstet Gynecol. Dec. 2001;18(6):629-35. X-4d. [pmid: 11844203].
4186 Pandis GK, Papageorghiou AT, Ramanathan VG, et al. Preinduction sonographic measurement of cervical length in the prediction of successful induction of labor. Ultrasound Obstet Gynecol. Dec. 2001;18(6):623-8. X-1. [pmid: 11844202].
4187 Pang MW, Lee TS, Leung AK, et al. A longitudinal observational study of preference for elective caesarean section among nulliparous Hong Kong Chinese women. BJOG. May. 2007;114(5):623-9. X-1. [pmid: 17355362].
4188 Pang SM, Leung DT, Leung TY, et al. Determinants of preference for elective caesarean section in Hong Kong Chinese pregnant women. Hong Kong Med J. Apr. 2007;13(2):100-5. X-1. [pmid: 17406036].
4189 Panni MK, Segal S. Local anesthetic requirements are greater in dystocia than in normal labor. Anesthesiology. Apr. 2003;98(4):957-63. X-1, X-3, X-4e. [pmid: 12657859].
4190 Panting-Kemp A, Nguyen T, Chang E, et al. Idiopathic polyhydramnios and perinatal outcome. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1079-82. X-1. [pmid: 10561621].
4191 Papadopoulos VG, Decavalas GO, Kondakis XG, et al. Vibroacoustic stimulation in abnormal biophysical profile: verification of facilitation of fetal well-being. Early Hum Dev. Mar. 2007;83(3):191-7. X-4e. [pmid: 16860496].
4192 Papageorgiou I, Tsionou C, Minaretzis D, et al. Labor characteristics of uncomplicated prolonged pregnancies after induction with intracervical prostaglandin E2 gel versus intravenous oxytocin. Gynecol Obstet Invest. 1992;34(2):92-6. X-4d. [pmid: 1398272].
4193 Papaloucas A, Kotoulas IG, Paradelis AG. Evaluation of cephradine-chemoprophylaxis in Cesarean section. Methods Find Exp Clin Pharmacol. Jan-Feb. 1981;3(1):29-32. X-9. [pmid: 7230973].
4194 Papamicheal E, Pillai R, Yoong W. Children having children: Outcome of extreme teenage pregnancies (13-15 years). Acta Obstet Gynecol Scand. 2009;88(11):1284-7. X-1. [pmid: 19900143].
4195 Papandreou L, Chasiotis G, Seferiadis K, et al. Calcium levels during the initiation of labor. Eur J Obstet Gynecol Reprod Biol. Jul. 15. 2004;115(1):17-22. X-1. [pmid: 15223159].
4196 Papanikolaou EG, Plachouras N, Drougia A, et al. Comparison of misoprostol and dinoprostone for elective induction of labour in nulliparous women at full term: a randomized prospective study. Reprod Biol Endocrinol. Sep. 27. 2004;2:70. X-4d. [pmid: 15450119].
4197 Papinniemi M, Keski-Nisula L, Heinonen S. Placental ratio and risk of velamentous umbilical cord insertion are increased in women with placenta previa. Am J Perinatol. Jun. 2007;24(6):353-7. X-1. [pmid: 17564954].
4198 Paquet C, Steben M. Prevention of and screening for herpes simplex infection: a survey of Quebec physicians. J Obstet Gynaecol Can. Feb. 2010;32(2):126-31. X-1. [pmid: 20181313].
4199 Paranjothy S, Frost C, Thomas J. How much variation in CS rates can be explained by case mix differences?. BJOG. May. 2005;112(5):658-66. X-1. [pmid: 15842293].
4200 Paraskeva A, Staikou C, Melemeni A, et al. Intravenous morphine and droperidol after caesarean delivery under subarachnoid anaesthesia has no effect on postoperative pain or analgesic requirements. Eur J Anaesthesiol. Oct. 2009;26(10):847-50. X-9. [pmid: 19606048].
4201 Paraskevaidis E, Koliopoulos G, Lolis E, et al. Delivery outcomes following loop electrosurgical excision procedure for microinvasive (FIGO stage IA1) cervical cancer. Gynecol Oncol. Jul. 2002;86(1):10-3. X-1. [pmid: 12079292].
4202 Parazzini F, Benedetto C, Danti L, et al. A randomized comparison of vaginal prostaglandin E2 with oxytocin plus amniotomy for induction of labour in women with intermediately ripe cervices. Eur J Obstet Gynecol Reprod Biol. Oct. 1998;81(1):15-20. X-4d. [pmid: 9846707].
4203 Parazzini F, Dindelli M, Luchini L, et al. Risk factors for placenta praevia. Placenta. Apr. 1994;15(3):321-6. X-1. [pmid: 8066055].
4204 Parazzini F, Tozzi L, Ferraroni M, et al. Risk factors for ectopic pregnancy: an Italian case-control study. Obstet Gynecol. Nov. 1992;80(5):821-6. X-1. [pmid: 1407922].
4205 Pardi G, Buscaglia M, Ferrazzi E, et al. Cord sampling for the evaluation of oxygenation and acid-base balance in growth-retarded human fetuses. Am J Obstet Gynecol. Nov. 1987;157(5):1221-8. X-1, X-3, X-4e, X-5. [pmid: 3688078].
4206 Parekh N, Husaini SW, Russell IF. Caesarean section for placenta praevia: a retrospective study of anaesthetic management. Br J Anaesth. Jun. 2000;84(6):725-30. X-1. [pmid: 10895745].
4207 Parilla BV, McDermott TM. Prophylactic amnioinfusion in preganancies complicated by chorioamnionitis: a prospective randomized trial. Am J Perinatol. 1998;15(12):649-52. X-4e, X-5. [pmid: 10333390].
4208 Park BJ, Kim YW. Safety of cesarean myomectomy. J Obstet Gynaecol Res. Oct. 2009;35(5):906-11. X-1. [pmid: 20149040].
4209 Park BY, Jeong CW, Jang EA, et al. Dose-related attenuation of cardiovascular responses to tracheal intubation by intravenous remifentanil bolus in severe pre-eclamptic patients undergoing Caesarean delivery. Br J Anaesth. Jan. 2011;106(1):82-7. X-9. [pmid: 20947593].
4210 Park CS, Yeoum SG, Choi ES. Study of subjectivity in the perception of cesarean birth. Nurs Health Sci. Mar. 2005;7(1):3-8. X-1. [pmid: 15670000].
4211 Park GE, Hauch MA, Curlin F, et al. The effects of varying volumes of crystalloid administration before cesarean delivery on maternal hemodynamics and colloid osmotic pressure. Anesth Analg. Aug. 1996;83(2):299-303. X-9. [pmid: 8694309].
4212 Parker CR Jr., Favor JK, Carden LG, et al. Effects of intrapartum stress on fetal adrenal function. Am J Obstet Gynecol. Dec. 1993;169(6):1407-11. X-1. [pmid: 8267037].
4213 Parker RK, Holtmann B, White PF. Patient-controlled epidural analgesia: interactions between nalbuphine and hydromorphone. Anesth Analg. Apr. 1997;84(4):757-63. X-9. [pmid: 9085953].
4214 Parker RK, Sawaki Y, White PF. Epidural patient-controlled analgesia: influence of bupivacaine and hydromorphone basal infusion on pain control after cesarean delivery. Anesth Analg. Nov. 1992;75(5):740-6. X-9. [pmid: 1384397].
4215 Parker RK, White PF. Epidural patient-controlled analgesia: an alternative to intravenous patient-controlled analgesia for pain relief after cesarean delivery. Anesth Analg. Aug. 1992;75(2):245-51. X-9. [pmid: 1378707].
4216 Parks DG, Ziel HK. Macrosomia. A proposed indication for primary cesarean section. Obstet Gynecol. Oct. 1978;52(4):407-9. X-1. [pmid: 309570].
4217 Parnass SM, Curran MJ, Becker GL. Incidence of hypotension associated with epidural anesthesia using alkalinized and nonalkalinized lidocaine for cesarean section. Anesth Analg. Nov. 1987;66(11):1148-50. X-1. [pmid: 3662059].
4218 Parpaglioni R, Baldassini B, Barbati G, et al. Adding sufentanil to levobupivacaine or ropivacaine intrathecal anaesthesia affects the minimum local anaesthetic dose required. Acta Anaesthesiol Scand. Oct. 2009;53(9):1214-20. X-9. [pmid: 19650807].
4219 Parpaglioni R, Capogna G, Celleno D, et al. Intraoperative fetal oxygen saturation during Caesarean section: general anaesthesia using sevoflurane with either 100% oxygen or 50% nitrous oxide in oxygen. Eur J Anaesthesiol. Feb. 2002;19(2):115-8. X-9. [pmid: 11999593].
4220 Parpaglioni R, Frigo MG, Lemma A, et al. Minimum local anaesthetic dose (MLAD) of intrathecal levobupivacaine and ropivacaine for Caesarean section. Anaesthesia. Feb. 2006;61(2):110-5. X-9. [pmid: 16430561].
4221 Parry E, Parry D, Pattison N. Induction of labour for post term pregnancy: an observational study. Aust N Z J Obstet Gynaecol. Aug. 1998;38(3):275-80. X-1. [pmid: 9761152].
4222 Parry MG, Fernando R, Bawa GP, et al. Dorsal column function after epidural and spinal blockade: implications for the safety of walking following low-dose regional analgesia for labour. Anaesthesia. Apr. 1998;53(4):382-7. X-9. [pmid: 9613305].
4223 Parsons AK, Sauer MV, Parsons MT, et al. Appendectomy at cesarean section: a prospective study. Obstet Gynecol. Oct. 1986;68(4):479-82. X-9. [pmid: 3748495].
4224 Parsons M, Nagy S. Anaesthetists' perspective on oral intake for women in labour. British Journal of Midwifery. 2006;14(8):488-491. X-1.
4225 Parsons M, Simpson M, Ponton T. Raspberry leaf and its effect on labour: safety and efficacy. Aust Coll Midwives Inc J. Sep. 1999;12(3):20-5. X-1. [pmid: 10754818].
4226 Parsons MT, Spellacy WN. Prospective randomized study of x-ray pelvimetry in the primigravida. Obstet Gynecol. Jul. 1985;66(1):76-9. X-4e, X-5. [pmid: 4011073].
4227 Parsons MT, Winegar A, Siefert L, et al. Pregnancy outcomes in short women. J Reprod Med. May. 1989;34(5):357-61. X-1. [pmid: 2732984].
4228 Pasquini L, Wimalasundera RC, Fichera A, et al. High perinatal survival in monoamniotic twins managed by prophylactic sulindac, intensive ultrasound surveillance, and Cesarean delivery at 32 weeks' gestation. Ultrasound Obstet Gynecol. Oct. 2006;28(5):681-7. X-1. [pmid: 17001748].
4229 Pasternak DP, Pine M, Nolan K, et al. Risk-adjusted measurement of primary cesarean sections: reliable assessment of the quality of obstetrical services. Qual Manag Health Care. Fall. 1999;8(1):47-54. X-1. [pmid: 10662103].
4230 Pastorfide GB, Gorgonio NM, Ganzon AR, et al. Zinc chloride spray--magnesium hydroxide ointment dual topical regimen in the treatment of obstetric and gynecologic incisional wounds. Clin Ther. Mar-Apr. 1989;11(2):258-63. X-3, X-4b, X-4e, X-5. [pmid: 2660997].
4231 Pasupathy D, Wood AM, Pell JP, et al. Time trend in the risk of delivery-related perinatal and neonatal death associated with breech presentation at term. Int J Epidemiol. Apr. 2009;38(2):490-8. X-1. [pmid: 18977783].
4232 Pasupathy D, Wood AM, Pell JP, et al. Time of birth and risk of neonatal death at term: retrospective cohort study. BMJ. 2010;341:c3498. X-1. [pmid: 20634347].
4233 Patel JA, Patel NA, Thomas RL, et al. Pregnancy outcomes after laparoscopic Roux-en-Y gastric bypass. Surg Obes Relat Dis. Jan-Feb. 2008;4(1):39-45. X-1. [pmid: 18201669].
4234 Patel M, Samsoon G, Swami A, et al. Posture and the spread of hyperbaric bupivacaine in parturients using the combined spinal epidural technique. Can J Anaesth. Oct. 1993;40(10):943-6. X-9. [pmid: 8222034].
4235 Patel P, Desai P, Gajjar F. Labor epidural analgesia in pre-eclampsia: a prospective study. J Obstet Gynaecol Res. Aug. 2005;31(4):291-5. X-4e. [pmid: 16018774].
4236 Pateman K, Khalil A, O'Brien P. Electronic fetal heart rate monitoring: help or hindrance?. British Journal of Midwifery. 2008;16(7):454-457. X-1, X-2.
4237 Paterson-Brown S, Fisk NM, Edmonds DK, et al. Preinduction cervical assessment by Bishop's score and transvaginal ultrasound. Eur J Obstet Gynecol Reprod Biol. Jun. 5. 1991;40(1):17-23. X-1, X-4e, X-5. [pmid: 1855604].
4238 Patnaik P, Rout GC. Prostaglandin E2 gel for cervical priming and induction of labour in unfavourable cervical state. J Indian Med Assoc. Apr. 1995;93(4):140-1. 135. X-1, X-4d, X-5. [pmid: 8699040].
4239 Patolia DS, Hilliard RL, Toy EC, et al. Early feeding after cesarean: randomized trial. Obstet Gynecol. Jul. 2001;98(1):113-6. X-9. [pmid: 11430967].
4240 Pattanittum P, Ewens MR, Laopaiboon M, et al. Use of antenatal corticosteroids prior to preterm birth in four South East Asian countries within the SEA-ORCHID project. BMC Pregnancy Childbirth. 2008;8:47. X-1. [pmid: 18925968].
4241 Patterson CC, Carson DJ, Hadden DR, et al. A case-control investigation of perinatal risk factors for childhood IDDM in Northern Ireland and Scotland. Diabetes Care. May. 1994;17(5):376-81. X-1. [pmid: 8062603].
4242 Patterson DA, Winslow M, Matus CD. Spontaneous vaginal delivery. Am Fam Physician. Aug. 1. 2008;78(3):336-41. X-1, X-2. [pmid: 18711948].
4243 Pattinson RC, Farrell EE. Pelvimetry for fetal cephalic presentations at or near term. Cochrane Database of Systematic Reviews. 1997;(2). X-1, X-2.
4244 Pattinson RC, Norman K, Odendaal HJ. The role of Doppler velocimetry in the management of high risk pregnancies. Br J Obstet Gynaecol. Feb. 1994;101(2):114-20. X-4e. [pmid: 8305384].
4245 Patumanond J, Tawichasri C, Khunpradit S. Infant male sex as a risk factor for shoulder dystocia but not for cephalopelvic disproportion: an independent or confounded effect?. Gend Med. Feb. 2010;7(1):55-63. X-1. [pmid: 20189155].
4246 Patwardhan VB. Eclampsia. J Indian Med Assoc. Feb. 1995;93(2):58-9. 48. X-1, X-2. [pmid: 7658039].
4247 Paul DA, Locke R, Zook K, et al. Racial differences in prenatal care of mothers delivering very low birth weight infants. J Perinatol. Feb. 2006;26(2):74-8. X-1. [pmid: 16407965].
4248 Paul DA, Mackley A, Locke RG, et al. State infant mortality: an ecologic study to determine modifiable risks and adjusted infant mortality rates. Matern Child Health J. May. 2009;13(3):343-8. X-1. [pmid: 18473130].
4249 Paumgartten FJ, Magalhaes-de-Souza CA, de-Carvalho RR, et al. Embryotoxic effects of misoprostol in the mouse. Braz J Med Biol Res. Mar. 1995;28(3):355-61. X-1. [pmid: 8520532].
4250 Paungmora N, Herabutya Y, OP P, et al. Comparison of oral and vaginal misoprostol for induction of labor at term: a randomized controlled trial. J Obstet Gynaecol Res. Oct. 2004;30(5):358-62. X-4d. [pmid: 15327448].
4251 Pavicic H, Hamelin K, Menticoglou SM. Does routine induction of labour at 41 weeks really reduce the rate of caesarean section compared with expectant management?. J Obstet Gynaecol Can. Jul. 2009;31(7):621-6. X-1. [pmid: 19761635].
4252 Pavlova-Greenfield T, Sutija VG, Gudavalli M. Adolescent pregnancy: positive perinatal outcome at a community hospital. J Perinat Med. 2000;28(6):443-6. X-1. [pmid: 11155429].
4253 Pavy TJ, Gambling DR, Merrick PM, et al. Rectal indomethacin potentiates spinal morphine analgesia after caesarean delivery. Anaesth Intensive Care. Oct. 1995;23(5):555-9. X-9. [pmid: 8787253].
4254 Pavy TJ, Paech MJ, Evans SF. The effect of intravenous ketorolac on opioid requirement and pain after cesarean delivery. Anesth Analg. Apr. 2001;92(4):1010-4. X-9. [pmid: 11273941].
4255 Payne SD, Resnik R, Moore TR, et al. Maternal characteristics and risk of severe neonatal thrombocytopenia and intracranial hemorrhage in pregnancies complicated by autoimmune thrombocytopenia. Am J Obstet Gynecol. Jul. 1997;177(1):149-55. X-1. [pmid: 9240599].
4256 Peaceman AM, Feinglass J, Manheim LM. Risk-adjustment of cesarean delivery rates: a practical method for use in quality improvement. Am J Med Qual. May-Jun. 2002;17(3):113-7. X-1. [pmid: 12073867].
4257 Peaceman AM, Lopez-Zeno JA, Minogue JP, et al. Factors that influence route of delivery--active versus traditional labor management. Am J Obstet Gynecol. Oct. 1993;169(4):940-4. X-1, X-5. [pmid: 8238153].
4258 Pearce C, Torres C, Stallings S, et al. Elective appendectomy at the time of cesarean delivery: a randomized controlled trial. Am J Obstet Gynecol. Nov. 2008;199(5):491 e1-5. X-9. [pmid: 18486093].
4259 Pearson L, Shoo R. Availability and use of emergency obstetric services: Kenya, Rwanda, Southern Sudan, and Uganda. Int J Gynaecol Obstet. Feb. 2005;88(2):208-15. X-1. [pmid: 15694109].
4260 Peck RW, Price DE, Lang GD, et al. Birthweight of babies born to mothers with type 1 diabetes: is it related to blood glucose control in the first trimester?. Diabet Med. Apr. 1991;8(3):258-62. X-1. [pmid: 1828742].
4261 Peckham C, Newell ML. Human immunodeficiency virus infection and mode of delivery. Acta Paediatr Suppl. Jun. 1997;421:104-6. X-1, X-2. [pmid: 9240868].
4262 Pedersen H, Santos AC, Steinberg ES, et al. Incidence of visceral pain during cesarean section: the effect of varying doses of spinal bupivacaine. Anesth Analg. Jul. 1989;69(1):46-9. X-9. [pmid: 2742167].
4263 Pedersen JE, Fernandes A, Christensen M. Halothane 2% for caesarean section. Eur J Anaesthesiol. Jul. 1992;9(4):319-24. X-9. [pmid: 1628635].
4264 Pedersen P, Avlund OL, Pedersen BL, et al. Intramuscular adrenaline does not reduce the incidence of respiratory distress and hypoglycaemia in neonates delivered by elective caesarean section at term. Arch Dis Child Fetal Neonatal Ed. May. 2009;94(3):F164-7. X-9. [pmid: 18786961].
4265 Peek M, Shennan A, Halligan A, et al. Hypertension in pregnancy: which method of blood pressure measurement is most predictive of outcome?. Obstet Gynecol. Dec. 1996;88(6):1030-3. X-1. [pmid: 8942848].
4266 Peipert JF, Bracken MB. Maternal age: an independent risk factor for cesarean delivery. Obstet Gynecol. Feb. 1993;81(2):200-5. X-1. [pmid: 8423950].
4267 Peipert JF, Hogan JW, Gifford D, et al. Strength of indication for cesarean delivery: comparison of private physician versus resident service labor management. Am J Obstet Gynecol. Aug. 1999;181(2):435-9. X-1. [pmid: 10454697].
4268 Peixoto AJ, Celich MF, Zardo L, et al. Ondansetron or droperidol for prophylaxis of nausea and vomiting after intrathecal morphine. Eur J Anaesthesiol. Aug. 2006;23(8):670-5. X-9. [pmid: 16805932].
4269 Peled Y, Perri T, Chen R, et al. Gestational diabetes mellitus--implications of different treatment protocols. J Pediatr Endocrinol Metab. Jun. 2004;17(6):847-52. X-1. [pmid: 15270402].
4270 Peleg D, Hannah ME, Hodnett ED, et al. Predictors of cesarean delivery after prelabor rupture of membranes at term. Obstet Gynecol. Jun. 1999;93(6):1031-5. X-4e. [pmid: 10362176].
4271 Pellegrini JE, Bailey SL, Graves J, et al. The impact of nalmefene on side effects due to intrathecal morphine at cesarean section. AANA J. Jun. 2001;69(3):199-205. X-9. [pmid: 11759562].
4272 Pelosi M, Langer A, Hung C. Prophylactic internal iliac artery ligation at cesarean hysterectomy. Am J Obstet Gynecol. Feb. 1. 1975;121(3):394-8. X-1. [pmid: 1115154].
4273 Peltz B, Sinclair DM. Induction agents for Caesarean section. A comparison of thiopentone and ketamine. Anaesthesia. Jan. 1973;28(1):37-42. X-9. [pmid: 4687055].
4274 Pembrey L, Newell ML, Tovo PA. The management of HCV infected pregnant women and their children European paediatric HCV network. J Hepatol. Sep. 2005;43(3):515-25. X-1. [pmid: 16144064].
4275 Pence S, Kocoglu H, Balat O, et al. The effect of delivery on umbilical arterial cord blood gases and lipid peroxides: comparison of vaginal delivery and cesarean section. Clin Exp Obstet Gynecol. 2002;29(3):212-4. X-1, X-3, X-4e. [pmid: 12519045].
4276 Penn ZJ, Steer PJ. Reasons for declining participation in a prospective randomized trial to determine the optimum mode of delivery of the preterm breech. Control Clin Trials. Aug. 1990;11(4):226-31. X-1. [pmid: 2171875].
4277 Penn ZJ, Steer PJ. How obstetricians manage the problem of preterm delivery with special reference to the preterm breech. Br J Obstet Gynaecol. Jun. 1991;98(6):531-4. X-1. [pmid: 1873242].
4278 Penn ZJ, Steer PJ, Grant A. A multicentre randomised controlled trial comparing elective and selective caesarean section for the delivery of the preterm breech infant. Br J Obstet Gynaecol. Jul. 1996;103(7):684-9. X-9. [pmid: 8688396].
4279 Pennell CE, Henderson JJ, O'Neill MJ, et al. Induction of labour in nulliparous women with an unfavourable cervix: a randomised controlled trial comparing double and single balloon catheters and PGE2 gel. BJOG. Oct. 2009;116(11):1443-52. X-4d. [pmid: 19656148].
4280 Pennison EH, Egerman RS. Perinatal outcomes in gestational diabetes: a comparison of criteria for diagnosis. Am J Obstet Gynecol. May. 2001;184(6):1118-21. X-1. [pmid: 11349174].
4281 Pentecost AF. The effect of buccal ‘pitocin’ on the unripe cervix. Curr Med Res Opin. 1973;1(8):482-4. X-1. [pmid: 4772976].
4282 Pepple DJ, Mullings AM, Reid HL. Increased incidence of adverse perinatal outcome with low maternal blood viscosity in preeclampsia. Clin Hemorheol Microcirc. 2004;30(2):127-31. X-1. [pmid: 15004337].
4283 Pereira C, Bugalho A, Bergstrom S, et al. A comparative study of caesarean deliveries by assistant medical officers and obstetricians in Mozambique. Br J Obstet Gynaecol. Jun. 1996;103(6):508-12. X-1, X-9. [pmid: 8645640].
4284 Peretz B, Kafka I. Baby bottle tooth decay and complications during pregnancy and delivery. Pediatr Dent. Jan-Feb. 1997;19(1):34-6. X-1. [pmid: 9048411].
4285 Perez-Then E, Pena R, Tavarez-Rojas M, et al. Preventing mother-to-child HIV transmission in a developing country: the Dominican Republic experience. J Acquir Immune Defic Syndr. Dec. 15. 2003;34(5):506-11. X-1. [pmid: 14657762].
4286 Periti P, Mazzei T, Lamanna S, et al. Single-dose ceftriaxone versus multi-dose cefotaxime antimicrobial prophylaxis in gynecologic and obstetrical surgery. Preliminary results of a multicenter prospective randomized study. Chemioterapia. Oct. 1984;3(5):299-304. X-9. [pmid: 6099757].
4287 Perkins RP. The merits of extraperitoneal cesarean section: a continuing experience. J Reprod Med. Sep. 1977;19(3):154-8. X-1. [pmid: 894659].
4288 Perkins RP. Perinatal observations in a high-risk population managed without intrapartum fetal pH studies. Am J Obstet Gynecol. Jun. 1. 1984;149(3):327-36. X-1. [pmid: 6731510].
4289 Perlman JM, Broyles RS, Rogers CG. Neonatal neurologic characteristics of preterm twin infants <1,250 gm birth weight. Pediatr Neurol. Nov. 1997;17(4):322-6. X-1. [pmid: 9436796].
4290 Perlow JH, Montgomery D, Morgan MA, et al. Severity of asthma and perinatal outcome. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):963-7. X-1. [pmid: 1415433].
4291 Perlow JH, Morgan MA. Massive maternal obesity and perioperative cesarean morbidity. Am J Obstet Gynecol. Feb. 1994;170(2):560-5. X-1. [pmid: 8116713].
4292 Perlow JH, Morgan MA, Montgomery D, et al. Perinatal outcome in pregnancy complicated by massive obesity. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):958-62. X-1. [pmid: 1415432].
4293 Perreault C, Blaise GA, Meloche R. Another look at maternal inspired oxygen concentration during cesarian section. Can J Anaesth. May. 1990;37(4 Pt 2):S118. X-9. [pmid: 2193727].
4294 Perreault C, Blaise GA, Meloche R. Maternal inspired oxygen concentration and fetal oxygenation during caesarean section. Can J Anaesth. Feb. 1992;39(2):155-7. X-9. [pmid: 1544196].
4295 Perreault C, Guay J, Gaudreault P, et al. Residual curarization in the neonate after caesarean section. Can J Anaesth. Jul. 1991;38(5):587-91. X-1. [pmid: 1934206].
4296 Perri T, Chen R, Yoeli R, et al. Are singleton assisted reproductive technology pregnancies at risk of prematurity?. J Assist Reprod Genet. May. 2001;18(5):245-9. X-1. [pmid: 11464574].
4297 Perriss BW, Latham BV, Wilson IH. Analgesia following extradural and i.m. pethidine in post-caesarean section patients. Br J Anaesth. Mar. 1990;64(3):355-7. X-9. [pmid: 2183864].
4298 Perry MY, Leaphart WL. Randomized trial of intracervical versus posterior fornix dinoprostone for induction of labor. Obstet Gynecol. Jan. 2004;103(1):13-7. X-4d. [pmid: 14704238].
4299 Persson M, Norman M, Hanson U. Obstetric and perinatal outcomes in type 1 diabetic pregnancies: A large, population-based study. Diabetes Care. Nov. 2009;32(11):2005-9. X-1. [pmid: 19675195].
4300 Persson-Kjerstadius N, Forsgren H, Westgren M. Intrapartum amnioinfusion in women with oligohydramniosis. A prospective randomized trial. Acta Obstet Gynecol Scand. Feb. 1999;78(2):116-9. X-4e. [pmid: 10023873].
4301 Perveen S. Maternal and neonatal adverse outcome at repeat cesarean delivery versus repeat vaginal delivery. J Coll Physicians Surg Pak. Feb. 2011;21(2):84-7. X-1. [pmid: 21333238].
4302 Peschers U, Schaer G, Anthuber C, et al. Changes in vesical neck mobility following vaginal delivery. Obstet Gynecol. Dec. 1996;88(6):1001-6. X-1. [pmid: 8942842].
4303 Peschers UM, Schaer GN, DeLancey JO, et al. Levator ani function before and after childbirth. Br J Obstet Gynaecol. Sep. 1997;104(9):1004-8. X-1. [pmid: 9307525].
4304 Peskin DT. The impact of analgesic dosing strategy on motor blockade and mode of delivery for women in labor. Ph.D. 2006:176. X-4e.
4305 Peters C, Cowley M, Standiford L. The process of outcomes management in an acute care facility. Nurs Adm Q. Fall. 1999;24(1):75-89. X-1. [pmid: 10765248].
4306 Peterson CM, Medchill M, Gordon DS, et al. Cesarean prophylaxis: a comparison of cefamandole and cefazolin by both intravenous and lavage routes, and risk factors associated with endometritis. Obstet Gynecol. Feb. 1990;75(2):179-82. X-9. [pmid: 2405316].
4307 Petraglia F, Di Blasio AM, Florio P, et al. High levels of fetal membrane activin beta A and activin receptor IIB mRNAs and augmented concentration of amniotic fluid activin A in women in term or preterm labor. J Endocrinol. Jul. 1997;154(1):95-101. X-1. [pmid: 9246942].
4308 Petropoulos G, Siristatidis C, Salamalekis E, et al. Spinal and epidural versus general anesthesia for elective cesarean section at term: effect on the acid-base status of the mother and newborn. J Matern Fetal Neonatal Med. Apr. 2003;13(4):260-6. X-1. [pmid: 12854928].
4309 Petrou S, Glazener C. The economic costs of alternative modes of delivery during the first two months postpartum: results from a Scottish observational study. BJOG. Feb. 2002;109(2):214-7. X-1. [pmid: 11888105].
4310 Pettker CM, Pocock SB, Smok DP, et al. Transcervical Foley catheter with and without oxytocin for cervical ripening: a randomized controlled trial. Obstet Gynecol. Jun. 2008;111(6):1320-6. X-4d. [pmid: 18515515].
4311 Pevzner L, Goffman D, Freda MC, et al. Patients' attitudes associated with cesarean delivery on maternal request in an urban population. Am J Obstet Gynecol. May. 2008;198(5):e35-7. X-1. [pmid: 18199421].
4312 Pevzner L, Powers BL, Rayburn WF, et al. Effects of maternal obesity on duration and outcomes of prostaglandin cervical ripening and labor induction. Obstet Gynecol. Dec. 2009;114(6):1315-21. X-4e, X-5. [pmid: 19935035].
4313 Pevzner L, Rayburn WF, Rumney P, et al. Factors predicting successful labor induction with dinoprostone and misoprostol vaginal inserts. Obstet Gynecol. Aug. 2009;114(2 Pt 1):261-7. X-4d, X-4e. [pmid: 19622986].
4314 Pezzlo MT, Hesser JW, Morgan T, et al. Improved laboratory efficiency and diagnostic accuracy with new double-lumen-protected swab for for endometrial specimens. J Clin Microbiol. Jan. 1979;9(1):56-9. X-1. [pmid: 372215].
4315 Phadungkiatwattana P, Rujiwetpongstorn J, Tansathit T, et al. Pregnancy outcomes of Southeast Asian immigrant pregnant women compared with Thai pregnant women in Rajavithi Hospital. J Med Assoc Thai. Feb. 2011;94(2):147-51. X-1. [pmid: 21534359].
4316 Pharaon S. Lower genito-urinary fistulae. Saudi J Kidney Dis Transpl. Nov. 2007;18(4):643-7. X-1. [pmid: 17951960].
4317 Phatak MS, Kurhade GA. A longitudinal study of antenatal changes in lung function tests and importance of postpartum exercises in their recovery. Indian J Physiol Pharmacol. Jul. 2003;47(3):352-6. X-1. [pmid: 14723324].
4318 Phelan JP. The maternal abdominal wall: a fortress against fetal health care?. South Calif Law Rev. Nov. 1991;65(1):461-90. X-1. [pmid: 11645842].
4319 Phelan JP, Korst LM, Settles DK. Uterine activity patterns in uterine rupture: a case-control study. Obstet Gynecol. Sep. 1998;92(3):394-7. X-1. [pmid: 9721777].
4320 Phelan JP, Pruyn SC. Prophylactic antibiotics in cesarean section: a double-blind study of cefazolin. Am J Obstet Gynecol. Mar. 1. 1979;133(5):474-8. X-9. [pmid: 375732].
4321 Philipp E. Guanfacine in the treatment of hypertension due to pre-eclamptic toxaemia in thirty women. Br J Clin Pharmacol. Suppl 1. 1980;10:137S-140S. X-1. [pmid: 6994768].
4322 Philipson EH, Kalhan SC, Riha MM, et al. Effects of maternal glucose infusion on fetal acid-base status in human pregnancy. Am J Obstet Gynecol. Oct. 1987;157(4 Pt 1):866-73. X-9. [pmid: 3314516].
4323 Philipson EH, Kalhan SC, Rosen MG, et al. Gestational diabetes mellitus. Is further improvement necessary?. Diabetes. Jun. Suppl 2. 1985;34:55-60. X-1. [pmid: 3888743].
4324 Phillips E, McGrath P, Vaughan G. ‘I wanted desperately to have a natural birth’: mothers' insights on vaginal birth after Caesarean (VBAC). Contemp Nurse. 2009 Dec-2010 Jan. 34(1):77-84. X-1. [pmid: 20230174].
4325 Phillips N. Surgical adhesions: ‘the ties that bind’. NurseWeek (15475131). 2009;16(11):20-25. X-1.
4326 Phillips N. Surgical adhesions: ‘the ties that bind’. Nursing Spectrum -- DC, Maryland & Virginia Edition. 2009;19(11):26-31. X-1.
4327 Phillips N. Surgical adhesions: ‘the ties that bind’. Nursing Spectrum -- Florida Edition. 2009;19(10):20-25. X-1.
4328 Phillips N. Surgical adhesions: ‘the ties that bind’. Nursing Spectrum -- Greater Chicago. 2009;22(11):16-21. X-1.
4329 Phillips N. Surgical adhesions: ‘the ties that bind’. Nursing Spectrum -- New York & New Jersey Edition. 2009;21(16):24-29. X-1.
4330 Phillips N. Surgical adhesions: ‘the ties that bind’. Nursing Spectrum -- Philadelphia Tri -- State Edition. 2009;18(10):16-21. X-1.
4331 Phillips N. Surgical adhesions: ‘the ties that bind’. NurseWeek (15470571). 2009;23(12):32-37. X-1.
4332 Phillips RN, Thornton J, Gleicher N. Physician bias in cesarean sections. JAMA. Sep. 3. 1982;248(9):1082-4. X-1. [pmid: 7109201].
4333 Phillips TW Jr., Broussard DM, Sumrall WD 3rd, et al. Intraoperative oxygen administration does not reduce the incidence or severity of nausea or vomiting associated with neuraxial anesthesia for cesarean delivery. Anesth Analg. Oct. 2007;105(4):1113-7. table of contents. X-9. [pmid: 17898396].
4334 Phipps H, Roberts CL, Nassar N, et al. The management of breech pregnancies in Australia and New Zealand. Aust N Z J Obstet Gynaecol. Aug. 2003;43(4):294-7. discussion 261. X-1. [pmid: 14714714].
4335 Phipps MG, Watabe B, Clemons JL, et al. Risk factors for bladder injury during cesarean delivery. Obstet Gynecol. Jan. 2005;105(1):156-60. X-1. [pmid: 15625157].
4336 Phupong V, Suebnukarn K. Obstetric outcomes in nulliparous young adolescents. Southeast Asian J Trop Med Public Health. Jan. 2007;38(1):141-5. X-1. [pmid: 17539260].
4337 Piazze J, Padula F, Cerekja A, et al. Prognostic value of umbilical-middle cerebral artery pulsatility index ratio in fetuses with growth restriction. Int J Gynaecol Obstet. Dec. 2005;91(3):233-7. X-1. [pmid: 16214144].
4338 Piccoli GB, Attini R, Vasario E, et al. Pregnancy and chronic kidney disease: a challenge in all CKD stages. Clin J Am Soc Nephrol. May. 2010;5(5):844-55. X-1. [pmid: 20413442].
4339 Picker RH, Robertson RD, Pennington JC, et al. A safe method of amniocentesis for lecithin/sphingomyelin determination in late pregnancy using ultrasound. Obstet Gynecol. Jun. 1976;47(6):722-4. X-1. [pmid: 947089].
4340 Pickles CJ, Broughton Pipkin F, Symonds EM. A randomised placebo controlled trial of labetalol in the treatment of mild to moderate pregnancy induced hypertension. Br J Obstet Gynaecol. Dec. 1992;99(12):964-8. X. [pmid: 1477017].
4341 Pierce ET, Carr DB, Datta S. Effects of ephedrine and phenylephrine on maternal and fetal atrial natriuretic peptide levels during elective cesarean section. Acta Anaesthesiol Scand. Jan. 1994;38(1):48-51. X-9. [pmid: 8140873].
4342 Piggott SE, Bogod DG, Rosen M, et al. Isoflurane with either 100% oxygen or 50% nitrous oxide in oxygen for caesarean section. Br J Anaesth. Sep. 1990;65(3):325-9. X-9. [pmid: 2121203].
4343 Pillar N, Levy A, Holcberg G, et al. Pregnancy and perinatal outcome in women with hyperthyroidism. Int J Gynaecol Obstet. Jan. 2010;108(1):61-4. X-1. [pmid: 19766207].
4344 Pitt C, Sanchez-Ramos L, Kaunitz AM. Adjunctive intravaginal metronidazole for the prevention of postcesarean endometritis: a randomized controlled trial. Obstet Gynecol. Nov. 2001;98(5 Pt 1):745-50. X-9. [pmid: 11704163].
4345 Pittard WB 3rd, Miller K, Sorensen RU. Normal lymphocyte responses to mitogens in term and premature neonates following normal and abnormal intrauterine growth. Clin Immunol Immunopathol. Feb. 1984;30(2):178-87. X-1. [pmid: 6692600].
4346 Pittard WB 3rd, Miller KM, Sorensen RU. Perinatal influences on in vitro B lymphocyte differentiation in human neonates. Pediatr Res. Jul. 1985;19(7):655-8. X-1. [pmid: 3875073].
4347 Place J. Two views of the same picture. AWHONN Lifelines. Oct-Nov. 2005;9(5):432. 431. X-1. [pmid: 16359085].
4348 Plante LA. Public health implications of cesarean on demand. Obstet Gynecol Surv. Dec. 2006;61(12):807-15. X-1, X-2. [pmid: 17107630].
4349 Plehwe WE, Shearman RP, Turtle JR. Management of pregnancy complicated by diabetes: experience with 232 patients in a 4-year period. Aust N Z J Obstet Gynaecol. Aug. 1984;24(3):167-73. X-1. [pmid: 6393944].
4350 Pliszczynska-Brennenstuhl M, Golabek W, Golabek E. Impedance audiometry in newborns of abnormal deliveries. Ann Univ Mariae Curie Sklodowska Med. 1995;50:55-8. X-4e. [pmid: 9263488].
4351 Plouin PF, Breart G, Llado J, et al. A randomized comparison of early with conservative use of antihypertensive drugs in the management of pregnancy-induced hypertension. Br J Obstet Gynaecol. Feb. 1990;97(2):134-41. X-4e. [pmid: 2180474].
4352 Plunkett BA, Grobman WA. Routine hepatitis C virus screening in pregnancy: a cost-effectiveness analysis. Am J Obstet Gynecol. Apr. 2005;192(4):1153-61. X-1. [pmid: 15846195].
4353 Plunkett BA, Lin A, Wong CA, et al. Management of the second stage of labor in nulliparas with continuous epidural analgesia. Obstet Gynecol. Jul. 2003;102(1):109-14. X-5. [pmid: 12850615].
4354 Pohl JE, Thurston H, Davis D, et al. Successful use of oral diazoxide in the treatment of severe toxaemia of pregnancy. Br Med J. Jun. 3. 1972;2(5813):568-70. X-1. [pmid: 5032785].
4355 Poindexter YM, Sangi-Haghpeykar H, Poindexter AN 3rd, et al. Previous cesarean section. A contraindication to vaginal hysterectomy?. J Reprod Med. Sep. 2001;46(9):840-4. X-1. [pmid: 11584488].
4356 Polishuk WZ, Anteby SO, Weinstein D. Puerperal endometritis and intrauterine adhesions. Int Surg. Aug. 1975;60(8):418-20. X-9. [pmid: 1158622].
4357 Polk BF, Krache M, Phillippe M, et al. Randomized clinical trial of perioperative cefoxitin in preventing maternal infection after primary cesarean section. Am J Obstet Gynecol. Apr. 15. 1982;142(8):983-7. X-9. [pmid: 7041652].
4358 Pollard JK, Mitchell MD. Effects of gestational age on prostaglandin production and its regulation in human myometrial cells. J Matern Fetal Med. Mar-Apr. 1996;5(2):93-8. X-1, X-9. [pmid: 8796776].
4359 Pollard JK, Mitchell MD. Intrauterine infection and the effects of inflammatory mediators on prostaglandin production by myometrial cells from pregnant women. Am J Obstet Gynecol. Feb. 1996;174(2):682-6. X-1. [pmid: 8623807].
4360 Pollnow DM, Broekhuizen FF. Randomized, double-blind trial of prostaglandin E2 intravaginal gel versus low-dose oxytocin for cervical ripening before induction of labor. Am J Obstet Gynecol. Jun. 1996;174(6):1910-3. discussion 1913-6. X-4d, X-5. [pmid: 8678158].
4361 Poma PA. Effect of departmental policies on cesarean delivery rates: a community hospital experience. Obstet Gynecol. Jun. 1998;91(6):1013-8. [pmid: 9611015].
4362 Poma PA. Effects of obstetrician characteristics on cesarean delivery rates. A community hospital experience. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1364-72. X-1. [pmid: 10368473].
4363 Pongraweewan O, Santawata U, Weerasarn L, et al. Epidural nalbuphine for post cesarean epidural morphine induced pruritus. J Med Assoc Thai. Jun. 2009;92(6):782-6. X-9. [pmid: 19530584].
4364 Pongthai S. Labour and delivery of obese parturients. J Med Assoc Thai. Feb. Suppl 1. 1990;73:52-6. X-1. [pmid: 2351914].
4365 Ponte J, Collett BJ, Walmsley A. Anaesthetic temperature and shivering in epidural anaesthesia. Acta Anaesthesiol Scand. Oct. 1986;30(7):584-7. X-9. [pmid: 3811803].
4366 Poon YY, Chen KP, Wong SY, et al. Combined epidural lidocaine-fentanyl-epinephrine for cesarean section. Ma Zui Xue Za Zhi. Jun. 1989;27(2):143-8. X-9. [pmid: 2796623].
4367 Poonam Banerjee B, Singh SN, et al. The Misgav Ladach method: a step forward in the operative technique of caesarean section. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2006;4(2):198-202. X-9. [pmid: 18603898].
4368 Popkin DR, Martinez LA, Carswell GA. Metronidazole in the prophylaxis of anaerobic infections in gynecologic surgery. Surgery. Jan. 1983;93(1 Pt 2):180-4. X-9. [pmid: 6849204].
4369 Popovic J, Grujic Z. Influence of pregnancy on one-compartmental bio-metric blood loss calculations after cesarean section and gynaecological surgery. Eur J Drug Metab Pharmacokinet. Jan-Mar. 2008;33(1):53-9. X-1. [pmid: 18543585].
4370 Popovic J, Grujic Z, Sabo A. Influence of pregnancy on ceftriaxone, cefazolin and gentamicin pharmacokinetics in caesarean vs. non-pregnant sectioned women. J Clin Pharm Ther. Dec. 2007;32(6):595-602. X-1. [pmid: 18021337].
4371 Porreco RP. High cesarean section rate: a new perspective. Obstet Gynecol. Mar. 1985;65(3):307-11. X-5. [pmid: 4038791].
4372 Porreco RP. Meeting the challenge of the rising cesarean birth rate. Obstet Gynecol. Jan. 1990;75(1):133-6. [pmid: 2296410].
4373 Porreco RP, Boehm FH, Dildy GA, et al. Dystocia in nulliparous patients monitored with fetal pulse oximetry. Am J Obstet Gynecol. Jan. 2004;190(1):113-7. X-1. [pmid: 14749645].
4374 Porreco RP, Schoolcraft CL, Schoolcraft WB. Pregnancy outcome following donor embryo replacement. J Matern Fetal Med. Jul-Aug. 1997;6(4):237-40. X-1. [pmid: 9260123].
4375 Portelinha A, Belo L, Cerdeira AS, et al. Lipid levels including oxidized LDL in women with history of preeclampsia. Hypertens Pregnancy. Jan. 2010;29(1):93-100. X-1. [pmid: 20132024].
4376 Porter M, Bhattacharya S, van Teijlingen E. Unfulfilled expectations: how circumstances impinge on women's reproductive choices. Soc Sci Med. Apr. 2006;62(7):1757-67. X-1. [pmid: 16191460].
4377 Potter JE, Berquo E, Perpetuo IH, et al. Unwanted caesarean sections among public and private patients in Brazil: prospective study. BMJ. Nov. 17. 2001;323(7322):1155-8. X-1. [pmid: 11711406].
4378 Potter JE, Perpetuo IH, Berquo E, et al. Frustrated demand for postpartum female sterilization in Brazil. Contraception. May. 2003;67(5):385-90. X-1. [pmid: 12742562].
4379 Pouta AM, Karinen J, Vuolteenaho OJ, et al. Effect of intravenous fluid preload on vasoactive peptide secretion during Caesarean section under spinal anaesthesia. Anaesthesia. Feb. 1996;51(2):128-32. X-9. [pmid: 8779366].
4380 Powell-Jackson T, Neupane BD, Tiwari S, et al. The impact of Nepal's national incentive programme to promote safe delivery in the district of Makwanpur. Adv Health Econ Health Serv Res. 2009;21:221-49. X-1. [pmid: 19791705].
4381 Power ML, Cogswell ME, Schulkin J. US obstetrician-gynaecologist's prevention and management of obesity in pregnancy. J Obstet Gynaecol. Jul. 2009;29(5):373-7. X-1. [pmid: 19603311].
4382 Prabhu M, Wang LF, Tait AR, et al. A randomized controlled study of whether the partner's presence in the operating room during neuraxial anesthesia for cesarean delivery reduces patient anxiety. Int J Obstet Anesth. Oct. 2009;18(4):362-7. X-9. [pmid: 19733054].
4383 Pradhan B. Spinal anesthesia for cesarean section: comparison of 5.0% lignocaine and 0.5% bupivacaine. Nepal Med Coll J. Mar. 2010;12(1):30-3. X-9. [pmid: 20677606].
4384 Prager M, Eneroth-Grimfors E, Edlund M, et al. A randomised controlled trial of intravaginal dinoprostone, intravaginal misoprostol and transcervical balloon catheter for labour induction. BJOG. Oct. 2008;115(11):1443-50. X-4d. [pmid: 18715244].
4385 Prakash S, Joshi N, Gogia AR, et al. Analgesic efficacy of two doses of intrathecal midazolam with bupivacaine in patients undergoing cesarean delivery. Reg Anesth Pain Med. May-Jun. 2006;31(3):221-6. X-9. [pmid: 16701187].
4386 Prakash S, Pramanik V, Chellani H, et al. Maternal and neonatal effects of bolus administration of ephedrine and phenylephrine during spinal anaesthesia for caesarean delivery: a randomised study. Int J Obstet Anesth. Jan. 2010;19(1):24-30. X-9. [pmid: 19665364].
4387 Prasad RN, Adaikan PG, Arulkumaran S, et al. Preinduction cervical priming with PGE2 vaginal film in primigravidae--a randomised, double blind, placebo controlled study. Prostaglandins Leukot Essent Fatty Acids. Jun. 1989;36(3):185-8. X-4d, X-5. [pmid: 2780762].
4388 Prather WR, Toren A, Meiron M, et al. The role of placental-derived adherent stromal cell (PLX-PAD) in the treatment of critical limb ischemia. Cytotherapy. 2009;11(4):427-34. X-1. [pmid: 19526389].
4389 Pratt R. Perinatal HIV infection in 1999: effective preventative strategies. Journal of Neonatal Nursing. 1999;5(2):37-41. X-1, X-2.
4390 Pratt RJ, Pellowe CM. Preventing perinatal and infant HIV infection. Infant. 2006;2(3):116-119. X-1, X-2.
4391 Pressman EK, Blakemore KJ. A prospective randomized trial of two solutions for intrapartum amnioinfusion: effects on fetal electrolytes, osmolality, and acid-base status. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):945-9. X-4e, X-5. [pmid: 8885752].
4392 Pressman EK, Tucker JA Jr., Anderson NC Jr., et al. Morphologic and electrophysiologic characterization of isolated pregnant human myometrial cells. Am J Obstet Gynecol. Nov. 1988;159(5):1273-9. X-9. [pmid: 3189460].
4393 Preston PG, Rosen MA, Hughes SC, et al. Epidural anesthesia with fentanyl and lidocaine for cesarean section: maternal effects and neonatal outcome. Anesthesiology. Jun. 1988;68(6):938-43. X-9. [pmid: 3288008].
4394 Price L. A mother's intuition. Pract Midwife. Dec. 2010;13(11):28-31. X-1, X-2. [pmid: 21218707].
4395 Price MR, Broomberg J. The impact of the fee-for-service reimbursement system on the utilisation of health services. Part III. A comparison of caesarean section rates in white nulliparous women in the private and public sectors. S Afr Med J. Aug. 4. 1990;78(3):136-8. X-1. [pmid: 2377944].
4396 Prins RP, Bolton RN, Mark C 3rd, et al. Cervical ripening with intravaginal prostaglandin E2 gel. Obstet Gynecol. Apr. 1983;61(4):459-62. X-4d, X-4e, X-5. [pmid: 6572335].
4397 Procianoy RS, Giacomini CB, Oliveira ML. Fetal and neonatal cortical adrenal function in birth asphyxia. Acta Paediatr Scand. Sep. 1988;77(5):671-4. X-1. [pmid: 2974231].
4398 Procianoy RS, Silveira RC, Mussi-Pinhata MM, et al. Sepsis and neutropenia in very low birth weight infants delivered of mothers with preeclampsia. J Pediatr. Sep. 2010;157(3):434-8. 438 e1. X-1. [pmid: 20400101].
4399 Pron G, Mocarski E, Bennett J, et al. Pregnancy after uterine artery embolization for leiomyomata: the Ontario multicenter trial. Obstet Gynecol. Jan. 2005;105(1):67-76. X-1. [pmid: 15625144].
4400 Protonotariou E, Malamitsi-Puchner A, Rizos D, et al. Alterations in Thl/Th2 cytokine concentrations in early neonatal life. J Matern Fetal Neonatal Med. Dec. 2003;14(6):407-10. X-1. [pmid: 15061321].
4401 Prysak M, Castronova FC. Elective induction versus spontaneous labor: a case-control analysis of safety and efficacy. Obstet Gynecol. Jul. 1998;92(1):47-52. X-1. [pmid: 9649091].
4402 Prytherch H, Massawe S, Kuelker R, et al. The unmet need for emergency obstetric care in Tanga Region, Tanzania. BMC Pregnancy Childbirth. 2007;7:16. X-1. [pmid: 17683590].
4403 Puchalski SA, Morison DH. Onset of subarachnoid bupivacaine in caesarean section. Can J Anaesth. May. 1990;37(4 Pt 2):S35. X-4b. [pmid: 2193747].
4404 Puertas A, Paz Carrillo M, Molto L, et al. Meconium-stained amniotic fluid in labor: a randomized trial of prophylactic amniofusion. Eur J Obstet Gynecol Reprod Biol. Nov. 2001;99(1):33-7. X-4e. [pmid: 11604183].
4405 Putre L. Patient care. Rise in C-sections tax hospitals' resources. Hosp Health Netw. Apr. 2008;82(4):12. X-1, X-2, X-3, X-4e, X-5.
4406 Qian XW, Chen XZ, Li DB. Low-dose ropivacaine-sufentanil spinal anaesthesia for caesarean delivery: a randomised trial. Int J Obstet Anesth. Oct. 2008;17(4):309-14. X-9. [pmid: 18617385].
4407 Qidwai GI, Caughey AB, Jacoby AF. Obstetric outcomes in women with sonographically identified uterine leiomyomata. Obstet Gynecol. Feb. 2006;107(2 Pt 1):376-82. X-1. [pmid: 16449127].
4408 Qiu H, Paneth N, Lorenz JM, et al. Labor and delivery factors in brain damage, disabling cerebral palsy, and neonatal death in low-birth-weight infants. Am J Obstet Gynecol. Oct. 2003;189(4):1143-9. X-1. [pmid: 14586368].
4409 Quayyum Z, Nadjib M, Ensor T, et al. Expenditure on obstetric care and the protective effect of insurance on the poor: lessons from two Indonesian districts. Health Policy Plan. May. 2010;25(3):237-47. X-1. [pmid: 20007133].
4410 Qublan HS, Merhej A, Dabbas MA, et al. Spinal versus general anesthesia for elective cesarean delivery: a prospective comparative study. Clin Exp Obstet Gynecol. 2001;28(4):246-8. X-9. [pmid: 11838750].
4411 Quenby S, Mountfield S, Cartwright JE, et al. Antiphospholipid antibodies prevent extravillous trophoblast differentiation. Fertil Steril. Mar. 2005;83(3):691-8. X-1, X-9. [pmid: 15749499].
4412 Quilligan EJ. Vaginal birth after Cesarean section: 270 degrees. J Obstet Gynaecol Res. Aug. 2001;27(4):169-73. X-1, X-2, X-3, X-4b, X-5. [pmid: 11721726].
4413 Quinlivan JA, Petersen RW, Nichols CN. Patient preference the leading indication for elective Caesarean section in public patients--results of a 2-year prospective audit in a teaching hospital. Aust N Z J Obstet Gynaecol. May. 1999;39(2):207-14. X-1. [pmid: 10755782].
4414 Quirk JG Jr., Raker RK, Petrie RH, et al. The role of glucocorticoids, unstressful labor, and atraumatic delivery in the prevention of respiratory distress syndrome. Am J Obstet Gynecol. Aug. 1. 1979;134(7):768-71. X-1, X-3, X-4e, X-5. [pmid: 463977].
4415 Qureshi B, Inafuku K, Oshima K, et al. Ultrasonographic evaluation of lower uterine segment to predict the integrity and quality of cesarean scar during pregnancy: a prospective study. Tohoku J Exp Med. Sep. 1997;183(1):55-65. X-1, X-4b, X-4e. [pmid: 9453117].
4416 Qvist N, Storm K. Cimethidine pre-anesthetic. A prophylactic method against Mendelson's syndrome in cesarean section. Acta Obstet Gynecol Scand. 1983;62(2):157-9. X-9. [pmid: 6346782].
4417 Qvist N, Storm K, Holmskov A. Cimetidine as pre-anesthetic agent for cesarean section: perinatal effects on the infant, the placental transfer of cimetidine and its elimination in the infants. J Perinat Med. 1985;13(4):179-83. X-9. [pmid: 4057034].
4418 Raatikainen K, Heiskanen N, Heinonen S. Transition from overweight to obesity worsens pregnancy outcome in a BMI-dependent manner. Obesity (Silver Spring). Jan. 2006;14(1):165-71. X-1. [pmid: 16493135].
4419 Rabe H, Wacker A, Hulskamp G, et al. A randomised controlled trial of delayed cord clamping in very low birth weight preterm infants. Eur J Pediatr. Oct. 2000;159(10):775-7. X-3, X-4e. [pmid: 11039135].
4420 Rabinovici J, Barkai G, Reichman B, et al. Randomized management of the second nonvertex twin: vaginal delivery or cesarean section. Am J Obstet Gynecol. Jan. 1987;156(1):52-6. X-3, X-4e, X-5. [pmid: 3799768].
4421 Rabl M, Ahner R, Bitschnau M, et al. Acupuncture for cervical ripening and induction of labor at term--a randomized controlled trial. Wien Klin Wochenschr. Dec. 17. 2001;113(23-24):942-6. X-4d, X-5. [pmid: 11802511].
4422 Rabl M, Joura EA, Yucel Y, et al. A randomized trial of vaginal prostaglandin E2 for induction of labor. Insert vs. tablet. J Reprod Med. Feb. 2002;47(2):115-9. X-4d, X-5. [pmid: 11883349].
4423 Raby C, Helewa M, Hazlitt G, et al. Are most patients on the labour floor in active labour? A descriptive study of a Canadian obstetrical unit. J Obstet Gynaecol Can. Feb. 2005;27(2):130-6. X-1. [pmid: 15937589].
4424 Radabaugh S, Everhart A. Cesarean births: reducing incidence while improving outcomes. AWHONN Lifelines. Feb-Mar. 1999;3(1):28-34. X-1, X-2, X-3, X-4e. [pmid: 10362917].
4425 Radin TG, Harmon JS, Hanson DA. Nurses' care during labor: its effect on the cesarean birth rate of healthy, nulliparous women. Birth. Mar. 1993;20(1):14-21. X-1. [pmid: 8503962].
4426 Rafique Z, Shibli KU, Russell IF, et al. A randomised controlled trial of the closure or non-closure of peritoneum at caesarean section: effect on post-operative pain. BJOG. Jun. 2002;109(6):694-8. X-9. [pmid: 12118650].
4427 Rafla N, Farquharson R. Lupus anticoagulant in pre-eclampsia and intra-uterine growth retardation. Eur J Obstet Gynecol Reprod Biol. Dec. 13. 1991;42(3):167-70. X-1. [pmid: 1773868].
4428 Rageth JC, Juzi C, Grossenbacher H. Delivery after previous cesarean: a risk evaluation. Swiss Working Group of Obstetric and Gynecologic Institutions. Obstet Gynecol. Mar. 1999;93(3):332-7. X-1. [pmid: 10074973].
4429 Rahaman J, Narayansingh GV, Roopnarinesingh S. Fetal outcome among obese parturients. Int J Gynaecol Obstet. Mar. 1990;31(3):227-30. X-1. [pmid: 1969362].
4430 Rahimi M, Makarem J. Effects of diclofenac epolamine patch on postoperative sore throat in parturients after cesarean delivery under endotracheal general anesthesia. Acta Anaesthesiol Taiwan. Mar. 2009;47(1):17-21. X-9. [pmid: 19318295].
4431 Rahimi M, Makarem J, Goharrizi AG. Succinylcholine-induced myalgia in obstetric patients scheduled for caesarean section--diclofenac vs placebo patches. Middle East J Anesthesiol. Oct. 2009;20(3):417-22. X-9. [pmid: 19950737].
4432 Rahman K, Jenkins JG. Failed tracheal intubation in obstetrics: no more frequent but still managed badly. Anaesthesia. Feb. 2005;60(2):168-71. X-1. [pmid: 15644015].
4433 Rainaldi MP, Tazzari PL, Scagliarini G, et al. Blood salvage during caesarean section. Br J Anaesth. Feb. 1998;80(2):195-8. X-9. [pmid: 9602584].
4434 Raio L, Ghezzi F, Di Naro E, et al. Perinatal outcome of fetuses with a birth weight greater than 4500 g: an analysis of 3356 cases. Eur J Obstet Gynecol Reprod Biol. Aug. 15. 2003;109(2):160-5. X-1. [pmid: 12860334].
4435 Rajab KE, Issa AA, Mohammed AM, et al. Sickle cell disease and pregnancy in Bahrain. Int J Gynaecol Obstet. May. 2006;93(2):171-5. X-1. [pmid: 16563397].
4436 Rajasingam D, Seed PT, Briley AL, et al. A prospective study of pregnancy outcome and biomarkers of oxidative stress in nulliparous obese women. Am J Obstet Gynecol. Apr. 2009;200(4):395 e1-9. X-1, X-4e. [pmid: 19200933].
4437 Rajdl D, Racek J, Steinerova A, et al. Markers of oxidative stress in diabetic mothers and their infants during delivery. Physiol Res. 2005;54(4):429-36. X-1. [pmid: 15588143].
4438 Ramadani H. Cesarean section intraoperative blood loss and mode of placental separation. Int J Gynaecol Obstet. Nov. 2004;87(2):114-8. X-9. [pmid: 15491554].
4439 Raman NV, Rao CA. Magnesium sulfate as an anticonvulsant in eclampsia. Int J Gynaecol Obstet. Jun. 1995;49(3):289-98. X-1. [pmid: 9764868].
4440 Ramanathan J, Angel JJ, Bush AJ, et al. Changes in maternal middle cerebral artery blood flow velocity associated with general anesthesia in severe preeclampsia. Anesth Analg. Feb. 1999;88(2):357-61. X-1, X-9. [pmid: 9972756].
4441 Ramanathan J, Sibai BM, Mabie WC, et al. The use of labetalol for attenuation of the hypertensive response to endotracheal intubation in preeclampsia. Am J Obstet Gynecol. Sep. 1988;159(3):650-4. X-9. [pmid: 3421264].
4442 Ramanathan J, Sibai BM, Vu T, et al. Correlation between bleeding times and platelet counts in women with preeclampsia undergoing cesarean section. Anesthesiology. Aug. 1989;71(2):188-91. X-1. [pmid: 2757243].
4443 Ramanathan J, Vaddadi AK, Arheart KL. Combined spinal and epidural anesthesia with low doses of intrathecal bupivacaine in women with severe preeclampsia: a preliminary report. Reg Anesth Pain Med. Jan-Feb. 2001;26(1):46-51. X-1. [pmid: 11172511].
4444 Ramanathan S, Desai NS, Zakowski M. Systemic vascular uptake of epinephrine from the lumbar epidural space in parturients. Reg Anesth. May-Jun. 1995;20(3):199-205. X-9. [pmid: 7547655].
4445 Ramanathan S, Gandhi S, Arismendy J, et al. Oxygen transfer from mother to fetus during cesarean section under epidural anesthesia. Anesth Analg. Jul. 1982;61(7):576-81. X-9. [pmid: 7201255].
4446 Ramanathan S, Grant GJ. Vasopressor therapy for hypotension due to epidural anesthesia for cesarean section. Acta Anaesthesiol Scand. Oct. 1988;32(7):559-65. X-1, X-9. [pmid: 3188826].
4447 Ramanathan S, Khoo P, Arismendy J. Perioperative maternal and neonatal acid-base status and glucose metabolism in patients with insulin-dependent diabetes mellitus. Anesth Analg. Aug. 1991;73(2):105-11. X-1. [pmid: 1854024].
4448 Rameez MF, Goonewardene IM. Nitric oxide donor isosorbide mononitrate for pre-induction cervical ripening at 41 weeks' gestation: A randomized controlled trial. J Obstet Gynaecol Res. Aug. 2007;33(4):452-6. X-4d, X-5. [pmid: 17688611].
4449 Ramin SM, Gambling DR, Lucas MJ, et al. Randomized trial of epidural versus intravenous analgesia during labor. Obstet Gynecol. Nov. 1995;86(5):783-9. X-4e, X-5. [pmid: 7566849].
4450 Ramin SM, Gilstrap LC 3rd, Leveno KJ, et al. Acid-base significance of meconium discovered prior to labor. Am J Perinatol. Mar. 1993;10(2):143-5. X-1. [pmid: 8476478].
4451 Ramin SM, Ramin KD, Cox K, et al. Comparison of prophylactic angiotensin II versus ephedrine infusion for prevention of maternal hypotension during spinal anesthesia. Am J Obstet Gynecol. Sep. 1994;171(3):734-9. X-9. [pmid: 8092223].
4452 Ramirez-Cacho WA, Flores S, Schrader RM, et al. Effect of chronic maternal methadone therapy on intrapartum fetal heart rate patterns. J Soc Gynecol Investig. Feb. 2006;13(2):108-11. X-1.
4453 Ramos GA, Jacobson GF, Kirby RS, et al. Comparison of glyburide and insulin for the management of gestational diabetics with markedly elevated oral glucose challenge test and fasting hyperglycemia. J Perinatol. May. 2007;27(5):262-7. X-1. [pmid: 17363911].
4454 Ramsay S. UK woman wins right to refuse caesarean section. Lancet. May. 16. 1998;351(9114):1499. X-1. [pmid: 11655349].
4455 Ramsey PS, Harris DY, Ogburn PL Jr., et al. Comparative efficacy and cost of the prostaglandin analogs dinoprostone and misoprostol as labor preinduction agents. Am J Obstet Gynecol. Feb. 2003;188(2):560-5. X-4d. [pmid: 12592272].
4456 Ramsey PS, Savage K, Lincoln T, et al. Vaginal misoprostol versus concentrated oxytocin and vaginal PGE2 for second-trimester labor induction. Obstet Gynecol. Jul. 2004;104(1):138-45. X-4d. [pmid: 15229013].
4457 Ramsey PS, White AM, Guinn DA, et al. Subcutaneous tissue reapproximation, alone or in combination with drain, in obese women undergoing cesarean delivery. Obstet Gynecol. May. 2005;105(5 Pt 1):967-73. X-9. [pmid: 15863532].
4458 Randalls B, Broadway JW, Browne DA, et al. Comparison of four subarachnoid solutions in a needle-through-needle technique for elective caesarean section. Br J Anaesth. Mar. 1991;66(3):314-8. X-9. [pmid: 2015147].
4459 Ranheim T, Haugen F, Staff AC, et al. Adiponectin is reduced in gestational diabetes mellitus in normal weight women. Acta Obstet Gynecol Scand. Apr. 2004;83(4):341-7. X-1. [pmid: 15005780].
4460 Ranheim T, Staff AC, Henriksen T. VEGF mRNA is unaltered in decidual and placental tissues in preeclampsia at delivery. Acta Obstet Gynecol Scand. Feb. 2001;80(2):93-8. X-1. [pmid: 11167201].
4461 Rankhethoa NM, Moodley J, Adhikari M, et al. Perinatal outcome of babies born to black South African women with hypertension. East Afr Med J. Jul. 1998;75(7):388-91. X-1. [pmid: 9803628].
4462 Ransom SB, Studdert DM, Dombrowski MP, et al. Reduced medicolegal risk by compliance with obstetric clinical pathways: a case--control study. Obstet Gynecol. Apr. 2003;101(4):751-5. X-1. [pmid: 12681881].
4463 Ranta PO, Ala-Kokko TI, Kukkonen JE, et al. Incisional and epidural analgesia after caesarean delivery: a prospective, placebo-controlled, randomised clinical study. Int J Obstet Anesth. Jul. 2006;15(3):189-94. X-9. [pmid: 16798442].
4464 Rao A, Celik E, Poggi S, et al. Cervical length and maternal factors in expectantly managed prolonged pregnancy: prediction of onset of labor and mode of delivery. Ultrasound Obstet Gynecol. Oct. 2008;32(5):646-51. X-1. [pmid: 18816476].
4465 Rao ZA, Choudhri A, Naqvi S, et al. Walking epidural with low dose bupivacaine plus tramadol on normal labour in primipara. J Coll Physicians Surg Pak. May. 2010;20(5):295-8. X-1. [pmid: 20642918].
4466 Rasheed R, Alam AA, Younus S, et al. Oral versus vaginal misoprostol for labour induction. J Pak Med Assoc. Aug. 2007;57(8):404-7. X-4d, X-5. [pmid: 17902524].
4467 Rasheed S, Abdelmonem A, Amin M. Adolescent pregnancy in Upper Egypt. Int J Gynaecol Obstet. Jan. 2011;112(1):21-4. X-1. [pmid: 21055750].
4468 Rashid M, Rashid RS. Higher order repeat caesarean sections: how safe are five or more?. BJOG. Oct. 2004;111(10):1090-4. X-1. [pmid: 15383111].
4469 Raskas M. Can you scrub?. J Surg Educ. Mar-Apr. 2009;66(2):118-9. X-1, X-2, X-9. [pmid: 19486877].
4470 Rasmussen MJ, Firth R, Foley M, et al. The timing of delivery in diabetic pregnancy: a 10-year review. Aust N Z J Obstet Gynaecol. Nov. 1992;32(4):313-7. X-1. [pmid: 1290426].
4471 Rasmussen OB, Pedersen BL, Wilken-Jensen C, et al. Stratified rates of cesarean sections and spontaneous vaginal deliveries. Data from five labor wards in Denmark--1996. Acta Obstet Gynecol Scand. Mar. 2000;79(3):227-31. X-1. [pmid: 10716305].
4472 Rasooli S, Moslemi F, Parish M, et al. Spinal anesthesia with minidose bupivacaine-fentanyl for cesarean section in preeclamptic parturients. Saudi Med J. Mar. 2008;29(3):460-2. X-1, X-2, X-3, X-4b, X-4e. [pmid: 18327382].
4473 Rath W, Loos W, Kuhn W, et al. The importance of early laboratory screening methods for maternal and fetal outcome in cases of HELLP syndrome. Eur J Obstet Gynecol Reprod Biol. Jul-Aug. 1990;36(1-2):43-51. X-1. [pmid: 2365128].
4474 Rauniar GP, Das BP, Banerje B, et al. Current status of prophylactic use of antimicrobial agents for caesarean section in a tertiary care teaching hospital in eastern Nepal. Nepal Med Coll J. Mar. 2006;8(1):14-8. X-1. [pmid: 16827083].
4475 Rawal N, Schollin J, Wesstrom G. Epidural versus combined spinal epidural block for cesarean section. Acta Anaesthesiol Scand. Jan. 1988;32(1):61-6. X-9. [pmid: 3278500].
4476 Ray DA, Garite TJ. Prostaglandin E2 for induction of labor in patients with premature rupture of membranes at term. Am J Obstet Gynecol. Mar. 1992;166(3):836-43. X-1, X-4d, X-4e, X-5. [pmid: 1550149].
4477 Rayamajhi R, Thapa M, Pande S. The challenge of grandmultiparity in obstetric practice. Kathmandu Univ Med J (KUMJ). Jan-Mar. 2006;4(1):70-4. X-1. [pmid: 18603872].
4478 Rayburn W, Gosen R, Ramadei C, et al. Outpatient cervical ripening with prostaglandin E2 gel in uncomplicated postdate pregnancies. Am J Obstet Gynecol. Jun. 1988;158(6 Pt 1):1417-23. X-4d, X-5. [pmid: 3289398].
4479 Rayburn W, Varner M, Galask R, et al. Comparison of moxalactam and cefazolin as prophylactic antibiotics during cesarean section. Antimicrob Agents Chemother. Mar. 1985;27(3):337-9. X-9. [pmid: 3994348].
4480 Rayburn WF, Geranis BJ, Ramadei CA, et al. Patient-controlled analgesia for post-cesarean section pain. Obstet Gynecol. Jul. 1988;72(1):136-9. X-9. [pmid: 3380504].
4481 Rayburn WF, Gittens LN, Lucas MJ, et al. Weekly administration of prostaglandin E2 gel compared with expectant management in women with previous cesareans. Prepidil Gel Study Group. Obstet Gynecol. Aug. 1999;94(2):250-4. X-4b. [pmid: 10432137].
4482 Rayburn WF, Powers BL, Plasse TF, et al. Pharmacokinetics of a controlled-release misoprostol vaginal insert at term. J Soc Gynecol Investig. Feb. 2006;13(2):112-7. X-1.
4483 Rayburn WF, Smith CV, Woods MP, et al. Combined continuous and demand narcotic dosing for patient-controlled analgesia after cesarean section. Anesthesiol Rev. Sep-Oct. 1990;17(5):58-62. X-9. [pmid: 10149050].
4484 Rayburn WF, Sokkary N, Clokey DE, et al. Consequences of routine delivery at 38 weeks for A-2 gestational diabetes. J Matern Fetal Neonatal Med. Nov. 2005;18(5):333-7. X-1. [pmid: 16390794].
4485 Raynes-Greenow CH, Roberts CL, Barratt A, et al. Pregnant women's preferences and knowledge of term breech management, in an Australian setting. Midwifery. Jun. 2004;20(2):181-7. X-1. [pmid: 15177862].
4486 Raziel A, Friedler S, Strassburger D, et al. Reproductive performance of patients undergoing intracytoplasmic sperm injection with 100% implantation rate. J Assist Reprod Genet. Aug. 2000;17(7):379-84. X-1. [pmid: 11077618].
4487 Read JS, Tuomala R, Kpamegan E, et al. Mode of delivery and postpartum morbidity among HIV-infected women: the women and infants transmission study. J Acquir Immune Defic Syndr. Mar. 1. 2001;26(3):236-45. X-1. [pmid: 11242196].
4488 Rebarber A, Lonser R, Jackson S, et al. The safety of intraoperative autologous blood collection and autotransfusion during cesarean section. Am J Obstet Gynecol. Sep. 1998;179(3 Pt 1):715-20. X-1. [pmid: 9757977].
4489 Reddy BK, Pizer B, Bull PT. Neonatal serum cortisol suppression by etomidate compared with thiopentone, for elective caesarean section. Eur J Anaesthesiol. May. 1988;5(3):171-6. X-9. [pmid: 3181146].
4490 Reddy D, Murphy SJ, Kane SV, et al. Relapses of inflammatory bowel disease during pregnancy: in-hospital management and birth outcomes. Am J Gastroenterol. May. 2008;103(5):1203-9. X-1. [pmid: 18422816].
4491 Reece EA, Leguizamon G, Homko C. Stringent controls in diabetic nephropathy associated with optimization of pregnancy outcomes. J Matern Fetal Med. Jul-Aug. 1998;7(4):213-6. X-1. [pmid: 9730491].
4492 Reece EA, Moya F, Yazigi R, et al. Persistent pulmonary hypertension: assessment of perinatal risk factors. Obstet Gynecol. Nov. 1987;70(5):696-700. X-1. [pmid: 3658275].
4493 Reece SA, Reece EA. Lack of consent although informed: fetal neglect. Med Trial Tech Q. Fall. 1985;32(2):130-44. X-1, X-4e. [pmid: 11649199].
4494 Reed B. A disappearing art: vaginal breech birth. Pract Midwife. Oct. 2003;6(9):16-8. X-1. [pmid: 14618884].
4495 Reed SD, Vollan TA, Svec MA. Pregnancy outcomes in women with rheumatoid arthritis in Washington State. Matern Child Health J. Jul. 2006;10(4):361-6. X-1. [pmid: 16649008].
4496 Rees KM, Shaw AR, Bennert K, et al. Healthcare professionals' views on two computer-based decision aids for women choosing mode of delivery after previous caesarean section: a qualitative study. BJOG. Jun. 2009;116(7):906-14. X-1. [pmid: 19522794].
4497 Rees SG, Thurlow JA, Gardner IC, et al. Maternal cardiovascular consequences of positioning after spinal anaesthesia for Caesarean section: left 15 degree table tilt vs. left lateral. Anaesthesia. Jan. 2002;57(1):15-20. X-9. [pmid: 11843736].
4498 Refuerzo JS, Momirova V, Peaceman AM, et al. Neonatal outcomes in twin pregnancies delivered moderately preterm, late preterm, and term. Am J Perinatol. Aug. 2010;27(7):537-42. X-1, X-4e. [pmid: 20175042].
4499 Regaert P, Noorduin H. General anesthesia with etomidate, alfentanil and droperidol for caesarean section. Acta Anaesthesiol Belg. Sep. 1984;35(3):193-200. X-1. [pmid: 6441435].
4500 Regan KJ, O'Sullivan G. The extension of epidural blockade for emergency Caesarean section: a survey of current UK practice. Anaesthesia. Feb. 2008;63(2):136-42. X-1. [pmid: 18211443].
4501 Reggiori A, Ravera M, Cocozza E, et al. Randomized study of antibiotic prophylaxis for general and gynaecological surgery from a single centre in rural Africa. Br J Surg. Mar. 1996;83(3):356-9. X-9. [pmid: 8665191].
4502 Regnier S, Fermand V, Levy P, et al. A case-control study of polymorphic eruption of pregnancy. J Am Acad Dermatol. Jan. 2008;58(1):63-7. X-1. [pmid: 17884242].
4503 Rehu M, Jahkola M. Prophylactic antibiotics in Caesarean section: effect of a short preoperative course of benzyl penicillin or clindamycin plus gentamicin on postoperative infectious morbidity. Ann Clin Res. Apr. 1980;12(2):45-8. X-9. [pmid: 7447362].
4504 Reichman O, Gdansky E, Latinsky B, et al. Digital rotation from occipito-posterior to occipito-anterior decreases the need for cesarean section. Eur J Obstet Gynecol Reprod Biol. Jan. 2008;136(1):25-8. X-1. [pmid: 17368909].
4505 Reid AJ, Carroll JC, Ruderman J, et al. Differences in intrapartum obstetric care provided to women at low risk by family physicians and obstetricians. CMAJ. Mar. 15. 1989;140(6):625-33. X-1. [pmid: 2920336].
4506 Reid GJ, Helewa ME. A trial of pulsatile versus continuous oxytocin administration for the induction of labor. J Perinatol. Sep-Oct. 1995;15(5):364-6. quiz 367-8. X-4d, X-5. [pmid: 8576747].
4507 Reid JA, Thorburn J. Extradural bupivacaine or lignocaine anaesthesia for elective caesarean section: the role of maternal posture. Br J Anaesth. Aug. 1988;61(2):149-53. X-9. [pmid: 3415886].
4508 Reilly DR. Caesarean section on maternal request: how clear medical evidence fails to produce ethical consensus. J Obstet Gynaecol Can. Dec. 2009;31(12):1176-9. X-1, X-2. [pmid: 20085684].
4509 Reime B, Klein MC, Kelly A, et al. Do maternity care provider groups have different attitudes towards birth?. BJOG. Dec. 2004;111(12):1388-93. X-1. [pmid: 15663124].
4510 Reis PM, Sander CM, Pearlman MD. Abruptio placentae after auto accidents. A case-control study. J Reprod Med. Jan. 2000;45(1):6-10. X-1. [pmid: 10664940].
4511 Reisner LS. Anesthesia for cesarean section. Current Reviews for Nurse Anesthetists. 1987;10(9):66-72. X-4b.
4512 Remer M. A tale of 2 births. Midwifery Today Int Midwife. Autumn. 2009;(91):11. X-1, X-2, X-3, X-4e, X-5. [pmid: 19824250].
4513 Remez L. Offering a woman sterilization during an emergency cesarean section may sometimes be appropriate. Int Fam Plan Perspect. Mar. 2003;29(1):52. X-1, X-2, X-3, X-4b, X-4e, X-5. [pmid: 12731485].
4514 Renner RM, Eden KB, Osterweil P, et al. Informational factors influencing patient's childbirth preferences after prior cesarean. Am J Obstet Gynecol. May. 2007;196(5):e14-6. X-1. [pmid: 17466665].
4515 Resick LK, Erlen JA. Vaginal birth after cesarean: issues and implications. J Am Acad Nurse Pract. Jul-Sep. 1990;2(3):100-6. X-1, X-2. [pmid: 2400620].
4516 Reti LL, Ross A, Kloss M, et al. The management of severe preeclampsia with intravenous magnesium sulphate, hydralazine and central venous catheterization. Aust N Z J Obstet Gynaecol. May. 1987;27(2):102-5. X-1. [pmid: 3675436].
4517 Retnakaran R, Qi Y, Sermer M, et al. An abnormal screening glucose challenge test in pregnancy predicts postpartum metabolic dysfunction, even when the antepartum oral glucose tolerance test is normal. Clin Endocrinol (Oxf). Aug. 2009;71(2):208-14. X-1. [pmid: 19178531].
4518 Reubinoff BE, Samueloff A, Ben-Haim M, et al. Is the obstetric outcome of in vitro fertilized singleton gestations different from natural ones? A controlled study. Fertil Steril. Jun. 1997;67(6):1077-83. X-1. [pmid: 9176447].
4519 Revicky V, Nirmal D, Mukhopadhyay S, et al. Could a mediolateral episiotomy prevent obstetric anal sphincter injury?. Eur J Obstet Gynecol Reprod Biol. Jun. 2010;150(2):142-6. X-1. [pmid: 20359810].
4520 Rey HR, James LS, Wiele RV. Optimized search for parameters useful in the interpretation of fetal heart rate data. Med Instrum. Nov-Dec. 1979;13(6):337-43. X-1. [pmid: 522717].
4521 Reynolds F, Laishley R, Morgan B, et al. Effect of time and adrenaline on the feto-maternal distribution of bupivacaine. Br J Anaesth. May. 1989;62(5):509-14. X-9. [pmid: 2730822].
4522 Reynolds JW, Barnhart BJ, Carlson CV. Feto-placental steroid metabolism in growth retarded human fetuses. Pediatr Res. Feb. 1986;20(2):166-8. X-1. [pmid: 2935778].
4523 Reza FM, Zahra F, Esmaeel F, et al. Preemptive analgesic effect of ketamine in patients undergoing elective cesarean section. Clin J Pain. Mar-Apr. 2010;26(3):223-6. X-9. [pmid: 20173436].
4524 Reza N, Ali SM, Saeed K, et al. The impact of music on postoperative pain and anxiety following cesarean section. Middle East J Anesthesiol. Oct. 2007;19(3):573-86. X-9. [pmid: 18044285].
4525 Rhee E, Detti L, Mari G. Superior mesenteric artery flow velocity waveforms in small for gestational age fetuses. J Matern Fetal Med. May-Jun. 1998;7(3):120-3. X-1. [pmid: 9642608].
4526 Rhoden NK. The judge in the delivery room: the emergence of court-ordered cesareans. Calif Law Rev. Dec. 1986;74(6):1951-2030. X-1. [pmid: 11658950].
4527 Rhoden NK. Cesareans and Samaritans. Law Med Health Care. Fall. 1987;15(3):118-25. X-1. [pmid: 3695574].
4528 Rhoden NK. Informed consent in obstetrics: some special problems. West New Engl Law Rev. 1987;9(1):67-88. X-1.
4529 Rhodes ET, Pawlak DB, Takoudes TC, et al. Effects of a low-glycemic load diet in overweight and obese pregnant women: a pilot randomized controlled trial. Am J Clin Nutr. Dec. 2010;92(6):1306-15. X-4e , X-5. [pmid: 20962162].
4530 Ribalta J, Reyes H, Gonzalez MC, et al. S-adenosyl-L-methionine in the treatment of patients with intrahepatic cholestasis of pregnancy: a randomized, double-blind, placebo-controlled study with negative results. Hepatology. Jun. 1991;13(6):1084-9. X-4e, X-5. [pmid: 2050326].
4531 Ribatti D, Loverro G, Vacca A, et al. Expression of tenascin is related to angiogenesis in pre-eclampsia. Eur J Clin Invest. May. 1998;28(5):373-8. X-1. [pmid: 9650010].
4532 Ricart W, Lopez J, Mozas J, et al. Potential impact of American Diabetes Association 2000 criteria for diagnosis of gestational diabetes mellitus in Spain. Diabetologia. Jun. 2005;48(6):1135-41. X-1. [pmid: 15889233].
4533 Ricart W, Lopez J, Mozas J, et al. Body mass index has a greater impact on pregnancy outcomes than gestational hyperglycaemia. Diabetologia. Sep. 2005;48(9):1736-42. X-1. [pmid: 16052327].
4534 Rice JP, Kay HH, Mahony BS. The clinical significance of uterine leiomyomas in pregnancy. Am J Obstet Gynecol. May. 1989;160(5 Pt 1):1212-6. X-1. [pmid: 2658611].
4535 Rice PL, Naksook C, Watson LE. The experiences of postpartum hospital stay and returning home among Thai mothers in Australia. Midwifery. Mar. 1999;15(1):47-57. X-1. [pmid: 10373873].
4536 Richard F, Ouedraogo C, De Brouwere V. Quality cesarean delivery in Ouagadougou, Burkina Faso: a comprehensive approach. Int J Gynaecol Obstet. Dec. 2008;103(3):283-90. X-1. [pmid: 18992882].
4537 Richard F, Witter S, de Brouwere V. Innovative approaches to reducing financial barriers to obstetric care in low-income countries. Am J Public Health. Oct. 2010;100(10):1845-52. X-1, X-2. [pmid: 20724689].
4538 Richards J. Ethics series. Too choosy about choice: the responsibility of the midwife. British Journal of Midwifery. 1997;5(3):163-168. X-1, X-2.
4539 Richards LB. The perpetuation of fear and cesarean. Midwifery Today Childbirth Educ. Autumn. 1992;(23):20-1. X-1. [pmid: 1339531].
4540 Richardson MG, Collins HV, Wissler RN. Intrathecal hypobaric versus hyperbaric bupivacaine with morphine for cesarean section. Anesth Analg. Aug. 1998;87(2):336-40. X-9. [pmid: 9706927].
4541 Richman VV. Setting goals for reductions in Canadian cesarean delivery rates: benchmarking medical practice patterns. Am J Obstet Gynecol. Sep. 1999;181(3):635-7. X-1. [pmid: 10486476].
4542 Ridgeway JJ, Weyrich DL, Benedetti TJ. Fetal heart rate changes associated with uterine rupture. Obstet Gynecol. Mar. 2004;103(3):506-12. X-1. [pmid: 14990414].
4543 Ridley RT, Davis PA, Bright JH, et al. What influences a woman to choose vaginal birth after cesarean?. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2002;31(6):665-72. X-1.
4544 Rieger L, Segerer S, Bernar T, et al. Specific subsets of immune cells in human decidua differ between normal pregnancy and preeclampsia--a prospective observational study. Reprod Biol Endocrinol. 2009;7:132. X-1. [pmid: 19930648].
4545 Rietberg CC, Elferink-Stinkens PM, Visser GH. The effect of the Term Breech Trial on medical intervention behaviour and neonatal outcome in The Netherlands: an analysis of 35,453 term breech infants. BJOG. Feb. 2005;112(2):205-9. X-1. [pmid: 15663585].
4546 Riis L, Vind I, Politi P, et al. Does pregnancy change the disease course? A study in a European cohort of patients with inflammatory bowel disease. Am J Gastroenterol. Jul. 2006;101(7):1539-45. X-1. [pmid: 16863558].
4547 Rijhsinghani A, Savopoulos SE, Walters JK, et al. Ampicillin/sulbactam versus ampicillin alone for cesarean section prophylaxis: a randomized double-blind trial. Am J Perinatol. Sep. 1995;12(5):322-4. X-9. [pmid: 8540932].
4548 Rijnders M, Baston H, Schonbeck Y, et al. Perinatal factors related to negative or positive recall of birth experience in women 3 years postpartum in the Netherlands. Birth. Jun. 2008;35(2):107-16. X-1. [pmid: 18507581].
4549 Rijnders M, Herschderfer K, Prins M, et al. A retrospective study of the success, safety and effectiveness of external cephalic version without tocolysis in a specialised midwifery centre in the Netherlands. Midwifery. Mar. 2008;24(1):38-45. X-1. [pmid: 17196716].
4550 Riley ET, Cohen SE, Macario A, et al. Spinal versus epidural anesthesia for cesarean section: a comparison of time efficiency, costs, charges, and complications. Anesth Analg. Apr. 1995;80(4):709-12. X-1. [pmid: 7893022].
4551 Riley ET, Cohen SE, Rubenstein AJ, et al. Prevention of hypotension after spinal anesthesia for cesarean section: six percent hetastarch versus lactated Ringer's solution. Anesth Analg. Oct. 1995;81(4):838-42. X-9. [pmid: 7574020].
4552 Riley ET, Walker D, Hamilton CL, et al. Intrathecal sufentanil for labor analgesia does not cause a sympathectomy. Anesthesiology. Oct. 1997;87(4):874-8. X-1. [pmid: 9357890].
4553 Riley LE, Tuomala RE, Heeren T, et al. Low risk of post-cesarean section infection in insulin-requiring diabetic women. Diabetes Care. Jun. 1996;19(6):597-600. X-1, X-9. [pmid: 8725858].
4554 Riley SC, Bassett NS, Berdusco ET, et al. Changes in the abundance of mRNA for type-I 3 beta-hydroxysteroid dehydrogenase/delta 5-->delta 4 isomerase in the human placenta and fetal membranes during pregnancy and labor. Gynecol Obstet Invest. 1993;35(4):199-203. X-1. [pmid: 8330763].
4555 Rinehart BK, Terrone DA, Lagoo-Deenadayalan S, et al. Expression of the placental cytokines tumor necrosis factor alpha, interleukin 1beta, and interleukin 10 is increased in preeclampsia. Am J Obstet Gynecol. Oct. 1999;181(4):915-20. X-1. [pmid: 10521753].
4556 Rioseco AJ, Ivankovic MB, Manzur A, et al. Intrahepatic cholestasis of pregnancy: a retrospective case-control study of perinatal outcome. Am J Obstet Gynecol. Mar. 1994;170(3):890-5. X-1. [pmid: 8141222].
4557 Riskin A, Abend-Weinger M, Riskin-Mashiah S, et al. Cesarean section, gestational age, and transient tachypnea of the newborn: timing is the key. Am J Perinatol. Oct. 2005;22(7):377-82. X-1. [pmid: 16215925].
4558 Riskin A, Riskin-Mashiah S, Lusky A, et al. The relationship between delivery mode and mortality in very low birthweight singleton vertex-presenting infants. BJOG. Dec. 2004;111(12):1365-71. X-1. [pmid: 15663120].
4559 Rix P, Ladehoff P, Moller AM, et al. Cervical ripening and induction of delivery by local administration of prostaglandin E2 gel or vaginal tablets is equally effective. Acta Obstet Gynecol Scand. Jan. 1996;75(1):45-7. X-4d. [pmid: 8560996].
4560 Rizk DE, Nsanze H, Mabrouk MH, et al. Systemic antibiotic prophylaxis in elective cesarean delivery. Int J Gynaecol Obstet. Jun. 1998;61(3):245-51. X-9. [pmid: 9688485].
4561 Rizvi JH, Rasul S, Malik S, et al. Experience with screening for abnormal glucose tolerance in pregnancy: maternal and perinatal outcome. Asia Oceania J Obstet Gynaecol. Jun. 1992;18(2):99-105. X-1. [pmid: 1503544].
4562 Rizzo N, Ciardelli V, Gandolfi Colleoni G, et al. Delivery and immigration: the experience of an Italian hospital. Eur J Obstet Gynecol Reprod Biol. Oct. 15. 2004;116(2):170-2. X-1. [pmid: 15358458].
4563 Roach VJ, Rogers MS. Pregnancy outcome beyond 41 weeks gestation. Int J Gynaecol Obstet. Oct. 1997;59(1):19-24. X-4e. [pmid: 9359441].
4564 Roan S. Once a C-section always a C-section? Yes, insist many experts: amid some doctors' and health plans' concerns about risks, fewer women are delivering vaginally after a caesarean. Los Angeles Times -- Southern California Edition (Front Page). 2001:S1. X-1.
4565 Roberts AB, Pattison NS. Pregnancy in women with diabetes mellitus, twenty years experience: 1968-1987. N Z Med J. May. 9. 1990;103(889):211-3. X-1. [pmid: 2342692].
4566 Roberts CL, Ford JB, Thompson JF, et al. Population rates of haemorrhage and transfusions among obstetric patients in NSW: a short communication. Aust N Z J Obstet Gynaecol. Jun. 2009;49(3):296-8. X-1. [pmid: 19566563].
4567 Roberts CL, Taylor L, Henderson-Smart D. Trends in births at and beyond term: evidence of a change?. Br J Obstet Gynaecol. Sep. 1999;106(9):937-42. X-1. [pmid: 10492105].
4568 Roberts D, Nwosu EC, Walkinshaw SA. The fetal outcome in pregnancies with isolated reduced amniotic fluid volume in the third trimester. J Perinat Med. 1998;26(5):390-5. X-1. [pmid: 10027135].
4569 Roberts RG, Deutchman M, King VJ, et al. Changing policies on vaginal birth after cesarean: impact on access. Birth. Dec. 2007;34(4):316-22. X-1. [pmid: 18021147].
4570 Roberts SS. The diabetes advisor. Diabetes Forecast. 2002;55(6):29-32. X-4e.
4571 Roberts WE, Fulp KS, Morrison JC, et al. The impact of leiomyomas on pregnancy. Aust N Z J Obstet Gynaecol. Feb. 1999;39(1):43-7. X-1. [pmid: 10099748].
4572 Robertson JA. Procreative liberty and the control of conception, pregnancy, and childbirth. Va Law Rev. Apr. 1983;69(3):405-64. X-1. [pmid: 11651806].
4573 Robins K, Wilson R, Watkins EJ, et al. Chlorhexidine spray versus single use sachets for skin preparation before regional nerve blockade for elective caesarean section: an effectiveness, time and cost study. Int J Obstet Anesth. Jul. 2005;14(3):189-92. X-9. [pmid: 15935648].
4574 Robinson CA, Macones GA, Roth NW, et al. Does station of the fetal head at epidural placement affect the position of the fetal vertex at delivery?. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):991-4. X-1. [pmid: 8885762].
4575 Robson BA. Breast engorgement in breastfeeding mothers. PH.D. 1990:164. X-4e.
4576 Robson S, Carey A, Mishra R, et al. Elective caesarean delivery at maternal request: a preliminary study of motivations influencing women's decision-making. Aust N Z J Obstet Gynaecol. Aug. 2008;48(4):415-20. X-1. [pmid: 18837848].
4577 Robson S, Ellwood D. Should obstetricians support a ‘term cephalic trial’?. Aust N Z J Obstet Gynaecol. Oct. 2003;43(5):341-3. X-1. [pmid: 14717307].
4578 Robson S, Ramsay B, Chandler K. Registrar experience in vaginal breech delivery. How much is occurring?. Aust N Z J Obstet Gynaecol. May. 1999;39(2):215-7. X-1. [pmid: 10755783].
4579 Robson S, Thompson J, Ellwood D. Obstetric management of the next pregnancy after an unexplained stillbirth: an anonymous postal survey of Australian obstetricians. Aust N Z J Obstet Gynaecol. Aug. 2006;46(4):278-81. X-1. [pmid: 16866786].
4580 Robson SC, Boys RJ, Rodeck C, et al. Maternal and fetal haemodynamic effects of spinal and extradural anaesthesia for elective caesarean section. Br J Anaesth. Jan. 1992;68(1):54-9. X-9. [pmid: 1739568].
4581 Robson SJ, Leader LR, Bennett MJ, et al. Do women's perceptions of care at the time of unexplained stillbirth influence their wishes for management in subsequent pregnancy? An Internet-based empirical study. J Obstet Gynaecol Res. Feb. 2010;36(1):108-14. X-1. [pmid: 20178535].
4582 Robson SJ, Leader LR, Dear KB, et al. Women's expectations of management in their next pregnancy after an unexplained stillbirth: an Internet-based empirical study. Aust N Z J Obstet Gynaecol. Dec. 2009;49(6):642-6. X-1. [pmid: 20070714].
4583 Robson SJ, Tan WS, Adeyemi A, et al. Estimating the rate of cesarean section by maternal request: anonymous survey of obstetricians in Australia. Birth. Sep. 2009;36(3):208-12. X-1. [pmid: 19747267].
4584 Rocha G, Fernandes P, Rocha P, et al. Pleural effusions in the neonate. Acta Paediatr. Jul. 2006;95(7):791-8. X-1. [pmid: 16801173].
4585 Rochelson B, Pagano M, Conetta L, et al. Previous preterm cesarean delivery: identification of a new risk factor for uterine rupture in VBAC candidates. J Matern Fetal Neonatal Med. Nov. 2005;18(5):339-42. X-1. [pmid: 16390795].
4586 Rocke DA, Rout CC, Gouws E. Intravenous administration of the proton pump inhibitor omeprazole reduces the risk of acid aspiration at emergency cesarean section. Anesth Analg. Jun. 1994;78(6):1093-8. X-9. [pmid: 8198263].
4587 Rodney WM, Hardison D, Rodney-Arnold K, et al. Impact of deliveries on the office practice of family medicine. J Natl Med Assoc. Oct. 2006;98(10):1685-90. X-1. [pmid: 17052062].
4588 Rodrigues R, Nunes F, Tiago D, et al. Induction of labor with intravaginal administration of misoprostol. Int J Gynaecol Obstet. Mar. 1998;60(3):233-7. X-1, X-4d. [pmid: 9544706].
4589 Rodriguez AI, Porter KB, O'Brien WF. Blunt versus sharp expansion of the uterine incision in low-segment transverse cesarean section. Am J Obstet Gynecol. Oct. 1994;171(4):1022-5. X-9. [pmid: 7943065].
4590 Rodriguez EJ, Spann C, Jamieson D, et al. Postoperative morbidity associated with cesarean delivery among human immunodeficiency virus-seropositive women. Am J Obstet Gynecol. May. 2001;184(6):1108-11. X-1. [pmid: 11349171].
4591 Rodriguez MI, Edelman A, Wallace N, et al. Denying postpartum sterilization to women with Emergency Medicaid does not reduce hospital charges. Contraception. Sep. 2008;78(3):232-6. X-1. [pmid: 18692614].
4592 Roemer FJ, Rowland DY, Nuamah IF. Retrospective study of fetal effects of prolonged labor before cesarean delivery. Obstet Gynecol. May. 1991;77(5):653-8. X-1. [pmid: 2014074].
4593 Roes EM, Raijmakers MT, Boo TM, et al. Oral N-acetylcysteine administration does not stabilise the process of established severe preeclampsia. Eur J Obstet Gynecol Reprod Biol. Jul. 2006;127(1):61-7. X-4e. [pmid: 16243427].
4594 Roethlisberger M, Womastek I, Posch M, et al. Early postpartum hysterectomy: incidence and risk factors. Acta Obstet Gynecol Scand. Aug. 2010;89(8):1040-4. X-1. [pmid: 20602600].
4595 Roex AJ, Puyenbroek JI, MacLaren DM, et al. A randomized clinical trial of antibiotic prophylaxis in cesarean section: maternal morbidity, risk factors and bacteriological changes. Eur J Obstet Gynecol Reprod Biol. Jul. 1986;22(3):117-24. X-9. [pmid: 3732582].
4596 Roex AJ, Puyenbroek JI, van Loenen AC, et al. Single- versus three-dose cefoxitin prophylaxis in caesarean section: a randomized clinical trial. Eur J Obstet Gynecol Reprod Biol. Aug. 1987;25(4):293-8. X-9. [pmid: 3308571].
4597 Rogers FB, Rozycki GS, Osler TM, et al. A multi-institutional study of factors associated with fetal death in injured pregnant patients. Arch Surg. Nov. 1999;134(11):1274-7. X-1. [pmid: 10555646].
4598 Rogers MS, Lau TK, Wang CC, et al. Amnioinfusion for the prevention of meconium aspiration during labour. Aust N Z J Obstet Gynaecol. Nov. 1996;36(4):407-10. X-1. [pmid: 9006822].
4599 Rogers R, Gilson G, Kammerer-Doak D. Epidural analgesia and active management of labor: effects on length of labor and mode of delivery. Obstet Gynecol. Jun. 1999;93(6):995-8. X-1. [pmid: 10362169].
4600 Rogers RG, Gardner MO, Tool KJ, et al. Active management of labor: a cost analysis of a randomized controlled trial. West J Med. Apr. 2000;172(4):240-3. X-1. [pmid: 10778374].
4601 Rogers S. Fetal rights and maternal rights: is there a conflict?. Can J Women Law. 1986;1(2):456-69. X-1. [pmid: 11651100].
4602 Rojansky N, Tanos V, Reubinoff B, et al. Effect of epidural analgesia on duration and outcome of induced labor. Int J Gynaecol Obstet. Mar. 1997;56(3):237-44. X-1, X-4e. [pmid: 9127155].
4603 Roland L, Beauchemin D, Acteau G, et al. Effects of labor on placental expression of superoxide dismutases in preeclampsia. Placenta. May. 2010;31(5):392-400. X-1, X-4e, X-5. [pmid: 20226522].
4604 Roland-Zejly L, Moisan V, St-Pierre I, et al. Altered placental glutathione peroxidase mRNA expression in preeclampsia according to the presence or absence of labor. Placenta. Feb. 2011;32(2):161-7. X-1. [pmid: 21145108].
4605 Rolbin SH, Cole AF, Hew EM, et al. Prophylactic intramuscular ephedrine before epidural anaesthesia for caesarean section: efficacy and actions on the fetus and newborn. Can Anaesth Soc J. Mar. 1982;29(2):148-53. X-9. [pmid: 7066739].
4606 Rollins NC, Filteau SM, Coutsoudis A, et al. Feeding mode, intestinal permeability, and neopterin excretion: a longitudinal study in infants of HIV-infected South African women. J Acquir Immune Defic Syndr. Oct. 1. 2001;28(2):132-9. X-1. [pmid: 11588506].
4607 Roman AS, Schreher J, Mackenzie AP, et al. Omega-3 fatty acids and decidual cell prostaglandin production in response to the inflammatory cytokine IL-1beta. Am J Obstet Gynecol. Dec. 2006;195(6):1693-9. X-1. [pmid: 16792994].
4608 Roman H, Robillard PY, Hulsey TC, et al. Obstetrical and neonatal outcomes in obese women. West Indian Med J. Oct. 2007;56(5):421-6. X-1, X-3, X-4e, X-5. [pmid: 18303754].
4609 Romanini C, Valensise H, Ciotti G, et al. Tryptophan availability and fetal behavioral states. Fetal Ther. Suppl 1. 1989;4:68-72. X-1. [pmid: 2487911].
4610 Romano AM, Goer H. Research summaries for normal birth. Journal of Perinatal Education. 2007. Winter. 2007;16(1):37-40. X-1, X-2. [pmid: 18408810].
4611 Romanyuk V, Raichel L, Sergienko R, et al. Pneumonia during pregnancy: radiological characteristics, predisposing factors and pregnancy outcomes. J Matern Fetal Neonatal Med. Jan. 2011;24(1):113-7. X-1. [pmid: 20476873].
4612 Romero R, Lafreniere D, Hobbins JC, et al. A product from human decidua inhibits prostaglandin production by human amnion. Prostaglandins Leukot Med. Nov. 1987;30(1):29-36. X-1. [pmid: 3481085].
4613 Ronsmans C, Endang A, Gunawan S, et al. Evaluation of a comprehensive home-based midwifery programme in South Kalimantan, Indonesia. Trop Med Int Health. Oct. 2001;6(10):799-810. X-1. [pmid: 11679128].
4614 Ronsmans C, Etard JF, Walraven G, et al. Maternal mortality and access to obstetric services in West Africa. Trop Med Int Health. Oct. 2003;8(10):940-8. X-1. [pmid: 14516306].
4615 Ronzoni S, Marconi AM, Cetin I, et al. Umbilical amino acid uptake at increasing maternal amino acid concentrations: effect of a maternal amino acid infusate. Am J Obstet Gynecol. Aug. 1999;181(2):477-83. X-1. [pmid: 10454703].
4616 Roohan PJ, Josberger RE, Gesten FC. Risk-adjusted primary cesarean delivery rates for managed care plans in New York State, 1998. Matern Child Health J. Sep. 2001;5(3):169-77. X-1. [pmid: 11605722].
4617 Rooks JP, Weatherby NL, Ernst EK, et al. Outcomes of care in birth centers. The National Birth Center Study. N Engl J Med. Dec. 28. 1989;321(26):1804-11. X-1. [pmid: 2687692].
4618 Rooney CM, Crawford AT, Vassallo BJ, et al. Is previous cesarean section a risk for incidental cystotomy at the time of hysterectomy? A case-controlled study. Am J Obstet Gynecol. Dec. 2005;193(6):2041-4. X-1. [pmid: 16325612].
4619 Roopnarinesingh SS. The young Negro primigravida in Jamaica. J Obstet Gynaecol Br Commonw. May. 1970;77(5):424-6. X-1. [pmid: 5310621].
4620 Roost M, Johnsdotter S, Liljestrand J, et al. A qualitative study of conceptions and attitudes regarding maternal mortality among traditional birth attendants in rural Guatemala. BJOG. Dec. 2004;111(12):1372-7. X-1. [pmid: 15663121].
4621 Roper RE, Salem MG. Effects of glycopyrrolate and atropine combined with antacid on gastric acidity. Br J Anaesth. Dec. 1981;53(12):1277-80. X-1. [pmid: 6274372].
4622 Rorarius M, Suominen P, Haanpaa M, et al. Neurologic sequelae after caesarean section. Acta Anaesthesiol Scand. Jan. 2001;45(1):34-41. X-1. [pmid: 11152030].
4623 Rorarius MG, Suominen P, Baer GA, et al. Diclofenac and ketoprofen for pain treatment after elective caesarean section. Br J Anaesth. Mar. 1993;70(3):293-7. X-9. [pmid: 8471372].
4624 Rorke MJ, Davey DA, Du Toit HJ. Foetal oxygenation during caesarean section. Anaesthesia. Oct. 1968;23(4):585-96. X-4b. [pmid: 5676669].
4625 Rosaeg OP, Lindsay MP. Epidural opioid analgesia after caesarean section: a comparison of patient-controlled analgesia with meperidine and single bolus injection of morphine. Can J Anaesth. Nov. 1994;41(11):1063-8. X-4e. [pmid: 7828253].
4626 Rosaeg OP, Lui AC, Cicutti NJ, et al. Peri-operative multimodal pain therapy for caesarean section: analgesia and fitness for discharge. Can J Anaesth. Aug. 1997;44(8):803-9. X-9. [pmid: 9260006].
4627 Rose GL, Chapman MG. Aetiological factors in placenta praevia--a case controlled study. Br J Obstet Gynaecol. Jun. 1986;93(6):586-8. X-1. [pmid: 3730327].
4628 Rosen DJ, Michaeli G, Markov S, et al. Fetal surveillance. Should it begin at 40 weeks' gestation in a low-risk population?. J Reprod Med. Feb. 1995;40(2):135-9. X-4e. [pmid: 7738924].
4629 Rosen MA, Hughes SC, Shnider SM, et al. Epidural morphine for the relief of postoperative pain after cesarean delivery. Anesth Analg. Jul. 1983;62(7):666-72. X-9. [pmid: 6859570].
4630 Rosen MG, Chik L. The association between cesarean birth and outcome in vertex presentation: relative importance of birth weight, Dubowitz scores, and delivery route. Am J Obstet Gynecol. Nov. 15. 1984;150(6):775-9. X-1. [pmid: 6496598].
4631 Rosen MG, Debanne SM, Thompson K, et al. Abnormal labor and infant brain damage. Obstet Gynecol. Dec. 1992;80(6):961-5. X-1. [pmid: 1280353].
4632 Rosenberg TJ, Garbers S, Lipkind H, et al. Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. Sep. 2005;95(9):1545-51. X-1. [pmid: 16118366].
4633 Rosenblatt RA, Dobie SA, Hart LG, et al. Interspecialty differences in the obstetric care of low-risk women. Am J Public Health. Mar. 1997;87(3):344-51. X-1. [pmid: 9096532].
4634 Rosenthal TC, Ferrara E, Hesler E. Providing birthing services in rural health networks: coping with change in New York State. J Rural Health. Spring. 1996;12(2):137-45. X-1. [pmid: 10159192].
4635 Roset E, Boulvain M, Irion O. Nonclosure of the peritoneum during caesarean section: long-term follow-up of a randomised controlled trial. Eur J Obstet Gynecol Reprod Biol. May. 1. 2003;108(1):40-4. X-1. [pmid: 12694968].
4636 Roshan DF, Petrikovsky B, Sichinava L, et al. Soft forceps. Int J Gynaecol Obstet. Mar. 2005;88(3):249-52. X-1. [pmid: 15733876].
4637 Roshanfekr D, Blakemore KJ, Lee J, et al. Station at onset of active labor in nulliparous patients and risk of cesarean delivery. Obstet Gynecol. Mar. 1999;93(3):329-31. X-1. [pmid: 10074972].
4638 Ross JA, Tunstall ME, Campbell DM, et al. The use of 0.25% isoflurane premixed in 50% nitrous oxide and oxygen for pain relief in labour. Anaesthesia. Dec. 1999;54(12):1166-72. X-1, X-4e, X-5. [pmid: 10594414].
4639 Ross MG, Devoe LD, Rosen KG. ST-segment analysis of the fetal electrocardiogram improves fetal heart rate tracing interpretation and clinical decision making. J Matern Fetal Neonatal Med. Mar. 2004;15(3):181-5. X-1. [pmid: 15280144].
4640 Ross SM, Windsor IM, Robins-Browne RM, et al. Microbiological studies during the perinatal period. An attempt to correlate selected bacterial and viral infections with intra-uterine deaths and preterm labour. S Afr Med J. Oct. 20. 1984;66(16):598-603. X-4e. [pmid: 6495099].
4641 Ross VH, Moore CH, Pan PH, et al. Reduced duration of intrathecal sufentanil analgesia in laboring cocaine users. Anesth Analg. Nov. 2003;97(5):1504-8. X-1, X-4e. [pmid: 14570675].
4642 Ross VH, Pan PH, Owen MD, et al. Neostigmine decreases bupivacaine use by patient-controlled epidural analgesia during labor: a randomized controlled study. Anesth Analg. Aug. 2009;109(2):524-31. X-3, X-4b, X-4e, X-5. [pmid: 19377050].
4643 Rosser J. Continuous electronic fetal heart monitoring during labour. Practising Midwife. 1998;1(7/8):60-61. X-1, X-2, X-3, X-4, X-5. [pmid: 10392156].
4644 Rossi E, Costa M. Fish oil derivatives as a prophylaxis of recurrent miscarriage associated with antiphospholipid antibodies (APL): a pilot study. Lupus. Oct. 1993;2(5):319-23. X-1. [pmid: 8305926].
4645 Rossouw HJ, Howarth G, Odendaal HJ. Ketanserin and hydralazine in hypertension in pregnancy--a randomised double-blind trial. S Afr Med J. Jun. 1995;85(6):525-8. X-4e, X-5. [pmid: 7652635].
4646 Roth RM, Gleckman RA, Gantz NM, et al. Antibiotic irrigations. A plea for controlled clinical trials. Pharmacotherapy. Jul-Aug. 1985;5(4):222-7. X-1, X-2. [pmid: 3898036].
4647 Rothbard MJ, Mayer W, Wystepek A, et al. Prophylactic antibiotics in cesarean section. Obstet Gynecol. Apr. 1975;45(4):421-4. X-9. [pmid: 164642].
4648 Rothman BK. The active management of physicians. Birth. Sep. 1993;20(3):158-9. X-1, X-2, X-3. [pmid: 8240626].
4649 Rotmensch S, Vishne TH, Celentano C, et al. Maternal infectious morbidity following multiple courses of betamethasone. J Infect. Jul. 1999;39(1):49-54. X-1, X-3, X-4e. [pmid: 10468129].
4650 Rouben D, Arias F. A randomized trial of extra-amniotic saline infusion plus intracervical Foley catheter balloon versus prostaglandin E2 vaginal gel for ripening the cervix and inducing labor in patients with unfavorable cervices. Obstet Gynecol. Aug. 1993;82(2):290-4. X-4d, X-5. [pmid: 8336880].
4651 Rouhe H, Salmela-Aro K, Halmesmaki E, et al. Fear of childbirth according to parity, gestational age, and obstetric history. BJOG. Jan. 2009;116(1):67-73. X-1. [pmid: 19055652].
4652 Roulson CJ, Bennett J, Shaw M, et al. Effect of extradural diamorphine on analgesia after caesarean section under subarachnoid block. Br J Anaesth. Dec. 1993;71(6):810-3. X-9. [pmid: 8280544].
4653 Roumen FJ, Luyben AG. Safety of term vaginal breech delivery. Eur J Obstet Gynecol Reprod Biol. Jul. 25. 1991;40(3):171-7. X-1. [pmid: 1879592].
4654 Rouse DJ, Hauth JC, Andrews WW, et al. Chlorhexidine vaginal irrigation for the prevention of peripartal infection: a placebo-controlled randomized clinical trial. Am J Obstet Gynecol. Mar. 1997;176(3):617-22. X-4b, X-4e, X-5. [pmid: 9077616].
4655 Rouse DJ, Landon M, Leveno KJ, et al. The Maternal-Fetal Medicine Units cesarean registry: chorioamnionitis at term and its duration-relationship to outcomes. Am J Obstet Gynecol. Jul. 2004;191(1):211-6. X-1. [pmid: 15295368].
4656 Rouse DJ, Leindecker S, Landon M, et al. The MFMU Cesarean Registry: uterine atony after primary cesarean delivery. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1056-60. X-1. [pmid: 16157111].
4657 Rouse DJ, MacPherson C, Landon M, et al. Blood transfusion and cesarean delivery. Obstet Gynecol. Oct. 2006;108(4):891-7. X-1. [pmid: 17012451].
4658 Rouse DJ, McCullough C, Wren AL, et al. Active-phase labor arrest: a randomized trial of chorioamnion management. Obstet Gynecol. Jun. 1994;83(6):937-40. X-5. [pmid: 8190435].
4659 Rouse DJ, Owen J, Hauth JC. Active-phase labor arrest: oxytocin augmentation for at least 4 hours. Obstet Gynecol. Mar. 1999;93(3):323-8. X-1. [pmid: 10074971].
4660 Rousseau JA, Girard K, Turcot-Lemay L, et al. A randomized study comparing skin closure in cesarean sections: staples vs subcuticular sutures. Am J Obstet Gynecol. Mar. 2009;200(3):265 e1-4. X-9. [pmid: 19254586].
4661 Rout CC, Akoojee SS, Rocke DA, et al. Rapid administration of crystalloid preload does not decrease the incidence of hypotension after spinal anaesthesia for elective caesarean section. Br J Anaesth. Apr. 1992;68(4):394-7. X-9. [pmid: 1642918].
4662 Rout CC, Rocke DA. Effects of alfentanil and fentanyl on induction of anaesthesia in patients with severe pregnancy-induced hypertension. Br J Anaesth. Oct. 1990;65(4):468-74. X-9. [pmid: 2123395].
4663 Rout CC, Rocke DA, Brijball R, et al. Prophylactic intramuscular ephedrine prior to caesarean section. Anaesth Intensive Care. Nov. 1992;20(4):448-52. X-9. [pmid: 1340780].
4664 Rout CC, Rocke DA, Gouws E. Intravenous ranitidine reduces the risk of acid aspiration of gastric contents at emergency cesarean section. Anesth Analg. Jan. 1993;76(1):156-61. X-9. [pmid: 8418717].
4665 Rout CC, Rocke DA, Gouws E. Leg elevation and wrapping in the prevention of hypotension following spinal anaesthesia for elective caesarean section. Anaesthesia. Apr. 1993;48(4):304-8. X-9. [pmid: 8494130].
4666 Rowan C. Court-ordered cesareans--choice or control?. Nurs Ethics. Nov. 1998;5(6):542-4. X-1, X-2, X-3, X-4e, X-5. [pmid: 9856072].
4667 Rowe-Murray HJ, Fisher JR. Operative intervention in delivery is associated with compromised early mother-infant interaction. BJOG. Oct. 2001;108(10):1068-75. X-1. [pmid: 11702839].
4668 Rowe-Murray HJ, Fisher JR. Baby friendly hospital practices: cesarean section is a persistent barrier to early initiation of breastfeeding. Birth. Jun. 2002;29(2):124-31. X-1. [pmid: 12000413].
4669 Rowland BL, Vermillion ST, Soper DE. Scheduled cesarean delivery and the prevention of human immunodeficiency virus transmission: a survey of practicing obstetricians. Am J Obstet Gynecol. Aug. 2001;185(2):327-31. X-1. [pmid: 11518886].
4670 Rowland TC Jr. Transactions of the Sixtieth Annual Meeting of The South Atlantic Association of Obstetricians and Gynecologists. What goes around comes around. Presidential address. Am J Obstet Gynecol. Aug. 1998;179(2):283-91. X-1, X-2. [pmid: 9731828].
4671 Roy JD, Girard M, Drolet P. Intrathecal meperidine decreases shivering during cesarean delivery under spinal anesthesia. Anesth Analg. Jan. 2004;98(1):230-4. table of contents. x-1. [pmid: 14693625].
4672 Roy KK, Baruah J, Moda N, et al. Evaluation of unilateral versus bilateral ovarian drilling in clomiphene citrate resistant cases of polycystic ovarian syndrome. Arch Gynecol Obstet. Oct. 2009;280(4):573-8. X-3, X-4e, X-5. [pmid: 19214545].
4673 Roy L, Ramanathan S. ST-segment depression and myocardial contractility during cesarean section under spinal anesthesia. Can J Anaesth. Jan. 1999;46(1):52-5. X-1. [pmid: 10078404].
4674 Rozenberg P, Chevret S, Goffinet F, et al. Induction of labour with a viable infant: a randomised clinical trial comparing intravaginal misoprostol and intravaginal dinoprostone. BJOG. Dec. 2001;108(12):1255-62. X-4d. [pmid: 11843388].
4675 Rozenberg P, Chevret S, Senat MV, et al. A randomized trial that compared intravaginal misoprostol and dinoprostone vaginal insert in pregnancies at high risk of fetal distress. Am J Obstet Gynecol. Jul. 2004;191(1):247-53. X-4d. [pmid: 15295374].
4676 Roztocil A, Pilka L, Jelinek J, et al. A comparison of three preinduction cervical priming methods: prostaglandin E2 gel, Dilapan S rods and Estradiol gel. Ceska Gynekol. Feb. 1998;63(1):3-9. X-4d, X-5. [pmid: 9650373].
4677 Rubinstein LM, Lebherz TB, Kleinkopf V. Laparoscopic tubal sterilization: long-term postoperative follow-up. Contraception. May. 1976;13(5):631-8. X-4e. [pmid: 131021].
4678 Rucklidge MW, Durbridge J, Barnes PK, et al. Glycopyrronium and hypotension following combined spinal-epidural anaesthesia for elective Caesarean section in women with relative bradycardia. Anaesthesia. Jan. 2002;57(1):4-8. X-9. [pmid: 11843734].
4679 Rucklidge MW, Paech MJ, Yentis SM. A comparison of the lateral, Oxford and sitting positions for performing combined spinal-epidural anaesthesia for elective Caesarean section. Anaesthesia. Jun. 2005;60(6):535-40. X-9. [pmid: 15918823].
4680 Rudd EG, Cobey EA, Long WH, et al. Prevention of endomyometritis using antibiotic irrigation during cesarean section. Obstet Gynecol. Oct. 1982;60(4):413-6. X-9. [pmid: 6750473].
4681 Rudd EG, Long WH, Dillon MB. Febrile morbidity following cefamandole nafate intrauterine irrigation during cesarean section. Am J Obstet Gynecol. Sep. 1. 1981;141(1):12-6. X-9. [pmid: 7270617].
4682 Ruderman J, Carroll JC, Reid AJ, et al. Are physicians changing the way they practise obstetrics?. CMAJ. Feb. 1. 1993;148(3):409-15. X-1. [pmid: 8439912].
4683 Rudge MV, Atallah AN, Peracoli JC, et al. Randomized controlled trial on prevention of postcesarean infection using penicillin and cephalothin in Brazil. Acta Obstet Gynecol Scand. 2006;85(8):945-8. X-9. [pmid: 16862472].
4684 Rudman A, El-Khouri B, Waldenstrom U. Evaluating multi-dimensional aspects of postnatal hospital care. Midwifery. Dec. 2008;24(4):425-41. X-1. [pmid: 17892904].
4685 Ruffatti A, Orsini A, Di Lenardo L, et al. A prospective study of fifty-three consecutive calcium heparin treated pregnancies in patients with antiphospholipid antibody-related fetal loss. Clin Exp Rheumatol. Sep-Oct. 1997;15(5):499-505. X-1. [pmid: 9307857].
4686 Ruiz I, Hernandez-Aguado I, Garrido P. Variation in surgical rates: a population study. Med Care. Sep. 1998;36(9):1315-23. X-1. [pmid: 9749655].
4687 Ruiz-Moreno JA, Garcia-Rojas JM, Lozada-Leon JD. Prevention of postcesarean infectious morbidity with a single dose of intravenous metronidazole. Int J Gynaecol Obstet. Mar. 1991;34(3):217-20. X-9. [pmid: 1673937].
4688 Runza M, Albani A, Tagliabue M, et al. Spinal anesthesia using hyperbaric 0.75% versus hyperbaric 1% bupivacaine for cesarean section. Anesth Analg. Nov. 1998;87(5):1099-103. X-9. [pmid: 9806688].
4689 Ruozi-Berretta A, Piazze JJ, Cosmi E, et al. Computerized cardiotocography parameters in pregnant women affected by pregestational diabetes mellitus. J Perinat Med. 2004;32(5):426-9. X-1. [pmid: 15493720].
4690 Ruparelia BA, Chapman MG. Early low-lying placentae--ultrasonic assessment, progress and outcome. Eur J Obstet Gynecol Reprod Biol. Oct. 1985;20(4):209-13. X-1. [pmid: 3902526].
4691 Rusconi F, Galassi C, Forastiere F, et al. Maternal complications and procedures in pregnancy and at birth and wheezing phenotypes in children. Am J Respir Crit Care Med. Jan. 1. 2007;175(1):16-21. X-1. [pmid: 16998092].
4692 Rush J, Burlock S, Lambert K, et al. The effects of whirlpools baths in labor: a randomized, controlled trial. Birth. Sep. 1996;23(3):136-43. X-5. [pmid: 8924099].
4693 Russell AW, McIntyre HD, Whitehead JP, et al. Adipose tissue from pregnant women with and without gestational diabetes mellitus: insulin-sensitive but resistant to hyperosomolarity. Am J Obstet Gynecol. Dec. 2005;193(6):2017-23. X-1. [pmid: 16325606].
4694 Russell D, Duncan LA, Frame WT, et al. Patient-controlled analgesia with morphine and droperidol following caesarean section under spinal anaesthesia. Acta Anaesthesiol Scand. May. 1996;40(5):600-5. X-9. [pmid: 8792892].
4695 Russell EC, Wrench I, Feast M, et al. Pre-oxygenation in pregnancy: the effect of fresh gas flow rates within a circle breathing system. Anaesthesia. Aug. 2008;63(8):833-6. X-1. [pmid: 18518865].
4696 Russell IF. Spinal anaesthesia for caesarean section. The use of 0.5% bupivacaine. Br J Anaesth. Apr. 1983;55(4):309-14. X-1. [pmid: 6838744].
4697 Russell IF. Effect of posture during the induction of subarachnoid analgesia for caesarean section. Right v. left lateral. Br J Anaesth. Mar. 1987;59(3):342-6. X-9. [pmid: 3828184].
4698 Russell IF, Holmqvist EL. Subarachnoid analgesia for caesarean section. A double-blind comparison of plain and hyperbaric 0.5% bupivacaine. Br J Anaesth. Mar. 1987;59(3):347-53. X-9. [pmid: 3548793].
4699 Rust LA, Waring RW, Hall GL, et al. Intrathecal narcotics for obstetric analgesia in a community hospital. Am J Obstet Gynecol. Jun. 1994;170(6):1643-6. discussion 1646-8. X-1. [pmid: 8203421].
4700 Rust OA, Greybush M, Atlas RO, et al. Preinduction cervical ripening. A randomized trial of intravaginal misoprostol alone vs. a combination of transcervical Foley balloon and intravaginal misoprostol. J Reprod Med. Oct. 2001;46(10):899-904. X-4d, X-5. [pmid: 11725734].
4701 Rutanen EM, Karkkainen TH, Lehtovirta J, et al. Evaluation of a rapid strip test for insulin-like growth factor binding protein-1 in the diagnosis of ruptured fetal membranes. Clin Chim Acta. Sep. 30. 1996;253(1-2):91-101. X-1. [pmid: 8879841].
4702 Ruth V, Fyhrquist F, Clemons G, et al. Cord plasma vasopressin, erythropoietin, and hypoxanthine as indices of asphyxia at birth. Pediatr Res. Oct. 1988;24(4):490-4. X-1. [pmid: 3174294].
4703 Ruth V, Pohjavuori M, Rovamo L, et al. Plasma beta-endorphin in perinatal asphyxia and respiratory difficulties in newborn infants. Pediatr Res. Jun. 1986;20(6):577-80. X-1. [pmid: 2940506].
4704 Ryan K, Schnatz P, Greene J, et al. Change in cesarean section rate as a reflection of the present malpractice crisis. Conn Med. Mar. 2005;69(3):139-41. X-1. [pmid: 15861999].
4705 Rybak EA. Hippocratic ideal, Faustian bargain and Damocles' sword: erosion of patient autonomy in obstetrics. J Perinatol. Nov. 2009;29(11):721-5. X-1, X-2. [pmid: 19861969].
4706 Rydhstrom H, Ingemarsson I. A case-control study of the effects of birth by caesarean section on intrapartum and neonatal mortality among twins weighing 1500-2499 g. Br J Obstet Gynaecol. Mar. 1991;98(3):249-53. X-1. [pmid: 2021562].
4707 Rydhstrom H, Ingemarsson I. No benefit from conservative management in nulliparous women with premature rupture of the membranes (PROM) at term. A randomized study. Acta Obstet Gynecol Scand. 1991;70(7-8):543-7. X-3, X-4e, X-5. [pmid: 1785268].
4708 Rydhstrom H, Walles B, Owman C. Myometrial norepinephrine in human pregnancy. Elevated levels in various disorders leading to cesarean section. J Reprod Med. Nov. 1989;34(11):901-4. X-1. [pmid: 2585392].
4709 Ryding EL. Investigation of 33 women who demanded a cesarean section for personal reasons. Acta Obstet Gynecol Scand. May. 1993;72(4):280-5. X-1. [pmid: 8389515].
4710 Ryding EL, Wijma B, Wijma K, et al. Fear of childbirth during pregnancy may increase the risk of emergency cesarean section. Acta Obstet Gynecol Scand. May. 1998;77(5):542-7. X-1. [pmid: 9654177].
4711 Ryding EL, Wiren E, Johansson G, et al. Group counseling for mothers after emergency cesarean section: a randomized controlled trial of intervention. Birth. Dec. 2004;31(4):247-53. X-9. [pmid: 15566336].
4712 Rytlewski K, Olszanecki R, Lauterbach R, et al. Effects of oral L-arginine on the foetal condition and neonatal outcome in preeclampsia: a preliminary report. Basic Clin Pharmacol Toxicol. Aug. 2006;99(2):146-52. X-4e, X-5. [pmid: 16918716].
4713 Saadat M, Nejad SM, Habibi G, et al. Maternal and neonatal outcomes in women with preeclampsia. Taiwan J Obstet Gynecol. Sep. 2007;46(3):255-9. X-1. [pmid: 17962105].
4714 Sabsamruei P, Tanprasertkul C. Intrapartum ultrasonogram for the determination of fetal occiput position and risk of cesarean section. J Med Assoc Thai. Feb. 2010;93(2):149-53. X-1. [pmid: 20301993].
4715 Sacks DA, Chen W, Greenspoon JS, et al. Should the same glucose values be targeted for type 1 as for type 2 diabetics in pregnancy?. Am J Obstet Gynecol. Nov. 1997;177(5):1113-9. X-1. [pmid: 9396904].
4716 Sacks DA, Feig DS, Liu IL, et al. Managing type I diabetes in pregnancy: how near normal is necessary?. J Perinatol. Aug. 2006;26(8):458-62. X-5, X-6. [pmid: 16761010].
4717 Sadan O, Ginath S, Gomel A, et al. Vacuum application through a nonfully dilated cervix: a viable option. Arch Gynecol Obstet. Oct. 2003;268(4):281-3. X-1. [pmid: 12764622].
4718 Sadeh-Mestechkin D, Walfisch A, Zeadna A, et al. Early post partum discharge: is it possible?. Arch Gynecol Obstet. Jul. 2007;276(1):65-70. X-1. [pmid: 17177028].
4719 Safir A, Levy A, Sikuler E, et al. Maternal hepatitis B virus or hepatitis C virus carrier status as an independent risk factor for adverse perinatal outcome. Liver Int. May. 2010;30(5):765-70. X-1. [pmid: 20214739].
4720 Sahu MT, Das V, Mittal S, et al. Overt and subclinical thyroid dysfunction among Indian pregnant women and its effect on maternal and fetal outcome. Arch Gynecol Obstet. Feb. 2010;281(2):215-20. X-1. [pmid: 19437026].
4721 Sainio S, Javela K, Kekomaki R, et al. Thrombopoietin levels in cord blood plasma and amniotic fluid in fetuses with alloimmune thrombocytopenia and healthy controls. Br J Haematol. May. 2000;109(2):330-5. X-1. [pmid: 10848820].
4722 Saisto T, Toivanen R, Salmela-Aro K, et al. Therapeutic group psychoeducation and relaxation in treating fear of childbirth. Acta Obstet Gynecol Scand. 2006;85(11):1315-9. X-1. [pmid: 17091410].
4723 Saisto T, Ylikorkala O, Halmesmaki E. Factors associated with fear of delivery in second pregnancies. Obstet Gynecol. Nov. 1999;94(5 Pt 1):679-82. X-1. [pmid: 10546709].
4724 Saito K, Haruki A, Ishikawa H, et al. Prospective study of intramuscular ergometrine compared with intramuscular oxytocin for prevention of postpartum hemorrhage. J Obstet Gynaecol Res. Jun. 2007;33(3):254-8. X-1. [pmid: 17578351].
4725 Saito T, Sessler DI, Fujita K, et al. Thermoregulatory effects of spinal and epidural anesthesia during cesarean delivery. Reg Anesth Pain Med. Jul-Aug. 1998;23(4):418-23. X-9. [pmid: 9690596].
4726 Sakala EP, Kaye S, Murray RD, et al. Epidural analgesia. Effect on the likelihood of a successful trial of labor after cesarean section. J Reprod Med. Sep. 1990;35(9):886-90. X-1. [pmid: 2231564].
4727 Sakala EP, Kaye S, Murray RD, et al. Oxytocin use after previous cesarean: why a higher rate of failed labor trial?. Obstet Gynecol. Mar. 1990;75(3 Pt 1):356-9. X-1. [pmid: 2304707].
4728 Sakura M, Nakabayashi M, Takeda Y, et al. Elevated fetal fibronectin in midtrimester amniotic fluid is involved with the onset of preeclampsia. J Obstet Gynaecol Res. Feb. 1998;24(1):73-6. X-1. [pmid: 9564109].
4729 Salant DJ, Marcus RG, Milne FJ, et al. Pregnancy in renal transplant recipients. S Afr Med J. Jul. 31. 1976;50(33):1288-90. X-1. [pmid: 785622].
4730 Saldana LR, Schulman H, Lin C. Routine amnioscopy at term. Obstet Gynecol. May. 1976;47(5):521-4. X-1. [pmid: 944404].
4731 Saleem S. Efficacy of dinoprostone, intracervical foleys and misoprostol in labor induction. J Coll Physicians Surg Pak. Apr. 2006;16(4):276-9. X-4d, X-5. [pmid: 16624192].
4732 Saleh A, Al-Sultan SM, Moria AM, et al. Fetal macrosomia greater than or equal to 4000 grams. Comparing maternal and neonatal outcomes in diabetic and nondiabetic women. Saudi Med J. Oct. 2008;29(10):1463-9. X-1. [pmid: 18946574].
4733 Salim R, Ben-Shlomo I, Nachum Z, et al. The incidence of large fetomaternal hemorrhage and the Kleihauer-Betke test. Obstet Gynecol. May. 2005;105(5 Pt 1):1039-44. X-1. [pmid: 15863542].
4734 Salim R, Garmi G, Nachum Z, et al. The impact of non-significant variable decelerations appearing in the latent phase on delivery mode: a prospective cohort study. Reprod Biol Endocrinol. 2010;8:81. X-1. [pmid: 20602762].
4735 Salim R, Shalev E. Health implications resulting from the timing of elective cesarean delivery. Neonatal Intensive Care. 2010;23(7):28. X-1, X-9.
4736 Salmon P, Drew NC. Multidimensional assessment of women's experience of childbirth: relationship to obstetric procedure, antenatal preparation and obstetric history. J Psychosom Res. May. 1992;36(4):317-27. X-1. [pmid: 1593507].
4737 Salomon O, Steinberg DM, Pshithizki M, et al. The influence of prothrombotic polymorphisms and obstetrical and medical variables on the length of secondary postpartum hemorrhage. J Womens Health (Larchmt). May. 2005;14(4):306-10. X-1. [pmid: 15916503].
4738 Salonen JT, Heinonen OP. Mental retardation and mother's hypertension during pregnancy. J Ment Defic Res. Mar. 1984;28(Pt 1):53-6. X-1. [pmid: 6716456].
4739 Saltzman DH, Eron LJ, Kay HH, et al. Single-dose antibiotic prophylaxis in high-risk patients undergoing cesarean section. Obstet Gynecol. May. 1985;65(5):655-7. X-9. [pmid: 3885107].
4740 Saltzman DH, Eron LJ, Toy C, et al. Ticarcillin plus clavulanic acid versus cefoxitin in the prophylaxis of infection after cesarean section. Am J Med. Nov. 29. 1985;79(5B):172-3. X-4b. [pmid: 3907340].
4741 Saltzman DH, Eron LJ, Tuomala RE, et al. Single-dose antibiotic prophylaxis in high-risk patients undergoing cesarean section. A comparative trial. J Reprod Med. Aug. 1986;31(8):709-12. X-9. [pmid: 3772891].
4742 Samadi S, Khadivzadeh T, Emami A, et al. The effect of Hypericum perforatum on the wound healing and scar of cesarean. J Altern Complement Med. Jan. 2010;16(1):113-7. X-9. [pmid: 20064022].
4743 Samarasekera DN, Bekhit MT, Wright Y, et al. Long-term anal continence and quality of life following postpartum anal sphincter injury. Colorectal Dis. Oct. 2008;10(8):793-9. X-1. [pmid: 18266886].
4744 Sambaziotis H, Conway C, Figueroa R, et al. Second-trimester sonographic comparison of the lower uterine segment in pregnant women with and without a previous cesarean delivery. J Ultrasound Med. Jul. 2004;23(7):907-11. quiz 913-4. X-1. [pmid: 15292558].
4745 Sampselle CM, Brink CA, Wells TJ. Digital measurement of pelvic muscle strength in childbearing women. Nurs Res. May-Jun. 1989;38(3):134-8. X-1. [pmid: 2717436].
4746 Sampselle CM, Miller JM, Mims BL, et al. Effect of pelvic muscle exercise on transient incontinence during pregnancy and after birth. Obstet Gynecol. Mar. 1998;91(3):406-12. X-3, X-4e, X-5. [pmid: 9491869].
4747 Samuels LA, Christie L, Roberts-Gittens B, et al. The effect of hyoscine butylbromide on the first stage of labour in term pregnancies. BJOG. Dec. 2007;114(12):1542-6. X-5. [pmid: 17903230].
4748 Samuels TA, Minkoff H, Feldman J, et al. Obstetricians, health attorneys, and court-ordered cesarean sections. Womens Health Issues. Mar-Apr. 2007;17(2):107-14. X-1. [pmid: 17403468].
4749 Samuels-Reid JH, Scott RB, Brown WE. Contraceptive practices and reproductive patterns in sickle cell disease. J Natl Med Assoc. Sep. 1984;76(9):879-83. X-1, X-4e. [pmid: 6492180].
4750 Sanansilp V, Areewatana S, Tonsukchai N. Droperidol and the side effects of epidural morphine after cesarean section. Anesth Analg. Mar. 1998;86(3):532-7. X-9. [pmid: 9495408].
4751 Sanchez-Ramos L, Farah LA, Kaunitz AM, et al. Preinduction cervical ripening with commercially available prostaglandin E2 gel: a randomized, double-blind comparison with a hospital-compounded preparation. Am J Obstet Gynecol. Oct. 1995;173(4):1079-84. X-4d, X-5. [pmid: 7485297].
4752 Sanchez-Ramos L, Kaunitz AM, Connor PM. Hygroscopic cervical dilators and prostaglandin E2 gel for preinduction cervical ripening. A randomized, prospective comparison. J Reprod Med. Apr. 1992;37(4):355-9. X-4d, X-5. [pmid: 1593561].
4753 Sanchez-Rodriguez EN, Nava-Salazar S, Mendoza-Rodriguez CA, et al. Persistence of decidual NK cells and KIR genotypes in healthy pregnant and preeclamptic women: a case-control study in the third trimester of gestation. Reprod Biol Endocrinol. 2011;9:8. X-1. [pmid: 21247496].
4754 Sanders RD, Mallory S, Lucas DN, et al. Extending low-dose epidural analgesia for emergency Caesarean section using ropivacaine 0.75%. Anaesthesia. Oct. 2004;59(10):988-92. X-9. [pmid: 15488058].
4755 Sandgren E, Sandgren S, Urazalin M, et al. HIV/AIDS awareness and risk behaviour among pregnant women in Semey, Kazakhstan, 2007. BMC Public Health. 2008;8:295. X-1. [pmid: 18721467].
4756 Sandmire HF, DeMott RK. The Green Bay cesarean section study. IV. The physician factor as a determinant of cesarean birth rates for the large fetus. Am J Obstet Gynecol. May. 1996;174(5):1557-64. X-1. [pmid: 9065129].
4757 Sanli S, Yegin A, Kayacan N, et al. Effects of hyperbaric spinal ropivacaine for caesarean section: with or without fentanyl. Eur J Anaesthesiol. Jun. 2005;22(6):457-61. X-9. [pmid: 15991510].
4758 Santema JG, Bourdrez P, Wallenburg HC. Maternal and perinatal complications in triplet compared with twin pregnancy. Eur J Obstet Gynecol Reprod Biol. Jun. 1995;60(2):143-7. X-1. [pmid: 7641966].
4759 Santerre RE. The effect of the ACOG guideline on vaginal births after cesarean. Med Care Res Rev. Sep. 1996;53(3):315-29. X-1, X-4b. [pmid: 10159931].
4760 Santiago JV, Clarke WL, Arias F. Studies with a pancreatic beta cell simulator in the third trimester of pregnancies complicated by diabetes. Am J Obstet Gynecol. Oct. 15. 1978;132(4):455-63. X-1. [pmid: 707588].
4761 Santos A, Datta S. Prophylactic use of droperidol for control of nausea and vomiting during spinal anesthesia for cesarean section. Anesth Analg. Jan. 1984;63(1):85-7. X-4b. [pmid: 6691570].
4762 Santulli P, Mandelbrot L, Facchiano E, et al. Obstetrical and neonatal outcomes of pregnancies following gastric bypass surgery: a retrospective cohort study in a French referral centre. Obes Surg. Nov. 2010;20(11):1501-8. X-1. [pmid: 20803358].
4763 Sapmaz E, Celik H, Altungul A. Bilateral ascending uterine artery ligation vs. tourniquet use for hemostasis in cesarean myomectomy. A comparison. J Reprod Med. Dec. 2003;48(12):950-4. X-3, X-4b, X-4e, X-5. [pmid: 14738022].
4764 Sarah R. Power, certainty, and the fear of death. Women Health. 1987;13(1-2):59-71. X-1. [pmid: 3332835].
4765 Sarandakou A, Rizos D, Botsis D, et al. Mucin-like carcinoma-associated antigen (MCA) during normal pregnancy. Eur J Obstet Gynecol Reprod Biol. May. 2001;96(1):51-4. X-1. [pmid: 11311760].
4766 Saraswat L, Porter M, Bhattacharya S. Caesarean section and tubal infertility: is there an association?. Reprod Biomed Online. Aug. 2008;17(2):259-64. X-1. [pmid: 18682001].
4767 Saravanan S, Kocarev M, Wilson RC, et al. Equivalent dose of ephedrine and phenylephrine in the prevention of post-spinal hypotension in Caesarean section. Br J Anaesth. Jan. 2006;96(1):95-9. X-9. [pmid: 16311286].
4768 Saravanan S, Robinson AP, Qayoum Dar A, et al. Minimum dose of intrathecal diamorphine required to prevent intraoperative supplementation of spinal anaesthesia for Caesarean section. Br J Anaesth. Sep. 2003;91(3):368-72. X-9. [pmid: 12925476].
4769 Saravolatz LD, Lee C, Drukker B. Comparison of intravenous administration with intrauterine irrigation with ceforanide for nonelective cesarean section. Obstet Gynecol. Oct. 1985;66(4):513-6. X-9. [pmid: 3900837].
4770 Sargent C, Stark N. Surgical birth: interpretations of cesarean delivery among private hospital patients and nursing staff. Soc Sci Med. 1987;25(12):1269-76. X-1. [pmid: 3433127].
4771 Sarkar RK, Cooley SM, Donnelly JC, et al. The incidence and impact of increased body mass index on maternal and fetal morbidity in the low-risk primigravid population. J Matern Fetal Neonatal Med. Dec. 2007;20(12):879-83. X-1. [pmid: 17963180].
4772 Sarna MC, Soni AK, Gomez M, et al. Intravenous oxytocin in patients undergoing elective cesarean section. Anesth Analg. Apr. 1997;84(4):753-6. X-9. [pmid: 9085952].
4773 Sarno AP Jr., Hinderstein WN, Staiano RA. Fetal macrosomia in a military hospital: incidence, risk factors, and outcome. Mil Med. Feb. 1991;156(2):55-8. X-1. [pmid: 1900588].
4774 Saropala N, Chaturachinda K. Outcome of premature rupture of membranes (PROM) at term: Ramathibodi Hospital, 1988. J Med Assoc Thai. Jan. Suppl 1. 1993;76:56-9. X-1. [pmid: 8113658].
4775 Sarowar MG, Medin E, Gazi R, et al. Calculation of costs of pregnancy- and puerperium-related care: experience from a hospital in a low-income country. J Health Popul Nutr. Jun. 2010;28(3):264-72. X-1. [pmid: 20635637].
4776 Sartain JB, Barry JJ, Howat PW, et al. Intravenous oxytocin bolus of 2 units is superior to 5 units during elective Caesarean section. Br J Anaesth. Dec. 2008;101(6):822-6. X-9. [pmid: 18845650].
4777 Sarvela J, Halonen P, Soikkeli A, et al. A double-blinded, randomized comparison of intrathecal and epidural morphine for elective cesarean delivery. Anesth Analg. Aug. 2002;95(2):436-40. table of contents. X-9. [pmid: 12145067].
4778 Sarvela PJ, Halonen PM, Korttila KT. Comparison of 9 mg of intrathecal plain and hyperbaric bupivacaine both with fentanyl for cesarean delivery. Anesth Analg. Nov. 1999;89(5):1257-62. X-9. [pmid: 10553846].
4779 Sarvela PJ, Halonen PM, Soikkeli AI, et al. Ondansetron and tropisetron do not prevent intraspinal morphine- and fentanyl-induced pruritus in elective cesarean delivery. Acta Anaesthesiol Scand. Feb. 2006;50(2):239-44. X-9. [pmid: 16430549].
4780 Sasaki Y, Morimoto T, Saito H, et al. The role of parathyroid hormone-related protein in intra-tracheal fluid. Endocr J. Apr. 2000;47(2):169-75. X-1. [pmid: 10943741].
4781 Satin AJ, Hankins GD, Yeomans ER. A prospective study of two dosing regimens of oxytocin for the induction of labor in patients with unfavorable cervices. Am J Obstet Gynecol. Oct. 1991;165(4 Pt 1):980-4. X-4d, X-5. [pmid: 1951567].
4782 Satin AJ, Leveno KJ, Sherman ML, et al. High- versus low-dose oxytocin for labor stimulation. Obstet Gynecol. Jul. 1992;80(1):111-6. X-1, X-4d, X-5. [pmid: 1603479].
4783 Satin AJ, Leveno KJ, Sherman ML, et al. High-dose oxytocin: 20- versus 40-minute dosage interval. Obstet Gynecol. Feb. 1994;83(2):234-8. X-1. [pmid: 8290186].
4784 Satin AJ, Leveno KJ, Sherman ML, et al. Factors affecting the dose response to oxytocin for labor stimulation. Am J Obstet Gynecol. Apr. 1992;166(4):1260-1. X-1. [pmid: 1566782].
4785 Satin AJ, Leveno KJ, Sherman ML, et al. Maternal youth and pregnancy outcomes: middle school versus high school age groups compared with women beyond the teen years. Am J Obstet Gynecol. Jul. 1994;171(1):184-7. X-1. [pmid: 8030697].
4786 Satin AJ, Maberry MC, Leveno KJ, et al. Chorioamnionitis: a harbinger of dystocia. Obstet Gynecol. Jun. 1992;79(6):913-5. X-1. [pmid: 1579312].
4787 Sato T, Konishi F, Minakami H, et al. Pelvic floor disturbance after childbirth: vaginal delivery damages the upper levels of sphincter innervation. Dis Colon Rectum. Aug. 2001;44(8):1155-61. X-1. [pmid: 11535856].
4788 Sauer L, Harrison MR, Flake AW, et al. Does an expanding fetal abdominal mass produce pulmonary hypoplasia?. J Pediatr Surg. Jun. 1987;22(6):508-12. X-3. [pmid: 3612441].
4789 Sauer M, Parsons M, Sampson M. Placenta previa: an analysis of three years experience. Am J Perinatol. Jan. 1985;2(1):39-42. X-1. [pmid: 3986026].
4790 Saunders DL, Makutu SL. Cesarean section deliveries in Fiji, 1986 to 1996. Pac Health Dialog. Mar. 2001;8(1):71-7. X-1. [pmid: 12017841].
4791 Saunders K. Should we worry about meconium? A controlled study of neonatal outcome. Trop Doct. Jan. 2002;32(1):7-10. X-1. [pmid: 11991044].
4792 Saunders LD, Flowerdew G. Cesarean sections in Alberta from April 1979 to March 1988. CMAJ. May. 15. 1991;144(10):1243-9. 1252. X-1. [pmid: 2025819].
4793 Saunders NJ, Barclay C. Closed suction wound drainage and lower-segment caesarean section. Br J Obstet Gynaecol. Oct. 1988;95(10):1060-2. X-9. [pmid: 3056499].
4794 Savage W. Cutting decision. Interview by Tricia Reid. Nurs Times. Oct. 6-12. 1993;89(40):16-7. X-1, X-2, X-3, X-4. [pmid: 8415109].
4795 Savage W. The right to choose. Nurs Stand. May. 20-26. 1998;12(35):14. X-1. [pmid: 9687689].
4796 Savage W, Francome C. British caesarean section rates: have we reached a plateau?. Br J Obstet Gynaecol. May. 1993;100(5):493-6. X-1, X-3, X-4e, X-5. [pmid: 8518254].
4797 Savitz DA, Stein CR, Siega-Riz AM, et al. Gestational weight gain and birth outcome in relation to prepregnancy body mass index and ethnicity. Ann Epidemiol. Feb. 2011;21(2):78-85. X-1. [pmid: 20702110].
4798 Sawai SK, Williams MC, O'Brien WF, et al. Sequential outpatient application of intravaginal prostaglandin E2 gel in the management of postdates pregnancies. Obstet Gynecol. Jul. 1991;78(1):19-23. X-4d. [pmid: 2047061].
4799 Sawchuck DJ. Evaluation of perinatal clinical practice guidelines in British Columbia. Ph.D. 2006:237. X-1.
4800 Saygan-Karamursel B, Teksam O, Aksu T, et al. Perinatal outcomes of spontaneous twins compared with twins conceived through intracytoplasmic sperm injection. J Perinat Med. 2006;34(2):132-8. X-1. [pmid: 16519618].
4801 Scaravelli G, Thorne C, Newell ML. The management of pregnancy and delivery in HIV-infected women in Europe. Eur J Obstet Gynecol Reprod Biol. Sep. 1995;62(1):7-13. X-1. [pmid: 7493713].
4802 Scarpignato C, Caltabiano M, Condemi V, et al. Short-term versus long-term cefuroxime prophylaxis in patients undergoing emergency cesarean section. Clin Ther. 1982;5(2):186-92. X-9. [pmid: 6760969].
4803 Schaap AH, Wolf H, Bruinse HW, et al. Effects of antenatal corticosteroid administration on mortality and long-term morbidity in early preterm, growth-restricted infants. Obstet Gynecol. Jun. 2001;97(6):954-60. X-1. [pmid: 11384702].
4804 Schadewaldt P, Hammen HW, Kamalanathan L, et al. Biochemical monitoring of pregnancy and breast feeding in five patients with classical galactosaemia--and review of the literature. Eur J Pediatr. Jun. 2009;168(6):721-9. X-1. [pmid: 18813948].
4805 Schaefer-Graf UM, Kjos SL, Fauzan OH, et al. A randomized trial evaluating a predominantly fetal growth-based strategy to guide management of gestational diabetes in Caucasian women. Diabetes Care. Feb. 2004;27(2):297-302. X-3, X-4e, X-5. [pmid: 14747203].
4806 Schafer-Graf UM, Dupak J, Vogel M, et al. Hyperinsulinism, neonatal obesity and placental immaturity in infants born to women with one abnormal glucose tolerance test value. J Perinat Med. 1998;26(1):27-36. X-1. [pmid: 9595364].
4807 Schalkwyk J, Amiri N, Lalji S, et al. Acceptance of a rapid herpes test in labour: survey of attitudes of patients and health care providers. J Obstet Gynaecol Can. Sep. 2008;30(9):776-80. X-1. [pmid: 18845046].
4808 Schannwell CM, Schneppenheim M, Perings SM, et al. Alterations of left ventricular function in women with insulin-dependent diabetes mellitus during pregnancy. Diabetologia. Feb. 2003;46(2):267-75. X-1. [pmid: 12627326].
4809 Schatz M, Zeiger RS, Hoffman CP, et al. Increased transient tachypnea of the newborn in infants of asthmatic mothers. Am J Dis Child. Feb. 1991;145(2):156-8. X-1. [pmid: 1994679].
4810 Schaub AF, Litschgi M, Hoesli I, et al. Obstetric gel shortens second stage of labor and prevents perineal trauma in nulliparous women: a randomized controlled trial on labor facilitation. J Perinat Med. 2008;36(2):129-35. X-4e, X-5. [pmid: 18211256].
4811 Schauberger CW. False labor. Obstet Gynecol. Dec. 1986;68(6):770-2. X-1. [pmid: 3785787].
4812 Schauberger CW, Rooney BL, Beguin EA, et al. Evaluating the thirty minute interval in emergency cesarean sections. J Am Coll Surg. Aug. 1994;179(2):151-5. X-1. [pmid: 8044383].
4813 Schauffler HH, Brown C, Milstein A. Raising the bar: the use of performance guarantees by the Pacific Business Group on Health. Health Aff (Millwood). Mar-Apr. 1999;18(2):134-42. X-1. [pmid: 10091440].
4814 Scheckler WE, Peterson PJ. Nosocomial infections in 15 rural Wisconsin hospitals--results and conclusions from 6 months of comprehensive surveillance. Infect Control. Aug. 1986;7(8):397-402. X-1. [pmid: 3528017].
4815 Schedvins K, Moberg PJ. Prevention of postoperative infection in cesarean section after rupture of the membranes. Int J Gynaecol Obstet. Jun. 1986;24(3):165-8. X-9. [pmid: 2880755].
4816 Scheepers HC, de Jong PA, Essed GG, et al. Carbohydrate solution intake during labour just before the start of the second stage: a double-blind study on metabolic effects and clinical outcome. BJOG. Dec. 2004;111(12):1382-7. X-5, X-6. [pmid: 15663123].
4817 Scheepers HC, Thans MC, de Jong PA, et al. The effects of oral carbohydrate administration on fetal acid base balance. J Perinat Med. 2002;30(5):400-4. X-1. [pmid: 12442604].
4818 Schenker JG. Codes of perinatal ethics: an international perspective. Clin Perinatol. Mar. 2003;30(1):45-65. X-1. [pmid: 12696785].
4819 Schenker JG, Simha A. Quintuplet pregnancy. Obstet Gynecol. May. 1975;45(5):590-3. X-1. [pmid: 1124180].
4820 Schiff E, Friedman SA, Mashiach S, et al. Maternal and neonatal outcome of 846 term singleton breech deliveries: seven-year experience at a single center. Am J Obstet Gynecol. Jul. 1996;175(1):18-23. X-1. [pmid: 8694048].
4821 Schiff MA, Grossman DC. Adverse perinatal outcomes and risk for postpartum suicide attempt in Washington state, 1987-2001. Pediatrics. Sep. 2006;118(3):e669-75. X-1. [pmid: 16950958].
4822 Schindl M, Birner P, Reingrabner M, et al. Elective cesarean section vs. spontaneous delivery: a comparative study of birth experience. Acta Obstet Gynecol Scand. Sep. 2003;82(9):834-40. X-1, X-3, X-4e, X-5. [pmid: 12911445].
4823 Schlenzig C, Maurer S, Goppelt M, et al. Postpartum curettage in patients with HELLP-syndrome does not result in accelerated recovery. Eur J Obstet Gynecol Reprod Biol. Jul. 2000;91(1):25-8. X-1. [pmid: 10817874].
4824 Schmitz T, Carnavalet Cde C, Azria E, et al. Neonatal outcomes of twin pregnancy according to the planned mode of delivery. Obstet Gynecol. Mar. 2008;111(3):695-703. X-1. [pmid: 18310373].
4825 Schneider KT, Luftner D, Rath W. Efficacy and safety of a 2-tier prostaglandin labor induction schedule. J Perinat Med. 1994;22(5):399-407. X-4d, X-5. [pmid: 7791015].
4826 Scholl TO, Sowers M, Chen X, et al. Maternal glucose concentration influences fetal growth, gestation, and pregnancy complications. Am J Epidemiol. Sep. 15. 2001;154(6):514-20. X-1. [pmid: 11549556].
4827 Scholz HS, Haas J, Petru E. Do primiparas aged 40 years or older carry an increased obstetric risk?. Prev Med. Oct. 1999;29(4):263-6. X-1. [pmid: 10547051].
4828 Schreiber J, Benedetti T. Conservative management of preterm premature rupture of the fetal membranes in a low socioeconomic population. Am J Obstet Gynecol. Jan. 1. 1980;136(1):92-6. X-1. [pmid: 7352493].
4829 Schrimmer DB, Macri CJ, Paul RH. Prophylactic amnioinfusion as a treatment for oligohydramnios in laboring patients: a prospective, randomized trial. Am J Obstet Gynecol. Oct. 1991;165(4 Pt 1):972-5. X. [pmid: 1951565].
4830 Schuler L, Pastuszak A, Sanseverino TV, et al. Pregnancy outcome after exposure to misoprostol in Brazil: a prospective, controlled study. Reprod Toxicol. Mar-Apr. 1999;13(2):147-51. X-1. [pmid: 10213522].
4831 Schultetus RR, Paulus DA, Spohr GL. Haemodynamic effects of ketamine and thiopentone during anaesthetic induction for caesarean section. Can Anaesth Soc J. Nov. 1985;32(6):592-6. X-9. [pmid: 3907790].
4832 Schultz CC, Wood JY, Magann EF, et al. Prediction of a caesarean delivery by labour and delivery nurses. Aust N Z J Obstet Gynaecol. Oct. 2007;47(5):402-5. X-1. [pmid: 17877599].
4833 Schulz-Stubner S, Zingel E, Rossaint R. Vibration sense testing with a 128-Hz tuning fork as a tool to determine recovery from epidural neuraxial block. Reg Anesth Pain Med. Nov-Dec. 2001;26(6):518-22. X-9. [pmid: 11707789].
4834 Schuster MW, Chauhan SP, McLaughlin BN, et al. Comparison of insulin regimens and administration modalities in pregnancy complicated by diabetes. J Miss State Med Assoc. Jun. 1998;39(6):208-12. X-4e, X-5. [pmid: 9635386].
4835 Schuster MW, Chauhan SP, McLaughlin BN, et al. Comparison of insulin regimens and administration modalities in pregnancy complicated by diabetes. J Miss State Med Assoc. Feb. 1998;39(2):51-5. X-3, X-4e, X-5. [pmid: 9476446].
4836 Schvarcz E, Palmer M, Ingberg CM, et al. Increased prevalence of upper gastrointestinal symptoms in long-term type 1 diabetes mellitus. Diabet Med. May. 1996;13(5):478-81. X-1. [pmid: 8737031].
4837 Schwappach DL, Blaudszun A, Conen D, et al. Women's experiences with low-risk singleton in-hospital delivery in Switzerland. Swiss Med Wkly. Feb. 21. 2004;134(7-8):103-9. X-1. [pmid: 15106027].
4838 Schwartz DB, Greenberg MD, Daoud Y, et al. Genital condylomas in pregnancy: use of trichloroacetic acid and laser therapy. Am J Obstet Gynecol. Jun. 1988;158(6 Pt 1):1407-16. X-1. [pmid: 3381865].
4839 Schwartz MA, Wang CC, Eckert LO, et al. Risk factors for urinary tract infection in the postpartum period. Am J Obstet Gynecol. Sep. 1999;181(3):547-53. X-1. [pmid: 10486462].
4840 Schytt E, Lindmark G, Waldenstrom U. Physical symptoms after childbirth: prevalence and associations with self-rated health. BJOG. Feb. 2005;112(2):210-7. X-1. [pmid: 15663586].
4841 Sciscione AC, Duhl A, Pollock MA, et al. Extramembranous placement of an air-coupled vs. transducer-tipped intrauterine pressure catheter. J Reprod Med. Aug. 2005;50(8):578-84. X-4e. [pmid: 16220762].
4842 Sciscione AC, Muench M, Pollock M, et al. Transcervical Foley catheter for preinduction cervical ripening in an outpatient versus inpatient setting. Obstet Gynecol. Nov. 2001;98(5 Pt 1):751-6. X-4e. [pmid: 11704164].
4843 Sciscione AC, Nguyen L, Manley J, et al. A randomized comparison of transcervical Foley catheter to intravaginal misoprostol for preinduction cervical ripening. Obstet Gynecol. Apr. 2001;97(4):603-7. X-4e. [pmid: 11275035].
4844 Sciscione AC, Nguyen L, Manley JS, et al. Uterine rupture during preinduction cervical ripening with misoprostol in a patient with a previous Caesarean delivery. Aust N Z J Obstet Gynaecol. Feb. 1998;38(1):96-7. X-1. [pmid: 9521403].
4845 Scott C. Resisting the temptation to turn medical recommendations into judicial orders: a reconsideration of court-ordered surgery for pregnant women. Ga State Univ Law Rev. May. 1994;10(4):615-89. X-1, X-2. [pmid: 11656420].
4846 Scott LL, Hollier LM, McIntire D, et al. Acyclovir suppression to prevent clinical recurrences at delivery after first episode genital herpes in pregnancy: an open-label trial. Infect Dis Obstet Gynecol. 2001;9(2):75-80. X-1. [pmid: 11495557].
4847 Scott LL, Hollier LM, McIntire D, et al. Acyclovir suppression to prevent recurrent genital herpes at delivery. Infect Dis Obstet Gynecol. 2002;10(2):71-7. X-4e. [pmid: 12530483].
4848 Scott LL, Sanchez PJ, Jackson GL, et al. Acyclovir suppression to prevent cesarean delivery after first-episode genital herpes. Obstet Gynecol. Jan. 1996;87(1):69-73. X-4e. [pmid: 8532270].
4849 Scott PV, Bowen FE, Cartwright P, et al. Intrathecal morphine as sole analgesic during labour. Br Med J. Aug. 2. 1980;281(6236):351-3. X-1. [pmid: 6893559].
4850 Scott R. The pregnant woman and the good Samaritan: can a woman have a duty to undergo a caesarean section?. Oxf J Leg Stud. Autumn. 2000;20(3):407-36. X-1. [pmid: 12452142].
4851 Scott RT, Strickland DM, Hankins GD, et al. Maternal height and weight gain during pregnancy as risk factors for cesarean section. Mil Med. Jul. 1989;154(7):365-7. X-1. [pmid: 2503778].
4852 Seago DP, Roberts WE, Johnson VK, et al. Planned cesarean hysterectomy: A preferred alternative to separate operations. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1385-93. X-1. [pmid: 10368475].
4853 Seah YS, Chen C, Ng YT, et al. Ilioinguinal nerve block with 0.375% marcaine for postoperative pain relief in cesarean section. Ma Zui Xue Za Zhi. Sep. 1990;28(3):307-10. X-9. [pmid: 2277571].
4854 Sears DH, Leeman MI, Jassy LJ, et al. The frequency of postdural puncture headache in obstetric patients: a prospective study comparing the 24-gauge versus the 22-gauge Sprotte needle. J Clin Anesth. Jan-Feb. 1994;6(1):42-6. X. [pmid: 8142098].
4855 Seaton S, Reeves M, McLean S. Oxycodone as a component of multimodal analgesia for lactating mothers after Caesarean section: relationships between maternal plasma, breast milk and neonatal plasma levels. Aust N Z J Obstet Gynaecol. Jun. 2007;47(3):181-5. X-9. [pmid: 17550483].
4856 Seaward PG, Hannah ME, Myhr TL, et al. International Multicentre Term Prelabor Rupture of Membranes Study: evaluation of predictors of clinical chorioamnionitis and postpartum fever in patients with prelabor rupture of membranes at term. Am J Obstet Gynecol. Nov. 1997;177(5):1024-9. X-4e. [pmid: 9396886].
4857 Sebhatu B. Determining the sensitivity of sitting height in predicting cephalo pelvic disproportion in Eritrea. Trop Doct. Oct. 2005;35(4):204-6. X-1. [pmid: 16354467].
4858 Sebitloane MH, Moodley J. Emergency peripartum hysterectomy. East Afr Med J. Feb. 2001;78(2):70-4. X-1. [pmid: 11682949].
4859 Secher NJ, Hansen PK, Lenstrup C, et al. Controlled trial of ultrasound screening for light for gestational age (LGA) infants in late pregnancy. Eur J Obstet Gynecol Reprod Biol. Dec. 1986;23(5-6):307-13. X-5. [pmid: 3542623].
4860 Secher NJ, Kern Hansen P, Lenstrup C, et al. A randomized study of fetal abdominal diameter and fetal weight estimation for detection of light-for-gestation infants in low-risk pregnancies. Br J Obstet Gynaecol. Feb. 1987;94(2):105-9. X-5. [pmid: 3548803].
4861 Seeras RC. Induction of labor utilizing vaginal vs. intracervical prostaglandin E2. Int J Gynaecol Obstet. Feb. 1995;48(2):163-7. X-4d. [pmid: 7789590].
4862 Seeras RC, Olatunbosun OA, Pierson RA, et al. Induction of labor using prostaglandin E2 (PGE2) vaginal gel in triacetin base. An efficacy study comparing two dosage regimens. Clin Exp Obstet Gynecol. 1995;22(2):105-10. X-4d. [pmid: 7781174].
4863 Seffah JD. Caesarean section and birth weight at Korle Bu Teaching Hospital--preliminary report. West Afr J Med. Jul-Sep. 2002;21(3):212-4. X-1. [pmid: 12744570].
4864 Seffah JD, Armah JO. Antenatal ultrasonography for breech delivery. Int J Gynaecol Obstet. Jan. 2000;68(1):7-12. X-4c. [pmid: 10687830].
4865 Segal D, Holcberg G, Sapir O, et al. Neurofibromatosis in pregnancy. Maternal and perinatal outcome. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):59-61. X-1. [pmid: 10413228].
4866 Segal D, Sheiner E, Yohai D, et al. Early amniotomy -- high risk factor for cesarean section. Eur J Obstet Gynecol Reprod Biol. Oct. 1999;86(2):145-9. X-1. [pmid: 10509782].
4867 Segal S, Eappen S, Datta S. Superiority of multi-orifice over single-orifice epidural catheters for labor analgesia and cesarean delivery. J Clin Anesth. Mar. 1997;9(2):109-12. X-1. [pmid: 9075034].
4868 Segal S, Shemesh IY, Blumenthal R, et al. Treatment of obstetric hemorrhage with recombinant activated factor VII (rFVIIa). Arch Gynecol Obstet. Oct. 2003;268(4):266-7. X-1. [pmid: 14504866].
4869 Segregur J, Bukovic D, Milinovic D, et al. Fetal macrosomia in pregnant women with gestational diabetes. Coll Antropol. Dec. 2009;33(4):1121-7. X-1. [pmid: 20102057].
4870 Seidman DS, Paz I, Nadu A, et al. Are multiple cesarean sections safe?. Eur J Obstet Gynecol Reprod Biol. Oct. 1994;57(1):7-12. X-1. [pmid: 7821507].
4871 Seiler JS. The demise of vaginal operative obstetrics: a suggested plan for its revival. Obstet Gynecol. Apr. 1990;75(4):710-3. X-1. [pmid: 2314791].
4872 Sekhavat L, Dehghani Firouzabadi R, Mojiri P. Effect of expansion technique of uterine incision on maternal blood loss in cesarean section. Arch Gynecol Obstet. Nov. 2010;282(5):475-9. X-1, X-9. [pmid: 19838721].
4873 Sekhavat L, Tabatabaii A, Dalili M, et al. Efficacy of tranexamic acid in reducing blood loss after cesarean section. J Matern Fetal Neonatal Med. Jan. 2009;22(1):72-5. X-9. [pmid: 19165682].
4874 Sekirime WK, Lule JC. Maternal morbidity following emergency caesarean section in asymptomatic HIV-1 infected patients in Mulago Hospital Kampala, Uganda. J Obstet Gynaecol. Oct. 2008;28(7):703-9. X-9. [pmid: 19065365].
4875 Sekizawa A, Yokokawa K, Sugito Y, et al. Evaluation of bidirectional transfer of plasma DNA through placenta. Hum Genet. Sep. 2003;113(4):307-10. X-1, X-9. [pmid: 12884005].
4876 Sela HY, Shveiky D, Laufer N, et al. Pregnant women injured in terror-related multiple casualty incidents: injuries and outcomes. J Trauma. Mar. 2008;64(3):727-32. X-1. [pmid: 18332814].
4877 Selo-Ojeme D, Abulhassan N, Mandal R, et al. Preferred and actual delivery mode after a cesarean in London, UK. Int J Gynaecol Obstet. Aug. 2008;102(2):156-9. X-1. [pmid: 18436222].
4878 Selo-Ojeme DO, Bhattacharjee P, Izuwa-Njoku NF, et al. Emergency peripartum hysterectomy in a tertiary London hospital. Arch Gynecol Obstet. Feb. 2005;271(2):154-9. X-1. [pmid: 15690169].
4879 Selo-Ojeme DO, Omosaiye M, Battacharjee P, et al. Risk factors for obstetric admissions to the intensive care unit in a tertiary hospital: a case-control study. Arch Gynecol Obstet. Sep. 2005;272(3):207-10. X-1. [pmid: 15690170].
4880 Semple AJ, Macrae DJ, Munishankarappa S, et al. Effect of the addition of adrenaline to extradural diamorphine analgesia after caesarean section. Br J Anaesth. May. 1988;60(6):632-8. X-9. [pmid: 3377947].
4881 Sempowski IP, Houlden RL. Managing diabetes during pregnancy. Guide for family physicians. Can Fam Physician. Jun. 2003;49:761-7. X-1, X-2. [pmid: 12836864].
4882 Semprini AE, Castagna C, Ravizza M, et al. The incidence of complications after caesarean section in 156 HIV-positive women. AIDS. Aug. 1995;9(8):913-7. X-1, X-9. [pmid: 7576327].
4883 Sen A, Rudra A, Sarkar SK, et al. Intrathecal midazolam for postoperative pain relief in caesarean section delivery. J Indian Med Assoc. Dec. 2001;99(12):683-4. 686. X-9. [pmid: 12022217].
4884 Sen S, Malik S, Salhan S. Ultrasonographic evaluation of lower uterine segment thickness in patients of previous cesarean section. Int J Gynaecol Obstet. Dec. 2004;87(3):215-9. X-1. [pmid: 15548392].
4885 Sen S, Ozmert G, Aydin ON, et al. The persisting analgesic effect of low-dose intravenous ketamine after spinal anaesthesia for caesarean section. Eur J Anaesthesiol. Jul. 2005;22(7):518-23. X-9. [pmid: 16045141].
4886 Sen S, Ozmert G, Turan H, et al. The effects of spinal anesthesia on QT interval in preeclamptic patients. Anesth Analg. Nov. 2006;103(5):1250-5. X-1. [pmid: 17056963].
4887 Sendag F, Terek MC, Itil IM, et al. Maternal and perinatal outcomes in women with gestational diabetes mellitus as compared to nondiabetic controls. J Reprod Med. Dec. 2001;46(12):1057-62. X-1. [pmid: 11789086].
4888 Senecal J, Xiong X, Fraser WD. Effect of fetal position on second-stage duration and labor outcome. Obstet Gynecol. Apr. 2005;105(4):763-72. X-1. [pmid: 15802403].
4889 Sener EB, Guldogus F, Karakaya D, et al. Comparison of neonatal effects of epidural and general anesthesia for cesarean section. Gynecol Obstet Invest. 2003;55(1):41-5. X-9. [pmid: 12624551].
4890 Seneviratne HR, de Silva GD, de Silva MV, et al. Obstetric performance, perinatal outcome and risk of infection to the newborn in spontaneous and artificial rupture of membranes during labour. Ceylon Med J. Mar. 1998;43(1):11-5. X-1. [pmid: 9624837].
4891 Sentilhes L, Goffinet F, Talbot A, et al. Attempted vaginal versus planned cesarean delivery in 195 breech first twin pregnancies. Acta Obstet Gynecol Scand. 2007;86(1):55-60. X-1. [pmid: 17230290].
4892 Sentilhes L, Gromez A, Razzouk K, et al. B-Lynch suture for massive persistent postpartum hemorrhage following stepwise uterine devascularization. Acta Obstet Gynecol Scand. 2008;87(10):1020-6. X-1. [pmid: 18927949].
4893 Seoud MA, Nassar AH, Usta IM, et al. Impact of advanced maternal age on pregnancy outcome. Am J Perinatol. Jan. 2002;19(1):1-8. X-1. [pmid: 11857090].
4894 Seracchioli R, Rossi S, Govoni F, et al. Fertility and obstetric outcome after laparoscopic myomectomy of large myomata: a randomized comparison with abdominal myomectomy. Hum Reprod. Dec. 2000;15(12):2663-8. X-1. [pmid: 11098042].
4895 Sercekus P, Okumus H. Fears associated with childbirth among nulliparous women in Turkey. Midwifery. Apr. 2009;25(2):155-62. X-1. [pmid: 17600599].
4896 Serenius F, Ewald U, Farooqi A, et al. Short-term outcome after active perinatal management at 23-25 weeks of gestation. A study from two Swedish tertiary care centres. Part 1: maternal and obstetric factors. Acta Paediatr. Jul. 2004;93(7):945-53. X-1. [pmid: 15303811].
4897 Serjeant GR, Hambleton I, Thame M. Fecundity and pregnancy outcome in a cohort with sickle cell-haemoglobin C disease followed from birth. BJOG. Sep. 2005;112(9):1308-14. X-1. [pmid: 16101613].
4898 Sermer M, Naylor CD, Farine D, et al. The Toronto Tri-Hospital Gestational Diabetes Project. A preliminary review. Diabetes Care. Aug. Suppl 2. 1998;21:B33-42. X-1. [pmid: 9704225].
4899 Sermer M, Naylor CD, Gare DJ, et al. Impact of increasing carbohydrate intolerance on maternal-fetal outcomes in 3637 women without gestational diabetes. The Toronto Tri-Hospital Gestational Diabetes Project. Am J Obstet Gynecol. Jul. 1995;173(1):146-56. X-1. [pmid: 7631672].
4900 Seron-Ferre M, Riffo R, Valenzuela GJ, et al. Twenty-four-hour pattern of cortisol in the human fetus at term. Am J Obstet Gynecol. May. 2001;184(6):1278-83. X-1. [pmid: 11349202].
4901 Seror J, Allouche C, Elhaik S. Use of Sengstaken-Blakemore tube in massive postpartum hemorrhage: a series of 17 cases. Acta Obstet Gynecol Scand. Jul. 2005;84(7):660-4. X-1. [pmid: 15954876].
4902 Serra A, Fitze G, Kamin G, et al. Preliminary report on elective preterm delivery at 34 weeks and primary abdominal closure for the management of gastroschisis. Eur J Pediatr Surg. Feb. 2008;18(1):32-7. X-1. [pmid: 18302067].
4903 Setayesh AR, Kholdebarin AR, Moghadam MS, et al. The Trendelenburg position increases the spread and accelerates the onset of epidural anesthesia for Cesarean section. Can J Anaesth. Oct. 2001;48(9):890-3. X-9. [pmid: 11606347].
4904 Seyb ST, Berka RJ, Socol ML, et al. Risk of cesarean delivery with elective induction of labor at term in nulliparous women. Obstet Gynecol. Oct. 1999;94(4):600-7. X-1. [pmid: 10511367].
4905 Seymour J. A pregnant woman's decision to decline treatment: how should the law respond?. J Law Med. Aug. 1994;2(1):27-37. X-1. [pmid: 11660250].
4906 Sezer OA, Gunaydin B. Efficacy of patient-controlled epidural analgesia after initiation with epidural or combined spinal-epidural analgesia. Int J Obstet Anesth. Jul. 2007;16(3):226-30. X-1. [pmid: 17509869].
4907 Sezik M, Ozkaya O, Sezik HT, et al. Does marriage between first cousins have any predictive value for maternal and perinatal outcomes in pre-eclampsia?. J Obstet Gynaecol Res. Oct. 2006;32(5):475-81. X-1. [pmid: 16984514].
4908 Shaffer BL, Cheng YW, Vargas JE, et al. Manual rotation to reduce caesarean delivery in persistent occiput posterior or transverse position. J Matern Fetal Neonatal Med. Jan. 2011;24(1):65-72. X-1. [pmid: 20350240].
4909 Shaffer TH, Lowe CA, Bhutani VK, et al. Liquid ventilation: effects on pulmonary function in distressed meconium-stained lambs. Pediatr Res. Jan. 1984;18(1):47-52. X-1. [pmid: 6422432].
4910 Shah M, Wright JD. Surgical intervention in the management of postpartum hemorrhage. Semin Perinatol. Apr. 2009;33(2):109-15. X-2. [pmid: 19324240].
4911 Shah MA, Williams DR. Cesarean section on demand: round one. J Midwifery Womens Health. Mar-Apr. 2004;49(2):85-6. X-1, X-2. [pmid: 15010659].
4912 Shah S, Mazher Y, John IS. Single or triple dose piperacillin prophylaxis in elective cesarean section. Int J Gynaecol Obstet. Jul. 1998;62(1):23-9. X-9. [pmid: 9722121].
4913 Shaheen AA, Myers RP. The outcomes of pregnancy in patients with cirrhosis: a population-based study. Liver Int. Feb. 2010;30(2):275-83. X-1. [pmid: 19874491].
4914 Shahin AY, Farghaly TA, Mohamed SA, et al. Bilateral uterine artery ligation plus B-Lynch procedure for atonic postpartum hemorrhage with placenta accreta. Int J Gynaecol Obstet. Mar. 2010;108(3):187-90. X-1. [pmid: 19944417].
4915 Shahin AY, Osman AM. Parietal peritoneal closure and persistent postcesarean pain. Int J Gynaecol Obstet. Feb. 2009;104(2):135-9. X-9. [pmid: 19022441].
4916 Shahin AY, Osman AM. Intraperitoneal lidocaine instillation and postcesarean pain after parietal peritoneal closure: a randomized double blind placebo-controlled trial. Clin J Pain. Feb. 2010;26(2):121-7. X-9. [pmid: 20090438].
4917 Shahriari A, Khooshideh M. Intrathecal fentanyl added to lidocaine for Cesarean delivery under spinal anesthesia--a randomised clinical trial. Middle East J Anesthesiol. Jun. 2007;19(2):397-406. X-9. [pmid: 17684879].
4918 Shahriari A, Khooshideh M, Heidari MH. Prevention of nausea and vomiting in caesarean section under spinal anaesthesia with midazolam or metoclopramide?. J Pak Med Assoc. Nov. 2009;59(11):756-9. X-9. [pmid: 20361674].
4919 Shaikh JM, Memon A, Memon MA, et al. Post dural puncture headache after spinal anaesthesia for caesarean section: a comparison of 25 g Quincke, 27 g Quincke and 27 g Whitacre spinal needles. J Ayub Med Coll Abbottabad. Jul-Sep. 2008;20(3):10-3. X-9. [pmid: 19610505].
4920 Shakur H, Elbourne D, Gulmezoglu M, et al. The WOMAN Trial (World Maternal Antifibrinolytic Trial): tranexamic acid for the treatment of postpartum haemorrhage: an international randomised, double blind placebo controlled trial. Trials. 2010;11:40. X-1, X-4e, X-5. [pmid: 20398351].
4921 Shakya A, Sharma J. Comparison of single versus multiple doses of antibiotic prophylaxis in reducing post-elective Caesarean section infectious morbidity. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2010;8(30):179-84. X-1. [pmid: 21209531].
4922 Shakya R, Shrestha J, Thapa P. Safety and efficacy of misoprostol and dinoprostone as cervical ripening agents. JNMA J Nepal Med Assoc. Jan-Mar. 2010;49(177):33-7. X-1. [pmid: 21180218].
4923 Shallow H. The caesarean section debate: reclaiming childbirth -- some thoughts from a midwife. Midwifery Matters. 2004;(101):13-14. X-1.
4924 Shalloway PB. Learning from the patient's view. Adv Nurse Pract. Mar. 1999;7(3):95. X-1, X-2, X-3, X-4e, X-5. [pmid: 10373807].
4925 Shammas AG, Momani MD. Misoprostol for termination of second trimester pregnancy in a scarred uterus. Saudi Med J. Aug. 2006;27(8):1173-6. X-1. [pmid: 16883447].
4926 Shanklin DR, Sibai BM. Ultrastructural aspects of preeclampsia. II. Mitochondrial changes. Am J Obstet Gynecol. Sep. 1990;163(3):943-53. X-1. [pmid: 2403173].
4927 Shao J, Catalano PM, Yamashita H, et al. Vanadate enhances but does not normalize glucose transport and insulin receptor phosphorylation in skeletal muscle from obese women with gestational diabetes mellitus. Am J Obstet Gynecol. Nov. 2000;183(5):1263-70. X-1. [pmid: 11084576].
4928 Shao J, Catalano PM, Yamashita H, et al. Decreased insulin receptor tyrosine kinase activity and plasma cell membrane glycoprotein-1 overexpression in skeletal muscle from obese women with gestational diabetes mellitus (GDM): evidence for increased serine/threonine phosphorylation in pregnancy and GDM. Diabetes. Apr. 2000;49(4):603-10. X-1. [pmid: 10871198].
4929 Shapira S, Goldberger S, Beyth Y, et al. Induced second trimester abortion by extra-amniotic prostaglandin infusion in patients with a cesarean scar: is it safe?. Acta Obstet Gynecol Scand. Jul. 1999;78(6):511-4. X-1. [pmid: 10376860].
4930 Shapiro S. Epidemiologic evaluation of large-scale perinatal programs. Mead Johnson Symp Perinat Dev Med. 1982;(20):13-21. X-1. [pmid: 6927514].
4931 Sharami SH, Milani F, Zahiri Z, et al. A randomized trial of prostaglandin E2 gel and extra-amniotic saline infusion with high dose oxytocin for cervical ripening. Med Sci Monit. Aug. 2005;11(8):CR381-6. X-4d, X-5. [pmid: 16049380].
4932 Sharar SR, Ready LB, Ross BK, et al. A comparison of postcesarean epidural morphine analgesia by single injection and by continuous infusion. Reg Anesth. Jul-Aug. 1991;16(4):232-5. X-9. [pmid: 1911501].
4933 Sharf M, Eibschitz I, Hakim M, et al. Is serum free estriol measurement essential in the management of hypertensive disorders during pregnancy?. Eur J Obstet Gynecol Reprod Biol. Aug. 1984;17(6):365-75. X-1, X-4e, X-5. [pmid: 6386561].
4934 Sharkey A, Gulden RH, Lipton JM, et al. Effect of radiant heat on the metabolic cost of postoperative shivering. Br J Anaesth. Apr. 1993;70(4):449-50. X-9. [pmid: 8499207].
4935 Sharma K, Batra YK, Singh H. Effect of decreased cerebrospinal fluid proteins on the spread of local anaesthetic drugs in pregnancy. Indian J Med Res. Jun. 1990;92:175-7. X-4e. [pmid: 2401538].
4936 Sharma PS, Eden KB, Guise JM, et al. Subjective risk vs. objective risk can lead to different post-cesarean birth decisions based on multiattribute modeling. J Clin Epidemiol. Jan. 2011;64(1):67-78. X-1. [pmid: 20558035].
4937 Sharma R, Nandi D, Shukla I, et al. Effect of pregnancy associated hypertension on immunoglobulin levels in newborns. Indian Pediatr. May. 1992;29(5):581-6. X-1. [pmid: 1500106].
4938 Sharma SK, Alexander JM, Messick G, et al. Cesarean delivery: a randomized trial of epidural analgesia versus intravenous meperidine analgesia during labor in nulliparous women. Anesthesiology. Mar. 2002;96(3):546-51. X-4e, X-5. [pmid: 11873026].
4939 Sharma SK, Sidawi JE, Ramin SM, et al. Cesarean delivery: a randomized trial of epidural versus patient-controlled meperidine analgesia during labor. Anesthesiology. Sep. 1997;87(3):487-94. X-4e, X-5. [pmid: 9316951].
4940 Shaxted EJ, Heyes VM, Walker MP, et al. Umbilical-cord plasma progesterone in term infants delivered by caesarean section. Br J Obstet Gynaecol. Jan. 1982;89(1):73-6. X-1. [pmid: 7059549].
4941 Shearer VE, Ramin SM, Wallace DH, et al. Fetal effects of prophylactic ephedrine and maternal hypotension during regional anesthesia for cesarean section. J Matern Fetal Med. Mar-Apr. 1996;5(2):79-84. X-9. [pmid: 8796773].
4942 Sheffield JS, Hill JB, Hollier LM, et al. Valacyclovir prophylaxis to prevent recurrent herpes at delivery: a randomized clinical trial. Obstet Gynecol. Jul. 2006;108(1):141-7. X-4e. [pmid: 16816068].
4943 Sheiner E, Abramowicz JS, Levy A, et al. Nuchal cord is not associated with adverse perinatal outcome. Arch Gynecol Obstet. May. 2006;274(2):81-3. X-1. [pmid: 16374604].
4944 Sheiner E, Bashiri A, Levy A, et al. Obstetric characteristics and perinatal outcome of pregnancies with uterine leiomyomas. J Reprod Med. Mar. 2004;49(3):182-6. X-1. [pmid: 15098887].
4945 Sheiner E, Levy A, Feinstein U, et al. Risk factors and outcome of failure to progress during the first stage of labor: a population-based study. Acta Obstet Gynecol Scand. Mar. 2002;81(3):222-6. X-1. [pmid: 11966478].
4946 Sheiner E, Levy A, Katz M, et al. Gender does matter in perinatal medicine. Fetal Diagn Ther. Jul-Aug. 2004;19(4):366-9. X-1. [pmid: 15192298].
4947 Sheiner E, Levy A, Katz M, et al. Identifying risk factors for peripartum cesarean hysterectomy. A population-based study. J Reprod Med. Aug. 2003;48(8):622-6. X-1. [pmid: 12971143].
4948 Sheiner E, Levy A, Katz M, et al. Pregnancy outcome following recurrent spontaneous abortions. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2005;118(1):61-5. X-1. [pmid: 15596274].
4949 Sheiner E, Levy A, Mazor M. Precipitate labor: higher rates of maternal complications. Eur J Obstet Gynecol Reprod Biol. Sep. 10. 2004;116(1):43-7. X-1. [pmid: 15294366].
4950 Sheiner E, Levy A, Menes TS, et al. Maternal obesity as an independent risk factor for caesarean delivery. Paediatr Perinat Epidemiol. May. 2004;18(3):196-201. X-1. [pmid: 15130159].
4951 Sheiner E, Levy A, Silverberg D, et al. Pregnancy after bariatric surgery is not associated with adverse perinatal outcome. Am J Obstet Gynecol. May. 2004;190(5):1335-40. X-1. [pmid: 15167839].
4952 Sheiner E, Mazor M, Levy A, et al. Pregnancy outcome of asthmatic patients: a population-based study. J Matern Fetal Neonatal Med. Oct. 2005;18(4):237-40. X-1. [pmid: 16318973].
4953 Sheiner E, Segal D, Shoham-Vardi I, et al. The impact of early amniotomy on mode of delivery and pregnancy outcome. Arch Gynecol Obstet. Sep. 2000;264(2):63-7. X-1. [pmid: 11045324].
4954 Sheiner E, Shoham-Vardi I, Hershkovitz R, et al. Infertility treatment is an independent risk factor for cesarean section among nulliparous women aged 40 and above. Am J Obstet Gynecol. Oct. 2001;185(4):888-92. X-1. [pmid: 11641672].
4955 Sheiner E, Shoham-Vardi I, Silberstein T, et al. Failed vacuum extraction. Maternal risk factors and pregnancy outcome. J Reprod Med. Sep. 2001;46(9):819-24. X-1. [pmid: 11584484].
4956 Shellhaas CS, Gilbert S, Landon MB, et al. The frequency and complication rates of hysterectomy accompanying cesarean delivery. Obstet Gynecol. Aug. 2009;114(2 Pt 1):224-9. X-1. [pmid: 19622981].
4957 Shen JJ, Tymkow C, MacMullen N. Disparities in maternal outcomes among four ethnic populations. Ethn Dis. Summer. 2005;15(3):492-7. X-1. [pmid: 16108310].
4958 Shende D, Cooper GM, Bowden MI. The influence of intrathecal fentanyl on the characteristics of subarachnoid block for caesarean section. Anaesthesia. Jul. 1998;53(7):706-10. X-9. [pmid: 9771182].
4959 Sherer DM, Menashe M, Ron M. Measures to enhance performance of an atraumatic cesarean section in prematurity. Am J Perinatol. Jan. 1989;6(1):22-3. X-1, X-2. [pmid: 2910314].
4960 Sherer DM, Onyeije CI, Binder D, et al. Uncomplicated baseline fetal tachycardia or bradycardia in postterm pregnancies and perinatal outcome. Am J Perinatol. May. 1998;15(5):335-8. X-1. [pmid: 9643641].
4961 Sheriff MH, Hardman M, Lamont CA, et al. Successful pregnancy in a 44-year-old haemodialysis patient. Br J Obstet Gynaecol. May. 1978;85(5):386-9. X-1. [pmid: 646973].
4962 Sherline DM. Picenadol (LY 150720) compared with meperidine and placebo for relief of post-cesarean section pain: a randomized double-blind study. Am J Obstet Gynecol. Oct. 15. 1983;147(4):404-6. X-9. [pmid: 6624809].
4963 Sherman D, Lurie S, Betzer M, et al. Uterine flora at cesarean and its relationship to postpartum endometritis. Obstet Gynecol. Nov. 1999;94(5 Pt 1):787-91. X-1. [pmid: 10546730].
4964 Sheth SS, Malpani AN. Vaginal hysterectomy following previous cesarean section. Int J Gynaecol Obstet. Aug. 1995;50(2):165-9. X-1. [pmid: 7589752].
4965 Shetty A, Burt R, Rice P, et al. Women's perceptions, expectations and satisfaction with induced labour--a questionnaire-based study. Eur J Obstet Gynecol Reprod Biol. Nov. 1. 2005;123(1):56-61. X-1. [pmid: 15905017].
4966 Shetty A, Danielian P, Templeton A. A comparison of oral and vaginal misoprostol tablets in induction of labour at term. BJOG. Mar. 2001;108(3):238-43. X-4d. [pmid: 11281461].
4967 Shetty A, Danielian P, Templeton A. Sublingual misoprostol for the induction of labor at term. Am J Obstet Gynecol. Jan. 2002;186(1):72-6. X-4d. [pmid: 11810088].
4968 Shetty A, Martin R, Danielian P, et al. A comparison of two dosage regimens of oral misoprostol for labor induction at term. Acta Obstet Gynecol Scand. Apr. 2002;81(4):337-42. X-4d. [pmid: 11952465].
4969 Sheybany S, Murphy JF, Evans D, et al. Ritodrine in the management of fetal distress. Br J Obstet Gynaecol. Sep. 1982;89(9):723-6. X-1. [pmid: 7115635].
4970 Shi JJ, Wang YP, Sun WZ, et al. The effect of low dose propofol for prevention of nausea and vomiting during spinal anesthesia for cesarean section. Acta Anaesthesiol Sin. Jun. 1994;32(2):95-8. X-9. [pmid: 8038981].
4971 Shibli KU, Dhillon AR, Goode JA, et al. Effect of intrathecal fentanyl on oxytocin secretion in pregnant women not in labour. Clin Sci (Lond). Oct. 2001;101(4):415-9. X-9. [pmid: 11566079].
4972 Shime J, Gare DJ, Andrews J, et al. Prolonged pregnancy: surveillance of the fetus and the neonate and the course of labor and delivery. Am J Obstet Gynecol. Mar. 1. 1984;148(5):547-52. X-1, X-4e, X-5. [pmid: 6702916].
4973 Shimizu I, Makino H, Imagawa A, et al. Clinical and immunogenetic characteristics of fulminant type 1 diabetes associated with pregnancy. J Clin Endocrinol Metab. Feb. 2006;91(2):471-6. X-1. [pmid: 16278271].
4974 Shimoni Z, Kama N, Mamet Y, et al. Empowering surgical nurses improves compliance rates for antibiotic prophylaxis after caesarean birth. J Adv Nurs. Nov. 2009;65(11):2345-9. X-1. [pmid: 19761458].
4975 Shimonovitz S, Botosneano A, Hochner-Celnikier D. Successful first vaginal birth after cesarean section: a predictor of reduced risk for uterine rupture in subsequent deliveries. Isr Med Assoc J. Jul. 2000;2(7):526-8. X-1. [pmid: 10979328].
4976 Shin YK, Kim YD, Collea JV. The effect of propofol on isolated human pregnant uterine muscle. Anesthesiology. Jul. 1998;89(1):105-9. X-1. [pmid: 9667300].
4977 Shipp TD, Zelop C, Cohen A, et al. Post-cesarean delivery fever and uterine rupture in a subsequent trial of labor. Obstet Gynecol. Jan. 2003;101(1):136-9. X-1. [pmid: 12517658].
4978 Shipp TD, Zelop C, Repke JT, et al. The association of maternal age and symptomatic uterine rupture during a trial of labor after prior cesarean delivery. Obstet Gynecol. Apr. 2002;99(4):585-8. X-1. [pmid: 12039116].
4979 Shirazian T, Monteith S, Friedman F, et al. Lifestyle modification program decreases pregnancy weight gain in obese women. Am J Perinatol. May. 2010;27(5):411-4. X-1. [pmid: 20013602].
4980 Shirgaonkar AT, Purva M, Russell IF. A double blind comparison of the variability of block levels assessed using a hand help Neurotip or a Neuropen at elective caesarean section under spinal anaesthesia. Int J Obstet Anesth. Jan. 2010;19(1):61-6. X-1. [pmid: 19945276].
4981 Shmorgun D, Chan WS, Ray JG. Association between Bell's palsy in pregnancy and pre-eclampsia. QJM. Jun. 2002;95(6):359-62. X-1. [pmid: 12037243].
4982 Shnider SM, Sun H. Recent advances in spinal anesthesia for cesarean section. Current Reviews for Nurse Anesthetists. 1993;15(25):207-212. X-4b.
4983 Shoaib T, Khan S, Javed I, et al. Loading dose of magnesium sulphate versus standard regime for prophylaxis of pre-eclampsia. J Coll Physicians Surg Pak. Jan. 2009;19(1):30-3. X-1. [pmid: 19149977].
4984 Shoham I, Wiznitzer A, Silberstein T, et al. Gestational diabetes complicated by hydramnios was not associated with increased risk of perinatal morbidity and mortality. Eur J Obstet Gynecol Reprod Biol. Dec. 10. 2001;100(1):46-9. X-1. [pmid: 11728656].
4985 Shoker J. Obstructed labours. CMAJ. Jan. 15. 2008;178(2):141. X-1, X-2. [pmid: 18195282].
4986 Shorten A, Chamberlain M, Shorten B, et al. Making choices for childbirth: development and testing of a decision-aid for women who have experienced previous caesarean. Patient Educ Couns. Mar. 2004;52(3):307-13. X-1. [pmid: 14998601].
4987 Shorten A, Lewis DE, Shorten B. Trial of labour versus elective repeat caesarean section: a cost-effectiveness analysis. Aust Health Rev. 1998;21(1):8-28. X-1. [pmid: 10181675].
4988 Shorten A, Shorten B, Keogh J, et al. Making choices for childbirth: a randomized controlled trial of a decision-aid for informed birth after cesarean. Birth. Dec. 2005;32(4):252-61. X-4b. [pmid: 16336366].
4989 Shrestha NS, Singh N. Nuchal cord and perinatal outcome. Kathmandu Univ Med J (KUMJ). Jul-Sep. 2007;5(3):360-3. X-1. [pmid: 18604054].
4990 Shrim A, Levin I, Mallozzi A, et al. Does very advanced maternal age, with or without egg donation, really increase obstetric risk in a large tertiary center?. J Perinat Med. Nov. 2010;38(6):645-50. X-1. [pmid: 20707613].
4991 Shrivastava V, Nageotte M, Major C, et al. Case-control comparison of cesarean hysterectomy with and without prophylactic placement of intravascular balloon catheters for placenta accreta. Am J Obstet Gynecol. Oct. 2007;197(4):402 e1-5. X-1. [pmid: 17904978].
4992 Shrivastava VK, Garite TJ, Jenkins SM, et al. A randomized, double-blinded, controlled trial comparing parenteral normal saline with and without dextrose on the course of labor in nulliparas. Am J Obstet Gynecol. Apr. 2009;200(4):379 e1-6. X-5. [pmid: 19217592].
4993 Shuaib AA, Frass KA, Al-Harazi AH, et al. Pregnancy outcomes of mothers aged 17 years or less. Saudi Med J. Feb. 2011;32(2):166-70. X-1. [pmid: 21301764].
4994 Shuiqing M, Xuming B, Jinghe L. Pregnancy and its outcome in women with malformed uterus. Chin Med Sci J. Dec. 2002;17(4):242-5. X-1. [pmid: 12901513].
4995 Sia AT, Lim Y, Lim EC, et al. A118G single nucleotide polymorphism of human mu-opioid receptor gene influences pain perception and patient-controlled intravenous morphine consumption after intrathecal morphine for postcesarean analgesia. Anesthesiology. Sep. 2008;109(3):520-6. X-1. [pmid: 18719451].
4996 Sia AT, Sng BL, Lim EC, et al. The influence of ATP-binding cassette sub-family B member -1 (ABCB1) genetic polymorphisms on acute and chronic pain after intrathecal morphine for caesarean section: a prospective cohort study. Int J Obstet Anesth. Jul. 2010;19(3):254-60. X-1. [pmid: 20627697].
4997 Sia AT, Thomas E, Chong JL, et al. Combination of suppository diclofenac and intravenous morphine infusion in post-caesarean section pain relief--a step towards balanced analgesia?. Singapore Med J. Feb. 1997;38(2):68-70. X-9. [pmid: 9269364].
4998 Sia WW, Powrie RO, Cooper AB, et al. The incidence of deep vein thrombosis in women undergoing cesarean delivery. Thromb Res. 2009;123(3):550-5. X-1, X-3, X-4e. [pmid: 18706683].
4999 Sibai BM, Mercer BM, Schiff E, et al. Aggressive versus expectant management of severe preeclampsia at 28 to 32 weeks' gestation: a randomized controlled trial. Am J Obstet Gynecol. Sep. 1994;171(3):818-22. X-4e, X-5. [pmid: 8092235].
5000 Sibanda N, Briggs JD, Davison JM, et al. Pregnancy after organ transplantation: a report from the UK Transplant pregnancy registry. Transplantation. May. 27. 2007;83(10):1301-7. X-1. [pmid: 17519778].
5001 Siddik SM, Aouad MT, Jalbout MI, et al. Diclofenac and/or propacetamol for postoperative pain management after cesarean delivery in patients receiving patient controlled analgesia morphine. Reg Anesth Pain Med. Jul-Aug. 2001;26(4):310-5. X-9. [pmid: 11464348].
5002 Siddik SM, Aouad MT, Kai GE, et al. Hydroxyethylstarch 10% is superior to Ringer's solution for preloading before spinal anesthesia for Cesarean section. Can J Anaesth. Jul. 2000;47(7):616-21. X-9. [pmid: 10930199].
5003 Siddik-Sayyid S, Aouad-Maroun M, Sleiman D, et al. Epidural tramadol for postoperative pain after Cesarean section. Can J Anaesth. Aug. 1999;46(8):731-5. X-9. [pmid: 10451131].
5004 Siddik-Sayyid SM, Aouad MT, Jalbout MI, et al. Intrathecal versus intravenous fentanyl for supplementation of subarachnoid block during cesarean delivery. Anesth Analg. Jul. 2002;95(1):209-13. table of contents. X-9. [pmid: 12088970].
5005 Siddik-Sayyid SM, Aouad MT, Jalbout MI, et al. Comparison of three modes of patient-controlled epidural analgesia during labour. Eur J Anaesthesiol. Jan. 2005;22(1):30-4. X-4e. [pmid: 15816570].
5006 Siddik-Sayyid SM, Aouad MT, Taha SK, et al. Does ondansetron or granisetron prevent subarachnoid morphine-induced pruritus after cesarean delivery?. Anesth Analg. Feb. 2007;104(2):421-4. X-9. [pmid: 17242102].
5007 Siddik-Sayyid SM, Nasr VG, Taha SK, et al. A randomized trial comparing colloid preload to coload during spinal anesthesia for elective cesarean delivery. Anesth Analg. Oct. 2009;109(4):1219-24. X-9. [pmid: 19641050].
5008 Siddik-Sayyid SM, Yazbeck-Karam VG, Zahreddine BW, et al. Ondansetron is as effective as diphenhydramine for treatment of morphine-induced pruritus after cesarean delivery. Acta Anaesthesiol Scand. Jul. 2010;54(6):764-9. X-9. [pmid: 20236094].
5009 Siddiqi R, Jafri SA. Maternal satisfaction after spinal anaesthesia for caesarean deliveries. J Coll Physicians Surg Pak. Feb. 2009;19(2):77-80. X-1. [pmid: 19208308].
5010 Siddiqui D, Stiller RJ, Collins J, et al. Pregnancy outcome after successful external cephalic version. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1092-5. X-1. [pmid: 10561624].
5011 Siddiqui M, Goldszmidt E, Fallah S, et al. Complications of exteriorized compared with in situ uterine repair at cesarean delivery under spinal anesthesia: a randomized controlled trial. Obstet Gynecol. Sep. 2007;110(3):570-5. X-9. [pmid: 17766602].
5012 Sidenvall R, Heijbel J, Blomquist HK, et al. An incident case-control study of first unprovoked afebrile seizures in children: a population-based study of pre- and perinatal risk factors. Epilepsia. Oct. 2001;42(10):1261-5. X-1. [pmid: 11737160].
5013 Sidorenko VN. Clinical application of Medical Resonance Therapy Music in high-risk pregnancies. Integr Physiol Behav Sci. Jul-Sep. 2000;35(3):199-207. X-1. [pmid: 11286372].
5014 Sieroszewski P, Jasinski A, Perenc M, et al. The Arabin pessary for the treatment of threatened mid-trimester miscarriage or premature labour and miscarriage: a case series. J Matern Fetal Neonatal Med. Jun. 2009;22(6):469-72. X-1. [pmid: 19530009].
5015 Sifakis S, Angelakis E, Makrigiannakis A, et al. Chemoprophylactic and bactericidal efficacy of 80 mg gentamicin in a single and once--daily dosing. Arch Gynecol Obstet. Sep. 2005;272(3):201-6. X-1. [pmid: 15605270].
5016 Siggelkow W, Boehm D, Skala C, et al. The influence of macrosomia on the duration of labor, the mode of delivery and intrapartum complications. Arch Gynecol Obstet. Dec. 2008;278(6):547-53. X-1. [pmid: 18379807].
5017 Signore C, Hemachandra A, Klebanoff M. Neonatal mortality and morbidity after elective cesarean delivery versus routine expectant management: a decision analysis. Semin Perinatol. Oct. 2006;30(5):288-95. X-1, X-2. [pmid: 17011401].
5018 Signorelli C, Autelitano M, Bailo U, et al. Case-control study on risk factors for caesarean section: methodological issues. Ann Ig. Nov-Dec. 1991;3(6):347-54. X-1. [pmid: 1726626].
5019 Signorelli C, Cattaruzza MS, Osborn JF. Risk factors for caesarean section in Italy: results of a multicentre study. Public Health. May. 1995;109(3):191-9. X-1. [pmid: 7597132].
5020 Sikorski J, Wilson J, Clement S, et al. A randomised controlled trial comparing two schedules of antenatal visits: the antenatal care project. BMJ. Mar. 2. 1996;312(7030):546-53. X-5. [pmid: 8595286].
5021 Silasi M, Coonrod DV, Kim M, et al. Transient tachypnea of the newborn: is labor prior to cesarean delivery protective?. Am J Perinatol. Nov. 2010;27(10):797-802. X-1. [pmid: 20486067].
5022 Sills ES, Sweitzer CL, Morton PC, et al. Dizygotic twin delivery following in vitro fertilization and transfer of thawed blastocysts cryopreserved at day 6 and 7. Fertil Steril. Feb. 2003;79(2):424-7. X-1, X-2. [pmid: 12568858].
5023 Silva AA, Lamy-Filho F, Alves MT, et al. Risk factors for low birthweight in north-east Brazil: the role of caesarean section. Paediatr Perinat Epidemiol. Jul. 2001;15(3):257-64. X-1. [pmid: 11489154].
5024 Silva DA, Singh PP, Bauman J, et al. Acute hypertensive response to prostaglandin F2 alpha during anesthesia administration. A case report. J Reprod Med. Sep. 1987;32(9):700-2. X-1, X-2. [pmid: 3478491].
5025 Silver RM, Landon MB, Rouse DJ, et al. Maternal morbidity associated with multiple repeat cesarean deliveries. Obstet Gynecol. Jun. 2006;107(6):1226-32. X-1. [pmid: 16738145].
5026 Silverman JA, Barrett J, Callum JL. The appropriateness of red blood cell transfusions in the peripartum patient. Obstet Gynecol. Nov. 2004;104(5 Pt 1):1000-4. X-1. [pmid: 15516391].
5027 Silverman NH, Schmidt KG. Ventricular volume overload in the human fetus: observations from fetal echocardiography. J Am Soc Echocardiogr. Jan-Feb. 1990;3(1):20-9. X-1. [pmid: 2310588].
5028 Simbar M, Karimian Z, Afrakhteh M, et al. Increased risk of pre-eclampsia (PE) among women with the history of migraine. Clin Exp Hypertens. May. 2010;32(3):159-65. X-1. [pmid: 20504123].
5029 Simetka O, Reilley B, Joseph M, et al. Obstetrics during Civil War: six months on a maternity ward in Mallavi, northern Sri Lanka. Med Confl Surviv. Jul-Sep. 2002;18(3):258-70. X-1. [pmid: 12201084].
5030 Simhayoff N, Sheiner E, Levy A, et al. To induce or not to induce labor: a macrosomic dilemma. Gynecol Obstet Invest. 2004;58(3):121-5. X-1. [pmid: 15467303].
5031 Simini F, Maillard F, Breart G. Cesarean section odds ratios. Eur J Obstet Gynecol Reprod Biol. Jan-Feb. 1990;34(1-2):1-13. X-1. [pmid: 2406165].
5032 Simmer HH, Frankland M, Greipel M. On the regulation of fetal and maternal 16 alpha- hydroxydehydroepiandrosterone and its sulfate by cortisol and ACTH in human pregnancy at term. Am J Obstet Gynecol. Mar. 1. 1975;121(5):646-52. X-1. [pmid: 163590].
5033 Simmer K, Lort-Phillips L, James C, et al. A double-blind trial of zinc supplementation in pregnancy. Eur J Clin Nutr. Mar. 1991;45(3):139-44. X-4e, X-5. [pmid: 2065637].
5034 Simmons D, Conroy C, Scott DJ. Impact of a diabetes midwifery educator on the diabetes in pregnancy service at Middlemore Hospital. Practical Diabetes International. 2001;18(4):119-122. X-1.
5035 Simms-Stewart D, Thame M, Hemans-Keen A, et al. Retained placenta in homozygous sickle cell disease. Obstet Gynecol. Oct. 2009;114(4):825-8. X-1. [pmid: 19888041].
5036 Simoes T, Aboim L, Costa A, et al. Puerperal complications following elective Cesarean sections for twin pregnancies. J Perinat Med. 2007;35(2):104-7. X-1. [pmid: 17302518].
5037 Simoes T, Condeco P, Dias E, et al. Induction of labor with oral misoprostol in nulliparous mothers of twins. J Perinat Med. 2006;34(2):111-4. X-1. [pmid: 16519614].
5038 Simon L, Provenchere S, de Saint Blanquat L, et al. Dose of prophylactic intravenous ephedrine during spinal anesthesia for cesarean section. J Clin Anesth. Aug. 2001;13(5):366-9. X-1. [pmid: 11498318].
5039 Simonson DC, Ahern MM, Hendryx MS. Anesthesia staffing and anesthetic complications during cesarean delivery: a retrospective analysis. Nurs Res. Jan-Feb. 2007;56(1):9-17. X-1. [pmid: 17179869].
5040 Simpkin JC, Kermani F, Palmer AM, et al. Effects of corticotrophin releasing hormone on contractile activity of myometrium from pregnant women. Br J Obstet Gynaecol. May. 1999;106(5):439-45. X-1. [pmid: 10430194].
5041 Simpson EL, Lawrenson RA, Nightingale AL, et al. Venous thromboembolism in pregnancy and the puerperium: incidence and additional risk factors from a London perinatal database. BJOG. Jan. 2001;108(1):56-60. X-1. [pmid: 11213005].
5042 Simpson KH, Madej TH, McDowell JM, et al. Comparison of extradural buprenorphine and extradural morphine after caesarean section. Br J Anaesth. May. 1988;60(6):627-31. X-9. [pmid: 3377946].
5043 Simpson KR. Surgical safety: minimizing risk of retained foreign bodies during cesarean birth. MCN Am J Matern Child Nurs. May-Jun. 2007;32(3):200. X-9. [pmid: 17479066].
5044 Simpson KR. Reconsideration of the costs of convenience: quality, operational, and fiscal strategies to minimize elective labor induction. J Perinat Neonatal Nurs. Jan-Mar. 2010;24(1):43-52. quiz 53-4. X-1. [pmid: 20147829].
5045 Sinatra R, Chung KS, Silverman DG, et al. An evaluation of morphine and oxymorphone administered via patient-controlled analgesia (PCA) or PCA plus basal infusion in postcesarean-delivery patients. Anesthesiology. Oct. 1989;71(4):502-7. X-9. [pmid: 2478049].
5046 Sinatra RS, Lodge K, Sibert K, et al. A comparison of morphine, meperidine, and oxymorphone as utilized in patient-controlled analgesia following cesarean delivery. Anesthesiology. Apr. 1989;70(4):585-90. X-9. [pmid: 2467588].
5047 Sindhvananda W, Leelanukrom R, Rodanant O, et al. Maternal satisfaction to epidural and spinal anesthesia for cesarean section. J Med Assoc Thai. Jun. 2004;87(6):628-35. X-9. [pmid: 15279340].
5048 Singh SI, Morley-Forster PK, Shamsah M, et al. Influence of injection rate of hyperbaric bupivacaine on spinal block in parturients: a randomized trial. Can J Anaesth. Apr. 2007;54(4):290-5. X-9. [pmid: 17400981].
5049 Siristatidis C, Salamalekis E, Vitoratos N, et al. Intrapartum surveillance of IUGR fetuses with cardiotocography and fetal pulse oximetry. Biol Neonate. 2003;83(3):162-5. X-1. [pmid: 12660431].
5050 Siti Salmah G, Choy YC. Comparison of morphine with fentanyl added to intrathecal 0.5% hyperbaric bupivacaine for analgesia after caesarean section. Med J Malaysia. Mar. 2009;64(1):71-4. X-9. [pmid: 19852327].
5051 Sitras V, Paulssen RH, Gronaas H, et al. Gene expression profile in labouring and non-labouring human placenta near term. Mol Hum Reprod. Jan. 2008;14(1):61-5. X-1. [pmid: 18048457].
5052 Sivaganesh S, Senarath U. Prevalence of antenatal risk conditions among women in an underserved district of Northern Sri Lanka. Ceylon Med J. Dec. 2009;54(4):110-4. X-1. [pmid: 20052851].
5053 Sivasubramaniam S, Paul J. Thromboprophylaxis in pregnancy: do we need new guidelines?. Internet Journal of Anesthesiology. 2008;17(2):12-12. X-1.
5054 Sivevski A. Spinal anaesthesia for cesarean section with reduced dose of intrathecal bupivacaine plus fentanyl. Prilozi. Dec. 2006;27(2):225-36. X-9. [pmid: 17211305].
5055 Skalkidis Y, Petridou E, Papathoma E, et al. Are operative delivery procedures in Greece socially conditioned?. Int J Qual Health Care. Apr. 1996;8(2):159-65. X-1. [pmid: 8792171].
5056 Skarsgard ED, Claydon J, Bouchard S, et al. Canadian Pediatric Surgical Network: a population-based pediatric surgery network and database for analyzing surgical birth defects. The first 100 cases of gastroschisis. J Pediatr Surg. Jan. 2008;43(1):30-4. discussion 34. X-1. [pmid: 18206451].
5057 Skimming JW, DeMarco VG, Cassin S. The effects of nitric oxide inhalation on the pulmonary circulation of preterm lambs. Pediatr Res. Jan. 1995;37(1):35-40. X-1. [pmid: 7700732].
5058 Skinner J, Greene RA, Gardeil F, et al. Does increased resistance on umbilical artery Doppler preclude a trial of labour?. Eur J Obstet Gynecol Reprod Biol. Jul. 1998;79(1):35-8. X-1. [pmid: 9643400].
5059 Skoner MM, Thompson WD, Caron VA. Factors associated with risk of stress urinary incontinence in women. Nurs Res. Sep-Oct. 1994;43(5):301-6. X-1. [pmid: 7937177].
5060 Skret-Magierlo J, Wicherek L, Basta P, et al. RCAS1 decidual immunoreactivity during cesarean section in scar deciduosis: immune cell presence and activity. Gynecol Obstet Invest. 2008;65(3):187-94. X-1. [pmid: 18032910].
5061 Skull AJ, Slater GH, Duncombe JE, et al. Laparoscopic adjustable banding in pregnancy: safety, patient tolerance and effect on obesity-related pregnancy outcomes. Obes Surg. Feb. 2004;14(2):230-5. X-1. [pmid: 15018752].
5062 Skupski DW, Abramovitz S, Samuels J, et al. Adverse effects of combined spinal-epidural versus traditional epidural analgesia during labor. Int J Gynaecol Obstet. Sep. 2009;106(3):242-5. X-4e, X-5. [pmid: 19481203].
5063 Skupski DW, Harrison-Restelli C, Dupont RB. External cephalic version: an approach with few complications. Gynecol Obstet Invest. 2003;56(2):83-8. X-1. [pmid: 12920344].
5064 Slattery MM, Brennan C, O'Leary MJ, et al. Human chorionic gonadotrophin inhibition of pregnant human myometrial contractility. BJOG. Jul. 2001;108(7):704-8. X-1. [pmid: 11467695].
5065 Slattery MM, Friel AM, Healy DG, et al. Uterine relaxant effects of cyclooxygenase-2 inhibitors in vitro. Obstet Gynecol. Oct. 2001;98(4):563-9. X-1. [pmid: 11576568].
5066 Slavotinek A, Hellen E, Gould S, et al. Three infants of diabetic mothers with malformations of left-right asymmetry--further evidence for the aetiological role of diabetes in this malformation spectrum. Clin Dysmorphol. Jul. 1996;5(3):241-7. X-1. [pmid: 8818453].
5067 Sleutel MR. Intrapartum nursing care: a case study of supportive interventions and ethical conflicts. Birth. Mar. 2000;27(1):38-45. X-1. [pmid: 10865559].
5068 Sloan FA, Conover CJ, Mah ML, et al. Impact of medicaid managed care on utilization of obstetric care: evidence from TennCare's early years. South Med J. Aug. 2002;95(8):811-21. X-1. [pmid: 12190214].
5069 Small M, Cassidy L, Leiper JM, et al. Outcome of pregnancy in insulin-dependent (type 1) diabetic women between 1971 and 1984. Q J Med. Dec. 1986;61(236):1159-69. X-1. [pmid: 3310067].
5070 Small R, Lumley J, Donohue L, et al. Randomised controlled trial of midwife led debriefing to reduce maternal depression after operative childbirth. BMJ. Oct. 28. 2000;321(7268):1043-7. X-4e. [pmid: 11053173].
5071 Smarason AK, Sargent IL, Starkey PM, et al. The effect of placental syncytiotrophoblast microvillous membranes from normal and pre-eclamptic women on the growth of endothelial cells in vitro. Br J Obstet Gynaecol. Oct. 1993;100(10):943-9. X-1. [pmid: 8217980].
5072 Smedstad KG, Morison DH. A comparative study of continuous and intermittent epidural analgesia for labour and delivery. Can J Anaesth. May. 1988;35(3 ( Pt 1)):234-41. X-4e, X-5. [pmid: 3289768].
5073 Smeeton NC, Rona RJ, Dobson P, et al. Assessing the determinants of stillbirths and early neonatal deaths using routinely collected data in an inner city area. BMC Med. Jul. 6. 2004;2:27. X-1. [pmid: 15238165].
5074 Smith BL, Martin JA, Ventura SJ. Births and deaths: preliminary data for July 1997-June 1998. Natl Vital Stat Rep. Jul. 29. 1999;47(22):1-32. X-1.
5075 Smith C, Crowther C, Wilkinson C, et al. Knee-chest postural management for breech at term: a randomized controlled trial. Birth. Jun. 1999;26(2):71-5. X-4c. [pmid: 10687569].
5076 Smith CM, Guralnick MS, Gelfand MM, et al. The effects of transcutaneous electrical nerve stimulation on post-cesarean pain. Pain. Nov. 1986;27(2):181-93. X-9. [pmid: 3540813].
5077 Smith CV, Miller A, Livezey GT. Double-blind comparison of 2.5 and 5.0 mg of prostaglandin E2 gel for preinduction cervical ripening. J Reprod Med. Oct. 1996;41(10):745-8. X-4d, X-5. [pmid: 8913976].
5078 Smith CV, Rayburn WF, Connor RE, et al. Double-blind comparison of intravaginal prostaglandin E2 gel and “chip” for preinduction cervical ripening. Am J Obstet Gynecol. Sep. 1990;163(3):845-7. X-4d, X-5. [pmid: 2206072].
5079 Smith CV, Rayburn WF, Miller AM. Intravaginal prostaglandin E2 for cervical ripening and initiation of labor. Comparison of a multidose gel and single, controlled-release pessary. J Reprod Med. May. 1994;39(5):381-4. X-4d, X-5. [pmid: 8064705].
5080 Smith EA, Thorburn J, Duckworth RA, et al. A comparison of 25 G and 27 G Whitacre needles for caesarean section. Anaesthesia. Oct. 1994;49(10):859-62. X-9. [pmid: 7802179].
5081 Smith GC. Age at menarche and the risk of operative first delivery. BJOG. Nov. 2009;116(12):1613-21. X-1. [pmid: 19781050].
5082 Smith GC, Celik E, To M, et al. Cervical length at mid-pregnancy and the risk of primary cesarean delivery. N Engl J Med. Mar. 27. 2008;358(13):1346-53. X-1. [pmid: 18367737].
5083 Smith GC, White IR, Pell JP, et al. Predicting cesarean section and uterine rupture among women attempting vaginal birth after prior cesarean section. PLoS Med. Sep. 2005;2(9):e252. X-1. [pmid: 16146414].
5084 Smith ID, Klubien KE, Wood ML, et al. Diamorphine analgesia after caesarean section. Comparison of intramuscular and epidural administration of four dose regimens. Anaesthesia. Nov. 1991;46(11):970-3. X-9. [pmid: 1750603].
5085 Smith J, Mousa HA. Peripartum hysterectomy for primary postpartum haemorrhage: incidence and maternal morbidity. J Obstet Gynaecol. Jan. 2007;27(1):44-7. X-1. [pmid: 17365458].
5086 Smith JE, John E. Neonatal hypotension: two years' experience in a neonatal intensive care nursery. Aust Paediatr J. Sep. 1983;19(3):162-4. X-1. [pmid: 6651662].
5087 Smith KL, Baskett TF. Uterine compression sutures as an alternative to hysterectomy for severe postpartum hemorrhage. J Obstet Gynaecol Can. Mar. 2003;25(3):197-200. X-1. [pmid: 12610671].
5088 Smith LP, Nagourney BA, McLean FH, et al. Hazards and benefits of elective induction of labor. Am J Obstet Gynecol. Mar. 1. 1984;148(5):579-85. X-1. [pmid: 6538386].
5089 Smith S. NCHS dataline. Public Health Reports. 2006;121(2):208-210. X-1.
5090 Smith YR, Dombrowski MP, Leach KC, et al. Decrease in myometrial beta-adrenergic receptors with prenatal cocaine use. Obstet Gynecol. Mar. 1995;85(3):357-60. X-1. [pmid: 7862372].
5091 Smulian JC, Potash SK, Lai YL, et al. Appropriateness of antibiotic use in the postpartum period. J Matern Fetal Med. Oct. 2001;10(5):312-7. X-1. [pmid: 11730493].
5092 Snell P, Hicks C. An exploratory study in the UK of the effectiveness of three different pain management regimens for post-caesarean section women. Midwifery. Sep. 2006;22(3):249-61. X-9. [pmid: 16356609].
5093 Sng BL, Pay LL, Sia AT. Comparison of 2% lignocaine with adrenaline and fentanyl, 0.75% ropivacaine and 0.5% levobupivacaine for extension of epidural analgesia for urgent caesarean section after low dose epidural infusion during labour. Anaesth Intensive Care. Sep. 2008;36(5):659-64. X-9. [pmid: 18853583].
5094 Sng BL, Sia AT, Quek K, et al. Incidence and risk factors for chronic pain after caesarean section under spinal anaesthesia. Anaesth Intensive Care. Sep. 2009;37(5):748-52. X-1. [pmid: 19775038].
5095 Snooks SJ, Swash M, Henry MM, et al. Risk factors in childbirth causing damage to the pelvic floor innervation. Int J Colorectal Dis. Jan. 1986;1(1):20-4. X-1. [pmid: 3598309].
5096 Sobande AA, Al-Bar H, Archibong EI. Diabetes and perinatal loss. A continuing problem. Saudi Med J. Feb. 2000;21(2):161-3. X-1. [pmid: 11533773].
5097 Sobande AA, Albar HM. Outcome of induced labour in pregnancies at 41 weeks gestation and over in Saudi Arabia. East Mediterr Health J. May. 2003;9(3):316-23. X-1. [pmid: 15751924].
5098 Sobande AA, Al-Bar HM, Archibong EI. A comparison of spontaneous labor with induced vaginal tablets prostaglandin E2 in grand multiparae. Saudi Med J. Aug. 2001;22(8):698-701. X-1. [pmid: 11573116].
5099 Sobande AA, Archibong EI, Akinola SE. Pregnancy outcome in asthmatic patients from high altitudes. Int J Gynaecol Obstet. May. 2002;77(2):117-21. X-1. [pmid: 12031561].
5100 Sobande AA, Eskandar M, Archibong EI. Complications of pregnancy and foetal outcomes in pregnant diabetic patients managed in a tertiary hospital in Saudi Arabia. West Afr J Med. Jan-Mar. 2005;24(1):13-7. X-1. [pmid: 15909703].
5101 Soderstrom-Anttila V, Hovatta O. An oocyte donation program with goserelin down-regulation of voluntary donors. Acta Obstet Gynecol Scand. Apr. 1995;74(4):288-92. X-1. [pmid: 7732801].
5102 Soderstrom-Anttila V, Tiitinen A, Foudila T, et al. Obstetric and perinatal outcome after oocyte donation: comparison with in-vitro fertilization pregnancies. Hum Reprod. Feb. 1998;13(2):483-90. X-1. [pmid: 9557862].
5103 Solca M, Kolobow T, Huang HH, et al. Respiratory distress syndrome in immature lambs. Prevention through antenatal accelerated conditioning of the lung. Am Rev Respir Dis. Jun. 1984;129(6):979-84. X-1. [pmid: 6563874].
5104 Soliman SR, Burrows RF. Cesarean section: analysis of the experience before and after the National Consensus Conference on Aspects of Cesarean Birth. CMAJ. Apr. 15. 1993;148(8):1315-20. X-1. [pmid: 8462053].
5105 Somell C. Induction of labor and cervical ripening with oral PGE2 in risk pregnancies. A placebo-controlled study. Acta Obstet Gynecol Scand. 1987;66(7):633-7. X-4d. [pmid: 3326393].
5106 Sommerville F. Paying for choice in childbirth. Nurs Times. Jun. 2-8. 1999;95(22):20. X-1, X-2. [pmid: 10455703].
5107 Somrat C, Oranuch K, Ketchada U, et al. Optimal dose of nalbuphine for treatment of intrathecal-morphine induced pruritus after caesarean section. J Obstet Gynaecol Res. Jun. 1999;25(3):209-13. X-9. [pmid: 10467795].
5108 Sonnad SS, Moyer CA, Bernstein SJ. Comparing physician and administrator responses to cesarean section guidelines and actual practice. Jt Comm J Qual Improv. Sep. 2000;26(9):515-24. X-1. [pmid: 10983292].
5109 Sonntag B, Stolze B, Heinecke A, et al. Preterm birth but not mode of delivery is associated with an increased risk of developing inflammatory bowel disease later in life. Inflamm Bowel Dis. Nov. 2007;13(11):1385-90. X-1. [pmid: 17567873].
5110 Sood AK, Sorosky JI, Mayr N, et al. Cervical cancer diagnosed shortly after pregnancy: prognostic variables and delivery routes. Obstet Gynecol. Jun. 2000;95(6 Pt 1):832-8. X-1. [pmid: 10831976].
5111 Soontranan P, Chayachinda D, Thaworanun J. Position for administering an epidural block using a photograph as a visual aid in cesarean section patients. J Med Assoc Thai. Sep. Suppl 3. 2002;85:S830-6. X-9. [pmid: 12452219].
5112 Soper DE, Mayhall CG, Dalton HP. Risk factors for intraamniotic infection: a prospective epidemiologic study. Am J Obstet Gynecol. Sep. 1989;161(3):562-6. discussion 566-8. X-1. [pmid: 2782335].
5113 Sorensen SS, Brocks V, Lenstrup C. Induction of labor and cervical ripening by intracervical prostaglandin E2. Obstet Gynecol. Jan. 1985;65(1):110-4. X-4d. [pmid: 3880877].
5114 Sorensen SS, Trauelsen AG. Obstetric implications of minor mullerian anomalies in oligomenorrheic women. Am J Obstet Gynecol. May. 1987;156(5):1112-8. X-1. [pmid: 3578421].
5115 Soriano D, Dulitzki M, Keidar N, et al. Early oral feeding after cesarean delivery. Obstet Gynecol. Jun. 1996;87(6):1006-8. X-9. [pmid: 8649680].
5116 Sorkio S, Cuthbertson D, Barlund S, et al. Breastfeeding patterns of mothers with type 1 diabetes: results from an infant feeding trial. Diabetes Metab Res Rev. Mar. 2010;26(3):206-11. X-1. [pmid: 20474068].
5117 Sorokin Y, Blackwell S, Reinke T, et al. Demographic and intrapartum characteristics of term pregnancies with early-onset neonatal seizures. J Perinatol. Mar. 2001;21(2):90-2. X-1. [pmid: 11324366].
5118 Sorosky JI, Squatrito R, Ndubisi BU, et al. Stage I squamous cell cervical carcinoma in pregnancy: planned delay in therapy awaiting fetal maturity. Gynecol Oncol. Nov. 1995;59(2):207-10. X-1. [pmid: 7590474].
5119 Sosa CG, Balaguer E, Alonso JG, et al. Meperidine for dystocia during the first stage of labor: A randomized controlled trial. Am J Obstet Gynecol. Oct. 2004;191(4):1212-8. X-5, X-6. [pmid: 15507943].
5120 Sosa R, Kennell J, Klaus M, et al. The effect of a supportive companion on perinatal problems, length of labor, and mother-infant interaction. N Engl J Med. Sep. 11. 1980;303(11):597-600. X-1. [pmid: 7402234].
5121 Soundararajan N, Russell I. A randomised comparison of a hand-held Neurotip and the Neuropen for assessing loss of touch sensation during spinal anaesthesia for caesarean section. Int J Obstet Anesth. Jul. 2007;16(3):202-7. X-9. [pmid: 17337179].
5122 Souza JP, Cecatti JG, Faundes A, et al. Maternal near miss and maternal death in the World Health Organization's 2005 global survey on maternal and perinatal health. Bull World Health Organ. Feb. 2010;88(2):113-9. X-1. [pmid: 20428368].
5123 Spaans WA, van der Velde FH, van Roosmalen J. Trial of labour after previous caesarean section in rural Zimbabwe. Eur J Obstet Gynecol Reprod Biol. Mar. 1997;72(1):9-14. X-1. [pmid: 9076415].
5124 Spellacy WN, Gall SA. Prostaglandin F 2 and oxytocin for term labor induction. J Reprod Med. Dec. 1972;9(6):300-3. X-4d. [pmid: 4567670].
5125 Spellacy WN, Gall SA, Shevach AB, et al. The induction of labor at term. Comparisons between prostaglandin F 2 and oxytocin infusions. Obstet Gynecol. Jan. 1973;41(1):14-21. X-4d, X-5. [pmid: 4566235].
5126 Spellacy WN, Mahan CS, Cruz AC. The adolescent's first pregnancy: a controlled study. South Med J. Jul. 1978;71(7):768-71. X-1. [pmid: 663717].
5127 Spellacy WN, Miller S, Winegar A, et al. Macrosomia--maternal characteristics and infant complications. Obstet Gynecol. Aug. 1985;66(2):158-61. X-1. [pmid: 4022478].
5128 Spellacy WN, Miller SJ, Winegar A. Pregnancy after 40 years of age. Obstet Gynecol. Oct. 1986;68(4):452-4. X-1. [pmid: 3748489].
5129 Spetz J, Smith MW, Ennis SF. Physician incentives and the timing of cesarean sections: evidence from California. Med Care. Jun. 2001;39(6):536-50. X-1. [pmid: 11404639].
5130 Spielman FJ, Corke BC. Advantages and disadvantages of regional anesthesia for cesarean section. A review. J Reprod Med. Nov. 1985;30(11):832-40. X-1, X-2. [pmid: 4078816].
5131 Spinnato JA, Youkilis B, Cook VD, et al. Antibiotic prophylaxis at Cesarean delivery. J Matern Fetal Med. Nov-Dec. 2000;9(6):348-50. X-9. [pmid: 11243292].
5132 Spitzer KA, Murphy K, Crowther M, et al. Postpartum management of women at increased risk of thrombosis--results of a Canadian pilot survey. J Rheumatol. Nov. 2006;33(11):2222-6. X-1. [pmid: 16981294].
5133 Spong CY, Landon MB, Gilbert S, et al. Risk of uterine rupture and adverse perinatal outcome at term after cesarean delivery. Obstet Gynecol. Oct. 2007;110(4):801-7. X-1. [pmid: 17906012].
5134 Sporri S, Hanggi W, Braghetti A, et al. Pelvimetry by magnetic resonance imaging as a diagnostic tool to evaluate dystocia. Obstet Gynecol. Jun. 1997;89(6):902-8. X-1. [pmid: 9170462].
5135 Sporri S, Thoeny HC, Raio L, et al. MR imaging pelvimetry: a useful adjunct in the treatment of women at risk for dystocia?. AJR Am J Roentgenol. Jul. 2002;179(1):137-44. X-1. [pmid: 12076922].
5136 Spreafico P, Scian A, Epis A, et al. Cesarean section: antibiotic prophylaxis with ceftezole. Chemioterapia. Jun. 1987;6(2 Suppl):613-6. X-4b. [pmid: 3334648].
5137 Springen K. The right to choose. Cesarean sections are on the rise again. Public-health officials want to limit them, but many patients and doctors are resisting. Newsweek. Dec. 4. 2000;136(23):73-4. X-1. [pmid: 11126067].
5138 Spurrett B, Cook CM. Why we choose caesarean section: a prospective study. Aust N Z J Obstet Gynaecol. Aug. 1997;37(3):297-300. X-1. [pmid: 9325509].
5139 Sreevidya S, Sathiyasekaran BW. High caesarean rates in Madras (India): a population-based cross sectional study. BJOG. Feb. 2003;110(2):106-11. X-1. [pmid: 12618152].
5140 Srinivas SK, Stamilio DM, Sammel MD, et al. Vaginal birth after caesarean delivery: does maternal age affect safety and success?. Paediatr Perinat Epidemiol. Mar. 2007;21(2):114-20. X-1. [pmid: 17302640].
5141 Srinivas SK, Stamilio DM, Stevens EJ, et al. Safety and success of vaginal birth after cesarean delivery in patients with preeclampsia. Am J Perinatol. Apr. 2006;23(3):145-52. X-1. [pmid: 16586227].
5142 St Onge RD, Connors GT. Preinduction cervical ripening: a comparison of intracervical prostaglandin E2 gel versus the Foley catheter. Am J Obstet Gynecol. Feb. 1995;172(2 Pt 1):687-90. X-4d, X-5. [pmid: 7856707].
5143 Stacey R, Jones R, Kar G, et al. High-dose intrathecal diamorphine for analgesia after Caesarean section. Anaesthesia. Jan. 2001;56(1):54-60. X-9. [pmid: 11167437].
5144 Stadlmayr W, Schneider H, Amsler F, et al. How do obstetric variables influence the dimensions of the birth experience as assessed by Salmon's item list (SIL-Ger)?. Eur J Obstet Gynecol Reprod Biol. Jul. 15. 2004;115(1):43-50. X-1. [pmid: 15223164].
5145 Staff AC, Braekke K, Harsem NK, et al. Circulating concentrations of sFlt1 (soluble fms-like tyrosine kinase 1) in fetal and maternal serum during pre-eclampsia. Eur J Obstet Gynecol Reprod Biol. Sep. 1. 2005;122(1):33-9. X-1. [pmid: 15935542].
5146 Staff AC, Braekke K, Johnsen GM, et al. Circulating concentrations of soluble endoglin (CD105) in fetal and maternal serum and in amniotic fluid in preeclampsia. Am J Obstet Gynecol. Aug. 2007;197(2):176 e1-6. X-1. [pmid: 17689641].
5147 Staff AC, Halvorsen B, Ranheim T, et al. Elevated level of free 8-iso-prostaglandin F2alpha in the decidua basalis of women with preeclampsia. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1211-5. X-1. [pmid: 10561647].
5148 Staff AC, Ranheim T, Halvorsen B. Augmented PLA2 activity in pre-eclamptic decidual tissue--a key player in the pathophysiology of ‘acute atherosis’ in pre-eclampsia?. Placenta. Nov. 2003;24(10):965-73. X-1. [pmid: 14580379].
5149 Staff AC, Ranheim T, Khoury J, et al. Increased contents of phospholipids, cholesterol, and lipid peroxides in decidua basalis in women with preeclampsia. Am J Obstet Gynecol. Mar. 1999;180(3 Pt 1):587-92. X-1. [pmid: 10076133].
5150 Staffolani R, Cester N, Magnanelli R, et al. Local anaesthetic effects on trophoblast membrane fluidity. Biochem Mol Biol Int. Mar. 1993;29(3):527-30. X-1. [pmid: 8485467].
5151 Stafford I, Belfort M. Placenta accreta, increta, and percreta: lifesaving strategies to stop the bleeding… part 1 of this two-part article. Contemporary OB/GYN. 2008;53(5):48-53. X-1, X-2.
5152 Stafford I, Belfort MA. Placenta accreta, increta, and percreta: a team-based approach starts with prevention. Contemporary OB/GYN. 2008;53(4):76-82. X-4e.
5153 Stafford RS. Alternative strategies for controlling rising cesarean section rates. JAMA. Feb. 2. 1990;263(5):683-7. X-4e, X-5. [pmid: 2296123].
5154 Stafford RS. The impact of nonclinical factors on repeat cesarean section. JAMA. Jan. 2. 1991;265(1):59-63. X-1. [pmid: 1984126].
5155 Stage AH, Gailey TA Jr., Hopkins WB 3rd. The transplacental transfer of cephradine. J La State Med Soc. Oct. 1980;132(10):148-50. X-1. [pmid: 7009769].
5156 Stage AH, Glover DD, Vaughan JE. Low-dose cephradine prophylaxis in obstetric and gynecologic surgery. J Reprod Med. Mar. 1982;27(3):113-9. X-9. [pmid: 7045356].
5157 Staikou C, Siafaka I, Petropoulos G, et al. Responses to mechanical and electrical stimuli are not attenuated by late pregnancy. Acta Anaesthesiol Belg. 2006;57(3):277-81. X-1, X-9. [pmid: 17067140].
5158 Stalberg K, Bodestedt A, Lyrenas S, et al. A narrow pelvic outlet increases the risk for emergency cesarean section. Acta Obstet Gynecol Scand. 2006;85(7):821-4. X-1, X-9. [pmid: 16817080].
5159 Stallmach T, Hebisch G, Joller H, et al. Expression pattern of cytokines in the different compartments of the feto-maternal unit under various conditions. Reprod Fertil Dev. 1995;7(6):1573-80. X-1. [pmid: 8743167].
5160 Stamer UM, Messerschmidt A, Wulf H. Anaesthesia for caesarean section--a German survey. Acta Anaesthesiol Scand. Jul. 1998;42(6):678-84. X-1. [pmid: 9689274].
5161 Stamilio DM, DeFranco E, Pare E, et al. Short interpregnancy interval: risk of uterine rupture and complications of vaginal birth after cesarean delivery. Obstet Gynecol. Nov. 2007;110(5):1075-82. X-1. [pmid: 17978122].
5162 Stampe Sorensen S, Palmgren Colov N, Andreasson B, et al. Induction of labor by vaginal prostaglandin E2. A randomized study comparing pessaries with vaginal tablets. Acta Obstet Gynecol Scand. Apr. 1992;71(3):201-6. X-4d. [pmid: 1317643].
5163 Stanek J. Acute and chronic placental membrane hypoxic lesions. Virchows Arch. Oct. 2009;455(4):315-22. X-1. [pmid: 19830452].
5164 Stanek J. Placental membrane and placental disc microscopic chorionic cysts share similar clinicopathologic associations. Pediatr Dev Pathol. Jan-Feb. 2011;14(1):1-9. X-1. [pmid: 20465421].
5165 Stanyer BT. Court-ordered cesarean sections: an example of the dangers of judicial involvement in medical decision making. Gonzaga Law Rev. 1992;28(1):121-40. X-1, X-2. [pmid: 11654037].
5166 Stark M, Hoyme UB, Stubert B, et al. Post-cesarean adhesions--are they a unique entity?. J Matern Fetal Neonatal Med. Aug. 2008;21(8):513-6. X-1. [pmid: 18609356].
5167 Stark MA, Miller MG. Barriers to the use of hydrotherapy in labor. J Obstet Gynecol Neonatal Nurs. Nov-Dec. 2009;38(6):667-75. X-1.
5168 Starr RV, Zurawski J, Ismail M. Preoperative vaginal preparation with povidone-iodine and the risk of postcesarean endometritis. Obstet Gynecol. May. 2005;105(5 Pt 1):1024-9. X-9. [pmid: 15863540].
5169 Steel JM. Contraception, pregnancy and breast feeding in the insulin-dependent diabetic. Practitioner. Nov. 9. 1987;231(1438):1489-95. X-1. [pmid: 3505682].
5170 Stein DJ, Birnbach DJ, Danzer BI, et al. Acupressure versus intravenous metoclopramide to prevent nausea and vomiting during spinal anesthesia for cesarean section. Anesth Analg. Feb. 1997;84(2):342-5. X-9. [pmid: 9024025].
5171 Stein JL, Bardeguez AD, Verma UL, et al. Nipple stimulation for labor augmentation. J Reprod Med. Jul. 1990;35(7):710-4. X-5. [pmid: 2198350].
5172 Steinbock B. Maternal-fetal conflict and in utero fetal therapy. Albany Law Rev. 1994;57(3):781-93. X-1. [pmid: 11652864].
5173 Steiner H, Zahradnik HP, Breckwoldt M, et al. Cervical ripening prior to induction of labor (intracervical application of a PG E2 viscous gel). Prostaglandins. Jan. 1979;17(1):125-33. X-1, x-4d, X-5. [pmid: 441422].
5174 Stell R, Myer P, Hood RJ, et al. Is granisetron 0.1 mg IV effective in preventing PONV and pruritis in groups of cesarean section patients receiving spinal anesthesia and intrathecal opioids?. AANA Journal. 2007;75(5):363-364. X-4b.
5175 Stella CL, O'Brien JM, Forrester KJ, et al. The coexistence of gestational hypertension and diabetes: influence on pregnancy outcome. Am J Perinatol. Jun. 2008;25(6):325-9. X-1. [pmid: 18493883].
5176 Stempel JE, Prins RP, Dean S. Preinduction cervical ripening: a randomized prospective comparison of the efficacy and safety of intravaginal and intracervical prostaglandin E2 gel. Am J Obstet Gynecol. Jun. 1997;176(6):1305-9. discussion 1309-12. X-4d. [pmid: 9215189].
5177 Stene LC, Joner G. Atopic disorders and risk of childhood-onset type 1 diabetes in individuals. Clin Exp Allergy. Feb. 2004;34(2):201-6. X-1. [pmid: 14987298].
5178 Stene LC, Ronningen KS, Undlien DE, et al. Does the relative risk for type 1 diabetes conferred by HLA-DQ, INS, and PTPN22 polymorphisms vary with maternal age, birth weight, or cesarean section?. Pediatr Diabetes. Mar. 2011;12(2):91-4. X-1. [pmid: 21352425].
5179 Stenius-Aarniala B, Piirila P, Teramo K. Asthma and pregnancy: a prospective study of 198 pregnancies. Thorax. Jan. 1988;43(1):12-8. X-1. [pmid: 2895502].
5180 Stepan H, Walther T, Faber R. C-type natriuretic peptide in maternal plasma in spontaneous labour, at elective cesarean section and during puerperium. J Perinat Med. 1998;26(5):396-9. X-1. [pmid: 10027136].
5181 Stephenson PA, Wagner MG. Reproductive rights and the medical care system: a plea for rational health policy. J Public Health Policy. Summer. 1993;14(2):174-82. X-1, X-2. [pmid: 8408608].
5182 Stern K. Court-ordered caesarian sections: in whose interests?. Mod Law Rev. Mar. 1993;56(2):238-43. X-1. [pmid: 11652316].
5183 Sterne G, Shields LE, Dubinsky TJ. Abnormal fetal cerebral and umbilical Doppler measurements in fetuses with intrauterine growth restriction predicts the severity of perinatal morbidity. J Clin Ultrasound. Mar-Apr. 2001;29(3):146-51. X-1. [pmid: 11329157].
5184 Stevens JD, Braithwaite P, Corke CF, et al. Double-blind comparison of epidural diamorphine and intramuscular morphine after elective caesarean section, with computerised analysis of continuous pulse oximetry. Anaesthesia. Apr. 1991;46(4):256-9. X-9. [pmid: 2024740].
5185 Stewart A, Fernando R, McDonald S, et al. The dose-dependent effects of phenylephrine for elective cesarean delivery under spinal anesthesia. Anesth Analg. Nov. 2010;111(5):1230-7. X-9. [pmid: 20841418].
5186 Stewart A, Sodhi V, Harper N, et al. Assessment of the effect upon maternal knowledge of an information leaflet about pain relief in labour. Anaesthesia. Oct. 2003;58(10):1015-9. X-1, X-3, X-4e. [pmid: 12969045].
5187 Stiehm ER, Lambert JS, Mofenson LM, et al. Efficacy of zidovudine and human immunodeficiency virus (HIV) hyperimmune immunoglobulin for reducing perinatal HIV transmission from HIV-infected women with advanced disease: results of Pediatric AIDS Clinical Trials Group protocol 185. J Infect Dis. Mar. 1999;179(3):567-75. X-4e, X-5. [pmid: 9952362].
5188 Stienstra R, Jonker TA, Bourdrez P, et al. Ropivacaine 0.25% versus bupivacaine 0.25% for continuous epidural analgesia in labor: a double-blind comparison. Anesth Analg. Feb. 1995;80(2):285-9. X-4e, X-5. [pmid: 7818114].
5189 Stiller-Timor L, Levy A, Holcberg G, et al. Upper respiratory tract infection during pregnancy: is it associated with adverse perinatal outcome?. Am J Perinatol. Sep. 2010;27(8):619-24. X-1. [pmid: 20200806].
5190 Stine LE, Phelan JP, Wallace R, et al. Update on external cephalic version performed at term. Obstet Gynecol. May. 1985;65(5):642-6. X-1. [pmid: 3982742].
5191 Stirrup CA, Lucas DN, Cox ML, et al. Maternal anti-factor Xa activity following subcutaneous unfractionated heparin after Caesarean section. Anaesthesia. Sep. 2001;56(9):855-8. X-1. [pmid: 11531671].
5192 Stiver HG, Forward KR, Livingstone RA, et al. Multicenter comparison of cefoxitin versus cefazolin for prevention of infectious morbidity after nonelective cesarean section. Am J Obstet Gynecol. Jan. 15. 1983;145(2):158-63. X-9. [pmid: 6336898].
5193 Stiver HG, Forward KR, Tyrrell DL, et al. Comparative cervical microflora shifts after cefoxitin or cefazolin prophylaxis against infection following cesarean section. Am J Obstet Gynecol. Aug. 1. 1984;149(7):718-21. X-9. [pmid: 6431820].
5194 Stock A, Ming WW, Rogers M, et al. Prediction of caesarean section from ultrasound and clinical assessment of fetal size. Aust N Z J Obstet Gynaecol. Aug. 1994;34(4):393-8. X-1. [pmid: 7848225].
5195 Stockbridge L. The light in the grey area: a wild woman's view of caesarean surgery. Midwifery Today Int Midwife. Summer. 67. 2008;(86):42-8. X-1, X-2, X-3, X-4e, X-5. [pmid: 18630016].
5196 Stoddart PA, Cooper A, Russell R, et al. A comparison of epidural diamorphine with intravenous patient-controlled analgesia using the Baxter infusor following caesarean section. Anaesthesia. Dec. 1993;48(12):1086-90. X-9. [pmid: 8285333].
5197 Stokowski LA. Noteworthy professional news. Advances in Neonatal Care (Elsevier Science). 2006;6(4):171-174. X-1.
5198 Stoll K, Fairbrother N, Carty E, et al. “It's all the rage these days”: University students' attitudes toward vaginal and cesarean birth. Birth. Jun. 2009;36(2):133-40. X-1. [pmid: 19489807].
5199 Stone JL, Lockwood CJ, Berkowitz G, et al. Use of cervical prostaglandin E2 gel in patients with previous cesarean section. Am J Perinatol. Jul. 1994;11(4):309-12. X-1, X-4b, X-5. [pmid: 7945629].
5200 Stone KM, Brooks CA, Guinan ME, et al. National surveillance for neonatal herpes simplex virus infections. Sex Transm Dis. Jul-Sep. 1989;16(3):152-6. X-1. [pmid: 2554515].
5201 Stotland NE, Hopkins LM, Caughey AB. Gestational weight gain, macrosomia, and risk of cesarean birth in nondiabetic nulliparas. Obstet Gynecol. Oct. 2004;104(4):671-7. X-1. [pmid: 15458884].
5202 Stotland NL. Women's bodies, doctors' dynamics. J Am Acad Psychoanal Dyn Psychiatry. Spring. 2004;32(1):181-91. X-1, X-2. [pmid: 15132197].
5203 Stovall TG, Thorpe EM Jr., Ling FW. Treatment of post-cesarean section endometritis with ampicillin and sulbactam or clindamycin and gentamicin. J Reprod Med. Nov. 1993;38(11):843-8. X-9. [pmid: 8277478].
5204 Strachan BK, van Wijngaarden WJ, Sahota D, et al. Cardiotocography only versus cardiotocography plus PR-interval analysis in intrapartum surveillance: a randomised, multicentre trial. FECG Study Group. Lancet. Feb. 5. 2000;355(9202):456-9. X-4e. [pmid: 10841126].
5205 Straughn HK, Goldenberg RL, Tolosa JE, et al. Birthweight-specific neonatal mortality in developing countries and obstetric practices. Int J Gynaecol Obstet. Jan. 2003;80(1):71-8. X-1. [pmid: 12527467].
5206 Strauss A, Kirz D, Modanlou HD, et al. Perinatal events and intraventricular/subependymal hemorrhage in the very low-birth weight infant. Am J Obstet Gynecol. Apr. 15. 1985;151(8):1022-7. X-1. [pmid: 3985063].
5207 Stray-Pedersen B, Solberg VM, Torkildsen E, et al. Postpartum bacteriuria. A multicenter evaluation of different screening procedures and a controlled short-course treatment trial with amoxycillin. Eur J Obstet Gynecol Reprod Biol. May. 1989;31(2):163-71. X-1. [pmid: 2668060].
5208 Street ME, Seghini P, Fieni S, et al. Changes in interleukin-6 and IGF system and their relationships in placenta and cord blood in newborns with fetal growth restriction compared with controls. Eur J Endocrinol. Oct. 2006;155(4):567-74. X-1. [pmid: 16990656].
5209 Stringer EM, Ekouevi DK, Coetzee D, et al. Coverage of nevirapine-based services to prevent mother-to-child HIV transmission in 4 African countries. JAMA. Jul. 21. 2010;304(3):293-302. X-1. [pmid: 20639563].
5210 Strobelt N, Meregalli V, Ratti M, et al. Randomized study on removable PGE2 vaginal insert versus PGE2 cervical gel for cervical priming and labor induction in low-Bishop-score pregnancy. Acta Obstet Gynecol Scand. 2006;85(3):302-5. X-4d. [pmid: 16553177].
5211 Strong C. Delivering hydrocephalic fetuses. Bioethics. Jan. 1991;5(1):1-22. X-1. [pmid: 11650945].
5212 Strong TH Jr., Brown WL Jr., Brown WL, et al. Experience with early postcesarean hospital dismissal. Am J Obstet Gynecol. Jul. 1993;169(1):116-9. X-1. [pmid: 8333434].
5213 Strong TH Jr., Hetzler G, Sarno AP, et al. Prophylactic intrapartum amnioinfusion: a randomized clinical trial. Am J Obstet Gynecol. Jun. 1990;162(6):1370-4. discussion 1374-5. [pmid: 2193511].
5214 Strulov L, Zimmer EZ, Granot M, et al. Pain catastrophizing, response to experimental heat stimuli, and post-cesarean section pain. J Pain. Mar. 2007;8(3):273-9. X-1. [pmid: 17113350].
5215 Strumper D, Louwen F, Durieux ME, et al. Epidural local anesthetics: a novel treatment for fetal growth retardation?. Fetal Diagn Ther. May-Jun. 2005;20(3):208-13. X-1. [pmid: 15824500].
5216 Stuart JC, Kan AF, Rowbottom SJ, et al. Acid aspiration prophylaxis for emergency Caesarean section. Anaesthesia. May. 1996;51(5):415-21. X-9. [pmid: 8694150].
5217 Stukin S. Poz partner: treatment. How to have a healthy baby. POZ. 1999;(53):89-90. X-2.
5218 Sturgess RH. In re A.C.: a court-ordered cesarean becomes precedent for nonconsensual organ harvesting. Nova Law Rev. Spring. 1989;13(2):649-69. X-1. [pmid: 11650356].
5219 Sturt AS, Dokubo EK, Sint TT. Antiretroviral therapy (ART) for treating HIV infection in ART-eligible pregnant women. Cochrane Database of Systematic Reviews. 2010;(3). X-1, X-2.
5220 Stutchfield P, Whitaker R, Russell I. Antenatal betamethasone and incidence of neonatal respiratory distress after elective caesarean section: pragmatic randomised trial. BMJ. Sep. 24. 2005;331(7518):662. X-9. [pmid: 16115831].
5221 Su M, Hannah WJ, Willan A, et al. Planned caesarean section decreases the risk of adverse perinatal outcome due to both labour and delivery complications in the Term Breech Trial. BJOG. Oct. 2004;111(10):1065-74. X-1. [pmid: 15383108].
5222 Su M, McLeod L, Ross S, et al. Factors associated with maternal morbidity in the Term Breech Trial. J Obstet Gynaecol Can. Apr. 2007;29(4):324-30. X-1. [pmid: 17475125].
5223 Sudik R, Husch K, Steller J, et al. Fertility and pregnancy outcome after myomectomy in sterility patients. Eur J Obstet Gynecol Reprod Biol. Apr. 1996;65(2):209-14. X-1. [pmid: 8730626].
5224 Sugano T, Nasu K, Narahara H, et al. Platelet-activating factor induces an imbalance between matrix metalloproteinase-1 and tissue inhibitor of metalloproteinases-1 expression in human uterine cervical fibroblasts. Biol Reprod. Mar. 2000;62(3):540-6. X-1. [pmid: 10684793].
5225 Suita S, Taguchi T, Yamanouchi T, et al. Fetal stabilization for antenatally diagnosed diaphragmatic hernia. J Pediatr Surg. Nov. 1999;34(11):1652-7. X-1. [pmid: 10591563].
5226 Sukalich S, Mingione MJ, Glantz JC. Obstetric outcomes in overweight and obese adolescents. Am J Obstet Gynecol. Sep. 2006;195(3):851-5. X-1. [pmid: 16949425].
5227 Suknikhom W, Tannirandorn Y. Previous uterine operation and placenta previa. J Med Assoc Thai. Mar. 2011;94(3):272-7. X-1. [pmid: 21560833].
5228 Sullivan CA, Benton LW, Roach H, et al. Combining medical and mechanical methods of cervical ripening. Does it increase the likelihood of successful induction of labor?. J Reprod Med. Nov. 1996;41(11):823-8. X-4d. [pmid: 8951132].
5229 Sullivan I, Faulds J, Ralph C. Contamination of salvaged maternal blood by amniotic fluid and fetal red cells during elective Caesarean section. Br J Anaesth. Aug. 2008;101(2):225-9. X-9. [pmid: 18515817].
5230 Sullivan JT, Grobman WA, Bauchat JR, et al. A randomized controlled trial of the effect of combined spinal-epidural analgesia on the success of external cephalic version for breech presentation. Int J Obstet Anesth. Oct. 2009;18(4):328-34. X-4c, X-4e. [pmid: 19682886].
5231 Sullivan S, Williamson B, Wilson LK, et al. Blunt needles for the reduction of needlestick injuries during cesarean delivery: a randomized controlled trial. Obstet Gynecol. Aug. 2009;114(2 Pt 1):211-6. X-9. [pmid: 19622979].
5232 Sullivan SA, Smith T, Chang E, et al. Administration of cefazolin prior to skin incision is superior to cefazolin at cord clamping in preventing postcesarean infectious morbidity: a randomized, controlled trial. Am J Obstet Gynecol. May. 2007;196(5):455 e1-5. X-9. [pmid: 17466699].
5233 Sultana A, Ahmed S. Attitude of women of NWFP towards antenatal care. J Ayub Med Coll Abbottabad. Apr-Jun. 2002;14(2):14-8. X-1. [pmid: 12238338].
5234 Sumiyoshi S, Machida J, Yamamoto T, et al. Massive immature teratoma in a neonate. Int J Oral Maxillofac Surg. Oct. 2010;39(10):1020-3. X-1. [pmid: 20483564].
5235 Sun HL, Cheng KW, Chien CC, et al. Diclofenac sodium and low dose epidural morphine for postcesarean analgesia. Ma Zui Xue Za Zhi. Sep. 1990;28(3):295-301. X-9. [pmid: 2277569].
5236 Sun HL, Ling QD, Sun WZ, et al. Lower limb wrapping prevents hypotension, but not hypothermia or shivering, after the introduction of epidural anesthesia for cesarean delivery. Anesth Analg. Jul. 2004;99(1):241-4. X-9. [pmid: 15281537].
5237 Sun HL, Wu CC, Lin MS, et al. Combination of low-dose epidural morphine and intramuscular diclofenac sodium in postcesarean analgesia. Anesth Analg. Jul. 1992;75(1):64-8. X-9. [pmid: 1616164].
5238 Sun LM, Walker MC, Cao HL, et al. Assisted reproductive technology and placenta-mediated adverse pregnancy outcomes. Obstet Gynecol. Oct. 2009;114(4):818-24. X-1. [pmid: 19888040].
5239 Sun SL, Cheng KW, Chien CC, et al. The effect of volume of epidural morphine on postoperative analgesia in patients undergoing cesarean section. Ma Zui Xue Za Zhi. Dec. 1990;28(4):433-7. X-9. [pmid: 2097484].
5240 Sunshine A, Olson NZ, O'Neill E, et al. Analgesic efficacy of a hydrocodone with ibuprofen combination compared with ibuprofen alone for the treatment of acute postoperative pain. J Clin Pharmacol. Oct. 1997;37(10):908-15. X-4e. [pmid: 9505982].
5241 Sunshine A, Olson NZ, Zighelboim I, et al. Ketoprofen, acetaminophen plus oxycodone, and acetaminophen in the relief of postoperative pain. Clin Pharmacol Ther. Nov. 1993;54(5):546-55. X-9. [pmid: 8222498].
5242 Sunshine A, Roure C, Olson N, et al. Analgesic efficacy of two ibuprofen-codeine combinations for the treatment of postepisiotomy and postoperative pain. Clin Pharmacol Ther. Oct. 1987;42(4):374-80. X-3, X-4e. [pmid: 3311548].
5243 Sunshine A, Zighelboim I, Laska E, et al. A double-blind, parallel comparison of ketoprofen, aspirin, and placebo in patients with postpartum pain. J Clin Pharmacol. Nov-Dec. 1986;26(8):706-11. X-3, X-4e. [pmid: 3540033].
5244 Sunshine A, Zighelboim I, Olson NZ, et al. A comparative oral analgesic study of indoprofen, aspirin, and placebo in postpartum pain. J Clin Pharmacol. Jul-Aug. 1985;25(5):374-80. X-3, X-4e. [pmid: 3897296].
5245 Sur S, Mackenzie IZ. Does discussion of possible scar rupture influence preferred mode of delivery after a caesarean section?. J Obstet Gynaecol. May. 2005;25(4):338-41. X-1. [pmid: 16091312].
5246 Sur S, Murphy KW, Mackenzie IZ. Delivery after caesarean section: consultant obstetricians' professional advice and personal preferences. J Obstet Gynaecol. Apr. 2009;29(3):212-6. X-1. [pmid: 19358027].
5247 Surakarn J, Tannirandorn Y. Intramuscular diclofenac for analgesia after cesarean delivery: a randomized controlled trial. J Med Assoc Thai. Jun. 2009;92(6):733-7. X-9. [pmid: 19530576].
5248 Suranyi A, Retz C, Rigo J, et al. Fetal renal hyperechogenicity in intrauterine growth retardation: importance and outcome. Pediatr Nephrol. Jul. 2001;16(7):575-80. X-1. [pmid: 11465807].
5249 Surapanthapisit P, Thitadilok W. Risk factors of caesarean section due to cephalopelvic disproportion. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S105-11. X-1. [pmid: 17725147].
5250 Surbek DV, Boesiger H, Hoesli I, et al. A double-blind comparison of the safety and efficacy of intravaginal misoprostol and prostaglandin E2 to induce labor. Am J Obstet Gynecol. Nov. 1997;177(5):1018-23. X-4d. [pmid: 9396885].
5251 Surbek DV, Visca E, Steinmann C, et al. Umbilical cord blood collection before placental delivery during cesarean delivery increases cord blood volume and nucleated cell number available for transplantation. Am J Obstet Gynecol. Jul. 2000;183(1):218-21. X-9. [pmid: 10920334].
5252 Surita FG, Cecatti JG, Parpinelli MA, et al. Hyaluronidase versus Foley catheter for cervical ripening in high-risk term and post term pregnancies. Int J Gynaecol Obstet. Mar. 2005;88(3):258-64. X-4b, X-4d. [pmid: 15733878].
5253 Sutcliffe AG, D'Souza SW, Cadman J, et al. Outcome in children from cryopreserved embryos. Arch Dis Child. Apr. 1995;72(4):290-3. X-1. [pmid: 7763057].
5254 Sutcliffe AG, Taylor B, Saunders K, et al. Outcome in the second year of life after in-vitro fertilisation by intracytoplasmic sperm injection: a UK case-control study. Lancet. Jun. 30. 2001;357(9274):2080-4. X-1. [pmid: 11445100].
5255 Sutherland J, Seaton H, Lowry C. The influence of epidural pethidine on shivering during lower segment caesarean section under epidural anaesthesia. Anaesth Intensive Care. May. 1991;19(2):228-32. X-9. [pmid: 2069245].
5256 Sutton L, Sayer GP, Bajuk B, et al. Do very sick neonates born at term have antenatal risks? 1. Infants ventilated primarily for problems of adaptation to extra-uterine life. Acta Obstet Gynecol Scand. Oct. 2001;80(10):905-16. X-1. [pmid: 11580735].
5257 Sutton L, Sayer GP, Bajuk B, et al. Do very sick neonates born at term have antenatal risks? 2. Infants ventilated primarily for lung disease. Acta Obstet Gynecol Scand. Oct. 2001;80(10):917-25. X-1. [pmid: 11580736].
5258 Suziedelis AK. Raising questions about society's “duty to rescue” the unborn. Health Care Ethics USA. 2004;12(1):E3. X-1, X-2, X-3, X-4, X-5. [pmid: 15685768].
5259 Suzuki S. Risk factors for emergency cesarean delivery of the second twin after vaginal delivery of the first twin. J Obstet Gynaecol Res. Jun. 2009;35(3):467-71. X-1. [pmid: 19527384].
5260 Suzuki S, Otsubo Y, Sawa R, et al. Clinical trial of induction of labor versus expectant management in twin pregnancy. Gynecol Obstet Invest. 2000;49(1):24-7. X-4d, X-4e. [pmid: 10629368].
5261 Suzuki S, Sawa R, Yoneyama Y, et al. Preoperative diagnosis of dehiscence of the lower uterine segment in patients with a single previous Caesarean section. Aust N Z J Obstet Gynaecol. Nov. 2000;40(4):402-4. X-1. [pmid: 11194423].
5262 Svanstrom MC, Biber B, Hanes M, et al. Signs of myocardial ischaemia after injection of oxytocin: a randomized double-blind comparison of oxytocin and methylergometrine during Caesarean section. Br J Anaesth. May. 2008;100(5):683-9. X-9. [pmid: 18385263].
5263 Svenningsen NW, Liedholm H, Aberg A. Hypertension in pregnancy and the infant. A controlled follow-up study. Acta Obstet Gynecol Scand Suppl. 1984;118:103-6. X-1. [pmid: 6587719].
5264 Swain S, Ojha KN, Prakash A, et al. Maternal and perinatal mortality due to eclampsia. Indian Pediatr. Jun. 1993;30(6):771-3. X-1. [pmid: 8132257].
5265 Swanson MJ. High religion in labor & delivery. The bonds of normalcy. Midwifery Today Int Midwife. Autumn. 1998;(47):18-9. X-1, X-2, X-3, X-4e, X-5. [pmid: 10338646].
5266 Swart M, Sewell J, Thomas D. Intrathecal morphine for caesarean section: an assessment of pain relief, satisfaction and side-effects. Anaesthesia. Apr. 1997;52(4):373-7. X-9. [pmid: 9135193].
5267 Swende TZ, Hwande TS. Female sterilization by tubal ligation at caesarean section in Makurdi, Nigeria. Ann Afr Med. Oct-Dec. 2010;9(4):246-50. X-1. [pmid: 20935426].
5268 Sword W, Watt S, Krueger P, et al. The Ontario Mother and Infant Study (TOMIS) III: a multi-site cohort study of the impact of delivery method on health, service use, and costs of care in the first postpartum year. BMC Pregnancy Childbirth. 2009;9:16. X-1. [pmid: 19397827].
5269 Sybulski S, Maughan GB. Relationship between cortisol levels in umbilical cord plasma and development of the respiratory distress syndrome in premature newborn infants. Am J Obstet Gynecol. May. 15. 1976;125(2):239-43. X-1. [pmid: 1266904].
5270 Syed S, Chaudhri R, Rizvi F, et al. Oral misoprostol for induction of labour. J Coll Physicians Surg Pak. Feb. 2010;20(2):102-5. X-1, X-4d. [pmid: 20378037].
5271 Sylvan K, Ryding EL, Rydhstroem H. Routine ultrasound screening in the third trimester: a population-based study. Acta Obstet Gynecol Scand. Dec. 2005;84(12):1154-8. X-1. [pmid: 16305700].
5272 Symon A. Obstetric litigation: effects on clinical practice. Gynakol Geburtshilfliche Rundsch. 2000;40(3-4):165-71. X-1, X-2. [pmid: 11326163].
5273 Szeverenyi M, Lampe L. Examination of gestations and deliveries subsequent to rivanol-induced interruption of first trimester pregnancies. Acta Med Hung. 1986;43(2):187-99. X-1. [pmid: 3108851].
5274 Szilagyi A, Szabo I. Improvement of perinatal outcome in diabetic pregnant women. Early Pregnancy. Jan. 2001;5(1):55-6. X-1. [pmid: 11753514].
5275 Szymankiewicz M, Jedrzejczak P, Rozycka J, et al. Newborn outcome after assisted reproductive technology: experiences and reflections from Poland. Int J Fertil Womens Med. Jul-Aug. 2004;49(4):150-4. X-1. [pmid: 15481479].
5276 Szymonowicz W, Yu VY. Severe pre-eclampsia and infants of very low birth weight. Arch Dis Child. Jul. 1987;62(7):712-6. X-1. [pmid: 3632019].
5277 Tabasi Z, Behrashi M, Mahdian M. Vaginal Misoprostol versus high dose of oxytocin for labor induction: a comparative study. Pak J Biol Sci. Mar. 15. 2007;10(6):920-3. X-4d. [pmid: 19069889].
5278 Tabedar S, Maharjan SK, Shrestha BR, et al. A comparison of 25 gauge Quincke spinal needle with 26 gauge Eldor spinal needle for the elective Caesarian sections: insertion characteristics and complications. Kathmandu Univ Med J (KUMJ). Oct-Dec. 2003;1(4):263-6. X-9. [pmid: 16388267].
5279 Tabowei TO, Oboro VO. Active management of labour in a district hospital setting. J Obstet Gynaecol. Jan. 2003;23(1):9-12. X-4e. [pmid: 12623473].
5280 Tabowei TO, Oboro VO. Low dose intravaginal misoprostol versus intracervical baloon catheter for pre-induction cervical ripening. East Afr Med J. Feb. 2003;80(2):91-4. X-4d. [pmid: 16167722].
5281 Tackley RM, Coe AJ. Alkalinized bupivacaine and adrenaline for epidural caesarean section. A comparison with 0.5% bupivacaine. Anaesthesia. Dec. 1988;43(12):1019-21. X-9. [pmid: 3069003].
5282 Tadesse E, Adane M, Abiyou M. Caesarean section deliveries at Tikur Anbessa Teaching Hospital, Ethiopia. East Afr Med J. Sep. 1996;73(9):619-22. X-1. [pmid: 8991247].
5283 Taeusch HW Jr., Frigoletto F, Kitzmiller J, et al. Risk of respiratory distress syndrome after prenatal dexamethasone treatment. Pediatrics. Jan. 1979;63(1):64-72. X-4e. [pmid: 375171].
5284 Taffel SM, Placek PJ, Liss T. Trends in the United States cesarean section rate and reasons for the 1980-85 rise. Am J Public Health. Aug. 1987;77(8):955-9. X-1. [pmid: 3605474].
5285 Taffel SM, Placek PJ, Moien M. Cesarean section rate levels off in 1987. Fam Plann Perspect. Sep-Oct. 1989;21(5):227-8. X-1, X-2, X-4e. [pmid: 2806490].
5286 Tahirovic H, Toromanovic A, Grbic S. Higher frequency of screening TSH above 5 mIU/l in infants likely exposed to higher doses of iodine-containing skin antiseptic: implications for assessment of iodine sufficiency. J Pediatr Endocrinol Metab. Apr. 2009;22(4):335-8. X-1. [pmid: 19554807].
5287 Tahirovic H, Toromanovic A, Grbic S, et al. Maternal and neonatal urinary iodine excretion and neonatal TSH in relation to use of antiseptic during caesarean section in an iodine sufficient area. J Pediatr Endocrinol Metab. Dec. 2009;22(12):1145-9. X-1. [pmid: 20333874].
5288 Tahirovic HF. Transient hypothyroxinemia in neonates with birth asphyxia delivered by emergency cesarean section. J Pediatr Endocrinol. Jan-Mar. 1994;7(1):39-41. X-1. [pmid: 8186822].
5289 Taillefer C, Dube J. Singleton breech at term: two continents, two approaches. J Obstet Gynaecol Can. Mar. 2010;32(3):238-43. X-1, X-2. [pmid: 20500968].
5290 Takayama T, Minakami H, Koike T, et al. Risks associated with cesarean sections in women with placenta previa. J Obstet Gynaecol Res. Aug. 1997;23(4):375-9. X-1. [pmid: 9311180].
5291 Takoudes TC, Weitzen S, Slocum J, et al. Risk of cesarean wound complications in diabetic gestations. Am J Obstet Gynecol. Sep. 2004;191(3):958-63. X-1. [pmid: 15467572].
5292 Talas BB, Altinkaya SO, Talas H, et al. Predictive factors and short-term fetal outcomes of breech presentation: a case-control study. Taiwan J Obstet Gynecol. Dec. 2008;47(4):402-7. X-1. [pmid: 19126505].
5293 Taljaard M, Donner A, Villar J, et al. Understanding the factors associated with differences in caesarean section rates at hospital level: the case of Latin America. Paediatr Perinat Epidemiol. Nov. 2009;23(6):574-81. X-1. [pmid: 19840294].
5294 Tam WH, Lee DT, Chiu HF, et al. A randomised controlled trial of educational counselling on the management of women who have suffered suboptimal outcomes in pregnancy. BJOG. Sep. 2003;110(9):853-9. X-3, X-4e. [pmid: 14511969].
5295 Tamdee D, Charuluxananan S, Punjasawadwong Y, et al. A randomized controlled trial of pentazocine versus ondansetron for the treatment of intrathecal morphine-induced pruritus in patients undergoing cesarean delivery. Anesth Analg. Nov. 2009;109(5):1606-11. X-9. [pmid: 19843798].
5296 Tamilselvan P, Fernando R, Bray J, et al. The effects of crystalloid and colloid preload on cardiac output in the parturient undergoing planned cesarean delivery under spinal anesthesia: a randomized trial. Anesth Analg. Dec. 2009;109(6):1916-21. X-9. [pmid: 19923521].
5297 Tamim H, El-Chemaly S, Nassar A, et al. Incidence and correlates of cesarean section in a capital city of a middle-income country. J Perinat Med. 2007;35(4):282-8. X-1. [pmid: 17542661].
5298 Tamim H, El-Chemaly SY, Nassar AH, et al. Cesarean delivery among nulliparous women in Beirut: assessing predictors in nine hospitals. Birth. Mar. 2007;34(1):14-20. X-1. [pmid: 17324173].
5299 Tamsen L, Lyrenas S, Cnattingius S. Premature rupture of the membranes--intervention or not. Gynecol Obstet Invest. 1990;29(2):128-31. X-1. [pmid: 2335312].
5300 Tan CH, Tay KH, Sheah K, et al. Perioperative endovascular internal iliac artery occlusion balloon placement in management of placenta accreta. AJR Am J Roentgenol. Nov. 2007;189(5):1158-63. X-1. [pmid: 17954654].
5301 Tan EC, Lim EC, Teo YY, et al. Ethnicity and OPRM variant independently predict pain perception and patient-controlled analgesia usage for post-operative pain. Mol Pain. 2009;5:32. X-1. [pmid: 19545447].
5302 Tan EC, Lim Y, Teo YY, et al. Ethnic differences in pain perception and patient-controlled analgesia usage for postoperative pain. J Pain. Sep. 2008;9(9):849-55. X-1. [pmid: 18550441].
5303 Tan KT, Tan KH. Pregnancy and delivery in primigravidae aged 35 and over. Singapore Med J. Oct. 1994;35(5):495-501. X-1. [pmid: 7701370].
5304 Tan L, Pepra E, Haloob RK. The outcome of pregnancy after large loop excision of the transformation zone of the cervix. J Obstet Gynaecol. Jan. 2004;24(1):25-7. X-1. [pmid: 14675976].
5305 Tan PC, Mubarak S, Omar SZ. Absorbable versus nonabsorbable sutures for subcuticular skin closure of a transverse suprapubic incision. Int J Gynaecol Obstet. Nov. 2008;103(2):179-81. X-9. [pmid: 18639876].
5306 Tan PC, Valiapan SD, Tay PY, et al. Concurrent oxytocin with dinoprostone pessary versus dinoprostone pessary in labour induction of nulliparas with an unfavourable cervix: a randomised placebo-controlled trial. BJOG. Jul. 2007;114(7):824-32. X-4d. [pmid: 17506788].
5307 Tan PC, Yow CM, Omar SZ. Effect of coital activity on onset of labor in women scheduled for labor induction: a randomized controlled trial. Obstet Gynecol. Oct. 2007;110(4):820-6. X-5. [pmid: 17906015].
5308 Tan SL, Doyle P, Campbell S, et al. Obstetric outcome of in vitro fertilization pregnancies compared with normally conceived pregnancies. Am J Obstet Gynecol. Sep. 1992;167(3):778-84. X-1, X-2. [pmid: 1530039].
5309 Tan T, Ojo R, Immani S, et al. Reduction of severity of pruritus after elective caesarean section under spinal anaesthesia with subarachnoid morphine: a randomised comparison of prophylactic granisetron and ondansetron. Int J Obstet Anesth. Jan. 2010;19(1):56-60. X-9. [pmid: 19945275].
5310 Tanaka M, Balki M, Parkes RK, et al. ED95 of phenylephrine to prevent spinal-induced hypotension and/or nausea at elective cesarean delivery. Int J Obstet Anesth. Apr. 2009;18(2):125-30. X-9. [pmid: 19162468].
5311 Tanaka S, Kobayashi T, Songjinda P, et al. Influence of antibiotic exposure in the early postnatal period on the development of intestinal microbiota. FEMS Immunol Med Microbiol. Jun. 2009;56(1):80-7. X-1. [pmid: 19385995].
5312 Tanbo T, Dale PO, Lunde O, et al. Obstetric outcome in singleton pregnancies after assisted reproduction. Obstet Gynecol. Aug. 1995;86(2):188-92. X-1. [pmid: 7617348].
5313 Taner CE, Hakverdi AU, Aban M, et al. Prevalence, management and outcome in eclampsia. Int J Gynaecol Obstet. Apr. 1996;53(1):11-5. X-1. [pmid: 8737298].
5314 Tang CH, Wang HI, Hsu CS, et al. Risk-adjusted cesarean section rates for the assessment of physician performance in Taiwan: a population-based study. BMC Public Health. 2006;6:246. X-1. [pmid: 17029640].
5315 Tangtrakul S, Taechaiya S, Suthutvoravut S, et al. Post-cesarean section urinary tract infection: a comparison between intermittent and indwelling catheterization. J Med Assoc Thai. May. 1994;77(5):244-8. X-9. [pmid: 7869005].
5316 Tangtrakul S, Thongjerm M, Suthutvoravuth S, et al. Outcome of delivery following first-pregnancy abortion. J Med Assoc Thai. Mar. Suppl 1. 1988;71:68-71. X-1. [pmid: 3418270].
5317 Tanir HM, Sener T, Gurer H, et al. A ten-year gestational diabetes mellitus cohort at a university clinic of the mid-Anatolian region of Turkey. Clin Exp Obstet Gynecol. 2005;32(4):241-4. X-1. [pmid: 16440823].
5318 Tantbirojn P, Saleemuddin A, Sirois K, et al. Gross abnormalities of the umbilical cord: related placental histology and clinical significance. Placenta. Dec. 2009;30(12):1083-8. X-1. [pmid: 19853300].
5319 Tarhan O, Canbay O, Celebi N, et al. Subhypnotic doses of midazolam prevent nausea and vomiting during spinal anesthesia for cesarean section. Minerva Anestesiol. Dec. 2007;73(12):629-33. X-9. [pmid: 18046293].
5320 Taricco E, Radaelli T, Rossi G, et al. Effects of gestational diabetes on fetal oxygen and glucose levels in vivo. BJOG. Dec. 2009;116(13):1729-35. X-1. [pmid: 19832834].
5321 Tarim E, Kilicdag E, Bagis T, et al. Second-trimester pregnancy termination with oral misoprostol in women who have had one cesarean section. Int J Gynaecol Obstet. Jul. 2005;90(1):84-5. X-4e. [pmid: 15992552].
5322 Tashima LS, Millar LK, Bryant-Greenwood GD. Genes upregulated in human fetal membranes by infection or labor. Obstet Gynecol. Sep. 1999;94(3):441-9. X-1. [pmid: 10472875].
5323 Tassi PG, Tarantini M, Cadenelli GP, et al. Ceftazidime in antibiotic prophylaxis for emergency cesarean section: a randomized prospective study. Int J Clin Pharmacol Ther Toxicol. Oct. 1987;25(10):582-8. X-9. [pmid: 3323074].
5324 Tastekin A, Ors R, Demircan B, et al. Oxidative stress in infants born to preeclamptic mothers. Pediatr Int. Dec. 2005;47(6):658-62. X-1. [pmid: 16354220].
5325 Tateishi SA. Apprehending the fetus en ventre sa mere: a study in judicial sleight of hand. Sask Law Rev. 1989;53(1):113-41. X-1. [pmid: 11656024].
5326 Tauer CA. Lives at stake: how to respond to a woman's refusal of cesarean surgery when she risks losing her child or her life. Health Prog. Sep. 1992;73(3):18, 20-27. X-1.
5327 Tauer CA. When pregnant patients refuse interventions. AWHONNS Clin Issues Perinat Womens Health Nurs. 1993;4(4):596-605. X-1, X-2. [pmid: 8220374].
5328 Tayebati SK, Giannella M, Indraccolo SR, et al. Muscarinic cholinergic receptors and acetylcholinesterase activity in umbilical artery and vein in pregnancy-induced hypertension (pre-eclampsia). Clin Exp Hypertens. Nov. 1997;19(8):1205-17. X-1. [pmid: 9385471].
5329 Taylor DR, Doughty AS, Kaufman H, et al. Uterine rupture with the use of PGE2 vaginal inserts for labor induction in women with previous cesarean sections. J Reprod Med. Jul. 2002;47(7):549-54. X-1. [pmid: 12170531].
5330 Taylor H. A self administration of balanced oral analgesia -- the successful ‘low-tech’ approach to pain management following caesarean section. MIDIRS Midwifery Digest. 1999;9(1):81-85. X-1, X-2.
5331 Taylor J, Johnson M. How women manage fatigue after childbirth. Midwifery. Jun. 2010;26(3):367-75. X-1. [pmid: 18771828].
5332 Taylor M. Rebalancing obstetric and midwifery thinking. Pract Midwife. Jul-Aug. 2008;11(7):24-8. X-1, X-2, X-3, X-4e, X-5.
5333 Taylor S, Armour C. Consumer preference for dinoprostone vaginal gel using stated preference discrete choice modelling. Pharmacoeconomics. 2003;21(10):721-35. X-1. [pmid: 12828494].
5334 Taylor VM, Kramer MD, Vaughan TL, et al. Placenta previa and prior cesarean delivery: how strong is the association?. Obstet Gynecol. Jul. 1994;84(1):55-7. X-1. [pmid: 8008323].
5335 Taylor VM, Peacock S, Kramer MD, et al. Increased risk of placenta previa among women of Asian origin. Obstet Gynecol. Nov. 1995;86(5):805-8. X-1. [pmid: 7566853].
5336 Tazeh-Kand NF, Eslami B, Mohammadian K. Inhaled fluticasone propionate reduces postoperative sore throat, cough, and hoarseness. Anesth Analg. Oct. 2010;111(4):895-8. X-9. [pmid: 20237046].
5337 Tchobroutsky C, Vray MM, Altman JJ. Risk/benefit ratio of changing late obstetrical strategies in the management of insulin-dependent diabetic pregnancies. A comparison between 1971-1977 and 1978-1985 periods in 389 pregnancies. Diabete Metab. Mar-Apr. 1991;17(2):287-94. X-1. [pmid: 1864436].
5338 Techanivate A, Rodanant O, Tachawattanawisal W, et al. Intrathecal fentanyl for prevention of shivering in cesarean section. J Med Assoc Thai. Sep. 2005;88(9):1214-21. X-9. [pmid: 16536107].
5339 Tei A, Mutoh S, Yaoi Y, et al. Serum levels of coagulation-fibrinolysis factors in normal pregnancy, labor and puerperium and in cesarean section delivery. Bull Tokyo Med Dent Univ. Jun. 1989;36(2):19-26. X-1. [pmid: 2776281].
5340 Tejani N, Verma U, Shiffman R, et al. Effect of route of delivery on periventricular/intraventricular hemorrhage in the low-birth-weight fetus with a breech presentation. J Reprod Med. Dec. 1987;32(12):911-4. X-1. [pmid: 3430500].
5341 Tenovuo AH, Kero PO, Korvenranta HJ, et al. Risk factors associated with severely small for gestational age neonates. Am J Perinatol. Jul. 1988;5(3):267-71. X-1. [pmid: 3382486].
5342 Teoh WH, Sia AT. Colloid preload versus coload for spinal anesthesia for cesarean delivery: the effects on maternal cardiac output. Anesth Analg. May. 2009;108(5):1592-8. X-9. [pmid: 19372341].
5343 Teoh WH, Thomas E, Tan HM. Ultra-low dose combined spinal-epidural anesthesia with intrathecal bupivacaine 3.75 mg for cesarean delivery: a randomized controlled trial. Int J Obstet Anesth. Oct. 2006;15(4):273-8. X-9. [pmid: 16774830].
5344 Teperi J. Multi method approach to the assessment of data quality in the Finnish Medical Birth Registry. J Epidemiol Community Health. Jun. 1993;47(3):242-7. X-1. [pmid: 8350040].
5345 Terajima K, Onodera H, Kobayashi M, et al. Efficacy of intrathecal morphine for analgesia following elective cesarean section: comparison with previous delivery. J Nippon Med Sch. Aug. 2003;70(4):327-33. X-9. [pmid: 12928713].
5346 Teramo K, Kari MA, Eronen M, et al. High amniotic fluid erythropoietin levels are associated with an increased frequency of fetal and neonatal morbidity in type 1 diabetic pregnancies. Diabetologia. Oct. 2004;47(10):1695-703. X-1. [pmid: 15502930].
5347 Teramo KA, Hiilesmaa VK, Schwartz R, et al. Amniotic fluid and cord plasma erythropoietin levels in pregnancies complicated by preeclampsia, pregnancy-induced hypertension and chronic hypertension. J Perinat Med. 2004;32(3):240-7. X-1. [pmid: 15188798].
5348 Teramo KA, Widness JA, Clemons GK, et al. Amniotic fluid erythropoietin correlates with umbilical plasma erythropoietin in normal and abnormal pregnancy. Obstet Gynecol. May. 1987;69(5):710-6. X-1. [pmid: 3574798].
5349 Tercanli S, Schneider M, Visca E, et al. Influence of volume preloading on uteroplacental and fetal circulation during spinal anaesthesia for caesarean section in uncomplicated singleton pregnancies. Fetal Diagn Ther. May-Jun. 2002;17(3):142-6. X-1. [pmid: 11914565].
5350 Ternov K, Nilsson M, Lofberg L, et al. Acupuncture for pain relief during childbirth. Acupunct Electrother Res. 1998;23(1):19-26. X-1, X-4e, X-5. [pmid: 9607101].
5351 Terui K, Omoto A, Osada H, et al. Influence of fetal stabilization on postnatal status of patients with congenital diaphragmatic hernia. Pediatr Surg Int. Jan. 2011;27(1):29-33. X-1, X-4e. [pmid: 20842386].
5352 Tessen JA, Zlatnik FJ. Monoamniotic twins: a retrospective controlled study. Obstet Gynecol. Jun. 1991;77(6):832-4. X-1. [pmid: 2030852].
5353 Tettambel MA. Preoperative use of antacids to prevent mendelson's syndrome in cesarean section: a pilot study. J Am Osteopath Assoc. Jul. 1983;82(11):858-60. X-3, X-4b. [pmid: 6885536].
5354 Tevaarwerk GJ, Harding PG, Milne KJ, et al. Pregnancy in diabetic women: outcome with a program aimed at normoglycemia before meals. Can Med Assoc J. Sep. 1. 1981;125(5):435-40. X-1. [pmid: 7026011].
5355 Thanasuan S, Borriboonhirunsarn D. Incidence of gestational diabetes mellitus among pregnant women with one abnormal value of oral glucose tolerance test. J Med Assoc Thai. Aug. 2006;89(8):1109-14. X-1. [pmid: 17048417].
5356 Thato S, Rachukul S, Sopajaree C. Obstetrics and perinatal outcomes of Thai pregnant adolescents: a retrospective study. Int J Nurs Stud. Sep. 2007;44(7):1158-64. X-1. [pmid: 16863648].
5357 Theodoridis TD, Chatzigeorgiou KN, Zepiridis L, et al. A prospective randomized study for evaluation of wound retractors in the prevention of incision site infections after cesarean section. Clin Exp Obstet Gynecol. 2011;38(1):57-9. X-1, X-9. [pmid: 21485728].
5358 Thiex NW, Chames MC, Loch-Caruso RK. Tissue-specific induction of COX-2 and prostaglandins in lipopolysaccharide-stimulated extraplacental human gestational membranes in a 2-chamber transwell culture system. Reprod Sci. Dec. 2010;17(12):1120-9. X-1. [pmid: 20861394].
5359 Thigpen BD, Hood WA, Chauhan S, et al. Timing of prophylactic antibiotic administration in the uninfected laboring gravida: a randomized clinical trial. Am J Obstet Gynecol. Jun. 2005;192(6):1864-8. discussion 1868-71. X-9. [pmid: 15970833].
5360 Thilaganathan B, Cutner A, Latimer J, et al. Management of the third stage of labour in women at low risk of postpartum haemorrhage. Eur J Obstet Gynecol Reprod Biol. Jan. 1993;48(1):19-22. X-3, X-4e, X-5. [pmid: 8449257].
5361 Thind GS, Wells JC, Wilkes RG. The effects of continuous intravenous naloxone on epidural morphine analgesia. Anaesthesia. Jun. 1986;41(6):582-5. X-9. [pmid: 3728926].
5362 Thomas DG, Robson SC, Redfern N, et al. Randomized trial of bolus phenylephrine or ephedrine for maintenance of arterial pressure during spinal anaesthesia for Caesarean section. Br J Anaesth. Jan. 1996;76(1):61-5. X-9. [pmid: 8672382].
5363 Thomas J, Paranjothy S, James D. National cross sectional survey to determine whether the decision to delivery interval is critical in emergency caesarean section. BMJ. Mar. 20. 2004;328(7441):665. X-1. [pmid: 15023829].
5364 Thomas JS, Koh SH, Cooper GM. Haemodynamic effects of oxytocin given as i.v. bolus or infusion on women undergoing Caesarean section. Br J Anaesth. Jan. 2007;98(1):116-9. X-9. [pmid: 17142825].
5365 Thomas PA, Weedon J, Krasinski K, et al. Maternal predictors of perinatal human immunodeficiency virus transmission. The New York City Perinatal HIV Transmission Collaborative Study Group. Pediatr Infect Dis J. Jun. 1994;13(6):489-95. X-1. [pmid: 8078735].
5366 Thompson DM, Dansereau J, Creed M, et al. Tight glucose control results in normal perinatal outcome in 150 patients with gestational diabetes. Obstet Gynecol. Mar. 1994;83(3):362-6. X-1. [pmid: 8127526].
5367 Thompson EM, Wilson CM, Moore J, et al. Plasma bupivacaine levels associated with extradural anaesthesia for caesarean section. Anaesthesia. May. 1985;40(5):427-32. X-9. [pmid: 4014618].
5368 Thompson TT, Thorp JM Jr., Mayer D, et al. Does epidural analgesia cause dystocia?. J Clin Anesth. Feb. 1998;10(1):58-65. X-1. [pmid: 9526940].
5369 Thomson F, Shanbhag S, Templeton A, et al. Obstetric outcome in women with subfertility. BJOG. May. 2005;112(5):632-7. X-1. [pmid: 15842289].
5370 Thomson M. After Re S. Med Law Rev. Summer. 1994;2(2):127-48. X-1, X-2. [pmid: 12159826].
5371 Thong MK, Ho JJ, Khatijah NN. A population-based study of birth defects in Malaysia. Ann Hum Biol. Mar-Apr. 2005;32(2):180-7. X-1. [pmid: 16096215].
5372 Thorburn J, Moir DD. Extradural analgesia: the influence of volume and concentration of bupivacaine on the mode of delivery, analgesic efficacy and motor block. Br J Anaesth. Sep. 1981;53(9):933-9. X-5. [pmid: 7284220].
5373 Thoren T, Holmstrom B, Rawal N, et al. Sequential combined spinal epidural block versus spinal block for cesarean section: effects on maternal hypotension and neurobehavioral function of the newborn. Anesth Analg. Jun. 1994;78(6):1087-92. X-9. [pmid: 8198262].
5374 Thornberry EA, Thomas TA. Posture and post-spinal headache. A controlled trial in 80 obstetric patients. Br J Anaesth. Feb. 1988;60(2):195-7. X-4e. [pmid: 3278726].
5375 Thorne C, Newell ML. Are girls more at risk of intrauterine-acquired HIV infection than boys?. AIDS. Jan. 23. 2004;18(2):344-7. X-1. [pmid: 15075561].
5376 Thorne C, Semenenko I, Pilipenko T, et al. Progress in prevention of mother-to-child transmission of HIV infection in Ukraine: results from a birth cohort study. BMC Infect Dis. 2009;9:40. X-1. [pmid: 19351387].
5377 Thorngren-Jerneck K, Herbst A. Perinatal factors associated with cerebral palsy in children born in Sweden. Obstet Gynecol. Dec. 2006;108(6):1499-505. X-1. [pmid: 17138786].
5378 Thornton JG, Lilford RJ. Active management of labour: current knowledge and research issues. BMJ. Aug. 6. 1994;309(6951):366-9. X-1. [pmid: 8081133].
5379 Thornton TE, Paltrow L. The rights of pregnant patients: Carder case brings bold policy initiatives. Healthspan. May. 1991;8(5):10-6. X-1. [pmid: 10111987].
5380 Thorp JA, Hu DH, Albin RM, et al. The effect of intrapartum epidural analgesia on nulliparous labor: a randomized, controlled, prospective trial. Am J Obstet Gynecol. Oct. 1993;169(4):851-8. X-4e, X-5. [pmid: 8238138].
5381 Thorp JA, McNitt JD, Leppert PC. Effects of epidural analgesia: some questions and answers. Birth. Sep. 1990;17(3):157-62. X-1, X-2. [pmid: 2222642].
5382 Thorp JA, Parisi VM, Boylan PC, et al. The effect of continuous epidural analgesia on cesarean section for dystocia in nulliparous women. Am J Obstet Gynecol. Sep. 1989;161(3):670-5. X-9. [pmid: 2782350].
5383 Thubisi M, Ebrahim A, Moodley J, et al. Vaginal delivery after previous caesarean section: is X-ray pelvimetry necessary?. Br J Obstet Gynaecol. May. 1993;100(5):421-4. X-4b. [pmid: 8518240].
5384 Thurman AR, Anca Y, White CA, et al. Post-cesarean delivery infectious morbidity: Focus on preoperative antibiotics and methicillin-resistant Staphylococcus aureus. Am J Infect Control. Oct. 2010;38(8):612-6. X-1, X-9. [pmid: 20627452].
5385 Thurman AR, Janecek T. One-year follow-up of women with unfulfilled postpartum sterilization requests. Obstet Gynecol. Nov. 2010;116(5):1071-7. X-1. [pmid: 20966691].
5386 Thurman AR, Zoller JS, Swift SE. Non-pregnant patients' preference for delivery route. Int Urogynecol J Pelvic Floor Dysfunct. Sep-Oct. 2004;15(5):308-12. X-1. [pmid: 15580415].
5387 Thwaites AJ, Rice CP, Smith I. Rapid sequence induction: a questionnaire survey of its routine conduct and continued management during a failed intubation. Anaesthesia. Apr. 1999;54(4):376-81. X-1. [pmid: 10455840].
5388 Thyfault JP, Hedberg EM, Anchan RM, et al. Gestational diabetes is associated with depressed adiponectin levels. J Soc Gynecol Investig. Jan. 2005;12(1):41-5. X-1.
5389 Tihtonen K, Koobi T, Yli-Hankala A, et al. Maternal haemodynamics in pre-eclampsia compared with normal pregnancy during caesarean delivery. BJOG. Jun. 2006;113(6):657-63. X-1. [pmid: 16709208].
5390 Tikkanen M, Nuutila M, Hiilesmaa V, et al. Clinical presentation and risk factors of placental abruption. Acta Obstet Gynecol Scand. 2006;85(6):700-5. X-1. [pmid: 16752262].
5391 Tikkanen M, Nuutila M, Hiilesmaa V, et al. Prepregnancy risk factors for placental abruption. Acta Obstet Gynecol Scand. 2006;85(1):40-4. X-1. [pmid: 16521678].
5392 Tilton Z, Hodgson MI, Donoso E, et al. Complications and outcome of pregnancy in obese women. Nutrition. Mar-Apr. 1989;5(2):95-9. X-1. [pmid: 2520281].
5393 Tingaker BK, Ekman-Ordeberg G, Facer P, et al. Influence of pregnancy and labor on the occurrence of nerve fibers expressing the capsaicin receptor TRPV1 in human corpus and cervix uteri. Reprod Biol Endocrinol. 2008;6:8. X-1. [pmid: 18267041].
5394 Tita AT, Hauth JC, Grimes A, et al. Decreasing incidence of postcesarean endometritis with extended-spectrum antibiotic prophylaxis. Obstet Gynecol. Jan. 2008;111(1):51-6. X-9. [pmid: 18165392].
5395 Tita AT, Landon MB, Spong CY, et al. Timing of elective repeat cesarean delivery at term and neonatal outcomes. N Engl J Med. Jan. 8. 2009;360(2):111-20. X-1. [pmid: 19129525].
5396 Tita AT, Owen J, Stamm AM, et al. Impact of extended-spectrum antibiotic prophylaxis on incidence of postcesarean surgical wound infection. Am J Obstet Gynecol. Sep. 2008;199(3):303 e1-3. X-9. [pmid: 18771992].
5397 To WW, Li IC. Occipital posterior and occipital transverse positions: reappraisal of the obstetric risks. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):275-9. X-1. [pmid: 11065033].
5398 Todd AL, Trudinger BJ, Cole MJ, et al. Antenatal tests of fetal welfare and development at age 2 years. Am J Obstet Gynecol. Jul. 1992;167(1):66-71. X-1. [pmid: 1442958].
5399 Todd DA, Jana A, John E. Chronic oxygen dependency in infants born at 24-32 weeks' gestation: the role of antenatal and neonatal factors. J Paediatr Child Health. Oct. 1997;33(5):402-7. X-1. [pmid: 9401883].
5400 Tomic V, Bosnjak K, Petrov B, et al. Macrosomic births at Mostar Clinical Hospital: a 2-year review. Bosn J Basic Med Sci. Aug. 2007;7(3):271-4. X-1. [pmid: 17848156].
5401 Tomic V, Grizelj B, Zadro M. Perinatal outcome in primiparous women aged 35 and older: a case-control study. Med Arh. 2008;62(1):18-9. X-1. [pmid: 18543748].
5402 Tomic V, Petrovic O, Petrov B, et al. Hypertensive disorders in pregnancy: a 5-year analysis of the wartime and postwar period in South-Western region of Bosnia and Herzegovina. Coll Antropol. Dec. Suppl 2. 2009;33:115-9. X-1. [pmid: 20120528].
5403 Tong S, Egan V, Wallace EM. Fetal activin A: associations with labour, umbilical artery pH and neonatal outcome. BJOG. Apr. 2004;111(4):326-30. X-1. [pmid: 15008767].
5404 Tongsong T, Wanapirak C, Kunavikatikul C, et al. Fetal loss rate associated with cordocentesis at midgestation. Am J Obstet Gynecol. Mar. 2001;184(4):719-23. X-1. [pmid: 11262478].
5405 Tonks A. Short cuts: all you need to read in the other general journals. BMJ: British Medical Journal. 2009;338(7687):134-135. X-1.
5406 Tonni G, Ferrari B, De Felice C, et al. Fetal acid-base and neonatal status after general and neuraxial anesthesia for elective cesarean section. Int J Gynaecol Obstet. May. 2007;97(2):143-6. X-1. [pmid: 17316645].
5407 Torkestani F, Zafarghandi N, Davati A, et al. Case-controlled study of the relationship between delivery method and incidence of post-partum urinary incontinence. J Int Med Res. Jan-Feb. 2009;37(1):214-9. X-1. [pmid: 19215693].
5408 Torrance E, Dockery K. Clinical governance and caesarean section. British Journal of Midwifery. 2003;11(2):94-96. X-1.
5409 Tough S, Benzies K, Fraser-Lee N, et al. Factors influencing childbearing decisions and knowledge of perinatal risks among Canadian men and women. Matern Child Health J. Mar. 2007;11(2):189-98. X-1. [pmid: 17237994].
5410 Tovo PA, de Martino M, Gabiano C, et al. Mode of delivery and gestational age influence perinatal HIV-1 transmission. Italian Register for HIV Infection in Children. J Acquir Immune Defic Syndr Hum Retrovirol. Jan. 1. 1996;11(1):88-94. X-1. [pmid: 8528738].
5411 Tovo PA, Gabiano C, Tulisso S. Maternal clinical factors influencing HIV-1 transmission. Acta Paediatr Suppl. Jun. 1997;421:52-5. X-1, X-2. [pmid: 9240858].
5412 Towers CV, Deveikis A, Asrat T, et al. A “bloodless cesarean section” and perinatal transmission of the human immunodeficiency virus. Am J Obstet Gynecol. Sep. 1998;179(3 Pt 1):708-14. X-1. [pmid: 9757976].
5413 Tracy SK, Sullivan E, Dahlen H, et al. Does size matter? A population-based study of birth in lower volume maternity hospitals for low risk women. BJOG. Jan. 2006;113(1):86-96. X-1. [pmid: 16398776].
5414 Tran SH, Caughey AB, Musci TJ. Meconium-stained amniotic fluid is associated with puerperal infections. Am J Obstet Gynecol. Sep. 2003;189(3):746-50. X-1. [pmid: 14526306].
5415 Tranmer JE. Nutritional support during labour: A randomized clinical trial of patient-controlled oral intake during labour. Ph.D. 1999:127. X-2.
5416 Tranquilli AL, Giannubilo SR. Cesarean delivery on maternal request in Italy. Int J Gynaecol Obstet. Feb. 2004;84(2):169-70. X-1, X-9. [pmid: 14871522].
5417 Tranquilli AL, Giannubilo SR, Bezzeccheri V, et al. Transabdominal amnioinfusion in preterm premature rupture of membranes: a randomised controlled trial. BJOG. Jun. 2005;112(6):759-63. X-4e. [pmid: 15924533].
5418 Tranquilli AL, Giannubilo SR, Tedeschi E, et al. Placental expression of nitric oxide synthase during HELLP syndrome: the correlation with maternal-fetal Doppler velocimetry. Acta Obstet Gynecol Scand. Sep. 2005;84(9):849-53. X-1. [pmid: 16097974].
5419 Trasande L, Lee M, Liu Y, et al. Incremental charges, costs, and length of stay associated with obesity as a secondary diagnosis among pregnant women. Med Care. Oct. 2009;47(10):1046-52. X-1. [pmid: 19820612].
5420 Traynor JD, Dooley SL, Seyb S, et al. Is the management of epidural analgesia associated with an increased risk of cesarean delivery?. Am J Obstet Gynecol. May. 2000;182(5):1058-62. X-1. [pmid: 10819827].
5421 Traynor JD, Peaceman AM. Maternal hospital charges associated with trial of labor versus elective repeat cesarean section. Birth. Jun. 1998;25(2):81-4. X-1. [pmid: 9668741].
5422 Trevisan G, Ramos JG, Martins-Costa S, et al. Pregnancy in patients with chronic renal insufficiency at Hospital de Clinicas of Porto Alegre, Brazil. Ren Fail. Jan. 2004;26(1):29-34. X-1. [pmid: 15083918].
5423 Triglia MT, Palamara F, Lojacono A, et al. A randomized controlled trial of 24-hour vaginal dinoprostone pessary compared to gel for induction of labor in term pregnancies with a Bishop score < or = 4. Acta Obstet Gynecol Scand. May. 2010;89(5):651-7. X-4d. [pmid: 20199360].
5424 Trindel RM. Fetal interests vs. maternal rights: is the state going too far?. Akron Law Rev. Spring. 1991;24(3-4):743-62. X-1. [pmid: 16273672].
5425 Tripathi A, Somwanshi M, Singh B, et al. A comparison of intravenous ranitidine and omeprazole on gastric volume and pH in women undergoing emergency caesarean section. Can J Anaesth. Sep. 1995;42(9):797-800. X-9. [pmid: 7497561].
5426 Tritten J. No second chances. Pract Midwife. Oct. 2004;7(9):4-5. X-1, X-2, X-3, X-4, X-5.
5427 Tritten J. The unkindest cut of all. Pract Midwife. Oct. 2006;9(9):4-5. X-1, X-2. [pmid: 17069080].
5428 Trivedi NS, Eddi D, Shevde K. Headache prevention following accidental dural puncture in obstetric patients. J Clin Anesth. Jan-Feb. 1993;5(1):42-5. X-3, X-4e. [pmid: 8442966].
5429 Trobough J. Pushing through: a tale of homebirth after cesarean. Midwifery Today Int Midwife. Summer. 2010;(94):26-7. 67. X-1, X-2, X-4e, X-5. [pmid: 20572617].
5430 Troche V, Ville Y, Fernandez H. Pregnancy after heart or heart-lung transplantation: a series of 10 pregnancies. Br J Obstet Gynaecol. Apr. 1998;105(4):454-8. X-1. [pmid: 9609275].
5431 Trofatter KF Jr. Effect of preinduction cervical softening with dinoprostone gel on outcome of oxytocin-induced labor. Clin Ther. Sep-Oct. 1993;15(5):838-44. X-4d, X-5. [pmid: 8269450].
5432 Trotter TN, Hayes-Gregson P, Robinson S, et al. Wound infiltration of local anaesthetic after lower segment caesarean section. Anaesthesia. May. 1991;46(5):404-7. X-9. [pmid: 2035794].
5433 Trovarelli T, Valenti J. The pregnant Jehovah's Witness: how nurse executives can assist staff in providing culturally competent care. JONAS Healthc Law Ethics Regul. Oct-Dec. 2005;7(4):105-9. quiz 110-1. X-1, X-2, X-3, X-4e, X-5. [pmid: 16331071].
5434 Trowell J. Possible effects of emergency caesarian section on the mother--child relationship. Early Hum Dev. Oct. 1982;7(1):41-51. X-1. [pmid: 7173099].
5435 Trowell JA. Emergency caesarian section: a research study of the mother/child relationship of a group of women admitted expecting a normal vaginal delivery. Child Abuse Negl. 1983;7(4):387-94. X-1. [pmid: 6686790].
5436 Trudinger BJ, Cook CM, Giles WB, et al. Umbilical artery flow velocity waveforms in high-risk pregnancy. Randomised controlled trial. Lancet. Jan. 24. 1987;1(8526):188-90. X-4e, X-5. [pmid: 2880017].
5437 Tsai FF, Fan SZ, Yang YM, et al. Human opioid mu-receptor A118G polymorphism may protect against central pruritus by epidural morphine for post-cesarean analgesia. Acta Anaesthesiol Scand. Nov. 2010;54(10):1265-9. X-1, X-9. [pmid: 21039348].
5438 Tsai MY, Shultz EK, Nelson JA. Amniotic fluid phosphatidylglycerol in diabetic and control pregnant patients at different gestational lengths. Am J Obstet Gynecol. Jun. 15. 1984;149(4):388-92. X-1. [pmid: 6731516].
5439 Tsai YC, Chu KS. A comparison of tramadol, amitriptyline, and meperidine for postepidural anesthetic shivering in parturients. Anesth Analg. Nov. 2001;93(5):1288-92. X-9. [pmid: 11682416].
5440 Tsai YW, Hu TW. National health insurance, physician financial incentives, and primary cesarean deliveries in Taiwan. Am J Public Health. Sep. 2002;92(9):1514-7. X-3, X-4e, X-5. [pmid: 12197985].
5441 Tschudin S, Alder J, Hendriksen S, et al. Pregnant women's perception of cesarean section on demand. J Perinat Med. 2009;37(3):251-6. X-1. [pmid: 19196209].
5442 Tschudin S, Alder J, Hendriksen S, et al. Previous birth experience and birth anxiety: predictors of caesarean section on demand?. J Psychosom Obstet Gynaecol. Sep. 2009;30(3):175-80. X-1. [pmid: 19639511].
5443 Tsen LC, Boosalis P, Segal S, et al. Hemodynamic effects of simultaneous administration of intravenous ephedrine and spinal anesthesia for cesarean delivery. J Clin Anesth. Aug. 2000;12(5):378-82. X-9. [pmid: 11025238].
5444 Tshorny M, Mimouni FB, Littner Y, et al. Decreased neonatal tibial bone ultrasound velocity in term infants born after breech presentation. J Perinatol. Nov. 2007;27(11):693-6. X-1. [pmid: 17703182].
5445 Tsu VD. Maternal height and age: risk factors for cephalopelvic disproportion in Zimbabwe. Int J Epidemiol. Oct. 1992;21(5):941-6. X-1. [pmid: 1468857].
5446 Tsuda H, Takahashi Y, Iwagaki S, et al. Intra-amniotic infection increases amniotic lamellar body count before 34 weeks of gestation. J Matern Fetal Neonatal Med. Oct. 2010;23(10):1230-6. X-1, X-9. [pmid: 20158396].
5447 Tubiana R, Le Chenadec J, Rouzioux C, et al. Factors associated with mother-to-child transmission of HIV-1 despite a maternal viral load <500 copies/ml at delivery: a case-control study nested in the French perinatal cohort (EPF-ANRS CO1). Clin Infect Dis. Feb. 15. 2010;50(4):585-96. X-1. [pmid: 20070234].
5448 Tubman TR, Rollins MD, Patterson C, et al. Increased incidence of respiratory distress syndrome in babies of hypertensive mothers. Arch Dis Child. Jan. 1991;66(1 Spec No):52-4. X-1. [pmid: 1996893].
5449 Tuffnell DJ, Jankowicz D, Lindow SW, et al. Outcomes of severe pre-eclampsia/eclampsia in Yorkshire 1999/2003. BJOG. Jul. 2005;112(7):875-80. X-1. [pmid: 15957986].
5450 Tukur J, Umar NI, Khan N, et al. Comparison of emergency caesarean section to misoprostol induction for the delivery of antepartum eclamptic patients: a pilot study. Niger J Med. Oct-Dec. 2007;16(4):364-7. X. [pmid: 18080597].
5451 Tuleu C, Allam J, Gill H, et al. Short term stability of pH-adjusted lidocaine-adrenaline epidural solution used for emergency caesarean section. Int J Obstet Anesth. Apr. 2008;17(2):118-22. X-1. [pmid: 18295471].
5452 Tully JL, Klapholz H, Baldini LM, et al. Perioperative use of cefoxitin in primary cesarean section. J Reprod Med. Dec. 1983;28(12):827-32. X-9. [pmid: 6363696].
5453 Tungphaisal S, Pinjaroen S, Chandeying V, et al. Incidental appendectomy at cesarean section: a prospective study. J Med Assoc Thai. Nov. 1989;72(11):633-7. X-9. [pmid: 2635207].
5454 Tunstall ME. The reduction of amnesic wakefulness during caesarean section. Anaesthesia. Apr. 1979;34(4):316-9. X-1, X-9. [pmid: 453504].
5455 Tunstall ME, Hawksworth GM. Halothane uptake and nitrous oxide concentration. Arterial halothane levels during Caesarean section. Anaesthesia. Feb. 1981;36(2):177-82. X-9. [pmid: 7212227].
5456 Tunstall ME, Sheikh A. Comparison of 1.5% enflurane with 1.25% isoflurane in oxygen for caesarean section: avoidance of awareness without nitrous oxide. Br J Anaesth. Feb. 1989;62(2):138-43. X-9. [pmid: 2923765].
5457 Tuomala RE, O'Driscoll PT, Bremer JW, et al. Cell-associated genital tract virus and vertical transmission of human immunodeficiency virus type 1 in antiretroviral-experienced women. J Infect Dis. Feb. 1. 2003;187(3):375-84. X-1. [pmid: 12552421].
5458 Turan S, Turan OM, Berg C, et al. Computerized fetal heart rate analysis, Doppler ultrasound and biophysical profile score in the prediction of acid-base status of growth-restricted fetuses. Ultrasound Obstet Gynecol. Oct. 2007;30(5):750-6. X-1. [pmid: 17688309].
5459 Turgut S, Kaptanoglu B, Emmungil G, et al. Increased plasma levels of growth hormone, insulin-like growth factor (IGF)-I and IGF-binding protein 3 in pregnant rats with exercise. Tohoku J Exp Med. Jan. 2006;208(1):75-81. X-1. [pmid: 16340176].
5460 Turhanoglu S, Kaya S, Erdogan H. Is there an advantage in using low-dose intrathecal bupivacaine for cesarean section?. J Anesth. 2009;23(3):353-7. X-9. [pmid: 19685114].
5461 Turkoz A, Togal T, Gokdeniz R, et al. Effectiveness of intravenous ephedrine infusion during spinal anaesthesia for caesarean section based on maternal hypotension, neonatal acid-base status and lactate levels. Anaesth Intensive Care. Jun. 2002;30(3):316-20. X-9. [pmid: 12075638].
5462 Turnbull DA, Wilkinson C, Yaser A, et al. Women's role and satisfaction in the decision to have a caesarean section. Med J Aust. Jun. 21. 1999;170(12):580-3. X-1. [pmid: 10416426].
5463 Turner CE, Young JM, Solomon MJ, et al. Vaginal delivery compared with elective caesarean section: the views of pregnant women and clinicians. BJOG. Nov. 2008;115(12):1494-502. X-1. [pmid: 18752584].
5464 Turner CE, Young JM, Solomon MJ, et al. Willingness of pregnant women and clinicians to participate in a hypothetical randomised controlled trial comparing vaginal delivery and elective caesarean section. Aust N Z J Obstet Gynaecol. Dec. 2008;48(6):542-6. X-1. [pmid: 19133040].
5465 Turner DJ, Wilson J. Effect of diazepam on awareness during caesarean section under general anaesthesia. Br Med J. Jun. 21. 1969;2(5659):736-7. X-9. [pmid: 4891882].
5466 Turner GA, Newnham JP, Johnson C, et al. Effects of extradural anaesthesia on umbilical and uteroplacental arterial flow velocity waveforms. Br J Anaesth. Sep. 1991;67(3):306-9. X-1. [pmid: 1911018].
5467 Turner MJ, Brassil M, Gordon H. Active management of labor associated with a decrease in the cesarean section rate in nulliparas. Obstet Gynecol. Feb. 1988;71(2):150-4. X-4e. [pmid: 3336547].
5468 Turnquest MA, How HY, Cook CR, et al. Chorioamnionitis: is continuation of antibiotic therapy necessary after cesarean section?. Am J Obstet Gynecol. Nov. 1998;179(5):1261-6. X-9. [pmid: 9822512].
5469 Turnquest MA, Lemke MD, Brown HL. Cervical ripening: randomized comparison of intravaginal prostaglandin E2 gel with prostaglandin E2 gel plus laminaria tents. J Matern Fetal Med. Sep-Oct. 1997;6(5):260-3. X-4d. [pmid: 9360182].
5470 Turnquest Wells M. A Guest Editorial: Safely Reducing the Cesarean Delivery Rate. Obstet Gynecol. 2002;57(7):409-412. X-1, X-2.
5471 Turrentine MA, Andres RL. Modern analysis of pathologic uterine rings. South Med J. Jan. 1997;90(1):40-2. X-1. [pmid: 9003822].
5472 Turrentine MA, Ramirez MM. Adverse perinatal events and subsequent cesarean rate. Obstet Gynecol. Aug. 1999;94(2):185-8. X-1. [pmid: 10432124].
5473 Turunen K, Sumanen M, Haukilahti RL, et al. Good pregnancy outcome despite intrahepatic cholestasis. Scand J Prim Health Care. Jun. 2010;28(2):102-7. X-1. [pmid: 20429741].
5474 Tussing AD, Wojtowycz MA. The cesarean decision in New York State, 1986. Economic and noneconomic aspects. Med Care. Jun. 1992;30(6):529-40. X-1. [pmid: 1593918].
5475 Tussing AD, Wojtowycz MA. The effect of physician characteristics on clinical behavior: cesarean section in New York State. Soc Sci Med. Nov. 1993;37(10):1251-60. X-1. [pmid: 8272903].
5476 Tussing AD, Wojtowycz MA. Health maintenance organizations, independent practice associations, and cesarean section rates. Health Serv Res. Apr. 1994;29(1):75-93. X-1. [pmid: 8163381].
5477 Tuzovic L, Djelmis J, Ilijic M. Obstetric risk factors associated with placenta previa development: case-control study. Croat Med J. Dec. 2003;44(6):728-33. X-1. [pmid: 14652887].
5478 Tyagi A, Girotra G, Kumar A, et al. Single-shot spinal anaesthesia, combined spinal-epidural and epidural volume extension for elective caesarean section: a randomized comparison. Int J Obstet Anesth. Jul. 2009;18(3):231-6. X-9. [pmid: 19447598].
5479 Tyden G, Brattstrom C, Bjorkman U, et al. Pregnancy after combined pancreas-kidney transplantation. Diabetes. Jan. Suppl 1. 1989;38:43-5. X-1. [pmid: 2642857].
5480 Tyrrell SN, Lilford RJ, Macdonald HN, et al. Randomized comparison of routine vs highly selective use of Doppler ultrasound and biophysical scoring to investigate high risk pregnancies. Br J Obstet Gynaecol. Oct. 1990;97(10):909-16. X. [pmid: 2223682].
5481 Tzeng JI, Mok MS. Combination of intramuscular Ketorolac and low dose epidural morphine for the relief of post-caesarean pain. Ann Acad Med Singapore. Nov. 1994;23(6 Suppl):10-3. X-9. [pmid: 7710217].
5482 Tzeng JI, Wang JJ, Ho ST, et al. Dexamethasone for prophylaxis of nausea and vomiting after epidural morphine for post-Caesarean section analgesia: comparison of droperidol and saline. Br J Anaesth. Dec. 2000;85(6):865-8. X-9. [pmid: 11732521].
5483 Tzingounis V, Makris N, Zolotas J, et al. Cefuroxime prophylaxis in caesarean section. Pharmatherapeutica. 1982;3(2):140-2. X-9. [pmid: 7100224].
5484 Udayasankar V, Padmagirison R, Majoko F. National survey of obstetricians in Wales regarding induction of labour in women with a previous caesarean section. J Obstet Gynaecol. Jan. 2008;28(1):48-50. X-1. [pmid: 18259898].
5485 Udom NU, Betley CL. Effects of maternity-stay legislation on ‘drive-through deliveries’. Health Aff (Millwood). Sep-Oct. 1998;17(5):208-15. X-1. [pmid: 9769584].
5486 Udy P. Emotional impact of cesareans. Midwifery Today Int Midwife. Spring. 2009;(89):12-3, 63-4. X-1, X-2, X-3, X-4e, X-5. [pmid: 19397143].
5487 Ueda K, Ikeda T, Iwanaga N, et al. Intrapartum fetal heart rate monitoring in cases of congenital heart disease. Am J Obstet Gynecol. Jul. 2009;201(1):64 e1-6. X-1. [pmid: 19481721].
5488 Ueyama H, He YL, Tanigami H, et al. Effects of crystalloid and colloid preload on blood volume in the parturient undergoing spinal anesthesia for elective Cesarean section. Anesthesiology. Dec. 1999;91(6):1571-6. X-9. [pmid: 10598596].
5489 Ukpong DI, Owolabi AT. Postpartum emotional distress: a controlled study of Nigerian women after caesarean childbirth. J Obstet Gynaecol. Feb. 2006;26(2):127-9. X-1. [pmid: 16483968].
5490 Ullmo S, Vial Y, Di Bernardo S, et al. Pathologic ventricular hypertrophy in the offspring of diabetic mothers: a retrospective study. Eur Heart J. Jun. 2007;28(11):1319-25. X-1. [pmid: 17158827].
5491 Ulmsten U, Ekman G, Belfrage P, et al. Intracervical versus intravaginal PGE2 for induction of labor at term in patients with an unfavorable cervix. Arch Gynecol. 1985;236(4):243-8. X-4d. [pmid: 3861138].
5492 Ulstein M. Breech delivery. Ann Chir Gynaecol. 1980;69(2):70-4. X-1. [pmid: 7377737].
5493 Uma R, Libby G, Murphy DJ. Obstetric management of a woman's first delivery and the implications for pelvic floor surgery in later life. BJOG. Aug. 2005;112(8):1043-6. X-1. [pmid: 16045515].
5494 Unfer V, Piazze Garnica J, Di Benedetto MR, et al. Pregnancy in adolescents. A case-control study. Clin Exp Obstet Gynecol. 1995;22(2):161-4. X-1. [pmid: 7781184].
5495 Unlugenc H, Ozalevli M, Gunduz M, et al. Comparison of intrathecal magnesium, fentanyl, or placebo combined with bupivacaine 0.5% for parturients undergoing elective cesarean delivery. Acta Anaesthesiol Scand. Mar. 2009;53(3):346-53. X-9. [pmid: 19173689].
5496 Unlugenc H, Ozalevli M, Gunes Y, et al. A double-blind comparison of intrathecal S(+) ketamine and fentanyl combined with bupivacaine 0.5% for Caesarean delivery. Eur J Anaesthesiol. Dec. 2006;23(12):1018-24. X-9. [pmid: 16824240].
5497 Unsal M, Yanik FF, Gurkan N, et al. Pulmonary functions in pre-eclamptic women. Eur J Obstet Gynecol Reprod Biol. Nov. 10. 2003;111(1):33-7. X-1. [pmid: 14557008].
5498 Unterweger M, Marincek B, Gottstein-Aalame N, et al. Ultrafast MR imaging of the pelvic floor. AJR Am J Roentgenol. Apr. 2001;176(4):959-63. X-1. [pmid: 11264088].
5499 Uotila J, Tuimala R, Kirkinen P. Good perinatal outcome in selective vaginal breech delivery at term. Acta Obstet Gynecol Scand. Jun. 2005;84(6):578-83. X-1. [pmid: 15901270].
5500 Ural SH, Lievense S. Suppression of herpes simplex virus during pregnancy. Hospital Physician. 2005;41(4):19. X-4e.
5501 Urasra DP, Carlstedt A, Nystrom L, et al. Are process indicators adequate to assess essential obstetric care at district level?--a case study from Rufiji district, Tanzania. Afr J Reprod Health. Dec. 2005;9(3):100-11. X-1. [pmid: 16623194].
5502 Urayama KY, Von Behren J, Reynolds P. Birth characteristics and risk of neuroblastoma in young children. Am J Epidemiol. Mar. 1. 2007;165(5):486-95. X-1. [pmid: 17164463].
5503 Urban J, Iwaszkiewicz-Pawlowska A. Concentration of free fatty acids (FFA) in amniotic fluid and maternal and cord serum in cases of intrauterine growth retardation. J Perinat Med. 1986;14(4):259-62. X-1. [pmid: 3820034].
5504 Ure D, James KS, McNeill M, et al. Glycopyrrolate reduces nausea during spinal anaesthesia for caesarean section without affecting neonatal outcome. Br J Anaesth. Feb. 1999;82(2):277-9. X-9. [pmid: 10365009].
5505 Urquhart DR, Tai C. Obstetric performance in the elderly Malaysian primigravida. Asia Oceania J Obstet Gynaecol. Dec. 1991;17(4):321-5. X-1. [pmid: 1801677].
5506 Usha Kiran TS, Jayawickrama NS. Who is responsible for the rising caesarean section rate?. J Obstet Gynaecol. Jul. 2002;22(4):363-5. X-1. [pmid: 12521454].
5507 Usta IM, Hobeika EM, Musa AA, et al. Placenta previa-accreta: risk factors and complications. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1045-9. X-1. [pmid: 16157109].
5508 Usta IM, Zoorob D, Abu-Musa A, et al. Obstetric outcome of teenage pregnancies compared with adult pregnancies. Acta Obstet Gynecol Scand. 2008;87(2):178-83. X-1. [pmid: 18231885].
5509 Ustun C, Kokcu A, Cil E, et al. Relationship between endomyometritis and the duration of premature membrane rupture. J Matern Fetal Med. Sep-Oct. 1998;7(5):243-6. X-1. [pmid: 9775994].
5510 Ustunyurt E, Ugur M, Ustunyurt BO, et al. Prospective randomized study of oxytocin discontinuation after the active stage of labor is established. J Obstet Gynaecol Res. Dec. 2007;33(6):799-803. X-4d, X-4e, X-5. [pmid: 18001445].
5511 Uszynski M, Maciejewski K, Uszynski W, et al. Placenta and myometrium--the two main sources of fibrinolytic components during pregnancy. Gynecol Obstet Invest. 2001;52(3):189-93. X-1. [pmid: 11598362].
5512 Uszynski M, Sztenc S, Zekanowska E, et al. Thrombomodulin in human gestational tissues: placenta, fetal membranes and myometrium. Adv Med Sci. 2006;51:312-5. X-1. [pmid: 17357332].
5513 Uygur D, Gun O, Kelekci S, et al. Multiple repeat caesarean section: is it safe?. Eur J Obstet Gynecol Reprod Biol. Apr. 1. 2005;119(2):171-5. X-1. [pmid: 15808374].
5514 Uygur D, Kis S, Tuncer R, et al. Risk factors and infant outcomes associated with umbilical cord prolapse. Int J Gynaecol Obstet. Aug. 2002;78(2):127-30. X-1. [pmid: 12175713].
5515 Vacca A, Grant A, Wyatt G, et al. Portsmouth operative delivery trial: a comparison vacuum extraction and forceps delivery. Br J Obstet Gynaecol. Dec. 1983;90(12):1107-12. X-4e, X-5. [pmid: 6652049].
5516 Vaillancourt C, Berger N, Boksa P. Effects of vaginal birth versus caesarean section birth with general anesthesia on blood gases and brain energy metabolism in neonatal rats. Exp Neurol. Nov. 1999;160(1):142-50. X-1. [pmid: 10630199].
5517 Vakhariya VR, Sherman AI. Prostaglandin F 2 for induction of labor. Am J Obstet Gynecol. May. 15. 1972;113(2):212-22. X-4d. [pmid: 4554553].
5518 Valanne J, Kauppila A, Hollmen A. Effect of halothane anaesthesia on blood loss during Caesarean section. Ann Chir Gynaecol Fenn. 1973;62(2):73-6. X-4b. [pmid: 4717365].
5519 Valentin L, Ekman G, Isberg PE, et al. Clinical evaluation of the fetus and neonate. Relation between intra-partum cardiotocography, Apgar score, cord blood acid-base status and neonatal morbidity. Arch Gynecol Obstet. 1993;253(2):103-15. X-1. [pmid: 8215607].
5520 Valentine BH. Intravenous oxytocin and oral prostaglandin E2 for ripening of the unfavourable cervix. Br J Obstet Gynaecol. Nov. 1977;84(11):846-54. X-1, X-4d, X-5. [pmid: 338022].
5521 Valentine JM, Lyons G, Bellamy MC. The effect of intrathecal midazolam on post-operative pain. Eur J Anaesthesiol. Nov. 1996;13(6):589-93. X-9. [pmid: 8958490].
5522 Valenzuela G, Harper MJ, Hayashi RH. Uterine venous, peripheral venous, and radial arterial levels of prostaglandins E and F in women with pregnancy-induced hypertension. Am J Obstet Gynecol. Jan. 1. 1983;145(1):11-4. X-1. [pmid: 6681580].
5523 Valenzuela GJ, Craig J, Bernhardt MD, et al. Placental passage of the oxytocin antagonist atosiban. Am J Obstet Gynecol. Apr. 1995;172(4 Pt 1):1304-6. X-1. [pmid: 7726274].
5524 Valle RF, Sciarra JJ. Hysteroscopy: a useful diagnostic adjunct in gynecology. Am J Obstet Gynecol. May. 1975;122(2):230-5. X-1. [pmid: 1171621].
5525 Vallejo MC, Mandell GL, Sabo DP, et al. Postdural puncture headache: a randomized comparison of five spinal needles in obstetric patients. Anesth Analg. Oct. 2000;91(4):916-20. X-9. [pmid: 11004048].
5526 Vallejo MC, Phelps AL, Shepherd CJ, et al. Nitrous oxide anxiolysis for elective cesarean section. J Clin Anesth. Nov. 2005;17(7):543-8. X-9. [pmid: 16297755].
5527 Valli J, Pirhonen J, Aantaa R, et al. The effects of regional anaesthesia for caesarean section on maternal and fetal blood flow velocities measured by Doppler ultrasound. Acta Anaesthesiol Scand. Feb. 1994;38(2):165-9. X-1, X-9. [pmid: 7909642].
5528 Valsky DV, Lipschuetz M, Bord A, et al. Fetal head circumference and length of second stage of labor are risk factors for levator ani muscle injury, diagnosed by 3-dimensional transperineal ultrasound in primiparous women. Am J Obstet Gynecol. Jul. 2009;201(1):91 e1-7. X-1. [pmid: 19481726].
5529 Valtonen M, Kanto J, Rosenberg P. Comparison of propofol and thiopentone for induction of anaesthesia for elective caesarean section. Anaesthesia. Sep. 1989;44(9):758-62. X-9. [pmid: 2802124].
5530 Vambergue A, Nuttens MC, Verier-Mine O, et al. Is mild gestational hyperglycaemia associated with maternal and neonatal complications?. The Diagest Study Diabet Med. Mar. 2000;17(3):203-8. X-1.
5531 van Amerongen D. Vaginal birth after cesarean section in an HMO. HMO Pract. May-Jun. 1989;3(3):104-7. X-1. [pmid: 10313505].
5532 van Beusekom CM, Zeegers TA, Martini IA, et al. Milk of patients with tightly controlled insulin-dependent diabetes mellitus has normal macronutrient and fatty acid composition. Am J Clin Nutr. Jun. 1993;57(6):938-43. X-1. [pmid: 8503365].
5533 van Bogaert LJ. Prevention of post-spinal hypotension at elective cesarean section by wrapping of the lower limbs. Int J Gynaecol Obstet. Jun. 1998;61(3):233-8. X-9. [pmid: 9688483].
5534 Van Bogaert LJ. Spinal block caesarean section in parturients with pregnancy-induced hypertension. East Afr Med J. Apr. 1998;75(4):227-31. X-1. [pmid: 9745840].
5535 van Bogaert LJ. Lumbar lordosis and the spread of subarachnoid hyperbaric 0.5% bupivacaine at cesarean section. Int J Gynaecol Obstet. Oct. 2000;71(1):65-6. X-3, X-4b, X-4e. [pmid: 11044545].
5536 Van Damme W, De Brouwere V, Boelaert M, et al. Effects of a refugee-assistance programme on host population in Guinea as measured by obstetric interventions. Lancet. May. 30. 1998;351(9116):1609-13. X-1. [pmid: 9620714].
5537 van de Geijn EJ, van Vugt JM, Sollie JE, et al. Ultrasonographic diagnosis and perinatal management of fetal abdominal wall defects. Fetal Diagn Ther. 1991;6(1-2):2-10. X-1. [pmid: 1837457].
5538 Van de Velde M, Teunkens A, Kuypers M, et al. General anaesthesia with target controlled infusion of propofol for planned caesarean section: maternal and neonatal effects of a remifentanil-based technique. Int J Obstet Anesth. Jul. 2004;13(3):153-8. X-1. [pmid: 15321393].
5539 Van de Velde M, Van Schoubroeck D, Jani J, et al. Combined spinal-epidural anesthesia for cesarean delivery: dose-dependent effects of hyperbaric bupivacaine on maternal hemodynamics. Anesth Analg. Jul. 2006;103(1):187-90. table of contents. X-9. [pmid: 16790651].
5540 van den Berg AA, Sadek M, Swanson S, et al. Epidural injection of lidocaine reduces the response to dural puncture accompanying spinal needle insertion when performing combined spinal-epidural anesthesia. Anesth Analg. Sep. 2005;101(3):882-5. table of contents. X-9. [pmid: 16116008].
5541 van den Bergh JE, Sueters M, Segaar M, et al. Determinants of episiotomy in rural Zimbabwe. Acta Obstet Gynecol Scand. Oct. 2003;82(10):966-8. X-1. [pmid: 12956849].
5542 van den Biggelaar AH, Richmond PC, Pomat WS, et al. Neonatal pneumococcal conjugate vaccine immunization primes T cells for preferential Th2 cytokine expression: a randomized controlled trial in Papua New Guinea. Vaccine. Feb. 25. 2009;27(9):1340-7. X-3, X-4e, X-5. [pmid: 19150378].
5543 van Der Hulst LA, van Teijlingen ER, Bonsel GJ, et al. Does a pregnant woman's intended place of birth influence her attitudes toward and occurrence of obstetric interventions?. Birth. Mar. 2004;31(1):28-33. X-1. [pmid: 15015990].
5544 van der Linden MC, van Erp EJ, Ruijs GJ, et al. A prospective randomized study comparing amoxycillin/clavulanate with cefuroxime plus metronidazole for perioperative prophylaxis in gynaecological surgery. Eur J Obstet Gynecol Reprod Biol. Jul. 1993;50(2):141-5. X-9. [pmid: 8405642].
5545 van der Walt D, Venter PF. Management of term pregnancy with premature rupture of the membranes and unfavourable cervix. S Afr Med J. Jan. 21. 1989;75(2):54-6. X-4d, X-4e, X-5. [pmid: 2913680].
5546 van Dongen PW, Nijhuis JG, Jongsma HW. Reduced blood loss during caesarean section due to a controlled stapling technique. Eur J Obstet Gynecol Reprod Biol. Aug. 1989;32(2):95-102. X-9. [pmid: 2673886].
5547 Van Dorsten JP, Schifrin BS, Wallace RL. Randomized control trial of external cephalic version with tocolysis in late pregnancy. Am J Obstet Gynecol. Oct. 15. 1981;141(4):417-24. X-4e, X-5. [pmid: 7282824].
5548 van Gemund N, Scherjon S, LeCessie S, et al. A randomised trial comparing low dose vaginal misoprostol and dinoprostone for labour induction. BJOG. Jan. 2004;111(1):42-9. X-4d. [pmid: 14687051].
5549 van Heerden J, Steyn DW. Management of premature rupture of the membranes after 34 weeks' gestation -- early versus delayed induction of labour. S Afr Med J. Mar. 1996;86(3):264-8. X-4d, X-4e. [pmid: 8658299].
5550 Van Hoof TJ, Casey BA, Tate JP, et al. The status of prenatal care among Medicaid Managed Care patients in Connecticut. Eval Health Prof. Dec. 2000;23(4):409-21. X-1. [pmid: 11139868].
5551 van Loon AJ, Mantingh A, Serlier EK, et al. Randomised controlled trial of magnetic-resonance pelvimetry in breech presentation at term. Lancet. Dec. 20-27. 1997;350(9094):1799-804. X-4c. [pmid: 9428250].
5552 van Runnard Heimel PJ, Schobben AF, Huisjes AJ, et al. The transplacental passage of prednisolone in pregnancies complicated by early-onset HELLP syndrome. Placenta. Nov. 2005;26(10):842-5. X-1. [pmid: 16226134].
5553 van Schie DL, de Jeu RM, Steyn DW, et al. The optimal dosage of ketanserin for patients with severe hypertension in pregnancy. Eur J Obstet Gynecol Reprod Biol. May. 10. 2002;102(2):161-6. X-3, X-4d, X-5. [pmid: 11950484].
5554 van Tuijl I, van Klei WA, van der Werff DB, et al. The effect of addition of intrathecal clonidine to hyperbaric bupivacaine on postoperative pain and morphine requirements after Caesarean section: a randomized controlled trial. Br J Anaesth. Sep. 2006;97(3):365-70. X-9. [pmid: 16861258].
5555 van Tuyl T. The Netherlands. AIMS Journal. 2008;20(2):16-17. X-1.
5556 Van Veelen AJ, Van Cappellen AW, Flu PK, et al. Effect of external cephalic version in late pregnancy on presentation at delivery: a randomized controlled trial. Br J Obstet Gynaecol. Aug. 1989;96(8):916-21. X-4c, X-4e. [pmid: 2673337].
5557 Van Voorhis LW, Reiter RC, Gambone JC, et al. Rate-based calculation of failure to progress a proposed quality improvement method. Obstet Gynecol. Apr. 1992;79(4):633-6. X-1. [pmid: 1553191].
5558 Van Wijk MJ, Boer K, Nisell H, et al. Endothelial function in myometrial resistance arteries of normal pregnant women perfused with syncytiotrophoblast microvillous membranes. BJOG. Sep. 2001;108(9):967-72. X-1. [pmid: 11563468].
5559 Van Winter JT, Harmon MC, Atkinson EJ, et al. Young Moms' Clinic: a multidisciplinary approach to pregnancy education in teens and in young single women. J Pediatr Adolesc Gynecol. Feb. 1997;10(1):28-33. X-1. [pmid: 9061632].
5560 Vandenbussche FP, De Jong-Potjer LC, Stiggelbout AM, et al. Differences in the valuation of birth outcomes among pregnant women, mothers, and obstetricians. Birth. Sep. 1999;26(3):178-83. X-1. [pmid: 10655818].
5561 Vanek M, Sheiner E, Levy A, et al. Chronic hypertension and the risk for adverse pregnancy outcome after superimposed pre-eclampsia. Int J Gynaecol Obstet. Jul. 2004;86(1):7-11. X-1. [pmid: 15207662].
5562 Vangen S, Johansen RE, Sundby J, et al. Qualitative study of perinatal care experiences among Somali women and local health care professionals in Norway. Eur J Obstet Gynecol Reprod Biol. Jan. 15. 2004;112(1):29-35. X-1. [pmid: 14687735].
5563 Vangen S, Stoltenberg C, Holan S, et al. Outcome of pregnancy among immigrant women with diabetes. Diabetes Care. Feb. 2003;26(2):327-32. X-1. [pmid: 12547857].
5564 Varastehpour A, Radaelli T, Minium J, et al. Activation of phospholipase A2 is associated with generation of placental lipid signals and fetal obesity. J Clin Endocrinol Metab. Jan. 2006;91(1):248-55. X-1. [pmid: 16249288].
5565 Vardo JH, Thornburg LL, Glantz JC. Maternal and neonatal morbidity among nulliparous women undergoing elective induction of labor. J Reprod Med. Jan-Feb. 2011;56(1-2):25-30. X-1. [pmid: 21366123].
5566 Varga J, Varga I. Thrombosis prophylaxis with subcutaneous heparin Ca injection in the course of caesarean sections. Ther Hung. 1991;39(1):41-3. X-1. [pmid: 1858073].
5567 Varma TR, Bateman S, Patel RH, et al. Ultrasound evaluation of amniotic fluid: outcome of pregnancies with severe oligohydramnios. Int J Gynaecol Obstet. Oct. 1988;27(2):185-92. X-1. [pmid: 2903084].
5568 Varma TR, Norman J, Cowell L. Induction of labor with vaginal prostaglandin E2 pessaries. Int J Gynaecol Obstet. Feb. 1983;21(1):55-64. X-1, X-4d. [pmid: 6133795].
5569 Varner MW, Fraser AM, Hunter CY, et al. The intergenerational predisposition to operative delivery. Obstet Gynecol. Jun. 1996;87(6):905-11. X-1. [pmid: 8649696].
5570 Varner MW, Thom E, Spong CY, et al. Trial of labor after one previous cesarean delivery for multifetal gestation. Obstet Gynecol. Oct. 2007;110(4):814-9. X-1. [pmid: 17906014].
5571 Varner MW, Weiner CP, Petzold CR, et al. Comparison of cefotetan and cefoxitin as prophylaxis in cesarean section. Am J Obstet Gynecol. Apr. 1986;154(4):951-4. X-9. [pmid: 3515950].
5572 Varvarigou AA, Petsali M, Vassilakos P, et al. Increased cortisol concentrations in the cord blood of newborns whose mothers smoked during pregnancy. J Perinat Med. 2006;34(6):466-70. X-1. [pmid: 17140296].
5573 Veena Saxena K, Singhal KC. Evaluation of PGE2 gel for cervical ripening and induction of labour. Indian J Physiol Pharmacol. Jul. 1994;38(3):193-6. X-1. [pmid: 7814081].
5574 Vega CE, Kahhale S, Zugaib M. Maternal mortality due to arterial hypertension in Sao Paulo City (1995-1999). Clinics (Sao Paulo). Dec. 2007;62(6):679-84. X-1. [pmid: 18209907].
5575 Veiby G, Daltveit AK, Engelsen BA, et al. Pregnancy, delivery, and outcome for the child in maternal epilepsy. Epilepsia. Sep. 2009;50(9):2130-9. X-1. [pmid: 19490036].
5576 Vejtorp M, Pedersen J, Klebbe JG, et al. Low concentration of plasma amino acids in newborn babies of diabetic mothers. Acta Paediatr Scand. Jan. 1977;66(1):53-8. X-1. [pmid: 831381].
5577 Velandia M, Matthisen AS, Uvnas-Moberg K, et al. Onset of vocal interaction between parents and newborns in skin-to-skin contact immediately after elective cesarean section. Birth. Sep. 2010;37(3):192-201. X-1, X-9. [pmid: 20887535].
5578 Vengalil SR, Guinn DA, Olabi NF, et al. A randomized trial of misoprostol and extra-amniotic saline infusion for cervical ripening and labor induction. Obstet Gynecol. May. 1998;91(5 Pt 1):774-9. X-4d. [pmid: 9572229].
5579 Ventolini G, Neiger R, McKenna D. Decreasing infectious morbidity in cesarean delivery by changing gloves. J Reprod Med. Jan. 2004;49(1):13-6. X-9. [pmid: 14976789].
5580 Ventura SJ, Anderson RN, Martin JA, et al. Births and deaths: preliminary data for 1997. Natl Vital Stat Rep. Oct. 7. 1998;47(4):1-41. X-1.
5581 Venturini P, Contu G, Mazza V, et al. Induction of labor in women with oligohydramnios. J Matern Fetal Neonatal Med. Feb. 2005;17(2):129-32. X-1. [pmid: 16076620].
5582 Vercauteren M, Vereecken K, La Malfa M, et al. Cost-effectiveness of analgesia after Caesarean section. A comparison of intrathecal morphine and epidural PCA. Acta Anaesthesiol Scand. Jan. 2002;46(1):85-9. X-9. [pmid: 11903078].
5583 Vercauteren MP, Coppejans HC, Hoffmann VH, et al. Prevention of hypotension by a single 5-mg dose of ephedrine during small-dose spinal anesthesia in prehydrated cesarean delivery patients. Anesth Analg. Feb. 2000;90(2):324-7. X-9. [pmid: 10648315].
5584 Vercauteren MP, Coppejans HC, Hoffmann VL, et al. Small-dose hyperbaric versus plain bupivacaine during spinal anesthesia for cesarean section. Anesth Analg. May. 1998;86(5):989-93. X-9. [pmid: 9585282].
5585 Vercauteren MP, Coppejans HC, ten Broecke PW, et al. Epidural sufentanil for postoperative patient-controlled analgesia (PCA) with or without background infusion: a double-blind comparison. Anesth Analg. Jan. 1995;80(1):76-80. X-9. [pmid: 7802305].
5586 Vercauteren MP, Hoffmann V, Coppejans HC, et al. Hydroxyethylstarch compared with modified gelatin as volume preload before spinal anaesthesia for Caesarean section. Br J Anaesth. May. 1996;76(5):731-3. X-9. [pmid: 8688278].
5587 Vercauteren MP, Saldien V, Bosschaerts P, et al. Potentiation of sufentanil by clonidine in PCEA with or without basal infusion. Eur J Anaesthesiol. Nov. 1996;13(6):571-6. X-9. [pmid: 8958487].
5588 Vercauteren MP, Vandeput DM, Meert TF, et al. Patient-controlled epidural analgesia with sufentanil following caesarean section: the effect of adrenaline and clonidine admixture. Anaesthesia. Sep. 1994;49(9):767-71. X-9. [pmid: 7978130].
5589 Vercellini P, Zuliani G, Rognoni MT, et al. Pregnancy at forty and over: a case-control study. Eur J Obstet Gynecol Reprod Biol. Mar. 1993;48(3):191-5. X-1. [pmid: 8335137].
5590 Verdiales M, Pacheco C, Cohen WR. The effect of maternal obesity on the course of labor. J Perinat Med. 2009;37(6):651-5. X-1. [pmid: 19591559].
5591 Vergani P, Ceruti P, Strobelt N, et al. Transabdominal amnioinfusion in oligohydramnios at term before induction of labor with intact membranes: a randomized clinical trial. Am J Obstet Gynecol. Aug. 1996;175(2):465-70. X-4e, X-5. [pmid: 8765270].
5592 Vergani P, Ghidini A, Strobelt N, et al. Do uterine leiomyomas influence pregnancy outcome?. Am J Perinatol. Sep. 1994;11(5):356-8. X-1. [pmid: 7993518].
5593 Vergani P, Roncaglia N, Andreotti C, et al. Prognostic value of uterine artery Doppler velocimetry in growth-restricted fetuses delivered near term. Am J Obstet Gynecol. Oct. 2002;187(4):932-6. X-1. [pmid: 12388980].
5594 Verkuyl DA. Sterilisation during unplanned caesarean sections for women likely to have a completed family--should they be offered? Experience in a country with limited health resources. BJOG. Aug. 2002;109(8):900-4. X-1. [pmid: 12197369].
5595 Verlaenen H, Cammu H, Derde MP, et al. Singleton pregnancy after in vitro fertilization: expectations and outcome. Obstet Gynecol. Dec. 1995;86(6):906-10. X-1. [pmid: 7501337].
5596 Verma A, Weir A, Drummond J, et al. Performance profile of an outcome measure: morbidity assessment index for newborns. J Epidemiol Community Health. May. 2005;59(5):420-6. X-1. [pmid: 15831693].
5597 Verstraelen H, Goetgeluk S, Derom C, et al. Preterm birth in twins after subfertility treatment: population based cohort study. BMJ. Nov. 19. 2005;331(7526):1173. X-1. [pmid: 16249191].
5598 Vertommen JD, Van Aken H, Vandermeulen E, et al. Maternal and neonatal effects of adding epidural sufentanil to 0.5% bupivacaine for cesarean delivery. J Clin Anesth. Sep-Oct. 1991;3(5):371-6. X-9. [pmid: 1834099].
5599 Vezina Y, Bujold E, Varin J, et al. Cesarean delivery after successful external cephalic version of breech presentation at term: a comparative study. Am J Obstet Gynecol. Mar. 2004;190(3):763-8. X-1. [pmid: 15042011].
5600 Vichitvejpaisal P, Svastdi-Xuto O, Udompunturux S. A comparative study of isobaric and hyperbaric solution of bupivacaine for spinal anaesthesia in caesarean section. J Med Assoc Thai. May. 1992;75(5):278-82. X-9. [pmid: 1460407].
5601 Videbech P, Nielsen J, Wohlert M, et al. The impact of large Y chromosome on pregnancy, foetus and birth. Clin Genet. Oct. 1984;26(4):281-8. X-1. [pmid: 6499243].
5602 Videla FL, Satin AJ, Barth WH Jr., et al. Trial of labor: a disciplined approach to labor management resulting in a high rate of vaginal delivery. Am J Perinatol. May. 1995;12(3):181-4. X-1. [pmid: 7612091].
5603 Viegas OA, Leong WP, Ahmed S, et al. Obstetrical outcome with increasing maternal age. J Biosoc Sci. Apr. 1994;26(2):261-7. X-1. [pmid: 8014181].
5604 Viegas OA, Singh K, Adaikan PG, et al. Preinduction cervical priming in high risk pregnancy--experience with a new sustained release PGE2 vaginal film. Prostaglandins Leukot Med. Jan. 1986;21(1):61-8. X-1, X-4d, X-5. [pmid: 3513209].
5605 Vieira EM, Ford NJ. Provision of female sterilization in Ribeirao Preto, Sao Paulo, Brazil. Cad Saude Publica. Sep-Oct. 2004;20(5):1201-10. X-1. [pmid: 15486662].
5606 Vierhout ME, Out JJ, Wallenburg HC. Elective induction of labor: a prospective clinical study, I: Obstetric and neonatal effects. J Perinat Med. 1985;13(4):155-62. X-1. [pmid: 4057031].
5607 Viinikainen K, Heinonen S, Eriksson K, et al. Community-based, prospective, controlled study of obstetric and neonatal outcome of 179 pregnancies in women with epilepsy. Epilepsia. Jan. 2006;47(1):186-92. X-1. [pmid: 16417548].
5608 Vijapurkar M, Mota L, Shetty S, et al. Menorrhagia and reproductive health in rare bleeding disorders: a study from the Indian subcontinent. Haemophilia. Jan. 2009;15(1):199-202. X-1. [pmid: 18803553].
5609 Villar J, Carroli G, Zavaleta N, et al. Maternal and neonatal individual risks and benefits associated with caesarean delivery: multicentre prospective study. BMJ. Nov. 17. 2007;335(7628):1025. X-1. [pmid: 17977819].
5610 Villar J, Valladares E, Wojdyla D, et al. Caesarean delivery rates and pregnancy outcomes: the 2005 WHO global survey on maternal and perinatal health in Latin America. Lancet. Jun. 3. 2006;367(9525):1819-29. X-1. [pmid: 16753484].
5611 Ville Y, Proudler A, Kuhn P, et al. Aldosterone concentration in normal, growth-retarded, anemic, and hydropic fetuses. Obstet Gynecol. Oct. 1994;84(4):511-4. X-1. [pmid: 8090385].
5612 Villeneuve MG, Khalife S, Marcoux S, et al. Surgical staples in cesarean section: a randomized controlled trial. Am J Obstet Gynecol. Nov. 1990;163(5 Pt 1):1641-6. X-9. [pmid: 2240118].
5613 Vimala N, Mittal S, Kumar S. Sublingual misoprostol versus oxytocin infusion to reduce blood loss at cesarean section. Int J Gynaecol Obstet. Feb. 2006;92(2):106-10. X-9. [pmid: 16343498].
5614 Vimercati A, Greco P, Loverro G, et al. Maternal complications after caesarean section in HIV infected women. Eur J Obstet Gynecol Reprod Biol. May. 2000;90(1):73-6. X-1. [pmid: 10767514].
5615 Vincent RD Jr., Chestnut DH, Choi WW, et al. Does epidural fentanyl decrease the efficacy of epidural morphine after cesarean delivery?. Anesth Analg. May. 1992;74(5):658-63. X-9. [pmid: 1567032].
5616 Vincent RD Jr., Werhan CF, Norman PF, et al. Prophylactic angiotensin II infusion during spinal anesthesia for elective cesarean delivery. Anesthesiology. Jun. 1998;88(6):1475-9. X-9. [pmid: 9637639].
5617 Vincenti E, Tambuscio B, Marchesoni D, et al. Use of intramyometrial injection of prostaglandin F 2 alpha in the management of intractable hemorrhage due to uterine atony. Clin Exp Obstet Gynecol. 1982;9(1):26-30. X-1. [pmid: 6959742].
5618 Vintzileos AM, Antsaklis A, Varvarigos I, et al. A randomized trial of intrapartum electronic fetal heart rate monitoring versus intermittent auscultation. Obstet Gynecol. Jun. 1993;81(6):899-907. X-4e, X-5. [pmid: 8497353].
5619 Vinukonda G, Dummula K, Malik S, et al. Effect of prenatal glucocorticoids on cerebral vasculature of the developing brain. Stroke. Aug. 2010;41(8):1766-73. X-1. [pmid: 20616316].
5620 Visalyaputra S, Rodanant O, Somboonviboon W, et al. Spinal versus epidural anesthesia for cesarean delivery in severe preeclampsia: a prospective randomized, multicenter study. Anesth Analg. Sep. 2005;101(3):862-8. table of contents. X-9. [pmid: 16116005].
5621 Visco AG, Viswanathan M, Lohr KN, et al. Cesarean delivery on maternal request: maternal and neonatal outcomes. Obstet Gynecol. Dec. 2006;108(6):1517-29. X-1. [pmid: 17138788].
5622 Viscomi CM, Rathmell JP, Mason SB, et al. Analgesic efficacy and side effects of subarachnoid sufentanil-bupivacaine administered to women in advanced labor. Reg Anesth. Sep-Oct. 1996;21(5):424-9. X-1. [pmid: 8896002].
5623 Visser AA, Giesteira MV, Prinsloo ST. The effectiveness of salbutamol as a suppressant of established labour. S Afr Med J. Sep. 1. 1979;56(12):481-4. X-1. [pmid: 550376].
5624 Visser AA, Prinsloo ST, Giesteira MV. Suppression of uterine activity with salbutamol before caesarean section. S Afr Med J. Dec. 15. 1979;56(25):1093-8. X-1. [pmid: 45058].
5625 Visser W, Wallenburg HC. Temporising management of severe pre-eclampsia with and without the HELLP syndrome. Br J Obstet Gynaecol. Feb. 1995;102(2):111-7. X-1. [pmid: 7756201].
5626 Vlachos DG, Schulpis KH, Parthimos T, et al. Maternal-neonatal erythrocyte membrane Na(+), K (+)-ATPase and Mg (2+)-ATPase activities in relation to the mode of delivery. Eur J Appl Physiol. Jul. 2008;103(5):501-8. X-1. [pmid: 18421470].
5627 Vlachos DG, Schulpis KH, Parthimos T, et al. The effect of the mode of delivery on the maternal-neonatal erythrocyte membrane acetylcholinesterase activity. Clin Biochem. Jul. 2008;41(10-11):818-23. X-1. [pmid: 18454940].
5628 Vladic-Stjernholm Y, Vladic T, Blesson CS, et al. Prostaglandin treatment is associated with a withdrawal of progesterone and androgen at the receptor level in the uterine cervix. Reprod Biol Endocrinol. 2009;7:116. X-1. [pmid: 19852793].
5629 Vlemmix F, Rosman AN, Fleuren MA, et al. Implementation of the external cephalic version in breech delivery. Dutch national implementation study of external cephalic version. BMC Pregnancy Childbirth. 2010;10:20. X-1, X-4c. [pmid: 20459717].
5630 Vogel I, Salvig JD, Secher NJ, et al. Association between raised serum relaxin levels during the eighteenth gestational week and very preterm delivery. Am J Obstet Gynecol. Feb. 2001;184(3):390-3. X-1. [pmid: 11228492].
5631 Voigt HJ, Becker V. Doppler flow measurements and histomorphology of the placental bed in uteroplacental insufficiency. J Perinat Med. 1992;20(2):139-47. X-1. [pmid: 1501057].
5632 Volkmer BG, Seidl EM, Gschwend JE, et al. Pregnancy in women with ureterosigmoidostomy. Urology. Dec. 2002;60(6):979-82. X-1. [pmid: 12475653].
5633 Volmink J. HIV: mother-to-child transmission. adapted with permission from Volmink J. HIV: mother to child transmission. Clin Evid Concise 2003;10:154-5. American Family Physician. 2004;69(5):1181. X-4e.
5634 Volpe L, Di Cianni G, Bottone P, et al. Gestational diabetes: clinical characteristics and birth weight. Ann Ist Super Sanita. 1997;33(3):407-10. X-1. [pmid: 9542272].
5635 von Mandach U, Huch R, Malinverni R, et al. Ceftriaxone (single dose) versus cefoxitin (multiple doses): success and failure of antibiotic prophylaxis in 1052 cesarean sections. J Perinat Med. 1993;21(5):385-97. X-9. [pmid: 8126635].
5636 Voss DH, Cumminsky KC, Cook VD, et al. Effect of three concentrations of intracervical prostaglandin E2 gel for cervical ripening. J Matern Fetal Med. Jul-Aug. 1996;5(4):186-93. X-4d, X-5. [pmid: 8796792].
5637 Vucevic M, Russell IF. Spinal anaesthesia for caesarean section: 0.125% plain bupivacaine 12 ml compared with 0.5% plain bupivacaine 3 ml. Br J Anaesth. Jun. 1992;68(6):590-5. X-9. [pmid: 1610633].
5638 Vukojevic M, Soldo I, Granic D. Risk factors associated with cerebral palsy in newborns. Coll Antropol. Dec. Suppl 2. 2009;33:199-201. X-1. [pmid: 20120414].
5639 Vuorela P, Matikainen MT, Kuusela P, et al. Endothelial tie receptor antigen in maternal and cord blood of healthy and preeclamptic subjects. Obstet Gynecol. Aug. 1998;92(2):179-83. X-1. [pmid: 9699747].
5640 Wackerle A, Blochlinger-Wegmann B, Burkhardt T, et al. Notes on a stick: use and acceptability of woman-held maternity notes. Eur J Obstet Gynecol Reprod Biol. Dec. 2010;153(2):156-9. X-1. [pmid: 20674133].
5641 Wadhawan R, Vohr BR, Fanaroff AA, et al. Does labor influence neonatal and neurodevelopmental outcomes of extremely-low-birth-weight infants who are born by cesarean delivery?. Am J Obstet Gynecol. Aug. 2003;189(2):501-6. X-1. [pmid: 14520225].
5642 Wager GP, Martin DH, Koutsky L, et al. Puerperal infectious morbidity: relationship to route of delivery and to antepartum Chlamydia trachomatis infection. Am J Obstet Gynecol. Dec. 1. 1980;138(7 Pt 2):1028-33. X-1. [pmid: 7468665].
5643 Wagner K. Women's health. Access. 1999;13(10):8-8. X-2.
5644 Wagner MV, Chin VP, Peters CJ, et al. A comparison of early and delayed induction of labor with spontaneous rupture of membranes at term. Obstet Gynecol. Jul. 1989;74(1):93-7. [pmid: 2733949].
5645 Wahab MA, Karantzis P, Eccersley PS, et al. A randomised, controlled study of uterine exteriorisation and repair at caesarean section. Br J Obstet Gynaecol. Sep. 1999;106(9):913-6. X-9. [pmid: 10492101].
5646 Wainer N. A butcher's dozen. Midwifery Today Int Midwife. Spring. 2001;(57):9-15. X-1, X-2, X-3, X-4e, X-5. [pmid: 12596399].
5647 Waldenstrom U. Experience of labor and birth in 1111 women. J Psychosom Res. Nov. 1999;47(5):471-82. X-1. [pmid: 10624845].
5648 Waldenstrom U, Axelsson O, Nilsson S, et al. Effects of routine one-stage ultrasound screening in pregnancy: a randomised controlled trial. Lancet. Sep. 10. 1988;2(8611):585-8. X-4e, X-5. [pmid: 2900977].
5649 Waldenstrom U, Bergman V, Vasell G. The complexity of labor pain: experiences of 278 women. J Psychosom Obstet Gynaecol. Dec. 1996;17(4):215-28. X-1. [pmid: 8997688].
5650 Waldenstrom U, Borg IM, Olsson B, et al. The childbirth experience: a study of 295 new mothers. Birth. Sep. 1996;23(3):144-53. X-1. [pmid: 8924100].
5651 Waldenstrom U, Hildingsson I, Ryding EL. Antenatal fear of childbirth and its association with subsequent caesarean section and experience of childbirth. BJOG. Jun. 2006;113(6):638-46. X-1. [pmid: 16709206].
5652 Walker NC, O'Brien B. The relationship between method of pain management during labor and birth outcomes. Clin Nurs Res. May. 1999;8(2):119-34. X-1. [pmid: 10887865].
5653 Walker R, Turnbull D, Wilkinson C. Increasing cesarean section rates: exploring the role of culture in an Australian community. Birth. Jun. 2004;31(2):117-24. X-1. [pmid: 15153131].
5654 Wallace DH, Leveno KJ, Cunningham FG, et al. Randomized comparison of general and regional anesthesia for cesarean delivery in pregnancies complicated by severe preeclampsia. Obstet Gynecol. Aug. 1995;86(2):193-9. X-9. [pmid: 7617349].
5655 Wallace RL, Eglinton GS, Yonekura ML, et al. Extraperitoneal cesarean section: a surgical form of infection prophylaxis?. Am J Obstet Gynecol. Jan. 15. 1984;148(2):172-7. X-9. [pmid: 6362417].
5656 Wallace RL, Schifrin BS, Paul RH. The delivery route for very-low-birth-weight infants. A preliminary report of a randomized, prospective study. J Reprod Med. Oct. 1984;29(10):736-40. X-1. [pmid: 6512783].
5657 Wallace RL, VanDorsten JP, Eglinton GS, et al. External cephalic version with tocolysis Observations and continuing experience at the Los Angeles County/University of Southern California Medical Center. J Reprod Med. Oct. 1984;29(10):745-8. X-1, X-3, X-4e, X-5. [pmid: 6150997].
5658 Wallace RL, Yonekura ML. The use of prophylactic antibiotics in patients undergoing emergency primary cesarean section. Am J Obstet Gynecol. Nov. 1. 1983;147(5):533-6. X-9. [pmid: 6638095].
5659 Wallin G, Fall O. Modified Joel-Cohen technique for caesarean delivery. Br J Obstet Gynaecol. Mar. 1999;106(3):221-6. X-9. [pmid: 10426640].
5660 Walling AD, Lin KW, Miller KE, et al. Tips. American Family Physician. 2006;74(5):835. X-1.
5661 Walmsley K, Hobbs L. Vaginal birth after lower segment caesarean section. Mod Midwife. Apr. 1994;4(4):20-1. X-1, X-2. [pmid: 7788367].
5662 Walsh D. Evidence-based care. Part four: fetal monitoring should be controlled. British Journal of Midwifery. 2000;8(8):511-516. X-1, X-2.
5663 Walsh D. National C-section audit … what it won't tell you. Pract Midwife. Nov. 2000;3(10):26-7. X-1. [pmid: 12026490].
5664 Walther T, Faber R, Maul B, et al. Fetal, neonatal cord, and maternal plasma concentrations of angiotensin-converting enzyme (ACE). Prenat Diagn. Feb. 2002;22(2):111-3. X-1. [pmid: 11857614].
5665 Walton DL, Ludlow D, Willis DC. Vaginal birth after cesarean section. Acceptance and outcome at a rural hospital. J Reprod Med. Sep. 1993;38(9):716-8. X-1. [pmid: 8254595].
5666 Walton SM, Maresh MJ, Murray A, et al. Induction of labour with prostaglandin gel in patients with unfavourable cervices. Clin Exp Obstet Gynecol. 1992;19(1):5-8. X-1. [pmid: 1606698].
5667 Wandabwa J, Doyle P, Paul K, et al. Risk factors for severe abruptio placenta in Mulago Hospital, Kampala, Uganda. Afr Health Sci. Dec. 2005;5(4):285-90. X-1. [pmid: 16615836].
5668 Wandabwa J, Doyle P, Todd J, et al. Risk factors for ruptured uterus in Mulago hospital Kampala, Uganda. East Afr Med J. Feb. 2008;85(2):56-63. X-1. [pmid: 18557248].
5669 Wandabwa J, Doyle P, Todd J, et al. Risk factors for severe post partum haemorrhage in Mulago hospital, Kampala, Uganda. East Afr Med J. Feb. 2008;85(2):64-71. X-1. [pmid: 18557249].
5670 Wang CS, Chou P. Characteristics and outcomes of adolescent pregnancies in Kaohsiung County, Taiwan. J Formos Med Assoc. Jun. 1999;98(6):415-21. X-1. [pmid: 10443065].
5671 Wang CY, Ong GS, Delilkan AE. Epidural anaesthesia for caesarean section: a comparison of 0.5% bupivacaine plain, 0.5% bupivacaine plus 100 micrograms fentanyl and 0.5% bupivacaine plus 50 micrograms fentanyl. Med J Malaysia. Sep. 1994;49(3):269-74. X-9. [pmid: 7845278].
5672 Wang F, Shen X, Guo X, et al. Epidural analgesia in the latent phase of labor and the risk of cesarean delivery: a five-year randomized controlled trial. Anesthesiology. Oct. 2009;111(4):871-80. X-9. [pmid: 19741492].
5673 Wang JH, He XH, Wu RJ, et al. Clinicopathologic characteristics of uterine adenomyoma in pregnant women. Fertil Steril. Jul. 2007;88(1):172-5. X-1. [pmid: 17336979].
5674 Wang JH, Xu KH, Lin J, et al. Methotrexate therapy for cesarean section scar pregnancy with and without suction curettage. Fertil Steril. Oct. 2009;92(4):1208-13. X-1. [pmid: 18976749].
5675 Wang JJ, Ho ST, Liu HS, et al. The preemptive effect of regional anesthesia on post-cesarean section pain. Acta Anaesthesiol Sin. Dec. 1995;33(4):211-6. X-9. [pmid: 8705153].
5676 Wang JJ, Ho ST, Wong CS, et al. Dexamethasone prophylaxis of nausea and vomiting after epidural morphine for post-Cesarean analgesia. Can J Anaesth. Feb. 2001;48(2):185-90. X-9. [pmid: 11220429].
5677 Wang JX, Norman RJ, Kristiansson P. The effect of various infertility treatments on the risk of preterm birth. Hum Reprod. Apr. 2002;17(4):945-9. X-1. [pmid: 11925387].
5678 Wang LH, Lin HC, Lin CC, et al. Increased risk of adverse pregnancy outcomes in women receiving zolpidem during pregnancy. Clin Pharmacol Ther. Sep. 2010;88(3):369-74. X-1. [pmid: 20686480].
5679 Wang LZ, Zhang YF, Tang BL, et al. Effects of intrathecal and i.v. small-dose sufentanil on the median effective dose of intrathecal bupivacaine for Caesarean section. Br J Anaesth. Jun. 2007;98(6):792-6. X-9. [pmid: 17478452].
5680 Wang YP, Cheng YJ, Fan SZ, et al. Conscious sedation by low dose propofol infusion during spinal anesthesia for cesarean section. Acta Anaesthesiol Sin. Sep. 1996;34(3):117-21. X-9. [pmid: 9084534].
5681 Waqar F, Nasar R, Fawad A. The comparison of placental removal methods on operative blood loss. J Ayub Med Coll Abbottabad. Jul-Sep. 2008;20(3):3-5. X-9. [pmid: 19610503].
5682 Ward HR, Jennings OG, Potgieter P, et al. Do plastic adhesive drapes prevent post caesarean wound infection?. J Hosp Infect. Mar. 2001;47(3):230-4. X-9. [pmid: 11247684].
5683 Ward PM, Biggs JS. Trends in adolescent pregnancies. Aust N Z J Obstet Gynaecol. May. 1981;21(2):88-92. X-1. [pmid: 6945857].
5684 Ward VP, Charlett A, Fagan J, et al. Enhanced surgical site infection surveillance following caesarean section: experience of a multicentre collaborative post-discharge system. J Hosp Infect. Oct. 2008;70(2):166-73. X-1. [pmid: 18723248].
5685 Wareing M, Akef H, Greenwood SL, et al. Umbilical artery Doppler waveform indices from normal pregnant women are related to vasodilatation of placental chorionic plate small arteries. J Obstet Gynaecol. Apr. 2005;25(3):248-52. X-1. [pmid: 16147727].
5686 Warren MA. Women's rights versus the protection of fetuses. Midwest Med Ethics. Winter. 3. 1991;7(1):1-7. X-1. [pmid: 16145788].
5687 Warszawski J, Tubiana R, Le Chenadec J, et al. Mother-to-child HIV transmission despite antiretroviral therapy in the ANRS French Perinatal Cohort. AIDS. Jan. 11. 2008;22(2):289-99. X-1. [pmid: 18097232].
5688 Warwick JP, Kearns CF, Scott WE. The effect of subhypnotic doses of propofol on the incidence of pruritus after intrathecal morphine for caesarean section. Anaesthesia. Mar. 1997;52(3):270-5. X-9. [pmid: 9124670].
5689 Watanabe T, Minakami H, Sakata Y, et al. Effect of heparin on activated partial thromboplastin time in patients undergoing gynecologic or obstetric surgery. Gynecol Obstet Invest. 2001;51(3):178-83. X-1. [pmid: 11306905].
5690 Watanasomsiri N, Rungruxsirivorn T, Chaithongwongwatthana S. Risk factors for cesarean hysterectomy in cesarean delivery. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S100-4. X-1. [pmid: 17725146].
5691 Waters JH, Biscotti C, Potter PS, et al. Amniotic fluid removal during cell salvage in the cesarean section patient. Anesthesiology. Jun. 2000;92(6):1531-6. X-1. [pmid: 10839901].
5692 Waterstone M, Bewley S, Wolfe C. Incidence and predictors of severe obstetric morbidity: case-control study. BMJ. May. 5. 2001;322(7294):1089-93. discussion 1093-4. X-1. [pmid: 11337436].
5693 Watkinson M, Dyas A. Staphylococcus aureus still colonizes the untreated neonatal umbilicus. J Hosp Infect. Jun. 1992;21(2):131-6. X-1, X-3, X-4b, X-4e, X-5. [pmid: 1353088].
5694 Watts DH, Brown ZA, Money D, et al. A double-blind, randomized, placebo-controlled trial of acyclovir in late pregnancy for the reduction of herpes simplex virus shedding and cesarean delivery. Am J Obstet Gynecol. Mar. 2003;188(3):836-43. X-4d, X-4e. [pmid: 12634667].
5695 Watts DH, Hillier SL, Eschenbach DA. Upper genital tract isolates at delivery as predictors of post-cesarean infections among women receiving antibiotic prophylaxis. Obstet Gynecol. Feb. 1991;77(2):287-92. X-9. [pmid: 1988895].
5696 Watts DH, Lambert JS, Stiehm ER, et al. Complications according to mode of delivery among human immunodeficiency virus-infected women with CD4 lymphocyte counts of < or = 500/microL. Am J Obstet Gynecol. Jul. 2000;183(1):100-7. X-1. [pmid: 10920316].
5697 Wauer RR, Schmalisch G, Menzel K, et al. The antenatal use of ambroxol (bromhexine metabolite VIII) to prevent hyaline membrane disease: a controlled double-blind study. Int J Biol Res Pregnancy. 1982;3(2):84-91. X-4e. [pmid: 7042592].
5698 Wax JR, Cartin A, Pinette MG, et al. Patient choice cesarean: an evidence-based review. Obstet Gynecol Surv. Aug. 2004;59(8):601-16. X-1, X-2. [pmid: 15277895].
5699 Wax JR, Cartin A, Pinette MG, et al. Patient choice cesarean--the Maine experience. Birth. Sep. 2005;32(3):203-6. X-1. [pmid: 16128974].
5700 Wax JR, Cartin A, Pinette MG, et al. The impact of Roux-en-Y gastric bypass surgery for morbid obesity on second trimester obstetric ultrasound completion rates. J Clin Ultrasound. Jul. 2010;38(6):283-6. X-1. [pmid: 20544862].
5701 Wax JR, Cartin A, Wolff R, et al. Pregnancy following gastric bypass surgery for morbid obesity: maternal and neonatal outcomes. Obes Surg. May. 2008;18(5):540-4. X-1. [pmid: 18317852].
5702 Wax JR, Hersey K, Philput C, et al. Single dose cefazolin prophylaxis for postcesarean infections: before vs. after cord clamping. J Matern Fetal Med. Jan-Feb. 1997;6(1):61-5. X-9. [pmid: 9029389].
5703 Wax JR, Philput C, Mather J, et al. Twin vaginal birth after cesarean. Conn Med. Apr. 2000;64(4):205-8. X-1. [pmid: 10812766].
5704 Wax JR, Seiler A, Horowitz S, et al. Interpregnancy interval as a risk factor for placenta accreta. Conn Med. Nov. 2000;64(11):659-61. X-1. [pmid: 11125633].
5705 Wax JR, Sutula K, Lerer T, et al. Labor and delivery following successful external cephalic version. Am J Perinatol. 2000;17(4):183-6. X-1. [pmid: 11041439].
5706 Wax JR, Watson WJ, Miller RC, et al. Prenatal sonographic diagnosis of hemivertebrae: associations and outcomes. J Ultrasound Med. Jul. 2008;27(7):1023-7. X-1. [pmid: 18577665].
5707 Weaver JJ, Statham H, Richards M. Are there “unnecessary” cesarean sections? Perceptions of women and obstetricians about cesarean sections for nonclinical indications. Birth. Mar. 2007;34(1):32-41. X-1. [pmid: 17324176].
5708 Webb AA, Shipton EA. Re-evaluation of i.m. ephedrine as prophylaxis against hypotension associated with spinal anaesthesia for Caesarean section. Can J Anaesth. Apr. 1998;45(4):367-9. X-9. [pmid: 9597213].
5709 Weber T, Obel E. Pregnancy complications following conization of the uterine cervix (I). Acta Obstet Gynecol Scand. 1979;58(3):259-63. X-1, X-2. [pmid: 484217].
5710 Webster J, Moore K, McMullan A. Breastfeeding outcomes for women with insulin dependent diabetes. J Hum Lact. Sep. 1995;11(3):195-200. X-1. [pmid: 7669239].
5711 Wedisinghe L, Macleod M, Murphy DJ. Use of oxytocin to prevent haemorrhage at caesarean section--a survey of practice in the United Kingdom. Eur J Obstet Gynecol Reprod Biol. Mar. 2008;137(1):27-30. X-1. [pmid: 17544563].
5712 Wee LY, Sebire NJ, Bhundia J, et al. Histomorphometric characterisation of shared and non-shared cotyledonary villus territories of monochorionic placentae in relation to pregnancy complications. Placenta. Apr-May. 2006;27(4-5):475-82. X-1. [pmid: 16023205].
5713 Weeks JW, Major CA, de Veciana M, et al. Gestational diabetes: does the presence of risk factors influence perinatal outcome?. Am J Obstet Gynecol. Oct. 1994;171(4):1003-7. X-1. [pmid: 7943062].
5714 Weerakiet S, Srisombut C, Rojanasakul A, et al. Prevalence of gestational diabetes mellitus and pregnancy outcomes in Asian women with polycystic ovary syndrome. Gynecol Endocrinol. Sep. 2004;19(3):134-40. X-1. [pmid: 15697074].
5715 Weerawetwat W, Buranawanich S, Kanawong M. Closure vs non-closure of the visceral and parietal peritoneum at cesarean delivery: 16 year study. J Med Assoc Thai. Sep. 2004;87(9):1007-11. X-9. [pmid: 15515998].
5716 Weimar CH, Lim AC, Bots ML, et al. Risk factors for uterine rupture during a vaginal birth after one previous caesarean section: a case-control study. Eur J Obstet Gynecol Reprod Biol. Jul. 2010;151(1):41-5. X-1. [pmid: 20427113].
5717 Weinstein D, Ezra Y, Picard R, et al. Expectant management of post-term patients: observations and outcome. J Matern Fetal Med. Sep-Oct. 1996;5(5):293-7. X-1. [pmid: 8930801].
5718 Weinstein L, Dyne PL, Duerbeck NB. The PROEF diet--a new postoperative regimen for oral early feeding. Am J Obstet Gynecol. Jan. 1993;168(1 Pt 1):128-31. X-9. [pmid: 8420315].
5719 Weinstein RB, Trussell J. Declining cesarean delivery rates in California: an effect of managed care?. Am J Obstet Gynecol. Sep. 1998;179(3 Pt 1):657-64. X-1. [pmid: 9757967].
5720 Weintraub AY, Levy A, Holcberg G, et al. The outcome of blunt abdominal trauma preceding birth. Int J Fertil Womens Med. Nov-Dec. 2006;51(6):275-9. X-1. [pmid: 17566571].
5721 Weiss E, Ulrich S, Berle P. Condition at birth of infants with previously absent or reverse umbilical artery end-diastolic flow velocities. Arch Gynecol Obstet. 1992;252(1):37-43. X-9. [pmid: 1417086].
5722 Weiss E, Ulrich S, Berle P, et al. CK-BB as indicator of prenatal brain-cell injury in fetuses with absent or reverse end-diastolic flow velocities of the umbilical arteries. J Perinat Med. 1994;22(3):219-26. X-1. [pmid: 7823262].
5723 Weiss JL, Malone FD, Emig D, et al. Obesity, obstetric complications and cesarean delivery rate--a population-based screening study. Am J Obstet Gynecol. Apr. 2004;190(4):1091-7. X-1. [pmid: 15118648].
5724 Weiss JL, Malone FD, Vidaver J, et al. Threatened abortion: A risk factor for poor pregnancy outcome, a population-based screening study. Am J Obstet Gynecol. Mar. 2004;190(3):745-50. X-1. [pmid: 15042008].
5725 Weiss N, Bernstein PS. Risk factor scoring for predicting venous thromboembolism in obstetric patients. Am J Obstet Gynecol. May. 2000;182(5):1073-5. X-1. [pmid: 10819831].
5726 Weiss PA, Kainer F, Haas J. Cord blood insulin to assess the quality of treatment in diabetic pregnancies. Early Hum Dev. Jul. 10. 1998;51(3):187-95. X-1. [pmid: 9692788].
5727 Weiss SL. An evaluation of muscle relaxants in cesarean sections. AANA J. Jun. 1977;45(3):306-8. X-4b. [pmid: 325986].
5728 Weiss V, Roth M. Gas chromatographic determination of methoxyflurane in maternal and foetal blood during anaesthesia for Caesarean sections. Anaesthesist. Feb. 1975;24(2):67-72. X-9. [pmid: 1122015].
5729 Weissman A, Hagay ZJ. Management of breech presentation: the 1993 Israeli census. Eur J Obstet Gynecol Reprod Biol. May. 1995;60(1):21-8. X-1. [pmid: 7635225].
5730 Weissman A, Talmon R, Jakobi P. The outcome of abdominally delivered triplets and twins: a matched case-control study. Eur J Obstet Gynecol Reprod Biol. Aug. 1998;79(2):123-5. X-1. [pmid: 9720827].
5731 Weisz B, Shrim A, Homko CJ, et al. One hour versus two hours postprandial glucose measurement in gestational diabetes: a prospective study. J Perinatol. Apr. 2005;25(4):241-4. X-1. [pmid: 15605070].
5732 Wells CE. Vaginal birth after cesarean delivery: views from the private practitioner. Semin Perinatol. Oct. 2010;34(5):345-50. X-1. [pmid: 20869551].
5733 Wen JC, Liu TC, Chen YH, et al. No increased risk of adverse pregnancy outcomes for women with myasthenia gravis: a nationwide population-based study. Eur J Neurol. Aug. 2009;16(8):889-94. X-1. [pmid: 19486132].
5734 Wen SW, Lei H, Kramer MS, et al. Determinants of intrapartum fetal death in a remote and indigent population in China. J Perinatol. Feb. 2004;24(2):77-81. X-1. [pmid: 14762450].
5735 Wen ZS, Lin L, Laufe LE, et al. The introduction of postpartum intrauterine devices in the People's Republic of China. Int J Gynaecol Obstet. Apr. 1983;21(2):151-4. X-1. [pmid: 6136435].
5736 Wendel PJ, Ramin SM, Barnett-Hamm C, et al. Asthma treatment in pregnancy: a randomized controlled study. Am J Obstet Gynecol. Jul. 1996;175(1):150-4. X-4e. [pmid: 8694041].
5737 Wendland CL. The vanishing mother: Cesarean section and “evidence-based obstetrics”. Med Anthropol Q. Jun. 2007;21(2):218-33. X-1, X-2. [pmid: 17601085].
5738 Wennberg E, Frid I, Haljamae H, et al. Colloid (3% Dextran 70) with or without ephedrine infusion for cardiovascular stability during extradural caesarean section. Br J Anaesth. Jul. 1992;69(1):13-8. X-9. [pmid: 1379056].
5739 Wennberg E, Frid I, Haljamae H, et al. Comparison of Ringer's acetate with 3% dextran 70 for volume loading before extradural caesarean section. Br J Anaesth. Nov. 1990;65(5):654-60. X-9. [pmid: 1701097].
5740 Wennerholm UB, Hamberger L, Nilsson L, et al. Obstetric and perinatal outcome of children conceived from cryopreserved embryos. Hum Reprod. Aug. 1997;12(8):1819-25. X-1. [pmid: 9308820].
5741 Wenstrom KD, Parsons MT. The prevention of meconium aspiration in labor using amnioinfusion. Obstet Gynecol. Apr. 1989;73(4):647-51. X-4e, X-5. [pmid: 2927860].
5742 Wenstrom KD, Weiner CP, Williamson RA. Antenatal treatment of fetal alloimmune thrombocytopenia. Obstet Gynecol. Sep. 1992;80(3 Pt 1):433-5. X-1. [pmid: 1495701].
5743 Werner M, Bjornsson E, Prytz H, et al. Autoimmune hepatitis among fertile women: strategies during pregnancy and breastfeeding?. Scand J Gastroenterol. Aug. 2007;42(8):986-91. X-1. [pmid: 17613929].
5744 Wessel J, Endrikat J, Buscher U. Elevated risk of neonatal outcome following denial of pregnancy: results of a one-year prospective study compared with control groups. reprinted from J Perinat Med 31 (2003) 29-35. Neonatal Intensive Care. 2003;16(7):17-22. X-1.
5745 Westergaard JG, Lange AP, Pedersen GT, et al. Use of oral oxytocics for stimulation of labor in cases of premature rupture of the membranes at term. A randomized comparative study of prostaglandin E2 tablets and demoxytocin resoriblets. Acta Obstet Gynecol Scand. 1983;62(2):111-6. X-4d. [pmid: 6575576].
5746 Westgate J, Harris M, Curnow JS, et al. Plymouth randomized trial of cardiotocogram only versus ST waveform plus cardiotocogram for intrapartum monitoring in 2400 cases. Am J Obstet Gynecol. Nov. 1993;169(5):1151-60. X-3. [pmid: 8238177].
5747 Westgren M, Dolfin T, Halperin M, et al. Mode of delivery in the low birth weight fetus. Delivery by cesarean section independent of fetal lie versus vaginal delivery in vertex presentation. A study with long-term follow-up. Acta Obstet Gynecol Scand. 1985;64(1):51-7. X-1. [pmid: 3976377].
5748 Westin B. Evaluation of a feto-pelvic scoring system in the management of breech presentations. Acta Obstet Gynecol Scand. 1977;56(5):505-8. X-1. [pmid: 602723].
5749 Wheeler AS, Harris BA. Anesthesia for pregnancy-induced hypertension. Clin Perinatol. Feb. 1982;9(1):95-111. X-1, X-2. [pmid: 7067327].
5750 Whitecar MP, Turner S, Higby MK. Adnexal masses in pregnancy: a review of 130 cases undergoing surgical management. Am J Obstet Gynecol. Jul. 1999;181(1):19-24. X-1. [pmid: 10411786].
5751 Whittle MJ, Hanretty KP, Primrose MH, et al. Screening for the compromised fetus: a randomized trial of umbilical artery velocimetry in unselected pregnancies. Am J Obstet Gynecol. Feb. 1994;170(2):555-9. X-4e. [pmid: 8116712].
5752 Whyte H, Hannah ME, Saigal S, et al. Outcomes of children at 2 years after planned cesarean birth versus planned vaginal birth for breech presentation at term: the International Randomized Term Breech Trial. Am J Obstet Gynecol. Sep. 2004;191(3):864-71. X-1. [pmid: 15467555].
5753 Wicherek L, Basta P, Sikora J, et al. RCAS1 decidual immunoreactivity in severe pre-eclampsia: immune cell presence and activity. Am J Reprod Immunol. Oct. 2007;58(4):358-66. X-1. [pmid: 17845206].
5754 Wicks E. The right to refuse medical treatment under the European Convention on Human Rights. Med Law Rev. Spring. 2001;9(1):17-40. X-1, X-2, X-3, X-4, X-5. [pmid: 14682324].
5755 Widness JA, Cowett RM, Coustan DR, et al. Neonatal morbidities in infants of mothers with glucose intolerance in pregnancy. Diabetes. Jun. Suppl 2. 1985;34:61-5. X-1. [pmid: 3996769].
5756 Widness JA, Teramo KA, Clemons GK, et al. Direct relationship of antepartum glucose control and fetal erythropoietin in human type 1 (insulin-dependent) diabetic pregnancy. Diabetologia. Jun. 1990;33(6):378-83. X-1. [pmid: 2199280].
5757 Wiese J. Factors of importance in the use-effectiveness of intrauterine devices. Dan Med Bull. Feb. 1977;24(1):23-5. X-4e. [pmid: 837738].
5758 Wig J, Biswas GC, Malhotra SK, et al. Comparison of sodium citrate with magnesium trisilicate as pre-anaesthetic antacid in emergency caesarean sections. Indian J Med Res. Mar. 1987;85:306-10. X-4b. [pmid: 3038744].
5759 Wijesiriwardana A, Bhattacharya S, Shetty A, et al. Obstetric outcome in women with threatened miscarriage in the first trimester. Obstet Gynecol. Mar. 2006;107(3):557-62. X-1. [pmid: 16507924].
5760 Wijma K, Ryding EL, Wijma B. Predicting psychological well-being after emergency caesarean section: a preliminary study. Journal of Reproductive & Infant Psychology. 2002;20(1):25-36. X-1.
5761 Wiklund I, Edman G, Andolf E. Cesarean section on maternal request: reasons for the request, self-estimated health, expectations, experience of birth and signs of depression among first-time mothers. Acta Obstet Gynecol Scand. 2007;86(4):451-6. X-1. [pmid: 17486467].
5762 Wiklund I, Edman G, Ryding EL, et al. Expectation and experiences of childbirth in primiparae with caesarean section. BJOG. Feb. 2008;115(3):324-31. X-1. [pmid: 18190368].
5763 Wiklund I, Norman M, Uvnas-Moberg K, et al. Epidural analgesia: breast-feeding success and related factors. Midwifery. Apr. 2009;25(2):e31-8. X-1. [pmid: 17980469].
5764 Wilailak S, Saropala N, Chaturachinda K. Elective induction of labor: Ramathibodi Hospital (Jan-Jun, 1990). J Med Assoc Thai. Jan. Suppl 1. 1993;76:44-7. X-1. [pmid: 8113655].
5765 Wilczynski J, Cypryk K, Zawodniak-Szalapska M, et al. The role of Staged Diabetes Management in improving diabetes care in Poland. Practical Diabetes International. 1999;16(5):137-141. X-1.
5766 Wilczynski JR, Tchorzewski H, Banasik M, et al. Lymphocyte subset distribution and cytokine secretion in third trimester decidua in normal pregnancy and preeclampsia. Eur J Obstet Gynecol Reprod Biol. Jul. 1. 2003;109(1):8-15. X-1. [pmid: 12818436].
5767 Wildemeersch DA, Schellen AM. Double-blind trial of prostaglandin F2alpha and oxytocin in the induction of labour. Curr Med Res Opin. 1976;4(4):263-6. X-4d, X-5. [pmid: 791584].
5768 Wilder-Smith CH, Hill L, Dyer RA, et al. Postoperative sensitization and pain after cesarean delivery and the effects of single im doses of tramadol and diclofenac alone and in combination. Anesth Analg. Aug. 2003;97(2):526-33. table of contents. X-9. [pmid: 12873948].
5769 Wilkes PT, Wolf DM, Kronbach DW, et al. Risk factors for cesarean delivery at presentation of nulliparous patients in labor. Obstet Gynecol. Dec. 2003;102(6):1352-7. X-1. [pmid: 14662226].
5770 Wilkinson C, McIlwaine G, Boulton-Jones C, et al. Is a rising caesarean section rate inevitable?. Br J Obstet Gynaecol. Jan. 1998;105(1):45-52. X-1. [pmid: 9442161].
5771 Willcourt RJ, Pager D, Wendel J, et al. Induction of labor with pulsatile oxytocin by a computer-controlled pump. Am J Obstet Gynecol. Feb. 1994;170(2):603-8. X-4d. [pmid: 8116721].
5772 Willet KE, Jobe AH, Ikegami M, et al. Pulmonary interstitial emphysema 24 hours after antenatal betamethasone treatment in preterm sheep. Am J Respir Crit Care Med. Sep. 2000;162(3 Pt 1):1087-94. X-1. [pmid: 10988135].
5773 Willi MJ, Winkler M, Fischer DC, et al. Chorioamnionitis: elevated interleukin-6 and interleukin-8 concentrations in the lower uterine segment. J Perinat Med. 2002;30(4):292-6. X-1. [pmid: 12235716].
5774 Williams A, Tincello DG, White S, et al. Risk scoring system for prediction of obstetric anal sphincter injury. BJOG. Aug. 2005;112(8):1066-9. X-1. [pmid: 16045519].
5775 Williams CM, Okada DM, Marshall JR, et al. Clinical and microbiologic risk evaluation for post-cesarean section endometritis by multivariate discriminant analysis: role of intraoperative mycoplasma, aerobes, and anaerobes. Am J Obstet Gynecol. Apr. 1987;156(4):967-74. X-1. [pmid: 3555082].
5776 Williams JH, Hepner DL. Risperidone and exaggerated hypotension during a spinal anesthetic. Anesth Analg. Jan. 2004;98(1):240-1. table of contents. X-1, X-2. [pmid: 14693627].
5777 Williams JK, Lewis ML, Cohen GR, et al. The sequential use of estradiol and prostaglandin E2 topical gels for cervical ripening in high-risk term pregnancies requiring induction of labor. Am J Obstet Gynecol. Jan. 1988;158(1):55-8. X-4d, X-5. [pmid: 3276201].
5778 Williams JK, Wilkerson WG, O'Brien WF, et al. Use of prostaglandin E2 topical cervical gel in high-risk patients: a critical analysis. Obstet Gynecol. Dec. 1985;66(6):769-73. X-4d. [pmid: 3906461].
5779 Williams KP, Farquharson DF, Bebbington M, et al. Screening for fetal well-being in a high-risk pregnant population comparing the nonstress test with umbilical artery Doppler velocimetry: a randomized controlled clinical trial. Am J Obstet Gynecol. May. 2003;188(5):1366-71. X-4e. [pmid: 12748513].
5780 Williams MA, Luthy DA, Zingheim RW, et al. Preinduction prostaglandin E2 gel prior to induction of labor in women with a previous cesarean section. Gynecol Obstet Invest. 1995;40(2):89-93. X-1. [pmid: 8575698].
5781 Williams MC, Knuppel RA, O'Brien WF, et al. A randomized comparison of assisted vaginal delivery by obstetric forceps and polyethylene vacuum cup. Obstet Gynecol. Nov. 1991;78(5 Pt 1):789-94. X-4e, X-5. [pmid: 1923198].
5782 Williamson W, Burks D, Pipkin J, et al. Effect of timing of fluid bolus on reduction of spinal-induced hypotension in patients undergoing elective cesarean delivery. AANA J. Apr. 2009;77(2):130-6. X-9. [pmid: 19388508].
5783 Williamson WD, Burks DS, Pipkin JM, et al. Effect of timing of fluid bolus on reduction of spinal induced hypotension in patients undergoing elective cesarean section… State of the Science Oral and Poster Sessions: part 2. AANA Journal. 2006;74(6):456-457. X-4b.
5784 Willis AT. Metronidazole in the prevention and treatment of anaerobic sepsis. Ann Ist Super Sanita. 1979;15(1):123-35. X-3. [pmid: 399831].
5785 Willis AT. Metronidazole in the prevention and treatment of anaerobic sepsis. Scand J Infect Dis Suppl. 1979;(19):98-104. X-4e. [pmid: 379992].
5786 Wilson B, Thornton JG, Hewison J, et al. The Leeds University Maternity Audit Project. Int J Qual Health Care. Jun. 2002;14(3):175-81. X-1. [pmid: 12108528].
5787 Wilson BL. The influence of hospitals, providers, and patients in birth outcomes following induction of labor. Ph.D. 2008:189. X-1, X-3, X-4e, X-5.
5788 Wilson BL, Effken J, Butler RJ. The relationship between cesarean section and labor induction. J Nurs Scholarsh. Jun. 2010;42(2):130-8. X-1. [pmid: 20618597].
5789 Wilson D, Douglas J, Heid R, et al. Preoperative dextrose does not affect spinal-induced hypotension in elective Cesarean section. Can J Anaesth. Nov. 1999;46(11):1024-9. X-9. [pmid: 10566921].
5790 Wilson KL, Zelig CM, Harvey JP, et al. Persistent pulmonary hypertension of the newborn is associated with mode of delivery and not with maternal use of selective serotonin reuptake inhibitors. Am J Perinatol. Jan. 2011;28(1):19-24. X-1. [pmid: 20607643].
5791 Wilson PD. A comparison of four methods of ripening the unfavourable cervix. Br J Obstet Gynaecol. Dec. 1978;85(12):941-4. X-4d. [pmid: 367426].
5792 Wilson RJ, Allen MJ, Nandi M, et al. Spontaneous contractions of myometrium from humans, non-human primate and rodents are sensitive to selective oxytocin receptor antagonism in vitro. BJOG. Sep. 2001;108(9):960-6. X-1. [pmid: 11563467].
5793 Wilson SH, Fecho K, Marshall J, et al. Factors influencing cesarean delivery operative times: a prospective observational cohort study. Int J Obstet Anesth. Oct. 2010;19(4):417-21. X-1, X-9. [pmid: 20833027].
5794 Windrim R, Bennett K, Mundle W, et al. Oral administration of misoprostol for labor induction: a randomized controlled trial. Obstet Gynecol. Mar. 1997;89(3):392-7. X-4d. [pmid: 9052592].
5795 Wing DA. Misoprostol vaginal insert compared with dinoprostone vaginal insert: a randomized controlled trial. Obstet Gynecol. Oct. 2008;112(4):801-12. X-4d. [pmid: 18827122].
5796 Wing DA, Fassett MJ, Guberman C, et al. A comparison of orally administered misoprostol to intravenous oxytocin for labor induction in women with favorable cervical examinations. Am J Obstet Gynecol. Jun. 2004;190(6):1689-94. discussion 1694-6. X-4d. [pmid: 15284771].
5797 Wing DA, Fassett MJ, Mishell DR. Mifepristone for preinduction cervical ripening beyond 41 weeks' gestation: a randomized controlled trial. Obstet Gynecol. Oct. 2000;96(4):543-8. X-4d, X-5. [pmid: 11004356].
5798 Wing DA, Guberman C, Fassett M. A randomized comparison of oral mifepristone to intravenous oxytocin for labor induction in women with prelabor rupture of membranes beyond 36 weeks' gestation. Am J Obstet Gynecol. Feb. 2005;192(2):445-51. X-4d, X-4e. [pmid: 15695985].
5799 Wing DA, Ham D, Paul RH. A comparison of orally administered misoprostol with vaginally administered misoprostol for cervical ripening and labor induction. Am J Obstet Gynecol. May. 1999;180(5):1155-60. X-4d. [pmid: 10329871].
5800 Wing DA, Jones MM, Rahall A, et al. A comparison of misoprostol and prostaglandin E2 gel for preinduction cervical ripening and labor induction. Am J Obstet Gynecol. Jun. 1995;172(6):1804-10. X-4d. [pmid: 7778636].
5801 Wing DA, Miller H, Parker L, et al. Misoprostol vaginal insert for successful labor induction: a randomized controlled trial. Obstet Gynecol. Mar. 2011;117(3):533-41. X-4d. [pmid: 21343755].
5802 Wing DA, Ortiz-Omphroy G, Paul RH. A comparison of intermittent vaginal administration of misoprostol with continuous dinoprostone for cervical ripening and labor induction. Am J Obstet Gynecol. Sep. 1997;177(3):612-8. X-4d. [pmid: 9322632].
5803 Wing DA, Paul RH. A comparison of differing dosing regimens of vaginally administered misoprostol for preinduction cervical ripening and labor induction. Am J Obstet Gynecol. Jul. 1996;175(1):158-64. X-4d. [pmid: 8694043].
5804 Wing DA, Paul RH. Induction of labor with misoprostol for premature rupture of membranes beyond thirty-six weeks' gestation. Am J Obstet Gynecol. Jul. 1998;179(1):94-9. X-4d, X-4e, X-5. [pmid: 9704771].
5805 Wing DA, Paul RH, Millar LK. Management of the symptomatic placenta previa: a randomized, controlled trial of inpatient versus outpatient expectant management. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):806-11. X-4e. [pmid: 8885726].
5806 Wing DA, Powers BL, Rayburn WF. Determining dose and endpoints of a controlled-release misoprostol vaginal insert for a phase III trial. J Reprod Med. Sep. 2008;53(9):695-6. X-1. [pmid: 18839824].
5807 Wing DA, Rahall A, Jones MM, et al. Misoprostol: an effective agent for cervical ripening and labor induction. Am J Obstet Gynecol. Jun. 1995;172(6):1811-6. X-4d. [pmid: 7778637].
5808 Winkler M, Rath W, Fischer DC, et al. Regulation of interleukin-8 synthesis in human lower uterine segment fibroblasts by cytokines and growth factors. Obstet Gynecol. Apr. 2000;95(4):584-8. X-1. [pmid: 10725494].
5809 Winograd RH. Uterine artery embolization for postpartum hemorrhage. Best Pract Res Clin Obstet Gynaecol. Dec. 2008;22(6):1119-32. X-1, X-2. [pmid: 18790676].
5810 Winslow EH. Hospital extra. Working smart. Rocking care. American Journal of Nursing. 1992;92(5):16G-16G. X-2.
5811 Wiruchpongsanon P. Relief of low back labor pain by using intracutaneous injections of sterile water: a randomized clinical trial. J Med Assoc Thai. May. 2006;89(5):571-6. X-4e, X-5. [pmid: 16756038].
5812 Witlin AG, Friedman SA, Sibai BM. The effect of magnesium sulfate therapy on the duration of labor in women with mild preeclampsia at term: a randomized, double-blind, placebo-controlled trial. Am J Obstet Gynecol. Mar. 1997;176(3):623-7. X-3, X-4e. [pmid: 9077617].
5813 Witlin AG, Mattar F, Sibai BM. Postpartum stroke: a twenty-year experience. Am J Obstet Gynecol. Jul. 2000;183(1):83-8. X-1. [pmid: 10920313].
5814 Wittels B, Glosten B, Faure EA, et al. Opioid antagonist adjuncts to epidural morphine for postcesarean analgesia: maternal outcomes. Anesth Analg. Nov. 1993;77(5):925-32. X-9. [pmid: 8214728].
5815 Wittels B, Glosten B, Faure EA, et al. Postcesarean analgesia with both epidural morphine and intravenous patient-controlled analgesia: neurobehavioral outcomes among nursing neonates. Anesth Analg. Sep. 1997;85(3):600-6. X-1. [pmid: 9296416].
5816 Wittels B, Glosten B, Faure EAM, et al. Postcesarean analgesia with both epidural morphine and intravenous patient-controlled analgesia: neurobehavioral outcomes among nursing neonates. reprinted from Anesthesia & Analgesia, Volume 85, Number 3, copyright 1997 by the International Anesthesia Research Society, published by Williams & Wilkins, Baltimore. Neonatal Intensive Care. 1998;11(2):42-46. X-4b.
5817 Wittels B, Scott DT, Sinatra RS. Exogenous opioids in human breast milk and acute neonatal neurobehavior: a preliminary study. Anesthesiology. Nov. 1990;73(5):864-9. X-9. [pmid: 2240676].
5818 Witter FR, Mercer BM. Improved intravaginal controlled-release prostaglandin E2 insert for cervical ripening at term. The Prostaglandin E2 insert Study Group. J Matern Fetal Med. Mar-Apr. 1996;5(2):64-9. X-4d, X-5. [pmid: 8796770].
5819 Witter FR, Rocco LE, Johnson TR. A randomized trial of prostaglandin E2 in a controlled-release vaginal pessary for cervical ripening at term. Am J Obstet Gynecol. Mar. 1992;166(3):830-4. X-4d, X-5. [pmid: 1550148].
5820 Witter FR, Weitz CM. A randomized trial of induction at 42 weeks gestation versus expectant management for postdates pregnancies. Am J Perinatol. Jul. 1987;4(3):206-11. X-4d, X-4e. [pmid: 3300672].
5821 Witter FR, Weitz CM. Cervical examination prior to induction in postdate pregnancies. Surg Gynecol Obstet. Mar. 1989;168(3):214-6. X-3, X-4d, X-4e, X-5. [pmid: 2645665].
5822 Witter S, Diadhiou M. Key informant views of a free delivery and caesarean policy in Senegal. Afr J Reprod Health. Dec. 2008;12(3):93-111. X-1. [pmid: 19435015].
5823 Wittgrove AC, Jester L, Wittgrove P, et al. Pregnancy following gastric bypass for morbid obesity. Obes Surg. Aug. 1998;8(4):461-4. discussion 465-6. X-1. [pmid: 9731683].
5824 Wiznitzer A. Obstructed labor and shoulder dystocia. Curr Opin Obstet Gynecol. Dec. 1995;7(6):486-91. X-1, X-2. [pmid: 8620085].
5825 Wohlmuth CT, Gumbs J, Quebral-Ivie J. B-Lynch suture: a case series. Int J Fertil Womens Med. Jul-Aug. 2005;50(4):164-73. X-1. [pmid: 16405101].
5826 Wolf ME, Daling JR, Voigt LF. Prior cesarean delivery in women with secondary tubal infertility. Am J Public Health. Nov. 1990;80(11):1382-3. X-1. [pmid: 2240313].
5827 Wolfe HM, Gross TL, Sokol RJ, et al. Determinants of morbidity in obese women delivered by cesarean. Obstet Gynecol. May. 1988;71(5):691-6. X-1. [pmid: 3357656].
5828 Wong CA, McCarthy RJ, Fitzgerald PC, et al. Gastric emptying of water in obese pregnant women at term. Anesth Analg. Sep. 2007;105(3):751-5. X-1, X-3, X-4e. [pmid: 17717235].
5829 Wong CA, McCarthy RJ, Sullivan JT, et al. Early compared with late neuraxial analgesia in nulliparous labor induction: a randomized controlled trial. Obstet Gynecol. May. 2009;113(5):1066-74. X-4d, X-4e. [pmid: 19384122].
5830 Wong CA, Peaceman AM. Effect of early epidural analgesia on labor: cutting through the confusion. Contemporary OB/GYN. 2006;51(7):64.
5831 Wong CA, Scavone BM, Peaceman AM, et al. The risk of cesarean delivery with neuraxial analgesia given early versus late in labor. N Engl J Med. Feb. 17. 2005;352(7):655-65. X-5 , X-6. [pmid: 15716559].
5832 Wong JO, Tan TD, Cheu NW, et al. Comparison of the efficacy of parecoxib versus ketorolac combined with morphine on patient-controlled analgesia for post-cesarean delivery pain management. Acta Anaesthesiol Taiwan. Dec. 2010;48(4):174-7. X-9. [pmid: 21195988].
5833 Wong JO, Tan TD, Leung PO, et al. Spinal anesthesia with two different dosages of 0.75% glucose-free ropivacaine: a comparison of efficacy and safety in Chinese parturients undergoing cesarean section. Acta Anaesthesiol Sin. Sep. 2003;41(3):131-8. X-9. [pmid: 14601199].
5834 Wong LF, Caughey AB, Nakagawa S, et al. Perinatal outcomes among different Asian-American subgroups. Am J Obstet Gynecol. Oct. 2008;199(4):382 e1-6. X-1. [pmid: 18722570].
5835 Wong R, Gee CL, Ledger WJ. Prophylactic use of cefazolin in monitored obstetric patients undergoing cesarean section. Obstet Gynecol. Apr. 1978;51(4):407-11. X-9. [pmid: 351488].
5836 Wong SF, Ho LC. Labour outcome of low-risk multiparas of 40 years and older. A case-control study. Aust N Z J Obstet Gynaecol. Nov. 1998;38(4):388-90. X-1. [pmid: 9890215].
5837 Wong SF, Hui SK, Choi H, et al. Does sweeping of membranes beyond 40 weeks reduce the need for formal induction of labour?. BJOG. Jun. 2002;109(6):632-6. X-4e, X-5. [pmid: 12118640].
5838 Wongcharoenkiat N, Boriboonhirunsarn D. Maternal height and the risk of cesarean delivery in nulliparous women. J Med Assoc Thai. Oct. Suppl 4. 2006;89:S65-9. X-1. [pmid: 17726812].
5839 Wood C, Renou P, Oats J, et al. A controlled trial of fetal heart rate monitoring in a low-risk obstetric population. Am J Obstet Gynecol. Nov. 1. 1981;141(5):527-34. X-1, X-4e, X-5. [pmid: 7294080].
5840 Wood RM, Simon H, Oz AU. Pelosi-type vs. traditional cesarean delivery. A prospective comparison. J Reprod Med. Sep. 1999;44(9):788-95. X-1. [pmid: 10509303].
5841 Wood SL, Chen S, Ross S, et al. The risk of unexplained antepartum stillbirth in second pregnancies following caesarean section in the first pregnancy. BJOG. May. 2008;115(6):726-31. X-1. [pmid: 18410656].
5842 Woods JR, Saywell RM Jr., Benson JT. Comparative costs of a cooperative care program versus inpatient hospital care for obstetric patients. Med Care. Jun. 1988;26(6):596-606. X-1. [pmid: 3379990].
5843 Woolbright LA. Why is the cesarean delivery rate so high in Alabama? An examination of risk factors, 1991-1993. Birth. Mar. 1996;23(1):20-5. X-1. [pmid: 8703253].
5844 Woolnough M, Allam J, Hemingway C, et al. Intra-operative fluid warming in elective caesarean section: a blinded randomised controlled trial. Int J Obstet Anesth. Oct. 2009;18(4):346-51. X-9. [pmid: 19665366].
5845 Woolnough MJ, Hemingway C, Allam J, et al. Warming of patients during Caesarean section: a telephone survey. Anaesthesia. Jan. 2009;64(1):50-3. X-1. [pmid: 19087007].
5846 Work BA Jr. Role of preventive antibiotics in patients undergoing cesarean section. South Med J. Oct. Suppl 1. 1977;70:44-5. X-9. [pmid: 333603].
5847 Worthington LM, Mulcahy AJ, White S, et al. Attitudes to oral feeding following caesarean section. Anaesthesia. Mar. 1999;54(3):292-6. X-1. [pmid: 10364870].
5848 Wray J. Review of the National Sentinel Caesarean Section Audit Report. Pract Midwife. Dec. 2001;4(11):24-5. X-1. [pmid: 12026696].
5849 Wrench IJ, Sanghera S, Pinder A, et al. Dose response to intrathecal diamorphine for elective caesarean section and compliance with a national audit standard. Int J Obstet Anesth. Jan. 2007;16(1):17-21. X-9. [pmid: 17125997].
5850 Wrich P, Whiteside J. Is amnioinfusion beneficial when umbilical cord compression is suspected during labor?. Evidence-Based Practice. 2010;13(6):9-10. X-1, X-2, X-3, X-4, X-5.
5851 Wright CH, Gardin TH, Wright CL. Obstetric care in a health maintenance organization and a private fee-for-service practice: a comparative analysis. Am J Obstet Gynecol. Aug. 15. 1984;149(8):848-56. X-1. [pmid: 6465249].
5852 Wright JD, Herzog TJ, Shah M, et al. Regionalization of care for obstetric hemorrhage and its effect on maternal mortality. Obstet Gynecol. Jun. 2010;115(6):1194-200. X-1. [pmid: 20502290].
5853 Wright M. The value of X-ray pelvimetry in previous caesarean section pregnancies. S Afr Med J. Sep. 14. 1985;68(6):409-11. X-1. [pmid: 4035514].
5854 Writer WD, Dewan DM, James FM 3rd. Three per cent 2-chloroprocaine for caesarean section: appraisal of a standardized dose technique. Can Anaesth Soc J. Sep. 1984;31(5):559-64. X-1. [pmid: 6498571].
5855 Writer WD, Hurtig JB, Evans D, et al. Epidural morphine prophylaxis of postoperative pain: report of a double-blind multicentre study. Can Anaesth Soc J. Jul. 1985;32(4):330-8. X-9. [pmid: 3896432].
5856 Wu HC, Liu YC, Ou KL, et al. Effects of acupuncture on post-cesarean section pain. Chin Med J (Engl). Aug. 5. 2009;122(15):1743-8. X-9. [pmid: 19781318].
5857 Wu JI, Lo Y, Chia YY, et al. Prevention of postoperative nausea and vomiting after intrathecal morphine for Cesarean section: a randomized comparison of dexamethasone, droperidol, and a combination. Int J Obstet Anesth. Apr. 2007;16(2):122-7. X-9. [pmid: 17275282].
5858 Wu JL, Hsu MS, Hsu TC, et al. The efficacy of intrathecal coadministration of morphine and bupivacaine for labor analgesia. Acta Anaesthesiol Sin. Dec. 1997;35(4):209-16. X-1. [pmid: 9553236].
5859 Wu JM, Hundley AF, Visco AG. Elective primary cesarean delivery: attitudes of urogynecology and maternal-fetal medicine specialists. Obstet Gynecol. Feb. 2005;105(2):301-6. X-1. [pmid: 15684156].
5860 Wu S, Kocherginsky M, Hibbard JU. Abnormal placentation: twenty-year analysis. Am J Obstet Gynecol. May. 2005;192(5):1458-61. X-1. [pmid: 15902137].
5861 Wu X, Sallinen K, Anttila L, et al. Expression of insulin-receptor substrate-1 and -2 in ovaries from women with insulin resistance and from controls. Fertil Steril. Sep. 2000;74(3):564-72. X-1. [pmid: 10973656].
5862 Wu YW, March WM, Croen LA, et al. Perinatal stroke in children with motor impairment: a population-based study. Pediatrics. Sep. 2004;114(3):612-9. X-1. [pmid: 15342829].
5863 Wu YW, Seah YS, Chung KT, et al. Postoperative pain relief in primigravida caesarean section patients--combination of intrathecal morphine and epinephrine. Acta Anaesthesiol Sin. Sep. 1999;37(3):111-4. X-1. [pmid: 10609343].
5864 Wu Z, Viisainen K, Li X, et al. Maternal care in rural China: a case study from Anhui province. Neonatal Intensive Care. 2009;22(5):26-31. X-1.
5865 Wuest S, Raio L, Wyssmueller D, et al. Effects of female genital mutilation on birth outcomes in Switzerland. BJOG. Aug. 2009;116(9):1204-9. X-1. [pmid: 19459862].
5866 Wylie BJ, Gilbert S, Landon MB, et al. Comparison of transverse and vertical skin incision for emergency cesarean delivery. Obstet Gynecol. Jun. 2010;115(6):1134-40. X-1. [pmid: 20502282].
5867 Wylie BR, Kong J, Kozak SE, et al. Normal perinatal mortality in type 1 diabetes mellitus in a series of 300 consecutive pregnancy outcomes. Am J Perinatol. May. 2002;19(4):169-76. X-1. [pmid: 12012277].
5868 Wyszynski DF, Wu T. Prenatal and perinatal factors associated with isolated oral clefting. Cleft Palate Craniofac J. May. 2002;39(3):370-5. X-1. [pmid: 12019016].
5869 Xavier P, Ayres-De-Campos D, Reynolds A, et al. The modified Misgav-Ladach versus the Pfannenstiel-Kerr technique for cesarean section: a randomized trial. Acta Obstet Gynecol Scand. Sep. 2005;84(9):878-82. X-9. [pmid: 16097980].
5870 Xenakis EM, Langer O, Piper JM, et al. Low-dose versus high-dose oxytocin augmentation of labor--a randomized trial. Am J Obstet Gynecol. Dec. 1995;173(6):1874-8. X-5. [pmid: 8610779].
5871 Xenakis EM, Piper JM, Field N, et al. Preeclampsia: is induction of labor more successful?. Obstet Gynecol. Apr. 1997;89(4):600-3. X-1. [pmid: 9083320].
5872 Xiong X, Saunders LD, Wang FL, et al. Gestational diabetes mellitus: prevalence, risk factors, maternal and infant outcomes. Int J Gynaecol Obstet. Dec. 2001;75(3):221-8. X-1. [pmid: 11728481].
5873 Xirasagar S, Lin HC. Maternal request CS--role of hospital teaching status and for-profit ownership. Eur J Obstet Gynecol Reprod Biol. May. 2007;132(1):27-34. X-1. [pmid: 16837120].
5874 Xirasagar S, Lin HC, Liu TC. Do group practices have lower caesarean rates than solo practice obstetric clinics? Evidence from Taiwan. Health Policy Plan. Jul. 2006;21(4):319-25. X-1. [pmid: 16790455].
5875 Xu J, Chen H, Ma T, et al. Termination of early pregnancy in the scarred uterus with mifepristone and misoprostol. Int J Gynaecol Obstet. Mar. 2001;72(3):245-51. X-1. [pmid: 11226445].
5876 Xu S, Liu L, Lu S, et al. Clinical observation on vertical transmission of human papillomavirus. Chin Med Sci J. Mar. 1998;13(1):29-31. X-1. [pmid: 11717920].
5877 Yadav S, Saxena U, Yadav R, et al. Hypertensive disorders of pregnancy and maternal and foetal outcome: a case controlled study. J Indian Med Assoc. Oct. 1997;95(10):548-51. X-1. [pmid: 9567600].
5878 Yahya SZ, Williams J, Mathers A, et al. Variations in the management of singleton breech presentation throughout Scotland. Scott Med J. Oct. 1998;43(5):144-5. X-1. [pmid: 9854300].
5879 Yakoob MY, Lawn JE, Darmstadt GL, et al. Stillbirths: Epidemiology, Evidence, and Priorities for Action. Seminars in Perinatology. 2010;34(6):387-394. X-1, X-2. [pmid: 21094413].
5880 Yalti S, Oral O, Gurbuz B, et al. Ratio of middle cerebral to umbilical artery blood velocity in preeclamptic & hypertensive women in the prediction of poor perinatal outcome. Indian J Med Res. Jul. 2004;120(1):44-50. X-1. [pmid: 15299232].
5881 Yamada H, Kishida T, Kobayashi N, et al. Massive immunoglobulin treatment in women with four or more recurrent spontaneous primary abortions of unexplained aetiology. Hum Reprod. Sep. 1998;13(9):2620-3. X-1. [pmid: 9806295].
5882 Yamada T, Minakami H, Matsubara S, et al. Meconium-stained amniotic fluid exhibits chemotactic activity for polymorphonuclear leukocytes in vitro. J Reprod Immunol. Feb. 2000;46(1):21-30. X-1. [pmid: 10708241].
5883 Yamani TY, Rouzi AA. Induction of labor with vaginal prostaglandin-E2 in grand multiparous women with one previous cesarean section. Int J Gynaecol Obstet. Jun. 1999;65(3):251-3. X-1. [pmid: 10428344].
5884 Yamani Zamzami TY. Vaginal birth after cesarean section in grand multiparous women. Arch Gynecol Obstet. Jul. 2004;270(1):21-4. X-1. [pmid: 15224215].
5885 Yamani-Zamzami TY. Delivery outcomes at term after one previous cesarean section. Saudi Med J. Dec. 2007;28(12):1845-9. X-1. [pmid: 18060214].
5886 Yamasmit W, Chaithongwongwatthana S. Risk factors for cesarean hysterectomy in tertiary center in Thailand: a case-control study. J Obstet Gynaecol Res. Feb. 2009;35(1):60-5. X-1. [pmid: 19215549].
5887 Yancey MK, Harlass FE, Benson W, et al. The perioperative morbidity of scheduled cesarean hysterectomy. Obstet Gynecol. Feb. 1993;81(2):206-10. X-1. [pmid: 8423951].
5888 Yang Q, Wen SW, Chen Y, et al. Neonatal mortality and morbidity in vertex-vertex second twins according to mode of delivery and birth weight. J Perinatol. Jan. 1. 2006;26(1):3-10. X-1. [pmid: 16307004].
5889 Yang Q, Wen SW, Phillips K, et al. Comparison of maternal risk factors between placental abruption and placenta previa. Am J Perinatol. Apr. 2009;26(4):279-86. X-1. [pmid: 19021090].
5890 Yang YW, Chen CS, Chen YH, et al. Psoriasis and pregnancy outcomes: a nationwide population-based study. J Am Acad Dermatol. Jan. 2011;64(1):71-7. X-1. [pmid: 20970879].
5891 Yarnell RW, Polis T, Reid GN, et al. Patient-controlled analgesia with epidural meperidine after elective cesarean section. Reg Anesth. Nov-Dec. 1992;17(6):329-33. X-9. [pmid: 1286054].
5892 Yasin SY, Beydoun SN. Pregnancy outcome at greater than or equal to 20 weeks' gestation in women in their 40s. A case-control study. J Reprod Med. Feb. 1988;33(2):209-13. X-1. [pmid: 3351820].
5893 Yasmeen S, Romano PS, Schembri ME, et al. Accuracy of obstetric diagnoses and procedures in hospital discharge data. Am J Obstet Gynecol. Apr. 2006;194(4):992-1001. X-1. [pmid: 16580288].
5894 Yasmeen S, Wilkins EE, Field NT, et al. Pregnancy outcomes in women with systemic lupus erythematosus. J Matern Fetal Med. Apr. 2001;10(2):91-6. X-1. [pmid: 11392599].
5895 Yasuda R, Takeuchi K, Funakoshi T, et al. Bioelectrical impedance analysis in the clinical management of preeclamptic women with edema. J Perinat Med. 2003;31(4):275-80. X-1. [pmid: 12951881].
5896 Yau G, Gin T, Ewart MC, et al. Propofol for induction and maintenance of anaesthesia at caesarean section. A comparison with thiopentone/enflurane. Anaesthesia. Jan. 1991;46(1):20-3. X-9. [pmid: 1996746].
5897 Yau G, Kan AF, Gin T, et al. A comparison of omeprazole and ranitidine for prophylaxis against aspiration pneumonitis in emergency caesarean section. Anaesthesia. Feb. 1992;47(2):101-4. X-9. [pmid: 1539776].
5898 Yazicioglu F, Gokdogan A, Kelekci S, et al. Incomplete healing of the uterine incision after caesarean section: Is it preventable?. Eur J Obstet Gynecol Reprod Biol. Jan. 1. 2006;124(1):32-6. X-9. [pmid: 16023780].
5899 Yazigi A, Chalhoub V, Madi-Jebara S, et al. Prophylactic ondansetron is effective in the treatment of nausea and vomiting but not on pruritus after cesarean delivery with intrathecal sufentanil-morphine. J Clin Anesth. May. 2002;14(3):183-6. X-9. [pmid: 12031749].
5900 Yeast JD, Garite TR. The role of cervical cerclage in the management of preterm premature rupture of the membranes. Am J Obstet Gynecol. Jan. 1988;158(1):106-10. X-1. [pmid: 3337156].
5901 Yee HY. Quantitative determination of lecithin and sphingomyelin in amniotic fluid. Clin Chem. Nov. 1982;28(11):2241-3. X-1. [pmid: 6290105].
5902 Yee I, Carstoniu J, Halpern S, et al. A comparison of two doses of epidural fentanyl during caesarean section. Can J Anaesth. Aug. 1993;40(8):722-5. X-9. [pmid: 8403156].
5903 Yeh HM, Chen LK, Lin CJ, et al. Prophylactic intravenous ondansetron reduces the incidence of intrathecal morphine-induced pruritus in patients undergoing cesarean delivery. Anesth Analg. Jul. 2000;91(1):172-5. X-9. [pmid: 10866907].
5904 Yeh J, Leipzig S, Friedman EA, et al. Results of in vitro fertilization pregnancies: experience at Boston's Beth Israel Hospital. Int J Fertil. Mar-Apr. 1990;35(2):116-9. X-1. [pmid: 1970980].
5905 Yeh YC, Chen SY, Lin CJ, et al. Differential analgesic effect of tenoxicam on post-cesarean uterine cramping pain between primiparous and multiparous women. J Formos Med Assoc. Sep. 2005;104(9):647-51. X-9. [pmid: 16276439].
5906 Yentur EA, Topcu I, Ekici Z, et al. The effect of epidural and general anesthesia on newborn rectal temperature at elective cesarean section. Braz J Med Biol Res. Sep. 2009;42(9):863-7. X-9. [pmid: 19738991].
5907 Yeo SN, Lo WK. Bispectral index in assessment of adequacy of general anaesthesia for lower segment caesarean section. Anaesth Intensive Care. Feb. 2002;30(1):36-40. X-1. [pmid: 11939437].
5908 Yildirim G, Gungorduk K, Guven HZ, et al. When should we perform prophylactic antibiotics in elective cesarean cases?. Arch Gynecol Obstet. Jul. 2009;280(1):13-8. X-9. [pmid: 19034470].
5909 Yilmazer M, Kurtay G, Sonmezer M, et al. Factor V Leiden and prothrombin 20210 G-A mutations in controls and in patients with thromboembolic events during pregnancy or the puerperium. Arch Gynecol Obstet. Oct. 2003;268(4):304-8. X-1. [pmid: 14504875].
5910 Ying H, Duan T, Bao YR, et al. Transverse annular compression sutures in the lower uterine segment to control postpartum hemorrhage at cesarean delivery for complete placenta previa. Int J Gynaecol Obstet. Mar. 2010;108(3):247-8. X-1. [pmid: 19939381].
5911 Yip SK, Lau TK, Rogers MS. A study on prophylactic antibiotics in cesarean sections--is it worthwhile?. Acta Obstet Gynecol Scand. Jul. 1997;76(6):547-9. X-9. [pmid: 9246960].
5912 YM AM, Elussein EA, Omer MM, et al. Heparin and aspirin in pregnant Sudanese women with recurrent miscarriage associated with antiphospholipid antibodies. Afr J Reprod Health. Aug. 2007;11(2):95-8. X-1. [pmid: 20690292].
5913 Yoder BA, Kirsch EA, Barth WH, et al. Changing obstetric practices associated with decreasing incidence of meconium aspiration syndrome. Obstet Gynecol. May. 2002;99(5 Pt 1):731-9. X-1. [pmid: 11978280].
5914 Yoder PR, Gibbs RS, Blanco JD, et al. A prospective, controlled study of maternal and perinatal outcome after intra-amniotic infection at term. Am J Obstet Gynecol. Mar. 15. 1983;145(6):695-701. X-1. [pmid: 6829656].
5915 Yogev Y, Ben-Haroush A, Chen R, et al. Active induction management of labor for diabetic pregnancies at term; mode of delivery and fetal outcome--a single center experience. Eur J Obstet Gynecol Reprod Biol. Jun. 15. 2004;114(2):166-70. X-1. [pmid: 15140510].
5916 Yogev Y, Ben-Haroush A, Gilboa Y, et al. Induction of labor with vaginal prostaglandin E2. J Matern Fetal Neonatal Med. Jul. 2003;14(1):30-4. X-1. [pmid: 14563089].
5917 Yogev Y, Ben-Haroush A, Horowitz ER, et al. PGE2 induction of labor for consistent decreased perception of fetal movements at term. Int J Gynaecol Obstet. Aug. 2003;82(2):173-8. X-1. [pmid: 12873778].
5918 Yogev Y, Ben-Haroush A, Lahav E, et al. Induction of labor with prostaglandin E2 in women with previous cesarean section and unfavorable cervix. Eur J Obstet Gynecol Reprod Biol. Oct. 15. 2004;116(2):173-6. X-1. [pmid: 15358459].
5919 Yogev Y, Langer O. Pregnancy outcome in obese and morbidly obese gestational diabetic women. Eur J Obstet Gynecol Reprod Biol. Mar. 2008;137(1):21-6. X-1. [pmid: 17517462].
5920 Yokoi R, Suda S, Kobayashi K, et al. Differential susceptibility of rat embryos to methyl methanesulfonate during the pregastrulation period. J Toxicol Sci. Dec. 2007;32(5):495-503. X-1. [pmid: 18198481].
5921 Yokoyama K, Suzuki M, Shimada Y, et al. Effect of administration of pre-warmed intravenous fluids on the frequency of hypothermia following spinal anesthesia for Cesarean delivery. J Clin Anesth. Jun. 2009;21(4):242-8. X-9. [pmid: 19502035].
5922 Yonekura ML, Appleman M, Wallace R, et al. Predictive value of amniotic-membrane cultures for the development of postcesarean endometritis. Rev Infect Dis. Mar-Apr. Suppl 1. 1984;6:S157-64. X-1. [pmid: 6372024].
5923 Yonekura ML, Songster G, Smith-Wallace T. Preinduction cervical priming with PGE2 intracervical gel. Am J Perinatol. Oct. 1985;2(4):305-10. X-4d. [pmid: 3863624].
5924 Yoo KY, Jeong CW, Kang MW, et al. Bispectral index values during sevoflurane-nitrous oxide general anesthesia in women undergoing cesarean delivery: a comparison between women with and without prior labor. Anesth Analg. Jun. 2008;106(6):1827-32. X-1. [pmid: 18499617].
5925 Yoo KY, Jeong CW, Park BY, et al. Effects of remifentanil on cardiovascular and bispectral index responses to endotracheal intubation in severe pre-eclamptic patients undergoing Caesarean delivery under general anaesthesia. Br J Anaesth. Jun. 2009;102(6):812-9. X-9. [pmid: 19429669].
5926 Yoon BH, Lee CM, Kim SW. An abnormal umbilical artery waveform: a strong and independent predictor of adverse perinatal outcome in patients with preeclampsia. Am J Obstet Gynecol. Sep. 1994;171(3):713-21. X-1. [pmid: 8092220].
5927 Yoong W, Kolhe S, Karoshi M, et al. The obstetric performance of United Kingdom asylum seekers from Somalia: a case-control study and literature review. Int J Fertil Womens Med. Jul-Aug. 2005;50(4):175-9. X-1. [pmid: 16405102].
5928 Yoong W, Wagley A, Fong C, et al. Obstetric performance of ethnic Kosovo Albanian asylum seekers in London: a case-control study. J Obstet Gynaecol. Aug. 2004;24(5):510-2. X-1. [pmid: 15369928].
5929 York R, Brown LP. Women with diabetes during pregnancy: sociodemographics, outcomes, and costs of care. Public Health Nurs. Oct. 1995;12(5):290-3. X-1. [pmid: 7479536].
5930 York S, Briscoe L, Walkinshaw S, et al. Why women choose to have a repeat caesarean section. British Journal of Midwifery. 2005;13(7):440-445. X-1.
5931 Yoshimura S, Masuzaki H, Miura K, et al. Effect of epidermal growth factor on lung growth in experimental fetal pulmonary hypoplasia. Early Hum Dev. Jan. 2000;57(1):61-9. X-1. [pmid: 10690712].
5932 Yost NP, Bloom SL, Sibley MK, et al. A hospital-sponsored quality improvement study of pain management after cesarean delivery. Am J Obstet Gynecol. May. 2004;190(5):1341-6. X-9. [pmid: 15167840].
5933 Young A, Thomson AJ, Ledingham M, et al. Immunolocalization of proinflammatory cytokines in myometrium, cervix, and fetal membranes during human parturition at term. Biol Reprod. Feb. 2002;66(2):445-9. X-1. [pmid: 11804961].
5934 Young BK, Klein SA, Katz M, et al. Intravenous dexamethasone for prevention of neonatal respiratory distress: A prospective controlled study. Am J Obstet Gynecol. Sep. 15. 1980;138(2):203-9. X-4e. [pmid: 7424985].
5935 Young DC, Popat R, Luther ER, et al. Influence of maternal oxygen administration on the term fetus before labor. Am J Obstet Gynecol. Feb. 1. 1980;136(3):321-4. X-3, X-4b, X-5. [pmid: 7352522].
5936 Young R, Platt L, Ledger W. Prophylactic cefoxitin in cesarean section. Surg Gynecol Obstet. Jul. 1983;157(1):11-4. X-9. [pmid: 6344283].
5937 Young RC, Zhang P. The mechanism of propagation of intracellular calcium waves in cultured human uterine myocytes. Am J Obstet Gynecol. May. 2001;184(6):1228-34. X-1. [pmid: 11349193].
5938 Young TK, Woodmansee B. Factors that are associated with cesarean delivery in a large private practice: the importance of prepregnancy body mass index and weight gain. Am J Obstet Gynecol. Aug. 2002;187(2):312-8. discussion 318-20. X-1. [pmid: 12193918].
5939 Youngstrom PC, Cowan RI, Sutheimer C, et al. Pain relief and plasma concentrations from epidural and intramuscular morphine in post-cesarean patients. Anesthesiology. Nov. 1982;57(5):404-9. X-9. [pmid: 6897154].
5940 Yousef AA, Amr YM. The effect of adding magnesium sulphate to epidural bupivacaine and fentanyl in elective caesarean section using combined spinal-epidural anaesthesia: a prospective double blind randomised study. Int J Obstet Anesth. Oct. 2010;19(4):401-4. X-9. [pmid: 20833531].
5941 Yu CC, Chuah EC, Ng YT, et al. Neonatal status in cesarean section under epidural anesthesia with supplementary oxygen. Ma Zui Xue Za Zhi. Dec. 1992;30(4):229-36. X-1. [pmid: 1344237].
5942 Yu PY, Gambling DR. A comparative study of patient-controlled epidural fentanyl and single dose epidural morphine for post-caesarean analgesia. Can J Anaesth. May. 1993;40(5 Pt 1):416-20. X-9. [pmid: 8513520].
5943 Yu SC, Ngan Kee WD, Kwan AS. Addition of meperidine to bupivacaine for spinal anaesthesia for Caesarean section. Br J Anaesth. Mar. 2002;88(3):379-83. X-9. [pmid: 11990270].
5944 Yu VY, Loke HL, Szymonowicz W. Outcome of singleton infants delivered vaginally or by caesarean section at 23 to 28 weeks' gestation. Aust N Z J Obstet Gynaecol. Aug. 1987;27(3):196-200. X-1. [pmid: 3325017].
5945 Yuen PM, Pang HY, Chung T, et al. Cervical ripening before induction of labour in patients with an unfavourable cervix: a comparative randomized study of the Atad Ripener Device, prostaglandin E2 vaginal pessary, and prostaglandin E2 intracervical gel. Aust N Z J Obstet Gynaecol. Aug. 1996;36(3):291-5. X-4d, X-5. [pmid: 8883753].
5946 Yun E, Topulos GP, Body SC, et al. Pulmonary function changes during epidural anesthesia for cesarean delivery. Anesth Analg. Apr. 1996;82(4):750-3. X-9. [pmid: 8615492].
5947 Yun EM, Marx GF, Santos AC. The effects of maternal position during induction of combined spinal-epidural anesthesia for cesarean delivery. Anesth Analg. Sep. 1998;87(3):614-8. X-9. [pmid: 9728840].
5948 Zahn J, Bernstein H, Hossain S, et al. Comparison of non-invasive blood pressure measurements on the arm and calf during cesarean delivery. J Clin Monit Comput. 2000;16(8):557-62. X-9. [pmid: 12580231].
5949 Zahran KM, Shahin AY, Abdellah MS, et al. Sublingual versus vaginal misoprostol for induction of labor at term: a randomized prospective placebo-controlled study. J Obstet Gynaecol Res. Dec. 2009;35(6):1054-60. X-4d. [pmid: 20144171].
5950 Zaiss I, Kehl S, Petri E, et al. Umbilical cord blood donation during caesarean section does not lead to increased maternal blood loss. In Vivo. May-Jun. 2010;24(3):339-40. X-1. [pmid: 20555010].
5951 Zakowski MI, Ramanathan S, Turndorf H. A two-dose epidural morphine regimen for cesarean section patients: therapeutic efficacy. Acta Anaesthesiol Scand. Oct. 1992;36(7):698-701. X-9. [pmid: 1441873].
5952 Zamzami TY. A comparison of induction with vaginal prostaglandin E2 versus spontaneous of labor in grand multiparous women. Arch Gynecol Obstet. Dec. 2005;273(3):176-9. X-1. [pmid: 16160873].
5953 Zamzami TY. Prelabor rupture of membranes at term in low-risk women: induce or wait?. Arch Gynecol Obstet. Feb. 2006;273(5):278-82. X-1. [pmid: 16208479].
5954 Zanardo V, Caroni G, Burlina A. Higher homocysteine concentrations in women undergoing caesarean section under general anesthesia. Thromb Res. 2003;112(1-2):33-6. X-1. [pmid: 15013270].
5955 Zanetta G, Tampieri A, Currado I, et al. Changes in cesarean delivery in an Italian university hospital, 1982-1996: a comparison with the national trend. Birth. Sep. 1999;26(3):144-8. X-1, X-4b, X-4e. [pmid: 10655813].
5956 Zareian Z, Zareian P. Non-closure versus closure of peritoneum during cesarean section: a randomized study. Eur J Obstet Gynecol Reprod Biol. Sep-Oct. 2006;128(1-2):267-9. X-9. [pmid: 16716491].
5957 Zaremba W, Grunert E, Aurich JE. Prophylaxis of respiratory distress syndrome in premature calves by administration of dexamethasone or a prostaglandin F2 alpha analogue to their dams before parturition. Am J Vet Res. Apr. 1997;58(4):404-7. X-1. [pmid: 9099388].
5958 Zaretsky MV, Alexander JM, McIntire DD, et al. Magnetic resonance imaging pelvimetry and the prediction of labor dystocia. Obstet Gynecol. Nov. 2005;106(5 Pt 1):919-26. X-1. [pmid: 16260507].
5959 Zdeb MS, Therriault GD, Logrillo VM. Frequency, spacing, and outcome of pregnancies subsequent to primary cesarean childbirth. Am J Obstet Gynecol. Sep. 15. 1984;150(2):205-12. X-1, X-2, X-4b, X-5. [pmid: 6476041].
5960 Zeanah M, Schlosser SP. Adherence to ACOG guidelines on exercise during pregnancy: effect on pregnancy outcome. J Obstet Gynecol Neonatal Nurs. Jul-Aug. 1993;22(4):329-35. X-1.
5961 Zeisler H, Joura EA, Bancher-Todesca D, et al. Prophylactic cerclage in pregnancy. Effect in women with a history of conization. J Reprod Med. Jul. 1997;42(7):390-2. X-1. [pmid: 9252928].
5962 Zelop C, Nadel A, Frigoletto FD Jr., et al. Placenta accreta/percreta/increta: a cause of elevated maternal serum alpha-fetoprotein. Obstet Gynecol. Oct. 1992;80(4):693-4. X-1. [pmid: 1383899].
5963 Zelop CM, Shipp TD, Cohen A, et al. Trial of labor after 40 weeks' gestation in women with prior cesarean. Obstet Gynecol. Mar. 2001;97(3):391-3. X-1. [pmid: 11239643].
5964 Zelop CM, Shipp TD, Repke JT, et al. Uterine rupture during induced or augmented labor in gravid women with one prior cesarean delivery. Am J Obstet Gynecol. Oct. 1999;181(4):882-6. X-1. [pmid: 10521747].
5965 Zelop CM, Shipp TD, Repke JT, et al. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. Oct. 2001;185(4):903-5. X-1. [pmid: 11641675].
5966 Zera CA, Seely EW. Diabetes: Treatment of gestational diabetes reduces obstetric morbidity. Nat Rev Endocrinol. Feb. 2010;6(2):69-70. X-1, X-2. [pmid: 20098447].
5967 Zeteroglu S, Engin-Ustun Y, Ustun Y, et al. A prospective randomized study comparing misoprostol and oxytocin for premature rupture of membranes at term. J Matern Fetal Neonatal Med. May. 2006;19(5):283-7. X-3, X-4d, X-5. [pmid: 16753768].
5968 Zeteroglu S, Sahin I, Gol K. Cesarean delivery rates in adolescent pregnancy. Eur J Contracept Reprod Health Care. Jun. 2005;10(2):119-22. X-1. [pmid: 16147817].
5969 Zeteroglu S, Ustun Y, Engin-Ustun Y, et al. Peripartum hysterectomy in a teaching hospital in the eastern region of Turkey. Eur J Obstet Gynecol Reprod Biol. May. 1. 2005;120(1):57-62. X-1. [pmid: 15866087].
5970 Zezai A, Apers L, Zishiri C. Caesarean section rate as a process indicator of safe motherhood programmes: the case of Midlands Province. Cent Afr J Med. May. 2001;47(5):129-34. X-1, X-4e, X-5. [pmid: 11921671].
5971 Zhang J, Landy HJ, Branch DW, et al. Contemporary patterns of spontaneous labor with normal neonatal outcomes. Obstet Gynecol. Dec. 2010;116(6):1281-7. X-1. [pmid: 21099592].
5972 Zhang J, Liu Y, Meikle S, et al. Cesarean delivery on maternal request in southeast China. Obstet Gynecol. May. 2008;111(5):1077-82. X-1. [pmid: 18448738].
5973 Zhang J, Savitz DA. Maternal age and placenta previa: a population-based, case-control study. Am J Obstet Gynecol. Feb. 1993;168(2):641-5. X-1. [pmid: 8438945].
5974 Zhang J, Troendle J, Reddy UM, et al. Contemporary cesarean delivery practice in the United States. Am J Obstet Gynecol. Oct. 2010;203(4):326 e1-326 e10. X-1. [pmid: 20708166].
5975 Zhang W, Song Y, He X, et al. Prevalence and risk factors of overactive bladder syndrome in Fuzhou Chinese women. Neurourol Urodyn. 2006;25(7):717-21. X-1. [pmid: 16944449].
5976 Zhang W, Wang L, Liu L. The study of levels of norepinephrine and dopamine-beta-hydroxylase in patients with pregnancy-induced hypertension. Zhonghua Yi Xue Za Zhi (Taipei). Jun. 2001;64(6):351-6. X-1. [pmid: 11534803].
5977 Zhang W, Zhao Y, Yin Y. The relationship between catecholamines levels in mother and fetus, and pathogenesis of pregnancy-induced hypertension. Chin Med J (Engl). Jul. 2003;116(7):1108-9. X-1. [pmid: 12890395].
5978 Zhang Y, Zhao YY, Qiao J. Obstetric outcome of women with uterine anomalies in China. Chin Med J (Engl). Feb. 20. 2010;123(4):418-22. X-1. [pmid: 20193480].
5979 Zhang YL, Liu JT, Gao JS, et al. Influential and prognostic factors of small for gestational age infants. Chin Med J (Engl). Feb. 20. 2009;122(4):386-9. X-1. [pmid: 19302741].
5980 Zhou HY, Li L, Li D, et al. Clinical observation on the treatment of post-cesarean hypogalactia by auricular points sticking-pressing. Chin J Integr Med. Apr. 2009;15(2):117-20. X-9. [pmid: 19407949].
5981 Zhou ZQ, Shao Q, Zeng Q, et al. Lumbar wedge versus pelvic wedge in preventing hypotension following combined spinal epidural anaesthesia for caesarean delivery. Anaesth Intensive Care. Nov. 2008;36(6):835-9. X-9. [pmid: 19115653].
5982 Zhu XM, Han T, Sargent IL, et al. Differential expression profile of microRNAs in human placentas from preeclamptic pregnancies vs normal pregnancies. Am J Obstet Gynecol. Jun. 2009;200(6):661 e1-7. X-1. [pmid: 19285651].
5983 Zhuang Y, Huang L. Uterine artery embolization compared with methotrexate for the management of pregnancy implanted within a cesarean scar. Am J Obstet Gynecol. Aug. 2009;201(2):152 e1-3. X-3, X-4e. [pmid: 19527897].
5984 Ziadeh S. Obstetric outcome of teenage pregnancies in North Jordan. Arch Gynecol Obstet. Mar. 2001;265(1):26-9. X-1. [pmid: 11327089].
5985 Ziadeh S, Yahaya A. Pregnancy outcome at age 40 and older. Arch Gynecol Obstet. Mar. 2001;265(1):30-3. X-1. [pmid: 11327090].
5986 Ziadeh SM. Maternal and perinatal outcome in nulliparous women aged 35 and older. Gynecol Obstet Invest. 2002;54(1):6-10. X-1. [pmid: 12297710].
5987 Ziadeh SM, Abu-Heija AT. Duration of labor in patients delivered vaginally after one previous lower segment cesarean section. Int J Gynaecol Obstet. Jun. 1994;45(3):213-5. X-1. [pmid: 7926238].
5988 Ziadeh SM, Sunna E. Obstetric and perinatal outcome of pregnancies with term labour and meconium-stained amniotic fluid. Arch Gynecol Obstet. Sep. 2000;264(2):84-7. X-1. [pmid: 11045329].
5989 Zimmer EZ, Jakobi P, Weissman A, et al. Maternal and fetal digoxin-like immunoreactive factor in elective cesarean sections and spontaneous vaginal delivery. Eur J Obstet Gynecol Reprod Biol. Jul-Aug. 1990;36(1-2):53-8. X-1. [pmid: 2163927].
5990 Ziogos E, Tsiodras S, Matalliotakis I, et al. Ampicillin/sulbactam versus cefuroxime as antimicrobial prophylaxis for cesarean delivery: a randomized study. BMC Infect Dis. 2010;10:341. X-9. [pmid: 21118502].
5991 Zite N, Wuellner S, Gilliam M. Failure to obtain desired postpartum sterilization: risk and predictors. Obstet Gynecol. Apr. 2005;105(4):794-9. X-1. [pmid: 15802407].
5992 Zlatnik FJ. The Iowa premature breech trial. Am J Perinatol. Jan. 1993;10(1):60-3. X-4b, X-4c, X-4e. [pmid: 8442804].
5993 Zohar E, Luban I, Zunser I, et al. Patient-controlled bupivacaine wound instillation following cesarean section: the lack of efficacy of adjuvant ketamine. J Clin Anesth. Nov. 2002;14(7):505-11. X-9. [pmid: 12477585].
5994 Zohar E, Shapiro A, Eidinov A, et al. Postcesarean analgesia: the efficacy of bupivacaine wound instillation with and without supplemental diclofenac. J Clin Anesth. Sep. 2006;18(6):415-21. X-9. [pmid: 16980157].
5995 Zollinger TW, Saywell RM Jr., Hubbs OA 3rd, et al. Assessing prenatal care in a family practice residency clinic. Fam Med. Nov-Dec. 1997;29(10):736-42. X-1. [pmid: 9397365].
5996 Zorlu CG, Turan C, Isik AZ, et al. Emergency hysterectomy in modern obstetric practice. Changing clinical perspective in time. Acta Obstet Gynecol Scand. Feb. 1998;77(2):186-90. X-1. [pmid: 9512325].
5997 Zorzoli A, Soliani A, Perra M, et al. Cervical changes throughout pregnancy as assessed by transvaginal sonography. Obstet Gynecol. Dec. 1994;84(6):960-4. X-1. [pmid: 7970477].
5998 Zubor P, Szunyogh N, Dokus K, et al. Application of uterotonics on the basis of regular ultrasonic evaluation of the uterus prevents unnecessary surgical intervention in the postpartum period. Arch Gynecol Obstet. Sep. 2010;282(3):261-7. X-1. [pmid: 19760186].
5999 Zwart JJ, Richters JM, Ory F, et al. Uterine rupture in The Netherlands: a nationwide population-based cohort study. BJOG. Jul. 2009;116(8):1069-78. discussion 1078-80. X-1. [pmid: 19515148].