# Exact Search Strings and Results

Table A1 PubMed search strategies

Search terms | | Search results
#1 | (cesarean section[mh:noexp] OR cesarean[tiab] OR caesarean[tiab] OR c-section[tiab]) AND pregnancy[mh] | 38234
#2 | randomized controlled trial[pt] OR controlled clinical trial[pt] OR random allocation[mh] OR double-blind method[mh] OR single-blind method[mh] OR clinical trial[pt] OR “clinical trial”[tiab] OR random[tiab] OR randomized[tiab] OR randomly[tiab] OR control[tiab] OR controlled[tiab] OR controls[tiab] OR interrupted time series[tiab] OR ecologic[tiab] OR delivery of health care[majr] OR health services research[majr] | 3072065
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 6966
#4 | #3 AND newspaper article[pt] | 7
#5 | #3 AND letter[pt] | 102
#6 | #3 AND comment[pt] | 92
#7 | #3 AND case reports[pt] | 340
#8 | #3 AND review[pt] | 552
#9 | #3 AND practice guideline[pt] | 11
#10 | #3 AND clinical conference[pt] | 3
#11 | #3 AND editorial[pt] | 36
#12 | #3 AND historical article[pt] | 10
#13 | #3 AND meta-analysis[pt] | 149
#14 | #3 AND congresses[pt] | 5
#15 | #3 AND in vitro[pt] | 50
#16 | #3 AND retracted publication[pt] | 1
#17 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16) | 5822

Key: [mh] Medical Subject Heading; [mh:noexp] Medical Subject Heading not including narrower subject terms; [majr] Medical Subject Heading as main focus of article; [tiab] title/abstract word; [pt] publication type

* Note: numbers do not tally as some articles are excluded in more than one category.

Table A2 CINAHL search results

Search terms | | Search results
#1 | “cesarean” OR (MH “Cesarean Section”) OR “caesarean” OR “c-section” | 7755
#2 | (MH “Pregnancy”) OR “pregnancy” | 80117
#3 | #1 AND #2 | 6447
#4 | (MH “Clinical Trials”) OR “randomized controlled trial” OR (MH “Random Assignment”) OR “random allocation” OR “random assignment” OR “clinical trial” OR random OR randomized OR randomly OR controlled OR control OR controls OR “interrupted time series” OR ecologic OR (MH “Health Care Delivery”) OR (MH “Health Services Research”) | 494241
#5 | #3 AND #4 AND English Language | 1684
#6 | #5 AND Publication Type: Letter | 77
#7 | #5 AND Publication Type: Commentary | 145
#8 | #5 AND Publication Type: Case study | 67
#9 | #5 AND Publication Type: Review | 81
#10 | #5 AND Publication Type: Practice Guidelines | 11
#11 | #5 AND Publication Type: Editorial | 24
#12 | #5 AND Publication Type: Historical Material | 0
#13 | #5 AND Publication Type: Anecdote | 5
#14 | #5 AND Publication Type: Interview | 1
#15 | #5 AND Publication Type: Proceedings | 2
#16 | #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 | 337
#17 | #5 NOT #16 | 1347
#18 | #17 Exclude MEDLINE records | 214

KEY: MH major heading