# Acronyms/Abbreviations/Symbols

±: plus or minus
≤: less than or equal to
≥: greater than or equal to
%: percent
AE: adverse events
AHRQ: Agency for Healthcare Research and Quality
AROM: artificial rupture of membranes
BMI: body mass index
BP: blood pressure
bpm: beats per minute
CDC: Center for Disease Control and Prevention
CER: comparative effectiveness review
CI: confidence interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
cm: centimeter
cm/min: centimeter per minute
CS: cesarean
°C: degree Celsius
CSE: combined spinal epidural
CTG: cardiotocography
ECG: electrocardiogram
EFM: electronic fetal monitoring
EPC: Evidence-based Practice Centers
EPDS: Edinburgh Postnatal Depression Scale
et al.: and others
etc.: et cetera
FBS: Fetal blood sampling
FHR: fetal heart rate
fl: fluid liter
FSPO_2_: Fetal oxygenation
°F: degree Fahrenheit
g: gram(s)
HIE: hypoxic-ischemic encephalopathy
HIV: human immunodeficiency virus
hr(s): hour(s)
IM: intramuscular
In: inch
IQR: interquartile range
IUPC: Intrauterine pressure catheter
IV: intravenous
kg: kilogram
kPa(s)/min: kilopascal per minute(s)
KQ: Key Question
L, l: liter
MAS: meconium aspiration syndrome
max: maximum
mg: milligram
mg/ml: milligram per milliliter
min: minute(s)
mL, ml: milliliter
mmHg: millimeters of mercury
mU/min: milliunit per minute
n: number
NHS: National Health Services
NICU: neonatal intensive care unit
NOQAS: Newcastle-Ottawa Quality Assessment Scale
NR: not reported
NRFS: nonreassuring fetal status
NS: not significant
OR: odds ratio
O_2_: oxygen
P, p: p value
PCO_2_: partial pressure of carbon dioxide
pH: power of hydrogen
PICOTS: Population(s), Intervention(s), Outcome(s), Timing, and Setting
PO_2_: partial pressure of oxygen
PROM: premature rupture of membrane
pt: patient
RCT: randomized controlled trial
RN: registered nurse(s)
ROB: Cochrane Risk of Bias
RR: relative risk
SD: standard deviation
SE: standard error
SEM: standard error of mean
STAN: ST segment analysis
TEP: technical expert panel
U.K., UK: United Kingdom
U.S., US: United States
VBAC: vaginal birth after cesarean
vs., v: versus
w/: with
wk(s): week(s)
yr(s): year(s)
μg/l: micrograms per liter