# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

Dr. Melissa McPheeters, Co-Director of the Evidence-based Practice Center, was crucial in conferring on and guiding review methods, including searches, data extraction, quality rating, strength-of-evidence reporting, and applicability assessment. She was especially helpful as a neutral adjudicator and as a sounding board for challenging decisions about scope and focus.

Dr. Mark Hartmann brought his extraordinary attention to detail—and his commitment to perfection—to completion of the evidence tables. He spent time checking and rechecking tables both for formatting and for content. His ability to point out inconsistencies and enhance uniformity was key to ensuring smooth development of the evidence tables.

Ms. Kerry Harville served as project coordinator, shepherding innumerable planning, implementation, and writing tasks to completion. She guided and contributed to production of the plethora of forms, spreadsheets, and tables that are required to produce reliable evidence tables and summary data. Her attentiveness to the needs of the investigator team and to pacing the work was especially valued.

Mr. Songphan Choemprayon's support of Ms. Jerome, including a detailed approach to abstract and full-text review, was invaluable.