# Appendix H List of Studies Included in Meta-Analyses

Amador-Licona, 2000 ^85^
Aronoff, 2000 ^165^
Baba, 1983 ^133^
Bailey, 2005 ^101^
Bakris, 2003 ^66^
Baksi, 2004 ^126^
Barnett, 2003 ^172^
Bech, 2003 ^197^
Betteridge, 2005 ^157^
Birkeland, 1994 ^110^
Blonde, 2002 ^81^
Campbell, 1994 ^83^
Cefalu, 1998 ^261^
Charbonnel, 2005 ^63^
Charpentier, 2001 ^89^
DeFronzo, 1995 ^88^
Del, Prato, 2003 ^149^
Derosa, 2003 ^118^
Derosa, 2004 ^90^
Dills, 1996 ^107^
Dornan, 1991 ^260^
Draeger, 1996 ^112^
Einhorn, 2000 ^160^
Erle, 1999 ^127^
Feinglos, 2005 ^104^
Fonseca, 2000 ^103^
Forst, 2005 ^145^
Garber, 1997 ^217^
Garber, 2002 ^79^
Garber, 2003 ^80^
Goldberg, 1996 ^134^
Goldberg, 1998 ^139^
Goldstein, 2003 ^82^
Gomez-Perez, 2002 ^102^
Grant, 1996 ^154^
Gregorio, 1999 ^129^
Hallsten, 2002 ^58^
Hanefeld, 2004 ^60^
Harrower, 1985 ^113^
Hasche, 1999 ^138^
Hermann, 1991 ^94^
Hermann, 1991 ^159^
Hermann, 1994 ^87^
Herz, 2003 ^163^
Horton, 2000 ^96^
Inukai, 2005 ^111^
Jovanovic, 2000 ^194^
Kardas, 2005 ^114^
Kerenyi, 2004 ^125^
Kilo, 1988 ^147^
Kim, 2005 ^152^
Kipnes, 2001 ^166^
Landgraf, 1999 ^121^
Lawrence, 2004 ^54^
Lebovitz, 2001 ^169^
Lee, 1998 ^259^
Leonhardt, 1991 ^263^
Luis Bautista, 2003 ^193^
Madsbad, 2001 ^119^
Manzella, 2004 ^148^
Marbury, 1999 ^116^
Mari, 2005 ^262^
Marre, 2002 ^84^
Matthews, 2005 ^70^
Moses, 2001 ^218^
Nakamura, 2000 ^64^
Natali, 2004 ^144^
Nishio, 2006 ^151^
Noury, 1991 ^86^
Patel, 1999 ^167^
Pavo, 2003 ^59^
Pfutzner, 2005 ^68^
Pfutzner, 2006 ^123^
Phillips, 2001 ^168^
Rachmani, 2002 ^150^
Ramachandran, 2004 ^55^
Rosenbaum, 2002 ^153^
Rosenblatt, 2001 ^162^
Rosenstock, 1993 ^109^
Rosenstock, 1996 ^189^
Rosenstock, 2006 ^124^
Saad, 2004 ^164^
Saloranta, 2002 ^241^
Schade, 1998 ^135^
Scherbaum, 2002 ^141^
Schernthaner, 2004 ^56^
Schneider, 1991 ^173^
Simonson, 1997 ^136^
Smith, 2005 ^161^
St John Sutto, 2002 ^67^
Tan, 2004 ^65^
Tan, 2004a ^69^
Testa, 1998 ^198^
Teupe, 1991 ^155^
Tosi, 2003 ^95^
Tseng, 2005 ^140^
UKPDS, 1985 ^91^
Vakkilainen, 2002 ^122^
Virtanen, 2003 ^143^
Vongthavaravat, 2002 ^170^
Vray, 1995 ^137^
Weissman, 2005 ^100^
Willms, 1999 ^99^
Wolever, 2000 ^98^
Wolffenbuttel, 1993 ^120^
Wolffenbuttel, 1999 ^117^
Wolffenbuttel, 2000 ^171^
Yamanouchi, 2005 ^57^
Yanagawa, 2004 ^62^
Zhu, 2003 ^188^