# Appendix G Placebo-Controlled Meta-Analyses

Figure 1b. Meta-analysis of post-treatment difference in hemoglobin A1c between rosiglitazone and placebo/diet in patients with type 2 diabetes

Figure 1c. Meta-analysis of post-treatment difference in hemoglobin A1c between metformin and placebo/diet in patients with type 2 diabetes

Figure 1d. Meta-analysis of post-treatment difference in hemoglobin A1c between second generation sulfonylureas and placebo/diet in patients with type 2 diabetes

Figure 1e. Meta-analysis of post-treatment difference in hemoglobin A1c between repaglinide and placebo/diet in patients with type 2 diabetes

Figure 1f. Meta-analysis of post-treatment difference in hemoglobin A1c between nateglinide and placebo/diet in patients with type 2 diabetes

Figure 2b. Meta-analysis of post-treatment difference in weight between rosiglitazone and placebo/diet in patients with type 2 diabetes

Figure 2c. Meta-analysis of post-treatment difference in weight between metformin and placebo/diet in patients with type 2 diabetes

Figure 2d. Meta-analysis of post-treatment difference in weight between second generation sulfonylurea and placebo/diet in patients with type 2 diabetes

Figure 2e. Meta-analysis of post-treatment difference in weight between alpha-glucosidase inhibitors and placebo/diet in patients with type 2 diabetes

Figure 3b. Meta-analysis of post-treatment difference in systolic blood pressure effect between metformin and placebo/diet in patients with type 2 diabetes

Figure 4b. Meta-analysis of post-treatment difference in low density lipoprotein effect between rosiglitazone and placebo/diet in patients with type 2 diabetes

Figure 4c. Meta-analysis of post-treatment difference in low density lipoprotein effect between metformin and placebo/diet in patients with type 2 diabetes

Figure 5b. Meta-analysis of post-treatment difference in triglycerides between rosiglitazone and placebo/diet in patients with type 2 diabetes

Figure 5c. Meta-analysis of post-treatment difference in triglycerides between metformin and placebo/diet in patients with type 2 diabetes

Figure 6a. Incidence of subjects with hypoglycemia in randomized controlled trials comparing pioglitazone with placebo/diet

Figure 6b. Incidence of subjects with hypoglycemia in randomized controlled trials comparing rosiglitazone with placebo/diet

Figure 6c. Incidence of subjects with hypoglycemia in randomized controlled trials comparing metformin with placebo/diet

Figure 6d. Incidence of subjects with hypoglycemia in randomized controlled trials comparing second generation sulfonylureas with placebo/diet

Figure 6e. Incidence of subjects with hypoglycemia in randomized controlled trials comparing repaglinide with placebo/diet