# Appendix F Evidence Tables

Table 1 Evidence Table. Quality of systematic reviews

Author, year | Question clearly stated | Search methods described / comprehensive | Inclusion criteria reported / appropriate | Study quality assessed / appropriate | Reproducible methodology demonstrated | Variation in results discussed | Results combined appropriately | Conclusions supported by data
Saenz, 2005 ^17^ | Yes | Yes / Yes | Yes / Yes | Yes / Yes | Yes | Yes | Yes | Yes
Van de Laar, 2005 ^38^ | Yes | Yes / Yes | Yes / Yes | Yes/ Partially | Yes | Yes | Yes | Yes
Chiquette, 2004 ^301^ | Yes | Yes / Partially | Yes / Yes | Partially / Partially | Can't tell | Yes | Yes | Yes
Wulffele, 2004 ^302^ | Yes | Yes / Partially | Yes / Yes | Yes / Yes | Can't tell | Partially | Yes | Yes
Meriden, 2004 ^303^ | Partially | Partially / Partially | Partially / No | No / Can't tell | Can't tell | No | No | Partially
Czoski-Murray, 2004 ^304^ | Yes | Yes / Yes | Yes / Yes | Yes / Yes | Can't tell | Partially | Yes | Yes
Buse, 2004 ^25^ | Yes | Yes / Partially | Yes / Yes | No / Can't tell | Can't tell | Partially | No | Partially
Stades, 2004 ^305^ | Yes | Yes / Yes | Yes / Yes | Yes / Partially | Partially | Yes | Yes | Yes
Salpeter, 2003 ^306^ | Yes | Yes / Yes | Yes / Yes | Yes / Yes | Yes | Yes | Yes | Yes
van Wijk, 2003 ^307^ | Yes | Yes / Partially | Yes / Yes | No / Can't tell | Can't tell | Yes | Yes | Yes
Salas, 2002 ^308^ | Yes | Partially / Partially | Partially / Yes | No / Can't tell | Can't tell | Partially | Yes | Yes
Inzucchi, 2002 ^266^ | Yes | Partially / Partially | Yes / Partially | No / Can't tell | Can't tell | Yes | Yes | Yes
Chilcott, 2001 ^267^ | Yes | Partially / Partially | Yes / Yes | Yes / Yes | Can't tell | Yes | Yes | Yes
Levien, 2001 ^309^ | Partially | Partially / Partially | No / Can't tell | No / No | Can't tell | Partially | No | Partially
Chilcott, 2001 ^310^ | Yes | Yes / Yes | Yes / Yes | Yes / Yes | Can't tell | Yes | Yes | Yes
Culy, 2001 ^311^ | No | Yes / Partially | Partially / Yes | No / Can't tell | Can't tell | No | Can't tell | Partially
Campbell, 2000 ^312^ | Partially | Partially / No | Yes / Partially | No / Can't tell | Can't tell | No | Yes | Yes
Johansen, 1999 ^313^ | Yes | Yes / Yes | Partially / Can't tell | No / Can't tell | Can't tell | Partially | Yes | Yes
Chan, 1999 ^314^ | Partially | Partially / Partially | No / Can't tell | No / Can't tell | Can't tell | No | Can't tell | Partially
McCartney, 1999 ^315^ | Partially | Yes / Yes | No / Can't tell | No / Can't tell | Can't tell | No | No | No
Campbell, 1998 ^316^ | Yes | Yes / Partially | No / No | No / No | Can't tell | No | Can't tell | Yes
Campbell, 1996 ^317^ | Yes | No / Can't tell | Yes / Yes | No / No | Can't tell | No | No | No
Melchior, 1996 ^318^ | Yes | Partially / Partially | Yes / Yes | No / Can't tell | Can't tell | No | No | Yes
Campbell, 1995 ^319^ | Yes | Yes / Partially | Yes / Yes | No / Can't tell | Can't tell | No | Yes | Yes
Campbell, 1985 ^320^ | Yes | Partially / Partially | Partially / Can't tell | No / Can't tell | Can't tell | No | Can't tell | Yes
Vreven, 2005 ^321^ | Yes | Partially / Partially | Partially / Can't tell | No / Can't tell | Can't tell | No | Can't tell | Yes
Kimmel, 2005 ^39^ | Partially | Partially / Partially | Yes / Yes | No / Can't tell | Can't tell | No | Partially | Yes
Chandler, 2005 ^19^ | Yes | Yes / Partially | Yes / Yes | Yes / Yes | Can't tell | Partially | Partially | Yes

Table 2 Evidence Table. Study design characteristics table for studies reporting on proximal clinical outcomes (Key Question 1)

Author, year | Study design | Country | Pharmaceutical support | Study duration (planned/mean) | Exclusion criteria
Study group
Ramachandran, 2004 ^55^ | RCT | India | NR | 14 weeks (planned duration) | Age <30 or >60, treatment experienced, HbA1c >11%, no type 2 diabetes, other
Rosenbaum, 2002 ^153^ | RCT | Brazil | NR | 24 weeks (planned duration) | Age <40 or >65, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
Nishio, 2006 ^151^ | RCT | Japan | NR | 6 months (planned duration) | Any liver disease, any kidney disease, no type 2 diabetes, other
Weissman, 2005 ^100^ | RCT | US | Yes | 24 weeks (planned duration) | Age <18 or >75, any liver disease, any kidney disease, history of CVD, HbA1c <6.5 or >8.5 for patients having received prior combination treatment; <7 or >10 prior monotherapy or drug naive patients, no type 2 diabetes, other
Rosenstock, 2006 ^124^ | RCT | US, Canada | NR | NR | Age <60, history of CVD, no type 2 diabetes, other
Bailey, 2005 ^101^ | RCT | UK, 14 European countries | Yes | 24 weeks (planned duration) | Age <18 or >70, history of CVD, no type 2 diabetes, other
Pfutzner, 2006 ^123^ | RCT | Germany | Yes | 16 weeks (planned duration) | NR
Betteridge, 2005 ^157^ | RCT | UK | Yes | 104 weeks (planned duration) | Age<35 or >75, HbA1c <7.5 or >11, no type 2 diabetes
Kardas, 2005 ^114^ | RCT | Poland | NR | NR | Age <40 or >75, HbA1c >9.0%, no type 2 diabetes, other
DIACOM
Forst, 2005 ^145^ | RCT | Germany | Yes | 24 weeks (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, HbA1c <6.6 or >9.9, no type 2 diabetes, other
Yamanouchi, 2005 ^57^ | RCT | Japan | NR | 12 months (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, HbA1c <7.0, no type 2 diabetes, other
Goldberg, 2005 ^52^ | RCT | US, Puerto Rico, Mexico, and Columbia | Yes | 24 weeks (planned duration) | Age <35, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7 or >11.5, if naive to antihyperglycemic therapy; <7 or >9.5 if previously treated with oral antihyperglycemic therapy, no type 2 diabetes, other
Pfutzner, 2005 ^68^ | RCT | Germany | Yes | 26 weeks (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, HbA1c <6.6% or >9.9%, other
Derosa, 2005 ^53^ | RCT | Italy | NR | NR | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5%, no type 2 diabetes, other
Derosa, 2005 ^72^ | RCT | Italy | NR | 12 months (planned duration) | Age <18, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5, no type 2 diabetes, other
Inukai, 2005 ^111^ | RCT | Japan | NR | 6 months (planned duration) | NR
Brunetti, 2004 ^322^ | RCT, cross-over | Italy | NR | 3 months (planned duration) | Age <35 or >70, any liver disease, any kidney disease, history of CVD, HbA1c <8.5, no type 2 diabetes, other
Langenfeld, 2005 ^146^ | RCT | Germany | Yes | 24 weeks (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, HbA1c <6.6 or >9.9, no type 2 diabetes, other
Feinglos, 2005 ^104^ | RCT | US | Yes | 16 weeks (planned duration) | Age <30 or >81, any liver disease, any kidney disease, history of CVD, HbA1c <7.0 or >8.5, no type 2 diabetes, other
Mari, 2005 ^262^ | RCT | 12 unspecified countries | Yes | 24 weeks (planned duration) | Age <31, any liver disease, history of CVD, treatment experienced, no type 2 diabetes, other
Goke, 2002 ^75^ | RCT | Germany | Yes | 26 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5 or >11.5, no type 2 diabetes, other
German Pioglitazone Study Group
Charbonnel, 2005 ^63^ | RCT | 14 European countries, Australia, Canada, South Africa and Israel | Yes | 52 weeks (planned duration) | Age <35 or >75, treatment experienced, HbA1c <7.5 or >11, no type 2 diabetes, other
Tan, 2005 ^61^ | RCT | Canada, UK, Australia, Finland, Poland, The Slovak Republic and South Africa | Yes | 104 weeks (planned duration) | Age <35 or >75, treatment experienced, HbA1c <7.5 or >11 with diet alone, no type 2 diabetes, other
One year extension study for Quartet study group
McCluskey, 2004 ^76^ | RCT | US | Yes | 30 weeks (planned duration) | Age <18 or >80, treatment experienced, HbA1c <7.5 or >9.5, no type 2 diabetes, other
Kim, 2005 ^152^ | RCT | Korea | NR | 12 weeks (planned duration) | Any liver disease, any kidney disease, treatment experienced, HbA1c <7.5, no type 2 diabetes, other
Schernthaner, 2004 ^56^ | RCT | Europe | NR | 12 months (planned duration) | Age <35 or >75, treatment experienced, HbA1c <7.5 or >11, no type 2 diabetes
Smith, 2005 ^161^ | RCT | US | Yes | 24 weeks (planned duration) | Age <35 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Choi, 2004 ^77^ | RCT | Korea | NR | 6 months (planned duration) | Any liver disease, any kidney disease, other
Matthews, 2005 ^70^ | RCT | Europe and Australia | Yes | 52 months (planned duration) | Age <35 or >75, history of CVD, HbA1c <7.5 or >11, no type 2 diabetes, other
Derosa, 2004 ^90^ | RCT | Italy | NR | 12 months (planned duration) | Age <46 or >67, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Schernthaner, 2004 ^106^ | RCT | Austria, Belgium, Czech Republic, France, Germany, Hungary, Italy, Netherlands, Poland, Slovakia, Spain, and United Kingdom | NR | 27 weeks (planned duration) | Age <35, any liver disease, any kidney disease, HbA1c <6.9 or >11.5, no type 2 diabetes, other
Tan, 2004 ^65^ | RCT | Denmark, Finland, Norway, and Sweden | Yes | 52 weeks (planned duration) | Treatment experienced, HbA1c <7.5 or >11 for patients not receiving ODM, <7.5 or >9.5 for patients receiving ODM, no type 2 diabetes, other
Baksi, 2004 ^126^ | RCT | 7 European countries | Yes | 26 weeks (planned duration) | Age <35 or >80, any liver disease, history of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Tan, 2004 ^69^ | RCT | Mexico | Yes | NR | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5 or >11 in patients who were not receiving ODMs, and <7.5 or >9.5 in patients who were receiving ODM monotherapy, no type 2 diabetes, other
Natali, 2004 ^144^ | RCT | London and Italy | Yes | 16 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c >10 after washout, other
Saad, 2004 ^164^ | RCT | US | Yes | 12 weeks (planned duration) | Age <18 or >73, any liver disease, any kidney disease, history of CVD, treatment experienced, other
Rosenstock, 2004 ^131^ | RCT | US | Yes | 16 weeks (planned duration) | Age <18, females, treatment experienced, no type 2 diabetes, other
Raskin, 2004 ^74^ | RCT | US | Yes | 12 titration and 12 maintenance weeks (planned duration) | Age <18, HbA1c <7 or >12 during previous monotherapy with sulfonylurea or metformin at 50% or more of maximal recommended dose for at least 3 months, no type 2 diabetes, other
Yanagawa, 2004 ^62^ | RCT | Japan | NR | 12 weeks (planned duration) | Age <40 or >80, any liver disease, HbA1c <7 or >10, no type 2 diabetes, other
Manzella, 2004 ^148^ | RCT | Italy | NR | 4 months (planned duration) | History of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Feinbock, 2003 ^130^ | RCT | Austria | Yes | 26 weeks (planned duration) | Age <36 or >80, any liver disease, any kidney disease, treatment experienced, HbA1c <7.8, no type 2 diabetes, other
Kerenyi, 2004 ^125^ | RCT | 15 countries | Yes | 26 weeks (planned duration) | Age <35 or >80, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Jovanovic, 2004 ^73^ | RCT | US | Yes | 12 titration and 12 maintenance weeks (planned duration) | Age <18, HbA1c <7 or >12, no type 2 diabetes, other
Hanefeld, 2004 ^60^ | RCT | Canada, UK, Hungary, Finland, Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and the Netherlands | Yes | NR | Age <35 or >75, history of CVD, HbA1c <7.5 or >11, no type 2 diabetes, other
QUARTET study group
Lawrence, 2004 ^54^ | RCT | UK | Yes | 12 titration and 12 maintenance weeks (planned duration) | Age <45 or >80, any liver disease, any kidney disease, history of CVD, HbA1c for diet treated diabetes: <7% or >10% and for low-dose oral hypoglycemic therapy: >7.5, no type 2 diabetes, other
Garber, 2003 ^80^ | RCT | US | Yes | 16 weeks (planned duration) | Age<20 or >79, any liver disease, any kidney disease, treatment experienced, HbA1c >7 or <12, no type 2 diabetes, other
Takagi, 2003 ^78^ | RCT | Japan | NR | NR | Any liver disease, any kidney disease, no type 2 diabetes, other
Tosi, 2003 ^95^ | RCT, cross-over | Italy | Yes | 6 months (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.3, no type 2 diabetes, other
Goldstein, 2003 ^82^ | RCT | US | Yes | 18 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5 and >12.0, other
Herz, 2003 ^163^ | RCT | Canada and Spain | Yes | 16 weeks (planned duration) | Any liver disease, any kidney disease, treatment experienced, HbA1c <6.5 or >9.8, no type 2 diabetes, other
Bech, 2003 ^197^ | RCT | Australia, Croatia, Czech Republic, France, Greece, Israel, Macedonia, Poland, Russia, Slovenia, and Spain | Yes | NR | Age<40 years, any liver disease, history of CVD, treatment experienced, no type 2 diabetes, other
Derosa, 2003 ^97^ | RCT | Italy | NR | 12 months (planned duration) | Any kidney disease, history of CVD, treatment experienced, HbA1c <7, no type 2 diabetes, other
Barnett, 2003 ^172^ | RCT | UK | NR | 26 weeks (planned duration) | Age<30 or >80, any liver disease, HbA1c <7.5, no type 2 diabetes, other
Fujioka, 2003 ^105^ | RCT | US | Yes | 24 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, HbA1c >8.5 and FPG>200 mg/dl while on metformin immediate release for >=8 weeks, no type 2 diabetes, other
Derosa, 2003 ^118^ | RCT | Italy | NR | 12 months (planned duration) | Any kidney disease, history of CVD, HbA1c <7.0%, no type 2 diabetes, other
Zhu, 2003 ^188^ | RCT | China | Yes | 24 weeks (planned duration) | Age<40 or >70, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5, no type 2 diabetes, other
Del Prato, 2003 ^149^ | RCT | France, Italy, Netherlands | NR | 29 weeks (planned duration) | Age<35 or >70, HbA1c <7.5 or >10 after run-in period, no type 2 diabetes, other
Pavo, 2003 ^59^ | RCT | Russia and Hungary | Yes | 32 weeks (planned duration) | Age<40, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7.5 or >11.0, no type 2 diabetes, other
Luis Bautista, 2003 ^193^ | RCT | US | Yes | 14 weeks (planned duration) | Age<35 or >80, HbA1c <8.0 or >10.5, no type 2 diabetes, other
Bakris, 2003 ^66^ | RCT | US and UK | Yes | 52 weeks (planned duration) | NR
Vongthavaravat, 2002 ^170^ | RCT | India, Thailand, Philippines, Tunisia, Argentina, and Brazil | Yes | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, no type 2 diabetes, other
Virtanen, 2003 ^143^ | RCT | Finland | Yes | 26 weeks (planned duration) | Age <45 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, no type 2 diabetes, other
Vakkilainen, 2002 ^122^ | RCT | Finland | Yes | 12 weeks (planned duration) | Age<18 or >75, any liver disease, any kidney disease, HbA1c <6.5 or >10, no type 2 diabetes, other
Cefalu, 2002 ^323^ | RCT | US | NR | 18 weeks (planned duration) | Age<35 or >70, HbA1c <7, no type 2 diabetes, other
Hallsten, 2002 ^58^ | RCT | Finland | Yes | 26 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Scherbaum, 2002 ^141^ | RCT | Germany | Yes | 26 weeks (planned duration) | Age<35 or >70, any liver disease, history of CVD, HbA1c <7.5 or >12, no type 2 diabetes, other
Blonde, 2002 ^81^ | RCT | US | Yes | 16 weeks (planned duration) | Age<30 or >75, any liver disease, any kidney disease, history of CVD, HbA1c <7.4, no type 2 diabetes, other
St John Sutto, 2002 ^67^ | RCT | US | Yes | 52 weeks (planned duration) | Age<40 or >80, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Rachmani, 2002 ^150^ | RCT | Israel | NR | 4 years (planned duration) | Age <40 or >75, no type 2 diabetes, other
Saloranta, 2002 ^241^ | RCT | Argentina, Australia, Belgium, Canada, Finland, France, Germany, Italy, Netherlands, New Zealand, Sweden, and US | Yes | 24 weeks (planned duration) | Age <30, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Marre, 2002 ^84^ | RCT | Netherlands, Denmark, Portugal, France, Belgium | Yes | 4 months (planned duration) | Age<18, any liver disease, any kidney disease, history of CVD, other
Garber, 2002 ^79^ | RCT | US | Yes | 20 weeks (planned duration) | Any liver disease, any kidney disease, treatment experienced, HbA1c <7% or >11%, no type 2 diabetes, other
Gomez-Perez, 2002 ^102^ | RCT | Mexico | Yes | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Khan, 2002 ^51^ | RCT | US | NR | 16 weeks (planned duration) | Any liver disease, other
Charpentier, 2001 ^89^ | RCT | France | Yes | 20 weeks (planned duration) | Age <= 34 or >= 71, any kidney disease, history of CVD, no type 2 diabetes, other
Rosenblatt, 2001 ^162^ | RCT | US | Yes | 16 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, HbA1c <8.0, no type 2 diabetes, other
Madsbad, 2001 ^119^ | RCT | Denmark and Scandinavia | Yes | 12 months (planned duration) | Age <=39 or >=76, any liver disease, any kidney disease, HbA1c <6.5 or >10, no type 2 diabetes, other
Kipnes, 2001 ^166^ | RCT | US | Yes | NR | Age <30 or >75, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <8, no type 2 diabetes, other
Amador-Licona, 2000 ^85^ | RCT | Mexico | NR | 12 weeks (planned duration) | Age >65, any liver disease, history of CVD, other
Lebovitz, 2001 ^169^ | RCT | US | NR | 26 weeks (planned duration) | Age <36 or >81, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Patel, 1999 ^167^ | RCT | US | NR | 12 weeks (planned duration) | Age <30 or >80, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Phillips, 2001 ^168^ | RCT | US | Yes | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, neuropathy, no type 2 diabetes, other
Moses, 2001 ^218^ | RCT | 13 countries | Yes | 16 weeks (planned duration) | Age <40, any liver disease, history of CVD, treatment experienced, no type 2 diabetes, other
Einhorn, 2000 ^160^ | RCT | US | Yes | 16 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <8.0, no type 2 diabetes, other
Fonseca, 2000 ^103^ | RCT | US | NR | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Nakamura, 2000 ^64^ | RCT | Japan | NR | 3 months (planned duration) | Any liver disease, history of CVD, treatment experienced, HbA1c <6.5, no type 2 diabetes, other
Horton, 2000 ^96^ | RCT | US | Yes | 24 weeks (planned duration) | Age <30, any kidney disease, HbA1c <6.8 or >11, no type 2 diabetes, other
Aronoff, 2000 ^165^ | RCT | US | Yes | 26 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7, no type 2 diabetes, other
Hanefeld, 2000 ^190^ | RCT | Europe | Yes | 12 weeks (planned duration) | Age <30 or >75, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c mean level of two tests <6.8 or >10.5, no type 2 diabetes, other
Hasche, 1999 ^138^ | RCT | Germany | NR | 104 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <7.5 or >9.5%, no type 2 diabetes, other
Wolffenbuttel, 2000 ^171^ | RCT | Italy, UK, France, Spain, Holland, and Switzerland | Yes | 26 weeks (planned duration) | Age <30 or >80, any liver disease, any kidney disease, neuropathy, HbA1c <7.5%, no type 2 diabetes, other
Gregorio, 1999 ^129^ | RCT | Italy | NR | 18 weeks (planned duration) | Age <70, any liver disease, any kidney disease, history of CVD, HbA1c <9, no type 2 diabetes, other
Jovanovic, 2000 ^194^ | RCT | US | Yes | 24 weeks (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, HbA1c with ODM (naive): <6.5%; with ODM-treatment: >12%, no type 2 diabetes, other
Willms, 1999 ^99^ | RCT | Germany | Yes | 12 weeks (planned duration) | Age <18, any liver disease, any kidney disease, history of CVD, HbA1c <7% or >13%, no type 2 diabetes, other
Erle, 1999 ^127^ | RCT | US and Italy | Yes | 6 months (planned duration) | No type 2 diabetes, other
Landgraf, 1999 ^121^ | RCT | Germany, Austria, and Netherlands | Yes | 14 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Marbury, 1999 ^116^ | RCT | US and Canada | Yes | 12 months (planned duration) | Age >37 or <75, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6.5% or 14.6%, no type 2 diabetes, other
Wolffenbuttel, 1999 ^117^ | RCT | Germany, Austria, and Netherlands | NR | 12 months (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.5 if treated with diet only; >12 if treated with diet plus ODM, other
Testa, 1998 ^198^ | RCT | US | Yes | 15 weeks (planned duration) | Age <30, no type 2 diabetes, other
Goldberg, 1998 ^139^ | RCT | US | Yes | 18 weeks (planned duration) | Age <40 or >75, no type 2 diabetes, other
1998, ^16^ | RCT | UK | Yes | NR | Age <25 or >65, any kidney disease, history of CVD, treatment experienced, retinopathy, no type 2 diabetes, other
UKPDS
Schade, 1998 ^135^ | RCT | US | Yes | 12 weeks (planned duration) | Age <30 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
1998, ^128^ | RCT | UK | Yes | 3 years (planned duration) | Age <25 or >65, any kidney disease, history of CVD, other
UKPDS
Lee, 1998 ^259^ | RCT | US | NR | NR | Males, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Garber, 1997 ^217^ | RCT | US | Yes | 14 weeks (planned duration) | Age <30, treatment experienced, no type 2 diabetes, other
Simonson, 1997 ^136^ | RCT | US | Yes | 16 weeks (planned duration) | Age <30, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6% at the end of week 2 of placebo administration, no type 2 diabetes, other
Rosenstock, 1996 ^189^ | RCT | US | Yes | 14 weeks (planned duration) | No type 2 diabetes, other
Dills, 1996 ^107^ | RCT | US | Yes | 12 months (planned duration) | Age <30 or >80, any liver disease, any kidney disease, no type 2 diabetes, other
Draeger, 1996 ^112^ | RCT | UK, Europe, Asia, South Africa and South America | NR | 12 months (planned duration) | Age <40 or >80, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
Goldberg, 1996 ^134^ | RCT | US | Yes | 14 weeks (planned duration) | Age <30 or >75, any liver disease, any kidney disease, no type 2 diabetes, other
Grant, 1996 ^154^ | RCT | UK | Yes | 24 weeks (planned duration) | No type 2 diabetes, other
Vray, 1995 ^137^ | RCT, factorial | France, China | Yes | 3 months (planned duration) | Age <40 or >70, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
DeFronzo, 1995 ^88^ | RCT | US | NR | 29 weeks (planned duration) | Age <40 or >70, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
1995, ^92^ | RCT | UK | Yes | 3 years (planned duration) | Age <25 or >65, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, no type 2 diabetes, other
UKPDS
Hermann, 1994 ^87^ | RCT | Sweden | Yes | 6 months (planned duration) | No type 2 diabetes, other
Campbell, 1994 ^83^ | RCT | UK | NR | 52 weeks (planned duration) | Age <40 or >69, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Birkeland, 1994 ^110^ | RCT | Norway | Yes | 15 months (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <7 or >11, no type 2 diabetes, other
Rosenstock, 1993 ^109^ | RCT | US | Yes | 4 months (planned duration) | Age <65, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
Carlson, 1993 ^108^ | RCT | US | Yes | 12 weeks (planned duration) | Age <30 or >75, any liver disease, any kidney disease, no type 2 diabetes, other
Wolffenbuttel, 1993 ^120^ | RCT | Netherlands | Yes | 12 (4 week titration, 8 week treatment) (planned duration) | Any liver disease, any kidney disease, HbA1c <7.0 or >12.0, no type 2 diabetes, other
Leonhardt, 1991 ^263^ | RCT | Germany | Yes | 24 weeks (planned duration) | Age <43 or >70, no type 2 diabetes, other
Teupe, 1991 ^155^ | RCT | Germany | NR | 2 years (planned duration) | Age >70, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Noury, 1991 ^86^ | RCT | France | NR | 3 months (planned duration) | Any liver disease, any kidney disease, no type 2 diabetes, other
Hermann, 1991 ^94^ | RCT | Sweden | Yes | 6 months (planned duration) | Any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Schneider, 1991 ^173^ | RCT | Germany | NR | 12 weeks (planned duration) | Age <37 or >77, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Hermann, 1991 ^159^ | RCT | Sweden | NR | 6 months (planned duration) | No type 2 diabetes, other
Dornan, 1991 ^260^ | RCT | UK | Yes | 8 months (planned duration) | Any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Kilo, 1988 ^147^ | RCT | US | NR | 3 months (planned duration) | Treatment experienced, no type 2 diabetes, other
1985, ^91^ | RCT | UK | Yes | 12 months (planned duration) | Age <25 or >65, any kidney disease, history of CVD, retinopathy, no type 2 diabetes, other
UKPDS
Harrower, 1985 ^113^ | RCT | UK and Scotland | NR | 1 year (planned duration) | No type 2 diabetes, other
Baba, 1983 ^133^ | RCT | Japan | NR | 24 weeks (planned duration) | No type 2 diabetes, other
Tseng, 2005 ^140^ | RCT | Taiwan | NR | 12 weeks (planned duration) | No type 2 diabetes, other
Wolever, 2000 ^98^ | RCT | Canada | Yes | 9 months (planned duration) | Age <40, any liver disease, history of CVD, treatment experienced, HbA1c <7.2 or >9.1, no type 2 diabetes, other
Cefalu, 1998 ^261^ | RCT | US | NR | 8 months (planned duration) | Age <30 or >73, any liver disease, any kidney disease, HbA1c >=11 at time of screening; >=7.8% in normal time, no type 2 diabetes, other
Turner, 1998 ^93^ | RCT | UK | Yes | 6 years (planned duration) | Age <25 or >/=65, any kidney disease, history of CVD, treatment experienced, retinopathy, no type 2 diabetes, other
UKPDS
Garber, 2006 ^71^ | RCT | US | Yes | 24 weeks (planned duration) | Age<20 or >78, any liver disease, any kidney disease, history of CVD, HbA1c <=7.0 or >=12.0, no type 2 diabetes, other

RCT = randomized controlled trial; NR = not reported; HbA1c = hemoglobin A1c; CVD = cardiovascular disease; US = United States; UK = United Kingdom; ODM = oral diabetic medicine; FPG = fasting plasma glucose; UKPDS = United Kingdom Prospective Diabetes Study; DIACOM = effect of Dosing frequency of oral Antidiabetic agents on the COMpliance and biochemical control of type 2 diabetes

Table 3 Evidence Table. Study population table for studies reporting on proximal clinical outcomes (Key Question 1)

Author, year | Group, n | Mean age in years (age range) | Male, n (%) | Race, n (%) | Mean BMI in kg/m^2^ (other measure) | Mean weight in kg (other measure) | Mean HbA1c % | Mean duration of diabetes in years
Study group
Ramachandran, 2004 ^55^ | Diet + exercise, 15 | 43.5 | 13 | AA: 0; C: 0; Asian: 0; H: 0; O: 100 | 26.1 | 71.2 | 7.5 | 0
| Diet + glimepiride, 18 | 45.3 | 14 | AA: 0; C: 0; Asian: 0; H: 0; O: 100 | 24.6 | 65.7 | 10.2 | 0
| Diet + metformin, 21 | 44.4 | 15 | AA: 0; C: 0; Asian: 0; H: 0; O: 100 | 25.7 | 67.7 | 9.6 | 0
| Diet + pioglitazone, 23 | 45.1 | 17 | AA: 0; C: 0; Asian: 0; H: 0; O: 100 | 25.5 | 68.9 | 9.3 | 0
Rosenbaum, 2002 ^153^ | Placebo, 20 | 62 | 8 | NR | 31.7 | 80.2 | 6.3 | NR
| Acarbose, 20 | 59.8 | 6 | NR | 30.3 | 75.1 | 6.4 | NR
Nishio, 2006 ^151^ | Control group (no placebo), 28 | 67.5 | 20 (71.4) | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.6 | NR | 6.9 | NR
| Pioglitazone, 26 | 66.2 | 19 (73.1) | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.6 | NR | 7.7 | NR
Weissman, 2005 ^100^ | Metformin + rosiglitazone, 358 | 55.5 | NR | NR | 34.4 | 98.2 | 8.05 | NR
| Metformin, 351 | 55.7 | NR | NR | 33.8 | 96.7 | 7.97 | NR
Rosenstock, 2006 ^124^ | Glipizide + rosiglitazone, 116 | 68.7 | (74.8) | NR | 30.2 | NR | 7.72 | 6.8
| Placebo + glipizide, 111 | 68.2 | (71.8) | NR | 30.5 | NR | 7.65 | 6.6
Bailey, 2005 ^101^ | Metformin + rosiglitazone, 288 | 58.1 | 168 (58) | AA: 2 (1); C: 280 (97); Asian: 3 (1); H: 0; O: 3 (1) | 32.2 | 90.9 | 7.4 | 6
| Metformin, 280 | 57.6 | 159 (57) | AA: 1 (<1); C: 273 (98); Asian: 3 (1); H: 0; O: 3 (1) | 32.1 | 89.5 | 7.5 | 6.1
Pfutzner, 2006 ^123^ | Placebo + glimepiride, 30 | 63.7 | 15 | NR | 30 | NR | 7.7 | 7.3
| Glimepiride + rosiglitazone, 31 | 59.8 | 15 | NR | 27.7 | NR | 8.3 | 5.9
| Glimepiride + rosiglitazone, 41 | 62.2 | 22 | NR | 29.3 | NR | 8 | 6.4
Betteridge, 2005 ^157^ | Metformin + pioglitazone, 317 | NR | NR | NR | NR | NR | NR | NR
| Metformin + glyclazide, 313 | NR | NR | NR | NR | NR | NR | NR
| Unspecified sulfonylurea + pioglitazone, 319 | NR | NR | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, 320 | NR | NR | NR | NR | NR | NR | NR
Kardas, 2005 ^114^ | Glyclazide, 55 | 60.9 | (53) | NR | 27.1 | 79 | 7.1 | 2.2
DIACOM | Glibenclamide, 50 | 62.4 | (38) | NR | 26.3 | 75 | 7.2 | 3.5
Forst, 2005 ^145^ | Glimepiride, 84 | 63 (SD 7.4) | 52 | NR | 31.8 | NR | 7.44 | 6.9
| Pioglitazone, 89 | 62.2 (SD 8.4) | 55 | NR | 31.7 | NR | 7.52 | 7.4
Yamanouchi, 2005 ^57^ | Diet + exercise + pioglitazone, 38 | 55.2 (46 – 64.4) | 18 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 25.8 | NR | 10.2 | 3.2 months
| Diet + exercise + metformin, 39 | 54.7 (44.9 – 64.5) | 20 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 26.2 | NR | 9.9 | 3 months
| Diet + exercise + glimepiride, 37 | 55.6 (46.3 – 64.9) | 19 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 25.6 | NR | 9.8 | 3.3 months
Goldberg, 2005 ^52^ | Diet + pioglitazone, 369 | 55.9 | 199 (53.9) | AA: 9 (2.4); C: 239 (64.8); Asian: 10 (2.7); H: 105 (28.5); O: 6 (1.6) | 33.7 | 93.7 | 7.6 | 3.9
| Diet + rosiglitazone, 366 | 56.3 | 201 (54.9) | AA: 10 (2.7); C: 219 (59.8); Asian: 12 (3.3); H: 118 (32.2); O: 7 (1.9) | 32.6 | 92.5 | 7.5 | 4
Pfutzner, 2005 ^68^ | Pioglitazone, 89 | 62.2 | 58 (61.8) | AA: 0; C: 88 (98.8); Asian: 0; H: 0; O: 1 (1.1) | 31.7 | NR | 7.52 | 7.4
| Glimepiride, 84 | 63 | 52 (61.9) | AA: 0; C: 81 (96.4); Asian: 0; H: 0; O: 3 (3.7) | 31.8 | NR | 7.44 | 6.9
Derosa, 2005 ^53^ | Diet + exercise + glimepiride + pioglitazone, 45 | 53 (47 – 59) | 21 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.4 | 68.9 | 8.2 | 5
| Diet + exercise glimepiride + rosiglitazone, 42 | 54 (49 – 59) | 22 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.3 | 67.8 | 8 | 6
Derosa, 2005 ^72^ | Diet + exercise + behavioral therapy + metformin + glimepiride, 47 | 52 (47 – 57) | 23 | NR | 26.8 | NR | 7.9 | 4
| Diet + exercise + behavioral therapy metformin + rosiglitazone, 48 | 54 (50 – 58) | 25 | NR | 26.6 | NR | 8 | 5
Inukai, 2005 ^111^ | Glibenclamide + glyclazide, 52 | 60.7 (49.2 – 72.2) | 24 (46.15) | NR | 24.9 | 62.9 | 7.46 | NR
| Glimepiride, 120 | 61.9 (50.8 – 72.0) | 56 (46.67) | NR | 24.8 | 62.2 | 7.64 | NR
Langenfeld, 2005 ^146^ | Pioglitazone, 89 | 62 | 55 (61.8) | AA: 0; C: 88 (98.9); Asian: 0; H: 0; O: (1.1) | 31.7 | NR | 7.52 | 7.4
| Glimepiride, 84 | 63 | 52 (61.9) | AA: 0; C: 81 (96.4); Asian: 0; H: 0; O: (3.6) | 31.8 | NR | 7.44 | 6.9
Feinglos, 2005 ^104^ | Metformin + glipizide, 61 | 57.7 (30–80) | 28 | AA: 5 (8.2); C: 48 (78.7); Asian: 2 (3.3); H: 5 (8.2); O: 1 (1.6) | 31.7 | 90 | 7.45 | 6.5
| Placebo + metformin, 61 | 58.8 (40–81) | 25 | AA: 10 (16.4); C: 42 (68.9); Asian: 2 (3.3); H: 5 (8.2); O: 2 (3.3) | 32.1 | 90.8 | 7.64 | 4.6
Mari, 2005 ^262^ | Placebo, 30 | 60 | 19 | NR | 28.3 | NR | 6.5 | 4.5
| Nateglinide, 26 | 56 | 14 | NR | 28.8 | NR | 6.5 | 2.9
| Nateglinide, 27 | 61 | 19 | NR | 27.8 | NR | 6.6 | 4.3
| Nateglinide, 25 | 62 | 15 | NR | 28.4 | NR | 6.6 | 5.2
Goke, 2002 ^75^ | Pioglitazone, 129 | 58.9 | 69 (53.5) | NR | 30.9 | NR | 8.98 | 57.0 months
German Pioglitazone Study Group | Acarbose, 136 | 58.8 | 74 (54.5) | NR | 30.8 | NR | 9.03 | 59.1 months
Charbonnel, 2005 ^63^ | Pioglitazone, NR (Total 1270) | NR | NR | NR | NR | NR | 8.7 | NR
| Glyclazide, NR (Total 1270) | NR | NR | NR | NR | NR | 8.7 | NR
Tan, 2005 ^61^ | Pioglitazone, 270 | 57 | 171 (63.3) | AA: 0; C: 253 (93.7); Asian: 0; H: 0; O: 17 (6.3) | 32 | 91.7 | NR | 2.7
One year extension study for Quartet study group | Glyclazide, 297 | 56 | 182 (61.3) | AA: 0; C: 275 (92.6); Asian: 0; H: 0; O: 22 (7.4) | 32 | 89.2 | NR | 2.9
McCluskey, 2004 ^76^ | Glimepiride + rosiglitazone, 25 | 60.2 (46 – 76) | 11 (44%) | AA: 0; C: 24 (96); Asian: 0; H: 0; O: 0 | NR | 100.5 | 7.9 | 7.2
| Placebo + rosiglitazone, 15 | 50.8 (35 – 69) | 6 (40%) | AA: 0; C: 12 (80); Asian: 0; H: 0; O: 0 | NR | 99.4 | 8.4 | 4.6
Kim, 2005 ^152^ | Diet + exercise + rosiglitazone, 63 | 58.8 (50.0 – 67.6) | NR | NR | 23.9 | 61.5 | 9.7 | 12
| Diet + exercise, 62 | 58.1 (48.6 – 67.6) | NR | NR | 24.5 | 62.3 | 9.3 | 10.1
Schernthaner, 2004 ^56^ | Placebo + diet + pioglitazone, 597 | 57 | 314 (52.6) | NR | 31.2 | 88.2 | 8.7 | 3.4
| Placebo + diet + metformin, 597 | 56 | 345 (57.8) | NR | 31.4 | 89.7 | 8.7 | 3.1
Smith, 2005 ^161^ | Placebo + diet, 21 | 53.1 | 10 | AA: 0; C: 16; Asian: 0; H: 0; O: 5 | 31.9 | 91.5 | 6.46 | NR
| Diet + pioglitazone, 21 | 56.2 | 9 | AA: 0; C: 15; Asian: 0; H: 0; O: 6 | 32.1 | 93.5 | 6.88 | NR
Choi, 2004 ^77^ | Rosiglitazone, 38 | 60.9 | 24 | NR | 24.9 | 67.6 | 7.79 | 7.5
| Uptitration of existing medications, 45 | 59.9 | 34 | NR | 24.8 | 68.1 | 7.72 | 7.2
Matthews, 2005 ^70^ | Diet + pioglitazone + metformin, 317 | 56 | 161 (50.8) | AA: 0; C: 315 (99.4); Asian: 2 (0.6); H: 0; O: 0 | 32.6 | NR | 8.71 | 5.8
| Diet + glycazide + metformin, 313 | 57 | 154 (49.2) | AA: 0; C: 313 (100); Asian: 0; H: 0; O: 0 | 32.6 | NR | 8.53 | 5.5
Derosa, 2004 ^90^ | Placebo + diet + exercise + glimepiride, 81 | 56 | 38 | NR | 27.6 | NR | 8.5 | NR
| Placebo + diet + exercise + metformin, 83 | 58 | 42 | NR | 28.1 | NR | 8.4 | NR
Schernthaner, 2004 ^106^ | Glyclazide, 405 | 60.5 | (51) | NR | 30.5 | 83.1 | 8.4 | 5.6
| Glimepiride, 440 | 60.6 | (52) | NR | 30.6 | 83.8 | 8.2 | 5.8
Tan, 2004 ^65^ | Glibenclamide, 109 | 57.9 | 80 (73) | AA: 0; C: 109 (100); Asian: 0; H: 0; O: 0 | 29.6 | 89 | 8.5 | 62.6 months
| Pioglitazone, 91 | 60 | 56 (62) | AA: 0; C: 90 (99); Asian: 0; H: 0; O: 1 (1) | 30.2 | 88.4 | 8.4 | 57.1 months
Baksi, 2004 ^126^ | Glyclazide, 241 | 61.9 | 151 (62.7) | AA: 1 (0.4); C: 235 (97.5); Asian: 1 (0.4); H: 0; O: 4 (1.7) | 29.7 | NR | 8.6 | 6.9
| Glyclazide + rosiglitazone, 225 | 61.1 | 129 (57.3) | AA: 1 (0.4); C: 219 (97.3); Asian: 3 (1.3); H: 0; O: 2 (0.9) | 30.2 | NR | 8.5 | 6.5
Tan, 2004 ^69^ | Diet + exercise + pioglitazone, 121 | 55.1 | 54 (45) | AA: 0; C: 0 (0); Asian: 0; H: 121 (100); O: 0 | 29.3 | 74.2 | 8.54 | 77.8 months
| Diet + exercise + glimepiride, 123 | 55.7 | 65 (53) | AA: 0; C: 1 (1); Asian: 0; H: 122 (99); O: 0 | 28.8 | 74.5 | 8.45 | 81.2 months
Natali, 2004 ^144^ | Placebo, 22 | 58 | 18 | NR | 30.2 | NR | 7.6 | 3.4
| Metformin, 28 | 58 | 22 | NR | 28 | NR | 7.8 | 6.3
| Rosiglitazone, 24 | 59 | 22 | NR | 27.6 | NR | 7.7 | 6.5
Saad, 2004 ^164^ | Placebo, 30 | 54 | 18 | NR | 31 | NR | 8.1 | NR
| Pioglitazone, 28 | 55 | 11 | NR | 31 | NR | 8.5 | NR
Rosenstock, 2004 ^131^ | Repaglinide, 76 | 50.9 | 41 | AA: 6; C: 60; Asian: 0; H: 9; O: 1 | 33 | NR | 8.9 | 3.5
| Nateglinide, 74 | 54 | 42 | AA: 3; C: 59; Asian: 1; H: 9; O: 2 | 32.9 | NR | 8.9 | 4.3
Raskin, 2004 ^74^ | Repaglinide, 63 | 58.5 | 39 | AA: 10; C: (40); Asian: 0; H: 1; O: 12 | NR | NR | NR | 7.2
| Rosiglitazone, 62 | 56.6 | 33 | AA: 8; C: (42); Asian: 0; H: 0; O: 12 | NR | NR | NR | 7.4
| Repaglinide + rosiglitazone, 127 | 57.5 | 65 | AA: 21; C: (83); Asian: 0; H: 4; O: 19 | NR | NR | NR | 7.3
Yanagawa, 2004 ^62^ | Glyclazide, 21 | 54 | 15 | NR | 24 | NR | 8.3 | 6
| Pioglitazone, 19 | 54 | 13 | NR | 24.6 | NR | 8.3 | 6.7
Manzella, 2004 ^148^ | Placebo + diet, 60 | 57 (all patients) | 33 | NR | 29.2 | NR | 8.1 | NR
| Diet + metformin, 60 | 57 (all patients) | 31 | NR | 29.5 | NR | 8 | NR
Feinbock, 2003 ^130^ | Glimepiride, 111 | 57.7 | 66 | AA: 0; C: 110; Asian: 1; H: 0; O: 0 | 29.2 | 85 | 9.1 | 36.3 months
| Acarbose, 108 | 57.1 | 58 | AA: 0; C: 107; Asian: 1; H: 0; O: 0 | 29.1 | 83 | 9.4 | 43.1 months
Kerenyi, 2004 ^125^ | Diet + glibenclamide, 170 | 59.9 | 105 | AA: 2; C: 163; Asian: 4; H: 0; O: 1 | 29.2 | NR | 8.1 | 6.7
| Diet + glibenclamide + rosiglitazone, 165 | 60 | 91 | AA: 1; C: 160; Asian: 3; H: 0; O: 1 | 30.7 | NR | 7.9 | 5.6
Jovanovic, 2004 ^73^ | Repaglinide, 61 | 57.8 | 36 | AA: 7; C: 46; Asian: 0; H: 3; O: 5 | 31.2 | NR | 9 | 6.9
| Pioglitazone, 62 | 56.2 | 31 | AA: 7; C: 51; Asian: 0; H: 2; O: 2 | 32.1 | NR | 9.1 | 6.1
Hanefeld, 2004 ^60^ | Placebo + unspecified sulfonylurea + pioglitazone, 31 | 60 | 171 (53.6) | AA: 2 (0.6); C: 317 (99.4); Asian: 0; H: 0; O: 0 (0) | 30.2 | 85.3 | 8.82 | 7
QUARTET Study Group | Placebo + metformin + unspecified sulfonylurea, 320 | 60 | 175 (54.7) | AA: 3 (0.9); C: 315 (98.4); Asian: 0; H: 0; O: 2 (0.6) | 30 | 84.9 | 8.8 | 7.1
Lawrence, 2004 ^54^ | Metformin, 20 | 59.5 | 12 | NR | (Median 29.2) | NR | 8.04 | NR
| Glyclazide, 20 | 63.5 | 13 | NR | (Median 28.7) | NR | 7.85 | NR
| Pioglitazone, 20 | 60.4 | 14 | NR | (Median 30.6) | NR | 7.43 | NR
Garber, 2003 ^80^ | Metformin + glyburide, 171 | 55.6 | 76 (44) | AA: 18 (10.5); C: 132 (77.2); Asian: 0; H: 15 (8.8); O: 6 (3.5) | 31.4 | 91.9 | 8.8 | 3
| Metformin, 164 | 54.7 | 71 (43.3) | AA: 11 (6.7); C: 132 (80.5); Asian: 0; H: 15 (9.1); O: 6 (3.7) | 31.4 | 92.8 | 8.5 | 2.6
| Glyburide, 151 | 55.3 | 66 (43.7) | AA: 11 (7.3); C: 123 (81.5); Asian: 0; H: 12 (7.9); O: 5 (3.3) | 31.1 | 91 | 8.7 | 3
Takagi, 2003 ^78^ | Pioglitazone, 23 | 64 | 20 | NR | 25.6 | NR | 6.8 | NR
| Control, 21 | 65 | 14 | NR | 24.5 | NR | 6.7 | NR
Tosi, 2003 ^95^ | Glibenclamide, 20 | NR | NR | NR | NR | NR | NR | NR
| Metformin + glibenclamide, 41 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 19 | NR | NR | NR | NR | NR | NR | NR
| Glibenclamide, 21 | NR | NR | NR | NR | NR | NR | NR
| Metformin + glibenclamide, 39 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 20 | NR | NR | NR | NR | NR | NR | NR
Goldstein, 2003 ^82^ | Metformin + glipizide, 87 | 54.6 | (58.6) | AA: (11.5); C: (72.4); Asian: (0); H: (16.1); O: 0 | 31.7 | 94 | 8.7 | 5.9
| Glipizide, 84 | 57.4 | (64.3) | AA: (11.9); C: (71.4); Asian: (2.4); H: (14.3); O: 0 | 30.6 | 89.9 | 8.9 | 6.5
| Metformin, 76 | 56.6 | (61.8) | AA: (15.8); C: (65.8); Asian: (1.3); H: (17.1); O: 0 | 31.6 | 93.8 | 8.7 | 7.3
Herz, 2003 ^163^ | Placebo, 99 | 58 (33 – 85) | 49 (49.5%) | AA: 0 (0); C: 96 (97); Asian: 3 (3); H: 0 (0); O: 0 | 31.7 | 86.3 | 7.5 | NR
| Pioglitazone, 99 | 59 (24 – 79) | 59 (59.6) | AA: 0 (0); C: 97 (98); Asian: 1 (1); H: 1 (1); O: 0 | 31.7 | 86.6 | 7.5 | NR
| Pioglitazone, 99 | 58.1 (24 –84) | 52 (52.5) | AA: 0 (0); C: 93 (93.9); Asian: 1 (3); H: 3 (3); O: 0 | 30.8 | 84.1 | 7.6 | NR
Bech, 2003 ^197^ | Repaglinide, 164 | 56.9 (40 –81) | (57.3) | AA: 1 (0.6); C: 161 (98.2); Asian: 0 (0); H: 0; O: 2 (1.2) | NR | NR | 7.8 | 2.77
| Placebo, 89 | 57.3 (40 –76) | (58.4) | AA: 0 (0); C: 88 (98); Asian: 0 (0); H: 0; O: 1 (1.1) | NR | NR | 7.6 | 2.81
Derosa, 2003 ^97^ | Diet + exercise + repaglinide, 56 | 55 | 29 | NR | 25.2 | 70.2 | 7.6 | 4
| Diet + exercise + metformin, 56 | 52 | 27 | NR | 24.7 | 72.3 | 7.4 | 5
Barnett, 2003 ^172^ | Placebo + unspecified sulfonylurea, 87 | 54.1 (32 –78) | (75) | AA: 0 (0); C: 0 (0); Asian: 0 (0); H: 0 (0); O: (100) | 26.4 | NR | 9.06 | 6.5
| Unspecified sulfonylurea + rosiglitazone, 84 | 54.3 (28 –76) | (80) | AA: 0 (0); C: 0 (0); Asian: 0 (0); H: 0 (0); O: (100) | 26.8 | NR | 9.21 | 6.5
Fujioka, 2003 ^105^ | Placebo + diet + metformin XR, 75 | 54 | 34 | NR | 32 | 92 | 7 | 3
| Placebo + diet + metformin XR, 71 | 55 | 28 | NR | 31 | 88 | 7 | 3
| Placebo + diet + metformin, 71 | 54 | 31 | NR | 33 | 96 | 7.1 | 3
Derosa, 2003 ^118^ | Placebo + repaglinide, 62 | 56 | 31 | NR | 26.1 | 76.4 | 8 | NR
| Placebo + glimepiride, 62 | 54 | 30 | NR | 26.4 | 77.1 | 7.8 | NR
Zhu, 2003 ^188^ | Placebo + unspecified sulfonylurea, 105 | 58.8 | (46) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 25.1 | NR | 9.8 | 7.6
| Unspecified sulfonylurea + rosiglitazone, 215 | 59 | (41) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 24.8 | NR | 9.8 | 7.2
| Unspecified sulfonylurea + rosiglitazone, 210 | 58.9 | (48) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 24.9 | NR | 9.9 | 7.9
Del Prato, 2003 ^149^ | Placebo, 144 | 56 | 91 | NR | 29.9 | NR | NR | NR
| Placebo + metformin, 284 | 56 | 68 | NR | 29.7 | NR | NR | NR
Pavo, 2003 ^59^ | Placebo + pioglitazone, 105 | 54.2 | (43.8) | NR | 31.3 | 86.6 | 8.6 | 0.47
| Placebo + metformin, 100 | 55.8 | (56) | NR | 31.1 | 88.9 | 8.6 | 0.53
Luis Bautista, 2003 ^193^ | Diet + exercise + glimepiride, 48 | 48.4 | 27 (56.3) | AA: 0; C: 0; Asian: 0; H: (100); O: 0 | NR | 83.3 | 10 | 4.2
| Placebo + diet + exercise, 22 | 50.7 | 11 (50) | AA: 0; C: 0; Asian: 0; H: (100); O: 0 | NR | 76.3 | 10.5 | 5.7
Bakris, 2003 ^66^ | Glyburide, 64 | 56.1 | (71) | NR | NR | NR | 9.5 | NR
| Rosiglitazone, 57 | 5.1 | (75) | NR | NR | NR | 9.1 | NR
Vongthavaravat, 2002 ^170^ | Diet + unspecified sulfonylurea + rosiglitazone, 164 | 54.6 (30 –76) | 75 (45.7) | AA: 6 (3.7); C: 66 (40.2); Asian: 91 (55.5); H: 0; O: 1 (0.6) | 27.1 | 69 | 9.1 | 5
| Diet + unspecified sulfonylurea, 170 | 57.3 (37 –77) | 72 (42.4) | AA: 4 (2.4); C: 62 (36.5); Asian: 101 (59.4); H: 0; O: 3 (1.8) | 27.1 | 68.8 | 8.9 | 6
Virtanen, 2003 ^143^ | Placebo + diet, 14 | 58 | 10 | NR | 30.3 | 88.3 | 6.3 | NR
| Diet + rosiglitazone, 14 | 58 | 10 | NR | 29.1 | 83.7 | 6.8 | NR
| Diet + metformin, 13 | 58 | 8 | NR | 29.9 | 88.8 | 6.9 | NR
Vakkilainen, 2002 ^122^ | Placebo + nateglinide, 23 | 63 | NR | AA: 0; C: (100); Asian: 0; H: 0; O: 0 | 27.8 | NR | 7.6 | NR
| Placebo + glibenclamide, 20 | 63 | NR | AA: 0; C: (100); Asian: 0; H: 0; O: 0 | 28.8 | NR | 7.6 | NR
Hallsten, 2002 ^58^ | Placebo + diet, 14 | 57.7 | 10 | NR | 30.3 | NR | 6.3 | NR
| Diet + metformin, 13 | 57.8 | 8 | NR | 29.9 | NR | 6.9 | NR
| Diet + rosiglitazone, 14 | 58.6 | 10 | NR | 29.3 | NR | 6.8 | NR
Scherbaum, 2002 ^141^ | Placebo + diet, 84 | 59.1 | 47 | NR | 29.2 | 84.8 | 8.75 | 5.6
| Diet + pioglitazone, 89 | 58 | 56 | NR | 29.9 | 87.2 | 9.33 | 5.4
| Diet + pioglitazone, 78 | 59.6 | 32 | NR | 29.3 | 82 | 9.06 | 4.6
Blonde, 2002 ^81^ | Glyburide, 164 | 55.8 | 94 (57.3) | AA: 20 (12.2); C: 109 (66.5); Asian: 0; H: 28 (17.1); O: 7 (4.3) | 30.3 | 88 | 9.64 | 7.01
| Metformin, 153 | 57.6 | 95 (62.1) | AA: 16 (10.5); C: 105 (69.3); Asian: 0; H: 26 (17); O: 5 (3.3) | 30.6 | 89.5 | 9.51 | 8.18
| Metformin + glyburide, 160 | 55.4 | 89 (55.6) | AA: 20 (12.5); C: 112 (70); Asian: 0; H: 25 (15.6); O: 3 (1.9) | 30.7 | 89.4 | 9.41 | 7.36
| Metformin + glyburide, 162 | 55.6 | 103 (63.6) | AA: 15 (9.3); C: 110 (67.9); Asian: 0; H: 31 (19.1); O: 6 (3.7) | 30.6 | 89.6 | 9.42 | 6.97
St John Sutto, 2002 ^67^ | Glyburide, 99 | 56.1 (40 –76) | (71) | AA: (3); C: (76); Asian: 0; H: 0; O: (21) | (% BMI >=27: 65.7%) | NR | 9.5 | 6.2
| Rosiglitazone, 104 | 55.1 (40 –77) | (75) | AA: (5); C: (73); Asian: 0; H: 0; O: (22) | (% BMI >=27: 67.3%) | NR | 9.1 | 5.3
Rachmani, 2002 ^150^ | Diet + metformin stopped, 198 | 64 | 102 | NR | 28.4 | NR | 8.6 | 14
| Diet + metformin continued, 195 | 65 | 103 | NR | 28.7 | NR | 8.6 | 15
Saloranta, 2002 ^241^ | Nateglinide, 166 | 61 | 105 (63.3) | AA: 2 (1.2); C: 162 (97.6); Asian: 1 (0.6); H: 0; O: 1 (0.6) | 28.95 | NR | 6.55 | 3.8
| Nateglinide, 175 | 61.1 | 107 (61.1) | AA: 1 (0.6); C: 163 (93.1); Asian: 3 (4.6); H: 0; O: 8 (4.6) | 28.92 | NR | 6.53 | 3.6
| Nateglinide, 171 | 59.6 | 112 (65.5) | AA: 2 (1.2); C: 163 (95.3); Asian: 4 (1.2); H: 0; O: 2 (1.2) | 29.12 | NR | 6.57 | 3.7
| Placebo, 163 | 59.1 | 98 (60.1) | AA: 2 (1.2); C: 157 (96.3); Asian: 1 (1.8); H: 0; O: 3 (1.8) | 28.78 | NR | 6.45 | 3.2
Marre, 2002 ^84^ | Metformin, 104 | 57.5 | 62 | NR | 29.9 | 84.9 | 8.09 | 5.4
| Glibenclamide, 103 | 58.7 | 57 | NR | 29.3 | 82.5 | 7.88 | 6.6
| Metformin + glibenclamide, 101 | 58 | 50 | NR | 30.1 | 84.7 | 7.89 | 5.9
| Metformin + glibenclamide, 103 | 60.7 | 56 | NR | 29.7 | 83.1 | 7.62 | 6.7
Garber, 2002 ^79^ | Placebo, 161 | 55.4 | 76 | AA: 122; C: 122; Asian: 0; H: 17; O: 6 | 30.2 | 86.2 | 8.21 | 2.76
| Glyburide, 161 | 56.5 | 82 | AA: 126; C: 126; Asian: 0; H: 14; O: 6 | 30.3 | 87.2 | 8.21 | 2.81
| Metformin, 161 | 56 | 93 | AA: 130; C: 130; Asian: 0; H: 20; O: 4 | 30.4 | 88.6 | 8.26 | 2.98
| Metformin + glyburide, 158 | 56.9 | 91 | AA: 117; C: 117; Asian: 0; H: 18; O: 3 | 30.1 | 88.8 | 8.25 | 3.52
| Metformin + glyburide, 165 | 58.1 | 96 | AA: 131; C: 131; Asian: 0; H: 16; O: 8 | 29.6 | 86.7 | 8.18 | 3.3
Gomez-Perez, 2002 ^102^ | Placebo + metformin, 34 | 53.4 (40 –68) | 10 | AA: 0; C: 1; Asian: 0; H: 26; O: 7 | 28.5 | NR | NR | 9.1
| Metformin + rosiglitazone, 35 | 51.7 (40 –73) | 10 | AA: 0; C: 0; Asian: 0; H: 28; O: 7 | 28 | NR | NR | 11.1
| Metformin + rosiglitazone, 36 | 54.2 (42 –76) | 7 | AA: 0; C: 4; Asian: 0; H: 26; O: 6 | 27.6 | NR | NR | 10.7
Khan, 2002 ^51^ | Rosiglitazone, 60 | 57.1 | 27 | NR | 35.6 | NR | 7.9 | NR
| Pioglitazone, 67 | 57.8 | 35 | NR | 35.2 | NR | 8 | NR
Charpentier, 2001 ^89^ | Placebo + metformin, 75 | 56.7 (36 –69) | 45 (60) | NR | 29.2 | 82.2 | 6.8 | 7
| Placebo + glimepiride, 150 | 55.4 (35 –70) | 87 (58) | NR | 29.3 | 81 | 6.5 | 5.3
| Metformin + glimepiride, 147 | 56.8 (36 –70) | 87 (59) | NR | 29.5 | 81.2 | 6.4 | 5.6
Rosenblatt, 2001 ^162^ | Placebo, 96 | 55.2 | (46.2) | AA: (11.5); C: (61.5); Asian: 0; H: (24); O: (3.1) | 30.7 | 87.2 | 10.42 | NR
| Pioglitazone, 101 | 53.8 | (50.5) | AA: (8.9); C: (69.3); Asian: 0; H: (19.8); O: (2) | 31.5 | 89.8 | 10.65 | NR
Madsbad, 2001 ^119^ | Repaglinide, 175 | 60.2 | 107 | NR | 28 | 82.9 | 7.3 | 8.1
| Placebo + glipizide, 81 | 62 | 52 | NR | 28 | 83.6 | 7.2 | 7
Kipnes, 2001 ^166^ | Placebo + unspecified sulfonylurea, 187 | 56.9 | 109 | AA: 25; C: 141; Asian: 3; H: 18; O: 0 | 32 | NR | 9.9 | 19
| Unspecified sulfonylurea + pioglitazone, 184 | 56.5 | 109 | AA: 20; C: 146; Asian: 3; H: 15; O: 0 | 31.4 | NR | 10 | 29
| Unspecified sulfonylurea + pioglitazone, 189 | 56.6 | 113 | AA: 17; C: 156; Asian: 3; H: 13; O: 0 | 32.4 | NR | 9.9 | 26
Amador-Licona, 2000 ^85^ | Glibenclamide, 23 | 48.2 | 7 | NR | 30.4 | 73.2 | 8.4 | 4
| Metformin, 28 | 49.3 | 11 | NR | 26.8 | 70.7 | 8.5 | 4.5
Lebovitz, 2001 ^169^ | Placebo, 158 | 59 | 104 | NR | 29.9 | NR | 9.0 | 4.6
| Rosiglitazone, 166 | 60 | 107 | NR | 30.2 | NR | 9.0 | 4.8
| Rosiglitazone, 169 | 61 | 113 | NR | 29.1 | NR | 8.8 | 5.4
Patel, 1999 ^167^ | Placebo, 75 | 56.8 (34 –83) | 52 (69.3) | AA: 2; C: 55; Asian: 0; H: 0; O: 18 | 28.9 | NR | 9.1 | 4.2
| Rosiglitazone, 74 | 56.7 (30 –76) | 49 (66.2) | AA: 4; C: 55; Asian: 0; H: 0; O: 15 | 29.4 | NR | 9.1 | 4.9
| Rosiglitazone, 72 | 55.8 (31 –74) | 51 (70.8) | AA: 6; C: 53; Asian: 0; H: 0; O: 13 | 28.6 | NR | 8.9 | 6.7
| Rosiglitazone, 79 | 59.8 (37 –79) | 51 (64.6) | AA: 4; C: 63; Asian: 0; H: 0; O: 12 | 29.5 | NR | 9 | 4.4
| Rosiglitazone, 80 | 59.7 (41 –81) | 55 (68.8) | AA: 5; C: 58; Asian: 0; H: 0; O: 17 | 28.4 | NR | 9 | 5.8
Phillips, 2001 ^168^ | Placebo, 173 | 57.7 | 119 (68.8) | AA: 16 (9.2); C: 137 (79.2); Asian: 0; H: 0; O: 20 (11.6) | 29.1 | NR | 8.9 | 6.6
| Rosiglitazone, 181 | 57.5 | 106 (58.6) | AA: 23 (12.7); C: 138 (76.2); Asian: 0; H: 0; O: 20 (11) | 29.9 | NR | 8.9 | 5.4
| Rosiglitazone, 186 | 56.8 | 110 (59.1) | AA: 15 (8.1); C: 145 (78); Asian: 0; H: 0; O: 26 (14) | 30 | NR | 8.9 | 5.5
| Rosiglitazone, 181 | 58.9 | 119 (65.7) | AA: 13 (7.2); C: 145 (80.1); Asian: 0; H: 0; O: 23 (12.7) | 30 | NR | 8.9 | 6.1
| Rosiglitazone, 187 | 56.5 | 122 (65.2) | AA: 20 (10.7); C: 133 (71.1); Asian: 0; H: 0; O: 34 (18.2) | 29.9 | NR | 9 | 5.9
Moses, 2001 ^218^ | Repaglinide, 260 | 57.5 | (53.5) | AA: (0.4); C: (98.8); Asian: (0); H: 0; O: (0.8) | 30 | 84 | 7.8 | 2.99
| Placebo, 134 | 57.4 | (57.5) | AA: (0); C: (98.5); Asian: (0); H: 0; O: (1.5) | 30.9 | 86.6 | 7.6 | 3.07
Einhorn, 2000 ^160^ | Diet + metformin + pioglitazone, 168 | 55.5 | 92 (54.8) | AA: 14 (8.3); C: 136 (81); Asian: 0; H: 17 (10.1); O: 1 (0.6) | 32.11 | NR | 9.86 | NR
| Placebo + diet + metformin, 160 | 55.7 | 96 (60) | AA: 10 (6.3); C: 139 (86.9); Asian: 0; H: 6 (3.8); O: 5 (3.1) | 32.12 | NR | 9.75 | NR
Fonseca, 2000 ^103^ | Placebo + metformin, 113 | 58.8 | 74.3 | AA: (3.5); C: (81.4); Asian: 0; H: 0; O: (15) | 30.3 | NR | 8.6 | 7.3
| Metformin + rosiglitazone, 116 | 57.5 | 62.1 | AA: (6.9); C: (80.2); Asian: 0; H: 0; O: (12.9) | 30.2 | NR | 8.9 | 7.5
| Metformin + rosiglitazone, 110 | 58.3 | 68.2 | AA: (10); C: (77.3); Asian: 0; H: 0; O: (12.7) | 29.8 | NR | 8.9 | 8.3
Nakamura, 2000 ^64^ | Pioglitazone, 15 | 60 | 7 | NR | NR | NR | 7.7 | 16
| Glibenclamide, 15 | 61 | 8 | NR | NR | NR | 7.8 | 14
| Voglibose, 15 | 56 | 8 | NR | NR | NR | 7.6 | 15
Horton, 2000 ^96^ | Nateglinide, 179 | 58.6 | 110 | AA: (9.5); C: (82.1); Asian: (2.8); H: 0; O: 5.6 | 29.6 | NR | 8.3 | 4.7
| Metformin, 178 | 56.8 | 121 | AA: (9.6); C: (79.2); Asian: (2.2); H: 0; O: 9 | 29.6 | NR | 8.4 | 7.5
| Metformin + nateglinide, 172 | 58.4 | 101 | AA: (11.6); C: (82.6); Asian: (0.6); H: 0; O: 5.2 | 30 | NR | 8.4 | 4.5
| Placebo, 172 | 59.6 | 104 | AA: (16.9); C: (78.5); Asian: (0.6); H: 0; O: 4.1 | 29.2 | NR | 8.3 | 4.6
Aronoff, 2000 ^165^ | Placebo, 79 | 53.7 overall (29 – 75 overall) | (58 overall) | AA: (8) overall; C: (78) overall; Asian: (2) overall; H: (12) overall; O: (1) overall | NR | 90.4 | 10.4 | NR
| Pioglitazone, 81 | 53.7 overall (29 – 75 overall) | (58 overall) | AA: (8) overall; C: (78) overall; Asian: (2) overall; H: (12) overall; O: (1) overall | NR | 93.5 | 10 | NR
| Pioglitazone, 81 | 53.7 overall (29 – 75 overall) | (58 overall) | AA: (8) overall; C: (78) overall; Asian: (2) overall; H: (12) overall; O: (1) overall | NR | 91.2 | 10.2 | NR
| Pioglitazone, 87 | 53.7 overall (29 – 75 overall) | (58 overall) | AA: (8) overall; C: (78) overall; Asian: (2) overall; H: (12) overall; O: (1) overall | NR | 90.3 | 10.2 | NR
| Pioglitazone, 80 | 53.7 overall (29 – 75 overall) | (58 overall) | AA: (8) overall; C: (78) overall; Asian: (2) overall; H: (12) overall; O: (1) overall | NR | 90.8 | 10.3 | NR
Hanefeld, 2000 ^190^ | Placebo, 60 | 57.4 | 36 | NR | 28.3 | NR | 8.5 | 5.4
| Nateglinide, 51 | 58 | 36 | NR | 29 | NR | 8.4 | 4.5
| Nateglinide, 58 | 56.1 | 41 | NR | 28.1 | NR | 8.3 | 6.2
| Nateglinide, 63 | 54.4 | 44 | NR | 28.6 | NR | 8.3 | 4.4
| Nateglinide, 57 | 56.5 | 36 | NR | 28.8 | NR | 8.5 | 3.7
Hasche, 1999 ^138^ | Diet + acarbose, 36 | 63.8 | 17 | NR | 26.1 | 74.3 | 8.5 | 1
| Placebo + diet, 38 | 63.1 | 19 | NR | 26.7 | 75.5 | 8.3 | 1
Wolffenbuttel, 2000 ^171^ | Placebo + unspecified sulfonylurea, 192 | 61.9 | 110 | AA: 2; C: 186; Asian: 0; H: 0; O: 4 | 28.1 | NR | 9.21 | 8
| Unspecified sulfonylurea + rosiglitazone, 19 | 61 | 125 | AA: 2; C: 190; Asian: 0; H: 0; O: 7 | 28.0 | NR | 9.2 | 7
| Unspecified sulfonylurea + rosiglitazone, 18 | 60.6 | 101 | AA: 2; C: 180; Asian: 0; H: 0; O: 1 | 28.3 | NR | 9.23 | 7
Gregorio, 1999 ^129^ | Glibenclamide + glyclazide, 85 | 75.73 | 40 | NR | NR | 76.61 | 10.32 | 14.67
| Metformin + glibenclamide + glyclazide, 89 | 75.42 | 42 | NR | NR | 76.44 | 10.33 | 15.11
Jovanovic, 2000 ^194^ | Placebo, 75 | 58.5 | 49 (65) | AA: 11 (15); C: 51 (68); Asian: 1 (1); H: 0; O: 12 (16) | 29.8 | NR | 8.6 | 6.8
| Repaglinide, 140 | 57.9 | 96 (69) | AA: 14 (10); C: 107 (76); Asian: 0 (0); H: 0; O: 19 (14) | 29.4 | NR | 8.9 | 6.6
| Repaglinide, 146 | 57.6 | 87 (60) | AA: 18 (12); C: 110 (75); Asian: 2 (1); H: 0; O: 16 (11) | 29.5 | NR | 8.7 | 6.3
Willms, 1999 ^99^ | Acarbose, 31 | 60.3 | 15 | NR | NR | 86.1 | 10.6 | 134.8 months
| Placebo, 29 | 59.2 | 17 | NR | NR | 90.2 | 10.6 | 119.6 months
| Metformin, 27 | 53.4 | 13 | NR | NR | 88.6 | 10.6 | 111.9 months
Erle, 1999 ^127^ | Glyburide, 20 | 60 overall | 21 overall | NR | 30.5 overall | 85.2 | 7.37 | NR
| Metformin + glyburide, 20 | 60 overall | 21 overall | NR | 30.5 overall | 85.5 | 7.67 | NR
Landgraf, 1999 ^121^ | Repaglinide, 94 | 61 | 56 | AA: 0; C: 90; Asian: 0; H: 0; O: 4 | 27.6 | 80 | 7.8 | 10
| Placebo + glibenclamide, 100 | 63 | 57 | AA: 6; C: 93; Asian: 0; H: 0; O: 1 | 27.5 | 79 | 8 | 10
Marbury, 1999 ^116^ | Repaglinide, 362 | 58.3 | 242 (67) | AA: 33 (9); C: 279 (77); Asian: 0; H: 0; O: 50 (14) | 29.4 | NR | 8.7 | 7.2
| Placebo + glyburide, 182 | 58.7 | 120 (66) | AA: 16 (9); C: 144 (79); Asian: 0; H: 0; O: 22 (12) | 29.1 | NR | 8.9 | 8.3
Wolffenbuttel, 1999 ^117^ | Repaglinide, 286 | 61 | (62) | NR | 28.4 | 81.5 | 7.1 | (Median 6)
| Placebo + glyburide, 139 | 61 | (68) | NR | 28 | 81.3 | 7 | (Median 6)
Testa, 1998 ^198^ | Placebo + diet, 192 | 58.4 (30 –82) | (58.9) | AA: (15.6); C: (72.9); Asian: 0; H: 0; O: (11.5) | 30.3 | NR | 8.7 | 4.7
| Diet + glipizide GITS, 377 | 58.7 (30 –85) | (54.9) | AA: (16.7); C: (71.9); Asian: 0; H: 0; O: (11.4) | 30.1 | NR | 8.5 | 5.6
Goldberg, 1998 ^139^ | Placebo, 33 | 56.4 | 25 (76) | AA: 0; C: 29 (88); Asian: 0; H: 0; O: 4 (12) | 30 | NR | 8.1 | 5.1
| Repaglinide, 67 | 58.7 | 49 (74) | AA: 0; C: 58 (88); Asian: 0; H: 0; O: 8 (12) | 30.6 | NR | 8.3 | 5.6
1998 ^15^ | Diet, 411 | 53 | 193 (47) | AA: 0; C: (86); Asian: (6); H: 0; O: (8) | 31.8 | 87 | 7.1 | NR
UKPDS | Diet + metformin, 342 | 53 | 157 (46) | AA: 0; C: (85); Asian: (4); H: 0; O: (11) | 31.6 | 87 | 7.3 | NR
| Diet + glibenclamide, 277 | 53 | 127 (46) | AA: 0; C: (87); Asian: (4); H: 0; O: (9) | 31.5 | 86 | 7.2 | NR
| Diet + unspecified sulfonylurea, 269 | 58 | 164 (61) | AA: 0; C: (77); Asian: (13); H: 0; O: (10) | 29.4 | 82 | 7.6 | NR
| Diet + metformin + unspecified sulfonylurea, 268 | 59 | 158 (59) | AA: 0; C: (77); Asian: (11); H: 0; O: (12) | 29.7 | 83 | 7.5 | NR
1998 ^16^ | Diet, 896 | 54 | 555 | AA: 0; C: (83); Asian: 0; H: 0; O: (16) | 27.5 | 77 | 6.2 | NR
UKPDS | Diet + glibenclamide, 615 | 54 | 381 | AA: 0; C: (84); Asian: 0; H: 0; O: (15) | 27.4 | 77 | 6.3 | NR
Schade, 1998 ^135^ | Glimepiride, 123 | 52 | NR | NR | NR | 86.8 | 9.1 | 3.1
| Placebo, 126 | 54 | NR | NR | NR | 87.3 | 8.9 | 3.1
1998 ^128^ | Diet + metformin + glibenclamide, 291 | 59 | (59) | AA: (14); C: (78); Asian: (8); H: 0; O: 0 | 29.2 | 81 | (Median 7.4) | NR
UKPDS | Diet + glibenclamide, 300 | 58 | (60) | AA: (11); C: (78); Asian: (11); H: 0; O: 0 | 29.1 | 81 | (Median 7.3) | NR
Lee, 1998 ^259^ | Placebo + diet + metformin, 24 | 59 (56 – 62) | 0 | NR | 40 | 112.8 | 8.3 | 4
| Placebo + diet, 24 | 61 (59 – 63) | 0 | NR | 39.6 | 108.6 | 8.1 | 3
Garber, 1997 ^217^ | Placebo, 79 | 55 | (56) | AA: (22); C: (66); Asian: 0; H: (11); O: (1) | NR | 90.9 | 9.9 | NR
| Metformin, 73 | 57 | (62) | AA: (11); C: (62); Asian: 0; H: (14); O: (1) | NR | 90 | 10.1 | NR
| Metformin, 73 | 55 | (55) | AA: (12); C: (55); Asian: 0; H: (10); O: (1) | NR | 90 | 10 | NR
| Metformin, 76 | 59 | (63) | AA: (12); C: (63); Asian: 0; H: (15); O: (2) | NR | 89.6 | 9.7 | NR
| Metformin, 73 | 60 | (53) | AA: (14); C: (53); Asian: 0; H: (12); O: (4) | NR | 89.1 | 10.1 | NR
| Metformin, 77 | 59 | (65) | AA: (10); C: (65); Asian: 0; H: (10); O: (0) | NR | 94.5 | 10 | NR
Simonson, 1997 ^136^ | Glipizide, 68 | 57.4 (33 –81) | 40 | AA: 10; C: 50; Asian: 0; H: 0; O: 8 | 29 | 185 pounds | 8.5 | 6.9
| Glipizide, 42 | 58.7 (34 –78) | 25 | AA: 4; C: 32; Asian: 0; H: 0; O: 6 | 28.4 | 181 pounds | 8.8 | 8.8
| Glipizide, 42 | 55.5 (130 –271) | 26 | AA: 4; C: 30; Asian: 0; H: 0; O: 8 | 29.5 | 187.3 pounds | 8.6 | 6.5
| Glipizide, 69 | 59.3 (128 –312) | 47 | AA: 7; C: 54; Asian: 0; H: 0; O: 8 | 28.8 | 186.7 pounds | 8.7 | 7.8
| Glipizide, 28 | 61.7 (144 –267) | 17 | AA: 1; C: 25; Asian: 0; H: 0; O: 2 | 29.6 | 196.2 pounds | 8.4 | 6.6
| Glipizide, 29 | 56.9 (142 –270) | 23 | AA: 1; C: 24; Asian: 0; H: 0; O: 4 | 30.5 | 201.1 pounds | 8.6 | 5.3
| Placebo, 69 | 60.2 (125 –280) | 53 | AA: 8; C: 50; Asian: 0; H: 0; O: 11 | 29.78 | 191.7 pounds | 8.3 | 7.5
Rosenstock, 1996 ^189^ | Placebo, 79 | 61.1 | (67) | NR | NR | 85.9 | 8 | median 6
| Glimepiride, 88 | 61.8 | (74) | NR | NR | 82.9 | 8.1 | median 7
| Glimepiride, 81 | 58.8 | (70) | NR | NR | 86.3 | 8.1 | median 6
| Glimepiride, 83 | 59.6 | (66) | NR | NR | 84.2 | 8 | median 5
| Glimepiride, 85 | 61.7 | (72) | NR | NR | 86.8 | 8.3 | median 7
Dills, 1996 ^107^ | Glimepiride, 289 | 59 | (61) | AA: 0; C: (86); Asian: 0; H: 0; O: (14) | NR | 192 pounds | 8.5 | 5
| Glyburide, 288 | 60 | (58) | AA: 0; C: (87); Asian: 0; H: 0; O: (13) | NR | 192 pounds | 8.5 | 5
Draeger, 1996 ^112^ | Glibenclamide, 520 | 60.7 (26 –81) | 340 | AA: 0; C: 0; Asian: 74; H: 0; O: (26) | 26.5 | NR | 8.1 | 5
| Glimepiride, 524 | 59.7 (27 –81) | 325 | NR | 26.5 | NR | 8.1 | 5
Goldberg, 1996 ^134^ | Placebo, 74 | 60.4 | 48 | AA: 0; C: 60; Asian: 0; H: 0; O: 14 | NR | 85 | 7.8 | 6
| Glimepiride, 78 | 58.9 | 56 | AA: 0; C: 65; Asian: 0; H: 0; O: 13 | NR | 83.9 | 7.8 | 7
| Glimepiride, 76 | 57.8 | 41 | AA: 0; C: 60; Asian: 0; H: 0; O: 16 | NR | 86.1 | 7.7 | 5
| Glimepiride, 76 | 59.6 | 43 | AA: 0; C: 64; Asian: 0; H: 0; O: 12 | NR | 85.3 | 7.8 | 6
Grant, 1996 ^154^ | Placebo, 23 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 25 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 27 | NR | NR | NR | NR | NR | NR | NR
Vray, 1995 ^137^ | Placebo, 56 | 56.8 | (36) | NR | F 23.7; M 23.8 | NR | 10 | 3.9
| Glibenclamide, 56 | 55.8 | (36) | NR | F 24.5; M 23.7 | NR | 9.6 | 2.4
DeFronzo, 1995 ^88^ | Metformin, 143 | 53 | 62 | NR | 29.9 | 94.4 | 8.4 | 6
| Placebo, 53 | 53 | 62 | NR | 29.2 | 92.2 | 8.2 | 6
| Placebo + metformin, 210 | 55 | 96 | NR | 29.4 | 92.6 | 8.9 | 8.4
| Placebo + glyburide, 209 | 56 | 103 | NR | 29.1 | 92.6 | 8.5 | 8.7
| Metformin + glyburide, 213 | 55 | 98 | NR | 29 | 92.1 | 8.8 | 7.8
1995 ^92^ | Diet, 664 | NR | NR | NR | NR | NR | NR | NR
UKPDS | Diet + glibenclamide, 472 | NR | NR | NR | NR | NR | NR | NR
| Diet + metformin, 262 | NR | NR | NR | NR | NR | NR | NR
Hermann, 1994 ^87^ | Diet + metformin, 25 | 60 (34 – 74) | (63%) | NR | NR | 78.6 | 6.9 | 4
| Diet + glibenclamide, 21 | NR | NR | NR | NR | 82.6 | 6.7 | NR
| Diet + metformin + glibenclamide, 54 | NR | NR | NR | NR | 80.2 | 6.8 | NR
| Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR | 84.6 | 7.8 | NR
| Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR | 76 | 7.8 | NR
| Diet + metformin + glibenclamide, 18 | NR | NR | NR | NR | 83.2 | 8.4 | NR
Campbell, 1994 ^83^ | Metformin, 24 | 57 | 8 | NR | 29.6 | 78.2 | 11.5 | 2.3
| Glipizide, 24 | 57 | 8 | NR | 31.2 | 82.2 | 11.8 | 2.8
Birkeland, 1994 ^110^ | Diet + glipizide, 46 | 59 | 22 | NR | 26.4 | NR | 8 | 3.5
| Diet + glyburide | NR | NR | NR | NR | NR | 8 | NR
| Placebo + diet | NR | NR | NR | NR | NR | 8.1 | NR
Rosenstock, 1993 ^109^ | Glyburide, 70 | 71.4 | 39 | AA: 0; C: 65; Asian: 0; H: 2; O: 3 | NR | 79.6 | 5.7 | 11
| Glyclazide, 69 | 70.2 | 48 | AA: 0; C: 64; Asian: 0; H: 2; O: 3 | NR | 80.5 | 5.8 | 11
Carlson, 1993 ^108^ | Glyburide, 104 | 59.2 (33 –80) | 61 | AA: 11; C: 81; Asian: 0; H: 7; O: 5 | NR | NR | 7.6 | N=15/32/57 for <1/1–5/>5 years
| Glyburide, 102 | 60.3 (38 –78) | 62 | AA: 13; C: 81; Asian: 0; H: 4; O: 4 | NR | NR | 7.6 | N=6/42/54 for <1/1–5/>5 years
Wolffenbuttel, 1993 ^120^ | Repaglinide, 29 | 62 (45 – 75) | 25 | NR | 26.1 | 74 | (Range 7.0 – 12.0) | 9
| Glibenclamide, 15 | 62 (45 – 75) | 25 | NR | 26.1 | 70.9 | (Range 7.0 – 12.0) | 9
Leonhardt, 1991 ^263^ | Acarbose, 47 | NR | NR | NR | NR | NR | NR | NR
| Placebo, 47 | NR | NR | NR | NR | NR | NR | NR
Teupe, 1991 ^155^ | Diet, 50 | 56 | 20 | NR | NR | 86.1 | 9.6 | 6.4
| Diet + metformin, 50 | 51.5 | 20 | NR | NR | 89.1 | 10 | 8.1
Noury, 1991 ^86^ | Metformin, 30 | 55 | 16 | NR | 29.1 | 80.4 | 9.75 | 3
| Glyclazide, 27 | 54.9 | 12 | NR | 28 | 79 | 9.72 | 3
Hermann, 1991 ^94^ | Diet + metformin, 16 | 60 overall (38 – 73 overall) | (64 overall) | NR | 27 | 76.5 | 6.7 | NR
| Diet + glibenclamide, 17 | 60 overall (38 – 73 overall) | (64 overall) | NR | 29.2 | 84.1 | 6.6 | NR
| Diet + metformin + glibenclamide, 12 | 60 overall (38 – 73 overall) | (64 overall) | NR | 30 | 87.3 | 7.7 | NR
| Diet + metformin + glibenclamide, 11 | 60 overall (38 – 73 overall) | (64 overall) | NR | 26.1 | 74.4 | 7.8 | NR
Schneider, 1991 ^173^ | Placebo, 16 | 61.5 | 9 | NR | 27.1 | NR | 6.48 | NR
| Metformin, 18 | 60.4 | 8 | NR | 26.1 | NR | 6.76 | NR
Hermann, 1991 ^159^ | Diet + metformin + glibenclamide, 72 | 60 (34 – 74) | 79 | NR | 28.4 | 82.3 | NR | NR
| Diet + metformin, 38 | NR | NR | NR | NR | NR | NR | NR
| Diet + glibenclamide, 34 | NR | NR | NR | NR | NR | NR | NR
| Diet, 14 | NR | NR | NR | NR | NR | NR | NR
Dornan, 1991 ^260^ | Metformin, 30 | 55 | (53) | NR | 30 | NR | 11.7 | NR
| Placebo, 30 | 55 | (30) | NR | 30 | NR | 11.8 | NR
Kilo, 1988 ^147^ | Glyburide, 47 | NR | 66 overall | NR | NR | NR | NR | NR
| Glipizide, 52 | NR | NR | NR | NR | NR | NR | NR
1985 ^91^ | Diet | 52 | (64%) | NR | NR | overall N=77 >120% ideal weight | NR | 0
UKPDS | Diet + unspecified sulfonylurea | NR | NR | NR | NR | overall N=77 >120% ideal weight | NR | 0
| Diet + metformin | NR | NR | NR | NR | overall N=77 >120% ideal weight | NR | 0
Harrower, 1985 ^113^ | Glipizide, 24 | 62 | NR | NR | NR | NR | 10 | 2.6
| Glyclazide, 22 | 60 | NR | NR | NR | NR | 13 | 3.5
| Glibenclamide, 23 | 60 | NR | NR | NR | NR | 11 | 3.5
Baba, 1983 ^133^ | Glyclazide, 146 | Age categories (N) | 78 (53.42) | NR | Obesity Index: <119%: 71.9%; >120%: 28.1% | NR | NR | Duration categories (N)
| | <39: 11 | | | | | | <1: 35
| | 40–49: 25 | | | | | | 1–4: 25
| | 50–59: 46 | | | | | | 5–9: 39
| | 60–69: 52 | | | | | | >10: 47
| | >70: 12
| Glibenclamide, 131 | Age categories (N) | 55 (41.98) | NR | Obesity Index: <119%: 71%; >120%: 29% | NR | NR | Duration categories (N)
| | <39: 13 | | | | | | <1: 30
| | 40–49: 24 | | | | | | 1–4: 35
| | 50–59: 46 | | | | | | 5–9: 34
| | 60–69: 35 | | | | | | >10: 35
| | >70: 13
Tseng, 2005 ^140^ | Unspecified sulfonylurea + pioglitazone, 23 | 58 | 8 | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | NR | 61.3 | NR | NR
| Placebo + unspecified sulfonylurea, 25 | 54 | 9 | NR | NR | 62.6 | NR | NR
Wolever, 2000 ^98^ | Placebo, 45 | 58.5 | 27 | NR | 30.8 | NR | 7.8 | 4.5
| Metformin, 62 | 58.7 | 45 | NR | 30.5 | NR | 8.2 | 7.3
| Miglitol, 45 | 56.8 | 39 | NR | 30.7 | NR | 7.9 | 4.7
| Metformin + miglitol, 47 | 59.5 | 42 | NR | 29.9 | NR | 8.2 | 5.2
Cefalu, 1998 ^261^ | Placebo, 20 | 58.7 | 15 (75) | NR | NR | 91 | NR | NR
| Glipizide GITS, 20 | 56.7 | 13 (65) | NR | NR | 84 | NR | NR
Turner, 1998 ^93^ | Diet + metformin | NR | NR | NR | NR | NR | NR | NR
UKPDS | Diet + glyburide or chlorpropamide | NR | NR | NR | NR | NR | NR | NR
Garber, 2006 ^71^ | Diet + metformin + glibenclamide, 160 | 56 (31 – 78) | 90 | AA: 8 (5); C: 128 (80); Asian: 4 (3); H: 17 (11); O: 3 (2) | 32 | 93 | 8.5 | 5
| Diet + metformin + rosiglitazone, 158 | 56 (24 – 78) | 102 | AA: 9 (6); C: 125 (79); Asian: 4 (3); H: 16 (10); O: 4 (3) | 32 | 94 | 8.4 | 6

BMI = body mass index; kg = kilograms; HbA1c = hemoglobin A1c; AA = African American; C = Caucasian; H = Hispanic; O = Other; NR = not reported; SD = standard deviation; XR = extended release; GITS = gastrointestinal therapeutic system; F = females; M = males; UKPDS = United Kingdom Prospective Diabetes Study; DIACOM = effect of Dosing frequency of oral Antidiabetic agents on the COMpliance and biochemical control of type 2 diabetes

Table 4 Evidence Table. Grading of the Body of Evidence for Proximal Clinical Outcome Measures

| Key Question 1
| Comparative Effectiveness of Short Term Outcomes and Quality of Life
| HbA1c/2hr PPG | BMI/Weight | SBP/DBP | Lipids | QOL
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Thiazolidinedione vs. Metformin
[underlined: Quantity of Evidence:] | 7/1 | 4/6 | 5/5 | 6/8/8 | 0
Number of studies
Total number of patients studied | 2194/36 | 268/2152 | 1546 | 1630 | 0
[underlined: Quality and Consistency of Evidence:] | high | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | 0 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | -1 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgement for absolute differences.] | +1 | +1 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +1 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | High | Moderate | Low | Moderate
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Thiazolidinediones vs Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 12/1 | 5/5 | 6/6 | 7/7/7 | 2 indirect studies only
Number of studies
Total number of patients studied | 2957/41 | 438/1911 | 820 | 1968 | 611
[underlined: Quality and Consistency of Evidence:] | high | High | High | High | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -1 | -2 | -0.5
Did the studies have important inconsistency? (-1) | 0 | -1 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | -1 | 0 | 0 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgement for absolute differences.] | +1 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +0.5 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Moderate | Low | Moderate | Low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 18/7 | 7/14 | 6/6 | 10/13/14 | 0
Number of studies
Total number of patients studied | 2494/1570 | 598/2445 | 957 | 2323 | 0
[underlined: Quality and Consistency of Evidence:] | high | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | 0 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | +1 | +1 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +0.5 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | high | High | Low | Moderate to Low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second Generation Sulfonylureas vs Meglitinides
[underlined: Quantity of Evidence:] | 7/3 | 1/5 | 2/2 | 3/6/5 | 2 indirect studies only
Number of studies
Total number of patients studied | 1486/358 | 124/1256 | 444 | 1514 | 822
[underlined: Quality and Consistency of Evidence:] | high | High | High | High | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -0.5 | -1 | -1 | 0 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | +1 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +0.5 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Moderate | Low | Very low | Moderate | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Metformin + Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 11/4 | 4/10 | 2/2 | 7/10/8 | 0
Number of studies
Total number of patients studied | 2631/1516 | 494/2186 | 645 | 2007 | 0
[underlined: Quality and Consistency of Evidence:] | high | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | 0 | 0 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | +1 | +2 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +1 | +1 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | High | High | Very low | Low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second Generation Sulfonylureas vs Metformin + Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 13/5 | 3/13 | 5/5 | 7/8/9 | 0
Number of studies
Total number of patients studied | 3457/1622 | 398/3513 | 1485 | 2835
[underlined: Quality and Consistency of Evidence:] | high | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | 0 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgement for absolute differences.] | +1 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | +1 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | High | Moderate | Low | Moderate
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Metformin +Tthiazolidinediones
[underlined: Quantity of Evidence:] | 4/0 | 0/2 | 0/0 | 4/4/4 | 1
Number of studies
Total number of patients studied | 1423/0 | 890 | 0 | 1311 | 528
[underlined: Quality and Consistency of Evidence:] | High | High | | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgement for absolute differences.] | 1 | 0 | | 1 | 1
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 1 | | 1 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Moderate | Low | | Moderate to low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second Generation Sulfonylurea versus Second generation Sulfonylurea + Thiazolidinediones
[underlined: Quantity of Evidence:] | 4/0 | 1/2 | 1/1 | 3/3/3 | 1
Number of studies
Total number of patients studied | 1061 | 95/598 | 95 | 785 | 237
[underlined: Quality and Consistency of Evidence:] | High | High | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | -1 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | 0 | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 1 | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Moderate | Very low | Very low | Low to very low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Pioglitazone vs Rosiglitazone
[underlined: Quantity of Evidence:] | 3/1 (direct); 8 (placebo-controlled trials each) | 1(direct) | 1/1(direct) | 3/3/3 (direct); 6–8 (placebo-controlled trials each) | 0
Number of studies
Total number of patients studied | 933/87 | 87 | 735 | 933
[underlined: Quality and Consistency of Evidence:] | High | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | 0 | 0 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 1
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Moderate to low | Very low | Very low | Moderate to low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Thiazolidinediones vs Alpha-glucosidase inhibitors
[underlined: Quantity of Evidence:] | 2/0(direct); 8, 8, & 28 (placebo-controlled trials) | 0/1(direct); 6, 4, & 16 (placebo-controlled trials) | 2/2 | 1/1/1 (direct); 6, 8 & 4(placebo-controlled trials for LDL), 4,6,&6 (for TG) | 0
Number of studies
Total number of patients studied | 295(direct) | 265(direct) | 295 | 265(direct)
[underlined: Quality and Consistency of Evidence:] | High | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -2 | -2 | 0 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | -1 | 0
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | -1 | -1
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | Very Low | Low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Alpha-glucosidase inhibitors
[underlined: Quantity of Evidence:] | 3/1 (direct); 15 and 28/ 1 and 23 (placebo-controlled trials) | 0/3 (direct); 8 and 16 (placebo-controlled trials) | 0/0 | 1/2/2(direct); 4 and 4 (placebo-controlled trials for LDL); 7 and 4 (for TG) | 0
Number of studies
Total number of patients studied | 227(direct) | 281(direct) | | 120 (direct)
[underlined: Quality and Consistency of Evidence:] | High | High | | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -2 | -2 | | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | | 0
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | | -1
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | | Low to very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second-generation sulfonylureas vs alpha-glucosidase inhibitors
[underlined: Quantity of Evidence:] | 11/8; 11, 28, and 7 (indirect) | 5/7 (direct); 4 and 16 (placebo-controlled trials) | 1/1 | 4/8/9 | 0
Number of studies
Total number of patients studied | 868 | 698 (direct) | 30 | 681
[underlined: Quality and Consistency of Evidence:] | High | High | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | -1 | 0 | 0
Did the studies have important inconsistency? (-1) | -1 | -1 | 0 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | 0 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | -1 | -1 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Low | Low | Very Low | Low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; very low = any estimate of effect is very uncertain.

Table 5 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: hemoglobin A1c

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with | P-value for comparisons with | Other
Study group | | | | | | GP1 final mean (SD) | GP2 final mean (SD) | | GP1 | GP2
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Khan, 2002 ^51^ | % | Rosiglitazone, 60 | Pioglitazone, 67 | 2–8 (fixed) | 15–45 (fixed) | 7.9 (1.9) | 8.0 (1.7) | -0.1 | NSG vs. GP2
| | | | | | 7.6 | 7.8
| | | | | | -0.3* | -0.2*
Goldberg, 2005 ^52^ | % | Rosiglitazone + diet, 356 | Pioglitazone + diet, 363 | 4 (esc) 8 | 30 (esc) 45 | 7.5 (SE 0.1) | 7.6 (SE 0.1) | 0.1 | <.05 vs. baseline | <.05 vs. baseline
| | | | | | 6.9 | 6.9
| | | | | | -0.6 (SE 0.1) | -0.7 (SE 0.1)
Derosa, 2005 ^53^ | % | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 8 (0.8) | 8.2 (0.7) | 0.1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | 4 (fixed) | 4 (fixed) | 6.7 (0.9) | 6.8 (0.8)
| | | | | | -1.3 | -1.4
Thiazolidinedione vs. Metformin
Pavo, 2003 ^59^ | % | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | 8.6 | 8.6 | 0.2 | 0.28 vs. GP2 | <0.0001 vs. baseline
| | | | | | 7.3 | 7.1 | | <0.0001 vs. baseline
| | | | | | -1.3 | -1.5
Lawrence, 2004 ^54^ | % | Pioglitazone, 20 | Metformin, 20 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 7.43 (0.9) | 8.04 (0.9) | 0.31 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.62 (0.5) | 6.9 (0.5) | | NSG vs. GP2
| | | | | | -0.81 (0.63) | -1.12 (0.84)
Ramachandran, 2004 ^55^ | % | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 9.3 (1.8) | 9.6 (2.4) | -1.2 | p<0.01 vs. baseline | p<0.05 vs. baseline
| | | | | | 6.7 (1.3) | 8.2 (2.5)
| | | | | | -2.6 | -1.4
Schernthaner, 2004 ^56^ | % | Pioglitazone + placebo + diet, 588 | Metformin + placebo + diet, 588 | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | 8.69 (1.02) | 8.68 (0.98) | 0.09 | NR | NR
| | | | | | 7.28 | 7.18
| | | | | | -1.41 | -1.5
Yamanouchi, 2005 ^57^ | % | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 10.2 (0.8) | 9.9 (0.7) | -0.2 | <0.005 vs. baseline | <0.005 vs. baseline
| | | | | | 7.9 (1.0) | 7.8 (1.0)
| | | | | | -2.3 | -2.1
Hallsten, 2002 ^58^ | % | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 6.8 (0.2) | 6.9 (0.2) | 0.4 | <0.05 vs. baseline | <0.0001 vs. baseline
Virtanen, 2003 ^143^ | | | | | | 6.5 (0.2) | 6.2 (0.2) | | NSG vs. GP2
| | | | | | -0.3 | -0.7
Hanefeld, 2004 ^60^ | % | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 8.82 (0.98) | 8.8 (0.97) | 0.16 | | 0.065 vs. GP1
QUARTET study group | | | | NR | NR | 7.61 (0.06) | 7.45 (0.06)
| | | | | | -1.2 | -1.36
Thiazolidinedione vs. Second Generation Sulfonylurea
Bakris, 2003 ^66^ | % | Rosiglitazone, 57 | Glyburide (no trade drug specified), 64 | 4 bid (fixed) | NR (esc) 20 | 9.1 (1.68) | 9.5 (1.59) | 0 | NSG vs. GP2
St John Sutto, 2002 ^67^ | | | | | | 8.2 | 8.6
| | | | | | -0.9 (1.38) | -0.9 (1.39)
Tan, 2004 ^65^ | % | Pioglitazone, 91 | Glibenclamide, 109 | 30 (esc) 45 | 1.75 (esc) 10.5 | 8.4 (0.7) | 8.5 (0.8) | -0.1 | <0.005 vs. baseline | <0.005 vs. baseline
| | | | | | 7.9 | 8.1
| | | | | | -0.5 | -0.4
Nakamura, 2000 ^64^ | % | Pioglitazone, 15 | Glibenclamide, 15 | 30 (fixed) | 5 (fixed) | 7.7 (1.2) | 7.8 (1.1) | 0 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 6.8 (1.0) | 6.9 (1.2)
| | | | | | -0.9 | -0.9
Charbonnel, 2005 ^63^ | % | Pioglitazone | Gliclazide | NR (esc) 45 | NR (esc) 320 | 8.7 | 8.7 | 0 | NR | NR
| | | | | | 7.2 | 7.3
| | | | | | -1.4 | -1.4
Tan, 2005 ^61^ | % | Pioglitazone, 147 | Gliclazide, 128 | 15 (esc) 45 | 80 (esc) 320 | 8.55* | 8.75* | -0.45 (0.66 - -0.23^‡^) | NR | NR
One year extension study for Quartet study group | | | | | | 7.3* | 7.6*
| | | | | | -1.25 | -1.15
Yanagawa, 2004 ^62^ | % | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | 8.3 (0.7) | 8.3 (0.9) | NR | NR | NSG vs. GP1
| | | | | | NR | NR
| | | | | | NR | NR
Lawrence, 2004 ^54^ | % | Pioglitazone, 20 | Gliclazide, 20 | 30 (esc) 45 | 80 od (esc) 160 bid | 7.43 (0.9) | 7.85 (0.9) | 0.4 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.62 (0.5) | 6.64 (0.5) | | NSG vs. GP2
| | | | | | -0.81 (0.63) | -1.21 (0.82)
Pfutzner, 2005 ^68^ | % | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 7.52 (0.85) | 7.44 (0.89) | -0.2 | <0.05 vs. baseline | <0.05 vs. baseline
Langenfeld, 2005 ^146^ | | | | | | 6.71 (0.89) | 6.83 (0.85)
Forst, 2005 ^145^ | | | | | | -0.81 | -0.61
Ramachandran, 2004 ^55^ | % | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 9.3 (1.8) | 10.2 (2.2) | -0.1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.7 (1.3) | 7.7 (1.7)
| | | | | | -2.6 | -2.5
Yamanouchi, 2005 ^57^ | % | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 10.2 (0.8) | 9.8 (0.7) | -0.2 | <0.005 vs. baseline | <0.005 vs. baseline
| | | | | | 7.9 (1.0) | 7.7 (0.9)
| | | | | | -2.3 | -2.1
Tan, 2004 ^69^ | % | Pioglitazone + diet + exercise, 109 | Glimepiride + diet + exercise, 99 | 15 (esc) 45 | 2 (esc) 8 | 8.54 (0.903) | 8.45 (1.02) | -0.1 | 0.638 vs. GP2 | <0.001 vs. baseline
| | | | | | 7.76 | 7.77 | | <0.001 vs. baseline
| | | | | | -0.78 (0.162) | -0.68 (0.169)
Matthews, 2005 ^70^ | % | Pioglitazone + metformin + diet, 317 | Metformin + gliclazide + diet, 313 | 15 (esc) 45 | NR | NR | NR | -0.02 | 0.837 vs. GP2
| | | | NR | 80 (esc) 320 | NR | NR
| | | | | | -0.99 | -1.01
Thiazolidinedione + Metformin vs. Second Generation Sulfonylurea + Metformin
Derosa, 2005 ^72^ | % | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 8 (0.7) | 7.9 (0.6) | -0.3 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | 1500 (fixed) | 2 (fixed) | 6.8 (0.6) | 7 (0.7) | | | NSG vs. GP1
| | | | | | -1.2 | -0.9
Garber, 2006 ^71^ | % | Rosiglitazone + metformin + diet, 155 | Metformin + glibenclamide + diet, 159 | 4 (esc) 8 | 1000 (esc) 2000 | 8.4 (1.1) | 8.5 (1.2) | 0.4 | | <0.001 vs. GP1
| | | | 1500–2000 (esc) 2000 | 5 (esc) 10 | 7.2 (1.4) | 6.7 (1.3)
| | | | | | -1.1 | -1.5
Thiazolidinedione vs. Meglitinide
Raskin, 2004 ^74^ | % | Rosiglitazone, 55 | Repaglinide, 59 | 2 bid (esc) 4 bid | 0.5 tid if HbA1c=8%, 1 tid if HbA1c>8% (esc) 4 tid | 9.0 | 9.3 | -0.39 | NR | NR
| | | | | | 8.5 | 9.1
| | | | | | -0.56 (SE 0.14) | -0.17 (SE 0.14)
Jovanovic, 2004 ^73^ | % | Pioglitazone, 57 | Repaglinide, 54 | 30 (fixed) | 0.5 tid if HbA1c=8%, 1 tid if HbA1c>8% (esc) 4 tid | 9.1 | 9 | 0.5 | NSG vs. GP2
| | | | | | 9.5 | 8.9
| | | | | | 0.32 (SE 0.16) | -0.18 (SE 0.17)
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Goke, 2002 ^75^ | % | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 100 tid | 8.98 (1.2) | 9.03 (1.32) | -0.7 | <0.001 vs. GP2
German Pioglitazone Study Group | | | | | | 7.82 (1.95) | 8.55 (1.96)
| | | | | | -1.2 | -0.5
Nakamura, 2000 ^64^ | % | Pioglitazone, 15 | Voglibose, 15 | 30 (fixed) | 0.6 (fixed) | 7.7 (1.2) | 7.6 (1.1) | -0.1 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 6.8 (1.0) | 6.8 (1.1)
| | | | | | -0.9 | -0.8
Other Thiazolidinedione Comparisons
McCluskey, 2004 ^76^ | % | Rosiglitazone + placebo, 15 | Rosiglitazone + glimepiride, 24 | 4 or 8 (fixed) | 4 or 8 fixed | 8.4 (0.7) | 7.9 (0.6) | 0.9 | | <0.05 vs. GP1
| | | | | 2 (esc) 8 | 8.1 | 6.7
| | | | | | -0.3 (SE 0.2) | -1.2 (SE 0.1)
Choi, 2004 ^77^ | % | Rosiglitazone + diet, 38 | Uptitration of existing medications, 45 | 8 (other) 4 | NR (esc) | 7.79 (1.3) | 7.72 (1.13) | 0.14 | <.05 vs. baseline | <.05 vs. baseline
| | | | | | 7.17 (0.98) | 7.23 (0.93)
| | | | | | -0.61 (1.15) | -0.75 (1.07)
Takagi, 2003 ^78^ | % | Pioglitazone, 23 | Control group (conventional antidiabetic therapy), 21 | 30 (fixed) | NR (NR) | 6.8 (0.6) | 6.7 (1.2) | -0.1 | 0.8140 vs. GP2
| | | | | | 6.5 (1.0) | 6.5 (1.3)
| | | | | | -0.3 | -0.2
Metformin vs. Second Generation Sulfonylurea
Garber, 2002 ^79^ | % | Metformin, 161 | Glyburide (Micronase), 161 | 500 (esc) 2000 | 2.5 (esc) 10 | 8.26 (1.08) | 8.21 (1.09) | 0.21 | NR | NR
| | | | | | 7.23 | 6.97
| | | | | | -1.03 | -1.24
Garber, 2003 ^80^ | % | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 8.42 (1.4) | 8.67 (1.4) | 0.37 | NR | NR
| | | | | | 7.01 | 6.75
| | | | | | -1.53 | -1.9
Blonde, 2002 ^81^ | % | Metformin, 104 | Glyburide (no trade drug specified), 132 | 500 (esc) 2000 | 10 bid (fixed) | 9.51 (1.34) | 9.64 (1.44) | 0.5 | NR | NR
| | | | | | 9.7 | 9.5
| | | | | | 0.39 | -0.11
Goldstein, 2003 ^82^ | % | Metformin, 71 | Glipizide, 79 | 500 (esc) 2000 | 15 bid (fixed) | 8.6 (1.2) | 8.9 (1.1) | 0.2 | NR | NR
| | | | | | 8.4 (0.1) | 8.5 (0.1)
| | | | | | -0.2 | -0.4
Campbell, 1994 ^83^ | % | Metformin, 24 | Glipizide, 24 | 500 bid (esc) 3000 | 5 (esc) 30 | 11.46 (1.92) | 11.75 (2.11) | -0.64 | <0.05 vs. GP2
| | | | | | 8.64 (1.21) | 9.72 (1.91)
| | | | | | -2.57 | -1.93
Marre, 2002 ^84^ | % | Metformin, 104 | Glibenclamide, 103 | 500 (esc) 2000 | 5 (esc) 20 | 8.09 (1.84) | 7.88 (1.65) | 0.1 | NSG vs. GP2
| | | | | | 7.89 | 7.58
| | | | | | -0.2 | -0.3
Amador-Licona, 2000 ^85^ | % | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 8.5 (1.5) | 8.4 (1.4) | 0.1 | 0.003 | 0.009
| | | | | | 7.6 (0.8) | 7.6 (0.8)
| | | | | | -0.9 | -0.8
Lawrence, 2004 ^54^ | % | Metformin, 20 | Gliclazide, 20 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 8.04 (0.9) | 7.85 (0.9) | 0.09 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.9 (0.5) | 6.64 (0.5) | | NSG vs. GP2
| | | | | | -1.12 (0.84) | -1.21 (0.82)
Noury, 1991 ^86^ | % | Metformin, 30 | Gliclazide, 27 | 1700 (fixed) | 80 (esc) 240 | 9.75 (3.67) | 9.72 (4.14) | -0.52 | <0.02 vs. baseline | <0.02 vs. baseline
| | | | | | 8.46 (3.74) | 8.95 (3.21) | | NSG vs. GP2
| | | | | | -1.29 | -0.77
Ramachandran, 2004 ^55^ | % | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 9.6 (2.4) | 10.2 (2.2) | 1.1 | <0.05 vs. baseline | <0.01 vs. baseline
| | | | | | 8.2 (2.5) | 7.7 (1.7)
| | | | | | -1.4 | -2.5
Hermann, 1994 ^87^ | % | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 6.9 (SE 0.3) | 6.7 (SE 0.3) | 0.4 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | | 5.8 (SE 0.2) | 5.3 (SE 0.1)
| | | | | | -0.9 (SE 0.2) | -1.3 (SE 0.2)
DeFronzo, 1995 ^88^ | % glycated Hb | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) 2500 | 5 bid (esc) 10 bid | 8.9 | 8.5 | -0.6 | <0.001 vs. GP2
| | | | | | 8.5 | 8.7
| | | | | | -0.4 (SE 0.1) | 0.2 (SE 0.1)
Charpentier, 2001 ^89^ | % | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 6.79 (1.17) | 6.52 (1.13) | -0.12 | | 0.369 vs. GP1
| | | | | | 6.86 (1.45) | 6.79 (1.43)
| | | | | | 0.07 (SE 0.14) | 0.27 (SE 0.09)
Yamanouchi, 2005 ^57^ | % | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 9.9 (0.7) | 9.8 (0.7) | 0 | <0.005 vs. baseline | <0.005 vs. baseline
| | | | | | 7.8 (1.0) | 7.7 (0.9)
| | | | | | -2.1 | -2.1
Derosa, 2004 ^90^ | % | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 8.4 (1.0) | 8.5 (1.2) | 0.2 | 0.01 vs. baseline | 0.01 vs. baseline
| | | | | | 7 (0.9) | 6.9 (0.7)
| | | | | | -1.4 (-5.7, -0.51^‡^) | -1.6 (-6.4, -0.47^‡^)
1985 ^91^ | % | Metformin + diet, 16 | Unspecified sulfonylurea + diet, 72 | NR (esc) 2550 | NR (esc) 500 of chlorpropamide or 10 bid of glibenclamide | 8.8 (1.8) | NR | 0.6 | NR | NR
UKPDS, 1 year f/u in obese and non-obese patients | | | | | | 8.1 (1) | 7.7* (7.0, 87^‡^)
| | | | | | -0.7 | -1.3
1995 ^92^ | % | Metformin + diet, 262 | Glibenclamide + diet, 212 | NR (esc) 850 tid | NR (esc) 500 of chlorpropamide or 10 bid of glibenclamide | 7.2* | 7.1* | -0.35 | NR | NR
UKPDS, 3 year f/u of obese patients | | | | | | 6.95*; 7.1 (6.9, 7.3^‡^) | 7.15*
| | | | | | -0.2* (-0.4, 0.01*^‡^) | 0.15* (-0.1, 0.4*^‡^)
Turner, 1998 ^93^ | % | Metformin + diet, 49 | Glyburide (Diabeta) or chlorpropamide + diet, 71 | NR (esc) 2550 | NR (esc) 500 of chlorpropamide or 20 of glyburide | NR | NR | -0.1 | NR | NR
UKPDS, 6 year f/u of primary diet failure group in obese subjects | | | | | | 8.2 (7.1, 9.4) | 8.1 (6.8, 9.7)
| | | | | | NR | NR
1998 ^15^ | % | Metformin, 342 | Glibenclamide, 277 | 850 (esc) 2550 | NR | 7.3 (1.5); 6.9*^#^ | 7.2 (1.5); 7*^#^ | 0.3 | NR | NR
UKPDS, 10 year f/u of obese patients | | | | | | 8.2* | 8*
| | | | | | 1.3 | 1
Hermann, 1991 ^94^ | % | Metformin + diet, 16 | Glibenclamide + diet, 17 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 6.7 (1.3) | 6.6 (1.3) | 0.4 | <0.01 vs. baseline | <0.001 vs. baseline
| | | | | | 5.8 (0.7) | 5.3 (0.5)
| | | | | | -0.9 | -1.3
Tosi, 2003 ^95^ | % | Metformin, 19 | Glibenclamide, 20 | 500 (esc) 3000 | 5 (esc) 15 | 7.7* (1.4) | 7.85* (1.4) | 0.05^§^ | NR | NR
| | | | | | 7.3*^§^ | 7.4*^§^
| | | | | | -0.4^§^ | -0.45^§^
Metformin vs. Meglitinide
Horton, 2000 ^96^ | % | Metformin, 133 | Nateglinide, 134 | 500 tid (fixed) | 120 tid (fixed) | 8.4 (1.2) | 8.3 (1.0) | -0.3 | ≤0.0001 vs. baseline | ≤0.0001 vs. baseline
| | | | | | 7.6 | 7.8 | | | NSG vs. GP1
| | | | | | -0.8 (SE 0.1*) | -0.5 (SE 0.1*)
Derosa, 2003 ^97^ | % | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 7.4 (0.9) | 7.6 (0.9) | -0.1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.5 | 6.8 | | NSG vs. GP2
| | | | | | -0.9 | -0.8
Metformin vs. Alpha-Glucosidase Inhibitor
Wolever, 2000 ^98^ | % | Metformin, 62 | Miglitol, 45 | 500 tid (fixed) | 25 tid (esc) 100 tid | 8.2 (SE 0.1) | 7.9 (SE 0.1) | -0.6 | <0.05 vs. GP2
| | | | | | 7.4 | 7.7
| | | | | | -0.8 (SE 0.2) | -0.2 (SE 0.2)
Willms, 1999 ^99^ | % | Metformin, 27 | Acarbose, 31 | 850 bid (fixed) | 100 tid (fixed) | 10.6 (1.4) | 10.6 (1.3) | -0.2 | | 0.651 vs. GP1
| | | | | | 7.7 | 7.8
| | | | | | -2.5 (SEM 0.16) | -2.3 (SEM 0.32)
Metformin vs. Thiazolidinedione + Metformin
Weissman, 2005 ^100^ | % | Metformin, 277 | Rosiglitazone + metformin, 296 | 1000 (esc) 2000 | 4 (esc) 8 | 7.97 (1.2) | 8.05 (1.2) | 0.2 | NR | NR
| | | | | 1000 (fixed) | 7.26 | 7.12
| | | | | | -0.71 | -0.93
Bailey, 2005 ^101^ | % | Metformin, 272 | Rosiglitazone + metformin, 279 | 2500 (esc) 3000 | 4 (esc) 8 | 7.5 (1.0) | 7.4 (1.0) | 0.22 | | 0.001 vs. GP1
| | | | | 2000 (fixed) | 7.4 (1.1) | 7.1 (1.1)
| | | | | | -0.13 | -0.33
Gomez-Perez, 2002 ^102^ | % | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 2500 (fixed) | 9.8* (SE 0.3*) | 9.75* (SE 0.2*) | 1.5 | 0.2651 vs. baseline | 0.0002 vs. GP1
| | | | | 4 bid (fixed) | 10.2* (SE 0.3*) | 8.6* (SE 0.4*) | | | 0.008 vs. baseline
| | | | | | 0.3 | -1.2
Gomez-Perez, 2002 ^102^ | % | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2500 (fixed) | 9.8* (SE 0.3*) | 10.2* (SE 0.2*) | 1 | 0.2651 vs. baseline | 0.0132 vs. GP1
| | | | | 2 bid (fixed) | 10.2* (SE 0.3*) | 9.5* (SE 0.3*) | | | 0.052 vs. baseline
| | | | | | 0.3 | -0.7
Fonseca, 2000 ^103^ | % | Metformin + placebo, 113 | Rosiglitazone + metformin, 116 | 2500 (fixed) | 4 (fixed) | 8.6 (1.3) | 8.9 (1.3) | -1 | | <0.001 vs. GP1
| | | | | 2500 (fixed) | 9.05 | 8.34
| | | | | | 0.45 | -0.56
Fonseca, 2000 ^103^ | % | Metformin + placebo, 113 | Rosiglitazone + metformin, 110 | 2500 (fixed) | 8 (fixed) | 8.6 (1.3) | 8.9 (1.5) | 1.2 | | <0.001 vs. GP1
| | | | | 2500 (fixed) | 9.05 | 8.12
| | | | | | 0.45 | -0.78
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2002 ^79^ | % | Metformin, 161 | Metformin + glyburide (Micronase), 165 | 500 (esc) 2000 | 500 (esc) 2000 | 8.26 (1.08) | 8.18 (1.14) | 0.5 | | <0.001 vs. GP1
| | | | | 2.5 (esc) 10 | 7.23 | 6.65
| | | | | | -1.03 | -1.53
Garber, 2002 ^79^ | % | Metformin, 161 | Metformin + glyburide (Micronase), 158 | 500 (esc) 2000 | 250 (esc) 1000 | 8.26 (1.08) | 8.25 (1.11) | 0.45 | | <0.001 vs. GP1
| | | | | 1.25 (esc) 5 | 7.23 | 6.77
| | | | | | -1.03 | -1.48
Garber, 2003 ^80^ | % | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 8.42 (1.4) | 8.78 (1.5) | -0.74 | | 0.0003 vs. GP1
| | | | | 1.25 (esc) 5 | 7.01 | 6.43
| | | | | | -1.53 | -2.27
Blonde, 2002 ^81^ | % | Metformin, 104 | Metformin + glyburide (no trade drug specified), 137 | 500 (esc) 2000 | 500 (esc) 2000 | 9.51 (1.34) | 9.42 (1.24) | 1.77 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 9.7 | 7.9
| | | | | | 0.39 | -1.38
Blonde, 2002 ^81^ | % | Metformin, 104 | Metformin + glyburide (no trade drug specified), 135 | 500 (esc) 2000 | 500 (esc) 2000 | 9.51 (1.34) | 9.41 (1.47) | 2.03 | | <0.001 vs. GP1
| | | | | 2.5 (esc) 10 | 9.7 | 7.9
| | | | | | 0.39 | -1.64
Goldstein, 2003 ^82^ | % | Metformin, 71 | Metformin + glipizide, 80 | 500 (esc) 2000 | 500 (esc) 2000 | 8.6 (1.2) | 8.7 (1.2) | 1.06 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 8.4 (0.1) | 7.4 (0.1)
| | | | | | -0.2 | -1.3
Marre, 2002 ^84^ | % | Metformin, 104 | Metformin + glibenclamide, 101 | 500 (esc) 2000 | 500 (esc) 2000 | 8.09 (1.84) | 7.89 (1.62) | 1 | | <0.05 vs. GP1
| | | | | 2.5 (esc) 10 | 7.89 | 6.69
| | | | | | -0.2 | -1.2
Marre, 2002 ^84^ | % | Metformin, 104 | Metformin + glibenclamide, 103 | 500 (esc) 2000 | 500 (esc) 2000 | 8.09 (1.84) | 7.62 (1.61) | 0.7 | | <0.05 vs. GP1
| | | | | 5 (esc) 20 | 7,89 | 6.72
| | | | | | -0.2 | -0.9
Hermann, 1994 ^87^ | % | Metformin + diet, 19 | Metformin + glyburide + diet, 17 | 1000 (esc) 3000 | 2000 (esc) 3000 | 6.9 (SE 0.3) | 8.4 (SE 0.4) | 1.3 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 7.0 (esc) 14.0 | 5.8 (SE 0.2) | 6.2 (SE 0.3)
| | | | | | -0.9 (SE 0.2) | -2.2 (SE 0.4)
Hermann, 1994 ^87^ | % | Metformin + diet, 19 | Metformin + glyburide + diet, 11 | 1000 (esc) 3000 | 1000 (esc) 3000 | 6.9 (SE 0.3) | 7.8 (SE 0.3) | 1.1 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 10.5 (esc) 14.0 | 5.8 (SE 0.2) | 5.7 (SE 0.3)
| | | | | | -0.9 (SE 0.2) | -2.0 (SE 0.4)
Hermann, 1994 ^87^ | % | Metformin + diet, 19 | Metformin + glyburide + diet, 12 | 1000 (esc) 3000 | 3000 (fixed) | 6.9 (SE 0.3) | 7.8 (SE 0.3) | 1.4 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 3.5 (esc) 14.0 | 5.8 (SE 0.2) | 5.4 (SE 0.3)
| | | | | | -0.9 (SE 0.2) | -2.3 (SE 0.4)
Hermann, 1994 ^87^ | % | Metformin + diet, 19 | Metformin + glyburide + diet, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 6.9 (SE 0.3) | 6.8 (SE 0.1) | 0.3 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 5.8 (SE 0.2) | 5.6 (SE 0.1)
| | | | | | -0.9 (SE 0.2) | -1.2 (SE 0.1)
Hermann, 1991 ^94^ | % | Metformin + diet, 16 | Metformin + glibenclamide + diet, 11 | 1000 (esc) 3000 | 1000 (esc) 3000 | 6.7 (1.3) | 7.8 (1.4) | 1.3 | <0.01 vs. baseline | <0.001 vs. baseline
| | | | | 10.5 (esc) 14 | 5.8 (0.7) | 5.7 (0.8)
| | | | | | -0.9 | -2.2
Hermann, 1991 ^94^ | % | Metformin + diet, 16 | Metformin + glibenclamide + diet, 12 | 1000 (esc) 3000 | 3000 (fixed) | 6.7 (1.3) | 7.7 (1.1) | 1.4 | <0.01 vs. baseline | <0.001 vs. baseline
| | | | | 3.5 (esc) 14 | 5.8 (0.7) | 5.4 (0.9)
| | | | | | -0.9 | -2.3
DeFronzo, 1995 ^88^ | % glycated Hb | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | 8.9 | 8.8 | 1.3 | <0.001 vs. GP2
| | | | | 10 (esc) 20 | 8.5 | 7.1
| | | | | | -0.4 (SE 0.1) | -1.7 (SE 0.1)
Charpentier, 2001 ^89^ | % | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 6.79 (1.17) | 6.42 (1.08) | 0.92 | | <0.001 vs. GP1
| | | | | 1 (esc) 6 | 6.86 (1.45) | 5.68 (0.99)
| | | | | | 0.07 (SE 0.14) | -0.74 (SE 0.8)
Feinglos, 2005 ^104^ | % | Metformin + placebo, 56 | Metformin + glipizide, 56 | at least 1000 (fixed) | at least 1000 (fixed) | 7.64 | 7.45 | 0.47 | <0.0002 vs. GP2
| | | | | 2.5 (fixed) | 7.46 (SE 0.1) | 6.8 (SE 0.1)
| | | | | | -0.19 | -0.66
Tosi, 2003 ^95^ | % | Metformin, 19 | Metformin + glibenclamide, 41 | 500 (esc) 3000 | 400 (esc) 2400 | 7.8 (1.4) | 7.8 (1.0) | 1.4 | NR | NR
| | | | | 2.5 (esc) 15 | 7.3^§^ | 5.9^§^
| | | | | | -0.5^§^ | -1.9^§^
Other Metformin Comparisons
Fujioka, 2003 ^105^ | % | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 7.1 (0.8) | 7 (0.8) | -0.08 | NR | NR
| | | | | | 7.25 | 7.23
| | | | | | 0.15 | 0.23
Fujioka, 2003 ^105^ | % | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 7.1 (0.8) | 7 (0.7) | 0.11 | NR | NR
| | | | | | 7.25 | 7.04
| | | | | | 0.15 | 0.04
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Schernthaner, 2004 ^106^ | % | Glimepiride + existing medications, 440 | Gliclazide + existing medications, 405 | 1 (esc) 6 | 30 (esc) 120 | 8.2 (1.0) | 8.4 (1.1) | 0.06 | <0.001 vs. baseline | <0.001 vs. baseline
| | | | | | 7.2 (1.1) | 7.2 (1.1) | | | <0.0001 vs. GP1 (noninferiority test)
| | | | | | -1 (1.1) | -1.1 (1.1)
Dills, 1996 ^107^ | % | Glyburide (Micronase), 259 | Glimepiride, 261 | 1.25 (esc) 20 | 1 (esc) 16 | 8.5 (1.3) | 8.5 (1.2) | 0.04 | NSG vs. GP2
| | | | | | 8.28 (1.48) | 8.24 (1.51)
| | | | | | -0.22 | -0.26
Carlson, 1993 ^108^ | % | Glyburide (Micronase), 98–104 | Glyburide (Glynase Prestab), 94–99 | 3 (fixed) | 5 (fixed) | 7.6 (SE 0.1) | 7.6 (SE 0.1) | -0.1 | NSG vs. GP2
| | | | | | 7.4 (SE 0.2) | 7.5 (SE 0.2)
| | | | | | -0.2 | -0.1
Rosenstock, 1993 ^109^ | % | Glyburide (no trade drug specified) | Gliclazide | 0.5 (esc) 20 | 5 (esc) 40 | 5.7 | 5.8 | 0 | NR | NR
| | | | | | 5.3 | 5.4
| | | | | | -0.4 | -0.4
Birkeland, 1994 ^110^ | % | Glyburide (no trade drug specified) + diet, 15 | Glipizide + diet, 15 | 1.75 (esc) 10.5 | 2.5 (esc) 15 | 8* | 8* | 0.1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 7.4* | 7.5*
| | | | | | -0.6 | -0.5
Inukai, 2005 ^111^ | % | Glimepiride, 120 | Glibenclamide or gliclazide, 52 | 1 or 2 (esc) 6 | 2.5 (fixed) | 7.64 (0.8) | 7.46 (0.83) | -0.15 | 0.73 vs. baseline | 0.538 vs. baseline
| | | | | 40 (fixed) | 7.61 (1.0) | 7.58 (1.03)
| | | | | | -0.03 | 0.12
Draeger, 1996 ^112^ | % | Glimepiride, 455 | Glibenclamide, 451 | 1 (esc) 8 | 2.5 (esc) 20 | 8.03 | 7.8 | 0.07 | 0.25 vs. GP2
| | | | | | 8.39 | 8.32
| | | | | | 0.38 | 0.31
Harrower, 1985 ^113^ | % HbA1 | Glipizide, 20 | Glibenclamide, 19 | 2.5 (esc) 20 | 2.5 (esc) 30 | 10 (2.0) | 11 (6.0) | 3.4 | NSG vs. baseline and vs. GP2 | <0.02 vs. baseline
| | | | | | 11 (3.0) | 9 (4.0)
| | | | | | 0.6 (0.81) | -2.8 (0.9)
Harrower, 1985 ^113^ | % HbA1 | Glipizide, 20 | Gliclazide, 20 | 2.5 (esc) 20 | 20 (esc) 320 | 10 (2.0) | 13 (5.0) | 4.3 | NSG vs. baseline | <0.01 vs. baseline
| | | | | | 11 (3.0) | 9 (4.0) | | <0.01 vs. GP2
| | | | | | 0.6 (0.81) | -3.7 (0.88)
Harrower, 1985 ^113^ | % HbA1 | Glibenclamide, 19 | Gliclazide, 20 | 2.5 (esc) 30 | 20 (esc) 320 | 11 (6.0) | 13 (5.0) | 0.9 | <0.02 vs. baseline | <0.01 vs. baseline
| | | | | | 9 (4.0) | 9 (4.0) | | NSG vs. GP2
| | | | | | -2.8 (0.9) | -3.7 (0.88)
Kardas, 2005 ^114^ | % | Glibenclamide, 48 | Gliclazide, 49 | 10 (esc) 15 | 60 (esc) 90 | 7.2 (1.1) | 6.9 (1.0) | 0.9 | 0.0014 vs. baseline | 0.0006 vs. baseline
DIACOM | | | | | | 7.6 (1.3) | 6.4 (1.6) | | 0.001 vs. GP2
| | | | | | 0.4 (1.2) | -0.5 (1.3)
Second Generation Sulfonylurea vs. Meglitinide
Marbury, 1999 ^116^ | % | Glyburide (no trade drug specified) + placebo, 171 | Repaglinide, 338 | 2.5 (esc) 15 | 0.5 (esc) 12 | 8.9 (1.6) | 8.7 (1.7) | 0.02 | NR | NR
| | | | | | 9.0 | 8.78
| | | | | | 0.1 (0.11) | 0.08 (0.07)
Wolffenbuttel, 1999 ^117^ | % | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 7 (1.2) | 7.1 (1.4) | -0.13 | NSG vs. GP2
| | | | | | 7.45 | 7.68
| | | | | | 0.45 (0.22, 0.69^‡^) | 0.58 (0.41, 0.7^‡^)
Derosa, 2003 ^118^ | % | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 7.8 (1.2) | 8 (1.1) | 0.1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 6.7 (0.9) | 6.8 (0.8) | | NSG vs. GP2
| | | | | | -1.1 (-5.6, -0.54^‡^) | -1.2 (-6.2, -0.48^‡^)
Madsbad, 2001 ^119^ | % | Glipizide + placebo, 81 | Repaglinide, 175 | 5 (esc) 15 | 0.5 (esc) 4 | 7.2 (1.4) | 7.3 (1.2) | 0.59 | | <0.05 vs. GP1
| | | | | | 7.7* (SE 0.2) | 7.4* (SE 0.15)
| | | | | | 0.78 (0.46, 1.1^‡^) | 0.19 (-0.02, 0.4^‡^)
Wolffenbuttel, 1993 ^120^ | % | Glibenclamide, 15 | Repaglinide, 27 | 5 (esc) 15 | 0.5 (esc) 4 | 8.7 (1.8) | 9 (1.9) | 0 | NR | NR
| | | | | | 8.5 (2.0) | 8.8 (2.0)
| | | | | | -0.2 | -0.2
Vakkilainen, 2002 ^122^ | % | Glibenclamide + placebo, 20 | Nateglinide + placebo, 23 | 5 (esc) 10 | 120 tid (fixed) | 7.6 (7.2, 8.1^‡^) | 7.6 (7.2, 8.0^‡^) | -0.5 | <0.001 vs. baseline | NSG vs. baseline
| | | | | | 6.9 (6.5, 7.3^‡^) | 7.4 (7.0, 7.9^‡^)
| | | | | | -0.7 | -0.2
Landgraf, 1999 ^121^ | % | Glibenclamide + placebo, 98 | Repaglinide, 94 | 1.75, 3.5, 7.0, or 10.5 (esc) 10.5 | 0.5, 1.0, 2.0, or 4.0 tid (esc) 4 tid | 8 | 7.8 | -0.1 | NR | NR
| | | | | | 7.6 (SE 0.1) | 7.5 (SE 0.1)
| | | | | | -0.4 | -0.3
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea + Thiazolidinedione
Pfutzner, 2006 ^123^ | % | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 8 (fixed) | 7.7 (1.4) | 8 (1.4) | 1.3 | NSG vs. baseline | <0.001 vs. baseline
| | | | | 3 (fixed) | 7.7 (1.5) | 6.7 (1.0)
| | | | | | 0 | -1.3
Pfutzner, 2006 ^123^ | % | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 4 (fixed) | 7.7 (1.4) | 8.3 (1.4) | 1.2 | NSG vs. baseline | <0.001 vs. baseline
| | | | | 3 (fixed) | 7.7 (1.5) | 7.1 (1.7)
| | | | | | 0 | -1.2
Rosenstock, 2006 ^124^ | % | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | 7.65 (0.99) | 7.72(1.03) | 0.79 | 0.1871 vs. baseline | <0.0001 vs. baseline
| | | | | 10 (esc) 20 | 7.78 | 6.99 | | | <0.0001 vs. GP1
| | | | | | 0.13 | -0.65
Kerenyi, 2004 ^125^ | % | Glibenclamide + diet, 154 | Rosiglitazone + glibenclamide + diet, 160 | 7.5 (esc) 15 | 4 bid (fixed) | 8.1 (1.3) | 7.9 (1.2) | 0.81 | 0.053 vs. baseline | <0.0001 vs. baseline
| | | | | 7.5 (fixed) | 7.96 | 6.99
| | | | | | -0.14 | -0.91
Baksi, 2004 ^126^ | % | Gliclazide | Rosiglitazone + gliclazide | 160 (esc) 320 | 160 (fixed) | 8.6 (1.45) | 8.5 (1.51) | 1.3 | | <0.0001 vs. GP1
| | | | | 4 bid (fixed) | NR | 7.3
| | | | | | NR | -1.2
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2002 ^79^ | % | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 165 | 2.5 (esc) 10 | 500 (esc) 2000 | 8.21 (1.09) | 8.18 (1.14) | 0.29 | | <0.004 vs. GP1
| | | | | 2.5 (esc) 10 | 6.97 | 6.65
| | | | | | -1.24 | -1.53
Garber, 2002 ^79^ | % | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 158 | 2.5 (esc) 10 | 250 (esc) 1000 | 8.21 (1.09) | 8.25 (1.11) | 0.24 | | <0.016 vs. GP1
| | | | | 1.25 (esc) 5 | 6.97 | 6.77
| | | | | | -1.24 | -1.48
Garber, 2003 ^80^ | % | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 8.67 (1.4) | 8.78 (1.5) | 0.37 | | | 0.0003 all group comparison
| | | | | 1.25 (esc) 5 | 6.75 | 6.43
| | | | | | -1.9 | -2.27
Blonde, 2002 ^81^ | % | Glyburide (no trade drug specified), 132 | Metformin + glyburide (no trade drug specified), 135 | 10 bid (fixed) | 500 (esc) 2000 | 9.64 (1.44) | 9.41 (1.47) | 1.53 | | <0.001 vs. GP1
| | | | | 2.5 (esc) 10 | 9.5 | 7.9
| | | | | | -0.11 | -1.64
Blonde, 2002 ^81^ | % | Glyburide (no trade drug specified), 132 | Metformin + glyburide (no trade drug specified), 137 | 10 bid (fixed) | 500 (esc) 2000 | 9.64 (1.44) | 9.42 (1.24) | 1.27 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 9.5 | 7.9
| | | | | | -0.11 | -1.38
Erle, 1999 ^127^ | % | Glyburide (no trade drug specified), 18 | Metformin + glyburide (no trade drug specified), 15 | 5 (esc) 15 | 800 (esc) 1600 | 7.37 (1.48) | 7.67 (1.75) | 1.03 | NSG vs. baseline | <0.01 vs. baseline and vs. GP1
| | | | | 5 (esc) 10 | 7.58 (1.69) | 6.85 (1.43)
| | | | | | 0.21 | -0.82
DeFronzo, 1995 ^88^ | % glycated Hb | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 8.5 | 8.8 | 1.9 | <0.001 vs. GP2
| | | | | 10 (esc) 20 | 8.7 | 7.1
| | | | | | 0.2 (SE 0.1) | -1.7 (SE 0.1)
Charpentier, 2001 ^89^ | % | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 6.52 (1.13) | 6.42 (1.08) | 1.04 | | <0.001 vs. GP1
| | | | | 1 (esc) 6 | 6.79 (1.43) | 5.68 (0.99)
| | | | | | 0.27 (SE 0.09) | -0.74 (SE 0.08)
Goldstein, 2003 ^82^ | % | Glipizide, 79 | Metformin + glipizide, 80 | 30 (fixed) | 500 (esc) 2000 | 8.9 (1.1) | 8.7 (1.2) | 1.06 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 8.5 (0.1) | 7.4 (0.1)
| | | | | | -0.4 | -1.3
Marre, 2002 ^84^ | % | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 (esc) 20 | 500 (esc) 2000 | 7.88 (1.65) | 7.89 (1.62) | 0.9 | | <0.05 vs. GP1
| | | | | 2.5 (esc) 10 | 7.58 | 6.69
| | | | | | -0.3 | -1.2
Marre, 2002 ^84^ | % | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 (esc) 20 | 500 (esc) 2000 | 7.88 (1.65) | 7.62 (1.61) | 0.6 | | <0.05 vs. GP1
| | | | | 5 (esc) 20 | 7.58 | 6.72
| | | | | | -0.3 | -0.9
Gregorio, 1999 ^129^ | % | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 10.32 (SE 0.13) | 10.33 (SE 0.13) | 0.01 | <0.0005 vs. baseline | <0.0005 vs. baseline
| | | | 120 (esc) 240 | NR (fixed) | 8.58 (SE 0.12) | 8.54 (SE 0.12)
| | | | | NR (fixed) | -1.74 | -1.75
Hermann, 1994 ^87^ | % | Glyburide + diet, 19 | Metformin + glyburide + diet, 17 | 3.5 (esc) 10.5 | 2000 (esc) 3000 | 6.7 (SE 0.3) | 8.4 (SE 0.4) | 0.9 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 7.0 (esc) 14.0 | 5.3 (SE 0.1) | 6.2 (SE 0.3)
| | | | | | -1.3 (SE 0.2) | -2.2 (SE 0.4)
Hermann, 1994 ^87^ | % | Glyburide + diet, 19 | Metformin + glyburide + diet, 12 | 3.5 (esc) 10.5 | 3000 (fixed) | 6.7 (SE 0.3) | 7.8 (SE 0.3) | 1 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 3.5 (esc) 14 | 5.3 (SE 0.1) | 5.4 (SE 0.3)
| | | | | | -1.3 (SE 0.2) | -2.3 (SE 0.4)
Hermann, 1994 ^87^ | % | Glyburide + diet, 19 | Metformin + glyburide + diet, 11 | 3.5 (esc) 10.5 | 1000 (esc) 3000 | 6.7 (SE 0.3) | 7.8 (SE 0.4) | 0.7 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 10.5 (esc) 14 | 5.3 (SE 0.1) | 5.7 (SE 0.3)
| | | | | | -1.3 (SE 0.2) | -2 (SE 0.4)
Hermann, 1994 ^87^ | % | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 6.7 (SE 0.3) | 6.8 (SE 0.1) | -0.1 | 0.001 vs. baseline | 0.001 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 5.3 (SE 0.1) | 5.6 (SE 0.1)
| | | | | | -1.3 (SE 0.2) | -1.2 (SE 0.1)
Hermann, 1991 ^94^ | % | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 11 | 3.5 (esc) 10.5 | 1000 (esc) 3000 | 6.6 (1.3) | 7.8 (1.4) | 0.7 | <0.001 vs. baseline | <0.001 vs. baseline
| | | | | 10.5 (esc) 14.0 | 5.3 (0.5) | 5.7 (0.8)
| | | | | | -1.3 | -2.0
Hermann, 1991 ^94^ | % | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 12 | 3.5 (esc) 10.5 | 3000 (fixed) | 6.6 (1.3) | 7.7 (1.1) | 0.9 | <0.001 vs. baseline | <0.001 vs. baseline
| | | | | 3.5 (esc) 14.0 | 5.3 (0.5) | 5.4 (0.9)
| | | | | | -1.3 | -2.2
1998 ^128^ | % | Glibenclamide + diet, 300 | Metformin + glibenclamide + diet, 291 | 10 (fixed) | 500 (esc) 2500 | 7.3^#^ (6.2, 8.8^##^) | 7.4^#^ (6.4, 8.8^##^) | 0.29 | | 0.0208 vs. GP1
UKPDS, 3 year f/u | | | | | 10 (fixed) | 8*^#^ | 7.45*^#^
| | | | | | 0.76 (0.52, 0.99^‡^) | 0.47 (0.24, 0.7^‡^)
Tosi, 2003 ^95^ | % | Glibenclamide, 20 | Metformin + glibenclamide, 41 | 5 (esc) 15 | 2400 (max); 15 (max) | 7.8 (1.4) | 8.6 (1) | 1.8^§^ | NR | NR
| | | | | | 7.4^§^ | 6.4^§^
| | | | | | -0.4^§^ | -2.2^§^
Second Generation Sulfonylurea vs. Alpha-Glucosidase Inhibitor
Feinbock, 2003 ^130^ | % | Glimepiride, 93 | Acarbose, 59 | 1 (esc) 6 | 50 tid (esc) 200 tid | 9.1 (1.9) | 9.4 (2.0) | -0.7 | 0.014 vs. GP2
| | | | | | 6.6 (1.3) | 7.7 (1.9)
| | | | | | -2.5 | -1.8
Nakamura, 2000 ^64^ | % | Glibenclamide, 15 | Voglibose, 15 | 5 (fixed) | 0.6 (fixed) | 7.8 (1.1) | 7.6 (1.1) | 0.1 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 6.9 (1.2) | 6.8 (1.1)
| | | | | | -0.9 | -0.8
Meglitinide vs. Meglitinide
Rosenstock, 2004 ^131^ | % | Nateglinide, 69 | Repaglinide, 71 | 60 (esc) 360 | 5 (esc) 16 | 8.9 (1.74) | 8.9 (1.34) | 0.53 | | 0.002 vs. GP1
| | | | | | 7.9 (1.36) | 7.3 (1.3)
| | | | | | -1.04 (0.14) | -1.57 (0.15)
Pioglitazone vs. Placebo
Saad, 2004 ^164^ | % | Pioglitazone, 24 | Placebo, 27 | 45 (fixed) | NA | 8.5 | 8.1 | -1.1 | <.05 vs. GP2
| | | | | | 8.2 | 8.9
| | | | | | -0.3 | 0.8
Herz, 2003 ^163^ | % | Pioglitazone, 95 | Placebo, 96 | 30 (fixed) | NA | 7.5 | 7.5 | -0.6 | <0.001 vs. baseline and vs. GP2 | 0.025 vs. baseline
| | | | | | 6.7 | 7.3
| | | | | | -0.8 | -0.2
Herz, 2003 ^163^ | % | Pioglitazone, 96 | Placebo, 96 | 45 (fixed) | NA | 7.6 | 7.5 | -0.7 | <0.001 vs. baseline and vs. GP2 | 0.025 vs. baseline
| | | | | | 6.7 | 7.3
| | | | | | -0.9 | -0.2
Rosenblatt, 2001 ^162^ | % | Pioglitazone, 100 | Placebo, 93 | 30 (NR) | NA | 10.65 (1.77) | 10.4 (1.7) | -1.36 | < 0.05 vs. baseline | < 0.05 vs. baseline
| | | | | | 10.05 | 11.18 | | <0.0001 vs. GP2
| | | | | | -0.6 | 0.76
Scherbaum, 2002 ^141^ | % | Pioglitazone + diet, 76 | Placebo + diet, 76 | 30 (fixed) | NA | 9.06 (1.2) | 8.75 (1.06) | -0.71 | 0.003 vs. GP2
| | | | | | 7.78 (1.18) | 8.29 (1.05)
| | | | | | -1.05 (1.25) | -0.34 (0.98)
Scherbaum, 2002 ^141^ | % | Pioglitazone + diet, 83 | Placebo + diet, 76 | 15 (fixed) | NA | 9.33 (1.18) | 8.75 (1.06) | -0.58 | NSG vs. GP2
| | | | | | 7.99 (0.95) | 8.29 (1.05)
| | | | | | -0.92 (1.50) | -0.34 (0.98)
Nishio, 2006 ^151^ | % | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 7.7 (2.2) | 6.9 (1.6) | -1.3 | 0.028 vs. baseline | 0.356 vs. baseline
| | | | | | 6 (0.9) | 6.5 (1.2)
| | | | | | -1.7 | -0.4
Aronoff, 2000 ^165^ | % | Pioglitazone, 80 | Placebo, 79 | 7.5 (fixed) | NA | 10.0 (SE 0.22) | 10.4 (SE 0.22) | -0.5
| | | | | | 10.2 (SE 0.25) | 11.1 (SE 0.26)
| | | | | | 0.2 (SE 0.17) | 0.7 (SE 0.17)
Aronoff, 2000 ^165^ | % | Pioglitazone, 79 | Placebo, 79 | 15 (fixed) | NA | 10.2 (SE 0.22) | 10.4 (SE 0.22) | -1 | ≤0.05 vs. baseline and GP2
| | | | | | 9.9 (SE 0.27) | 11.1 (SE 0.26)
| | | | | | -0.3 (SE 0.17) | 0.7 (SE 0.17)
Aronoff, 2000 ^165^ | % | Pioglitazone, 85 | Placebo, 79 | 30 (fixed) | NA | 10.2 (SE 0.21) | 10.4 (SE 0.22) | -1 | ≤0.05 vs. baseline and GP2
| | | | | | 9.9 (SE 0.29) | 11.1 (SE 0.26)
| | | | | | -0.3 (SE 0.17) | 0.7 (SE 0.17)
Aronoff, 2000 ^165^ | % | Pioglitazone, 76 | Placebo, 79 | 45 (fixed) | NA | 10.3 (SE 0.22) | 10.4 (SE 0.22) | -1.6 | ≤0.05 vs. baseline and GP2
| | | | | | 9.4 (SE 0.29) | 11.1 (SE 0.26)
| | | | | | -0.9 (SE 0.18) | 0.7 (SE 0.17)
Einhorn, 2000 ^160^ | % | Pioglitazone + metformin + diet, 168 | Metformin + placebo + diet, 160 | 30 (fixed) | NR (NR) | 9.86 (SE 1.4) | 9.75 (SE 1.3) | -0.83 | <0.05 vs. baseline and vs. GP1 | <0.05 vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | NR | NR
Smith, 2005 ^161^ | % | Pioglitazone + diet, 21 | Placebo + diet, 21 | 30 (esc) 45 | NA | 6.88 (1.35) | 6.46 (0.72) | -0.85 | 0.0054 vs. GP2
| | | | | | -0.96 | -0.11
Tseng, 2005 ^140^ | % | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | NR | NR | NR | <0.05 vs. baseline | NSG vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | -8.70%^†^ | 2.6%^†^
Kipnes, 2001 ^166^ | % | Pioglitazone + unspecified sulfonylurea, 176 | Unspecified sulfonylurea + placebo, 181 | 15 (fixed) | NR (fixed) | 10 (9.8, 10.2^‡^) | 9.9 (9.7, 10.1^‡^) | -0.9 (-1.2, -0.6^‡^) | NR | NR
| | | | NR (fixed) | | 9.1 (8.9, 9.3^‡^) | 10 (9.8, 10.2^‡^)
| | | | | | -0.8 (-1.0, -0.6^‡^) | 0.1 (-0.1, 0.2^‡^)
Kipnes, 2001 ^166^ | % | Pioglitazone + unspecified sulfonylurea, 182 | Unspecified sulfonylurea + placebo, 181 | 30 (fixed) | NR (fixed) | 9.9 (9.7, 10.1^‡^) | 9.9 (9.7, 10.1^‡^) | -1.3 (-1.6, -1.0^‡^) | NR | NR
| | | | NR (fixed) | | 8.7 (8.5, 8.9^‡^) | 10 (9.8, 10.2^‡^)
| | | | | | -1.2 (-1.4, -1.0^‡^) | 0.1 (-0.1, 0.2^‡^)
Rosiglitazone vs. Placebo
Patel, 1999 ^167^ | % | Rosiglitazone, 70 | Placebo, 74 | 0.05 bid (fixed) | NA | 9.1 | 9.1 | 0.3 | 0.0569 vs. GP2
| | | | | | 9.7 | 9.4
| | | | | | 0.6 (SE 0.14) | 0.3 (SE 0.13)
Patel, 1999 ^167^ | % | Rosiglitazone, 72 | Placebo, 74 | 0.25 bid (fixed) | NA | 8.9 | 9.1 | 0.3 | 0.0565 vs. GP2
| | | | | | 9.7 | 9.4
| | | | | | 0.6 (SE 0.14) | 0.3 (SE 0.13)
Patel, 1999 ^167^ | % | Rosiglitazone, 79 | Placebo, 74 | 1.0 bid (fixed) | NA | 9.0 | 9.1 | -0.2 | 0.4716 vs. GP2
| | | | | | 9.1 | 9.4
| | | | | | 0.1 (SE 0.13) | 0.3 (SE 0.13)
Patel, 1999 ^167^ | % | Rosiglitazone, 79 | Placebo, 74 | 2.0 bid (fixed) | NA | 9.0 | 9.1 | -0.4 | 0.0287 vs. GP2
| | | | | | 8.9 | 9.4
| | | | | | -0.1 (SE 0.13) | 0.3 (SE 0.13)
Kim, 2005 ^152^ | % | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 9.8 (1.8) | 9.3 (1.3) | 1.1 | <0.001 vs. baseline | NSG vs. baseline
| | | | | | 8.6 (1.3) | 9.2 (1.3)
| | | | | | -1.2 | -0.1
Hallsten, 2002 ^58^ | % | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 6.8 (SE 0.2) | 6.3 (SE 0.1) | 0.1 | <0.05 vs. baseline
Virtanen, 2003 ^143^ | | | | | | 6.5 (SE 0.2) | 6.1 (SE 0.1)
| | | | | | -0.3 | -0.2
Lebovitz, 2001 ^169^ | % | Rosiglitazone, 169 | Placebo, 158 | 4 bid (fixed) | NA | 8.8 (1.6) | 9.0 (1.7) | -1.5 | <0.0001 vs. baseline and vs. GP2 | <0.001 vs. baseline
| | | | | | 8.2 | 9.9
| | | | | | -0.6 (SE 0.3*) | 0.9 (SE 0.3*)
Lebovitz, 2001 ^169^ | % | Rosiglitazone, 166 | Placebo, 158 | 2 bid (fixed) | NA | 9.0 (1.5) | 9.0 (1.7) | -1.2 | 0.0001 vs. baseline | <0.001 vs. baseline
| | | | | | 8.7 | 9.9
| | | | | | -0.3 (SE 0.2*) | 0.9 (SE 0.3*)
Phillips, 2001 ^168^ | % | Rosiglitazone, 186 | Placebo, 173 | 2 bid (fixed) | NA | 8.9 (1.5) | 8.9 (1.5) | -0.9 | <0.0001 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Phillips, 2001 ^168^ | % | Rosiglitazone, 181 | Placebo, 173 | 8 od (fixed) | NA | 8.9 (1.5) | 8.9 (1.5) | -1.1 | <0.0001vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Phillips, 2001 ^168^ | % | Rosiglitazone, 187 | Placebo, 173 | 4 bid (fixed) | NA | 9.0 (1.5) | 8.9 (1.5) | -1.5 | <0.0001vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Phillips, 2001 ^168^ | % | Rosiglitazone, 181 | Placebo, 173 | 4 od (fixed) | NA | 8.9 (1.6) | 8.9 (1.5) | -0.8 | <0.0001vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Barnett, 2003 ^172^ | % | Rosiglitazone + unspecified sulfonylurea, 84 | Unspecified sulfonylurea + placebo, 87 | 4 bid (fixed) | NR (NR) | 9.21 (1.27) | 9.06 (1.3) | -1.42 | <0.001 vs. baseline and vs. GP2 | <0.001 vs. baseline
| | | | NR (NR) | | 8.05 | 9.32
| | | | | | -1.16 | 0.26
Zhu, 2003 ^188^ | % | Rosiglitazone + unspecified sulfonylurea, 215 | Unspecified sulfonylurea + placebo, 105 | 2 bid (fixed) | NR (fixed) | 9.8 (1.5) | 9.8 (1.3) | -1.04 | 0.0001 vs. GP2
| | | | NR (fixed) | | 8.4 (1.4) | 9.4 (1.5)
| | | | | | -1.4 (-1.6, -1.3^‡^) | -0.4 (-0.6, -0.1^‡^)
Zhu, 2003 ^188^ | % | Rosiglitazone + unspecified sulfonylurea, 210 | Unspecified sulfonylurea + placebo, 105 | 4 bid (fixed) | NR (fixed) | 9.9 (1.6) | 9.8 (1.3) | -1.44 | 0.0001 vs. GP2
| | | | NR (fixed) | | 8 (1.27) | 9.4 (1.5)
| | | | | | -1.9 (-2.1, -1.7^‡^) | -0.4 (-0.6, -0.1^‡^)
Vongthavaravat, 2002 ^170^ | % | Rosiglitazone + unspecified sulfonylurea + diet, 164 | Unspecified sulfonylurea + diet, 170 | 2 bid (fixed) | NR (NR) | 9.1 | 8.9 | -1.2 | | 0.0001 vs. GP2
| | | | | | 7.9 | 9
| | | | | | -1.1 (-1.37, -0.89^‡^) | 0.1 (-0.1, 0.2^‡^)
Wolffenbuttel, 2000 ^171^ | % | Rosiglitazone + unspecified sulfonylurea, 199 | Unspecified sulfonylurea + placebo, 192 | 1 bid (fixed) | NR (fixed) | 9.2 (1.19) | 9.21 (1.3) | -0.59 | <0.0001 vs. GP2 and vs. baseline | 0.0671 vs. baseline
| | | | NR (fixed) | | 8.7 | 9.41
| | | | | | -0.5* | 0.2*
Wolffenbuttel, 2000 ^171^ | % | Rosiglitazone + unspecified sulfonylurea, 183 | Unspecified sulfonylurea + placebo, 192 | 2 bid (fixed) | NR (fixed) | 9.23 (1.18) | 9.21 (1.3) | -1.03 | <0.0001 vs. GP2 and vs. baseline | 0.0671 vs. baseline
| | | | NR (fixed) | | 8.33 | 9.41
| | | | | | -0.9* | 0.2*
Metformin vs. Placebo
Garber, 2002 ^79^ | % | Metformin, 161 | Placebo, 161 | 500 (esc) 2000 | NA | 8.26 (1.08) | 8.21 (1.0) | -0.82 | NR | NR
| | | | | | 7.23 | 8.00
| | | | | | -1.03 | -0.21
Horton, 2000 ^96^ | % | Metformin, 133 | Placebo, 106 | 500 tid (fixed) | NA | 8.4 (1.2) | 8.3 (1.1) | -1.2 | ≤0.0001 vs. baseline and vs. GP2
| | | | | | 7.6 | 8.8
| | | | | | -0.8 (SE 0.1*) | 0.5 (SE 0.1*)
Willms, 1999 ^99^ | % | Metformin, 27 | Placebo, 29 | 850 bid (fixed) | NA | 10.6 (1.4) | 10.6 (1.6) | -1.3 | 0.004 vs. GP2
| | | | | | 7.7 | 8.7
| | | | | | -2.5 (SEM 0.16) | -1.3 (SEM 0.34)
Grant, 1996 ^154^ | % | Metformin, 27 | Placebo, 23 | 1500 (esc) 3000 | NA | NR | NR | -1.8 | <0.001 vs. GP2
| | | | | | NR | NR
| | | | | | -1.2 (1.3) | 0.6 (0.8)
Grant, 1996 ^154^ | % | Metformin, 25 | Placebo, 23 | 1500 (fixed) | NA | NR | NR | -1.5 | <0.001 vs. GP2
| | | | | | NR | NR
| | | | | | -0.9 (1.0) | 0.6 (0.8)
DeFronzo, 1995 ^88^ | % | Metformin, 143 | Placebo, 146 | 850 (esc) 850 tid | NA | 8.4 | 8.2 | -1.8 | <0.001 vs. GP2
| | | | | | 7.0 | 7.8
| | | | | | -1.4 (SE 0.1) | 0.4 (SE 0.1)
Schneider, 1991 ^173^ | % | Metformin, 18 | Placebo, 16 | 850 (esc) 1700 | NA | 6.76 (1.05) | 6.48 (0.87) | -0.56 | 0.054 vs. GP2
| | | | | | 6.08 (0.98) | 6.34 (1.11)
| | | | | | -0.69 (0.87) | -0.13 (0.69)
Dornan, 1991 ^260^ | % | Metformin, 30 | Placebo, 30 | 500 (esc) 1000 tid | NA | 11.7 (SE 0.4) | 11.8 (SE 0.4) | -3.0 | <0.001 vs. GP2
| | | | | | 10.3 (SE 0.4) | 13.3 (SE 0.4)
| | | | | | -1.4 | 1.5
Wolever, 2000 ^98^ | % | Metformin, 62 | Placebo, 45 | 500 tid (fixed) | NA | 8.2 (SE 0.1) | 7.8 (SE 0.1) | -1.2 | <0.05 vs. GP2
| | | | | | 7.4 | 8.2
| | | | | | -0.8 (SE 0.2*) | 0.4 (SE 0.2*)
Teupe, 1991 ^155^ | % | Metformin + diet, 25 | Diet, 29 | NR (esc) 1700 | NA | 9.0 (1.3) | 8.7 (0.8) | -0.2 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 8.1 (1.7) | 8.0 (1.2) | | NSG vs. GP2
| | | | | | -0.9 | -0.7
Manzella, 2004 ^148^ | % | Metformin + diet, 60 | Placebo + diet, 60 | 850 bid (fixed) | NA | 8.0 (0.2) | 8.1 (0.2) | -0.6 | <0.05 vs. GP2
| | | | | | 7.2 (0.1) | 7.9 (0.3)
| | | | | | -0.8 | -0.2
Hallsten, 2002 ^58^ | % glycated Hb | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 6.9 (SE 0.2) | 6.3 (SE 0.1) | -0.5 | <0.0001 vs. baseline | NSG vs. baseline
Virtanen, 2003 ^143^ | | | | | | 6.2 (SE 0.2) | 6.1 (SE 0.1)
| | | | | | -0.7 | -0.2
Del Prato, 2003 ^149^ | % | Metformin + placebo, 250 | Placebo, 127 | 850 (esc) 2550 | NA | 7.79 (1.61) | 7.43 (1.48) | -1.5 | NR | NR
| | | | | | 6.77 (1.34) | 7.91 (1.86)
| | | | | | -1.02 | 0.48
Lee, 1998 ^259^ | % | Metformin + placebo + diet, 24 | Placebo + diet, 24 | 850 (fixed) | NA | 8.4 (SE 0.3) | 8.4 (SE 0.2) | -0.9 | <0.05 vs. GP2
| | | | | | 7.4 (SE 0.2) | 8.3 (SE 0.2)
| | | | | | -1 | -0.1
Garber, 1997 ^217^ | % | Metformin, 73 | Placebo, 79 | NR (esc) 500 | NA | 10.1 (1.7) | 9.9 (1.9) | -0.9 | <0.01 vs. GP2
| | | | | | 10.4 | 11.1
| | | | | | 0.3 | 1.2
Garber, 1997 ^217^ | % | Metformin, 73 | Placebo, 79 | NR (esc) 1000 | NA | 10.0 (2.0) | 9.9 (1.9) | -1.19 | <0.001 vs. GP2
| | | | | | 10.01 | 11.1
| | | | | | 0.01 | 1.2
Garber, 1997 ^217^ | % | Metformin, 76 | Placebo, 79 | NR (esc) 1500 | NA | 9.7 (1.5) | 9.9 (1.9) | -1.7 | <0.001 vs. GP2
| | | | | | 9.2 | 11.1
| | | | | | -0.5 | 1.2
Garber, 1997 ^217^ | % | Metformin, 73 | Placebo, 79 | NR (esc) 2000 | NA | 10.1 (2.1) | 9.9 (1.9) | -2 | <0.001 vs. GP2
| | | | | | 9.3 | 11.1
| | | | | | -0.8 | 1.2
Garber, 1997 ^217^ | % | Metformin, 77 | Placebo, 79 | NR (esc) 2500 | NA | 10 (1.8) | 9.9 (1.9) | -1.6 | <0.001 vs. GP2
| | | | | | 9.6 | 11.1
| | | | | | -0.4 | 1.2
1985 ^91^ | % | Metformin + diet, 16 | Diet, 57 | NR (esc) 2550 | NA | 8.8 (1.8) | NR | -0.9 | NR | NR
UKPDS, 1 year f/u of obese patients | | | | | | 8.1 (1.0) | 9.0* (7.7, 10.2*^‡^)
| | | | | | -0.8 | NR
1995 ^92^ | % | Metformin + diet, 262 | Diet, 291 | NR (esc) 850 tid | NA | 7.2* | 7.0* | -1 | NR | NR
UKPDS, 3 year f/u of obese patients | | | | | | 7.1 (6.9, 7.3^‡^); 6.95* | 7.8 (7.6, 8.0^‡^)
| | | | | | -0.2* (-0.4, 0.01^‡^) | 0.8* (0.55, 1.1)
1998 ^15^ | % | Metformin, 342 | Diet, 411 | 850 (esc) 2550 | NA | 7.3 (1.5); 6.9*^#^ | 7.1 (1.5); 6.9*^#^ | -1.3 | NR | NR
UKPDS, 10 year f/u of obese patients | | | | | | 8*^#^ | 9.3*^#^
| | | | | | 1.1 | 2.4
Rachmani, 2002 ^150^ | % | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NA | 8.6 (SE 0.4) | 8.6 (SE 0.5) | -0.3 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | | | 8.8 | 9.1 | | NSG vs. GP2
| | | | | | 0.2 | 0.5
Second Generation Sulfonylurea vs. Placebo
Garber, 2002 ^79^ | % | Glyburide (Micronase), 161 | Placebo, 161 | 2.5 (esc) 10 | NA | 8.21 (1.09) | 8.21 (1.0) | -1.03 | NR | NR
| | | | | | 6.97 | 8.00
| | | | | | -1.24 | -0.21
Birkeland, 1994 ^110^ | % | Glyburide (no trade drug specified) + diet, 15 | Placebo + diet, 16 | 1.75 (esc) 10.5 | NA | 8* | 8.1* | -1 | <.05 vs. GP2
| | | | | | 7.4* | 8.5*
| | | | | | -0.6 | 0.4
Birkeland, 1994 ^110^ | % | Glipizide + diet, 15 | Placebo + diet, 16 | 2.5 (esc) 15 | NA | 8 (1.5*) | 8.1 (1.1*) | -0.9 | <.05 vs. GP2
| | | | | | 7.5 (1.4*) | 8.5 (1.2*)
| | | | | | -0.5* | 0.4*
Schade, 1998 ^135^ | % | Glimepiride, 106 | Placebo, 97 | 1 (esc) 8 | NA | 9.1^#^ | 8.9^#^ | -1.4^#^ | 0.001 vs. GP2
| | | | | | 6.7^#^ | 7.9^#^
| | | | | | -2.1*^#^ | -1.0*^#^
Goldberg, 1996 ^134^ | % | Glimepiride, 68 | Placebo, 59 | 8 (fixed) | NA | 7.8^#^ | 7.8^#^ | -1.9^#^ | <0.001 vs. GP2
| | | | | | 7.5^#^ | 9.5^#^
| | | | | | -0.3^#^ | 1.7^#^
Goldberg, 1996 ^134^ | % | Glimepiride, 65 | Placebo, 59 | 1 (fixed) | NA | 7.8^#^ | 7.8^#^ | -1.2 | <0.001 vs. GP2
| | | | | | 8^#^ | 9.5^#^
| | | | | | 0.2^#^ | 1.7^#^
Goldberg, 1996 ^134^ | % | Glimepiride, 65 | Placebo, 59 | 4 (fixed) | NA | 7.7^#^ | 7.8^#^ | -1.8 | <0.001 vs. baseline
| | | | | | 7.7^#^ | 9.5^#^
| | | | | | 0^#^ | 1.7^#^
Luis Bautista, 2003 ^193^ | % | Glimepiride + diet + exercise, 42 | Placebo + diet + exercise, 18 | 1 (esc) 4 | NA | 10.1 (SE 0.3) | 10.6 (SE 0.6) | -1.8 | <0.001 vs. baseline
| | | | | | 7.8 (SE 0.2) | 9.9 (SE 0.7)
| | | | | | -2.3 | -0.7
Rosenstock, 1996 ^189^ | % | Glimepiride, 75 | Placebo, 66 | 16 od (fixed) | NA | NR | 7.7^#^ | -1.7^#^ | | | <0.01 all group comparison
| | | | | | NR | 9.7^#^
| | | | | | -0.4*^#^ | 1.3*^#^
Rosenstock, 1996 ^189^ | % | Glimepiride, 74 | Placebo, 66 | 4 bid (fixed) | NA | NR | 7.7^#^ | -1.75^#^ | | <0.001 vs. baseline | <0.01 all group comparison
| | | | | | NR | 9.7^#^
| | | | | | -0.45*^#^ | 1.3*^#^
Rosenstock, 1996 ^189^ | % | Glimepiride, 76 | Placebo, 66 | 8 od (fixed) | NA | NR | 7.7^#^ | -1.7^#^ | | <0.001 vs. baseline | <0.01 all group comparison
| | | | | | NR | 9.7^#^
| | | | | | -0.4*^#^ | 1.3*^#^
Rosenstock, 1996 ^189^ | % | Glimepiride, 80 | Placebo, 66 | 8 bid (fixed) | NA | NR | 7.7^#^ | -1.75^#^ | | <0.001 vs. baseline | <0.01 all group comparison
| | | | | | NR | 9.7^#^
| | | | | | -0.6*^#^ | 1.3*^#^
Simonson, 1997 ^136^ | % | Glipizide GITS, 42 | Placebo, 68 | 10 (fixed) | NA | 8.8 (SE 0.2) | 8.3 (SE 0.2) | -2.04 | <0.001 vs. GP2
| | | | | | 7.6 (SE 0.2) | 9.14 (SE 0.2)
| | | | | | -1.2 | 0.84
Simonson, 1997 ^136^ | % | Glipizide GITS, 41 | Placebo, 68 | 15 (fixed) | NA | 8.6 (SE 0.2) | 8.3 (SE 0.2) | -1.33 | <0.0001 vs. GP2
| | | | | | 8.11 (SE 0.2) | 9.14 (SE 0.2)
| | | | | | -0.49 | 0.84
Simonson, 1997 ^136^ | % | Glipizide GITS, 26 | Placebo, 68 | 40 (fixed) | NA | 8.4 (SE 0.3) | 8.3 (SE 0.2) | -2.11 | <0.0001 vs. GP2
| | | | | | 7.13 (SE 0.3) | 9.14 (SE 0.2)
| | | | | | -1.27 | 0.84
Simonson, 1997 ^136^ | % | Glipizide GITS, 29 | Placebo, 68 | 60 (fixed) | NA | 8.6 (SE 0.3) | 8.3 (SE 0.2) | -1.94 | <0.0001 vs. GP2
| | | | | | 7.5 (SE 0.24) | 9.14 (SE 0.2)
| | | | | | -1.1 | 0.84
Simonson, 1997 ^136^ | % | Glipizide GITS, 68 | Placebo, 68 | 20 (fixed) | NA | 8.7 (SE 0.2) | 8.3 (SE 0.2) | -1.74 | <0.0001 vs. GP2
| | | | | | 7.8 (SE 0.2) | 9.14 (SE 0.2)
| | | | | | -0.9 | 0.84
Simonson, 1997 ^136^ | % | Glipizide GITS, 66 | Placebo, 68 | 5 (fixed) | NA | 8.5 (SE 0.2) | 8.3 (SE 0.2) | -1.74 | <0.0001 vs. GP2
| | | | | | 7.6 (SE 0.2) | 9.14 (SE 0.2)
| | | | | | -0.9 | 0.84
Testa, 1998 ^198^ | % | Glipizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | 8.5 (1.5) | 8.7 (1.4) | -1.6 | | <.001 vs. GP1
| | | | | | 7.5 (1.94; SE 0.1) | 9.3 (1.39; SE 0.1)
| | | | | | -0.9 | 0.7
Vray, 1995 ^137^ | % HbA1 | Glibenclamide, 46 | Traditional Chinese treatment, 46 | 2.5 tid (fixed) | Administered in 7 capsules (fixed) | NR | NR | -1.63 | <0.001 vs. baseline | 0.87 vs. baseline
| | | | | | NR | NR
| | | | | | -1.6 (SE 0.3) | 0.03 (SE 0.4)
1998 ^15^ | % | Glibenclamide, 277 | Diet, 411 | NR | NA | 7.2 (1.5); | 7.1 (1.5); | -0.3^#^ | NR | NR
UKPDS, 10 year f/u of overweight patients | | | | | | 7*^#^ | 6.9*^#^
| | | | | | 9.1*^#^ | 9.3*^#^
| | | | | | 2.1 | 2.4
1998 ^16^ | % | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 6.3 (1.3); | 6.2 (1.2); | 0.2^#^ | | <0.0001 vs. GP1
UKPDS, 10 year f/u | | | | | | 6.9*^#^ | 6.9*^#^
| | | | | | 8.2*^#^ | 8.4*^#^
| | | | | | 1.3 | 1.5
1995 ^92^ | % | Glibenclamide + diet, 472 | Diet, 373 | NR (esc) 10 bid | NA | 7.1* | 7.1* | -0.9 | <0.05 vs. baseline | <0.05 vs. baseline
UKPDS, 3 year f/u of non-obese patients | | | | | | 6.9 (6.7, 7.0^‡^) | 7.6 (7.4, 7.7^‡^)
| | | | | | -0.6* (-0.85, -0.4^‡^) | 0.3* (0.1, 0.5)
1995 ^92^ | % | Glibenclamide + diet, 212 | Diet, 291 | NR (esc) 10 bid | NA | 7.1* | 7.0* | -0.65 | NSG vs. baseline | <0.05 vs. baseline
UKPDS, 3 year f/u of obese patients | | | | | | 7.15* | 7.8* (7.6, 8)
| | | | | | 0.15* (-0.15, 0.4^‡^) | 0.8* (0.55, 1.1)
1985 ^91^ | % | Unspecified sulfonylurea + diet, 72 | Diet, 57 | NR (esc) 500 of chlorpropamide or 10 bid of glibenclamide | NA | 9.1 (2.1) | 8.8 (1.7) | -1.6 | <0.001 vs. baseline | NSG vs. baseline
UKPDS, 1 year f/u | | | | | | 7.8 (1.2) | 9.1 (1.6)
| | | | | | -1.3 | 0.3
Cefalu, 1998 ^261^ | % total glycated Hb | Glipizide GITS, 20 | Placebo, 20 | 5 (esc) 10 | NA | 10.3 (SE 0.4) | 9.4 (SE 0.5) | 1.9 | <0.005 vs. baseline
| | | | | | 9.6 (SE 0.5) | 10.6 (SE 0.3)
| | | | | | -0.7 | 1.2
Repaglinide vs. Placebo
Bech, 2003 ^197^ | % | Repaglinide, 164 | Placebo, 89 | 0.5 (esc) 4 per meal | NA | 7.8 (1.7) | 7.6 (1.6) | 0.9 | <0.001 vs. baseline and vs. GP2
| | | | | | 6.7 (1.2) | 7.4 (1.5)
| | | | | | -1.1 | -0.2
Moses, 2001 ^218^ | % | Repaglinide, 260 | Placebo, 134 | 0.5 (esc) 1 per meal | NA | 7.8 (SE 1.8) | 7.6 (SE 1.5) | -0.99 | <0.001 vs. baseline and vs. GP2 | 0.16 vs. baseline
| | | | | | 6.66 | 7.45
| | | | | | -1.14 | -0.15
Goldberg, 1998 ^139^ | % | Repaglinide, 61 | Placebo, 28 | 0.25 tid (esc) 8.0 | NA | 8.3 | 8.1 | -1.8 | ≤0.05 vs. GP2
| | | | | | 7.6* | 9.2*
| | | | | | -0.7 | 1.1
Jovanovic, 2000 ^194^ | % | Repaglinide, 146 | Placebo, 75 | 4 tid (fixed) | NA | 8.7 (1.7) | 8.6 (1.4) | -1.9 | <0.001 vs. GP2
| | | | | | 8.2 | 10
| | | | | | -0.5 | 1.4
Jovanovic, 2000 ^194^ | % | Repaglinide, 140 | Placebo, 75 | 1 tid (fixed) | NA | 8.9 (1.9) | 8.6 (1.4) | -1.8 | <0.001 vs. GP2
| | | | | | 8.2 | 10
| | | | | | -0.7 | 1.4
Nateglinide vs. Placebo
Mari, 2005 ^262^ | % | Nateglinide, 27 | Placebo, 30 | 60 (fixed) | NA | 6.6 (0.6) | 6.5 (0.6) | -0.1 | NR | NR
| | | | | | 6.4 | 6.4
| | | | | | -0.2 (0.5) | -0.1 (0.5)
Mari, 2005 ^262^ | % | Nateglinide, 26 | Placebo, 30 | 30 (fixed) | NA | 6.5 (0.6) | 6.5 (0.6) | -0.1 | NR | NR
| | | | | | 6.3 | 6.4
| | | | | | -0.2 (0.5) | -0.1 (0.5)
Mari, 2005 ^262^ | % | Nateglinide, 25 | Placebo, 30 | 120 (fixed) | NA | 6.6 (0.7) | 6.5 (0.6) | -0.2 | NR | NR
| | | | | | 6.3 | 6.4
| | | | | | -0.3 (0.4) | -0.1 (0.5)
Saloranta, 2002 ^241^ | % | Nateglinide, 166 | Placebo, 163 | 30 (fixed) | NA | 6.55 (0.63) | 6.45 (0.6) | -0.26 | <0.001 vs. GP2
| | | | | | 6.44 | 6.61
| | | | | | -0.11* (SE 0.5) | 0.16 (SE 0.5)
Saloranta, 2002 ^241^ | % | Nateglinide, 175 | Placebo, 163 | 60 (fixed) | NA | 6.53 (0.6) | 6.45 (0.6) | -0.31 | <0.001 vs. GP2
| | | | | | 6.34 | 6.61
| | | | | | -0.19* (SE 0.4) | 0.16 (SE 0.5)
Saloranta, 2002 ^241^ | % | Nateglinide, 171 | Placebo, 163 | 120 (fixed) | NA | 6.57 (0.69) | 6.45 (0.6) | -0.39 | <0.001 vs. GP2
| | | | | | 6.29 | 6.61
| | | | | | -0.28* (SE 0.5) | 0.16 (SE 0.5)
Horton, 2000 ^96^ | % | Nateglinide, 134 | Placebo, 106 | 120 (fixed) | NA | 8.3 (1.0) | 8.3 (1.1) | -0.9 | ≤0.0001 vs. baseline and vs. GP2
| | | | | | 7.8 | 8.8
| | | | | | -0.5 (SE 0.1*) | 0.5 (SE 0.1*)
Hanefeld, 2000 ^190^ | % | Nateglinide, 57 | Placebo, 60 | 180 (fixed) | NA | 8.5 (1.1) | 8.5 (1.0) | -0.64 | <0.001 vs. GP2
| | | | | | 7.94 | 8.57
| | | | | | -0.56 | 0.07 (-0.18, 0.32^‡^)
Hanefeld, 2000 ^190^ | % | Nateglinide, 63 | Placebo, 60 | 120 (fixed) | NA | 8.3 (0.9) | 8.5 (1.0) | -0.62 | <0.001 vs. GP2
| | | | | | 7.75 | 8.57
| | | | | | -0.55 (-0.97, -0.27^‡^) | 0.07 (-0.18, 0.32^‡^)
Hanefeld, 2000 ^190^ | % | Nateglinide, 58 | Placebo, 60 | 60 (fixed) | NA | 8.3 (1.1) | 8.5 (1.0) | -0.45 | <0.05 vs. GP2
| | | | | | 7.92 | 8.57
| | | | | | -0.38 (-0.8, -0.1^‡^) | 0.07 (-0.18, 0.32^‡^)
Hanefeld, 2000 ^190^ | % | Nateglinide, 51 | Placebo, 60 | 30 (fixed) | NA | 8.4 (1.1) | 8.5 (1.0) | -0.27 | NSG vs. GP2
| | | | | | 8.2 | 8.57
| | | | | | -0.2 (-0.65, 0.1^‡^) | 0.07 (-0.18, 0.32^‡^)
Alpha-Glucosidase Inhibitor vs. Placebo
Wolever, 2000 ^98^ | % | Acarbose + diet, 28 | Placebo, 45 | 25 tid (esc) 300 tid | NA | 7.9 (SE 0.1) | 7.8 (SE 0.1) | -0.5 | <0.05 vs. GP2
| | | | | | 7.8 | 8.2
| | | | | | -0.1* (SE 0.2*) | 0.4* (SE 0.2*)
Willms, 1999 ^99^ | % | Acarbose, 31 | Placebo, 29 | 100 tid (fixed) | NA | 10.6 (1.3) | 10.6 (1.6) | -1 | <0.01 vs. GP2
| | | | | | 7.8 | 8.7
| | | | | | -2.3 (SEM 0.32) | -1.3 (SEM 0.34)
Hasche, 1999 ^138^ | % | Acarbose, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 8.6 (0.7) | 8.2 (0.7) | -0.89 | 0.02 vs. GP2
| | | | | | 6.85 (1.7) | 7.41 (1.0)
| | | | | | -1.71 (1.6) | -0.82 (1.1)
Rosenbaum, 2002 ^153^ | % total glycated Hb | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 6.4 (1.7) | 6.3 (2.1) | -0.8 | 0.03 vs. baseline | 0.15 vs. baseline
| | | | | | 5.6 (1.9) | 6.3 (2.0)
| | | | | | -0.8 | 0
Metformin + Second Generation Sulfonylurea vs. Placebo
Garber, 2002 ^79^ | % | Metformin + glyburide (Micronase), 158 | Placebo, 161 | 250 (esc) 1000 | NA | 8.25 (1.11) | 8.21 (1.0) | -1.27 | <0.001 vs. GP2
| | | | 1.25 (esc) 5 | | 6.77 | 8.00
| | | | | | -1.48 | -0.21
Garber, 2002 ^79^ | % | Metformin + glyburide (Micronase), 165 | Placebo, 161 | 500 (esc) 2000 | NA | 8.18 (1.14) | 8.21 (1.0) | -1.32 | <0.001 vs. GP2
| | | | 2.5 (esc) 10 | | 6.65 | 8.00
| | | | | | -1.53 | -0.21

Comp = comparison; BL = baseline; GP = group; mg = milligrams; esc = escalated; max = maximum; diff = difference; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; od = once daily; bid = twice daily; tid = three times daily; HbA1c = hemoglobin A1c; HbA1 = hemoglobin A1; Hb = hemoglobin; UKPDS = United Kingdom Prospective Diabetes Study; f/u = follow-up; DIACOM = effect of Dosing frequency of oral Antidiabetic agents on the COMpliance and biochemical control of type 2 diabetes; XR = extended release; GITS = gastrointestinal therapeutic system; vs = versus

* Number obtained from a figure

† Percent change from baseline

‡ 95% confidence interval

# Median

## Interquartile range

§ Data from after first cross-over

Table 6 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: two hour postprandial glucose

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
Study group | | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Other Diabetic Medications
Ramachandran, 2004 ^55^ | mg | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 286.2 (84.6) | 334.8 (75.6) | 19.8 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 178.2 (61.2) | 207 (79.2)
| | | | | | -108 | -127.8
Ramachandran, 2004 ^55^ | mg | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 286.2 (84.6) | 313.2 (75.6) | -18 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 178.2 (61.2) | 223.2 (86.4)
| | | | | | -108 | -90
Derosa, 2005 ^53^ | mg | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 192.78 (27.9) | 194.76 (25.02) | 5.94 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | 4 (fixed) | 4 (fixed) | 163.8 (25.02) | 159.84 (21.96)
| | | | | | -28.98 | -34.92
Derosa, 2005 ^72^ | mg | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Glimepiride + metformin diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 199 (21) | 194 (19) | -6 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | 1500 (fixed) | 2 (fixed) | 170 (18) | 171 (21)
| | | | | | -29 | -23
Metformin vs. Second Generation Sulfonylurea
Garber, 2002 ^79^ | mg | Metformin, 161 | Glyburide (Micronase), 161 | 500 (esc) 2000 | 2.5 (esc) 10 | NR | NR | -1.8 | NR | NR
| | | | | | NR | NR
| | | | | | -41.4 | -39.6
Garber, 2003 ^80^ | mg | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 232.2 | 251 | -7.4 | NR | NR
| | | | | | 169 | 184
| | | | | | -70 | -62.6
Blonde, 2002 ^81^ | mg | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 (esc) 2000 | 10 (fixed) | 280.8 (72) | 289.8 (72) | 5.4 | NR | NR
| | | | | | 286.2 | 289.8
| | | | | | 5.4 | 0
Noury, 1991 ^86^ | mg | Metformin, 30 | Gliclazide, 27 | 1700 (fixed) | 80 (esc) 240 | 211 (96) | 221 (91) | 3 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 174 (82) | 181 (99)
| | | | | | -37 | 40
Ramachandran, 2004 ^55^ | mg | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 313.2 (75.6) | 334.8 (75.6) | 37.8 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 223.2 (86.4) | 207 (79.2)
| | | | | | -90 | -127.8
Charpentier, 2001 ^89^ | mg | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 273.6 (100.8) | 268.2 (93.6) | 34.2 | | <0.001 vs. GP2
| | | | | | 304.2 (108) | 264.6 (106.2)
| | | | | | 30.6 | -3.6
Derosa, 2004 ^90^ | mg | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 192 (28) | 189 (33) | 1 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | 166 (28) | 162 (26)
| | | | | | -26 | -27
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2002 ^79^ | mg | Metformin, 161 | Metformin + glyburide (Micronase), 165 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | 18 | NR | NR
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | -41.4 | -59.4
Garber, 2002 ^79^ | mg | Metformin, 161 | Metformin + glyburide (Micronase), 158 | 500 (esc) 2000 | 250 (esc) 1000 | NR | NR | 19.8 | NR | NR
| | | | | 1.25 (esc) 5 | NR | NR
| | | | | | -41.4 | -61.2
Garber, 2003 ^80^ | mg | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 232.2 | 245.8 | 12.5 | | 0.016 vs. GP1
| | | | | 1.25 (esc) 5 | 169 | 161
| | | | | | -70 | -82.5
Blonde, 2002 ^81^ | mg | Metformin, 153 | Metformin + glyburide (no trade drug specified), 162 | 500 (esc) 2000 | 500 (esc) 2000 | 280.8 (72) | 279 (63) | 68.4 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 286.2 | 216
| | | | | | 5.4 | -63
Blonde, 2002 ^81^ | mg | Metformin, 153 | Metformin + glyburide (no trade drug specified), 160 | 500 (esc) 2000 | 500 (esc) 2000 | 280.8 (72) | 280.8 (64.8) | 63 | | <0.001 vs. GP1
| | | | | 2.5 (esc) 10 | 286.2 | 223.2
| | | | | | 5.4 | -57.6
Charpentier, 2001 ^89^ | mg | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 273.6 (100.8) | 266.4 (91.8) | 75.6 | NR | <0.001 vs. baseline
| | | | | 1 (esc) 6 | 304.2 (108) | 221.4 (66.6)
| | | | | | 30.6 | -45
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2002 ^79^ | mg | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 158 | 2.5 (esc) 10 | 250 (esc) 1000 | NR | NR | 21.6 | NR | NR
| | | | | 1.25 (esc) 5 | NR | NR
| | | | | | -39.6 | -61.2
Garber, 2002 ^79^ | mg | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 165 | 2.5 (esc) 10 | 500 (esc) 2000 | NR | NR | 19.8 | NR | NR
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | -39.6 | -59.4
Garber, 2003 ^80^ | mg | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 251 | 245.8 | 20 | | <0.001 vs. GP1
| | | | | 1.25 (esc) 5 | 184 | 161
| | | | | | -62.6 | -82.5
Erle, 1999 ^127^ | mg | Glyburide (no trade drug specified), 18 | Metformin + glyburide (no trade drug specified), 15 | 5 (esc) 15 | 800 (esc) 1600 | 285 (103) | 272 (85) | 15 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 5 (esc) 10 | 258 (63) | 230 (77) | | | <0.01 vs. GP1
| | | | | | -27 | -42
Blonde, 2002 ^81^ | mg | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 162 | 10 bid (fixed) | 500 (esc) 2000 | 289.8 (72) | 279 (63) | 63 | | <0.001 vs. GP1
| | | | | 5 (esc) 20 | 289.8 | 216
| | | | | | 0 | -63
Blonde, 2002 ^81^ | mg | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 160 | 10 bid (fixed) | 500 (esc) 2000 | 289.8 (72) | 280.8 (64.8) | 57.6 | | <0.001 vs. GP1
| | | | | 2.5 (esc) 10 | 289.8 | 223.2
| | | | | | 0 | -57.6
Charpentier, 2001 ^89^ | mg | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 268.2 (93.6) | 266.4 (91.8) | 41.4 | | <0.001 vs. GP1
| | | | | 1 (esc) 6 | 264.6 (106.2) | 221.4 (66.6)
| | | | | | -3.6 | -45
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Carlson, 1993 ^108^ | mg | Glyburide (Micronase), 102 | Glyburide (Glynase Prestab), 100 | 3 (fixed) | 5 (fixed) | 213.7 | 224.7 | 11.4 | <0.01 vs. baseline | NR
| | | | | | 226.5 (SE 8.2) | 226.1 (SE 6.6)
| | | | | | 12.8 | 1.4
Dills, 1996 ^107^ | mg | Glyburide (Micronase), 288 | Glimepiride, 289 | 1.25 (esc) 20 | 1 (esc) 16 | NR | NR | -2 | =0.001 vs. baseline | =0.001 vs. baseline
| | | | | | NR | NR
| | | | | | 51 | 53
Baba, 1983 ^133^ | mg | Glibenclamide, 131 | Gliclazide, 146 | 2.5 (esc) 10 | 40 (esc) 160 | 275 | 295 | 12.5 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 200 | 207.5 | | NSG vs. GP2
| | | | | | -75 | -87.5
Repaglinide vs. Other Diabetes Medications
Derosa, 2003 ^118^ | mg | Repaglinide + diet + exercise, 56 | Metformin + diet + exercise, 56 | 0.5 bid (esc) 4 | 500 bid (esc) 2500 | 183.6 (34.92) | 194.4 (30.06) | -7 | <0.05 vs. baseline and vs. GP2 | <0.05 vs. baseline
| | | | | | 154.8 (30.06) | 172.8 (27.9)
| | | | | | -28.8 | -21.6
Derosa, 2003 ^118^ | mg | Repaglinide + placebo | Glimepiride + placebo | 1 (esc) 2.5 mean final dose | 1 (esc) 3 mean final dose | 194 (30) | 188 (32) | -25 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | | | 148 (27) | 167 (28)
| | | | | | -46 | -21
Wolffenbuttel, 1993 ^120^ | mg | Repaglinide, 27 | Glibenclamide, 15 | 0.5 (esc) 4 | 5 (esc) 15 | 248.4 (70.2) | 212.4 (57.6) | -27 | <0.05 vs. baseline | NR
| | | | | | 219.6 (75.6) | 210.6 (39.6)
| | | | | | -28.8 | -1.8
Landgraf, 1999 ^121^ | mg | Repaglinide, 94 | Glibenclamide + placebo, 98 | 0.5 (esc) 4 | 1.75 (esc) 10.5 | 273.6 (61.2) | 280.8 (64.8) | -18 | 0.07 vs. GP2
| | | | | | 145.8 (SE 10.8) | 163.8 (SE 10.8)
| | | | | | -127.8 | -117
Metformin vs. Placebo
Garber, 2002 ^79^ | mg | Metformin, 161 | Placebo, 161 | 500 (esc) 2000 | NA | NR | NR | -46.8 | NR | NR
| | | | | | NR | NR
| | | | | | -41.4 | 5.4
Second Generation Sulfonylurea vs. Placebo
Garber, 2002 ^79^ | mg | Glyburide (Micronase), 161 | Placebo, 161 | 2.5 (esc) 10 | NA | NR | NR | -45 | NR | NR
| | | | | | NR | NR
| | | | | | -39.6 | 5.4
Goldberg, 1996 ^134^ | mg | Glimepiride, 69 | Placebo, 55 | 4 (fixed) | NA | 284.4 | 286.2 | -108 | <0.001 vs. GP2
| | | | | | 203.4 | 313.2
| | | | | | -81 | 27
Goldberg, 1996 ^134^ | mg | Glimepiride, 65 | Placebo, 55 | 1 (fixed) | NA | 280.8 | 286.2 | -91.8 | <0.001 vs. GP2
| | | | | | 216 | 313.2
| | | | | | -64.8 | 27
Goldberg, 1996 ^134^ | mg | Glimepiride, 64 | Placebo, 55 | 8 (fixed) | NA | 295.2 | 286.2 | -109.8 | <0.001 vs. GP2
| | | | | | 212.4 | 313.2
| | | | | | -82.8 | 27
Schade, 1998 ^135^ | mg | Glimepiride, 108 | Placebo, 101 | 1 (esc) 8 | NA | 291^#^ | 268^#^ | -86 | <0.001 vs. GP2
| | | | | | 174^#^ | 237^#^
| | | | | | -117 | -31
Simonson, 1997 ^136^ | mg | Glipizide GITS, 68 | Placebo, 69 | 5 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -60 (10)* | NR
| | | | | | -52 (10)^†^
Simonson, 1997 ^136^ | mg | Glipizide GITS, 42 | Placebo, 69 | 10 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -57 (10) | NR
Simonson, 1997 ^136^ | mg | Glipizide GITS, 42 | Placebo, 69 | 15 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -38 (10) | NR
Simonson, 1997 ^136^ | mg | Glipizide GITS, 69 | Placebo, 69 | 20 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -58 (10)* | NR
| | | | | | -57 (10)^†^
Simonson, 1997 ^136^ | mg | Glipizide GITS, 28 | Placebo, 69 | 40 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -83 (11) | NR
Simonson, 1997 ^136^ | mg | Glipizide GITS, 29 | Placebo, 69 | 60 (fixed) | NA | NR | NR | NR | <0.01 vs. GP2 | | NSG all glipizide doses
| | | | | | NR | NR
| | | | | | -49 (10) | NR
Vray, 1995 ^137^ | mg | Glibenclamide, 46 | Placebo, 51 | 2.5 tid (fixed) | NA | NR | NR | -29.2 | <0.001 vs. GP2
| | | | | | NR | NR
| | | | | | -35.1 | -5.94
Metformin + Second Generation Sulfonylurea vs. Placebo
Garber, 2002 ^79^ | mg | Metformin + glyburide (Micronase), 165 | Placebo, 161 | 500 (esc) 2000 | NA | NR | NR | -64.8 | NR | NR
| | | | 2.5 (esc) 10 | | NR | NR
| | | | | | -59.4 | 5.4
Garber, 2002 ^79^ | mg | Metformin + glyburide (Micronase), 158 | Placebo, 161 | 250 (esc) 1000 | NA | NR | NR | -66.6 | NR | NR
| | | | 1.25 (esc) 5 | | NR | NR
| | | | | | -61.2 | 5.4
Acarbose vs. Placebo
Hasche, 1999 ^138^ | mg | Acarbose + diet, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 219.4 (40.7) | 228.9 (36) | -15 | 0.11 vs. GP2
| | | | | | 139.4 | 164
| | | | | | -80 | -64.9
Repaglinide vs. Placebo
Goldberg, 1998 ^139^ | mg | Repaglinide, 59 | Placebo, 27 | 0.25 (esc) 8 | NA | NR | NR | -104 | 0.000 vs. GP2
| | | | | | 214.2 | 300.6
| | | | | | -46.8 | 55.8
Pioglitazone vs. Placebo
Tseng, 2005 ^140^ | % | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | NR | NR | -12.8^‡^ | <0.05 vs. baseline | NSG vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | -12.5^‡^ | 0.3^‡^
Scherbaum, 2002 ^141^ | mg | Pioglitazone + diet, 83 | Placebo + diet, 76 | 15 (fixed) | NA | NR | NR | NR | 0.014 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Scherbaum, 2002 ^141^ | mg | Pioglitazone + diet, 76 | Placebo + diet, 76 | 30 (fixed) | NA | NR | NR | NR | 0.014 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR

Comp = comparison; BL = baseline; GP = group; mg = milligrams; max = maximum; esc = escalated; diff = difference; SD = standard deviation; SE = standard error; NR = not reported; NSG = not significant; NA = not applicable; bid = twice daily; tid = three times daily; GITS = gastrointestinal therapeutic system; vs = versus

* Data from Trial 1

† Data from Trial 2

‡ Percent change from baseline

# Median

Table 7 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: weight

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg | Group 2, initial dose in mg | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
Study group | | | | (fixed or esc) max dose | (fixed or esc) max dose | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Khan, 2002 ^51^ | kg | Rosiglitazone, 60 | Pioglitazone, 67 | 2–8 (fixed) | 15–45 (fixed) | 103.2 (24.8) | 101.4 (24.2) | 0 | <0.01 vs. baseline | <0.01 vs. baseline
| | | | | | NR | NR
| | | | | | 2* | 2*
Goldberg, 2005 ^52^ | kg | Rosiglitazone + diet, 356 | Pioglitazone + diet, 363 | 4 (esc) 8 | 30 (esc) 45 | 92.5 (21) | 93.7 (20.6) | -0.4 | 0.164 vs. GP2
| | | | | | 94.1 | 95.7
| | | | | | 1.6 (SE 0.2) | 2.0 (SE 0.2)
Thiazolidinedione vs. Metformin
Hallsten, 2002 ^58^ | kg | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 83.7 (7.9) | 88.8 (10.8) | 2.6 | NSG vs. baseline | <0.05 vs. baseline
Virtanen, 2003 ^143^ | | | | | | 84.3 (3.5) | 86.8
| | | | | | 0.6 | -2
Pavo, 2003 ^59^ | kg | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | 86.1 (15.6) | 88.9 (15.9) | 3.1 | <0.0001 vs. GP2
| | | | | | 86.8 | 90.2
| | | | | | 0.7 (0.4) | -2.4
Ramachandran, 2004 ^55^ | kg | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 68.9 (9.1) | 67.7 (11.5) | -0.4 | NR | NR
| | | | | | 67.8 (7.9) | 67 (11.4)
| | | | | | -1.1 | -0.7
Natali, 2004 ^144^ | kg | Rosiglitazone, 44 | Metformin, 22 | 4 bid (fixed) | 500 tid (fixed) | 80.4 (SEM 10.1) | 77.3 (SEM 12.5) | 1.2 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 80.9 | 76.7
| | | | | | 0.5 (0.5) | -0.6 (0.4)
Schernthaner, 2004 ^56^ | kg | Pioglitazone + placebo + diet, 597 | Metformin + placebo + diet, 597 | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | NR | NR | 4.4 | NR | NR
| | | | | | NR | NR
| | | | | | 1.9 | -2.5
Hanefeld, 2004 ^60^ | kg | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 85.3 (15.1) | 84.9 (14.5) | 3.8 | NR | NR
QUARTET study group | | | | NR | NR | 88.1 | 83.9
| | | | | | 2.8 | -1
Thiazolidinedione vs. Second Generation Sulfonylurea
St John Sutto, 2002 ^67^ | kg | Rosiglitazone, 104 | Glyburide (no trade drug specified), 99 | 4 bid (fixed) | NR (esc) 20 | 86.2 (15.6) | 85.1 (13.6) | 1.6 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 91.2 | 88.5
| | | | | | 5 (3.7–6.2^‡^) | 3.4 (2.7–4.1^‡^)
Tan, 2004 ^65^ | kg | Pioglitazone, 90 | Glibenclamide, 108 | 30 (esc) 45 | 1.75 (esc) 10.5 | 88.7 (17.4) | 89.1 (16) | 1.9 | <0.001 vs. baseline | 0.008 vs. baseline
| | | | | | 91.7 | 90.2 | | 0.002 vs. GP2
| | | | | | 3 | 1.1
Tan, 2005 ^61^ | kg | Pioglitazone, 146 | Gliclazide, 127 | 15 (esc) 45 | 80 (esc) 320 | 91.7 | 89.2 | -0.3 | <0.001 vs. GP2
One year extension study for Quartet study group | | | | | | 95.6 | 93.4
| | | | | | 3.9 | 4.2
Ramachandran, 2004 ^55^ | kg | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 68.9 (9.1) | 65.7 (9.1) | -2.9 | NR | <0.05 vs. baseline
| | | | | | 67.8 (7.9) | 67.5 (9.2)
| | | | | | -1.1 | 1.8
Charbonnel, 2005 ^63^ | kg | Pioglitazone | Gliclazide | NR (esc) 45 | NR (esc) 320 | NR | NR | 0.9 | NR | NR
| | | | | | NR | NR
| | | | | | 2.8 | 1.9
Thiazolidinedione + Metformin vs. Second Generation Sulfonylurea + Metformin
Derosa, 2005 ^72^ | kg | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 74.2 (3.6) | 75.6 (4.2) | -1.4 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | 1500 (fixed) | 2 (fixed) | 68.3 (3) | 71.1 (3.2)
| | | | | | -5.9 | -4.5
Garber, 2006 ^71^ | kg | Rosiglitazone + metformin + diet, 155 | Metformin + glibenclamide + diet, 159 | 4 (esc) 8 | 1000 (esc) 2000 | 94 | 92 | -1.5 | | <0.001 vs. GP1
| | | | 1500–2000 (esc) 2000 | 5 (esc) 10 | 95.4 | 95
| | | | | | 1.4 | 3
Thiazolidinedione vs. Meglitinide
Raskin, 2004 ^74^ | kg | Rosiglitazone, 37 | Repaglinide, 38 | 2 bid (esc) 4 bid | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | NR | NR | 0.7 | NR | NR
| | | | | | NR | NR
| | | | | | 2.3 | 1.6
Jovanovic, 2004 ^73^ | kg | Pioglitazone | Repaglinide | 30 (fixed) | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | NR | NR | 1.7 | <0.05 vs. baseline | NR
| | | | | | NR | NR
| | | | | | 2 | 0.3
Other Thiazolidinedione Comparisons
Goke, 2002 ^75^ | kg | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 100 tid | NR | NR | 3.3 | | <0.001 vs. GP1
German Pioglitazone Study Group | | | | | | NR | NR
| | | | | | 1.23 (5.42) | -2.09 (3.58)
McCluskey, 2004 ^76^ | kg | Rosiglitazone + placebo, 15 | Rosiglitazone + glimepiride, 24 | 4 or 8 (fixed) | 4 or 8 fixed; | 99.4 (SE 5.1) | 100.5 (SE 4) | -2.7 | NSG vs. GP2
| | | | | 2 (esc) 8 | 101.8 | 105.6
| | | | | | 2.4 | 5.1
Metformin vs. Second Generation Sulfonylurea
Garber, 2002 ^79^ | kg | Metformin, 161 | Glyburide (Micronase), 161 | 500 (esc) 2000 | 2.5 (esc) 10 | NR | NR | -2.3 | <0.05 vs. baseline
| | | | | | NR | NR
| | | | | | -0.6 | 1.7
Garber, 2003 ^80^ | kg | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 92.8 (15.6) | 91 (16.0) | -3.1 | <0.001 vs. baseline | NSG vs. baseline
| | | | | | 91.7 | 93
| | | | | | -1.1 | 2
Blonde, 2002 ^81^ | kg | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 (esc) 2000 | 10 bid (fixed) | 89.5 (16.9) | 88 (15.9) | -2.5 | NR | NR
| | | | | | 87.5 | 88.5
| | | | | | -2 | 0.5
Campbell, 1994 ^83^ | kg | Metformin, 24 | Glipizide, 24 | 500 bid (esc) 3000 | 5 (esc) 30 | 78.2 (15.7) | 82.2 (16.8) | -4.57 | <0.001 vs. GP2
| | | | | | 76.23 | 84.8
| | | | | | -1.97 | 2.67
Goldstein, 2003 ^82^ | kg | Metformin, 75 | Glipizide, 83 | 500 (esc) 2000 | 15 bid (fixed) | 94.2 (16.7) | 90 (17.4) | -2.3 | NR | NR
| | | | | | 91.5 | 89.6
| | | | | | -2.7 (SE 0.3) | -0.4 (SE 0.3)
Marre, 2002 ^84^ | kg | Metformin, 104 | Glibenclamide, 103 | 500 (esc) 2000 | 5 (esc) 20 | 84.9 (17.6) | 82.5 (15.4) | -1.7 | NR | NR
| | | | | | 84.1 | 83.4
| | | | | | -0.8 | 0.9
Amador-Licona, 2000 ^85^ | kg | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 70.7 (14.8) | 73.2 (11.8) | -1.7 | 0.07 vs. baseline | 0.1 vs. baseline
| | | | | | 69.6 (14.3) | 74.1 (12.6)
| | | | | | -0.9 | 0.9
Noury, 1991 ^86^ | kg | Metformin, 30 | Gliclazide, 27 | 1700 (fixed) | 80 (esc) 240 | 80.4 (14.4) | 79 (16.2) | -0.9 | <0.03 vs. baseline | NSG vs. baseline
| | | | | | 79.5 (14.5) | 79 (15.4) | | NSG vs. GP2
| | | | | | -0.9 | 0
Ramachandran, 2004 ^55^ | kg | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 67.7 (11.5) | 65.7 (9.1) | -2.5 | NR | <0.05 vs. baseline
| | | | | | 67 (11.4) | 67.5 (9.2)
| | | | | | -0.7 | 1.8
Hermann, 1994 ^87^ | kg | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 78.6 (SE 2.9) | 82.6 (SE 2.7) | -3.6 | >0.1vs. baseline | 0.001 vs. baseline
| | | | | | 78.8 (SE 2.9) | 86.2 (SE 3.3)
| | | | | | -0.8 (SE 0.5) | 2.8 (SE 0.7)
Hermann, 1991 ^94^ | kg | Metformin + diet, 16 | Glibenclamide + diet, 17 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 76.5 (11.5) | 84.1 (13.2) | 3.7 | NSG vs. baseline | <0.01 vs. baseline
| | | | | | 76.1 (11.1) | 87.4 (14.8)
| | | | | | -0.4 | 3.3
1995 ^92^ | kg | Metformin + diet, 262 | Glibenclamide + diet, 472 | NR (esc) 850 tid | NR (esc) 500 of chlorpropamide or 10 bid of glibenclamide | 88 (14.7) | 86 (14.7) | -2 | NR | NR
UKPDS, 3 year f/u of obese patients | | | | | | 87 | 87
| | | | | | -1 | 1
Turner, 1998 ^93^ | kg | Metformin + diet, 49 | Glyburide (Diabeta) or chlorpropamide + diet, 231 | NR (esc) 2550 | NR (esc) 500 of chlorpropamide or 20 of glyburide | NR | NR | -5 | NSG vs. baseline | NSG vs. baseline
UKPDS, 6 year f/u of primary diet failure group | | | | | | NR | NR
| | | | | | -1.3 (SE 0.2) | 3.7 (-0.5)
1998 ^15^ | kg | Metformin, 181 | Glibenclamide, 148 | 850 (esc) 2550 | NR | 87 (SE 17) | NR | -2 | NR | NR
UKPDS, 10 year f/u of obese patients for metformin and obese and non-obese patients for glibenclamide | | | | | | 88.25 | NR
| | | | | | 1.25* | 3.4*
DeFronzo, 1995 ^88^ | kg | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) 2500 | 5 bid (esc) 10 bid | 92.6 (14.5) | NR | -3.5 | <0.001 vs. baseline | NSG vs. baseline
| | | | | | 87.8 | NR
| | | | | | -3.8 (SE 0.2) | -0.3 (SE 0.2)
Charpentier, 2001 ^89^ | kg | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 82.2 (range 53–115) | 81 (range 48–135) | -1.52 | NR | NR
| | | | | | 81.46 | 81.78
| | | | | | -0.74 (2.58) | 0.78 (2.98)
Metformin vs. Meglitinide
Derosa, 2003 ^97^ | kg | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 72.3 (7.1) | 70.0 (6.5) | -1.6 | 0.14 vs. baseline | >0.2 vs. baseline
| | | | | | 70.3 | 69.6 | | NSG vs. GP2
| | | | | | -2 (-6, 4^‡^) | -0.4 (-0.8, 0.28^‡^)
Metformin vs. Alpha-Glucosidase Inhibitor
Willms, 1999 ^99^ | kg | Metformin, 27 | Acarbose, 31 | 850 bid (fixed) | 100 tid (fixed) | 88.6 (17.7) | 86.1 (15.4) | 1.3 | NSG vs. GP2
| | | | | | 87.0 | 83.2
| | | | | | -1.6 (SE 0.89) | -2.9 (SE 0.72)
Metformin vs. Metformin + Thiazolidinedione
Bailey, 2005 ^101^ | kg | Metformin, 272 | Rosiglitazone + metformin, 279 | 2500 (esc) 3000 | 4 (esc) 8 | 89.5 (14.4) | 90.9 (15.6) | -2.2 | NR | NR
| | | | | 2000 (fixed) | 88.6 | 92.2
| | | | | | -0.9 (SE 0.26) | 1.3 (SE 0.22)
Fonseca, 2000 ^103^ | kg | Metformin + placebo, 113 | Rosiglitazone + metformin, 116 | 2500 (fixed) | 4 (fixed) | NR | NR | -1.9 | | 0.0001 vs. GP1
| | | | | 2500 (fixed) | NR | NR
| | | | | | -1.2 | 0.7
Fonseca, 2000 ^103^ | kg | Metformin + placebo, 113 | Rosiglitazone + metformin, 110 | 2500 (fixed) | 8 (fixed) | NR | NR | -3.1 | | 0.0001 vs. GP1
| | | | | 2500 (fixed) | NR | NR
| | | | | | -1.2 | 1.9
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2002 ^79^ | kg | Metformin, 161 | Metformin + glyburide (Micronase), 165 | 500 (esc) 2000 | 500 (esc) 2000 | 88.6 (14.9) | NR | 2.5 | | <0.05 vs. baseline
| | | | | 2.5 (esc) 10 | 88 | NR
| | | | | | -0.6 | 1.9
Garber, 2002 ^79^ | kg | Metformin, 161 | Metformin + glyburide (Micronase), 158 | 500 (esc) 2000 | 250 (esc) 1000 | NR | NR | -2 | | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | NR | NR
| | | | | | -0.6 | 1.4
Garber, 2003 ^80^ | kg | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 92.8 (15.6) | 91.9 (17.4) | -2.7 | <0.001 vs. baseline | NSG vs. baseline
| | | | | 1.25 (esc) 5 | 91.7 | 93.5
| | | | | | -1.1 | 1.6
Goldstein, 2003 ^82^ | kg | Metformin, 75 | Metformin + glipizide, 81 | 500 (esc) 2000 | 500 (esc) 2000 | 94.2 (16.7) | 95.1 (17.8) | -2.4 | <0.001 vs. GP2
| | | | | 5 (esc) 20 | 91.5 | 94.8
| | | | | | -2.7 (SE 0.3) | -0.3 (SE 0.3)
Marre, 2002 ^84^ | kg | Metformin, 104 | Metformin + glibenclamide, 101 | 500 (esc) 2000 | 500 (esc) 2000 | 84.9 (17.6) | 84.7 (15.1) | -1.4 | NR | NR
| | | | | 2.5 (esc) 10 | 84.1 | 85.3
| | | | | | -0.8 | 0.6
Marre, 2002 ^84^ | kg | Metformin, 104 | Metformin + glibenclamide, 103 | 500 (esc) 2000 | 500 (esc) 2000 | 84.9 (17.6) | 83.1 (13.3) | -1.8 | NR | NR
| | | | | 5 (esc) 20 | 84.1 | 84.1
| | | | | | -0.8 | 1
Hermann, 1994 ^87^ | kg | Metformin + diet, 19 | Metformin + glyburide + diet, 46 | 1000 (esc) 3000 | 2000 (esc) 3000 | 78.6 (SE 2.9) | 80.2 (SE 2.4) | -0.9 | >0.1vs. baseline | >0.1 vs. baseline
| | | | | 7 (esc) 14.0 | 78.8 (SE 2.9) | 81 (SE 2.5)
| | | | | | -0.2 (SE 0.5) | 0.7 (SE 0.4)
DeFronzo, 1995 ^88^ | kg | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | NR | NR | -4.2 | <0.001 vs. baseline | NSG vs. baseline
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -3.8 (SE 0.2) | 0.4 (SE 0.2)
Charpentier, 2001 ^89^ | kg | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 82.2 (range 53–115) | 81.2 (range 52.6–116) | -1.34 | NR | NR
| | | | | 1 (esc) 6 | 81.46 | 81.8
| | | | | | -0.74 (2.58) | 0.6 (2.86)
Feinglos, 2005 ^104^ | kg | Metformin + placebo, 56 | Metformin + glipizide, 56 | at least 1000 (fixed) | at least 1000 (fixed) | 90.8 (18.4) | 90 (18.7) | -2.1 | < 0.0001 vs. GP2
| | | | | 2.5 (fixed) | 89.1 | 90.4
| | | | | | -1.7 | 0.4
Hermann, 1991 ^94^ | kg | Metformin + diet, 16 | Metformin + glibenclamide + diet, 12 | 1000 (esc) 3000 | 3000 (fixed) | 76.5 (11.5) | 87.3 (15.6) | -0.4 | NSG vs. baseline | NSG vs. baseline
| | | | | 3.5 (esc) 14 | 76.1 (11.1) | 87.3 (15.9)
| | | | | | -0.4 | 0
Hermann, 1991 ^94^ | kg | Metformin + diet, 16 | Metformin + glibenclamide + diet, 11 | 1000 (esc) 3000 | 1000 (esc) 3000 | 76.5 (11.5) | 74.4 (11.4) | -2 | NSG vs. baseline | <0.001 vs. baseline
| | | | | 10.5 (esc) 14 | 76.1 (11.1) | 76 (11.8)
| | | | | | -0.4 | +1.6
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Kilo, 1988 ^147^ | kg | Glyburide (no trade drug specified), 47 | Glipizide, 52 | 1.25, 2.5, or 5 (esc) 20 | 5 or 10 (esc) 40 | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Inukai, 2005 ^111^ | kg | Glimepiride, 120 | Glibenclamide + gliclazide, 52 | 1 or 2 (esc) 6 | 2.5 (fixed) | 62.2 (12.6) | 62.9 (13.4) | -1.17 | NR | NR
| | | | | 40 (fixed) | 62.2 (12.3) | 63.4 (13.1)
| | | | | | 0 | 0.5
Harrower, 1985 ^113^ | kg | Glipizide, 20 | Glibenclamide, 19 | 2.5 (esc) 20 | 2.5 (esc) 30 | 64 (15) | 57 (26) | -1.17 | NSG vs. baseline | <0.05 vs. baseline
| | | | | | 64 (15) | 59 (26)
| | | | | | 0.86 (0.91) | 2.03 (0.85)
Harrower, 1985 ^113^ | kg | Glipizide, 2 | Gliclazide, 20 | 2.5 (esc) 20 | 20 (esc) 320 | 64 (15) | 65 (13) | 0.68 | NSG vs. baseline | NSG vs. baseline
| | | | | | 64 (15) | 65 (13)
| | | | | | 0.86 (0.91) | 0.18 (1.04)
Harrower, 1985 ^113^ | kg | Glibenclamide, 19 | Gliclazide, 20 | 2.5 (esc) 30 | 20 (esc) 320 | 57 (26) | 65 (13) | 1.85 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 59 (26) | 65 (13)
| | | | | | 2.03 (0.85) | 0.18 (1.04)
Schernthaner, 2004 ^106^ | kg | Glimepiride + existing medications + diet, 440 | Gliclazide + existing medications + diet, 405 | 1 (esc) 6 | 30 (esc) 120 | 83.7 | 83.1 | 0.1 | NSG vs. baseline | NSG vs. baseline
| | | | | | 84.3 | 83.6
| | | | | | 0.6 | 0.5
Second Generation Sulfonylurea vs. Meglitinide
Wolffenbuttel, 1999 ^117^ | kg | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 81.3 (12.2) | 81.5 (13.4) | 0.7 | NSG vs. baseline | NSG vs. baseline
| | | | | | 82 (11.9) | 81.5 (13.5)
| | | | | | 0.7 | 0
Marbury, 1999 ^116^ | kg | Glyburide (no trade drug specified) + placebo, 216 | Repaglinide, 115 | 2.5 (esc) 15 | 0.5 (esc) 12 | NR | NR | 0.27 | NSG vs. GP2
| | | | | | NR | NR
| | | | | | 0.05 (SE 0.5) | -0.22 (SE 0.5)
Derosa, 2003 ^118^ | kg | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 77.1 (5.9) | 76.4 (5.2) | -0.6 | NSG vs. GP2
| | | | | | 76.6 (5.3) | 76.5 (5.3)
| | | | | | -0.5 | 0.1
Wolffenbuttel, 1993 ^120^ | kg | Glibenclamide, 15 | Repaglinide, 27 | 5 (esc) 15 | 0.5 (esc) 4 | 70.9 (10.8) | 74 (9.6) | 1.3 | NSG vs. baseline | <0.05 vs. baseline
| | | | | | 70.5 (10.2) | 72.3 (9.4)
| | | | | | -0.4 | -1.7
Landgraf, 1999 ^121^ | kg | Glibenclamide + placebo, 100 | Repaglinide, 94 | 1.75, 3.5, 7.0, or 10.5 (esc) 10.5 | 0.5, 1.0, 2.0, or 4.0 tid (esc) 4 tid | 78.9 (12.8) | 79.6 (10.3) | -0.7 | NSG vs. baseline and GP2 | NSG vs. baseline
| | | | | | 77.5 | 78.9
| | | | | | -1.4 | -0.7
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea + Thiazolidinedione
Rosenstock, 2006 ^124^ | kg | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | -5.5 | NR | NR
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -1.2 | 4.3
Baksi, 2004 ^126^ | kg | Gliclazide | Rosiglitazone + gliclazide | 160 (esc) 320 | 160 (fixed) | NR | NR | -3.4 | | 0.0001 vs. GP1
| | | | | 4 bid (fixed) | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | kg | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 91 (16) | 91.1 (17.4) | 0.4 | NSG vs. baseline | NSG vs. baseline
| | | | | 1.25 (esc) 5 | 93 | 92.7
| | | | | | 2 | 1.6
Erle, 1999 ^127^ | kg | Glyburide (no trade drug specified), 18 | Metformin + glyburide (no trade drug specified), 15 | 5 (esc) 15 | 800 (esc) 1600 | 85.2 (12.5) | 85.5 (13.2) | 0.2 | NSG vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 10 | 85.2 (13.3) | 85.3 (13.3)
| | | | | | 0 | -0.2
Blonde, 2002 ^81^ | kg | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 160 | 10 bid (fixed) | 500 (esc) 2000 | 88 (15.9) | 89.4 (17.5) | NR | NR | NR
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | <1 | <1
Blonde, 2002 ^81^ | kg | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 162 | 10 bid (fixed) | 500 (esc) 2000 | 88 (15.9) | 89.6 (16.8) | NR | NR | NR
| | | | | 5 (esc) 20 | NR | NR
| | | | | | <1 | <1
Garber, 2002 ^79^ | kg | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 158 | 2.5 (esc) 10 | 250 (esc) 1000 | NR | NR | 0.3 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | NR | NR
| | | | | | 1.7 | 1.4
Garber, 2002 ^79^ | kg | Glyburide (Micronase), 161 | Metformin + glyburide (Micronase), 165 | 2.5 (esc) 10 | 500 (esc) 2000 | NR | NR | -0.2 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | 1.7 | 1.9
DeFronzo, 1995 ^88^ | kg | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 92.6 | 92.1 | -0.7 | NSG vs. baseline | <0.001 vs. baseline
| | | | | 10 (esc) 20 | 92.3 | 91.7
| | | | | | -0.3 (SE 0.2) | -0.4 (SE 0.2)
Charpentier, 2001 ^89^ | kg | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 81 (range 48–135) | 81.2 (range 52.6–116) | 0.18 | NR | NR
| | | | | 1 (esc) 6 | 81.78 | 81.8
| | | | | | 0.78 (2.98) | 0.6 (2.86)
Goldstein, 2003 ^82^ | kg | Glipizide, 83 | Metformin + glipizide, 81 | 30 (fixed) | 500 (esc) 2000 | 90 (17.8) | 95.1 (17.8) | -0.1 | NR | NR
| | | | | 5 (esc) 20 | 89.6 | 94.8
| | | | | | -0.4 (SE 0.3) | -0.3 (SE 0.3)
Marre, 2002 ^84^ | kg | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 (esc) 20 | 500 (esc) 2000 | 82.5 (15.4) | 83.1 (13.3) | -0.1 | NR | NR
| | | | | 5 (esc) 20 | 83.4 | 84.1
| | | | | | 0.9 | 1
Marre, 2002 ^84^ | kg | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 (esc) 20 | 500 (esc) 2000 | 82.5 (15.4) | 84.7 (15.1) | 0.3 | NR | NR
| | | | | 2.5 (esc) 10 | 83.4 | 85.3
| | | | | | 0.9 | 0.6
Hermann, 1994 ^87^ | kg | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 82.6 (SE 2.7) | 80.2 (SE 2.4) | 2.1 | 0.001 vs. baseline | NSG vs. baseline
| | | | | 1.75 (esc) 5.25 | 86.2 (SE 3.3) | 81 (SE 2.5) | | 0.008 vs. GP2
| | | | | | 2.8 (SE 0.7) | 0.7 (SE 0.4)
Hermann, 1991 ^94^ | kg | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 12 | 3.5 (esc) 10.5 | 3000 (fixed) | 84.1 (13.2) | 87.3 (15.6) | 3.3 | <0.01 vs. baseline
| | | | | 3.5 (esc) 14.0 | 87.4 (14.8) | 87.3 (15.9)
| | | | | | 3.3 | 0
Hermann, 1991 ^94^ | kg | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 11 | 3.5 (esc) 10.5 | 1000 (esc) 3000 | 84.1 (13.2) | 74.4 (11.4) | 1.9 | <0.01 vs. baseline | <0.001 vs. baseline
| | | | | 10.5 (esc) 14.0 | 87.4 (14.8) | 76 (11.8)
| | | | | | 3.3 | 1.6
1998 ^128^ | kg | Glibenclamide + diet, 300 | Metformin + glibenclamide + diet, 291 | 10 (fixed) | 500 (esc) 2500 | NR | NR | 0.3 | 0.0015 vs. baseline | <0.00001 vs. baseline
UKPDS, 3 year f/u | | | | | 10 (fixed) | NR | NR | | NSG vs. GP2
| | | | | | -0.78 (-1.26) | -1.08 (-1.55)
Gregorio, 1999 ^129^ | kg | Metformin + glibenclamide + gliclazide, 89 | Glibenclamide + gliclazide, 85 | 10 (esc) 15 | 850 (esc) 1700 | 76.4 (SE 1.41) | 76.6 (SE 1.73) | -0.5 | NR | NR
| | | | 120 (esc) 240 | NR (fixed) | 76 (SE 1.51) | 76.7 (SE 1.69)
| | | | | NR (fixed) | -0.4 | 0.1
Second Generation Sulfonylurea vs. Alpha-Glucosidase Inhibitor
Feinbock, 2003 ^130^ | kg | Glimepiride, 108 | Acarbose, 103 | 1 (esc) 6 | 50 tid (esc) 200 tid | 85 (12.8) | 83 (12.5) | 1.5 | NSG vs. baseline | 0.001 vs. baseline
| | | | | | 84.6 | 81.1
| | | | | | -0.4 (5.2) | -1.9 (3.9)
Repaglinide vs. Nateglinide
Rosenstock, 2004 ^131^ | kg | Repaglinide | Nateglinide | 5 (esc) 16 | 60 (esc) 360 | NR | NR | 1.1 | 0.04 vs. GP2
| | | | | | NR | NR
| | | | | | 1.8 | 0.7
Pioglitazone vs. Placebo
Rosenblatt, 2001 ^162^ | kg | Pioglitazone, 101 | Placebo, 96 | 30 (NR) | NA | 89.8 (18) | 87.2 (18.4) | 3.22 | <0.0001 vs. baseline and vs. placebo | <0.0001 vs. baseline
| | | | | | 91.15 | 86.33
| | | | | | 1.35 | -1.87
Herz, 2003 ^163^ | kg | Pioglitazone, 95 | Placebo, 97 | 30 (fixed) | NA | 86.6 (15.9) | 86.3 (17.4) | 1.93 | <0.001 vs. GP2
| | | | | | 86.95 | 84.72
| | | | | | 0.35 | -1.58
Herz, 2003 ^163^ | kg | Pioglitazone, 96 | Placebo, 97 | 45 (fixed) | NA | 84.1 (16.8) | 86.3 (17.4) | 2.4 | <0.001 vs. GP2
| | | | | | 84.92 | 84.72
| | | | | | 0.82 | -1.58
Aronoff, 2000 ^165^ | kg | Pioglitazone, 81 | Placebo, 79 | 7.5 (fixed) | NA | 93.5 (SE 1.59) | 90.4 (SE 1.47) | 0.7 | NSG vs. GP2
| | | | | | 92.9 | 89.1
| | | | | | -0.6 (SE 0.9) | -1.3 (SE 0.36)
Aronoff, 2000 ^165^ | kg | Pioglitazone, 79 | Placebo, 79 | 15 (fixed) | NA | 91.2 (SE 1.8) | 90.4 (SE 1.47) | 2.6 | NSG vs. GP2
| | | | | | 92.5 | 89.1
| | | | | | 1.3 (SE 0.33) | -1.3 (SE 0.36)
Aronoff, 2000 ^165^ | kg | Pioglitazone, 87 | Placebo, 79 | 30 (fixed) | NA | 90.3 (SE 0.38) | 90.4 (SE 1.47) | 2.6 | NSG vs. GP2
| | | | | | 91.6 | 89.1
| | | | | | 1.3 (SE 0.38) | -1.3 (SE 0.36)
Aronoff, 2000 ^165^ | kg | Pioglitazone, 79 | Placebo, 79 | 45 (fixed) | NA | 90.8 (SE 0.39) | 90.4 (SE 1.47) | 4.1 | NSG vs. GP2
| | | | | | 93.6 | 89.1
| | | | | | 2.8 (SE 0.39) | -1.3 (SE 0.36)
Smith, 2005 ^161^ | kg | Pioglitazone + diet, 21 | Placebo + diet, 21 | 30 (esc) 45 | NA | 93.48 (18.48) | 92.13 (14.65) | 4.67 | 0.0004 vs. GP2
| | | | | | 97.36 | 91.34
| | | | | | 3.88 (3.11) | -0.79 (3.36)
Tseng, 2005 ^140^ | kg | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | 61.3 (10.9) | NR | NR | <0.001 vs. baseline | NSG vs. baseline
| | | | NR (NR) | | 62.3 (11.4) | NR
| | | | | | 1 | NR
Kipnes, 2001 ^166^ | kg | Pioglitazone + existing unspecified sulfonylurea, 189 | Existing unspecified sulfonylurea + placebo, 187 | 30 (fixed) | NR (fixed) | NR | NR | 3.7 | <0.05 vs. GP1
| | | | NR (fixed) | | NR | NR
| | | | | | 2.9 | -0.8
Kipnes, 2001 ^166^ | kg | Pioglitazone + existing unspecified sulfonylurea, 184 | Existing unspecified sulfonylurea + placebo, 187 | 15 (fixed) | NR (fixed) | NR | NR | 2.7 | <0.05 vs. GP1
| | | | NR (fixed) | | NR | NR
| | | | | | 1.9 | -0.8
Einhorn, 2000 ^160^ | kg | Pioglitazone + existing metformin + diet, 168 | Placebo + existing metformin + diet, 160 | 30 (fixed) | NR (NR) | NR | NR | 2.31 | NR | NR
| | | | NR (NR) | | NR | NR
| | | | | | 0.95 | -1.36
Rosiglitazone vs. Placebo
Virtanen, 2003 ^143^ | kg | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 83.7 (7.9) | 88.3 (9.7) | 0.5 | NSG vs. GP2
| | | | | | 84.3 (3.5) | 88.4 (9.7)
| | | | | | 0.6 | 0.1
Lebovitz, 2001 ^169^ | kg | Rosiglitazone, 166 | Placebo, 158 | 2 bid (fixed) | NA | NR | NR | 2.6 | <0.05 vs. baseline and vs. GP2
| | | | | | NR | NR
| | | | | | 1.6 (3.1) | -1 (2.9)
Lebovitz, 2001 ^169^ | kg | Rosiglitazone, 169 | Placebo, 158 | 4 bid (fixed) | NA | NR | NR | 4.5 | <0.05 vs. baseline and vs. GP2
| | | | | | NR | NR
| | | | | | 3.5 (3.6) | -1 (2.9)
Natali, 2004 ^144^ | kg | Rosiglitazone, 24 | Placebo, 22 | 8 (fixed) | NA | 80.4 (SEM 10.1) | 86.9 (SEM 10.5) | 1 | NSG vs. GP2
| | | | | | 80.9 | 86.6
| | | | | | 0.5 (0.5) | -0.3 (0.8)
Barnett, 2003 ^172^ | kg | Rosiglitazone + unspecified sulfonylurea, 84 | Unspecified sulfonylurea + placebo, 87 | 4 bid (fixed) | NR (NR) | NR | NR | 4 | <0.001 vs. GP2
| | | | NR (NR) | | NR | NR
| | | | | | 3.9 (3.16) | -0.1
Metformin vs. Placebo
DeFronzo, 1995 ^88^ | kg | Metformin, 143 | Placebo, 146 | 850 (esc) 850 tid | NA | 92.6 | NR | -0.5 | NSG vs. GP2
| | | | | | 92 | NR
| | | | | | -0.6 (SE 0.3) | -1.1 (SE 0.2)
Garber, 2002 ^79^ | kg | Metformin, 161 | Placebo, 161 | 500 (esc) 2000 | NA | 87 (14.9) | NR | 0.1 | NSG vs. GP2
| | | | | | 86.4 | NR
| | | | | | -0.6 | -0.7
Willms, 1999 ^99^ | kg | Metformin, 27 | Placebo, 29 | 850 bid (fixed) | NA | 88.6 (17.7) | 90.2 (15.4) | 0.8 | NR | NR
| | | | | | 87 | 87.85
| | | | | | -1.6 (SE 0.89) | -2.4 (SE 0.99)
Natali, 2004 ^144^ | kg | Metformin | Placebo | 1500 (fixed) | NA | 77.3 (SEM 12.5) | 86.9 (SEM 10.5) | -0.3 | NSG vs. baseline | NSG vs. baseline
| | | | | | 76.7 | 86.6
| | | | | | -0.6 (0.4) | -0.3 (0.8)
Dornan, 1991 ^260^ | kg | Metformin, 30 | Placebo, 30 | 500 (esc) 1000 tid | NA | 84.6 (14.8) | 79.5 (13.7) | 0.9 | NSG vs. GP2
| | | | | | 84.6 (SE 2.6) | 78.6 (SE 2.4)
| | | | | | 0 | -0.9
Teupe, 1991 ^155^ | kg | Metformin + diet, 25 | Diet, 29 | NR (esc) 1700 | NA | 87.7 (11.9) | 83.1 (11.7) | -0.5 | NR | NR
| | | | | | 85.1 (10) | 81 (11.7)
| | | | | | -2.6 | -2.1
1995 ^92^ | kg | Metformin + diet, 262 | Diet, 291 | NR (esc) 850 tid | NA | 88* | 87* | 0.2 | NR | NR
UKPDS, 3 year f/u of obese patients in primary diet failure and main randomization groups | | | | | | 87.4 (85.3, 89.5^‡^) | 86.2 (84.4, 88^‡^)
| | | | | | -0.6* | -0.8*
1998 ^15^ | kg | Metformin, 181 | Diet, 200 | 850 (esc) 2550 | NA | 87 (17) | NR | 0 | NR | NR
UKPDS, 10 year f/u of obese patients for metformin and obese and non-obese patients for glibenclamide | | | | | | 88.25 | NR
| | | | | | 1.25* | 1.25*
Hallsten, 2002 ^324^ | kg | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 88.8 (SE 3.1) | 88.3 (SE 2.6) | -2.1 | <0.05 vs. GP2
Virtanen, 2003 ^143^ | | | | | | 86.8 (SE 3) | 88.4 (SE 2.6)
| | | | | | -2 | 0.1
Del Prato, 2003 ^149^ | kg | Metformin + placebo, 284 | Placebo, 138 | 850 (esc) 2550 | NA | 82.6 (14.6) | 84.5 (14.8) | 0.3 | NR | NR
| | | | | | 81.9 (15) | 83.5 (14.5)
| | | | | | -0.7 | -1
Lee, 1998 ^259^ | kg | Metformin + placebo + diet, 24 | Placebo + diet, 24 | 850 (fixed) | NA | 112.3 (SE 6.9) | 109.8 (SE 3.4) | -7.8 | <0.001 vs. GP2
| | | | | | 103.5 (SE 6.6) | 108.8 (SE 3.4)
| | | | | | -8.8 | -1
Second Generation Sulfonylurea vs. Placebo
Simonson, 1997 ^136^ | kg | Glipizide GITS | Placebo | 5, 20, 40 or 60 (fixed) | NA | NR | NR | 3.27 | NSG vs. baseline
Trial 1 | | | | | | NR | NR | | <0.001 vs. GP2
| | | | | | -0.32 (0.27) | -3.58 (0.59)
Simonson, 1997 ^136^ | kg | Glipizide GITS | Placebo | 5, 10, 15, or 20 (fixed) | NA | NR | NR | 2.99 | NSG vs. baseline
Trial 2 | | | | | | NR | NR | | <0.001 vs. GP2
| | | | | | 0.14 (0.18) | -3.13 (0.36)
Cefalu, 1998 ^261^ | kg | Glipizide GITS, 20 | Placebo, 20 | 5 (esc) 10 | NA | 82.7 (16.2) | 89.5 (14.2) | 0.9 | NSG vs. baseline | NSG vs. baseline
| | | | | | 82.7 | 88.6
| | | | | | 0 | -0.9
Garber, 2002 ^79^ | kg | Glyburide (Micronase), 161 | Placebo, 161 | 2.5 (esc) 10 | NA | 87.2 (15.3) | 86.2 (16.6) | 2.4 | <0.05 vs. baseline
| | | | | | 88.9 | 85.5
| | | | | | 1.7 | -0.7
Luis Bautista, 2003 ^193^ | kg | Glimepiride + diet + exercise, 48 | Placebo + diet + exercise, 22 | 1 (esc) 4 | NA | 83.3 (SE 17) | 76.3 (SE 18.5) | 4.4 (SE 1.1) | <0.001 vs. GP2
| | | | | | 85.5 | 74.2
| | | | | | 2.3 (2.6) | -2.1
Vray, 1995 ^137^ | kg | Glibenclamide, 51 | Traditional Chinese treatment, 46 | 2.5 tid (fixed) | Administered in 7 capsules (fixed) | NR | NR | 1.21 | <0.001 vs. baseline | 0.89 vs. baseline
| | | | | | NR | NR
| | | | | | 0.67 (SE 0.4) | -0.54 (SE 0.3)
1998 ^16^ | kg | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | NR | NR | 1.8 | <0.001 vs. GP2
UKPDS, 10 year f/u | | | | | | NR | NR
| | | | | | 4* (0.7) | 2.2*
1995 ^92^ | kg | Glibenclamide + diet, 212 | Diet, 291 | NR (esc) 10 bid | NA | 86 (14.7) | 87* | 1.8
UKPDS, 3 year f/u of obese patients | | | | | | 87 | 86.2 (84.4, 88)
| | | | | | 1 | -0.8
1995 ^92^ | kg | Glibenclamide + diet, 472 | Diet, 373 | NR (esc) 10 bid | NA | 69* | 68* | 3
UKPDS, 3 year f/u of non-obese patients | | | | | | 73* | 69*
| | | | | | 4 | 1
1998 ^15^ | kg | Glibenclamide, 148 | Diet, 200 | NR | NA | 86 (range 14–16) | 87 (range 14–16) | 2.15 | NR | NR
UKPDS, 10 year f/u of obese | | | | | | 89.4 | 88.25
| | | | | | 3.4* | 1.25*
Meglitinide vs. Placebo
Saloranta, 2002 ^241^ | kg | Nateglinide, 166 | Placebo, 163 | 30 (fixed) | NA | NR | NR | 0.34 | NR | NR
| | | | | | NR | NR
| | | | | | 0.65 | .31
Moses, 2001 ^218^ | kg | Repaglinide, 260 | Placebo, 134 | 0.5 (esc) 1 per meal | NA | 84 (16.1) | 86.6 (16.7) | -0.05 | NSG vs. baseline and vs. GP2
| | | | | | 84.35 | 87*
| | | | | | 0.35 | 0.4
Alpha-Glucosidase Inhibitor vs. Placebo
Willms, 1999 ^99^ | kg | Acarbose, 31 | Placebo, 29 | 100 tid (fixed) | NA | 86.1 (15.4) | 90.2 (15.4) | -0.5 | NR | NR
| | | | | | 83.2 | 87.8
| | | | | | -2.9 (SE 0.72) | -2.4 (SE 0.99)
Rosenbaum, 2002 ^153^ | kg | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 75.1 (11.6) | 80.2 (9.8) | -1.1 | <0.01 vs. baseline | 0.1 vs. baseline
| | | | | | 73.1 (11.6) | 79.3 (9.7)
| | | | | | -2 | -0.9
Hasche, 1999 ^138^ | kg | Acarbose + diet, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 74.9 (8.7) | 74.5 (8.6) | -0.1 | NR | NR
| | | | | | 73.5 | 73.2
| | | | | | -1.4 | -1.3
Metformin + Second Generation Sulfonylurea vs. Placebo
Garber, 2002 ^79^ | kg | Metformin + glyburide (Micronase), 165 | Placebo, 161 | 500 (esc) 2000 | NA | NR | NR | 2.6 | <0.05 vs. GP2
| | | | 2.5 (esc) 10 | | NR | NR
| | | | | | 1.9 | -0.7
Garber, 2002 ^79^ | kg | Metformin + glyburide (Micronase), 158 | Placebo, 161 | 250 (esc) 1000 | NA | NR | NR | 2.1 | <0.05 vs. GP2
| | | | 1.25 (esc) 5 | | NR | NR
| | | | | | 1.4 | -0.7

Comp = comparison; BL = baseline; GP = group; mg = milligrams; max = maximum; esc = escalated; diff = difference; kg = kilograms; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; od = once daily; bid = twice daily; tid = three times daily; HbA1c = hemoglobin A1c; UKPDS = United Kingdom Prospective Diabetes Study; f/u = follow-up; GITS = gastrointestinal therapeutic system; vs = versus

* Number obtained from a figure

‡ 95% confidence interval

Table 8 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: body mass index

Author, year Study group | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
| | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Derosa, 2005 ^53^ | kg/m^2^ | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 24.3 (0.7) | 24.4 (0.8) | 0.3 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | 4 (fixed) | 4 (fixed) | 25.8 (0.9) | 25.6 (0.9) | | NSG vs. GP2
| | | | | | 1.5 | 1.2
Thiazolidinedione vs. Metformin
Virtanen, 2003 ^143^ | kg/m^2^ | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 29.1 (SE 1) | 29.9 (SE 1.1) | 0.9 | NSG vs. baseline | NSG vs. baseline
| | | | | | 29.3 (SE 1.1) | 29.2 (SE 1.1)
| | | | | | 0.2 | -0.7
Lawrence, 2004 ^54^ | kg/m^2^ | Pioglitazone, 20 | Metformin, 20 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 30.6^#^(29.4–35.2) ^##^ | 29.2^#^ (28.1–31.6) ^##^ | 2.1 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 32.1^#^ (29.8-NR)^##^ | 28.6^#^ (27.3-NR)^##^
| | | | | | 1.5 | -0.6
Ramachandran, 2004 ^55^ | kg/m^2^ | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 25.5 (2.2) | 25.7 (2.6) | -0.2 | NR | NR
| | | | | | 25.1 (2) | 25.5 (3)
| | | | | | -0.4 | -0.2
Yamanouchi, 2005 ^57^ | kg/m^2^ | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 25.8 (4.2) | 26.2 (3.8) | 1.6 | NSG vs. baseline | NSG vs. baseline
| | | | | | 26.7 (3.9) | 25.5 (4.2)
| | | | | | 0.9 | -0.7
Thiazolidinedione vs. Second Generation Sulfonylurea
Pfutzner, 2005 ^68^ | kg/m^2^ | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 31.7 (5) | 31.8 (4.3) | 1.4 | | 0.001 vs. GP1
Langenfeld, 2005 ^146^ | | | | | | 33.1 (5.1) | 31.8 (4.1)
Forst, 2005 ^145^ | | | | | | 1.4 | 0
Lawrence, 2004 ^54^ | kg/m^2^ | Pioglitazone, 20 | Gliclazide, 20 | 30 (esc) 45 | 80 od (esc) 160 bid | 30.6^#^ (29.4–35.2)^##^ | 28.7^#^ (28.3–34.4)^##^ | -0.4 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 32.1^#^ (29.8-NR)^##^ | 30.6^#^ (28.0-NR)^##^
| | | | | | 1.5 | 1.9
Yanagawa, 2004 ^62^ | kg/m^2^ | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | 24.6 (2) | 24 (3.5) | NR | | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Ramachandran, 2004 ^55^ | kg/m^2^ | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 25.5 (2.2) | 24.6 (2.5) | -1.1 | NR | NR
| | | | | | 25.1 (2) | 25.3 (2.5)
| | | | | | -0.4 | 0.7
Yamanouchi, 2005 ^57^ | kg/m^2^ | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 25.8 (4.2) | 25.6 (3.5) | 1.1 | NSG vs. baseline | NSG vs. baseline
| | | | | | 26.7 (3.9) | 25.4 (4)
| | | | | | 0.9 | -0.2
Thiazolidinedione + Metformin vs. Second Generation Sulfonylurea + Metformin
Derosa, 2005 ^72^ | kg/m^2^ | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 26.6 (1.3) | 26.8 (1.5) | -0.5 | <0.01 vs. baseline | <0.05 vs. baseline
| | | | 1500 (fixed) | 2 (fixed) | 24.5 (1.1) | 25.2 (1.4)
| | | | | | -2.1 | -1.6
Metformin vs. Second Generation Sulfonylurea
Tosi, 2003 ^95^ | kg/m^2^ | Metformin, 19 | Glibenclamide, 20 | 500 (esc) 3000 | 5 (esc) 15 | NR | NR | -0.78 | <0.02 vs. GP2
| | | | | | NR | NR
| | | | | | -0.51 (0.83) | 0.27 (0.88)
Lawrence, 2004 ^54^ | kg/m^2^ | Metformin, 20 | Gliclazide, 20 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 29.2^#^ (28.1–31.6)^##^ | 28.7 (28.3–34.4)^#^ | -2.5 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 28.6^#^ (27.3-NR)^##^ | 30.6^#^ (28.0-NR)^##^
| | | | | | -0.6 | 1.9
Ramachandran, 2004 ^55^ | kg/m^2^ | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 25.7 (2.6) | 24.6 (2.5) | -0.9 | NR | <0.05 vs. baseline
| | | | | | 25.5 (3) | 25.3 (2.5)
| | | | | | -0.2 | 0.7
Charpentier, 2001 ^89^ | kg/m^2^ | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 29.2 (range 20.1–39.9) | 29.3 (range 17.9–39.8) | -0.53 | <0.001 vs. GP2
| | | | | | 28.95 | 29.58
| | | | | | -0.25 (0.9) | 0.28 (1.04)
Yamanouchi, 2005 ^57^ | kg/m^2^ | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 26.2 (3.8) | 25.6 (3.5) | -0.5 | NSG vs. baseline | NSG vs. baseline
| | | | | | 25.5 (4.2) | 25.4 (4)
| | | | | | -0.7 | -0.2
Derosa, 2004 ^90^ | kg/m^2^ | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 28.1 (1.5) | 27.6 (1.2) | 0.1 | NSG vs. baseline | NSG vs. baseline
| | | | | | 27.5 (0.9) | 26.9 (1)
| | | | | | -0.6 (-1.24, 0.33^‡^) | -0.7 (-1.35, 0.25^†^)
Hermann, 1991 ^94^ | kg/m^2^ | Metformin + diet, 16 | Glibenclamide + diet, 17 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 27 (3.0) | 29.2 (4.3) | -1.2 | NSG vs. baseline | <0.001 vs. baseline
| | | | | | 26.9 (2.8) | 30.3 (4.8) | | <0.001 vs. GP2
| | | | | | -0.1 | 1.1
Metformin vs. Meglitinide
Derosa, 2003 ^97^ | kg/m^2^ | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 24.7 (1.2) | 25.2 (1.1) | -0.5 | 0.12 vs. baseline | >0.2 vs. baseline
| | | | | | 24.1 | 25.1 | | NSG vs. GP2
| | | | | | -0.6 (-1.5, 1.2^‡^) | -0.1 (-0.3, 0.19^‡^)
Metformin vs. Metformin + Second Generation Sulfonylurea
Tosi, 2003 ^95^ | kg/m^2^ | Metformin, 19 | Metformin + glibenclamide, 41 | 500 (esc) 3000 | 400 (esc) 2400 | NR | NR | -0.74 | <0.02 vs. GP2
| | | | | 2.5 (esc) 15 | NR | NR
| | | | | | -0.51 (0.83) | 0.23 (1.10)
Charpentier, 2001 ^89^ | kg/m^2^ | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 29.2 (range 20.1–39.9) | 29.5 (range 20.2–39.8) | -0.46 | <0.002 vs. GP2
| | | | | 1 (esc) 6 | 28.95 | 29.71
| | | | | | -0.25 (0.9) | 0.21 (1.05)
Feinglos, 2005 ^104^ | kg/m^2^ | Metformin + placebo, 56 | Metformin + glipizide, 56 | at least 1000 (fixed) | at least 1000 (fixed) | 32.1 (4.9) | 31.7 (4.4) | -0.7 | < 0.0001 vs. GP2
| | | | | 2.5 (fixed) | 31.5 | 31.8
| | | | | | -0.6 | 0.1
Hermann, 1991 ^94^ | kg/m^2^ | Metformin + diet, 16 | Metformin + glibenclamide + diet, 11 | 1000 (esc) 3000 | 1000 (esc) 3000 | 27 (3.0) | 26.1 (3.6) | -0.9 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 10.5 (esc) 14 | 26.9 (2.8) | 26.9 (3.8)
| | | | | | -0.1 | 0.8
Hermann, 1991 ^94^ | kg/m^2^ | Metformin + diet, 16 | Metformin + glibenclamide + diet, 12 | 1000 (esc) 3000 | 3000 (fixed) | 27 (3.0) | 30.0 (6.5) | -0.3 | | NSG vs. baseline
| | | | | 3.5 (esc) 14 | 26.9 (2.8) | 30.2 (6.5)
| | | | | | -0.1 | 0.2
Second Generation Sulfonylurea vs. Meglitinide
Derosa, 2003 ^118^ | kg/m^2^ | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 26.4 (1) | 26.1 (1.2) | -0.6 | NSG vs. GP2
| | | | | | 25.9 (1.2) | 26.2 (.8)
| | | | | | -0.5 | 0.1
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea + Thiazolidinedione
Pfutzner, 2006 ^123^ | kg/m^2^ | Glimepiride + placebo | Rosiglitazone + glimepiride, 30 | 3 (fixed) | 8 (fixed) | 30 (3.4) | 29.3 (4.8) | -0.4 | NR | NR
| | | | | 3 (fixed) | 29.8 (3.4) | 29.5 (4.8)
| | | | | | -0.2 | 0.2
Pfutzner, 2006 ^123^ | kg/m^2^ | Glimepiride + placebo | Rosiglitazone + glimepiride, 30 | 3 (fixed) | 4 (fixed) | 30 (3.4) | 27.7 (4.1) | -0.2 | NR | NR
| | | | | 3 (fixed) | 29.8 (3.4) | 27.7 (4.1)
| | | | | | -0.2 | 0
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Charpentier, 2001 ^89^ | kg/m^2^ | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 29.3 (range 17.9–39.8) | 29.5 (range 20.2–39.8) | 0.07 | NSG vs. GP2
| | | | | 1 (esc) 6 | 29.58 | 29.71
| | | | | | 0.28 (1.04) | 0.21 (1.05)
Tosi, 2003 ^95^ | kg/m^2^ | Glibenclamide, 20 | Metformin + glibenclamide, 41 | 5 (esc) 15 | 400 (esc) 2400 | NR | NR | 0.04 | NR | NR
| | | | | 2.5 (esc) 15 | NR | NR
| | | | | | 0.27 (0.88) | 0.23 (1.10)
Hermann, 1991 ^94^ | kg/m^2^ | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 11 | 3.5 (esc) 10.5 | 1000 (esc) 3000 | 29.2 (4.3) | 26.1 (3.6) | 0.3 | <0.001 vs. baseline | <0.05 vs. baseline
| | | | | 10.5 (esc) 14.0 | 30.3 (4.8) | 26.9 (3.8)
| | | | | | 1.1 | 0.8
Hermann, 1991 ^94^ | kg/m^2^ | Glibenclamide + diet, 17 | Metformin + glibenclamide + diet, 12 | 3.5 (esc) 10.5 | 3000 (fixed) | 29.2 (4.3) | 30 (6.5) | 0.9 | <0.001 vs. baseline | NSG vs. baseline
| | | | | 3.5 (esc) 14.0 | 30.3 (4.8) | 30.2 (6.5)
| | | | | | 1.1 | 0.2
Metformin vs. Placebo
Rachmani, 2002 ^150^ | kg/m^2^ | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NA | 28.7 (SE 0.7) | 28.4 (SE 0.6) | -0.8 | NSG vs. baseline | <0.05 vs. baseline
| | | | | | 29.1 | 29.6
| | | | | | 0.4 | 1.2
Manzella, 2004 ^148^ | kg/m^2^ | Metformin + diet, 60 | Placebo + diet, 60 | 850 bid (fixed) | NA | 29.5 (0.1) | 29.2 (0.2) | -0.7 | NSG vs. placebo
| | | | | | 29.1 (0.2) | 29.5 (0.4)
| | | | | | -0.4 | 0.3
Virtanen, 2003 ^143^ | kg/m^2^ | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 29.9 (SE 1.1) | 30.3 (SE 1.2) | -0.7 | <0.05 vs. GP2
| | | | | | 29.2 (SE 1.1) | 30.3 (SE 1.2)
| | | | | | -0.7 | 0
Del Prato, 2003 ^149^ | kg/m^2^ | Metformin + placebo, 279 | Placebo, 138 | 850 (esc) 2550 | NA | 29.8 (4.2) | 29.9 (3.9) | 0 | NR | NR
| | | | | | 29.5 (4.3) | 29.6 (4.0)
| | | | | | -0.3 | -0.3
Thiazolidinedione vs. Placebo
Takagi, 2003 ^78^ | kg/m^2^ | Pioglitazone, 23 | Control group (conventional antidiabetic therapy), 21 | 30 (fixed) | NR (NR) | 25.6 (2.8) | 24.5 (2.9) | 0.1 | 0.2001 vs. GP2 final mean
| | | | | | 25.3 (2.7) | 24.1 (2.8)
| | | | | | -0.3 | -0.4
Nishio, 2006 ^151^ | kg/m^2^ | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 24.6 (3.9) | 24.6 (3.5) | 0.2 | 0.901 vs. baseline
| | | | | | 24.7 (3.6) | 24.5 (2.9) | | 0.57 vs. GP2 final mean
| | | | | | 0.1 | -0.1
Virtanen, 2003 ^143^ | kg/m^2^ | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 29.1 (SE 1) | 30.3 (SE 1.2) | 0.2 | NSG vs. GP2
| | | | | | 29.3 (SE 1.1) | 30.3 (SE 1.2)
| | | | | | 0.2 | 0
Kim, 2005 ^152^ | kg/m^2^ | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 23.9 (2.5) | 24.5 (3) | 0.5 | <0.01 vs. baseline | NSG vs. baseline
| | | | | | 24.4 (2.7) | 24.5 (3)
| | | | | | 0.5 | 0
Alpha-Glucosidase Inhibitor vs. Placebo
Rosenbaum, 2002 ^153^ | kg/m^2^ | Acarbose | Placebo | 50 bid (esc) 100 tid | NA | 30.3 (2.9) | 31.7 (3.9) | -0.3 | <0.05 vs. baseline | 0.4 vs. baseline
| | | | | | 29.8 (2.7) | 31.5 (3.7)
| | | | | | -0.5 | -0.2

2 Comp = comparison; BL = baseline; GP = group; mg = milligrams; max = maximum; esc = escalated; diff = difference; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; od = once daily; bid = twice daily; tid = three times daily; UKPDS = United Kingdom Prospective Diabetes Study; f/u = follow-up; vs = versus; kg/m = kilograms per meter squared

* Number obtained from a figure

# Median

## Interquartile range

‡ 95% confidence interval

Table 10 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: diastolic blood pressure

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg | Group 2, initial dose in mg | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
Study group | | | | (fixed or esc) max dose | (fixed or esc) max dose | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Metformin
Pavo, 2003 ^59^ | mmHg | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | 87 (8.5) | 88 (8.2) | 0 | 0.979 vs. GP2
| | | | | | 83.1 | 84.1
| | | | | | -3.9 (0.6) | -3.9 (0.6)
Yamanouchi, 2005 ^57^ | mmHg | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 85.3 (9.8) | 86.3 (10.1) | -1.2 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 80.5 (7.8) | 82.7 (8.7)
| | | | | | -4.8 | -3.6
Hallsten, 2002 ^58^ | mmHg | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 90.5 (SE 2.1) | 91.4 (SE 2.5) | -0.4 | | | NSG vs. all groups
| | | | | | 84.2 (2.4) | 85.5 (2.6)
| | | | | | -6.3 | -5.9
Natali, 2004 ^144^ | mmHg | Rosiglitazone | Metformin | 4 bid (fixed) | 500 tid (fixed) | 72 (SEM 6) | 75 (SEM 9) | -4 (-7, -1^‡^) | <0.05 vs. GP2
| | | | | | 74 | 76
| | | | | | -2 (1) | -1 (1)
Schernthaner, 2004 ^56^ | mmHg | Pioglitazone + placebo + diet, 48 | Metformin + placebo + diet, 47 | 30 (esc) 45 | 850 (esc) 2550 | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Thiazolidinedione vs. Second Generation Sulfonylurea
Tan, 2004 ^65^ | mmHg | Pioglitazone, 91 | Glibenclamide, 109 | 30 (esc) 45 | 1.75 (esc) 10.5 | 87 (10.3) | 85.8 (9.3) | -2.3 | <0.001 vs. baseline | <0.001 vs. baseline
| | | | | | 82.7 | 83.3
| | | | | | -4.3 | -2.5
Nakamura, 2000 ^64^ | mmHg | Pioglitazone,15 | Glibenclamide, 15 | 30 (fixed) | 5 (fixed) | 76 (14) | 78 (14) | -5 | NR | NR
| | | | | | 72 (12) | 79 (12)
| | | | | | -4 | 1
Yanagawa, 2004 ^62^ | mmHg | Pioglitazone,19 | Gliclazide, 21 | NR | NR | 80.7 | 81 (10) | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Yamanouchi, 2005 ^57^ | mmHg | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 85.3 (9.8) | 84.9 (7.7) | 0 | NSG vs. GP2
| | | | | | 80.5 (7.8) | 80.1 (8.3)
| | | | | | -4.8 | -4.8
Langenfeld, 2005 ^146^ | mmHg | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 87 (12) | 85 (10) | -5 | <0.001 vs. baseline and vs. GP2 | NSG vs. baseline
Forst, 2005 ^145^ | | | | | | 84 (10) | 87 (10)
| | | | | | -3 | 2.0
St John Sutto, 2002 ^67^ | mmHg | Rosiglitazone, 63 | Glyburide (no trade drug specified), 66 | 4 bid (fixed) | NR(esc) 20 | 78 (SE 7.7) | 76.3 (SE 7.7) | -2.7 | 0.0046 vs. GP2 | 0.2801 vs. baseline
| | | | | | 75.7 | 77
| | | | | | -2.3 (SE 5.6) | 0.7 (SE 5.3) | | 0.0016 vs. baseline
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Goke, 2002 ^75^ | mmHg | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 300 | 84.8 (10.6) | 84.4 (11.2) | -1.8 | 0.078 vs. GP2
German Pioglitazone Study Group | | | | | | 81.8 | 83.2
| | | | | | -3 | -1.2
Nakamura, 2000 ^64^ | mmHg | Pioglitazone,15 | Voglibose, 15 | 30 (fixed) | 0.6 (fixed) | 76 (14) | 78 (12) | -6 | NSG vs. baseline | NSG vs. baseline
| | | | | | 72 (12) | 80 (14)
| | | | | | -4 | 2.0
Metformin vs. Second Generation Sulfonylurea
Amador-Licona, 2000 ^85^ | mmHg | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 75 | 70 | -13.93 | 0.009 vs. baseline | 0.16 vs. baseline
| | | | | | 70 | 80
| | | | | | -3.93 (-5.92, -1.94^‡^) | 10.0
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 85 (SE 2) | 84 (SE 1) | -0.1 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 85 (SE 1) | 84 (SE 2)
| | | | | | 0.6 (SE 1.2) | 0.5 (SE 1.2)
Charpentier, 2001 ^89^ | mmHg | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 81 (7) | 80 (7) | -0.53 | NR | NR | 0.502 all group comparison
| | | | | | 81.15 | 80.68
| | | | | | 0.15 (9.22) | 0.68 (8.25)
Yamanouchi, 2005 ^57^ | mmHg | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 86.3 (10.1) | 84.9 (7.7) | 1.2 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 82.7 (8.7) | 80.1 (8.3)
| | | | | | -3.6 | -4.8
Derosa, 2004 ^90^ | mmHg | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 86 (3) | 85 (4) | -4 | NR | NR
| | | | | | 83 (3) | 86 (4)
| | | | | | -3 | 1
DeFronzo, 1995 ^88^ | mmHg | Metformin | Glyburide (no trade drug specified) + placebo | 500 (esc) 2500 | 5 bid (esc) 10 bid | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Metformin vs. Metformin + Second Generation Sulfonylurea
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 17 | 1000 (esc) 3000 | 2000 (esc) 3000 | 85 (SE 2) | 83 (SE 1) | -1.4 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 7.0 (esc) 14.0 | 85 (SE 1) | 85 (SE 1)
| | | | | | 0.6 (SE 1.2) | 2
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 85 (SE 2) | 83 (SE 1) | -1.5 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 85 (SE 1) | 85 (SE 1)
| | | | | | 0.6 (SE 1.2) | 2.1
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 12 | 1000 (esc) 3000 | 3000 (fixed) | 85 | 83 | -1.4 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 3.5 (esc) 14.0 | 85 (SE 1) | 85 (SE 2)
| | | | | | 0.6 | 2
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 11 | 1000 (esc) 3000 | 1000 (esc) 3000 | 85 | 85 | 2.6 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 10.5 (esc) 14.0 | 85 (SE 1) | 83 (SE 3)
| | | | | | 0.6 | -2
Charpentier, 2001 ^89^ | mmHg | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 81 (7) | 81 (7) | 0.84 | NR | NR | 0.502 all group comparison
| | | | | 1 (esc) 6 | 81.15 | 80.31
| | | | | | 0.15 | -0.69
DeFronzo, 1995 ^88^ | mmHg | Metformin + placebo | Metformin + glyburide (no trade drug specified) | 500 (esc) 2500 | 500 (esc) 2500 | NR | NR | NR | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 10 (esc) 20 | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 17 | 3.5 (esc) 10.5 | 2000 (esc) 3000 | 84 | 85 | -2.5 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 7.0 (esc) 14.0 | 84 (SE 2) | 83 (SE 2)
| | | | | | 0.5 | -2
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 11 | 3.5 (esc) 10.5 | 1000 (esc) 3000 | 84 | 85 | 2.5 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 10.5 (esc) 14 | 84 (SE 2) | 83 (SE 3)
| | | | | | 0.5 | -2
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 84 (SE 1) | 83 (SE 1) | -1.6 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 84 (SE 2) | 85 (SE 1)
| | | | | | 0.5 (SE 1.2) | 2.1 (SE 1.3)
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 12 | 3.5 (esc) 10.5 | 3000 (fixed) | 84 | 83 | -1.5 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 3.5 (esc) 14 | 84 (SE 2) | 85 (SE 2)
| | | | | | 0.5 | 2
1998 ^128^ | mmHg | Glibenclamide + diet, 300 | Metformin + glibenclamide + diet, 291 | 10 (fixed) | 500 (esc) 2500 | NR | NR | -0.12 | 0.0043 vs. baseline | 0.0068 vs. baseline
UKPDS, 3 year f/u | | | | | 10 (fixed) | NR | NR | | NSG vs. GP2
| | | | | | -1.66 | -1.54
Charpentier, 2001 ^89^ | mmHg | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 80 (7) | 81 (7) | 1.37 | NR | NR | 0.502 all group comparison
| | | | | 1 (esc) 6 | 80.68 | 80.31
| | | | | | 0.68 (8.25) | -0.69 (7.91)
Gregorio, 1999 ^129^ | mmHg | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 78.63 (SE 2.1) | 80.23 (SE 2.22) | -2.01 | NSG vs. baseline | NSG vs. baseline
| | | | 120 (esc) 240 | NR(fixed) | 78.33 (SE 1.86) | 82.21 (SE 1.95)
| | | | | NR(fixed) | -0.3 | 1.98
DeFronzo, 1995 ^88^ | mmHg | Glyburide (no trade drug specified) + placebo | Metformin + glyburide (no trade drug specified) | 5 bid (esc) 10 bid | 500 (esc) 2500 | NR | NR | NR | NSG vs. GP2
| | | | | 10 (esc) 20 | NR | NR
| | | | | | NR | NR
Other Comparisons
Wolffenbuttel, 1999 ^117^ | mmHg | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 83 | 86 | 2 | NSG vs. GP2
| | | | | | 83 | 84
| | | | | | 0 | -2.0
Derosa, 2003 ^118^ | mmHg | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 85 (3) | 85 (4) | -1 | NSG vs. GP2
| | | | | | 85 (5) | 84 (4)
| | | | | | 0 | -1
Goldberg, 2005 ^52^ | mmHg | Rosiglitazone + diet, 366 | Pioglitazone + diet, 369 | 4 (esc) 8 | 30 (esc) 45 | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Hanefeld, 2004 ^60^ | mmHg | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | NR | NR | NR | NR | NR | No clinically relevant changes vs. baseline or between groups
QUARTET study group | | | | NR | NR | NR | NR
| | | | | | NR | NR
Pfutzner, 2006 ^123^ | mmHg | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 8 (fixed) | 83 (7) | 82 (9) | 0 | NR | NR
| | | | | 3 (fixed) | 83 (9) | 82 (9)
| | | | | | 0 | 0.0
Pfutzner, 2006 ^123^ | mmHg | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 4 (fixed) | 83 (7) | 82 (9) | 0 | NR | NR
| | | | | 3 (fixed) | 83 (9) | 82 (7)
| | | | | | 0 | 0.0
Derosa, 2003 ^97^ | mmHg | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 81 (4.5) | 80 (4.1) | -2 | NSG vs. GP2
| | | | | | 80 (4.5) | 81 (5.1)
| | | | | | -1 | 1.0
Nakamura, 2000 ^64^ | mmHg | Glibenclamide, 15 | Voglibose, 15 | 5 (fixed) | 0.6 (fixed) | 78 (14) | 78 (12) | -1 | NR | NR
| | | | | | 79 (12) | 80 (14)
| | | | | | 1 | 2.0
Thiazolidinedione vs. Placebo
Nishio, 2006 ^151^ | mmHg | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 74.3 (7.5) | 74.1 (11.1) | -1.3 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 73.5 (8.8) | 74.6 (9.9)
| | | | | | -0.8 | 0.5
Hallsten, 2002 ^58^ | mmHg | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 90.5 (SE 2.1) | 85.1 (SE 2.3) | -6.6 | NR | NR | NSG all group comparison
| | | | | | 84.2 (SE 2.4) | 85.4 (SE 2.7)
| | | | | | -6.3 | 0.3
Kim, 2005 ^152^ | mmHg | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 83.4 (10.5) | 86.1 (15.4) | -1.2 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 80.5 (10.3) | 84.4 (14)
| | | | | | -2.9 | -1.7
Natali, 2004 ^144^ | mmHg | Rosiglitazone | Placebo | 4 bid (fixed) | NA | 72 (SEM 6) | 76 (SEM 8) | -2.1
| | | | | | 70 | 76.1 | (-5, 1^‡^)
| | | | | | -2 (1) | 0.1 (1)
Metformin vs. Placebo
Natali, 2004 ^144^ | mmHg | Metformin | Placebo | 500 tid (fixed) | NA | 75 (SEM 9) | 76 (SEM 8) | -1.1 | NR | NR
| | | | | | 74 | 76.1
| | | | | | -1 (1) | 0.1 (1)
Rachmani, 2002 ^150^ | mmHg | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR | NA | 82 (SE 2) | 83 (SE 2) | 1 | NSG vs. baseline and vs. GP2 | <0.05 vs. baseline
| | | | | | 80 | 80
| | | | | | -2 | -3.0
Teupe, 1991 ^155^ | mmHg | Metformin + diet, 25 | Diet, 29 | NR(esc) 1700 | NA | 92 (9) | 95 (15) | 5 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 89 (6) | 87 (10)
| | | | | | -3 | -8.0
Hallsten, 2002 ^58^ | mmHg | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 91.4 (SE 2.5) | 85.1 (SE 2.3) | -6.2 | | | NSG vs. all groups
| | | | | | 85.5 (SE 2.6) | 85.4 (SE 2.7)
| | | | | | -5.9 | 0.3
DeFronzo, 1995 ^88^ | mmHg | Metformin + placebo | Placebo | 850 (esc) 850 tid | NA | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Alpha-Glucosidase Inhibitor vs. Placebo
Rosenbaum, 2002 ^153^ | mmHg | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 82.5 (7.3) | 87.6 (5.5) | 1.8 | 0.32 vs. baseline | 0.01 vs. baseline
| | | | | | 80.9 (4.5) | 84.2 (5.4)
| | | | | | -1.6 | -3.4

Comp = comparison; BL = baseline; GP = group; mg = milligrams; max = maximum; esc = escalated; diff = difference; mmHg = millimeters of mercury; NR= not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; bid = twice daily; tid = three times daily; UKPDS = United Kingdom Prospective Diabetes Study; f/u = follow-up; vs = versus

‡ 95% confidence interval

Table 9 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: systolic blood pressure

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg | Group 2, initial dose in mg | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
Study group | | | | (fixed or esc) max dose | (fixed or esc) max dose | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Metformin
Hallsten, 2002 ^58^ | mmHg | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 152 (5) | 145 (4.1) | 0.2 | | | NSG vs. all groups
| | | | | | 149 (4.5) | 141.8 (4)
| | | | | | -3 | -3.2
Pavo, 2003 ^59^ | mmHg | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | 140.1 (SEM 15.4) | 142.6 (SEM 14.2) | 0.5 | 0.774 vs. GP2
| | | | | | 133.9 (SEM 1.2) | 135.9 (SEM 1.2)
| | | | | | -6.2 | -6.7
Yamanouchi, 2005 ^57^ | MmHg | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 142.8 (17.1) | 143.3 (18.8) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 137.5 (19.5) | 138 (14.8)
| | | | | | -5.3 | -5.3
Natali, 2004 ^144^ | mmHg | Rosiglitazone | Metformin | 4 bid (fixed) | 500 tid (fixed) | 129 (SEM 14) | 131 (SEM 14) | -1 (-6, 3^‡^)
| | | | | | 135 | 128
| | | | | | -4 (2) | -3 (2)
Schernthaner, 2004 ^56^ | mmHg | Pioglitazone + placebo + diet | Metformin + placebo + diet | 30 (esc) 45 | 850 (esc) 2550 | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Hanefeld, 2004 ^60^ | mmHg | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | NR | NR | NR | NR | NR | No clinically relevant changes vs. baseline or between groups
QUARTET study group | | | | NR | NR | NR | NR
| | | | | | NR | NR
Thiazolidinedione vs. Second Generation Sulfonylurea
St John Sutto, 2002 ^67^ | mmHg | Rosiglitazone, 63 | Glyburide (no trade drug specified), 66 | 4 bid (fixed) | NR(esc) 20 | 131.2 (SE 11.7) | 129.5 (SE 13.5) | -3.5 | 0.0219 vs. GP2 | 0.0006 vs. baseline
| | | | | | 131.1 | 133.3 | | NSG vs. baseline
| | | | | | -0.1 (SE 9.0) | 3.8 (SE 8.7)
Tan, 2004 ^65^ | mmHg | Pioglitazone, 91 | Glibenclamide, 109 | 30 (esc) 45 | 1.75 (esc) 10.5 | 145.4 (20) | 142.9 (15.5) | 0.3 | 0.001 vs. baseline | <0.001 vs. baseline
| | | | | | 140.4 | 137.6
| | | | | | -5.0 | -5.3
Nakamura, 2000 ^64^ | mmHg | Pioglitazone, 15 | Glibenclamide, 15 | 30 (fixed) | 5 (fixed) | 122 (17) | 122 (18) | -8 | NR | NR
| | | | | | 116 (15) | 124 (16)
| | | | | | -6 | 2
Yanagawa, 2004 ^62^ | mmHg | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | 130 (12) | 134 (17) | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Yamanouchi, 2005 ^57^ | mmHg | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 142.8 (17.1) | 141.3 (21.3) | -1.2 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 137.5 (19.5) | 137.2 (16.3)
| | | | | | -5.3 | -4.1
Langenfeld, 2005 ^146^ | mmHg | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 149 (21) | 148 (20) | -9 | <0.0001 vs. baseline | NSG vs. baseline
Forst, 2005 ^145^ | | | | | | 141 (16) | 147 (19) | | <0.01 vs. GP2
| | | | | | -8 | 1
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Goke, 2002 ^75^ | mmHg | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 300 | 145.2 (19) | 141.5 (18.8) | 6.0 | <0.001 vs. GP2
German Pioglitazone Study Group | | | | | | 139.6 | 141.9
| | | | | | -5.6 (17.7) | 0.4 (18.4)
Nakamura, 2000 ^64^ | mmHg | Pioglitazone, 15 | Voglibose, 15 | 30 (fixed) | 0.6 (fixed) | 122 (17) | 118 (16) | -10 | NSG vs. baseline | NSG vs. baseline
| | | | | | 116 (15) | 122 (18)
| | | | | | -6 | 4
Metformin vs. Second Generation Sulfonylurea
Amador-Licona, 2000 ^85^ | mmHg | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 120 | 120 | -15 | 0.002 vs. baseline | NSG vs. baseline
| | | | | | 115 | 130
| | | | | | -5 (2.7, 7.8^‡^) | 10
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 150 (SE 4) | 141 (SE 3) | 3 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 152 (SE 3) | 140 (SE 3)
| | | | | | 2.4 (SE 2.5) | -1 (SE 2)
Charpentier, 2001 ^89^ | mmHg | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 142 (11) | 137 (12) | -2.25 | NR | NR | Treatment effect p=0.811
| | | | | | 141.35 | 138.6
| | | | | | -0.65 | 1.6
Yamanouchi, 2005 ^57^ | mmHg | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 143.3 (18.8) | 141.3 (21.3) | -1.2 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 138 (14.8) | 137.2 (16.3)
| | | | | | -5.3 | -4.1
Derosa, 2004 ^90^ | mmHg | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 129 (5) | 128 (5) | -3 | NR | NR
| | | | | | 125 (3) | 129 (4)
| | | | | | -4 | 1
DeFronzo, 1995 ^88^ | mmHg | Metformin | Glyburide (no trade drug specified) + placebo | 500 (esc) 2500 | 5 bid (esc) 10 bid | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Charpentier, 2001 ^89^ | mmHg | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 137 (12) | 140 (12) | 1.74 | NR | NR | Treatment effect p=0.811
| | | | | 1 (esc) 6 | 138.6 | 139.86
| | | | | | 1.6 (12.76) | -0.14(13.2)
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 17 | 3.5 (esc) 10.5 | 2000 + 7 (esc) 3000 + 14 | 141 | 146 | 1 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 140 (SE 3) | 144 (SE 4)
| | | | | | -1 (SE 2.0) | 2
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 11 | 3.5 (esc) 10.5 | 1000 + 10.5 (esc) 3000 + 14 | 141 | 142 | -8 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 140 (SE 3) | 149 (SE 5)
| | | | | | -1 (SE 2.0) | -7
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 141 | 143 | -2 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 140 (SE 3) | 144 (SE 3)
| | | | | | -1 (SE 2.0) | 1 (SE 2.4)
Hermann, 1994 ^87^ | mmHg | Glyburide + diet, 19 | Metformin + glyburide + diet, 12 | 3.5 (esc) 10.5 | 3000 + 3.5 (fixed + esc) 14 | 141 | 144 | -9 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 140 (SE 3) | 152 (SE 5)
| | | | | | -1 (SE 2.0) | -8
1998 ^128^ | mmHg | Glibenclamide + diet, 300 | Metformin + glibenclamide + diet, 291 | 10 (fixed) | 500 (esc) 2500 | NR | NR | -1.8 | NSG vs. GP2
UKPDS, 3 year f/u | | | | | 10 (fixed) | NR | NR
| | | | | | 0.72 (-1.17, 2.61^‡^) | 2.51 (0.69, 4.34^‡^)
Gregorio, 1999 ^129^ | mmHg | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 165.4 (2.74) | 157.6 (2.51) | 1.3 | NSG vs. baseline | NSG vs. baseline
| | | | 120 (esc) 240 | NR(fixed) | 163.5 (2.45) | 154.4 (2.26)
| | | | | NR(fixed) | -1.9 | -3.2
DeFronzo, 1995 ^88^ | mmHg | Glyburide (no trade drug specified) + placebo | Metformin + glyburide (no trade drug specified) | 5 bid (esc) 10 bid | 500 (esc) 2500 | NR | NR | NR | NSG vs. GP2
| | | | | 10 (esc) 20 | NR | NR
| | | | | | NR | NR
Other Comparisons
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 17 | 1000 (esc) 3000 | 2000 + 7 (esc) 3000 + 14 | 150 | 146 | -4 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 152 (SE 3) | 144 (SE 4)
| | | | | | 2.4 (SE 2.5) | -0.5
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 11 | 1000 (esc) 3000 | 1000 + 10.5 (esc) 3000 + 14 | 150 | 142 | 5 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 152 (SE 3) | 149 (SE 5)
| | | | | | 2.4 (SE 2.5) | 5.9
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 150 (SE 4) | 143 (SE 3) | 1 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | 1.75 (esc) 5.25 | 152 (SE 3) | 144 (SE 3)
| | | | | | 2.4 (SE 2.5) | 1 (SE 2.4)
Hermann, 1994 ^87^ | mmHg | Metformin + diet, 19 | Metformin + glyburide + diet, 12 | 1000 (esc) 3000 | 3000 + 3.5 (fixed + esc) 14 | 150 | 144 | 6 | >0.1 vs. baseline | >0.1 vs. baseline | >0.1 all group comparison
| | | | | | 152 (SE 3) | 152 (SE 5)
| | | | | | 2.4(SE 2.5) | 8.8
Charpentier, 2001 ^89^ | mmHg | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 142 (11) | 140 (12) | -0.51 | NR | NR | Treatment effect p=0.811
| | | | | 1 (esc) 6 | 141.35 | 139.86
| | | | | | -0.65 (12.22) | -0.14 (13.2)
DeFronzo, 1995 ^88^ | mmHg | Metformin + placebo | Metformin + glyburide (no trade drug specified) | 500 (esc) 2500 | 500 (esc) 2500 | NR | NR | NR | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 10 (esc) 20 | NR | NR
| | | | | | NR | NR
Wolffenbuttel, 1999 ^117^ | mmHg | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 146 | 147 | 2 | NSG vs. GP2
| | | | | | 143 | 142
| | | | | | -3 | -5
Derosa, 2003 ^118^ | mmHg | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 128 (5) | 129 (4) | 2 | NSG vs. GP2
| | | | | | 129 (4) | 128 (5)
| | | | | | 1 | -1
Goldberg, 2005 ^52^ | mmHg | Rosiglitazone + diet, 366 | Pioglitazone + diet, 369 | 4 (esc) 8 | 30 (esc) 45 | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Pfutzner, 2006 ^123^ | mmHg | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 8 (fixed) | 142 (13) | 141 (82) | -2 | NR | NR
| | | | | 3 (fixed) | 140 (14) | 141 (81)
| | | | | | -2 | 0
Pfutzner, 2006 ^123^ | mmHg | Glimepiride + placebo | Rosiglitazone + glimepiride | 3 (fixed) | 4 (fixed) | 142 (13) | 139 (16) | 0 | NR | NR
| | | | | 3 (fixed) | 140 (14) | 137 (17)
| | | | | | -2 | -2
Derosa, 2005 ^72^ | mmHg | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 131.6 (4) | 131.4 (4.2) | -2.2 | <0.05 vs. baseline and vs. GP2
| | | | 1500 (fixed) | 2 (fixed) | 126.2 (3.6) | 128.2 (3.7)
| | | | | | -5.4 | -3.2
Derosa, 2003 ^97^ | mmHg | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 125 (6.5) | 124 (6.9) | 4 | NSG vs. GP2
| | | | | | 126 (5.1) | 121 (7.1)
| | | | | | 1 | -3
Nakamura, 2000 ^64^ | mmHg | Glibenclamide, 15 | Voglibose, 15 | 5 (fixed) | 0.6 (fixed) | 122 (18) | 118 (16) | -2 | NSG vs. baseline | NSG vs. baseline
| | | | | | 124 (16) | 122 (18)
| | | | | | 2 | 4
Thiazolidinedione vs. Placebo
Nishio, 2006 ^151^ | mmHg | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 126.9 (19.4) | 131.7 (16.9) | -3.3 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 125.1 (23.4) | 133.2 (19.6)
| | | | | | -1.8 | 1.5
Hallsten, 2002 ^58^ | mmHg | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 152 (5) | 147.2 (3.2) | -0.2 | NR | NR | NSG vs. all groups
| | | | | | 149 (4.5) | 144.4 (3.8)
| | | | | | -3 | -2.8
Kim, 2005 ^152^ | mmHg | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 139.8 (17.7) | 143.9 (17.7) | -0.5 | NSG vs. baseline | NSG vs. baseline
| | | | | | 137.4 (18) | 142 (22)
| | | | | | -2.4 | -1.9
Natali, 2004 ^144^ | mmHg | Rosiglitazone | Placebo | 4 bid (fixed) | NA | 129 (SEM 14) | 132 (SEM 18) | -5
| | | | | | 125 | 132.03 | (-10, 0.4^‡^)
| | | | | | -4 (2) | 0.3 (2)
Metformin vs. Placebo
Grant, 1996 ^154^ | NR | Metformin | Placebo | 1500 (fixed) | NA | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Grant, 1996 ^154^ | NR | Metformin | Placebo | 1500 (esc) 3000 | NA | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Rachmani, 2002 ^150^ | mmHg | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR | NA | 143 (6) | 144 (5) | -2 | NSG vs. GP2
| | | | | | 144 | 147
| | | | | | 1 | 3
Teupe, 1991 ^155^ | mmHg | Metformin + diet, 25 | Diet, 29 | NR(esc) 1700 | NA | 160 (23) | 168 (26) | 10 | <0.05 | <0.05
| | | | | | 150 (17) | 148 (21)
| | | | | | -10 (-7.4%^†^) | -20 (-12%^†^)
Hallsten, 2002 ^58^ | mmHg | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 145 (4.1) | 147.2 (3.2) | -0.4 | NR | NR | NSG vs. all groups
| | | | | | 141.8 (4) | 144.4 (3.8)
| | | | | | -3.2 | -2.8
DeFronzo, 1995 ^88^ | mmHg | Metformin | Placebo | 850 (esc) 850 tid | NA | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Natali, 2004 ^144^ | mmHg | Metformin | Placebo | 500 tid (fixed) | NA | 131 (SEM 14) | 132 (SEM 18) | -3.3 | NR | NR
| | | | | | 128 | 132.03
| | | | | | -3 (2) | 0.3 (2)
Alpha-Glucosidase Inhibitor vs. Placebo
Rosenbaum, 2002 ^153^ | mmHg | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 140.2 (16.2) | 148.5 (13) | 1.6 | 0.13 vs. baseline | 0.02 vs. baseline
| | | | | | 134 (11.9) | 140.7 (12)
| | | | | | -6.2 | -7.8

Comp = comparison; BL = baseline; GP = group; mg = milligrams; max = maximum; esc = escalated; diff = difference; mmHg = millimeters of mercury; NR= not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; bid = twice daily; tid = three times daily; UKPDS = United Kingdom Prospective Diabetes Study; f/u = follow-up; vs = versus

† Percent change from baseline

‡ 95% confidence interval

Table 11 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: low density lipoprotein

Author, year | Outcome (calc or meas) | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2
Study group | Units | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Goldberg, 2005 ^52^ | (meas) mg/dL | Rosiglitazone + diet, 356 | Pioglitazone + diet, 363 | 4 (esc) 8 | 30 (esc) 45 | 109.1 (SE 1.4) | 107.1 (SE 1.3) | 9 | < 0.05 vs. baseline | < .05 vs. baseline
| | | | | | 130.4 | 119.4 | | <0.001 vs. GP2
| | | | | | 21.3 (SE 1.6) | 12.3 (SE 1.6)
Khan, 2002 ^51^ | (calc) mg/dL | Rosiglitazone, 60 | Pioglitazone, 67 | 2–8 (fixed) | 15–45 (fixed) | 105.9 (29.7) | 116.2 (38) | 16 | NSG vs. baseline | <0.01 vs. baseline
| | | | | | 103.9 | 98.2 | | <0.01 vs. GP2
| | | | | | -2 | -18
Derosa, 2005 ^156^ | (calc) mg/dL | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 121 (17) | 125 (15) | -35 | <0.05 vs. GP2
| | | | 4 (fixed) | 4 (fixed) | 141 (20) | 110 (13
| | | | | | 20 | -15
Thiazolidinedione vs. Metformin
Schernthaner, 2004 ^56^ | (calc) mg/dL | Pioglitazone + placebo + diet | Metformin + placebo + diet | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | 138.84 | 138.84 | 15.21 | 0.001 vs. GP2
| | | | | | 149.37 | 134.16
| | | | | | 10.53 | -4.68
Lawrence, 2004 ^54^ | (meas) mg/dL | Pioglitazone, 20 | Metformin, 20 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 194.2 (43.2) | 200.5 (42.6) | 7.8 | NR | NR
| | | | | | 202.4 (46.9) | 200.9 (50.5)
| | | | | | 8.2 | 0.4
Pavo, 2003 ^59^ | (calc) mg/dL | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | NR | NR | 13.26 | 0.055 vs. baseline | 0.04 vs. baseline
| | | | | | NR | NR | | 0.003 vs. GP2
| | | | | | 6.24 | -7.02
Hanefeld, 2004 ^60^ | (meas) mg/dL | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 139.23 (33.54) | 139.62 (35.58) | 9.36 | 0.0002 vs. GP2
QUARTET study group | | | | NR | NR | 142.74 (1.56) | 132.99 (1.56)
Betteridge, 2005 ^157^ | | | | | | 3.12 | -6.24
Natali, 2004 ^144^ | (meas) mg/dL | Rosiglitazone | Metformin | 4 bid (fixed) | 500 tid (fixed) | 120 (SE 29) | 118 (SE 25) | 10 (-4, 23^‡^) | NSG vs. GP2
| | | | | | 131 | 120
| | | | | | 11 | 2
Virtanen, 2003 ^143^ | (meas) mg/dL | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 113.1 (SE 7.8) | 109.2 (SE 7.8) | 31.2 | NR | NR
| | | | | | 136.5 (SE 7.8) | 101.4 (SE 7.8)
| | | | | | 23.4 | -7.8
Thiazolidinedione vs. Second Generation Sulfonylurea
Pfutzner, 2005 ^68^ | (meas) mg/dL | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 136 (29) | 137 (25) | 5 | NSG vs. GP2
Forst, 2005 ^145^ | | | | | | 133 (31) | 129 (27)
Langenfeld, 2005 ^146^ | | | | | | -3 | -8
Matthews, 2005 ^70^ | (meas) mg/dL | Pioglitazone + metformin, 317 | Gliclazide + metformin, 313 | 15 (esc) 45 | 80 (esc) 320 | 130.26 (38.22) | 127.92 (36.27) | 14.6 | | <0.001 vs. GP1
Betteridge, 2005 ^157^ (52 week data) | | | | NR | NR | 140.66 | 123.72
| | | | | | 10.4 | -4.2
Betteridge, 2005 ^157^ (104 week data) | (meas) mg/dL | Pioglitazone + metformin, 317 | Gliclazide + metformin, 313 | 15 (esc) 45 | 80 (esc) 320 | 130.26 (38.22) | 127.92 (36.27) | 10.53 | | <0.001 vs. GP1
| | | | NR | NR | 132.99 | 120.12
| | | | | | 2.73 | -7.8
Charbonnel, 2005 ^63^ | (meas) mg/dL | Pioglitazone | Gliclazide | NR (esc) 45 | NR (esc) 320 | 137.28 | 136.5 | 11.31 (7.8, 14.04^‡^) | <0.001 vs. GP2
| | | | | | 141.96 | 129.87
| | | | | | 4.68 | -6.63
Tan, 2004 ^65^ | (calc) mg/dL | Pioglitazone, 91 | Glibenclamide, 109 | 30 (esc) 45 | 1.75 (esc) 10.5 | 141.18 | 135.72 | 6.63 | NSG vs. baseline | NSG vs. baseline
| | | | | | 146.64 | 134.55
| | | | | | 5.46 | -1.17
Lawrence, 2004 ^54^ | (meas) mg/dL | Pioglitazone, 20 | Gliclazide, 20 | 30 (esc) 45 | 80 od (esc) 160 bid | 194.2 (43.2) | 196.6 (62.3) | 9.9 | NSG vs. baseline | NSG vs. baseline
| | | | | | 202.4 (46.9) | 194.9 (64.6)
| | | | | | 8.2 | -1.7
St John Sutto, 2002 ^67^ | (meas) mg/dL | Rosiglitazone, 63 | Glyburide (no trade drug specified), 66 | 4 bid (fixed) | NR (esc) 20 | 140.2 | 135.4 | 15.2 | NR | NR
| | | | | | 146.5 | 126.5
| | | | | | 6.3; 7.7^#^ | -8.9
Thiazolidinedione + Metformin vs. Metformin + Second Generation Sulfonylurea
Derosa, 2005 ^72^ ^158^ | (meas) mg/dL | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 116 (15) | 118 (13) | 20 | | <0.05 vs. baseline and vs. GP1
| | | | 1500 (fixed) | 2 (fixed) | 120 (17) | 102 (11)
| | | | | | 4 | -16
Garber, 2006 ^71^ | (calc) mg/dL | Rosiglitazone + metformin + diet, 99 | Metformin + glibenclamide + diet, 110 | 4 (esc) 8 | 1000 (esc) 2000 | 116 | 119 | 14 (-6, 22^‡^) | NSG vs. GP2
| | | | 1500–2000 (esc) 2000 | 5 (esc) 10 | 125 | 115
| | | | | | 9 (35) | -4 (26)
Thiazolidinedione vs. Meglitinide
Raskin, 2004 ^74^ | (meas) mg/dL | Rosiglitazone, 29 | Repaglinide, 25 | 2 bid (esc) 4 bid | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 125 (23.5) | 124 (33.8) | 15 | NR | NR
| | | | | | 139 (34.3) | 123 (32.3)
| | | | | | 14 | -1
Jovanovic, 2004 ^73^ | (meas) mg/dL | Pioglitazone, 21 | Repaglinide, 35 | 30 (fixed) | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 106 (37) | 124 (36) | 16 | NR | NR
| | | | | | 116 (42) | 118 (38)
| | | | | | 10 | -6
Other Thiazolidinedione Comparisons
Goke, 2002 ^75^ | (meas) mg/dL | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 100 tid | 137.4 (36.1) | 141.9 (36.8) | -4 | 0.124 vs. GP2
German Pioglitazone Study Group | | | | | | 136.9 | 146.46
| | | | | | 0.5 (30.7) | 4.56 (27.6)
McCluskey, 2004 ^76^ | (calc) mg/dL | Rosiglitazone + placebo, 15 | Rosiglitazone + glimepiride, 24 | 4 or 8 (fixed) | 4 or 8 fixed | 60.9 (SE 4.4) | 58 (SE 3.3) | -0.3 | NSG vs. GP2
| | | | | 2 (esc) 8 | 60.8 | 58.2
| | | | | | -0.1 (SE 3.4) | 0.2 (SE 2.3)
Metformin vs. Second Generation Sulfonylurea
Derosa, 2004 ^90^ | (meas) mg/dL | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 144 (20) | 135 (20) | -9 | <0.05 vs. baseline
| | | | | | 130 (25) | 130 (15)
| | | | | | -14 (-42, -8^‡^) | -5 (2.8, 9.6^‡^)
Lawrence, 2004 ^54^ | (meas) mg/dL | Metformin, 20 | Gliclazide, 20 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 200.5 (42.6) | 196.6 (62.3) | 2.1 | NSG vs. baseline | NSG vs. baseline
| | | | | | 200.9 (50.5) | 194.9 (64.6)
| | | | | | 0.4 | -1.7
Garber, 2003 ^80^ | (meas) mg/dL | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 122.7 (3.2) | 122.2 (3.2) | -8 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 117 | 124.5
| | | | | | -5.7 | 2.3
Goldstein, 2003 ^82^ | (meas) mg/dL | Metformin, 67 | Glipizide | 500 (esc) 2000 | 15 bid (fixed) | 109.7 (35.2) | 111.2 (34.6) | -6.8 | NR | NR
| | | | | | 102.5 | 110.8
| | | | | | -7.2 (-15, 0.6^‡^) | -0.4 (-6.7, 5.8^‡^)
Blonde, 2002 ^81^ | NR | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 (esc) 2000 | 10 bid (fixed) | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Marre, 2002 ^84^ | (meas) mg/dL | Metformin, 104 | Glibenclamide, 103 | 500 (esc) 2000 | 5 (esc) 20 | 148.2 (SE 39) | 152.1 (SE 42.9) | -7.8 | NSG vs. GP2
| | | | | | 136.5 | 148.2
| | | | | | -11.7 (SE 31.2) | -3.9 (SE 39)
Hermann, 1991 ^159^ | (calc) mg/dL | Metformin + diet, 28 | Glibenclamide + diet, 28 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | NR | NR | -5.85 | NR | NR
| | | | | | NR | NR
| | | | | | -0.78 (SE 3.9) | 5.07 (SE 7.41)
Campbell, 1994 ^83^ | (calc) mg/dL | Metformin, 24 | Glipizide, 24 | 500 bid (esc) 3000 | 5 (esc) 30 | 4.65 (1.07) | 4.51 (1.26) | -0.55 | NSG vs. GP2
| | | | | | 4.58 (1.19) | 4.99 (1.16)
| | | | | | -0.07 | 0.48
DeFronzo, 1995 ^88^ | (calc) mg/dL | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) | 5 bid (esc) | 134 (SE 3) | 136 (SE 3) | -9 | 0.009 vs. GP2
| | | | 2500 | 10 bid | 129 (SE 3) | 141 (SE 3)
| | | | | | -6 (SE 2) | 3 (SE 2)
Hermann, 1994 ^87^ | (calc) mg/dL | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 142.74 (SE 9.75) | 153.27 (SE 5.46) | -10.53 | 0.052 vs. baseline | >0.1 vs. baseline
| | | | | | 131.82 (SE 8.97) | 157.56 (SE 5.07) | | 0.086 comparison of all study groups
| | | | | | -5.85 (SE 2.73) | 4.68 (SE 3.51)
Metformin vs. Thiazolidinedione + Metformin
Weissman, 2005 ^100^ | (calc) mg/dL | Metformin, 277 | Rosiglitazone + metformin, 268 | 1000 (esc) 2000 | 4 (esc) 8 | 105.1 (103.4, 106.8^‡^) | 106.3 (104.5, 108.2^‡^) | -15.7 | NR | NR
| | | | | 1000 (fixed) | 101.6 (99.7, 103.6^‡^) | 118.5 (116.3, 120.7^‡^)
| | | | | | -3.5 | 12.2
Bailey, 2005 ^101^ | (meas) mg/dL | Metformin, 215 | Rosiglitazone + metformin, 220 | 2500 (esc) 3000 | 4 (esc) 8 | 111.9 (109.7, 114.1^‡^) | 109.5 (107.1, 111.8^‡^) | -13.4 | NR | NR
| | | | | 2000 (fixed) | 114.9 (112.6, 117.2^‡^) | 125.9 (122.9, 128.9^‡^)
| | | | | | 3 | 16.4
Gomez-Perez, 2002 ^102^ | (calc) mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 2500 (fixed) | 116 (27.7) | 106.9 (25.7) | -15.9 (-4.73, -27^‡^) | <0.05 vs. GP2
| | | | | 4 bid (fixed) | 115 | 123.5
| | | | | | -1 (20.9) | 16.6 (24.7)
Gomez-Perez, 2002 ^102^ | (calc) mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2500 (fixed) | 116 (27.7) | 108.2 (30) | -7.1 | NSG vs. GP2
| | | | | 2 bid (fixed) | 115 | 114.3
| | | | | | -1 (20.9) | 6.1 (22.5)
Fonseca, 2000 ^103^ | (calc) mg/dL | Metformin + placebo, 104 | Rosiglitazone + metformin, 108 | 2500 (fixed) | 4 (fixed) | 118.17 (34.32) | 116.61 (30.42) | -14.04 | | <0.0001 vs. GP1
| | | | | 2500 (fixed) | 122.07 (37.83) | 134.94 (33.54)
| | | | | | 3.9 | 18.33
Fonseca, 2000 ^103^ | (calc) mg/dL | Metformin + placebo, 104 | Rosiglitazone + metformin, 102 | 2500 (fixed) | 8 (fixed) | 118.17 (34.32) | 113.49 (32.76) | -17.16 | | <0.0001 vs. GP1
| | | | | 2500 (fixed) | 122.07 (37.83) | 134.55 (40.56)
| | | | | | 3.9 | 21.06
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | (meas) mg/dL | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 122.7 (3.2) | 118.3 (3.5) | -10.2 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | 115 | 122.8
| | | | | | -5.7 | 4.5
Goldstein, 2003 ^82^ | (meas) mg/dL | Metformin, 67 | Metformin + glipizide | 500 (esc) 2000 | 500 (esc) 2000 | 109.7 (35.2) | 119.7 (29.5) | -7 | NR | NR
| | | | | 5 (esc) 20 | 102.5 | 119.5
| | | | | | -7.2 (-15, 0.6^‡^) | -0.2 (-6.7, 6.3^‡^)
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 160 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | NR | NR
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 162 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 5 (esc) 20 | NR | NR
| | | | | | NR | NR
Marre, 2002 ^84^ | (meas) mg/dL | Metformin, 104 | Metformin + glibenclamide, 101 | 500 (esc) 2000 | 500 (esc) 2000 | 148.2 (39) | 152.1 (42.9) | -3.9 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (esc) 10 | 136.5 | 144.3
| | | | | | -11.7 (31.2) | -7.8 (27.3)
Marre, 2002 ^84^ | (meas) mg/dL | Metformin, 104 | Metformin + glibenclamide, 103 | 500 (esc) 2000 | 500 (esc) 2000 | 148.2 (39) | 152.1 (35.1) | -3.9 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 5 (esc) 20 | 136.5 | 144.3
| | | | | | -11.7 (31.2) | -7.8 (27.3)
Hermann, 1994 ^87^ | (calc) mg/dL | Metformin + diet, 19 | Metformin + glyburide + diet, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 142.74 (SE 9.75) | 143.13 (SE 5.46) | -3.12 | NR | NR
| | | | | 1.75 (esc) 5.25 | 131.82 (SE 8.97) | 139.62 (SE 4.68)
| | | | | | -5.85 (SE 2.73) | -2.73 (SE 2.34)
Hermann, 1991 ^159^ | (calc) mg/dL | Metformin + diet, 28 | Metformin + glibenclamide + diet, 60 | 1000 (esc) 3000 | 3000 (fixed) | NR | NR | 7.02 | <0.05 vs. GP2
| | | | | 1.75 (esc) 14 | NR | NR
| | | | | | 0.78 (SE 3.9) | -6.24 (SE 2.34)
DeFronzo, 1995 ^88^ | (calc) mg/dL | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | 134 (SE 3) | 137 (SE 3) | 2 | NSG vs. GP2
| | | | | 10 (esc) 20 | 129 (SE 3) | 128 (SE 3)
| | | | | | -6 (SE 2) | -8 (SE 2)
Other Metformin Comparisons
Fujioka, 2003 ^105^ | (meas) mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 122 (30) | 116 (34) | 2 | NR | NR
| | | | | | 118 | 110
| | | | | | -4 (-9, 1^‡^) | -6 (-11, -1^‡^)
Fujioka, 2003 ^105^ | (meas) mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 122 (30) | 124 (33) | 2 | NR | NR
| | | | | | 118 | 118
| | | | | | -4 (-9, 1^‡^) | -6 (-11, -1^‡^)
Derosa, 2003 ^97^ | (meas) mg/dL | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 132.21 (26.13) | 127.14 (25.35) | -3.12 | <0.05 vs. baseline | 0.065 vs. baseline
| | | | | | 117 | 115.05 | | >0.05 vs. GP2
| | | | | | -15.21 (-34.32, -8.19^‡^) | -12.09 (-29.05, 20.28^‡^)
Second Generation Sulfonylurea vs. Meglitinide
Derosa, 2003 ^118^ | (calc) mg/dL | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 142 (24) | 139 (22) | 1 | NSG vs. GP2
| | | | | | 136 (25) | 132 (18)
| | | | | | -6 | -7
Vakkilainen, 2002 ^122^ | NR | Glibenclamide + placebo, 20 | Nateglinide + placebo, 23 | 5 (esc) 10 | 120 tid (fixed) | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Marbury, 1999 ^116^ | (meas) mg/dL | Glyburide (no trade drug specified) + placebo | Repaglinide | 2.5 (esc) 15 | 0.5 (esc) 12 | NR | NR | -1.48 (-6.499, 3.532^‡^) | NSG vs. GP2
| | | | | | NR | NR
| | | | | | -6.51 | -5.03
Second Generation Sulfonylurea vs. Thiazolidinedione + Second Generation Sulfonylurea
Rosenstock, 2006 ^124^ | (calc) % | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | -4.60% | NR | NR
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -1.30%^†^ | 3.30%^†^
Baksi, 2004 ^126^ | (meas) mg/dL | Gliclazide, 187 | Rosiglitazone + gliclazide, 189 | 160 (esc) 320 | 160 (fixed) | 117^#^ | 124.8^#^ | -11.7 (-14,-7.7^‡^)
| | | | | 4 bid (fixed) | 117^#^ | 136.5^#^
| | | | | | 0 | 11.7
Kerenyi, 2004 ^125^ | (meas) mg/dL | Glibenclamide + diet, 130 | Rosiglitazone + glibenclamide + diet, 132 | 7.5 (esc) 15 | 4 bid (fixed) | 123.63 | 125.19 | -19.50 | NR | NR
| | | | | 7.5 (fixed) | 115.05 | 136.11
| | | | | | -8.58 | 10.92
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | (meas) mg/dL | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 122.2 (3.2) | 118.3 (3.5) | -2.2 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | 124.5 | 122.5
| | | | | | 2.3 | 4.5
Goldstein, 2003 ^82^ | (meas) mg/dL | Glipizide | Metformin + glipizide | 30 (fixed) | 500 (esc) 2000 | 111.2 (34.6) | 119.7 (29.5) | -0.2 | NSG vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 20 | 110.8 | 119.5
| | | | | | -0.4 (-6.7, 5.8^‡^) | -0.2 (-6.7, 6.3^‡^)
Marre, 2002 ^84^ | (meas) mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 (esc) 20 | 500 (esc) 2000 | 152.1 (42.9) | 152.1 (42.9) | 3.9 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (esc) 10 | 148.2 | 144.3
| | | | | | -3.9 (39) | -7.8 (27.3)
Marre, 2002 ^84^ | (meas) mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 (esc) 20 | 500 (esc) 2000 | 152.1 (42.9) | 152.1 (35.1) | 3.9 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 5 (esc) 20 | 148.2 | 144.3
| | | | | | -3.9 (39) | -7.8 (27.3)
Hermann, 1994 ^87^ | (calc) mg/dL | Glyburide + diet, 19 | Metformin + glyburide + diet, 17 | 3.5 (esc) 10.5 | 2000 (esc) 3000 | 153.27 (SE 5.46) | 157.56 | 17.16 | | 0.019 vs. baseline
| | | | | 7.0 (esc) 14.0 | 157.56 (SE 5.07) | 144.69 (SE 7.41)
| | | | | | 4.68 (SE 3.51) | -12.48 (SE 4.68)
Hermann, 1991 ^159^ | (calc) mg/dL | Glibenclamide + diet, 28 | Metformin + glibenclamide + diet, 60 | 3.5 (esc) 14 | 500 (esc) 3000 | NR | NR | 11.31 | <0.05 vs. GP2
| | | | | 1.75 (esc) 14 | NR | NR
| | | | | | 5.07 (SE 7.41) | -6.24 (SE 2.34)
DeFronzo, 1995 ^88^ | (calc) mg/dL | Glyburide + placebo, 209 | Metformin + glyburide, 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 136 (SE 3) | 137 (SE 3) | 11 | 0.001 vs. GP2
| | | | | 10 (esc) 20 | 141 (SE 3) | 128 (SE 3)
| | | | | | 3 (SE 2) | -8 (SE 2)
Gregorio, 1999 ^129^ | (calc) mg/dL | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 169.26 (SE 4.68) | 176.28 (SE 5.46) | 10.14 | <0.05 vs. baseline
| | | | 120 (esc) 240 | NR (fixed) | 164.58 (5.46) | 161.46 (SE 4.68)
| | | | | NR (fixed) | -4.68 | -14.82
Pioglitazone vs. Placebo
Nishio, 2006 ^151^ | (meas) mg/dL | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 123.24 (30.81) | 116.22 (22.62) | -4.68 | 0.352 vs. baseline
| | | | | | 118.17 (37.44) | 115.83 (25.35) | | 0.865 between final means
| | | | | | -5.07 | -0.39
Smith, 2005 ^161^ | (meas) mg/dL | Pioglitazone + diet, 21 | Placebo + diet, 21 | 30 (esc) 45 | NA | 107.4 (32.97) | 103.51 (23.22) | 11.51 | 0.3538 vs. placebo
| | | | | | 125.69 | 110.29
| | | | | | 18.29 (26.86) | 6.78 (18.97)
Saad, 2004 ^164^ | (meas) % | Pioglitazone, 22 | Placebo, 20 | 45 (fixed) | NA | NR | NR | 11.4% | NR | NR
| | | | | | NR | NR
| | | | | | 11.60%^†^ | 0.20%^†^
Takagi, 2003 ^78^ | (calc) mg/dL | Pioglitazone, 23 | Control group (conventional antidiabetic therapy), 21 | 30 (fixed) | NR | 134 (24) | 144 (29) | 12 | 0.9813 between-group difference at f/u
| | | | | | 136 (16) | 134 (28)
| | | | | | 2 | -10
Rosenblatt, 2001 ^162^ | (calc) mg/dL | Pioglitazone, 101 | Placebo, 96 | 30 (NR) | NA | 129.87 (35.49) | 134.94 (37.05) | -.051 | NSG vs. baseline | NSG vs. baseline
| | | | | | 136.1 | 141.68
| | | | | | 4.8% (2.5%^†^*) | 5% (2.5%^†^*)
Aronoff, 2000 ^165^ | (calc) mg/dL | Pioglitazone, 67 | Placebo, 66 | 7.5 (fixed) | NA | 122.9 (4.52) | 138.8 (4.54) | 1.2 | NSG vs. GP2
| | | | | | 127.2 (3.68) | 141.9 (5.1)
| | | | | | -4.3 | -3.1
Aronoff, 2000 ^165^ | (calc) mg/dL | Pioglitazone, 64 | Placebo, 66 | 15 (fixed) | NA | 131.9 (4.64) | 138.8 (4.54) | 3.2 | NSG vs. GP2
| | | | | | 138.2 (4.52) | 141.9 (5.1)
| | | | | | -6.3 | -3.1
Aronoff, 2000 ^165^ | (calc) mg/dL | Pioglitazone, 74 | Placebo, 66 | 30 (fixed) | NA | 135.6 (4.33) | 138.8 (4.54) | 0.7 | NSG vs. GP2
| | | | | | 139.4 (5.1) | 141.9 (5.1)
| | | | | | 3.8 | 3.7
Aronoff, 2000 ^165^ | (calc) mg/dL | Pioglitazone, 65 | Placebo, 66 | 45 (fixed) | NA | 126.8 (4.6) | 138.8 (4.54) | 5.5 | NSG vs. GP2
| | | | | | 135.4 (4.43) | 141.9 (5.1)
| | | | | | -8.6 | -3.1
Kipnes, 2001 ^166^ | (calc) mg/dL | Pioglitazone + unspecified sulfonylurea, 155 | Unspecified sulfonylurea + placebo, 151 | 30 (fixed) | NR (fixed) | 127 (121, 132^‡^) | 124 (118, 130^‡^) | -4 | NSG vs. GP2
| | | | NR (fixed) | | 130 (126, 134^‡^) | 131 (127, 135^‡^)
| | | | | | 3 | 7
Kipnes, 2001 ^166^ | (calc) mg/dL | Pioglitazone + unspecified sulfonylurea, 150 | Unspecified sulfonylurea + placebo, 151 | 15 (fixed) | NR (fixed) | 124 (118, 130^‡^) | 124 (118, 130^‡^) | -3 | NSG vs. GP2
| | | | NR (fixed) | | 128 (124, 132^‡^) | 131 (127, 135^‡^)
| | | | | | 4 | 7
Einhorn, 2000 ^160^ | (calc) mg/dL | Pioglitazone + metformin + diet, 129 | Metformin + placebo + diet, 125 | 30 (fixed) | NR (NR) | 119.3 (3.07) | 118 (6.9) | 4.2% | <0.05 vs. baseline
| | | | NR (NR) | | 128.5 | 132
| | | | | | 7.7%^†^ | 11.9%^†^
Tseng, 2005 ^140^ | (meas) % | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | NR | NR | 10.1%^†^ | >0.05 vs. baseline | >0.05 vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | 12.3%^†^ | 2.20%^†^
Rosiglitazone vs. Placebo
Kim, 2005 ^152^ | (meas) mg/dL | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 121.29 (40.95) | 120.12 (32.76) | 7.41 | >0.05 vs. baseline | >0.05 vs. baseline
| | | | | | 126.36 (34.32) | 117.78 (32.37)
| | | | | | 5.07 | -2.34
Natali, 2004 ^144^ | (meas) mg/dL | Rosiglitazone | Placebo | 4 bid (fixed) | NA | 120 (SE 29) | 124 (SE 26) | 13 (-2, 20^‡^) | NSG vs. GP2
| | | | | | 131 | 121
| | | | | | 11 | -3
Virtanen, 2003 ^143^ | (meas) mg/dL | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 113.1 (SE 7.8) | 97.5 (SE 7.8) | 15.6 | <0.05 vs. placebo
| | | | | | 136.5 (SE 28) | 105.3 (SE 7.8)
| | | | | | 23.4 | 7.8
Lebovitz, 2001 ^169^ | (meas) mg/dL | Rosiglitazone, 169 | Placebo, 158 | 4 bid (fixed) | NA | 125.19 (37.05) | 122.85 (37.44) | 18.21 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 148.98 | 128.43
| | | | | | 23.79 (31.59) | 5.85 (25.35)
Lebovitz, 2001 ^169^ | (meas) mg/dL | Rosiglitazone, 166 | Placebo, 158 | 2 bid (fixed) | NA | 122.07 (34.71) | 122.85 (37.44) | 11.19 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 138.84 | 128.43
| | | | | | 16.77 (27.3) | 5.85 (25.35)
Patel, 1999 ^167^ | (calc) mg/dL | Rosiglitazone, 79 | Placebo, 74 | 2.0 bid (fixed) | NA | 125.6 | 130.2 | 15.3 (6.9, 23.8^‡^) | 0.0001 vs. GP2
| | | | | | 142.5 | 131.8
| | | | | | 16.9 (SE 2.52) | 1.6 (SE 2.6)
Patel, 1999 ^167^ | (calc) mg/dL | Rosiglitazone, 79 | Placebo, 74 | 1.0 bid (fixed) | NA | 126.3 | 130.2 | 1.7 (-6.8, 10.2^‡^) | NSG vs. GP2
| | | | | | 129.6 | 131.8
| | | | | | 3.3 (SE 2.6) | 1.6 (SE 2.6)
Patel, 1999 ^167^ | (calc) mg/dL | Rosiglitazone, 72 | Placebo, 74 | 0.25 bid (fixed) | NA | 127.8 | 130.2 | 1.4 (-7.3, 10.1^‡^) | NSG vs. GP2
| | | | | | 130.8 | 131.8
| | | | | | 3 (SE 2.69) | 1.6 (SE 2.6)
Patel, 1999 ^167^ | (calc) mg/dL | Rosiglitazone, 70 | Placebo, 74 | 0.05 bid (fixed) | NA | 121.3 | 130.2 | -0.9 (-9.6, 7.9^‡^) | NSG vs. GP2
| | | | | | 122.0 | 131.8
| | | | | | 0.7 (SE 2.73) | 1.6 (SE 2.6)
Phillips, 2001 ^168^ | (calc) mg/dL | Rosiglitazone, 146 | Placebo, 97 | 2 bid (fixed) | NA | 131.04^#^ | 127.92^#^ | 7.4%^¶¶^ (1.7%, 13.6%^‡^) | <0.05 vs. GP2
| | | | | | 145.08^#^ | 125.19^#^
| | | | | | 9.5%^¶^ (6.2%, 13.3%^‡^) | 1.7% (1.6%, 4.9%^‡^)
Phillips, 2001 ^168^ | (calc) mg/dL | Rosiglitazone, 128 | Placebo, 97 | 4 od (fixed) | NA | 125.97^#^ | 127.92^#^ | 8.7%^¶¶^ (2.8%, 14.7%^‡^) | <0.05 vs. GP2
| | | | | | 140.4^#^ | 125.19^#^
| | | | | | 10.6%^¶^ (7.1%, 14.4%^‡^) | 1.7% (1.6%, 4.9%^‡^)
Phillips, 2001 ^168^ | (calc) mg/dL | Rosiglitazone, 113 | Placebo, 97 | 8 od (fixed) | NA | 130.26^#^ | 127.92^#^ | 16.5%^¶^ (8.3%, 24.7%^‡^) | <0.05 vs. GP2
| | | | | | 151.32^#^ | 125.19^#^
| | | | | | 18.3%^¶^ (12.6%, 24.2%^‡^) | 1.7% (1.6%, 4.9%^‡^)
Phillips, 2001 ^168^ | (calc) mg/dL | Rosiglitazone, 128 | Placebo, 97 | 4 bid (fixed) | NA | 125.97^#^ | 127.92^#^ | 12.2%^¶^ (5.7%, 18.8%^‡^) | <0.05 vs. GP2
| | | | | | 141.18^#^ | 125.19^#^
| | | | | | 14.3%^¶^ (10.3%, 18.6%^‡^) | 1.7% (1.6%, 4.9%^‡^)
Vongthavaravat, 2002 ^170^ | (calc) mg/dL | Rosiglitazone + unspecified sulfonylurea + diet, 164 | Unspecified sulfonylurea + diet, 170 | 2 bid (fixed) | NR | 130 (SE 3.3) | 130 (SE 3) | 10 | NR | NR
| | | | | | 135 (SE 3.9) | 125 (SE 2.4)
| | | | | | 5 | -5
Wolffenbuttel, 2000 ^171^ | (calc) mg/dL | Rosiglitazone + unspecified sulfonylurea, 183 | Unspecified sulfonylurea + placebo, 192 | 2 bid (fixed) | NR (fixed) | 140.4 (31.2) | 140.4 (31.2) | 7.8 | 0.0006 vs. baseline | 0.9664 vs. baseline
| | | | NR (fixed) | | 148.2 (39) | 140.4 (31.2) | | | 0.0030 vs. GP1
| | | | | | 7.8 | 0
Wolffenbuttel, 2000 ^171^ | (calc) mg/dL | Rosiglitazone + unspecified sulfonylurea, 199 | Unspecified sulfonylurea + placebo, 192 | 1 bid (fixed) | NR (fixed) | 132.6 (35.1) | 140.4 (31.2) | 3.9 | 0.1747 vs. baseline | 0.9664 vs. baseline
| | | | NR (fixed) | | 136.5 (35.1) | 140.4 (31.2) | | 0.7921 vs. GP2
| | | | | | 3.9 | 0
Barnett, 2003 ^172^ | NR | Rosiglitazone + unspecified sulfonylurea, 84 | Unspecified sulfonylurea + placebo, 87 | 4 bid (fixed) | NR (NR) | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | NR | NR
Metformin vs. Placebo
Natali, 2004 ^144^ | (meas) mg/dL | Metformin | Placebo | 500 tid (fixed) | NA | 118 (SE 29) | 124 (SE 26) | 5 | NR | NR
| | | | | | 120 | 121
| | | | | | 2 (SE 6) | -3 (SE 2)
Virtanen, 2003 ^143^ | (meas) mg/dL | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 109.2 (SE 7.8) | 97.5 (SE 7.8) | -15.6 | >0.05 vs. GP2
| | | | | | 101.4 (SE 7.8) | 105.3 (SE 7.8)
| | | | | | -7.8 | 7.8
Rachmani, 2002 ^150^ | (meas) mg/dL | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR | NA | 139.62 (SE 7.8) | 140.4 (SE 3.9) | -3.9 | NSG vs. baseline
| | | | | | 138.84 | 143.52 | | NSG vs. GP2
| | | | | | -0.78 | 3.12
DeFronzo, 1995 ^88^ | (calc) mg/dL | Metformin, 143 | Placebo, 146 | 850 (esc) 850 tid | NA | 136 (SE 3) | 138 (SE 3) | -9 | 0.019 vs. GP2
| | | | | | 123 (SE 3) | 135 (SE 3)
| | | | | | -11 (SE 3) | -2 (SE 2)
Second Generation Sulfonylurea vs. Placebo
Rosenstock, 1996 ^189^ | NR | Glimepiride | Placebo, 66 | 4 bid (fixed) or 8 od (fixed) or 16 od (fixed) or 8 bid (fixed) | NA | NR | NR | NR | 0.018 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Repaglinide vs. Placebo
Goldberg, 1998 ^139^ | (meas) mg/dL | Repaglinide, 56 | Placebo, 23 | 0.25 tid (esc) 8.0 | NA | NR | NR | 1.326 | 0.718 vs. GP2
| | | | | | NR | NR
| | | | | | 15.21 | 11.7
Alpha-Glucosidase Inhibitor vs. Placebo
Hasche, 1999 ^138^ | (calc) mg/dL | Acarbose + diet, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 159.7 (31.2) | 170 (31.9) | -1.7 | NR | NR
| | | | | | 151.6 (30.5) | 163.6 (38.2)
| | | | | | -8.1 | -6.4
Rosenbaum, 2002 ^153^ | (calc) mg/dL | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 300.3 (66.3) | 327.6 (97.5) | -3.9 | 0.34 vs. baseline | 0.47 vs. baseline
| | | | | | 288.6 (66.3) | 319.8 (54.6)
| | | | | | -11.7 | -7.8
Other Second Generation Sulfonylurea Comparisons
Schernthaner, 2004 ^106^ | (calc) mg/dL | Glimepiride + existing medications + diet, 440 | Gliclazide + existing medications + diet, 405 | 1 (esc) 6 | 30 (esc) 120 | 124.8 | 128.7 | 3.9 | NSG vs. baseline | NSG vs. baseline
| | | | | | 124.8 | 124.8
| | | | | | 0 | -3.9

Calc = calculated; Meas = measured; Comp = comparison; BL = baseline; GP = group; mg = milligrams; dL = deciliter; max = maximum; esc = escalated; diff = difference; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; od = once daily; bid = twice daily; tid = three times daily; HbA1c = hemoglobin A1c; f/u = follow-up; XR = extended release; vs = versus

* Number obtained from a figure

† Percent change from baseline

‡ 95% confidence interval

# Median

¶ Median percent change from baseline

¶¶ Median percent difference from placebo

Table 12 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: high density lipoprotein

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2 | Other
Study group | | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Khan, 2002 ^51^ | mg/dL | Rosiglitazone, 60 | Pioglitazone, 67 | 2–8 (fixed) | 15–45 (fixed) | 45.3 (15.2) | 44.7 (15.6) | -0.5 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 48.6 | 46.7
| | | | | | 1.5* | 2.0*
Goldberg, 2005 ^52^ | mg/dL | Rosiglitazone + diet, 356 | Pioglitazone + diet, 363 | 4 (esc) 8 | 30 (esc) 45 | 39.8 (SE 0.6) | 38.8 (SE 0.5) | -2.8 | <0.001 vs. GP2
| | | | | | 42.2 | 44
| | | | | | 2.4 (SE 0.5) | 5.2 (SE 0.5)
Derosa, 2005 ^156^ | mg/dL | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 42 (5) | 40 (4) | -5 | NSG vs. baseline | <0.05 vs. baseline and vs. GP1
| | | | 4 (fixed) | 4 (fixed) | 43 (4) | 46 (5)
| | | | | | 1 | 6
Thiazolidinedione vs. Metformin
Natali, 2004 ^144^ | mg/dL | Rosiglitazone | Metformin | 4 bid (fixed) | 500 tid (fixed) | 46 (SEM 9) | 46 (SEM 15) | 0.4 (-5, 6^‡^) | NSG vs. GP2
| | | | | | 50 | 49
| | | | | | 4 | 3
Virtanen, 2003 ^143^ | mg/dL | Rosiglitazone + diet | Metformin + diet | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 42.9 (SE 3.9) | 42.9 (SE 3.9) | 0 | NSG vs. baseline | NSG vs. baseline
| | | | | | 46.8 (SE 3.9) | 46.8 (SE 3.9)
| | | | | | 3.9 | 3.9
Lawrence, 2004 ^54^ | mg/dL | Pioglitazone, 20 | Metformin, 20 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 49.6 (11.8) | 48.7 (9.4) | 5 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 52.7 (11.1) | 46.8 (8.5) | | 0.026 vs. GP2
| | | | | | 3.1 | -1.9
Pavo, 2003 ^59^ | mg/dL | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | NR | NR | 3.51 | 0.02 vs. GP2
| | | | | | NR | NR
| | | | | | 8.58 | 5.07
Ramachandran, 2004 ^55^ | mg/dL | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 38.22 (5.85) | 39 (7.8) | 0.78 | <0.01 vs. baseline
| | | | | | 42.9 (7.8) | 42.9 (11.7)
| | | | | | 4.68 | 3.9
Schernthaner, 2004 ^56^ | mg/dL | Pioglitazone + placebo + diet | Metformin + placebo + diet | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | 44.07 | 44.07 | 3.12 | 0.001 vs. GP2
| | | | | | 50.31 | 47.19
| | | | | | 6.24 | 3.12
Yamanouchi, 2005 ^57^ | mg/dL | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 53.82 (4.68) | 51.87 (3.51) | 4.68 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 58.11 (3.51) | 51.48 (4.68)
| | | | | | 4.29 | -0.39
Hanefeld, 2004 ^60^ | mg/dL | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 42.51 (9.36) | 43.29 (10.53) | 3.12 | <0.0001 vs. GP2
QUARTET study group | | | | NR | NR | 48.75 (0.39) | 46.41 (0.39)
Betteridge, 2005 ^157^ | | | | | | 6.24 | 3.12
Thiazolidinedione vs. Second Generation Sulfonylurea
Pfutzner, 2005 ^68^ | mg/dL | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 46 (11) | 46 (14) | 7 | 0.001 vs. GP2
Forst, 2005 ^145^ | | | | | | 54 (13) | 47 (12)
Langenfeld, 2005 ^146^ | | | | | | 8 | 1
Tan, 2004 ^65^ | mg/dL | Pioglitazone, 91 | Glibenclamide, 109 | 30 (esc) 45 | 1.75 (esc) 10.5 | 46.02 | 43.68 | 7.02 | <0.001 vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 54.21 | 44.85
| | | | | | 8.19 | 1.17
Charbonnel, 2005 ^63^ | mg/dL | Pioglitazone | Gliclazide | NR (esc) 45 | NR (esc) 320 | 40.17 | 40.56 | 6.24 (5.07, 6.63^‡^) | <0.001 vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 48.75 | 42.9
| | | | | | 8.58 | 2.34
Lawrence, 2004 ^54^ | mg/dL | Pioglitazone, 20 | Gliclazide, 20 | 30 (esc) 45 | 80 od (esc) 160 bid | 49.6 (11.8) | 49.5 (9.8) | 4.3 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 52.7 (11.1) | 48.3 (10.1)
| | | | | | 3.1 | -1.2
Yanagawa, 2004 ^62^ | mg/dL | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | 57 (13) | 50 (14) | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Ramachandran, 2004 ^55^ | mg/dL | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 38.22 (5.85) | 37.05 (11.7) | -1.17 | <0.01 vs. baseline | NSG vs. baseline
| | | | | | 42.9 (7.8) | 42.9 (7.8)
| | | | | | 4.68 | 5.85
Yamanouchi, 2005 ^57^ | mg/dL | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 53.82 (4.68) | 52.65 (4.29) | 4.68 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 58.11 (3.51) | 52.26 (4.29)
| | | | | | 4.29 | -0.39
Betteridge, 2005 ^157^ | mg/dL | Pioglitazone + metformin, 317 | Metformin + gliclazide, 313 | 15 (esc) 45 | 80 (esc) 320 | 42.9 (9.75) | 42.51 (8.97) | 6.54 | NR | NR
| | | | NR | NR | 52.65 | 45.72
| | | | | | 9.75 (SEM 0.30) | 3.21 (SEM 0.39)
Thiazolidinedione + Metformin vs. Second Generation Sulfonylurea + Metformin
Garber, 2006 ^71^ | mg/dL | Rosiglitazone + metformin + diet, 117 | Metformin + glibenclamide + diet, 122 | 4 (esc) 8 | 1000 (esc) 2000 | 45 | 47 | 4 (1, 7^‡^) | <0.05 vs. GP2
| | | | 1500–2000 (esc) 2000 | 5 (esc) 10 | 48 | 45
| | | | | | 3 (10) | -2 (10)
Derosa, 2005 ^158^ | mg/dL | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 42 (4) | 43 (5) | 2 | NSG vs. GP2
| | | | 1500 (fixed) | 2 (fixed) | 44 (3) | 43 (4)
| | | | | | 2 | 0
Thiazolidinedione vs. Meglitinide
Raskin, 2004 ^74^ | mg/dL | Rosiglitazone, 37 | Repaglinide, 37 | 2 bid (esc) 4 bid | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 39.9 (10.6) | 39.2 (10.5) | 1.3 | NR | NR
| | | | | | 42.5 (11.3) | 40.5 (11.5)
| | | | | | 2.6 | 1.3
Jovanovic, 2004 ^73^ | mg/dL | Pioglitazone, 26 | Repaglinide, 35 | 30 (fixed) | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 41 (8.8) | 45.4 (12.5) | 7 | NR | NR
| | | | | | 47.2 (9.4) | 44.6 (11.8)
| | | | | | 6.2 | -0.8
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Goke, 2002 ^75^ | mg/dL | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 100 tid | 41.4 (12.8) | 43.5 (27.9) | 8.6 | <0.001 vs. GP2
German Pioglitazone Study Group | | | | | | 49.2 | 42.7
| | | | | | 7.8 | -0.8
Other Thiazolidinedione Comparisons
Choi, 2004 ^77^ | mg/dL | Rosiglitazone + diet, 38 | Uptitration of existing medications, 45 | 8 (other) 4 | NR (esc) | 39.39 (10.92) | 41.34 (10.92) | 1.17 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 43.68 (8.19) | 44.46 (10.53) | | NSG vs. GP2
| | | | | | 4.29 (8.19) | 3.12 (8.58)
Metformin vs. Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 42.3 (0.9) | 41.6 (1) | -0.9 | NSG vs. baseline | NSG vs. baseline
| | | | | | 41.9 | 42.1
| | | | | | -0.4 | 0.5
Goldstein, 2003 ^82^ | mg/dL | Metformin, 67 | Glipizide | 500 (esc) 2000 | 15 bid (fixed) | 42.3 (9.7) | 43.5 (9.8) | 0 | NSG vs. baseline | NSG vs. baseline
| | | | | | 42.7 | 43.9
| | | | | | 0.4 | 0.4
Campbell, 1994 ^83^ | mg/dL | Metformin, 24 | Glipizide, 24 | 500 bid (esc) 3000 | 5 (esc) 30 | 35.88 (11.31) | 36.27 (8.58) | 1.17 | NSG vs. GP2
| | | | | | 37.05 (11.31) | 36.27 (8.58)
| | | | | | 1.17 | 0
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Glibenclamide, 103 | 500 (esc) 2000 | 5 (esc) 20 | 46.8 (11.7) | 46.8 (11.7) | 0.78 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 47.97 | 47.19
| | | | | | 1.17 | 0.39
Amador-Licona, 2000 ^85^ | mg/dL | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 31.98 (8.97) | 36.66 (7.02) | 1.17 | 0.0001 vs. baseline | 0.01 vs. baseline
| | | | | | 35.49 (8.97) | 39 (10.92)
| | | | | | 3.51 | 2.34
Lawrence, 2004 ^54^ | mg/dL | Metformin, 20 | Gliclazide, 20 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 48.7 (9.4) | 49.5 (9.8) | -0.7 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 46.8 (8.5) | 48.3 (10.1)
| | | | | | -1.9 | -1.2
Ramachandran, 2004 ^55^ | mg/dL | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 39 (7.8) | 37.05 (11.7) | -1.95 | NSG vs. baseline | NSG vs. baseline
| | | | | | 42.9 (11.7) | 42.9 (7.8)
| | | | | | 3.9 | 5.85
Hermann, 1994 ^87^ | mg/dL | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 31.59 (SE 2.34) | 34.71 (SE 1.95) | -0.39 | >0.1 vs. baseline and vs. GP2 | >0.1 vs. baseline
| | | | | | 30.03 (SE 1.56) | 35.88 (SE 1.95)
| | | | | | 0.78 (SE 0.78) | 1.17 (SE 0.78)
DeFronzo, 1995 ^88^ | mg/dL | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) | 5 bid (esc) | 37 (SE 1) | 37 (SE 1) | 1 | NR | NR
| | | | 2500 | 10 bid | 39 (SE 1) | 38 (SE 1)
| | | | | | 2 | 1
Charpentier, 2001 ^89^ | mg/dL | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 46.41 (13.65) | 45.24 (12.87) | 1.56 | NR | NR | 0.14 all group comparison
| | | | | | 48.36 | 45.63
| | | | | | 1.95 | 0.39
Yamanouchi, 2005 ^57^ | mg/dL | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 51.87 (3.51) | 52.65 (4.29) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 51.48 (4.68) | 52.26 (4.29)
| | | | | | -0.39 | -0.39
Derosa, 2004 ^90^ | mg/dL | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) | 1 (esc) 2 bid | 43 (5) | 42 (4) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | 1000 tid | | 45 (4) | 44 (6)
| | | | | | 2 | 2
Blonde, 2002 ^81^ | NR | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 (esc) 2000 | 10 bid (fixed) | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Metformin vs. Thiazolidinedione + Metformin
Weissman, 2005 ^100^ | mg/dL | Metformin, 302 | Rosiglitazone + metformin, 309 | 1000 (esc) 2000 | 4 (esc) 8 | 43.7 | 45 | -2.5 | NR | NR
| | | | | 1000 (fixed) | 45.3 | 49.1
| | | | | | 1.6 | 4.1
Bailey, 2005 ^101^ | mg/dL | Metformin, 230 | Rosiglitazone + metformin, 245 | 2500 (esc) 3000 | 4 (esc) 8 | 47.2 | 45.3 | -2.6 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | 2000 (fixed) | 46.4 | 47.1
| | | | | | -0.8 | 1.8
Fonseca, 2000 ^103^ | mg/dL | Metformin + placebo, 112 | Rosiglitazone + metformin, 110 | 2500 (fixed) | 8 (fixed) | 44.46 (10.92) | 46.8 (14.43) | -3.9 | | 0.0002 vs. GP1
| | | | | 2500 (fixed) | 46.8 (11.31) | 53.04 (16.38)
| | | | | | 2.34 | 6.24
Fonseca, 2000 ^103^ | mg/dL | Metformin + placebo, 112 | Rosiglitazone + metformin, 116 | 2500 (fixed) | 4 (fixed) | 44.4 (10.92) | 46.02 (11.31) | -3.06 | | 0.0002 vs. GP1
| | | | | 2500 (fixed) | 46.8 (11.31) | 51.48 (13.26)
| | | | | | 2.4 | 5.46
Gomez-Perez, 2002 ^102^ | mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2500 (fixed) | 49.4 (11.9) | 51.5 (10) | -5.7 | | <0.05 vs. GP1
| | | | | 2 bid (fixed) | 48.9 | 56.7
| | | | | | -0.5 (7.2) | 5.2 (7)
Gomez-Perez, 2002 ^102^ | mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 2500 (fixed) | 49.4 (11.9) | 51.5 (10.9) | -6.9 | | <0.05 vs. GP1
| | | | | 4 bid (fixed) | 48.9 | 57.9
| | | | | | -0.5 (7.2) | 6.4 (7)
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 42.3 (0.9) | 41.3 (0.9) | -1.2 | NSG vs. baseline | NSG vs. baseline
| | | | | 1.25 (esc) 5 | 41.9 | 42.1
| | | | | | -0.4 | 0.8
Goldstein, 2003 ^82^ | mg/dL | Metformin, 67 | Metformin + glipizide | 500 (esc) 2000 | 500 (esc) 2000 | 42.3 (9.7) | 43.2 (10.0) | -0.5 | NSG vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 20 | 42.7 | 44.1
| | | | | | 0.4 | 0.9
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Metformin + glibenclamide, 103 | 500 (esc) 2000 | 500 (esc) 2000 | 46.8 (11.7) | 50.7 (11.7) | 1.17 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 5 (esc) 20 | 58.5 | 50.7
| | | | | | 1.17 | 0
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Metformin + glibenclamide, 101 | 500 (esc) 2000 | 500 (esc) 2000 | 46.8 (11.7) | 46.8 (15.6) | 0.78 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (esc) 10 | 47.97 | 47.19
| | | | | | 1.17 | 0.39
Hermann, 1994 ^87^ | mg/dL | Metformin + diet, 19 | Metformin + glyburide, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 31.59 (SE 2.34) | 35.49 (SE 1.56) | -0.78 | >0.1 vs. baseline and vs. GP2 | >0.1 vs. baseline
| | | | | 1.75 (esc) 5.25 | 30.03 (SE 1.56) | 37.05 (SE 1.95)
| | | | | | 0.78 (SE 0.78) | 1.56 (SE 1.17)
DeFronzo, 1995 ^88^ | mg/dL | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | 37 (SE 1) | 39 (SE 1) | 1 | NR | NR
| | | | | 10 (esc) 20 | 39 (SE 1) | 40 (SE 1)
| | | | | | 2 | 1
Charpentier, 2001 ^89^ | mg/dL | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 46.41 (13.65) | 46.41 (12.09) | 3.12 | NR | NR | 0.14 all group comparison
| | | | | 1 (esc) 6 | 60.06 | 45.24
| | | | | | 0.24 (9.36) | -1.17 (9.87)
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 160 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | NR | NR
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 162 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 5 (esc) 20 | NR | NR
| | | | | | NR | NR
Feinglos, 2005 ^104^ | NR | Metformin + placebo, 56 | Metformin + glipizide, 56 | at least 1000 (fixed) | at least 1000 (fixed) | NR | NR | NR | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (fixed) | NR | NR
| | | | | | NR | NR
Other Metformin Comparisons
Derosa, 2003 ^97^ | mg/dL | metformin + diet + exercise, 56 | repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 46.41 (8.19) | 42.51 (7.02) | -4.29 | NSG vs. GP2
| | | | | | 45.24 | 45.63
| | | | | | -1.17 | 3.12
Fujioka, 2003 ^105^ | mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 42 (9) | 45 (11) | 4 | NSG vs. baseline | NSG vs. baseline
| | | | | | 44 | 43
| | | | | | 2 | -2
Fujioka, 2003 ^105^ | mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 42 (9) | 42 (10) | 2 | NSG vs. baseline | NSG vs. baseline
| | | | | | 44 | 42
| | | | | | 2 | 0
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Inukai, 2005 ^111^ | mg/dL | Glimepiride, 120 | Glibenclamide or gliclazide, 52 | 1 or 2 (esc) 6 | 2.5 (fixed) | 53.3 (13.6) | 52.3 (15.5) | -0.9 | NSG vs. GP2
| | | | | 40 (fixed) | 52.3 (12.9) | 52.2 (14)
| | | | | | -1 | -0.1
Baba, 1983 ^133^ | mg/dL | Glibenclamide, 131 | Gliclazide, 146 | 2.5 (esc) 10 | 40 (esc) 160 | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NRNR | NR
Second Generation Sulfonylurea vs. Meglitinide
Wolffenbuttel, 1999 ^117^ | mg/dL | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 45.63 (12.48) | 44.85 (14.82) | -1.17 | NSG vs. baseline | NSG vs. baseline
| | | | | | 45.63 (12.48) | 46.02 (14.43)
| | | | | | 0 | 1.17
Marbury, 1999 ^116^ | mg/dL | Glyburide (no trade drug specified) + placebo, 216 | Repaglinide, 115 | 2.5 (esc) 15 | 0.5 (esc) 12 | NR | NR | 0.68 (-0.8, 2.15^‡^) | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | NR | NR
| | | | | | -0.13 | -0.81
Derosa, 2003 ^118^ | mg/dL | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 44 (5) | 43 (7) | -3 | NSG vs. GP2
| | | | | | 43 (6) | 45 (7)
| | | | | | -1 | 2
Madsbad, 2001 ^119^ | mg/dL | Glipizide + placebo, 81 | Repaglinide, 175 | 5 (esc) 15 | 0.5 (esc) 4 | NR | NR | 1.17 (1.56, -3.5^‡^) | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | NR | NR
| | | | | | 0.78 | 0
Landgraf, 1999 ^121^ | mg/dL | Glibenclamide + placebo | Repaglinide | 1.75, 3.5, 7.0, or 10.5 (esc) 10.5 | 0.5, 1.0, 2.0, or 4.0 tid (esc) 4 tid | NR | NR | -0.04 | | 0.005 vs. GP1
| | | | | | NR | NR
| | | | | | 1.11^‖^ (SE 0.03) | 1.15 (SE 0.03)
Vakkilainen, 2002 ^122^ | NR | Glibenclamide + placebo, 20 | Nateglinide + placebo, 23 | 5 (esc) 10 | 120 tid (fixed) | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Thiazolidinedione + Second Generation Sulfonylurea
Kerenyi, 2004 ^125^ | mg/dL | Glibenclamide + diet, 138 | Rosiglitazone + glibenclamide + diet, 143 | 7.5 (esc) 15 | 4 bid (fixed) | 46.02 | 47.19 | 0 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | 7.5 (fixed) | 53.04 | 54.21 | | NSG vs. GP2
| | | | | | 7.02 | 7.02
Baksi, 2004 ^126^ | mg/dL | Gliclazide, 201 | Rosiglitazone + gliclazide, 204 | 160 (esc) 320 | 160 (fixed) | 46.8^#^ | 50.7^#^ | 6.8%^¶^ | <0.05 vs. baseline | NSG vs. baseline
| | | | | 4 bid (fixed) | 50.7^#^ | 50.7^#^
| | | | | | 6.8^†^ | 0^†^
Rosenstock, 2006 ^124^ | % | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | -1.10% | NR | NR
| | | | | 10 (esc) 20 | NR | NR
| | | | | | 1.6^†^ | 2.7^†^
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 41.6 (1) | 41.3 (0.9) | -0.3 | NSG vs. baseline | NSG vs. baseline
| | | | | 1.25 (esc) 5 | 42.1 | 42.1
| | | | | | 0.5 | 0.8
DeFronzo, 1995 ^88^ | mg/dL | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 37 (SE 1) | 39 (SE 1) | 0 | NR | NR
| | | | | 10 (esc) 20 | 38 (SE 1) | 40 (SE 1)
| | | | | | 1 | 1
Charpentier, 2001 ^89^ | mg/dL | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 45.24 (12.87) | 46.41 (12.09) | 1.56 | NR | NR | 0.14 all group comparison
| | | | | 1 (esc) 6 | 45.63 | 45.24
| | | | | | 0.39 | -1.17
Goldstein, 2003 ^82^ | mg/dL | Glipizide | Metformin + glipizide | 30 (fixed) | 500 (esc) 2000 | 43.5 (9.8) | 43.2 (10) | -0.5 | NSG vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 20 | 43.9 | 44.1
| | | | | | 0.4 | 0.9
Marre, 2002 ^84^ | mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 (esc) 20 | 500 (esc) 2000 | 46.8 (11.7) | 50.7 (11.7) | 0.39 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 5 (esc) 20 | 47.19 | 50.7
| | | | | | 0.39 | 0
Marre, 2002 ^84^ | mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 (esc) 20 | 500 (esc) 2000 | 46.8 (11.7) | 46.8 (15.6) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (esc) 10 | 47.19 | 47.19
| | | | | | 0.39 | 0.39
Hermann, 1994 ^87^ | mg/dL | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 34.71 (SE 1.95) | 35.49 (SE 1.56) | -0.39 | >0.1 vs. baseline and vs. GP2 | >0.1 vs. baseline and vs. GP2
| | | | | 1.75 (esc) 5.25 | 35.88 (SE 1.95) | 37.05 (SE 1.95)
| | | | | | 1.17 (SE 0.78) | 1.56 (SE 1.17)
Gregorio, 1999 ^129^ | mg/dL | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 38.22 (SE 1.56) | 36.66 (SE 1.95) | 3.9 | <0.02 vs. baseline
| | | | 120 (esc) 240 | NR (fixed) | 42.9 (SE 1.17) | 37.44 (SE 1.17)
| | | | | NR (fixed) | 4.68 | 0.78
Blonde, 2002 ^81^ | NR | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 160 | 10 bid (fixed) | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | NR | NR
Blonde, 2002 ^81^ | NR | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 162 | 10 bid (fixed) | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 5 (esc) 20 | NR | NR
| | | | | | NR | NR
Pioglitazone vs. Placebo
Rosenblatt, 2001 ^162^ | mg/dL | Pioglitazone, 101 | Placebo, 96 | 30 (NR) | NA | 40.17 (10.53) | 39.78 (10.92) | 12.8^†^ | 0.0065 vs. GP2
| | | | | | 46.5 | 40.07
| | | | | | 15.8^†^ | 3^†^
Herz, 2003 ^163^ | mg/dL | Pioglitazone, 95 | Placebo, 96 | 30 (fixed) | NA | 44.46 | 46.8 | 7^†^ | 0.028 vs. GP2
| | | | | | 51.8 | 51.0
| | | | | | 16^†^ | 9^†^
Herz, 2003 ^163^ | mg/dL | Pioglitazone, 96 | Placebo, 96 | 45 (fixed) | NA | 44.07 | 46.8 | 11^†^ | <0.001 vs. GP2
| | | | | | 52.9 | 51.0
| | | | | | 20^†^ | 9^†^
Saad, 2004 ^164^ | % | Pioglitazone, 26 | Placebo, 29 | 45 (fixed) | NA | NR | NR | 12.4^†^ | NSG vs. GP2
| | | | | | NR | NR
| | | | | | 15.1^†^ | 2.7^†^
Nishio, 2006 ^151^ | mg/dL | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 44.07 (11.7) | 42.12 (10.92) | -1.95 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 42.51 (12.09) | 42.51 (11.7)
| | | | | | -1.56 | 0.39
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 79 | Placebo, 79 | 7.5 (fixed) | NA | 40.5 (SE 1.24) | 41.7 (SE 1.24) | 0.3 | <=0.05 vs. baseline | <=0.05 vs. baseline
| | | | | | 43.4 (SE 1.31) | 44.3 (SE 1.25)
| | | | | | 2.9 | 2.6 (SE 2.03)
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 77 | Placebo, 79 | 45 (fixed) | NA | 40.7 (SE 1.25) | 41.7 (SE 1.24) | 4.5 | <=0.05 vs. baseline and GP2 | <=0.05 vs. baseline
| | | | | | 47.8 (SE 1.56) | 44.3 (SE 1.25)
| | | | | | 7.1 | 2.6 (SE 2.03)
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 79 | Placebo, 79 | 15 (fixed) | NA | 40.4 (SE 1.24) | 41.7 (SE 1.24) | 2.4 | <=0.05 vs. baseline | <=0.05 vs. baseline
| | | | | | 45.4 (SE 1.19) | 44.3 (SE 1.25)
| | | | | | 5 | 2.6 (SE 2.03)
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 83 | Placebo, 79 | 30 (fixed) | NA | 40.8 (SE 1.21) | 41.7 (SE 1.24) | 1.6 | <=0.05 vs. baseline | <=0.05 vs. baseline
| | | | | | 45 (SE 1.25) | 44.3 (SE 1.25)
| | | | | | 4.2 | 2.6 (SE 2.03)
Smith, 2005 ^161^ | mg/dL | Pioglitazone + diet, 21 | Placebo + diet, 21 | 30 (esc) 45 | NA | 47.45 (14.34) | 46.9 (10.05) | 6.33 | 0.0003 vs. GP2
| | | | | | 55.22 | 48.34
| | | | | | 7.77(5.22) | 1.44 (3.77)
Einhorn, 2000 ^160^ | mg/dL | Pioglitazone + metformin + diet, 158 | Metformin + placebo + diet, 143 | 30 (fixed) | NR (NR) | 42.9 (0.95) | 42.1 (1) | 8.7 | <=0.05 vs. GP2
| | | | NR (NR) | | 53.1 | 43.6
| | | | | | 10.2 | 1.5
Tseng, 2005 ^140^ | % | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | NR | NR | 18.3^†^ | <0.01 vs. baseline | NSG vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | 15.5^†^ | -2.8^†^
Kipnes, 2001 ^166^ | mg/dL | Pioglitazone + unspecified, 171 | Unspecified sulfonylurea + placebo, 175 | 15 (fixed) | NR (fixed) | 41 | 43 | 5 | <0.05 vs. GP2
| | | | NR (fixed) | | 44 | 41
| | | | | | 3 | -2
Kipnes, 2001 ^166^ | mg/dL | Pioglitazone + unspecified sulfonylurea, 179 | Unspecified sulfonylurea + placebo, 175 | 30 (fixed) | NR (fixed) | 42 | 43 | 6 | <0.05 vs. GP2
| | | | NR (fixed) | | 46 | 41
| | | | | | 4 | -2
Rosiglitazone vs. Placebo
Natali, 2004 ^144^ | mg/dL | Rosiglitazone | Placebo | 4 bid (fixed) | NA | 46 (SEM 9) | 45 (SEM 12) | 3 (-4, 9^‡^) | NSG vs. GP2
| | | | | | 50 | 46
| | | | | | 4 (3) | 1 (1)
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 72 | Placebo, 74 | 0.25 bid (fixed) | NA | 48.5 | 47.6 | -0.9 | NSG vs. GP2
| | | | | | 49.7 | 49.7 | (-3.5, 1.7^‡^)
| | | | | | 1.2 (SE 0.80) | 2.1 (SE 0.79)
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 79 | Placebo, 74 | 1.0 bid (fixed) | NA | 48.4 | 47.6 | -0.3 | NSG vs. GP2
| | | | | | 50.3 | 49.7 | (-2.8, 2.3^‡^)
| | | | | | 1.9 (SE 0.77) | 2.1 (SE 0.79)
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 79 | Placebo, 74 | 2.0 bid (fixed) | NA | 48 | 47.6 | 3.5 (0.9, 6.0^‡^) | 0.0009 vs. GP2
| | | | | | 53.6 | 49.7
| | | | | | 5.6 (SE 0.76) | 2.1 (SE 0.79)
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 70 | Placebo, 74 | 0.05 bid (fixed) | NA | 47.1 | 47.6 | -2.3 | NSG vs. GP2
| | | | | | 47.1 | 49.7 | (-4.9, 0.4^‡^)
| | | | | | -0.1 (SE 0.82) | 2.1 (SE 0.79)
Virtanen, 2003 ^143^ | mg/dL | Rosiglitazone + diet | Placebo + diet | 2 bid (esc) 8 bid | NA | 42.9 (SE 3.9) | 46.8 (SE 3.9) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 46.8 (SE 3.9) | 46.02 (SE 3.9)
| | | | | | 3.9 | 3.9
Kim, 2005 ^152^ | mg/dL | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 44.85 (9.36) | 46.41 (10.53) | 1.17 | NSG vs. baseline | NSG vs. baseline
| | | | | | 45.63 (10.14) | 46.02 (11.31)
| | | | | | 0.78 | -0.39
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 156 | Placebo, 110 | 2 bid (fixed) | NA | 46.41^#^ | 42.51^#^ | -1.17 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 50.31^#^ | 47.58^#^
| | | | | | 3.9 | 5.07
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 140 | Placebo, 110 | 8 od (fixed) | NA | 43.29^#^ | 42.51^#^ | -0.78 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 47.58^#^ | 47.58^#^
| | | | | | 4.29 | 5.07
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 143 | Placebo, 110 | 4 bid (fixed) | NA | 42.51^#^ | 42.51^#^ | 0.78 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 48.36^#^ | 47.58^#^
| | | | | | 5.85 | 5.07
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 169 | Placebo, 110 | 4 od (fixed) | NA | 44.46^#^ | 42.51^#^ | -1.17 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 48.36^#^ | 47.58^#^
| | | | | | 3.9 | 5.07
Lebovitz, 2001 ^169^ | mg/dL | Rosiglitazone, 169 | Placebo, 158 | 4 bid (fixed) | NA | 42.51 (10.14) | 43.29 (13.26) | 1.95 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 46.79 | 45.63
| | | | | | 4.29 (8.97) | 2.34 (7.41)
Lebovitz, 2001 ^169^ | mg/dL | Rosiglitazone, 166 | Placebo, 158 | 2 bid (fixed) | NA | 42.51 (9.75) | 43.29 (13.26) | 1.95 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 46.8 | 45.63
| | | | | | 4.29 (7.02) | 2.34 (7.41)
Vongthavaravat, 2002 ^170^ | mg/dL | Rosiglitazone + unspecified sulfonylurea + diet, 164 | Unspecified sulfonylurea + diet, 170 | 2 bid (fixed) | NR | 41 (SE 0.9) | 44 (SE 1) | 2 | NR | NR
| | | | | | 45 (SE 1) | 46 (SE 1)
| | | | | | 4 | 2
Wolffenbuttel, 2000 ^171^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 199 | Unspecified sulfonylurea + placebo, 192 | 1 bid (fixed) | NR (fixed) | 42.9 (11.7) | 46.8 (15.6) | 3.9 | 0.0043 vs. baseline | 0.3858 vs. baseline
| | | | NR (fixed) | | 46.8 (11.7) | 46.8 (11.7) | | NSG vs. GP2
| | | | | | 3.9 | 0
Wolffenbuttel, 2000 ^171^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 183 | Unspecified sulfonylurea + placebo, 192 | 2 bid (fixed) | NR (fixed) | 42.9 (11.7) | 46.8 (15.6) | 3.9 | <0.0001 vs. baseline | 0.3858 vs. baseline
| | | | NR (fixed) | | 46.8 (11.7) | 46.8 (11.7) | | 0.0019 vs. GP2
| | | | | | 3.9 | 0
Barnett, 2003 ^172^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 84 | Unspecified sulfonylurea + placebo, 87 | 4 bid (fixed) | NR (NR) | NR | NR | NR | NSG vs. GP2
| | | | NR (NR) | | NR | NR
| | | | | | NR | NR
Metformin vs. Placebo
Natali, 2004 ^144^ | mg/dL | Metformin | Placebo | 500 tid (fixed) | NA | 46 (SEM 15) | 45 (SEM 12) | 2 | NR | NR
| | | | | | 49 | 46
| | | | | | 3 (2) | 1 (1)
DeFronzo, 1995 ^88^ | mg/dL | Metformin, 143 | Placebo, 146 | 850 (esc) 850 tid | NA | 39 (SE 1) | 41 (SE 1) | 1 | NR | NR
| | | | | | 40 (SE 1) | 41 (SE 1)
| | | | | | 1 | 0
Schneider, 1991 ^173^ | mg/dL | Metformin, 18 | Placebo, 16 | 850 (esc) 1700 | NA | 47 (22) | 38 (13) | -3 | NSG vs. baseline | NSG vs. baseline
| | | | | | 49 (21) | 43 (10)
| | | | | | 2 | 5
Rachmani, 2002 ^150^ | mg/dL | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR | NA | 38.22 (SE 1.17) | 40.95 (SE 0.78) | 2.73 | <0.05 vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 40.95 | 40.95
| | | | | | 2.73 | 0
Virtanen, 2003 ^143^ | mg/dL | Metformin + diet | Placebo + diet | 500 bid (esc) 1000 bid | NA | 42.9 (SE 3.9) | 46.8 (SE 3.9) | 0 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 46.8 (SE 3.9) | 50.7 (SE 3.9)
| | | | | | 3.9 | 3.9
Del Prato, 2003 ^149^ | mg/dL | Metformin + placebo, 233 | Placebo, 115 | 850 (esc) 2550 | NA | 44.46 (11.7) | 44.85 (11.31) | 2.34 | NR | NR
| | | | | | 47.97 (13.65) | 46.02 (11.7)
| | | | | | 3.51 | 1.17
Alpha-Glucosidase Inhibitor vs. Placebo
Rosenbaum, 2002 ^153^ | mg/dL | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 85.8 (23.4) | 78 (15.6) | 3.9 | 0.56 vs. baseline | 0.44 vs. baseline
| | | | | | 85.8 (15.6) | 74.1 (15.6)
| | | | | | 0 | -3.9
Hasche, 1999 ^138^ | mg/dL | Acarbose + diet, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 49.2 (9.2) | 46.1 (9.9) | 2.9 | NR | NR
| | | | | | 50.7 (14.2) | 44.7 (7.8)
| | | | | | 1.5 | -1.4
Second Generation Sulfonylurea vs. Placebo
Simonson, 1997 ^136^ | mg/dL | Glipizide GITS, 278 | Placebo, 69 | 5, 10, 15, 20, 40, or 60 (fixed) | NA | 37 | 37 | 1 | NR | NR
| | | | | | 37 | 36
| | | | | | 0 | -1
Repaglinide vs. Placebo
Goldberg, 1998 ^139^ | mg/dL | Repaglinide, 56 | Placebo, 23 | 0.25 tid (esc) 8.0 | NA | NR | NR | -0.31 | 0.873 vs. GP2
| | | | | | NR | NR
| | | | | | -1.17 | -1.17

Comp = comparison; BL = baseline; GP = group; mg = milligrams; dL = deciliter; esc = escalated; max = maximum; diff = difference; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; od = once daily; bid = twice daily; tid = three times daily; HbA1c = hemoglobin A1c; f/u = follow-up; XR = extended release; GITS = gastrointestinal therapeutic system; vs = versus

* Number obtained from figure

† Percent change from baseline

‡ 95% confidence interval

# Median

‖ Article states a mean change of baseline as 1.11 mmol/L and 1.15 mmol/L for GP1 and GP2 respectively. We suspect that there may be a reporting error, and therefore have recorded these values as mg/dL.

¶ Median percent difference between groups.

Table 13 Evidence Table. Comparative effectiveness of oral diabetes medications on proximal clinical outcomes: triglycerides

Author, year | Units | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL1 - mean diff BL2 | P-value for comparisons with GP1 | P-value for comparisons with GP2
Study group | | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Thiazolidinedione vs. Thiazolidinedione
Khan, 2002 ^51^ | mg/dL | Rosiglitazone, 60 | Pioglitazone, 67 | 2–8 (fixed) | 15–45 (fixed) | 236 (222) | 181 (110.1) | 21 | NSG vs. baseline | NSG vs. baseline
| | | | | | 242 | 166
| | | | | | 6* | -15*
Goldberg, 2005 ^52^ | mg/dL | Rosiglitazone + diet, 356 | Pioglitazone + diet, 363 | 4 (esc) 8 | 30 (esc) 45 | 235.3 (SE 6.6) | 257.8 (SE 8.2) | 65 | NSG vs. baseline | <0.05 vs. baseline and vs. GP1
| | | | | | 248.4 | 205.9
| | | | | | 13.1 (SE 7.8) | -51.9 (SE 7.8)
Derosa, 2005 ^53^ | mg/dL | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 (fixed) | 15 (fixed) | 162.87 (29.37) | 156.65 (35.6) | 64.08 | <0.05 vs. baseline and GP2 | p<0.05 vs. baseline
| | | | 4 (fixed) | 4 (fixed) | 192.24 (32.04) | 121.93 (28.48)
| | | | | | 29.37 | -34.71
Thiazolidinedione vs. Metformin
Lawrence, 2004 ^54^ | mg/dL | Pioglitazone, 20 | Metformin, 20 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 203 (149) | 202 (110) | -0.6 | NSG vs. baseline and vs. GP2
| | | | | | 176 (115) | 175.6 (114.4)
| | | | | | -27 | -6.4
Pavo, 2003 ^59^ | mg/dL | Pioglitazone + placebo, 100 | Metformin + placebo, 91 | 30 (esc) 45 | 850 (esc) 2550 | NR | NR | -24.92 | 0.001 vs. baseline | 0.03 vs. baseline
| | | | | | NR | NR
| | | | | | -80.99 | -56.07
Hanefeld, 2004 ^60^ | mg/dL | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 219.83 (150.41) | 211.82 (153.08) | -20.47 | 0.008 vs. GP2
QUARTET study group | | | | NR | NR | 178.89 (5.34) | 191.35 (5.34)
| | | | | | -40.94 | -20.47
Ramachandran, 2004 ^55^ | mg/dL | Pioglitazone + diet, 23 | Metformin + diet, 21 | 15 (esc) 30 | 250 (esc) 850 | 258.1 (213.6) | 249.2 (222.5) | -35.6 | <0.05 vs. baseline
| | | | | | 195.8 (124.6) | 222.5 (160.2)
| | | | | | -62.3 | -26.7
Schernthaner, 2004 ^56^ | mg/dL | Pioglitazone + placebo + diet | Metformin + placebo + diet | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | 234.96 | 232.29 | -27.59 | 0.001 vs. GP2
| | | | | | 180.67 | 205.59
| | | | | | -54.29 | -26.7
Yamanouchi, 2005 ^57^ | mg/dL | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men (fixed) | 750 (fixed) | 219.83 (112.14) | 205.59 (101.46) | -31.15 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 185.12 (96.12) | 197.58 (94.34)
| | | | | | -39.16 | -8.01
Natali, 2004 ^144^ | mg/dL | Rosiglitazone | Metformin | 4 bid (fixed) | 500 tid (fixed) | 142 (SEM 7.3) | 196 (SEM 251) | 47 | NSG vs. GP2
| | | | | | 178 | 152
| | | | | | 36 (32) | -44 (41)
Virtanen, 2003 ^143^ | mg/dL | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 151.3 (SE 17.8) | 106.8 (SE 8.9) | -26.7 | NSG vs. GP2
| | | | | | 133.5 (SE 17.8) | 115.7 (SE 17.8)
| | | | | | -17.8 | 8.9
Thiazolidinedione vs. Second Generation Sulfonylurea
Pfutzner, 2005 ^68^ | mg/dL | Pioglitazone, 89 | Glimepiride, 84 | 45 (fixed) | 1 (esc) 6 | 190 (109) | 202 (111) | -5 | <0.005 vs. baseline | <0.001 vs. baseline
| | | | | | 168 (102) | 185 (106) | | NSG vs. GP2
| | | | | | -22 | -17
Tan, 2004 ^65^ | mg/dL | Pioglitazone, 91 | Glibenclamide, 109 | 15 (esc) 45 | 2 (esc) 8 | 182.45 | 202.03 | -29.37 | <0.05 vs. baseline and 0.019 vs. GP2 | NS
| | | | | | 150.41 | 199.36
| | | | | | -32.04 | -2.67
Charbonnel, 2005 ^63^ | mg/dL | Pioglitazone | Gliclazide | NR (esc) 45 | NR (esc) 320 | 232.29 | 249.2 | -6.23 (-22.25, 8.9^‡^) | 0.413 vs. GP2
| | | | | | 190.46 | 203.81
| | | | | | -45.39 | -39.16
Lawrence, 2004 ^54^ | mg/dL | Pioglitazone, 20 | Gliclazide, 20 | 30 (esc) 45 | 80 od (esc) 160 bid | 203 (149) | 157 (93.14) | -37.6 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 176 (115) | 167.6 (94)
| | | | | | -27 | 10.6
Yanagawa, 2004 ^62^ | mg/dL | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | 140 (72) | 164 (134) | NR | F-statistic = 1.4; NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Ramachandran, 2004 ^55^ | mg/dL | Pioglitazone + diet, 23 | Glimepiride + diet, 18 | 15 (esc) 30 | 1 (esc) 2 | 258.1 (213.6) | 195.8 (124.6) | -17.8 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 195.8 (124.6) | 151.3 (80.1)
| | | | | | -62.3 | -44.5
Yamanouchi, 2005 ^57^ | mg/dL | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men (fixed) | 1.0 (esc) 2.0 | 219.83 (112.14) | 234.07 (121.93) | -30.26 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 185.12 (96.12) | 229.62 (112.14)
| | | | | | -34.71 | -4.45
Betteridge, 2005 ^157^ | mg/dL | Pioglitazone + existing metformin, 317 | Gliclazide + existing metformin, 313 | 15 (esc) 45 | 80 (esc) 320 | 258.1 (172.66) | 247.42 (168.21) | -48.06 | <0.001 vs. baseline
| | | | NR | NR | 192.24 | 229.62
| | | | | | -65.86 (SEM 6.23) | -17.8 (SEM 6.23)
St John Sutto, 2002 ^67^ | mg/dL | Rosiglitazone, 63 | Glyburide (no trade drug specified), 66 | 4 bid (fixed) | NR (esc) 20 | 226.6 | 189.6 | 11 | NSG vs. baseline | NSG vs. baseline
| | | | | | 223.8 | 175.8
| | | | | | -2.8 | -13.8
Thiazolidinedione + Metformin vs. Second Generation Sulfonylurea + Metformin
Garber, 2006 ^71^ | mg/dL | Rosiglitazone + metformin + diet, 116 | Metformin + glibenclamide + diet, 120 | 4 (esc) 8 | 1000 (esc) 2000 | 218 | 226 | 9 (-22, 40) | NSG vs. GP2
| | | | 1500–2000 (esc) 2000 | 5 (esc) 10 | 238 | 238
| | | | | | 21 (113) | 12 (133)
Derosa, 2005 ^72^ | mg/dL | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Metformin + glimepiride + diet + exercise + behavioral therapy, 47 | 4 (fixed) | 1500 (fixed) | 186 (28) | 178 (23) | -16 | NSG and vs. GP2
| | | | 1500 (fixed) | 2 (fixed) | 129 (18) | 137 (20)
| | | | | | -57 | -41
Thiazolidinedione vs. Meglitinide
Raskin, 2004 ^74^ | mg/dL | Rosiglitazone, 37 | Repaglinide, 37 | 2 bid (esc) 4 bid | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 245 (211) | 306 (246) | 23 | NR | NR
| | | | | | 246 (174) | 284 (211)
| | | | | | 1 | -22
Jovanovic, 2004 ^73^ | mg/dL | Pioglitazone, 26 | Repaglinide, 35 | 30 (fixed) | 0.5 tid if HbA1c≤8%, 1 tid if HbA1c>8% (esc) 4 tid | 291 (232) | 174 (80) | -96 | NR | NR
| | | | | | 200 (99) | 179 (78)
| | | | | | -91 | 5
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Goke, 2002 ^75^ | mg/dL | Pioglitazone, 129 | Acarbose, 136 | 45 (fixed) | 50 (esc) 100 tid | 275.3 (240.4) | 322 (339.9) | -33 | 0.001 vs. GP2
German Pioglitazone Study Group | | | | | | 204.2 | 283.9
| | | | | | -71.1 (184.1) | -38.1 (171.3)
Other Thiazolidinedione Comparisons
Takagi, 2003 ^78^ | mg/dL | Pioglitazone + existing medications, 23 | Uptitration of existing medications, 21 | 30 (fixed) | NR (NR) | 173 (91) | 162 (47) | -30 | NSG vs. GP2
| | | | NR | | 143 (78) | 162 (57)
| | | | | | -30 | 0
Choi, 2004 ^77^ | mg/dL | Rosiglitazone + existing medications, 45 | Uptitration of existing medications, 38 | 8 (other) 4 | NR (esc) | 168.21 (61.41) | 160.2 (55.18) | -23.14 | <.001 vs. baseline
| | | | | | 119.26 (39.16) | 127.27 (61.41)
| | | | | | -48.95 (49.84) | -25.81 (50.73)
Metformin vs. Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 256.8 (26.7) | 236.3 (19.1) | -24.5 | NSG vs. baseline | NS vs. baseline
| | | | | | 217.2 | 221.2
| | | | | | -39.6 | -15.1
Goldstein, 2003 ^82^ | mg/dL | Metformin, 67 | Glipizide | 500 (esc) 2000 | 15 bid (fixed) | 218.7 (120.2) | 213.8 (127.2) | -70.4 | <0.05 vs. baseline | <0.05 vs. baseline
| | | | | | 217.1 | 273.6
| | | | | | -1.6 (-25.3, 22^‡^) | 59.8 (22.5, 97.1^‡^)
Campbell, 1994 ^83^ | mg/dL | Metformin, 24 | Glipizide, 24 | 500 bid (esc) 3000 | 5 (esc) 30 | 191.35 (130.83) | 183.34 (61.41) | -10.68 | NSG vs. baseline
| | | | | | 202.92 (163.76) | 205.59 (108.58)
| | | | | | 11.57 | 22.25
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Glibenclamide, 103 | 500 (esc) 2000 | 5 (esc) 20 | 204.7 (169.1) | 204.7 (151.3) | -17.8 | NSG vs. GP2
| | | | | | 186.9 | 204.7
| | | | | | -17.8 (89) | 0 (133.5)
Amador-Licona, 2000 ^85^ | mg/dL | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | 195.8 (81.88) | 174.44 (81.88) | -10.68 | 0.04 vs. baseline | 0.67 vs. baseline
| | | | | | 178 (65.86) | 166.43 (97.9)
| | | | | | -17.8 | -8.01
Lawrence, 2004 ^54^ | mg/dL | Metformin, 20 | Gliclazide, 20 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 202 (110) | 157 (93.14) | -37 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 175.6 (114.4) | 167.6 (94)
| | | | | | -26.4 | 10.6
Noury, 1991 ^86^ | mg/dL | Metformin, 30 | Gliclazide, 27 | 1700 (fixed) | 80 (esc) 240 | 199.36 (226.06) | 150.41 (99.68) | -51.62 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 177.11 (135.28) | 179.78 (161.98)
| | | | | | -22.25 | 29.37
Ramachandran, 2004 ^55^ | mg/dL | Metformin + diet, 21 | Glimepiride + diet, 18 | 250 (esc) 850 | 1 (esc) 2 | 249.2 (222.5) | 195.8 (124.6) | 17.8 | | <0.05 vs. baseline
| | | | | | 222.5 (160.2) | 151.3 (80.1)
| | | | | | -26.7 | -44.5
Hermann, 1994 ^87^ | mg/dL | Metformin + diet, 19 | Glyburide + diet, 19 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 179.78 (SE 18.69) | 178.89 (SE 32.93) | -14.24 | >0.1 vs. GP2
| | | | | | 173.55 (SE 14.24) | 186.9 (SE 31.15)
| | | | | | -6.23 (SE 12.46) | 8.01 (SE 11.57)
DeFronzo, 1995 ^88^ | mg/dL | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) 2500 | 5 bid (esc) 10 bid | 231 (SE 12) | 210 (SE 8) | -37 | 0.001 vs. GP2
| | | | | | 221 (SE 13) | 227 (SE 11)
| | | | | | -16 (SE 7) | 21 (SE 9)
Charpentier, 2001 ^89^ | mg/dL | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 tid (fixed) | 1 (esc) 6 | 171.77 (119.26) | 189.57 (143.29) | 2.67 | 0.029 for all treatment groups in study
| | | | | | 185.12 | 200.25
| | | | | | 13.35 (104.13) | 10.68 (108.58)
Yamanouchi, 2005 ^57^ | mg/dL | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 (fixed) | 1 (esc) 2 | 205.59 (101.46) | 234.07 (121.93) | -3.56 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 197.58 (94.34) | 229.62 (112.14)
| | | | | | -8.01 | -4.45
Derosa, 2004 ^90^ | mg/dL | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 (esc) 1000 tid | 1 (esc) 2 bid | 180 (25) | 160 (20) | 0 | NSG vs. baseline | NSG vs. baseline
| | | | | | 165 (25) | 145 (25)
| | | | | | -15 | -15
Blonde, 2002 ^81^ | NR | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 (esc) 2000 | 10 bid (fixed) | NR | NR | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Metformin vs. Meglitinide
Derosa, 2003 ^97^ | mg/dL | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 bid (esc) 2500 | 0.5 bid (esc) 4 | 176.22 (4.806) | 156.64 (52.51) | -8.01 | <0.05 vs. baseline | 0.065 vs. baseline
| | | | | | 152.19 | 140.62 | | NSG vs. GP2
| | | | | | -24.03 (-55.18, -15.13^‡^) | -16.02 (-38.27, 17.8^‡^)
Metformin vs. Alpha-Glucosidase Inhibitor
Willms, 1999 ^99^ | mg/dL | Metformin, 27 | Acarbose, 31 | 850 bid (fixed) | 100 tid (fixed) | NR | NR | 12.5 | NR | NR
| | | | | | NR | NR
| | | | | | -24.03^#^ | -36.49^#^
Metformin vs. Thiazolidinedione + Metformin
Weissman, 2005 ^100^ | mg/dL | Metformin, 266 | Rosiglitazone + metformin, 271 | 1000 (esc) 2000 | 4 (esc) 8 | 179.2 | 184.8 | -14.2 | NSG vs. baseline | NSG vs. baseline
| | | | | 1000 (fixed) | 176.8 (170.9, 182.9^‡^) | 196.6 (189.2, 204.2^‡^)
| | | | | | -2.4 | 11.8
Bailey, 2005 ^101^ | mg/dL | Metformin, 230 | Rosiglitazone + metformin, 245 | 2500 (esc) 3000 | 4 (esc) 8 | 180.8 (175.5, 186.3^‡^) | 189.3 (183.5, 195.2^‡^) | -13.4 | <0.05 vs. baseline | NSG vs. baseline
| | | | | 2000 (fixed) | 167.5 (161.8, 173.4^‡^) | 189.4 (183.1, 195.9^‡^)
| | | | | | -13.3 | 0.1
Fonseca, 2000 ^103^ | mg/dL | Metformin + placebo, 113 | Rosiglitazone + metformin, 116 | 2500 (fixed) | 4 (fixed) | 246.53 (194.91) | 226.06 (138.84) | -6.23 | | 0.73 vs. GP1
| | | | | 2500 (fixed) | 247.42 (159.31) | 233.18 (139.73)
| | | | | | 0.89 | 7.12
Fonseca, 2000 ^103^ | mg/dL | Metformin + placebo, 113 | Rosiglitazone + metformin, 110 | 2500 (fixed) | 8 (fixed) | 246.53 (194.91) | 228.73 (184.23) | 0.89 | | 0.56 vs. GP1
| | | | | 2500 (fixed) | 247.42 (159.31) | 228.73 (166.43)
| | | | | | 0.89 | 0
Gomez-Perez, 2002 ^102^ | mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 4 bid (fixed) | 227.2 (126.8) | 204.4 (113.3) | 10.7 | NR | NR
| | | | | 2500 (fixed) | 233.4 | 199.9
| | | | | | 6.2 | -4.5
Gomez-Perez, 2002 ^102^ | mg/dL | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2 bid (fixed) | 227.2 (126.8) | 199.6 (133.2) | 12 | NR | NR
| | | | | 2500 (fixed) | 233.4 | 193.8
| | | | | | 6.2 | -5.8
Metformin vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 256.8 (26.7) | 248.4 (26.2) | 12.4 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | 217.2 | 196.4
| | | | | | -39.6 | -52
Goldstein, 2003 ^82^ | mg/dL | Metformin, 67 | Metformin + glipizide, | 500 (esc) 2000 | 500 (esc) 2000 | 218.7 (120.2) | 237.5 (192.2) | -20.1 | NSG vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 20 | 217.1 | 256
| | | | | | -1.6 (-25.3, 22^‡^) | 18.5 (-16.8, 53.7^‡^)
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Metformin + glibenclamide, 103 | 500 (esc) 2000 | 500 (esc) 2000 | 204.7 (169.1) | 213.6 (160.2) | 0 | NSG vs. GP2
| | | | | 5 (esc) 20 | 186.9 | 195.8
| | | | | | -17.8 (89) | -17.8 (151.3)
Marre, 2002 ^84^ | mg/dL | Metformin, 104 | Metformin + glibenclamide, 101 | 500 (esc) 2000 | 500 (esc) 2000 | 204.7 (169.1) | 222.5 (284.8) | 26.7 | NSG vs. GP2
| | | | | 2.5 (esc) 10 | 186.9 | 178
| | | | | | -17.8 (89) | -44.5 (186.9)
Hermann, 1994 ^87^ | mg/dL | Metformin + diet, 19 | Metformin + glyburide, 46 | 1000 (esc) 3000 | 500 (esc) 1500 | 179.78 (SE 18.69) | 175.33 (SE 20.47) | 2.67 | >0.1 vs. baseline and vs. GP2 | >0.1 vs. baseline
| | | | | 1.75 (esc) 5.25 | 173.55 (SE 14.24) | 168.21 (SE 17.8)
| | | | | | 8.01 (SE 12.46) | 5.34 (SE 11.57)
DeFronzo, 1995 ^88^ | mg/dL | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | 231 (SE 12) | 216 (SE 10) | 4 | NR | NR
| | | | | 10 (esc) 20 | 221 (SE 13) | 194 (SE 9)
| | | | | | -16 (SE 7) | -20 (SE 7)
Charpentier, 2001 ^89^ | mg/dL | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 tid (fixed) | 850 tid (fixed) | 171.77 (119.26) | 169.99 (110.36) | 16.02 | | 0.029 all group comparison
| | | | | 1 (esc) 6 | 185.12 | 167.32
| | | | | | 13.35 (104.13) | -2.67 (93.45)
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 160 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 2.5 (esc) 10 | NR | NR
| | | | | | NR | NR
Blonde, 2002 ^81^ | NR | Metformin, 153 | Metformin + glyburide (no trade drug specified), 162 | 500 (esc) 2000 | 500 (esc) 2000 | NR | NR | NR | NSG vs. GP2
| | | | | 5 (esc) 20 | NR | NR
| | | | | | NR | NR
Feinglos, 2005 ^104^ | NR | Metformin + placebo, 56 | Metformin + glipizide, 56 | at least 1000 (fixed) | at least 1000 (fixed) | NR | NR | NR | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | 2.5 (fixed) | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Inukai, 2005 ^111^ | mg/dL | Glibenclamide or gliclazide, 52 | Glimepiride, 120 | 2.5 (fixed) | 1 or 2 (esc) 6 | 143.4 (120.3) | 149.6 (118.8) | 16 | 0.66 vs. baseline | 0.08 vs. baseline
| | | | 40 (fixed) | | 146.2 (100.3) | 136.4 (84.6)
| | | | | | 2.8 | -13.2
Baba, 1983 ^133^ | mg/dL | Glibenclamide, 131 | Gliclazide, 146 | 2.5 (esc) 10 | 40 (esc) 160 | 135* | 133* | 2 | NSG vs. GP2
| | | | | | 136* | 132*
| | | | | | 1 | -1
Schernthaner, 2004 ^106^ | mg/dL | Glimepiride + existing oral diabetes medications + diet, 440 | Gliclazide + existing oral diabetes medications + diet, 405 | 1 (esc) 6 | 30 (esc) 120 | 204.7 | 195.8 | 0 | NSG vs. baseline | NSG vs. baseline
| | | | | | 195.8 | 186.9
| | | | | | -8.9 | -8.9
Second Generation Sulfonylurea vs. Meglitinide
Wolffenbuttel, 1999 ^117^ | mg/dL | Glyburide (no trade drug specified) + placebo, 109 | Repaglinide, 211 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | 163.76^#^ | 170.88^#^ | 3.56 | NSG vs. baseline | NSG vs. baseline
| | | | | | 174.44^#^ | 178^#^
| | | | | | 10.68 | 7.12
Marbury, 1999 ^116^ | mg/dL | Glyburide (no trade drug specified) + placebo, 216 | Repaglinide, 115 | 2.5 (esc) 15 | 0.5 (esc) 12 | NR | NR | -13.02 (-31.24, 57.28^‡^) | NSG vs. GP2
| | | | | | NR | NR
| | | | | | -6.45 | 6.57
Derosa, 2003 ^118^ | mg/dL | Glimepiride + placebo, 62 | Repaglinide + placebo, 62 | 1 (esc) 3 mean final dose | 1 (esc) 2.5 mean final dose | 170 (36) | 153 (32) | 3 | NSG vs. GP2
| | | | | | 155 (39) | 135 (36)
| | | | | | -15 | -18
Madsbad, 2001 ^119^ | mg/dL | Glipizide + placebo, 81 | Repaglinide, 175 | 5 (esc) 15 | 0.5 (esc) 4 | NR | NR | 0 (-31.15, 31.15^‡^) | NSG vs. GP2
| | | | | | NR | NR
| | | | | | 3.56 (-23.14, 29.37^‡^) | 3.56 (-14.24, 20.47^‡^)
Vakkilainen, 2002 ^122^ | NR | Glibenclamide + placebo, 20 | Nateglinide + placebo, 23 | 5 (esc) 10 | 120 tid (fixed) | NR | NR | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Second Generation Sulfonylurea vs. Thiazolidinedione + Second Generation Sulfonylurea
Rosenstock, 2006 ^124^ | % | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | -14.9 | NR | NR
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -5.4^†^ | 9.5^†^
Kerenyi, 2004 ^125^ | mg/dL | Glibenclamide + diet, 139 | Rosiglitazone + glibenclamide + diet, 144 | 7.5 (esc) 15 | 4 bid (fixed) | 169.1 | 173.55 | 1.78 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 7.5 (fixed) | 163.76 | 166.43
| | | | | | -5.34 | -7.12
Baksi, 2004 ^126^ | mg/dL | Gliclazide, 201 | Rosiglitazone + gliclazide, 205 | 160 (esc) 320 | 160 (fixed) | 142.4^#^ | 151.3^#^ | -4.2 | NR | NR
| | | | | 4 bid (fixed) | 151.3^#^ | 160.2^#^
| | | | | | 3.5^†^ | 7.7^†^
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Garber, 2003 ^80^ | mg/dL | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 236.3 (19.1) | 246.4 (26.2) | 36.9 | NSG vs. baseline | <0.05 vs. baseline
| | | | | 1.25 (esc) 5 | 22.12 | 196.2
| | | | | | -15.1 | -52
DeFronzo, 1995 ^88^ | mg/dL | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 210 (SE 8) | 216 (SE 10) | 41 | 0.001 vs. GP2
| | | | | 10 (esc) 20 | 227 (SE 11) | 194 (SE 9)
| | | | | | 21 (SE 9) | -20 (SE 7)
Charpentier, 2001 ^89^ | mg/dL | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 (esc) 6 | 850 tid (fixed) | 189.57 (143.29) | 169.99 (110.36) | 13.35 | | 0.029 all group comparison
| | | | | 1 (esc) 6 | 200.25 | 167.32
| | | | | | 10.68 (108.58) | -2.67 (93.45)
Goldstein, 2003 ^82^ | mg/dL | Glipizide | Metformin + glipizide | 30 (fixed) | 500 (esc) 2000 | 213.8 (127.2) | 237.5 (192.2) | 41.3 | <0.05 vs. baseline | NSG vs. baseline
| | | | | 5 (esc) 20 | 273.6 | 256
| | | | | | 59.8 | 18.5
Marre, 2002 ^84^ | mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 (esc) 20 | 500 (esc) 2000 | 204.7 (151.3) | 213.6 (160.2) | 17.8 | NSG vs. baseline and vs. GP2 | NSG vs. baseline and vs. GP2
| | | | | 5 (esc) 20 | 204.7 | 195.8
| | | | | | 0 (133.5) | -17.8 (151.3)
Marre, 2002 ^84^ | mg/dL | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 (esc) 20 | 500 (esc) 2000 | 204.7 (151.3) | 222.5 (284.8) | 44.5 | NSG vs. baseline and vs. GP2 | NSG vs. baseline and vs. GP2
| | | | | 2.5 (esc) 10 | 204.7 | 178
| | | | | | 0 (133.5) | -44.5 (186.9)
Hermann, 1994 ^87^ | mg/dL | Glyburide + diet, 19 | Metformin + glyburide + diet, 46 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 178.89 (SE 32.93) | 175.33 (SE 20.47) | 1.78 | >0.1 vs. baseline and vs. GP2 | >0.1 vs. baseline
| | | | | 1.75 (esc) 5.25 | 186.9 (SE 31.15) | 168.21 (SE 17.8)
| | | | | | 7.12 (SE 11.57) | 5.34 (SE 11.57)
1998 ^128^ | mg/dL | Glibenclamide + diet, 300 | Metformin + glibenclamide + diet, 291 | 10 (fixed) | 500 (esc) 2500 | NR | NR | -8.9 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
UKPDS, 3 year f/u | | | | | 10 (fixed) | NR | NR
| | | | | | -14.24 (-51.62, 23.14^‡^) | -5.34 (-18.69, 8.01^‡^)
Gregorio, 1999 ^129^ | mg/dL | Glibenclamide or gliclazide, 85 | Metformin + glibenclamide or metformin + gliclazide, 89 | 10 (esc) 15 | 850 (esc) 1700 | 169.99 (10.68) | 172.66 (11.57) | -0.89 | NSG vs. baseline | NSG vs. baseline
| | | | 120 (esc) 240 | NR (fixed) | 162.87 (10.68) | 166.43 (10.68)
| | | | | NR (fixed) | -7.12 | -6.23
Other Comparisons
Fujioka, 2003 ^105^ | mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 181 (113) | 187 (200) | -33 | NSG vs. baseline | <0.05 vs. baseline
| | | | | | 182 | 221
| | | | | | 1 (-14, 17) | 34 (15, 53)
Fujioka, 2003 ^105^ | mg/dL | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 199 (34) | 201 (137) | -41 | NSG vs. baseline | <0.05 vs. baseline
| | | | | | 200 | 243
| | | | | | 1 (-14, 17) | 42 (6, 78)
McCluskey, 2004 ^76^ | mg/dL | Rosiglitazone + placebo, 11 | Rosiglitazone + glimepiride, 23 | 4 or 8 (fixed) | 4 or 8 fixed | 45.9 (SE 6.4) | 41.3 (SE 5) | 29.1 | NSG vs. GP2
| | | | | 2 (esc) 8 | 67.5 | 33.8
| | | | | | 21.6 (SE 13.7) | -7.5 (SE 10)
Pioglitazone vs. Placebo
Rosenblatt, 2001 ^162^ | mg/dL | Pioglitazone, 101 | Placebo, 96 | 30 (NR) | NA | 357.78 (533.11) | 173.55 (347.1) | -0.65% | 0.0178 vs. GP2
| | | | | | 304.83 | 163.48
| | | | | | -14.8%^†^ | 1.8%^†^
Saad, 2004 ^164^ | mg/dL | Pioglitazone, 24 | Placebo, 28 | 45 (fixed) | NA | 315 (122) | 351 (168) | -118 | <.05 vs. GP2
| | | | | | 214 | 368
| | | | | | -101 | 17
Tseng, 2005 ^140^ | % | Pioglitazone + unspecified sulfonylurea, 23 | Unspecified sulfonylurea + placebo, 25 | 30 (fixed) | NR (NR) | NR | NR | -36.6% | <0.05 vs. baseline | NSG vs. baseline
| | | | NR (NR) | | NR | NR
| | | | | | -16.6%^†^ | 20%^†^
Herz, 2003 ^163^ | mg/dL | Pioglitazone, 96 | Placebo, 96 | 45 (fixed) | NA | 177.11 | 153.08 | -29.9 | <0.001 vs. baseline
| | | | | | 148.77 | 154.6 | | 0.007 vs. GP2
| | | | | | -16%^†^ | 1%^†^
Herz, 2003 ^163^ | mg/dL | Pioglitazone, 95 | Placebo, 96 | 30 (fixed) | NA | 169.99 | 153.08 | -10 | NSG vs. GP2
| | | | | | 161.49 | 154.6
| | | | | | -5%^†^ | 1%^†^
Nishio, 2006 ^151^ | mg/dL | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | 97.01 (32.93) | 133.5 (111.25) | 45.39 | NSG vs. baseline and vs. GP2 | NSG vs. baseline
| | | | | | 151.3 (81.88) | 142.4 (64.08)
| | | | | | 54.29 | 8.9
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 77 | Placebo, 79 | 45 (fixed) | NA | 259.7 (SE 34.87) | 262.8 (SE 34.35) | -30.7 | <=0.05 vs. baseline
| | | | | | 218.9 (SE 14.24) | 252.7 (SE 20.71)
| | | | | | -40.8 | -10.1
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 79 | Placebo, 79 | 15 (fixed) | NA | 283.8 (SE 34.4) | 262.8 (SE 34.35) | -47.7 | <=0.05 vs. baseline
| | | | | | 226 (SE 20.15) | 252.7 (SE 20.71)
| | | | | | -57.8 | -10.1
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 80 | Placebo, 79 | 7.5 (fixed) | NA | 319 (SE 34.23) | 262.8 (SE 34.35) | -44.8 | <=0.05 vs. baseline
| | | | | | 264.1 (SE 33.08) | 252.7 (SE 20.71)
| | | | | | -54.9 | -10.1
Aronoff, 2000 ^165^ | mg/dL | Pioglitazone, 84 | Placebo, 79 | 30 (fixed) | NA | 261.1 (SE 33.44) | 262.8 (SE 34.35) | -25.8 | <=0.05 vs. baseline
| | | | | | 225.2 (SE 24.77) | 252.7 (SE 20.71)
| | | | | | -35.9 | -10.1
Smith, 2005 ^161^ | mg/dL | Pioglitazone + diet, 21 | Placebo + diet, 21 | 30 (esc) 45 | NA | 205.79 (182.61) | 221.96 (141.66) | -56.16 | 0.0035 vs. GP2
| | | | | | 147.27 | 219.6
| | | | | | -58.52 (123.26) | -2.36 (59.87)
Einhorn, 2000 ^160^ | mg/dL | Pioglitazone + existing metformin + diet, 161 | Existing metformin + placebo + diet, 149 | 30 (fixed) | NR (NR) | 298.9 (24.9) | 300.4 (25.86) | -18.2 | ≤0.05 vs. GP2
| | | | NR (NR) | | 289.2 | 308.9
| | | | | | -9.7 | 8.5
Kipnes, 2001 ^166^ | mg/dL | Pioglitazone + existing unspecified sulfonylurea, 181 | Unspecified sulfonylurea + placebo, 180 | 30 (fixed) | NR (NR) | 260 | 259 | -70 | <0.05 vs. baseline and vs. GP2
| | | | NR (NR) | | 198 | 267
| | | | | | -62 | 8
Kipnes, 2001 ^166^ | mg/dL | Pioglitazone + existing unspecified sulfonylurea, 177 | Unspecified sulfonylurea + placebo, 180 | 15 (fixed) | NR (NR) | 272 | 259 | -50 | <0.05 vs. baseline and vs. GP2
| | | | NR (NR) | | 230 | 267
| | | | | | -42 | 8
Rosiglitazone vs. Placebo
Barnett, 2003 ^172^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 84 | Unspecified sulfonylurea + placebo, 87 | 4 bid (fixed) | NR (NR) | 179.78 (91.67) | 176.22 (94.34) | NR | NSG vs. GP2
| | | | NR (NR) | | NR | NR
| | | | | | NR | NR
Natali, 2004 ^144^ | mg/dL | Rosiglitazone | Placebo | 4 bid (fixed) | NA | 142 (SEM 73) | 155 (SEM 76) | 30 (-40, 96^‡^) | NSG vs. GP2
| | | | | | 178 | 161
| | | | | | 36 | 6
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 79 | Placebo, 74 | 1.0 bid (fixed) | NA | 209.8 | 208 | -9.3 (-60.0, 41.5^‡^) | NSG vs. GP2
| | | | | | 216.7 | 224.1
| | | | | | 6.9 | 16.1
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 79 | Placebo, 74 | 2.0 bid (fixed) | NA | 189.5 | 208 | 1.2 (-49.7, 52.0^‡^) | NSG vs. GP2
| | | | | | 206.8 | 224.1
| | | | | | 17.3 | 16.1
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 70 | Placebo, 74 | 0.05 bid (fixed) | NA | 217.9 | 208 | 10.6 (-41.6, 62.8^‡^) | NSG vs. GP2
| | | | | | 244.6 | 224.1
| | | | | | 26.7 | 16.1
Patel, 1999 ^167^ | mg/dL | Rosiglitazone, 72 | Placebo, 74 | 0.25 bid (fixed) | NA | 222.9 | 208 | 7.7 (-44.5, 62.8^‡^) | NSG vs. GP2
| | | | | | 246.7 | 224.1
| | | | | | 23.8 | 16.1
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 158 | Placebo, 110 | 2 bid (fixed) | NA | 168.21^#^ | 175.33^#^ | 24.03 | NSG vs. GP2
| | | | | | 188.68^#^ | 171.77^#^
| | | | | | 20.47 | -3.56
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 142 | Placebo, 110 | 8 od (fixed) | NA | 186.01^#^ | 175.33^#^ | 29.37 | NSG vs. GP2
| | | | | | 211.82^#^ | 171.77^#^
| | | | | | 25.81 | -3.56
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 145 | Placebo, 110 | 4 bid (fixed) | NA | 161.98^#^ | 175.33^#^ | 30.26 | NSG vs. GP2
| | | | | | 188.68^#^ | 171.77^#^
| | | | | | 26.7 | -3.56
Phillips, 2001 ^168^ | mg/dL | Rosiglitazone, 158 | Placebo, 110 | 4 od (fixed) | NA | 194.02^#^ | 175.33^#^ | 3.56 | NSG vs. GP2
| | | | | | 194.02^#^ | 171.77^#^
| | | | | | 0 | -3.56
Lebovitz, 2001 ^169^ | mg/dL | Rosiglitazone, 166 | Placebo, 158 | 2 bid (fixed) | NA | 253.65 (299.04) | 226.95 (179.78) | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Lebovitz, 2001 ^169^ | mg/dL | Rosiglitazone, 169 | Placebo, 158 | 4 bid (fixed) | NA | 236.74 (157.53) | 226.95 (179.78) | NR | NSG vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Virtanen, 2003 ^143^ | mg/dL | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 151.3 (SE 17.8) | 169.1 (SE 62.3) | 26.7 | >0.05 vs. GP2
| | | | | | 133.5 (SE 17.8) | 124.6 (SE 26.7)
| | | | | | -17.8 | -44.5
Kim, 2005 ^152^ | mg/dL | Rosiglitazone + diet + exercise, 60 | Diet + exercise, 60 | 4 (fixed) | NA | 211.82 (145.07) | 189.57 (94.34) | 4.45 | NSG vs. baseline | NSG vs. baseline
| | | | | | 210.93 (115.7) | 184.23 (105.02)
| | | | | | -0.89 | -5.34
Wolffenbuttel, 2000 ^171^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 183 | Unspecified sulfonylurea + placebo, 192 | 2 bid (fixed) | NR (fixed) | 178 (106.8) | 160.2 (89) | 8.9 | 0.0198 vs. baseline | 0.4115 vs. baseline
| | | | NR (fixed) | | 195.8 (169.1) | 169.1 (106.8) | | 0.1393 vs. GP2
| | | | | | 17.8 | 8.9
Wolffenbuttel, 2000 ^171^ | mg/dL | Rosiglitazone + unspecified sulfonylurea, 199 | Unspecified sulfonylurea + placebo, 192 | 1 bid (fixed) | NR (fixed) | 169.1 (97.9) | 160.2 (89) | 26.7 | <0.0001 vs. baseline | 0.4115 vs. baseline
| | | | NR (fixed) | | 204.7 (151.3) | 169.1 (106.8) | | 0.0020 vs. GP2
| | | | | | 35.6 | 8.9
Metformin vs. Placebo
Willms, 1999 ^99^ | mg/dL | Metformin, 27 | Placebo, 29 | 850 bid (fixed) | NA | NR | NR | -50.73 | NR | NR
| | | | | | NR | NR
| | | | | | -24.03^#^ | 26.7^#^
Natali, 2004 ^144^ | mg/dL | Metformin | Placebo | 500 tid (fixed) | NA | 196 (SEM 251) | 155 (SEM 76) | -50 | NR | NR
| | | | | | 152 | 161
| | | | | | -44 (41) | 6 (17)
DeFronzo, 1995 ^88^ | mg/dL | Metformin, 143 | Placebo, 146 | 850 (esc) 2550 | NS (NR) | 209 (SE 15) | 185 (SE 9) | -22 | NSG vs. GP2
| | | | | | 193 (SE 10) | 191 (SE 10)
| | | | | | -17 (SE 12) | 6 (SE 7)
Grant, 1996 ^154^ | mg/dL | Metformin, 25 | Placebo, 23 | 1500 (fixed) | NA | 284.8 | NR | NR | 0.06 vs. GP2
| | | | | | 191.35 | NR
| | | | | | -93.45 | NR
Grant, 1996 ^154^ | mg/dL | Metformin, 27 | Placebo, 23 | 1500 (esc) 3000 | NA | 257.21 | NR | NR | <0.05 vs. GP2
| | | | | | 201.14 | NR
| | | | | | -56.07 | NR
Dornan, 1991 ^260^ | mg/dL | Metformin, 30 | Placebo, 30 | 500 (esc) 1000 tid | NA | 240.3^#^ | 204.7^#^ | -26.7 | NR | NR
| | | | | | 231.4^#^ | 222.5^#^
| | | | | | -8.9^#^ | 17.8^#^
Schneider, 1991 ^173^ | mg/dL | Metformin, 18 | Placebo, 16 | 850 (esc) 1700 | NA | 340 (207) | 309 (168) | -58 | 0.009 vs. GP2
| | | | | | 242 (156) | 269 (85)
| | | | | | -98 | -40
Teupe, 1991 ^155^ | mg/dL | Metformin + diet, 25 | Diet, 29 | NR (esc) 1700 | NA | 177 (112) | 142 (43) | -16 | NR | NR
| | | | | | 212 (151) | 193 (100)
| | | | | | 35 | 51
Manzella, 2004 ^148^ | mg/dL | Metformin + diet, 60 | Placebo + diet, 60 | 850 bid (fixed) | NA | 197.58 (35.6) | 202.03 (17.8) | -18.69 | <0.05 vs. GP2
| | | | | | 172.66 (13.35) | 195.8 (9.79)
| | | | | | -24.92 | -6.23
Virtanen, 2003 ^143^ | mg/dL | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 106.8 (SE 8.9) | 169.1 (SE 62.3) | 53.4 | >0.05 vs. GP2
| | | | | | 115.7 (SE 17.8) | 124.6 (SE 26.7)
| | | | | | 8.9 | -44.5
Del Prato, 2003 ^149^ | mg/dL | Metformin + placebo, 234 | Placebo, 115 | 850 (esc) 2550 | NA | 156.64 (102.35) | 138.84 (88.11) | -37.38 | NR | NR
| | | | | | 143.29 (90.78) | 162.87 (152.19)
| | | | | | -13.35 | 24.03
Second Generation Sulfonylurea vs. Placebo
Simonson, 1997 ^136^ | mg/dL | Glipizide GITS, 278 | Placebo, 69 | 5, 10, 15, 20, 40, or 60 (fixed) | NA | 168 | 178 | -12 | NR | NR
| | | | | | 154 | 176
| | | | | | -14 | -2
Meglitinide vs. Placebo
Goldberg, 1998 ^139^ | mg/dL | Repaglinide, 62 | Placebo, 30 | 0.25 tid (esc) 8.0 | NA | NR | NR | -47.17 | 0.404 vs. GP2
| | | | | | NR | NR
| | | | | | -33.82 | 13.35
Alpha-Glucosidase Inhibitor vs. Placebo
Willms, 1999 ^99^ | mg/dL | Acarbose, 31 | Placebo, 29 | 100 tid (fixed) | NA | NR | NR | -63.19 | NR | NR
| | | | | | NR | NR
| | | | | | -36.49^#^ | 26.7^#^
Rosenbaum, 2002 ^153^ | mg/dL | Acarbose, 20 | Placebo, 20 | 50 bid (esc) 100 tid | NA | 7.9 (3.1) | 10.8 (4.6) | 1.2 | 0.37 | 0.45
| | | | | | 8.6 (4.5) | 10.3 (4.9)
| | | | | | 0.7 | -0.5
Leonhardt, 1991 ^263^ | mg/dL | Acarbose, 47 | Placebo, 47 | 100 tid (fixed) | NA | 195 (1.88) | 186 (1.58) | -8 | NR | NR
| | | | | | 177 | 176
| | | | | | -18 | -10
Hasche, 1999 ^138^ | mg/dL | Acarbose + diet, 28 | Placebo + diet, 32 | 50 bid (esc) 100 tid | NA | 186 | 185.2 | -13.2 | NR | NR
| | | | | | 174.8 | 185
| | | | | | -13.3 (78.8) | -0.1 (72.9)

Comp = comparison; BL = baseline; GP = group; mg = milligrams; dL = deciliter; esc = escalated; max = maximum; diff = difference; NR = not reported; NSG = not significant; NA = not applicable; SD = standard deviation; SE = standard error; SEM = standard error of the mean; od = once daily; bid = twice daily; tid = three times daily; HbA1c = hemoglobin A1c; f/u = follow-up; XR = extended release; GITS = gastrointestinal therapeutic system; vs = versus

* Number obtained from a figure

† Percent change from baseline

‡ 95% confidence interval

# Median

Table 14 Evidence Table. Quality of randomized controlled trials evaluating comparative effectiveness of oral diabetes medications on proximal clinical outcomes

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score
Ramachandran, 2004 ^55^ | Yes | Not described | No | No | No | 1
Rosenbaum, 2002 ^153^ | Yes | Not described | Yes | Not described | Yes | 3
Nishio, 2006 ^151^ | Yes | Not described | No | No | Yes | 2
Weissman, 2005 ^100^ | Yes | Not described | Yes | Yes | Yes | 4
Rosenstock, 2006 ^124^ | Yes | Not described | Yes | Not described | Yes | 3
Bailey, 2005 ^101^ | Yes | Yes | Yes | Not described | Yes | 4
Pfutzner, 2006 ^123^ | Yes | Not described | Yes | Not described | Yes | 3
Betteridge, 2005 ^157^ | Yes | Not described | Yes | Yes | No | 3
Kardas, 2005 ^114^ | Yes | Not described | No | No | Yes | 2
Forst, 2005 ^145^ | Yes | Not described | No | No | No | 1
Yamanouchi, 2005 ^57^ | Yes | Yes | No | No | Yes | 3
Goldberg, 2005 ^52^ | Yes | Not described | Nr | Not described | No | 1
Pfutzner, 2005 ^68^ | Yes | Not described | No | No | No | 1
Derosa, 2005 ^53^ | Yes | Yes | Yes | Yes | Yes | 5
Derosa, 2005 ^72^ | Yes | Yes | Yes | Yes | Yes | 5
Inukai, 2005 ^111^ | Yes | Not described | No | No | No | 1
Langenfeld, 2005 ^146^ | Yes | Inappropriate | No | No | Yes | 1
Feinglos, 2005 ^104^ | Yes | Not described | Yes | Not described | Yes | 3
Mari, 2005 ^262^ | Yes | Not described | Yes | Not described | No | 2
Goke, 2002 ^75^ | Yes | Not described | No | No | Yes | 2
Charbonnel, 2005 ^63^ | Yes | Not described | Yes | Yes | No | 3
Tan, 2005 ^61^ | Yes | Not described | Yes | Yes | Yes | 4
McCluskey, 2004 ^76^ | Yes | Not described | Yes | Not described | Yes | 3
Kim, 2005 ^152^ | Yes | Not described | No | No | Yes | 2
Schernthaner, 2004 ^56^ | Yes | Yes | Yes | Yes | Yes | 5
Smith, 2005 ^161^ | Yes | Not described | Yes | Yes | No | 3
Choi, 2004 ^77^ | Yes | Not described | No | No | Yes | 2
Matthews, 2005 ^70^ | Yes | Not described | Yes | Yes | Yes | 4
Derosa, 2004 ^90^ | Yes | Not described | No | No | Yes | 2
Schernthaner, 2004 ^106^ | Yes | Yes | Nr | Not described | Yes | 3
Tan, 2004 ^65^ | Yes | Not described | Nr | Not described | Yes | 2
Baksi, 2004 ^126^ | Yes | Not described | Yes | Not described | Yes | 3
Tan, 2004 ^69^ | Yes | Not described | Yes | Not described | Yes | 3
Natali, 2004 ^144^ | Yes | Not described | Yes | Yes | Yes | 4
Saad, 2004 ^164^ | Yes | Not described | No | No | Yes | 2
Rosenstock, 2004 ^131^ | Yes | Not described | No | No | Yes | 2
Raskin, 2004 ^74^ | Yes | Not described | Nr | No | Yes | 2
Yanagawa, 2004 ^62^ | Yes | Not described | Nr | No | No | 1
Manzella, 2004 ^148^ | Yes | Not described | No | No | Yes | 2
Feinbock, 2003 ^130^ | Yes | Not described | No | No | Yes | 2
Kerenyi, 2004 ^125^ | Yes | Not described | Yes | Yes | Yes | 4
Jovanovic, 2004 ^73^ | Yes | Not described | No | No | Yes | 2
Hanefeld, 2004 ^60^ | Yes | Not described | Yes | Yes | No | 3
Lawrence, 2004 ^54^ | Yes | Not described | No | No | Yes | 2
Garber, 2003 ^80^ | Yes | Yes | Yes | Yes | Yes | 5
Takagi, 2003 ^78^ | Yes | Not described | No | No | No | 1
Tosi, 2003 ^95^ | Yes | Not described | Yes | Yes | Yes | 4
Goldstein, 2003 ^82^ | Yes | Yes | No | No | Yes | 3
Herz, 2003 ^163^ | Yes | Not described | Yes | Not described | Yes | 3
Bech, 2003 ^197^ | Yes | Not described | Yes | Not described | No | 2
Derosa, 2003 ^97^ | Yes | Not described | No | No | Yes | 2
Barnett, 2003 ^172^ | Yes | Not described | Yes | Yes | Yes | 4
Fujioka, 2003 ^105^ | Yes | Not described | Yes | Yes | Yes | 4
Del Prato, 2003 ^149^ | Yes | Not described | Yes | Yes | Yes | 4
Pavo, 2003 ^59^ | Yes | Not described | Yes | Not described | Yes | 3
Luis Bautista, 2003 ^193^ | Yes | Not described | Yes | Yes | Yes | 4
Vongthavaravat, 2002 ^170^ | Yes | Yes | No | No | No | 2
Virtanen, 2003 ^143^ | Yes | Not described | Nr | Not described | Yes | 2
Vakkilainen, 2002 ^122^ | Yes | Not described | Yes | Yes | Yes | 4
Hallsten, 2002 ^58^ | Yes | Not described | No | No | Yes | 2
Scherbaum, 2002 ^141^ | Yes | Not described | Yes | Not described | Yes | 3
Blonde, 2002 ^81^ | Yes | Not described | Yes | Not described | Yes | 3
St John Sutto, 2002 ^67^ | Yes | Not described | No | No | Yes | 2
Rachmani, 2002 ^150^ | Yes | Yes | No | No | Yes | 3
Saloranta, 2002 ^241^ | Yes | Not described | Yes | Yes | Yes | 4
Marre, 2002 ^84^ | Yes | Not described | Yes | Not described | Yes | 3
Garber, 2002 ^79^ | Yes | Not described | Yes | Yes | Yes | 4
Gomez-Perez, 2002 ^102^ | Yes | Not described | Yes | Not described | Yes | 3
Khan, 2002 ^51^ | Yes | Not described | No | No | Yes | 2
Charpentier, 2001 ^89^ | Yes | Not described | Yes | Not described | Yes | 3
Rosenblatt, 2001 ^162^ | Yes | Yes | Yes | Not described | Yes | 4
Madsbad, 2001 ^119^ | Yes | Not described | Yes | Not described | Yes | 3
Kipnes, 2001 ^166^ | Yes | Not described | Yes | Not described | Yes | 3
Amador-Licona, 2000 ^85^ | Yes | Not described | No | No | Yes | 2
Lebovitz, 2001 ^169^ | Yes | Not described | No | No | No | 1
Patel, 1999 ^167^ | Yes | Inappropriate | Yes | Not described | Yes | 2
Phillips, 2001 ^168^ | Yes | Not described | Yes | Not described | Yes | 3
Moses, 2001 ^218^ | Yes | Not described | Yes | Not described | Yes | 3
Einhorn, 2000 ^160^ | Yes | Not described | Yes | Not described | Yes | 3
Fonseca, 2000 ^103^ | Yes | Yes | Yes | Yes | Yes | 5
Nakamura, 2000 ^64^ | Yes | Not described | No | No | No | 1
Horton, 2000 ^96^ | Yes | Not described | Yes | Yes | Yes | 4
Aronoff, 2000 ^165^ | Yes | Not described | Yes | Not described | No | 2
Hanefeld, 2000 ^190^ | Yes | Not described | Yes | Yes | No | 3
Hasche, 1999 ^138^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 2000 ^171^ | Yes | Not described | Yes | Not described | No | 2
Gregorio, 1999 ^129^ | Yes | Yes | No | No | Yes | 3
Jovanovic, 2000 ^194^ | Yes | Yes | Yes | Yes | Yes | 5
Willms, 1999 ^99^ | Yes | Not described | Yes | Yes | Yes | 4
Erle, 1999 ^127^ | Yes | Not described | Yes | Not described | Yes | 3
Landgraf, 1999 ^121^ | Yes | Not described | Yes | Yes | Yes | 4
Marbury, 1999 ^116^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 1999 ^117^ | Yes | Not described | Yes | Yes | Yes | 4
Testa, 1998 ^198^ | Yes | Not described | Yes | Not described | Yes | 3
Goldberg, 1998 ^139^ | Yes | Not described | Yes | Not described | Yes | 3
1998, ^16^ | Yes | Yes | No | No | No | 2
Schade, 1998 ^135^ | Yes | Not described | Yes | Not described | Yes | 3
1998, ^128^ | Yes | Not described | No | No | No | 1
Lee, 1998 ^259^ | Yes | Not described | Yes | Yes | Yes | 4
Simonson, 1997 ^136^ | Yes | Not described | Yes | Not described | Yes | 3
Rosenstock, 1996 ^189^ | Yes | Not described | Yes | Not described | Yes | 3
Dills, 1996 ^107^ | Yes | Not described | Yes | Not described | Yes | 3
Goldberg, 1996 ^134^ | Yes | Not described | Yes | Not described | Yes | 3
Grant, 1996 ^154^ | Yes | Not described | Yes | Not described | No | 2
Vray, 1995 ^137^ | Yes | Not described | Yes | Not described | Yes | 3
DeFronzo, 1995 ^88^ | Yes | Not described | Yes | Yes | Yes | 4
1995, ^92^ | Yes | Not described | No | No | No | 1
Hermann, 1994 ^87^ | Yes | Yes | Yes | Yes | No | 4
Campbell, 1994 ^83^ | Yes | Yes | No | No | Yes | 3
Birkeland, 1994 ^110^ | Yes | Not described | Yes | Yes | Yes | 4
Rosenstock, 1993 ^109^ | Yes | Not described | No | No | Yes | 2
Carlson, 1993 ^108^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 1993 ^120^ | Yes | Yes | No | No | Yes | 3
Leonhardt, 1991 ^263^ | Yes | Yes | No | No | Yes | 3
Teupe, 1991 ^155^ | Yes | Not described | No | No | Yes | 2
Noury, 1991 ^86^ | Yes | Not described | Nr | No | Yes | 2
Hermann, 1991 ^94^ | Yes | Yes | Yes | Yes | No | 4
Schneider, 1991 ^173^ | Yes | Inappropriate | Yes | Not described | Yes | 2
Hermann, 1991 ^159^ | Yes | Not described | Yes | Not described | Yes | 3
Dornan, 1991 ^260^ | Yes | Not described | Yes | Not described | No | 2
Kilo, 1988 ^147^ | Yes | Not described | No | No | No | 1
1985, ^91^ | Yes | Not described | No | No | No | 1
Harrower, 1985 ^113^ | Yes | Not described | No | No | Yes | 2
Baba, 1983 ^133^ | Yes | Not described | Yes | Not described | Yes | 3
Tseng, 2005 ^140^ | Yes | Not described | Yes | Not described | No | 2
Wolever, 2000 ^98^ | Yes | Not described | No | No | No | 1
Cefalu, 1998 ^261^ | Yes | Not described | Yes | Not described | No | 2
Turner, 1998 ^93^ | Yes | Not described | No | No | Yes | 2
Garber, 2006 ^71^ | Yes | Not described | Yes | Yes | Yes | 4
Zhu, 2003 ^188^ | Yes | Yes | Yes | Yes | Yes | 5
Bakris, 2003 ^66^ | Yes | Not described | No | No | No | 1
Draeger, 1996 ^112^ | Yes | Not described | Yes | Yes | Yes | 4
Derosa, 2003 ^118^ | Yes | Yes | Yes | Yes | Yes | 5
Garber, 1997 ^217^ | Yes | Not described | Yes | Yes | Yes | 4

Table 15 Evidence Table. Study Design Characteristics Table for Studies Reporting on Distal-Diabetes Related Complications (Key Question 2)

Author, year | Study design | Country | Pharmaceutical support | Study duration (planned/mean) | Exclusion criteria
Study group
Simpson, 2006 ^14^ | Cohort | Canada | No | 4.6 years (mean followup) | Age <30, other
Nishio, 2006 ^151^ | RCT | Japan | No | 6 months (planned duration) | Any liver disease, any kidney disease, no type 2 diabetes, other
Weissman, 2005 ^100^ | RCT | US | Yes | 24 weeks (planned duration) | Age <18 and >75, any liver disease, any kidney disease, history of CVD, HbA1c <6.5 or >8.5 for patients having received prior combination treatment; <7 or >10 prior monotherapy or drug naive patients, no type 2 diabetes, other
Rosenstock, 2006 ^124^ | RCT | US, Canada | No | NR | Age <60, history of CVD, no type 2 diabetes, other
Bailey, 2005 ^101^ | RCT | UK, 14 European countries | Yes | 24 weeks (planned duration) | Age <18 or >70, history of CVD, no type 2 diabetes, other
Dormandy, 2005 ^185^ PROactive | RCT | 19 European countries | Yes | NR | Age <35 or >75, any liver disease, HbA1c <6.5% for assay or lab equivalent DCCT, no type 2 diabetes, other
Eurich, 2005 ^179^ , | Cohort | Canada | No | 2.1 years (mean followup) | History of CVD, treatment experienced, other
Saskatchewan Health database
Johnson, 2005 ^13^ | Cohort | Canada | No | Median followup periods for each group ranged from 4.6 to 5.6 yeas | Age <30, no type 2 diabetes, other
Saskatchewan health database
Cryer, 2005 ^176^ | RCT | US | Yes | 12 months (planned duration) | Age <18, any liver disease, any kidney disease, no type 2 diabetes, other
COSMIC Approach Study
Schernthaner, 2004 ^56^ | RCT | Europe | No | 12 months (planned duration) | Age <35 or >75, treatment experienced, HbA1c <7.5% or >11%, no type 2 diabetes
Choi, 2004 ^77^ | RCT | Korea | No | 6 months (planned duration) | Any liver disease, any kidney disease, other
Baksi, 2004 ^126^ | RCT | 7 European countries | Yes | 26 weeks (planned duration) | Age <35 or >80, any liver disease, history of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Gulliford, 2004 ^177^ | Cohort | UK, Wales, Scotland, and Ireland | No | Median followup for each group ranged from 1.67 to 3.49 years | Treatment experienced, no type 2 diabetes, other
UK General Practice Research Database
Yanagawa, 2004 ^62^ | RCT | Japan | No | 12 weeks (planned duration) | Age <40 or >80, any liver disease, HbA1c <7 or >10, no type 2 diabetes, other
Manzella, 2004 ^148^ | RCT | Italy | No | 4 months (planned duration) | History of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Mannucci, 2004 ^181^ | Cohort | Italy | No | 220.4 (mean followup) | No type 2 diabetes, other
Hanefeld, 2004 ^60^ | RCT | Canada, UK, Hungary, Finland, Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and Netherlands | Yes | NR | Age <35 or >75, history of CVD, HbA1c <7.5 or >11, no type 2 diabetes, other
QUARTET study group
Lawrence, 2004 ^54^ | RCT | UK | Yes | 12 titration, 12 week maintenance (planned duration) | Age <45 or >80, any liver disease, any kidney disease, history of CVD, HbA1c for diet treated diabetes: <7% or >10% for low-dose oral hypoglycemic therapy: >7.5%, no type 2 diabetes, other
Meier, 2003 ^182^ | Cohort | Germany | No | NR | Hba1c < 6.2%, no type 2 diabetes, other
The Langendreer Myocardial Infarction and Blood Glucose in Diabetic Patients Assessment (LAMBDA)
Garber, 2003 ^80^ | RCT | US | Yes | 16 weeks (planned duration) | Age < 20 and age>79, any liver disease, any kidney disease, treatment experienced, HbA1c > 7 and <12%, no type 2 diabetes, other
Takagi, 2003 ^78^ | RCT | Japan | No | NR | Any liver disease, any kidney disease, no type 2 diabetes, other
Goldstein, 2003 ^82^ | RCT | US | Yes | 18 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, HbA1c <7.5 and >12.0, other
Herz, 2003 ^163^ | RCT | Canada and Spain | Yes | 16 weeks (planned duration) | Any liver disease, any kidney disease, treatment experienced, HbA1c < 6.5% or HbA1c>9.8%, no type 2 diabetes, other
Barnett, 2003 ^172^ | RCT | UK | No | 26 weeks (planned duration) | Age <30 or age > 80, any liver disease, HbA1c <7.5%, no type 2 diabetes, other
Fujioka, 2003 ^105^ | RCT | US | Yes | 24 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, HbA1c >8.5% and FPG>200 mg/dl while on MIR for >=8 weeks, no type 2 diabetes, other
Zhu, 2003 ^188^ | RCT | China | Yes | 24 weeks (planned duration) | Age <40 or age>70, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7.5%, no type 2 diabetes, other
Luis Bautista, 2003 ^193^ | RCT | US | Yes | NR | Age <35 or >80, HbA1c <8.0% or >10.5%, no type 2 diabetes, other
Bakris, 2003 ^66^ | RCT | likely US and UK | Yes | 52 weeks (planned duration) | NR
Vongthavaravat, 2002 ^170^ | RCT | India, Thailand, Philippines, Tunisia, Argentina, and Brazil | Yes | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, no type 2 diabetes, other
Virtanen, 2003 ^143^ | RCT | Finland | Yes | 26 weeks (planned duration) | Age <45 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, retinopathy, no type 2 diabetes, other
Johnson, 2002 ^12^ | Cohort | Canada | No | 5.1 years (mean followup) | Age <30, other
Saskatchewan health database
Hallsten, 2002 ^58^ | RCT | Finland | Yes | 26 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
St John Sutto, 2002 ^67^ | RCT | US | Yes | 52 weeks (planned duration) | Age <40 or age >80, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Rachmani, 2002 ^150^ | RCT | Israel | No | 4 years (planned duration) | Age < 40 or > 75, no type 2 diabetes, other
Gomez-Perez, 2002 ^102^ | RCT | Mexico | Yes | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Fisman, 2001 ^186^ | Cohort | Israel | No | 7.7 years (mean followup) | Age < 45 or >74, any liver disease, any kidney disease, other
Kipnes, 2001 ^166^ | RCT | US | Yes | NR | Age <30 or >75, any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <8, no type 2 diabetes, other
Gegick, 2001 ^192^ | Cohort | US | Yes | 12.8 (mean followup) | Hba1c had not had at least two baseline determinations while receiving maintenance troglitazone therapy, no type 2 diabetes, other
Amador-Licona, 2000 ^85^ | RCT | Mexico | No | 12 weeks (planned duration) | Age >65, any liver disease, history of CVD, other
Lebovitz, 2001 ^169^ | RCT | US | No | 26 weeks (planned duration) | Age < 36 or >81, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Fonseca, 2000 ^103^ | RCT | US | No | 26 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, neuropathy, no type 2 diabetes, other
Nakamura, 2000 ^64^ | RCT | Japan | No | 3 months (planned duration) | Any liver disease, history of CVD, treatment experienced, HbA1c <6.5%, no type 2 diabetes, other
Horton, 2000 ^96^ | RCT | US | Yes | 24 weeks (planned duration) | Age <30, any kidney disease, HbA1c <6.8% or >11%, no type 2 diabetes, other
Aronoff, 2000 ^165^ | RCT | US | Yes | 26 weeks (planned duration) | Any liver disease, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c <7%, no type 2 diabetes, other
Hanefeld, 2000 ^190^ | RCT | Europe | Yes | 12 weeks (planned duration) | Age <30 or >75, any kidney disease, history of CVD, neuropathy, retinopathy, HbA1c mean level of two tests <6.8 or >10.5, no type 2 diabetes, other
Olsson, 2000 ^178^ | Cohort | Sweden | No | 6.1 (0.1–13.0) years (mean followup) | No type 2 diabetes
Hasche, 1999 ^138^ | RCT | Germany | No | 104 weeks (planned duration) | Age < 40 or >80, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <7.5 or >9.5%, no type 2 diabetes, other
Klamann, 2000 ^183^ | Cohort | Germany | No | NR | No type 2 diabetes, other
Jovanovic, 2000 ^194^ | RCT | US | Yes | 24 weeks (planned duration) | Age <40 or > 75, any liver disease, any kidney disease, history of CVD, HbA1c with ODM (naive): <6.5%; with ODM-treatment: > 12%, no type 2 diabetes, other
Marbury, 1999 ^116^ | RCT | US and Canada | Yes | 12 months (planned duration) | Age >37 or <75, any liver disease, any kidney disease, history of CVD, treatment experienced, retinopathy, HbA1c <6.5% or 14.6%, no type 2 diabetes, other
Wolffenbuttel, 1999 ^117^ | RCT | Germany, Austria, and Netherlands | No | 12 months (planned duration) | Age <40 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, HbA1c <6.5 if treated with diet only; >12% if treated with diet plus oral, other
Garratt, 1999 ^10^ | Cohort | US | No | Mean followup for each group ranged from 2.3 to 3.8 years (mean followup) | No type 2 diabetes, other
Goldberg, 1998 ^139^ | RCT | US | Yes | 18 weeks (planned duration) | Age <40 and >75, no type 2 diabetes, other
1998, ^15^ | RCT | UK | Yes | NR | Age <25 or >65, treatment experienced, no type 2 diabetes, other
UKPDS
1998, ^16^ | RCT | UK | Yes | NR | Age <25 or >65, any kidney disease, history of CVD, treatment experienced, retinopathy, no type 2 diabetes, other
UKPDS
Sonnenberg, 1997 ^191^ | RCT, cross-over | US | Yes | 4 weeks (planned duration) | Age <40 or >80, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
Rosenstock, 1996 ^189^ | NR | NR | No | NR | No type 2 diabetes, other
Draeger, 1996 ^112^ | RCT | UK, Europe, Asia, South Africa, and South America | No | 12 months (planned duration) | Age < 40 or > 80, any liver disease, any kidney disease, treatment experienced, no type 2 diabetes, other
Lomuscio, 1996 ^11^ | unable to tell - may be cohort or case-control | Italy | No | NR | Other
DeFronzo, 1995 ^88^ | RCT | US | No | 29 weeks (planned duration) | Age <40 or >70, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Ikeda, 1994 ^195^ | Cohort | Japan | No | NR | Age <50 or >70, no type 2 diabetes, other
Hermann, 1994 ^87^ | RCT | Sweden | Yes | 6 months (planned duration) | No type 2 diabetes, other
Carlson, 1993 ^108^ | RCT | US | Yes | 12 weeks (planned duration) | Age <30 or >75, any liver disease, any kidney disease, no type 2 diabetes, other
Teupe, 1991 ^155^ | RCT | Germany | No | 2 years (planned duration) | Age >70, any liver disease, any kidney disease, history of CVD, no type 2 diabetes, other
Akanuma, 1988 ^196^ | RCT | Japan | No | 5 years (planned duration) | No type 2 diabetes, other
Diabetic Retinopathy Program
Baba, 1983 ^133^ | RCT | Japan | No | 24 weeks (planned duration) | No type 2 diabetes, other
Inzucchi, 2005 ^184^ | Cohort | US | No | NR | Age <65, no type 2 diabetes, other
Florkowski, 2001 ^187^ | Cohort | New Zealand | No | NR | Diagnosed diabetes before age 30, no type 2 diabetes, other

RCT = Randomized controlled trial; CVD = cardiovascular disease; HbA1c = Hemoglobin A1c; MIR = Metformin Immediate Release; US = United States; UK = United Kingdom; DCCT = Diabetes Control and Complications Trial-traceable assay; FPG = fasting plasma glucose; ODM = oral diabetes medication

Table 16 Evidence Table. Study Population Table for Studies Reporting on Distal Diabetes-Related Complications (Key Question 2)

Author, year | Group, N | Mean age (age range) | Male, n (%) | Race, n (%) | Mean BMI in kg/m^2^ (other measure) | Mean weight (other measure) | Mean HbA1c | Mean duration of diabetes
Study group
Simpson, 2006 ^14^ | Metformin, N=769 | 63.2 | 419 (54) | NR | NR | NR | NR | NR
| Metformin, N=768 | 64.6 | 409 (53) | NR | NR | NR | NR | NR
| Glyburide, N=2071 | 66.4 | 1148 (55) | NR | NR | NR | NR | NR
| Glyburide, N=2067 | 67.8 | 1239 (60) | NR | NR | NR | NR | NR
Nishio, 2006 ^151^ | Control group (no placebo), N=28 | 67.5 | 20 (71.4) | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.6 | NR | 6.9 | NR
| Pioglitazone, N=26 | 66.2 | 19 (73.1) | AA: 0; C: 0; Asian: 0; H: 0; O: (100) | 24.6 | NR | 7.7 | NR
Weissman, 2005 ^100^ | Metformin + rosiglitazone, N=382 | 55.5 | NR | NR | 34.4 | 98.2 | 8.05 | NR
| Metformin, N=384 | 55.7 | NR | NR | 33.8 | 96.7 | 7.97 | NR
Rosenstock, 2006 ^124^ | Glipizide + rosiglitazone, N=116 | 68.7 | (74.8) | NR | 30.2 | NR | 7.72 | 6.8
| Placebo + glipizide, N=111 | 68.2 | (71.8) | NR | 30.5 | NR | 7.65 | 6.6
Bailey, 2005 ^101^ | Metformin + rosiglitazone, N=288 | 58.1 | 168 (58) | AA: 2 (1); C: 280 (97); Asian: 3 (1); H: 0; O: 3 (1) | 32.2 | 90.9 | 7.4 | 6
| Metformin, N=280 | 57.6 | 159 (57) | AA: 1 (<1); C: 273 (98); Asian: 3 (1); H: 0; O: 3 (1) | 32.1 | 89.5 | 7.5 | 6.1
Dormandy, 2005 ^185^ | Pioglitazone, N=2605 | 61.9 (54.3 – 69.5) | 1735 (67) | AA: 0; C: 2564 (98); Asian: 0; H: 0; O: 0 | 30.7 | NR | Median 7.8 | Median 8
PROactive | Placebo, N=2633 | 61.6 (53.8 – 69.4) | 1728 (66) | AA: 0; C: 2600 (99); Asian: 0; H: 0; O: 0 | 31 | NR | Median 7.9 | Median 8
Eurich, 2005 ^179^ | Unspecified sulfonylurea, N=773 | 74.8 | 451 (58) | NR | NR | NR | NR | NR
Saskatchewan Health database | Metformin, N=208 | 72.5 | 123 (59) | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, N=852 | 70 | 472 (55) | NR | NR | NR | NR | NR
Johnson, 2005 ^13^ | Unspecified sulfonylurea, N=2138 | 67.8 (55.4 – 80.2) | (59) | NR | NR | NR | NR | NR
Saskatchewan health database | Metformin, N=923 | 64.3 (51.9 – 76.7) | (52) | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, N=1081 | 62 (49.7 – 74.3) | (54) | NR | NR | NR | NR | NR
Cryer, 2005 ^176^ | Diet + metformin + existing metformin, N=7227 | 58.3 | (49.3) | AA: (16.2); C: (78); Asian: (2.9); H: 0; O: (2.8) | 92.5 | NR | 4.9 | NR
COSMIC Approach Study | Diet + usual care, N=1505 | 58.8 | (49.5) | AA: (17.5); C: (76.2); Asian: (2.7); H: 0; O: (3.6) | 92.2 | NR | 4.7 | NR
Schernthaner, 2004 ^56^ | Placebo + diet + pioglitazone, N=597 | 57 | 314 (52.6) | 31.2 | 88.2 | 8.7 | 3.4 | NR
| Placebo + diet + metformin, N=597 | 56 | 345 (57.8) | 31.4 | 89.7 | 8.7 | 3.1 | NR
Choi, 2004 ^77^ | Rosiglitazone + diet, 38 | 60.9 | 24 | NR | 24.9 | 67.6 | 7.79 | 7.5
| Uptitration of existing medications, 45 | 59.9 | 34 | NR | 24.8 | 68.1 | 7.72 | 7.2
Baksi, 2004 ^126^ | Glyclazide, N=241 | 61.9 | 151 (62.7) | AA: 1 (0.4); C: 235 (97.5); Asian: 1 (0.4); H: 0; O: 4 (1.7) | 29.7 | NR | 8.6 | 6.9
| Glyclazide + rosiglitazone, N=225 | 61.1 | 129 (57.3) | AA: 1 (0.4); C: 219 (97.3); Asian: 3 (1.3); H: 0; O: 2 (0.9) | 30.2 | NR | 8.5 | 6.5
Gulliford, 2004 ^177^ | Unspecified sulfonylurea, N=6620 | 67 | 3644 (55) | NR | NR | NR | NR | NR
UK General Practice Research Database | Metformin + unspecified sulfonylurea, N=1868 | 61 | 945 (51) | NR | NR | NR | NR | NR
| Metformin, N=2232 | 61 | 1120 (50) | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, N=867 | 58 | 389 (45) | NR | NR | NR | NR | NR
Yanagawa, 2004 ^62^ | Glyclazide, N=21 | 54 | 15 | NR | 24 | NR | 8.3 | 6
| Pioglitazone, N=19 | 54 | 13 | NR | 24.6 | NR | 8.3 | 6.7
Manzella, 2004 ^148^ | Placebo + diet, N=60 | 57 (all patients) | 33 | NR | 29.2 | NR | 8.1 | NR
| Diet + metformin, N=60 | 57 (all patients) | 31 | NR | 29.5 | NR | 8 | NR
Mannucci, 2004 ^181^ | Metformin + unspecified sulfonylurea (women), N=197 | 67.6 | (0) | NR | 28.8 | NR | 8.9 | 14.5
| SU or biguanide or insulin (women), N=237 | 68.7 | (0) | NR | 27.2 | NR | 8.1 | 13.5
| Metformin + unspecified sulfonylurea (men), N=179 | 64.2 | (100) | NR | 27.8 | NR | 8.6 | 14
| SU or biguanide or insulin (men), N=314 | 62.8 | (100) | NR | 26.7 | NR | 8 | 10.5
Hanefeld, 2004 ^60^ | Placebo + unspecified sulfonylurea + pioglitazone, N=31 | 60 | 171 (53.6) | AA: 2 (0.6); C: 317 (99.4); Asian: 0; H: 0; O: 0 (0) | 30.2 | 85.3 | 8.82 | 7
QUARTET study group | Placebo + metformin + unspecified sulfonylurea, N=320 | 60 | 175 (54.7) | AA: 3 (0.9); C: 315 (98.4); Asian: 0; H: 0; O: 2 (0.6) | 30 | 84.9 | 8.8 | 7.1
Lawrence, 2004 ^54^ | Metformin, N=20 | 59.5 | 12 | NR | median 29.2 | 8.04 | NR | NR
| Glyclazide, N=20 | 63.5 | 13 | NR | median 28.7 | 7.85 | NR | NR
| Pioglitazone, N=20 | 60.4 | 14 | NR | median 30.6 | 7.43 | NR | NR
Meier, 2003 ^182^ | Glibenclamide, N=77 | 73 | 33 | NR | 26 | 71 | 8.4 | 10
The Langendreer Myocardial Infarction and Blood Glucose in Diabetic Patients Assessment (LAMBDA) | Not glibenclamide (other diabetes medications), N=75 | NR | NR | NR | NR | NR | NR | NR
Garber, 2003 ^80^ | Metformin + glyburide, N=171 | 55.6 | 76 (44) | AA: 18 (10.5); C: 132 (77.2); Asian: 0; H: 15 (8.8); O: 6 (3.5) | 31.4 | 91.9 | 8.8 | 3
| Metformin, N=164 | 54.7 | 71 (43.3) | AA: 11 (6.7); C: 132 (80.5); Asian: 0; H: 15 (9.1); O: 6 (3.7) | 31.4 | 92.8 | 8.5 | 2.6
| Glyburide, N=151 | 55.3 | 66 (43.7) | AA: 11 (7.3); C: 123 (81.5); Asian: 0; H: 12 (7.9); O: 5 (3.3) | 31.1 | 91 | 8.7 | 3
Takagi, 2003 ^78^ | Pioglitazone, N=23 | 64 | 20 | NR | 25.6 | NR | 6.8 | NR
| Control group (conventional antidiabetic therapy), N=21 | 65 | 14 | NR | 24.5 | | 6.7
Goldstein, 2003 ^82^ | Metformin + glipizide, N=87 | 54.6 | (58.6) | AA: (11.5); C: (72.4); Asian: (0); H: (16.1); O: 0 | 31.7 | 94 | 8.7 | 5.9
| Glipizide, N=84 | 57.4 | (64.3) | AA: (11.9); C: (71.4); Asian: (2.4); H: (14.3); O: 0 | 30.6 | 89.9 | 8.9 | 6.5
| Metformin, N=76 | 56.6 | (61.8) | AA: (15.8); C: (65.8); Asian: (1.3); H: (17.1); O: 0 | 31.6 | 93.8 | 8.7 | 7.3
Herz, 2003 ^163^ | Placebo, N=99 | 58 (33–85) | 49 (49.5) | AA: 0 (0); C: 96 (97); Asian: 3 (3); H: 0 (0); O: 0 | 31.7 | 86.3 | 7.5 | NR
| Pioglitazone, N=99 | 59 (24–79) | 59 (59.6) | AA: 0 (0); C: 97 (98); Asian: 1 (1); H: 1 (1); O: 0 | 31.7 | 86.6 | 7.5 | NR
| Pioglitazone, N=99 | 58.1 (24–84) | 52 (52.5) | AA: 0 (0); C: 93 (93.9); Asian: 1 (3); H: 3 (3); O: 0 | 30.8 | 84.1 | 7.6 | NR
Barnett, 2003 ^172^ | Placebo + unspecified sulfonylurea, N=87 | 54.1 (32–78) | (75) | AA: 0 (0); C: 0 (0); Asian: 0 (0); H: 0 (0); O: 100 | 26.4 | NR | 9.06 | 6.5
| Unspecified sulfonylurea + rosiglitazone, N=84 | 54.3 (28–76) | (80) | AA: 0 (0); C: 0 (0); Asian: 0 (0); H: 0 (0); O: 100 | 26.8 | NR | 9.21 | 6.5
Fujioka, 2003 ^105^ | Placebo + diet + metformin XR, N=75 | 54 | 34 | NR | 32 | 92 | 7 | 3
| Placebo + diet + metformin XR, N=71 | 55 | 28 | NR | 31 | 88 | 7 | 3
| Placebo + Diet + metformin, N=71 | 54 | 31 | NR | 33 | 96 | 7.1 | 3
Zhu, 2003 ^188^ | Placebo + unspecified sulfonylurea, N=105 | 58.8 | (46) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 25.1 | NR | 9.8 | 7.6
| Unspecified sulfonylurea + rosiglitazone, N=215 | 59 | (41) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 24.8 | NR | 9.8 | 7.2
| Unspecified sulfonylurea + rosiglitazone, N=210 | 58.9 | (48) | AA: 0; C: 0; Asian: 100; H: 0; O: 0 | 24.9 | NR | 9.9 | 7.9
Luis Bautista, 2003 ^193^ | Diet + exercise + glimepiride, N=48 | 48.4 | 27 (56.3) | AA: 0; C: 0; Asian: 0; H: (100); O: 0 | 83.3 | 10 | 4.2 | NR
| Placebo + diet + exercise, N=22 | 50.7 | 11 (50) | AA: 0; C: 0; Asian: 0; H: (100); O: 0 | 76.3 | 10.5 | 5.7 | NR
Bakris, 2003 ^66^ | Glyburide, N=99 | 56.1 | 71 | NR | NR | NR | 9.5 | NR
| Rosiglitazone, N=104 | 55.1 | 75 | NR | NR | NR | 9.1 | NR
Vongthavaravat, 2002 ^170^ | Diet + unspecified sulfonylurea + rosiglitazone, N=164 | 54.6 (30–76) | 75 (\45.7) | AA: 6 (3.7); C: 66 (40.2); Asian: 91 (55.5); H: 0; O: 1 (0.6) | 27.1 | 69 | 9.1 | 5
| Diet + unspecified sulfonylurea, N=170 | 57.3 (37–77) | 72 (42.4) | AA: 4 (2.4); C: 62 (36.5); Asian: 101 (59.4); H: 0; O: 3 (1.8) | 27.1 | 68.8 | 8.9 | 6
Virtanen, 2003 ^143^ | Placebo + diet, N=14 | 58 | 10 | NR | 30.3 | 88.3 | 6.3 | NR
| Diet + rosiglitazone, N=14 | 58 | 10 | NR | 29.1 | 83.7 | 6.8 | NR
| Diet + metformin, N=13 | 58 | 8 | NR | 29.9 | 88.8 | 6.9 | NR
Johnson, 2002 ^12^ | Unspecified sulfonylurea, N=3033 | 67.2 | 1789 (59) | NR | NR | NR | NR | NR
Saskatchewan health database | Metformin, N=1150 | 63.8 | 621 (54) | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, N=4683 | 62.1 | 2543 (54.3) | NR | NR | NR | NR | NR
Hallsten, 2002 ^58^ | Placebo + diet, N=14 | 57.7 | 10 | NR | 30.3 | NR | 6.3 | NR
| Diet + metformin, N=13 | 57.8 | 8 | NR | 29.9 | NR | 6.9 | NR
| Diet + rosiglitazone, N=14 | 58.6 | 10 | NR | 29.3 | NR | 6.8 | NR
St John Sutto, 2002 ^67^ | Glyburide, N=99 | 56.1 (40–76) | (71) | AA: (3); C: (76); Asian: 0; H: 0; O: (21) | 65.7% >=27 | 9.5 | 6.2 | NR
| Rosiglitazone, N=104 | 55.1 (40–77) | (75) | AA: (5); C: (73); Asian: 0; H: 0; O: (22) | 67.3% >=27 | 9.1 | 5.3 | NR
Rachmani, 2002 ^150^ | Metformin stopped + diet, N=198 | 64 | 102 | NR | 28.4 | NR | 8.6 | 14
| Metformin continued + diet, N=195 | 65 | 103 | NR | 28.7 | NR | 8.6 | 15
Gomez-Perez, 2002 ^102^ | Placebo + metformin, N=34 | 53.4 (40–68) | 10 | AA: 0; C: 1; Asian: 0; H: 26; O: 7 | 28.5 | NR | NR | 9.1
| Metformin + rosiglitazone, N=35 | 51.7 (40–73) | 10 | AA: 0; C: 0; Asian: 0; H: 28; O: 7 | 28 | NR | NR | 11.1
| Metformin + rosiglitazone, N=36 | 54.2 (42–76) | 7 | AA: 0; C: 4; Asian: 0; H: 26; O: 6 | 27.6 | NR | NR | 10.7
Fisman, 2001 ^186^ | Diet, N=990 | 60.3 | (76) | NR | 27 | 76 | NR | NR
| Glyburide, N=953 | 59.8 | (76) | NR | 27 | 77 | NR | NR
| Metformin, N=79 | 59.5 | (66) | NR | 29 | 81 | NR | NR
| Metformin + glyburide, N=253 | 60.7 | (66) | NR | 27 | 75 | NR | NR
Kipnes, 2001 ^166^ | Placebo + unspecified sulfonylurea, N=187 | 56.9 | 109 | AA: 25; C: 141; Asian: 3; H: 18; O: 0 | 32 | NR | 9.9 | 19
| Unspecified sulfonylurea + pioglitazone, N=184 | 56.5 | 109 | AA: 20; C: 146; Asian: 3; H: 15; O: 0 | 31.4 | NR | 10 | 29
| Unspecified sulfonylurea + pioglitazone, N=189 | 56.6 | 113 | AA: 17; C: 156; Asian: 3; H: 13; O: 0 | 32.4 | NR | 9.9 | 26
Gegick, 2001 ^192^ | Pioglitazone, N=67 | 66 (57 – 75) | NR | NR | 98.3 | 7.1 | 14 | NR
| Rosiglitazone, N=77 | 59 (48.6 – 69.4) | NR | NR | 103 | 6.97 | 12 | NR
Amador-Licona, 2000 ^85^ | Glibenclamide, N=23 | 48.2 | 7 | NR | 30.4 | 73.2 | 8.4 | 4
| Metformin, N=28 | 49.3 | 11 | NR | 26.8 | 70.7 | 8.5 | 4.5
Lebovitz, 2001 ^169^ | Placebo, N=158 | 59 | 104 | NR | 29.9 | NR | 9.0 | 4.6
| Rosiglitazone, N=166 | 60 | 107 | NR | 30.2 | NR | 9.0 | 4.8
| Rosiglitazone, N=169 | 61 | 113 | NR | 29.1 | NR | 8.8 | 5.4
Fonseca, 2000 ^103^ | Placebo + metformin, N=113 | 58.8 | 74.3 | AA: (3.5); C: (81.4); Asian: 0; H: 0; O: (15) | 30.3 | NR | 8.6 | 7.3
| Metformin + rosiglitazone, N=116 | 57.5 | 62.1 | AA: (6.9); C: (80.2); Asian: 0; H: 0; O: (12.9) | 30.2 | NR | 8.9 | 7.5
| Metformin + rosiglitazone, N=110 | 58.3 | 68.2 | AA: (10); C: (77.3); Asian: 0; H: 0; O: (12.7) | 29.8 | NR | 8.9 | 8.3
Nakamura, 2000 ^64^ | Pioglitazone, N=15 | 60 | 7 | NR | NR | NR | 7.7 | 16
| Glibenclamide, N=15 | 61 | 8 | NR | NR | NR | 7.8 | 14
| Voglibose, N=15 | 56 | 8 | NR | NR | NR | 7.6 | 15
Horton, 2000 ^96^ | Nateglinide, N=179 | 58.6 | 110 | AA: (9.5); C: (82.1); Asian: (2.8); H: 0; O: 5.6 | 29.6 | NR | 8.3 | 4.7
| Metformin, N=178 | 56.8 | 121 | AA: (9.6); C: (79.2); Asian: (2.2); H: 0; O: 9 | 29.6 | NR | 8.4 | 7.5
| Metformin + nateglinide, N=172 | 58.4 | 101 | AA: (11.6); C: (82.6); Asian: (0.6); H: 0; O: 5.2 | 30 | NR | 8.4 | 4.5
| Placebo, N=172 | 59.6 | 104 | AA: (16.9); C: (78.5); Asian: (0.6); H: 0; O: 4.1 | 29.2 | NR | 8.3 | 4.6
Aronoff, 2000 ^165^ | Placebo, N=79 | 53.7 overall mean (29–75 overall age) | (58 overall) | AA: overall (8); C: overall (78); Asian: overall (2); H: overall (12); O: (1) | 90.4 | 10.4 | NR | NR
| Pioglitazone, N=81 | 53.7 overall mean (29–75 overall age) | (58overall) | AA: overall (8); C: overall (78); Asian: overall (2); H: overall (12); O: (1) | 93.5 | 10 | NR | NR
| Pioglitazone, N=81 | 53.7 overall mean (29–75 overall age) | (58overall) | AA: overall (8); C: overall (78); Asian: overall (2); H: overall (12); O: (1) | 91.2 | 10.2 | NR | NR
| Pioglitazone, N=87 | 53.7 overall mean (29–75 overall age) | (58overall) | AA: overall (8); C: overall (78); Asian: overall (2); H: overall (12); O: (1) | 90.3 | 10.2 | NR | NR
| Pioglitazone, N=80 | 53.7 overall mean (29–75 overall age) | (58overall) | AA: overall (8); C: overall (78); Asian: overall (2); H: overall (12); O: (1) | 90.8 | 10.3 | NR | NR
Hanefeld, 2000 ^190^ | Placebo, N=60 | 57.4 | 36 | NR | 28.3 | NR | 8.5 | 5.4
| Nateglinide, N=51 | 58 | 36 | NR | 29 | NR | 8.4 | 4.5
| Nateglinide, N=58 | 56.1 | 41 | NR | 28.1 | NR | 8.3 | 6.2
| Nateglinide, N=63 | 54.4 | 44 | NR | 28.6 | NR | 8.3 | 4.4
| Nateglinide, N=57 | 56.5 | 36 | NR | 28.8 | NR | 8.5 | 3.7
Olsson, 2000 ^178^ | Unspecified sulfonylurea, N=741 | NR | 26.3 | NR | 7.3 | NR | NR | NR
| Metformin + unspecified sulfonylurea, N=169 | 3.6 yr younger than group 1 | 28.8 | NR | 8.3 | NR | NR | NR
Hasche, 1999 ^138^ | Diet + acarbose, N=36 | 63.8 | 17 | NR | 26.1 | 74.3 | 8.5 | 1
| Placebo + diet, N=38 | 63.1 | 19 | NR | 26.7 | 75.5 | 8.3 | 1
Klamann, 2000 ^183^ | Glibenclamide, N=76 | 72 | 37 | NR | 26.8 | 73 | 8.4 | 10
| Not glibenclamide (other diabetes medications, diet or no treatment), N=89 | 73 | 54 | NR | 26.8 | 71 | 7.7 | 8
Jovanovic, 2000 ^194^ | Placebo, N=75 | 58.5 | 49 (65) | AA: 11 (15); C: 51 (68); Asian: 1 (1); H: 0; O: 12 (16) | 29.8 | NR | 8.6 | 6.8
| Repaglinide, N=140 | 57.9 | 96 (69) | AA: 14 (10); C: 107 (76); Asian: 0 (0); H: 0; O: 19 (14) | 29.4 | NR | 8.9 | 6.6
| Repaglinide, N=146 | 57.6 | 87 (60) | AA: 18 (12); C: 110 (75); Asian: 2 (1); H: 0; O: 16 (11) | 29.5 | NR | 8.7 | 6.3
Marbury, 1999 ^116^ | Repaglinide, N=362 | 58.3 | 242 (67) | AA: 33 (9); C: 279 (77); Asian: 0; H: 0; O: 50 (14) | 29.4 | NR | 8.7 | 7.2
| Placebo + glyburide, N=182 | 58.7 | 120 (66) | AA: 16 (9); C: 144 (79); Asian: 0; H: 0; O: 22 (12) | 29.1 | NR | 8.9 | 8.3
Wolffenbuttel, 1999 ^117^ | Repaglinide, N=286 | 61 years | (62) | NR | 28.4 | 81.5 | 7.1 | Median 6
| Placebo + glyburide, N=139 | 61 years | (68) | NR | 28 | 81.3 | 7 | Median 6
Garratt, 1999 ^10^ | Unspecified sulfonylurea, N=67 | 68.4 years | 40 (59.7) | NR | NR | NR | NR | NR
| Diet, insulin, or other oral diabetes medication, N=118 | 63.2 years | 73 (61.9) | NR | NR | NR | NR | NR
Goldberg, 1998 ^139^ | Placebo, N=33 | 56.4 | 25 (76) | AA: 0; C: 29 (88); Asian: 0; H: 0; O: 4 (12) | 30 | NR | 8.1 | 5.1
| Repaglinide, N=67 | 58.7 | 49 (74) | AA: 0; C: 58 (88); Asian: 0; H: 0; O: 8 (12) | 30.6 | NR | 8.3 | 5.6
UKPDS, 1998 ^15^ | Diet, N=411 | 53 | 193 (47) | AA: 0; C: (86); Asian: (6); H: 0; O: (8) | 31.8 | 87 | 7.1 | NR
| Diet + metformin, N=342 | 53 | 157 (46) | AA: 0; C: (85); Asian: (4); H: 0; O: (11) | 31.6 | 87 | 7.3 | NR
| Diet + glibenclamide, N=277 | 53 | 127 (46) | AA: 0; C: (87); Asian: (4); H: 0; O: (9) | 31.5 | 86 | 7.2 | NR
| Diet + unspecified sulfonylurea, N=269 | 58 | 164 (61) | AA: 0; C: (77); Asian: (13); H: 0; O: (10) | 29.4 | 82 | 7.6 | NR
| Diet + metformin + unspecified sulfonylurea, N=268 | 59 | 158 (59) | AA: 0; C: (77); Asian: (11); H: 0; O: (12) | 29.7 | 83 | 7.5 | NR
UKPDS, 1998 ^16^ | Diet, N=896 | 54 | 555 | AA: 0; C: (83); Asian: 0; H: 0; O: (16) | 27.5 | 77 | 6.2 | NR
| Diet + chlorpropamide, N=619 | 54 | 359 | AA: 0; C: (79); Asian: 0; H: 0; O: (21) | 27 | 75 | 6.3 | NR
| Diet + glibenclamide, N=615 | 54 | 381 | AA: 0; C: (84); Asian: 0; H: 0; O: (15) | 27.4 | 77 | 6.3 | NR
Sonnenberg, 1997 ^191^ | Glimepiride, N=53 | 61 | (70) | NR | NR | 86 | NR | 7.2
| Glimepiride, N=53 | NR | NR | NR | NR | NR | NR | NR
| Glimepiride, N=48 | NR | NR | NR | NR | NR | NR | NR
| Glimepiride, N=46 | NR | NR | NR | NR | NR | NR | NR
Rosenstock, 1996 ^189^ | Placebo, N=79 | 61.1 | (67) | NR | NR | 85.9 | 8 | Median 6
| Glimepiride, N=88 | 61.8 | (74) | NR | NR | 82.9 | 8.1 | Median 7
| Glimepiride, N=81 | 58.8 | (70) | NR | NR | 86.3 | 8.1 | Median 6
| Glimepiride, N=83 | 59.6 | (66) | NR | NR | 84.2 | 8 | Median 5
| Glimepiride, N=85 | 61.7 | (72) | NR | NR | 86.8 | 8.3 | Median 7
Draeger, 1996 ^112^ | Glibenclamide, N=520 | 60.7 (26–81) | 340 | AA: 0; C: 0; Asian: 74; H: 0; O: (26) | 26.5 | NR | 8.1 | 5
| Glimepiride, N=524 | 59.7 (27–81) | 325 | NR | 26.5 | NR | 8.1 | 5
DeFronzo, 1995 ^88^ | Metformin, N=143 | 53 | 62 | NR | 29.9 | 94.4 | 8.4 | 6
| Placebo, N=53 | 53 | 62 | NR | 29.2 | 92.2 | 8.2 | 6
| Placebo + metformin, N=210 | 55 | 96 | NR | 29.4 | 92.6 | 8.9 | 8.4
| Placebo + glyburide, N=209 | 56 | 103 | NR | 29.1 | 92.6 | 8.5 | 8.7
| Metformin + glyburide, N=213 | 55 | 98 | NR | 29 | 92.1 | 8.8 | 7.8
Ikeda, 1994 ^195^ | Diet, N=20 | 63.6 | 10 | NR | NR | NR | 7.3 | 13.2
| Glibenclamide, N=20 | 62.6 | 10 | NR | NR | NR | 7.7 | 13.5
Hermann, 1994 ^87^ | Diet + metformin, N=25 | 60 (34–74) | (63) | NR | NR | 78.6 | 6.9 | 4
| Diet + glibenclamide, N=21 | NR | NR | 82.6 | 6.7 | NR | NR | NR
| Diet + metformin + glibenclamide + other A, N=54 | NR | 80.2 | 6.8 | NR | NR | NR | NR
Carlson, 1993 ^108^ | Glyburide, N=104 | 59.2 (33–80) | 61 | AA: 11; C: 81; Asian: 0; H: 7; O: 5 | 7.6 | N=15/32/57 for <1/1–5/>5 yrs | NR | NR
| Glyburide, N=102 | 60.3 (38–78) | 62 | AA: 13; C: 81; Asian: 0; H: 4; O: 4 | 7.6 | N=6/42/54 for <1/1–5/>5 yrs | NR | NR
Teupe, 1991 ^155^ | Diet, N=50 | 56 | 20 | NR | NR | 86.1 | 9.6 | 6.4
| Diet + metformin, N=50 | 51.5 | 20 | NR | NR | 89.1 | 10 | 8.1
Akanuma, 1988 ^196^ | Glipizide, N=21 | 57 | 10 (47.6) | NR | Relative Wt at 1st Visit: 115% | 131 months | NR | NR
Diabetic Retinopathy Program | Unspecified sulfonylurea, N=19 | 58 | 10 (52.6) | NR | Relative Wt at 1st Visit: 115% | 115 months | NR | NR
| Diet, N=20 | 57 | 16 (80) | NR | Relative Wt at 1st Visit: 114% | 120 months | NR | NR
Baba, 1983 ^133^ | Glyclazide, N=146 | (<39 – >70) | 78 (53.42) | Obesity Index: <119: 71.9; >120: 28.1 | N=35/25/39/47 for <1/1–4/5–9/>=10 yrs | NR | NR | NR
| Glibenclamide, N=131 | (<39 – >70) | 55 (41.98) | Obesity Index: <119: 71; >120: 29 | N=30/35/31/35 for <1/1–4/5–9/>=10 yrs | NR | NR | NR
Inzucchi, 2005 ^184^ | Non-insulin-sensitizing antihyperglycemic, N=6641 | 76.8 +/- 7.1 | 3108 (46.8) | AA: 0; C: 5811 (87.5); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Metformin, N=1273 | 75.2 +/- 7.0 | 659 (51.8) | AA: 0; C: 1164 (91.4); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Unspecified TZD, N=819 | 75.8 +/- 6.9 | 385 (47) | AA: 0; C: 731 (89.3); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Metformin + unspecified TZD, N=139 | 73.6 +/- 6.8 | 74 (53.2) | AA: 0; C: 123 (88.5); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
Florkowski, 2001 ^187^ | Metformin, N=447 baseline for entire group | 62.2 (30–82) | 208 | NR | overall 28.4 | 6.3 (glycated hemoglobin) | overall 9.6 | NR

AA = African American; C = Caucasian; H = Hispanic; O = Other; XR = extended release; HbA1c = hemoglobin A1c; BMI = body-mass index; TZD = thiazolidinedione

Table 17 Evidence Table. Grading of the Body of Evidence for Distal Diabetes-Related Complications

| Key Question 2 Comparative Effectiveness of Distal Complications
| All Cause Mortality | CVD Mortality/Morbidity | Microvascular outcomes (retinopathy, neuropathy, nephropathy) | Peripheral vascular disease
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Thiazolidinedione vs. Metformin
[underlined: Quantity of Evidence:] | 2 | 3 | 2 | 3 (indirect)
Number of studies
Total number of patients studied | 1833 | 96 | 1838 | 6545
[underlined: Quality and Consistency of Evidence:] | high | high | high | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -0.5 | -1 | 0 | -0.5
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | NA
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -1 | -1 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | Very low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Thiazolidinediones vs Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 0 (direct) | 2 | 3 | 3 (indirect)
Number of studies | 7 (indirect)
Total number of patients studied | 10,548 | 246 | 191 | 7303
[underlined: Quality and Consistency of Evidence:] | low | high | high | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -1 | -0.5
Did the studies have important inconsistency? (-1) | -0.5 | 0 | 0 | NA
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -2 | -1 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 4 (direct) | 5 | 1 (direct); 1 (indirect) | 1 (indirect)
Number of studies | 5 (indirect)
Total number of patients studied | 7072 (direct) | 9,212 | 51 (direct); 2264 (indirect) | 2264
[underlined: Quality and Consistency of Evidence:] | low | medium | high | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -2 | -1 | -2 | -1
Did the studies have important inconsistency? (-1) | 0 | 0 | 0 | NA
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -1 | 0 | -2
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | -1 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | +0.5 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low to low | Very low to low | Very low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second Generation Sulfonylureas vs Meglitinide
[underlined: Quantity of Evidence:] | 1 | 2 | 0 | 0
Number of studies
Total number of patients studied | 576 | 1001 | 0 | 0
[underlined: Quality and Consistency of Evidence:] | high | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1
Did the studies have important inconsistency? (-1) | NA | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -2 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Metformin vs Metformin + Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 4 (direct) | 4 | 0 | 0
Number of studies | 3 (indirect)
Total number of patients studied | 5267 (direct) | 4026 | 0 | 0
[underlined: Quality and Consistency of Evidence:] | medium | low
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1
Did the studies have important inconsistency? (-1) | -0.5 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -2 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low to low | Very low
Grading of the quality of evidence of the efficacy/effectiveness of oral diabetes medications: Second generation Sulfonylurea vs Metformin + Second Generation Sulfonylureas
[underlined: Quantity of Evidence:] | 5(direct) | 6 | 1 | 1
Number of studies | 3(indirect)
Total number of patients studied | 21,218 | 14,010 | 45 | 545
[underlined: Quality and Consistency of Evidence:] | low | medium | high | high
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -2 | -1 | -2 | -1
Did the studies have important inconsistency? (-1) | -0.5 | -0.5 | 0 | NA
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest?) [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -1 | 0 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between intervention and recruitment outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2) | 0 | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low to Low | Very low | Very low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; very low = any estimate of effect is very uncertain.

Table 18 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications in randomized controlled trials: all cause mortality

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
UKPDS, 1998 ^15^ | RCT | All cause mortality/unclear mortality | Unspecified SU + diet, 269 | Metformin + Unspecified SU + diet, 268 | NR (NR) | NR (NR) | 31 | 47 | IR 19.1 | IR 30.3
| | | | | | | | | | HR 1.6 (1.02–2.52)
Other Direct Comparisons
Weissman, 2005 ^100^ | RCT | All cause mortality/unclear mortality | Metformin, 384 | Rosiglitazone + metformin, 382 | 1000 (esc) 2000 | 4 (esc) 8 | 0 | 1 | NR | NR
| | | | | | 1000 (fixed)
Schernthaner, 2004 ^56^ | RCT | All cause mortality/unclear mortality | Pioglitazone + placebo + diet, 597 | Metformin + placebo + diet, 597 | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | 3 | 2 | NR | NR
Hanefeld, 2004 ^60^ | RCT | All cause mortality/unclear mortality | Pioglitazone + Unspecified SU + placebo, 319 | Metformin + Unspecified SU + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | 1 | 2 | NR | NR
QUARTET study group | | | | | NR | NR
Garber, 2003 ^80^ | RCT | All cause mortality/unclear mortality | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 (esc) 2000 | 2.5 (esc) 10 | 0 | 0 | NR | NR
Garber, 2003 ^80^ | RCT | All cause mortality/unclear mortality | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 (esc) 2000 | 250 (esc) 1000 | 0 | 2 | NR | NR
| | | | | | 1.25 (esc) 5
Garber, 2003 ^80^ | RCT | All cause mortality/unclear mortality | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (esc) 10 | 250 (esc) 1000 | 0 | 2 | NR | NR
| | | | | | 1.25 (esc) 5
Goldstein, 2003 ^82^ | RCT | All cause mortality/unclear mortality | Metformin, 75 | Glipizide, 84 | 500 (esc) 2000 | 15 bid (fixed) | 0 | 0 | NR | NR
Goldstein, 2003 ^82^ | RCT | All cause mortality/unclear mortality | Metformin, 75 | Metformin + glipizide, 87 | 500 (esc) 2000 | 500 (esc) 2000 | 0 | 0 | NR | NR
| | | | | | 5 (esc) 20
Goldstein, 2003 ^82^ | RCT | All cause mortality/unclear mortality | Glipizide, 84 | Metformin + glipizide, 87 | 30 (fixed) | 500 (esc) 2000 | 0 | 0 | NR | NR
| | | | | | 5 (esc) 20
Fujioka, 2003 ^105^ | RCT | All cause mortality/unclear mortality | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 0 | 1 | NR | NR
Fujioka, 2003 ^105^ | RCT | All cause mortality/unclear mortality | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 0 | 0 | NR | NR
Marbury, 1999 ^116^ | RCT | All cause mortality/not specified | Glyburide (no trade drug specified) + placebo, 193 | Repaglinide, 383 | 2.5 (esc) 15 | 0.5 (esc) 12 | 1 | 3 | NR | NR
Draeger, 1996 ^112^ | RCT | All cause mortality/not specified | Glimepiride, 524 | Glibenclamide, 520 | 1 (esc) 8 | 2.5 (esc) 20 | 11 | 5 | NR | NR
Cryer, 2005 ^176^ | RCT | All cause mortality/unclear mortality | Metformin + existing medications + diet, 7227 | Diet + usual care, 1505 | 500 (esc) 2500 | NR (NR) | (1.1) | (1.3) | NR | NR
COSMIC Approach Study
Choi, 2004 ^77^ | RCT | Mortality | Rosiglitazone + existing oral diabetes medications, 38 | Uptitration of usual care, 45 | 8 (other) 4 | NR (esc) | 0 | 0 | NR | NR
Metformin Or Second Generation Sulfonylurea vs. Placebo
UKPDS, 1998 ^15^ | RCT | All cause mortality/unclear mortality | Metformin + diet, 342 | Diet, 411 | 850 (esc) 2550 | NA | 50 | 89 | IR 13.5 | IR 20.6, reference group
| | | | | | | | | HR 0.64 (0.45–0.91)
UKPDS, 1998 ^16^ | RCT | All cause mortality/unclear mortality | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 18.2 | 19.9 | RR 0.91 (0.73–1.15) | Reference group
Rachmani, 2002 ^150^ | RCT | All cause mortality/unclear mortality | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | 62 (32) | 64 (34) | no significant differences between groups
Pioglitazone vs. Placebo
Dormandy, 2005 ^185^ | RCT | Primary endpoint (all-cause mortality, non-fatal MI, stroke, acute coronary syndrome, endovascular or surgical intervention in the coronary or leg arteries, and amputation above the ankle) | Pioglitazone + existing diabetes medications, 2605 | Placebo + existing diabetes medications, 2633 | 15 (esc) 45 | NR (NR) | 514 | 572 | HR 0.90 (0.80–1.02) | Reference group
PROactive
Dormandy, 2005 ^185^ | RCT | Secondary endpoint: death from any cause, nonfatal MI (excluding silent MI), or stroke | Pioglitazone + existing diabetes medications, 2605 | Placebo + existing diabetes medications, 2633 | 15 (esc) 45 | NR (NR) | 358 | 301 | Adjusted HR 0.84 (0.72–0.98); 0.03 | HR ref
PROactive
Nishio, 2006 ^151^ | RCT | All cause mortality/unclear mortality | Pioglitazone, 26 | Control group (existing medications), 28 | 30 (fixed) | NR (NR) | 0 | 0 | NR | NR

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; NR = not reported; RCT = randomized controlled trial; ref = reference; MI = myocardial infarction; XR = extended release

Table 19 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications in non-randomized trials and cohort studies: all cause mortality

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Metformin Or Second Generation Sulfonylurea Monotherapy vs. Metformin + Second Generation Sulfonylurea
Gulliford, 2004 ^177^ | Cohort | All cause mortality/used research database to identify | Metformin, 3099 | Metformin + unspecified SU, 1868 | NR (NR) | NR (NR) | 144 | 127 | Reference | Adjusted HR 1.06 (0.85–1.31); 0.616
UK General Practice Research Database
Gulliford, 2004 ^177^ | Cohort | All cause mortality/used research database to identify | Unspecified SU, 8488 | Metformin + unspecified SU, 867 | NR (NR) | NR (NR) | 1030 | 32 | Reference group | Adjusted HR 0.95 (0.64–1.4); 0.801
UK General Practice Research Database
Eurich, 2005 ^179^ | Cohort | All cause mortality/unclear mortality | Unspecified SU | Metformin + SU | NR (NR) | NR (NR) | NR | NR | Reference group | Adjusted HR 0.61 (0.52–0.72)
Saskatchewan Health database
Johnson, 2002 ^12^ | Cohort | All cause mortality/mortality registry + vital statistics file of Saskatchewan database | Unspecified SU, 3033 | Metformin + unspecified SU, 4683 | NR (NR) | NR (NR) | 750 (24.7) | 635 (13.6) | RR 1 OR 1.0 (ref) | Adjusted RR 0.63 (0.58–0.75)
Saskatchewan health database | | | | | | | | | | Adjusted OR 0.66 (0.58–0.75)
Olsson, 2000 ^178^ | Cohort | All cause mortality/mortality registry | Unspecified SU, 741 | Metformin + unspecified SU, 169 | NR (NR) | NR (NR) | NR | NR | OR 1 | Adjusted OR 1.63 (1.27–2.09)
Metformin + Second Generation Sulfonylurea vs. Other Oral Diabetes Medications
Mannucci, 2004 ^181^ | Cohort | All cause mortality/city of Florence registry office or other registry offices | Metformin + Unspecified SU, 314 | SU or biguanide or insulin, 197 | Mean dose = 7.3 for glibenclamide; 338 for chlorpropamide; 1100 metformin; 60.1 phenformin | NR (NR) | NR | NR | Adjusted HR for women only: 2.08 (1.18–3.67) | Reference group
Mannucci, 2004 ^181^ | Cohort | All cause mortality/city of Florence registry office or other registry offices | Metformin + Unspecified SU, 314 | SU or biguanide or insulin, 179 | Mean dose = 7.3 for glibenclamide; 338 for chlorpropamide; 1100 metformin; 60.1 phenformin | NR (NR) | NR | NR | Adjusted HR for men only: 1.68 (1.01–2.79) | Reference group
Metformin vs. Second Generation Sulfonylurea
Eurich, 2005 ^179^ | Cohort | All cause mortality/unclear mortality | Metformin | SU | NR (NR) | NR (NR) | NR | NR | Adjusted HR 0.70 (0.54–0.91) | Reference group
Saskatchewan Health database
Evans*, 2006 ^180^ | Cohort | All cause mortality/unclear mortality | SU, 3331 | Metformin, 2286 | NR (NR) | NR (NR) | NR | NR | Adjusted RR 1.43 (1.15–1.77) | Reference group
Second Generation Sulfonylurea vs. Other
Garratt, 1999 ^10^ | Cohort | All cause mortality/mortality registry + medical record review + standardized questionnaire | Glibenclamide, 67 | Diet, insulin, or other oral diabetes medication, 118 | NR (NR) | NR (NR) | NR | NR | Adjusted OR 2.53 (1.13– 5.67) | Reference group
Lomuscio, 1996 ^11^ | Cohort | All cause mortality/unclear mortality | Glibenclamide, 106 | Not glibenclamide), 126 | at minimum 10 (NR) | NR (NR) | 12 (11) | 27 (25) | NR | NR
Meier, 2003 ^182^ | Cohort | Mortality post-myocardial infarction | Glibenclamide, 77 | Not glibenclamide (other diabetes medications), 75 | NR (NR) | NR (NR) | NR | NR | p=0.53 vs. GP2
The LAngendreer Myocardial Infarction and Blood Glucose in Diabetic Patients Assessment (LAMBDA)
Klamann, 2000 ^183^ | Cohort | Mortality/fatal myocardial infarction + CVD mortality ICD-9 413 for acute MI + used hospital records to see who died during hospitalization | Glibenclamide, 76 | Not glibenclamide (other diabetes medications or \diet or no treatment), 89 | 7.4 mean (NR) | NR (NR) | 25 (32.9) | 29 (33) | p=0.97 vs. GP2
Thiazolidinedione Or Metformin vs. Other Diabetes Medications
Inzucchi, 2005 ^184^ | Cohort | All cause mortality/Linkage with the Medicare Enrollment Database | Unspecified TZD, 819 | Non-insulin-sensitizing antihyperglycemic, 6641 | NR (NR) | NR (NR) | 237 (28.9) | 2014 (30.3) | Adjusted HR 0.92 (0.8–1.05); 0.221 | HR 1
Inzucchi, 2005 ^184^ | Cohort | All cause mortality/Linkage with the Medicare Enrollment Database | Metformin, 1273 | Non-insulin-sensitizing antihyperglycemic, 6641 | NR (NR) | NR (NR) | 246 (19.3) | 2014 (30.3) | Adjusted HR 0.92 (0.81–1.06); 0.255 | HR 1
Metformin Or Second Generation Sulfonylurea vs. Placebo/Diet
Simpson, 2006 ^14^ | Cohort | All cause mortality/vital statistics files of Saskatchewan Health database | Glyburide high dose | Glyburide low dose | High dose/above group median (NR) | Low dose/below group median (NR) | 41.5 | 70.2 | HR 1.29 (1.1–1.45)
Simpson, 2006 ^14^ | Cohort | All cause mortality/vital statistics files of Saskatchewan Health database | Metformin high dose | Metformin low dose | High dose/above group median (NR) | Low dose/below group median (NR) | 37.6 | 53.4 | HR 0.84 (0.70–1.1)
Fisman, 2001 ^186^ | Cohort | All cause mortality/mortality registry + matched the patients' ID number with their life status in the population registry | Metformin, 79 | Diet, 990 | NR (NR) | NR (NR) | NR | NR | IR 55.7 | IR 39.5; HR 1 (ref)
| | | | | | | | | Adjusted HR 1.26 (0.81–1.96)
Fisman, 2001 ^186^ | Cohort | All cause mortality/mortality registry + matched the patients' ID number with their life status in the population registry | Glyburide (no trade drug specified), 953 | Diet, 990 | NR (NR) | NR (NR) | NR | NR | IR 53.6 | IR 39.5; HR 1 (ref)
| | | | | | | | | HR 1.22 (1.02–1.45)
Florkowski, 2001 ^187^ | Cohort | All cause mortality/mortality registry + death certificates + clinic records | Metformin | Diet | NR (NR) | NR (NR) | NR | NR | HR 0.79 (0.4–1.58) | HR 1(ref)
Florkowski, 2001 ^187^ | Cohort | All cause mortality/mortality registry + death certificates + clinic records | Unspecified SU | Diet | NR (NR) | NR (NR) | NR | NR | HR 1 (0.56–1.79) | HR 1 (ref)
Metformin + Second Generation Sulfonylurea vs. Placebo
Fisman, 2001 ^186^ | Cohort | All cause mortality/mortality registry + matched the patients' ID number with their life status in the population registry | Metformin + glyburide (no trade drug specified), 253 | Diet, 990 | NR (NR) | NR (NR) | NR | NR | IR 75.8 | IR 39.5; HR 1 (ref)
| | | | | | | | | HR 1.53 (1.2–1.96)
Florkowski, 2001 ^187^ | Cohort | All cause mortality/mortality registry + death certificates + clinic records | SU + metformin | Diet | NR (NR) | NR (NR) | NR | NR | HR 1.3 (0.71–2.38) | HR 1 (ref)

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; TZD = Thiazolidinedione; NR = not reported; ref = reference; MI = myocardial infarction; CVD = cardiovascular disease; ICD-9 = International Classification of Diseases — 9; ID = identification; UK = United Kingdom; vs = versus

* Study was published after the end date of our search.

Table 20 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications for randomized controlled trials: cardiovascular mortality

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Thiazolidinedione vs. Other Diabetes Medications
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Pioglitazone, 21 | Metformin, 21 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 0 | 1 | NR | NR
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Pioglitazone, 21 | Gliclazide, 22 | 30 (esc) 45 | 80 od (esc) 160 bid | 0 | 0 | NR | NR
Choi, 2004 ^77^ | RCT | Cardiovascular disease mortality | Rosiglitazone + existing oral diabetes medications, 38 | Uptitration of usual care, 45 | 8 (other) 4 | NR (esc) | 0 | 0 | NR | NR
Metformin vs. Second Generation Sulfonylurea
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Metformin, 21 | Gliclazide, 22 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 1 | 0 | NR | NR
DeFronzo, 1995 ^88^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 (esc) 2500 | 5 bid (esc) 10 bid | 1 | 0 | NR | NR
Metformin vs. Meglitinide
Horton, 2000 ^96^ | RCT | Cardiovascular disease mortality/due to arteriolosclerotic and hypertensive heart disease + unclear CHD | Metformin, 178 | Nateglinide, 179 | 500 tid (fixed) | 120 tid (fixed) | 1 | 0 | NR | NR
Metformin vs. Metformin + Thiazolidinedione
Bailey, 2005 ^101^ | RCT | Cardiovascular disease mortality/sudden cardiac death | Metformin, 280 | Rosiglitazone + metformin, 288 | 2500 (esc) 3000 | 4 (esc) 8 | 0 | 1 | NR | NR
| | | | | | 2000 (fixed)
Fonseca, 2000 ^103^ | RCT | Cardiovascular disease mortality/unclear mortality + fatal myocardial infarction | Metformin + placebo, 113 | Rosiglitazone + metformin, 116 | 2500 (fixed) | 4 (fixed) | 0 | 1 | NR | NR
| | | | | | 2500 (fixed)
Fonseca, 2000 ^103^ | RCT | Cardiovascular disease mortality/unclear mortality + fatal myocardial infarction | Metformin + placebo, 113 | Rosiglitazone + metformin, 110 | 2500 (fixed) | 8 (fixed) | 0 | 0 | NR | NR
| | | | | | 2500 (fixed)
Metformin vs. Metformin + Second Generation Sulfonylurea
DeFronzo, 1995 ^88^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 (esc) 2500 | 500 (esc) 2500 | 1 | 0 | NR | NR
| | | | | | 10 (esc) 20
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
DeFronzo, 1995 ^88^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 5 bid (esc) 10 bid | 500 (esc) 2500 | 0 | 0 | NR | NR
| | | | | | 10 (esc) 20
UKPDS, 1998 ^15^ | RCT | Fatal myocardial infarction | SU, 269 | Metformin + SU, 268 | NR (esc) 10 bid | 850 (esc) 2550 | NR | NR | RR 1 (ref) | RR 1.79 (0.64 – 4.99)
| | | | | | NR (esc) 10 bid
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Draeger, 1996 ^112^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction + CHF death + myocardial ischemia | Glimepiride, 524 | Glibenclamide, 520 | 1 (esc) 8 | 2.5 (esc) 20 | 5 | 3 | NR | NR
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea + Thiazolidinedione
Rosenstock, 2006 ^124^ | RCT | Cardiovascular disease mortality/unclear CVD mortality | Glipizide + placebo, 111 | Rosiglitazone + glipizide, 116 | 10 (esc) 20 | 4 (fixed) | 2 | 0 | NR | NR
| | | | | | 10 (esc) 20
Baksi, 2004 ^126^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Gliclazide, 241 | Rosiglitazone + gliclazide, 225 | 160 (esc) 320 | 160 (fixed) | 0 | 1 | NR | NR
| | | | | | 4 bid (fixed)
Rosiglitazone vs. Placebo
Zhu, 2003 ^188^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Rosiglitazone + un-specified SU, 221 | Placebo + existing SU, 112 | 2 bid (fixed) | NR (fixed) | 0 | 0 | NR | NR
| | | | | NR (fixed)
Zhu, 2003 ^188^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Rosiglitazone + existing SU, 221 | Placebo + existing SU, 112 | 4 bid (fixed) | NR (fixed) | 1 | 0 | NR | NR
| | | | | NR (fixed)
Second Generation Sulfonylurea vs. Placebo
Rosenstock, 1996 ^189^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Glimepiride, 88 | Placebo, 79 | 8 od (fixed) | NA | 0 | 0 | NR | NR
Rosenstock, 1996 ^189^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Glimepiride, 85 | Placebo, 79 | 8 bid (fixed) | NA | 0 | 0 | NR | NR
Rosenstock, 1996 ^189^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Glimepiride, 83 | Placebo, 79 | 16 od (fixed) | NA | 0 | 0 | NR | NR
Rosenstock, 1996 ^189^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Glimepiride, 81 | Placebo, 79 | 4 bid (fixed) | NA | 1 | 0 | NR | NR
Metformin vs. Placebo
DeFronzo, 1995 ^88^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Metformin, 143 | Placebo, 146 | 850 (esc) 850 tid | NA | 0 | 0 | NR | NR
Horton, 2000 ^96^ | RCT | Cardiovascular disease mortality/due to arteriolosclerotic and hypertensive heart disease + unclear CHD | Metformin, 178 | Placebo, 172 | 500 tid (fixed) | NA | 1 | 0 | NR | NR
Rachmani, 2002 ^150^ | RCT | Cardiovascular disease mortality/unclear CVD mortality | Continued metformin + diet, 195 | Stopped metformin + diet, 198 | NR (NR) | NR (NR) | 50 (26) | 52 (26) | NR | NR
Meglitinide vs. Placebo
Horton, 2000 ^96^ | RCT | Cardiovascular disease mortality/due to arteriolosclerotic and hypertensive heart disease + unclear CHD | Nateglinide, 179 | Placebo, 172 | 120 (fixed) | NA | 0 | 0 | NR | NR
Hanefeld, 2000 ^190^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Nateglinide, 51 | Placebo, 60 | 30 (fixed) | NA | 1 | 0 | NR | NR
Hanefeld, 2000 ^190^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Nateglinide, 58 | Placebo, 60 | 60 (fixed) | NA | 0 | 0 | NR | NR
Hanefeld, 2000 ^190^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Nateglinide, 63 | Placebo, 60 | 120 (fixed) | NA | 0 | 0 | NR | NR
Hanefeld, 2000 ^190^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Nateglinide, 57 | Placebo, 60 | 180 (fixed) | NA | 0 | 0 | NR | NR
Goldberg, 1998 ^139^ | RCT | Cardiovascular disease mortality/fatal myocardial infarction | Repaglinide, 67 | Placebo, 33 | 0.25 tid (esc) 8.0 | NA | 1 | 0 | NR | NR

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; NR = not reported; RCT = randomized controlled trial; ref = reference; CVD = cardiovascular disease; od = once daily; bid = twice daily; tid = three times daily; vs = versus; CAD = coronary artery disease; CHD = coronary heart disease; CHF = congestive heart failure

Table 21 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications fornon-randomized trials and cohort studies: cardiovascular mortality

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Metformin vs. Second Generation Sulfonylurea
Johnson, 2002 ^12^ | Cohort | Cardiovascular disease mortality/fatal myocardial infarction + fatal stroke + CVD mortality + ICD-9 codes 390–398, 401–417, 420–438, 440–444, 446–448, 451–459 | Metformin, 1150 | Unspecified SU, 3033 | NR (NR) | NR (NR) | 80 (7) | 351 (11.6) | Adjusted RR 0.84 (0.49–0.84) | OR 1.0 (ref)
Saskatchewan health database | | | | | | | | | OR 0.64 (0.49–0.84)
Johnson, 2005 ^13^ | Cohort | Cardiovascular disease mortality/CVD mortality registry + CVD mortality + ICD-9 codes 410, 411–414, 420–427, 429, 428, 430–432, 433–434, 436–438, 440 | Metformin, 923 | Unspecified SU, 2138 | 250 minimum dose | Various minimum doses | 14.4 | 25.5 | Adjusted HR 0.76 (0.58–1) | HR reference
Saskatchewan health database
Fisman, 2001 ^186^ | Cohort | Cardiovascular disease mortality/CVD mortality + ICD-9 codes 410–414 + matched the patients ID number with their life status in the population registry + ischemic heart disease | Metformin, 79 | Glyburide (no trade drug specified), 953 | NR (NR) | NR (NR) | NR | NR | Age-adjusted IR 30 per 1000 person-years | Age-adjusted IR 24.5 per 1000 person-years
Evans, 2006 ^180^ | Cohort | Cardiovascular mortality | Metformin, 2286 | Unspecified SU, 3331 | NR (NR) | NR (NR) | NR | NR | RR 1 (ref) | Adjusted RR 1.7 (1.18–2.45)
Second Generation Sulfonylurea vs. Other Oral Diabetes Medication
Garratt, 1999 ^10^ | Cohort | Cardiovascular disease mortality/fatal myocardial infarction + CVD mortality registry + ventricular arrhythmias, death following emergency CABG + review of medical records | Unspecified SU, 67 | Not SU (diet, insulin, or other oral diabetes medications), 118 | NR (NR) | NR (NR) | (24) | (11) | Adjusted OR 2.53 (1.13–5.67); 0.024 | OR ref
Lomuscio, 1996 ^11^ | Cohort | Cardiovascular disease mortality/unclear mortality + heart failure | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 6 (50) | 23 (85) | p<0.05 vs. GP2
Lomuscio, 1996 ^11^ | Cohort | Cardiovascular disease mortality/death from arrhythmia | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 0 (0) | 3 (11) | NSG vs. GP2
Lomuscio, 1996 ^11^ | Cohort | Cardiovascular disease mortality/cardiac rupture | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 1 (8) | 0 (0) | NSG vs. GP2
Second Generation Sulfonylurea or Metformin vs. Metformin + Second Generation Sulfonylurea
Fisman, 2001 ^186^ | Cohort | Cardiovascular disease mortality/CVD mortality +ICD-9 codes 410–414 + matched the patients ID number with their life status in the population registry + ischemic heart disease | Metformin, 79 | Metformin + glyburide (no trade drug specified), 253 | NR (NR) | NR (NR) | NR | NR | Age-adjusted IR 30 per 1000 person-years | Age-adjusted IR 31.2 per 1000 person-years
Fisman, 2001 ^186^ | Cohort | Cardiovascular disease mortality/CVD mortality + ICD-9 codes 410–414 + matched the patients ID number with their life status in the population registry + ischemic heart disease | Glyburide (no trade drug specified), 953 | Metformin + glyburide (no trade drug specified), 253 | NR (NR) | NR (NR) | NR | NR | Age-adjusted IR 24.5 per 1000 person-years | Age-adjusted IR 31.2 per 1000 person-years
Johnson, 2005 ^13^ | Cohort | Cardiovascular disease mortality/CVD mortality registry + CVD mortality + ICD-9 codes 410, 411–414, 420–427, 429, 428, 430–432, 433–434, 436–438, 440 | Unspecified SU, 2138 | Metformin + unspecified SU, 1081 | Various minimum doses | 250 minimum dose | 14.4 | 10.9 | HR 1 (ref) | Adjusted HR 0.59 (0.45–0.78)
Saskatchewan health database | | | | | | Various minimum doses
Evans, 2006 ^180^ | Cohort | Cardiovascular mortality | Metformin, 2286 | Metformin with later addition of SU, 985 | NR (NR) | NR (NR) | NR | NR | RR 1 (ref) | Adjusted RR 2.29 (1.45–3.61)
Evans, 2006 ^180^ | Cohort | Cardiovascular mortality | Metformin, 2286 | SU with later addition of metformin, 1252 | NR (NR) | NR (NR) | NR | NR | RR 1 (ref) | Adjusted RR 2.43 (1.61–3.66)
Olsson, 2000 ^178^ | Cohort | Cardiovascular disease mortality/ICD-8 codes for ischemic heart disease: 410–414 | Unspecified SU, 741 | Metformin + unspecified SU, 169 | NR | NR (NR) | NR | NR | OR 1 | Adjusted OR 1.73 (1.17–2.55)
Olsson, 2000 ^178^ | Cohort | Cardiovascular disease mortality/fatal stroke + ICD-8 codes for ischemic heart disease: 410–414 and ICD-8 codes for stroke: 430–438 | Unspecified SU, 741 | Metformin + unspecified SU, 169 | NR | NR (NR) | NR | NR | OR 1 | Adjusted OR 2.33 (1.17–4.63)
Johnson, 2002 ^12^ | Cohort | Cardiovascular disease mortality/fatal myocardial infarction + fatal stroke + CVD mortality + ICD-9 codes 390–398, 401–417, 420–438, 440–444, 446–448, 451–459 | Unspecified SU, 3033 | Metformin + unspecified SU, 4683 | NR (NR) | NR (NR) | 351 (11.6) | 299 (6.4) | OR and RR 1.0 (ref) | Adjusted RR 0.63 (0.54–0.77)
Saskatchewan health database | | | | | | | | | | OR 0.64 (0.54–0.77)
Metformin or Second Generation Sulfonylurea vs. Placebo
Simpson, 2006 ^14^ | Cohort | Cardiovascular disease mortality/fatal myocardial infarction + CVD mortality + ICD-9 codes 410, 411–414 | Glyburide high dose | Glyburide low dose | High dose/below group median | Low dose/below group median | 17.6 per 1000 person-years | 12 per 1000 person-years | Adjusted HR 1.37 (1.25–1.5) | HR1 (ref)
Simpson, 2006 ^14^ | Cohort | Cardiovascular disease mortality/fatal myocardial infarction + CVD mortality + ICD-9 codes 410, 411–414 | Metformin high dose | Metformin low dose | High dose/above group median | Low dose/below group median | 11.5 per 1000 person-years | 9.5 per 1000 person-years | Adjusted HR 1.1 (0.8–1.3) | HR 1 (ref)
Florkowski, 2001 ^187^ | Cohort | Cardiovascular disease mortality/CVD mortality registry | Metformin | Diet | NR (NR) | NR (NR) | NR | NR | (1) CAD absent at baseline: adjusted HR 1.07 (0.32–3.68);; (2) CAD present at baseline: adjusted HR 0.78 (0.16–3.73) | HR 1 (ref)
Florkowski, 2001 ^187^ | Cohort | Cardiovascular disease mortality/CVD mortality registry | Unspecified SU | Diet | NR (NR) | NR (NR) | NR | NR | (1) CAD absent at baseline: adjusted HR 2.19 (0.84–5.65);; (2) CAD present at baseline: adjusted HR 0.91 (0.23–3.69) | HR 1 (ref)
Metformin + Second Generation Sulfonylurea vs. Placebo
Florkowski, 2001 ^187^ | Cohort | Cardiovascular disease mortality/CVD mortality registry | SU + metformin | Diet | NR (NR) | NR (NR) | NR | NR | 1) CAD absent at baseline: Adjusted HR 1.66 (0.56–4.88); 2) CAD present at baseline: Adjusted HR 2.39 (0.57–10.06) | HR 1(ref)

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; NR = notreported; ref = reference; NSG = not significant; ICD = International Classification of Diseases; CVD = cardiovascular disease; vs = versus; CABG = coronary artery bypass graft surgery; CAD = coronary artery disease

Table 22 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications for randomized controlled trials: cardiovascular morbidity

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg(fixed or esc) max dose | GP2, initial dose in mg(fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Thiazolidinedione vs. Second Generation Sulfonylurea
St John Sutto, 2002 ^67^ | RCT | Cardiovascular disease morbidity/heart disease | Rosiglitazone, 104 | Glyburide (no trade drug specified), 99 | 4 bid (fixed) | NR (esc) 20 | 9 | 5 | NR | NR
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Pioglitazone, 21 | Gliclazide, 22 | 30 (esc) 45 | 80 od (esc) 160 bid | 0 | 1 | NR | NR
Thiazolidinedione vs. Metformin
Virtanen, 2003 ^143^ | RCT | Cardiovascular disease morbidity/ischemic heart disease | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 2 bid (esc) 4 bid | 500 bid (esc) 1000 bid | 0 | 1 | NR | NR
Hallsten, 2002 ^58^
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Pioglitazone, 21 | Metformin, 21 | 30 (esc) 45 | 500 bid (esc) 1000 tid | 0 | 0 | NR | NR
Hanefeld, 2004 ^60^ | RCT | Coronary heart diseases/cardiac disorders | Pioglitazone + unspecified SU + placebo, 319 | Metformin + unspecified SU + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | (3.1) | (4.1) | NR | NR
QUARTET study group | | | | | NR | NR
Metformin vs. Second Generation Sulfonylurea
Lawrence, 2004 ^54^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin, 21 | Gliclazide, 22 | 500 bid (esc) 1000 tid | 80 (esc) 160 bid | 0 (0) | 1 (4.5) | NR | NR
Hermann, 1994 ^87^ | RCT | Cardiovascular disease morbidity/unclear CHD | Metformin + diet, 38 | Glyburide + diet, 34 | 1000 (esc) 3000 | 3.5 (esc) 10.5 | 2 (5) | 3 (9) | NR | NR
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Hermann, 1994 ^87^ | RCT | Cardiovascular disease morbidity/unclear CHD | Glyburide + diet, 34 | Metformin + glyburide, 72 | 3.5 (esc) 10.5 | 500 (esc) 1500 | 3 (9) | 10 (14) | NR | NR
| | | | | | 1.75 (esc) 5.25
UKPDS, 1998 ^15^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Unspecified SU + diet, 269 | Metformin + unspecified SU + diet, 268 | NR (NR) | NR (NR) | 23 | 14 | RR 1 (ref) | RR 0.62 (0.26–1.42)
UKPDS, 1998 ^15^ | RCT | Cardiovascular disease morbidity/coronary heart disease | Unspecified SU + diet, 269 | Metformin + unspecified SU + diet, 268 | NR (NR) | NR (NR) | 18 | 11 | RR 1 (ref) | RR 0.64 (0.24–1.71)
UKPDS, 1998 ^15^ | RCT | Cerebrovascular diseases/stroke | Unspecified SU + diet, 269 | Metformin + unspecified SU + diet, 268 | NR (NR) | NR (NR) | 12 | 10 | RR 1 (ref) | RR 0.68 (0.29–2.64)
Metformin vs. Other
Rachmani, 2002 ^150^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | 51 (26) | 53 (27) | no significant differences between groups
Rachmani, 2002 ^150^ | RCT | Cardiovascular disease morbidity/All CVD events | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | 102 (55) | 108 (55) | no significant differences between groups
Cryer, 2005 ^176^ | RCT | Cardiovascular disease morbidity/CAD | Metformin + existing medications + diet, 7227 | Diet + usual care, 1505 | 500 (esc) 2500 | NR (NR) | (1) | (1.1) | NR | NR
COSMIC Approach Study
Cryer, 2005 ^176^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin + existing medications + diet, 7227 | Diet + usual care, 1505 | 500 (esc) 2500 | NR (NR) | (0.7) | (0.7) | NR | NR
COSMIC Approach Study
Cryer, 2005 ^176^ | RCT | Cerebrovascular diseases/stroke | Metformin + existing medications + diet, 7227 | Diet + usual care, 1505 | 500 (esc) 2500 | NR (NR) | (0.4) | (0.7) | NR | NR
COSMIC Approach Study
Metformin vs. Thiazolidinedione + Metformin
Weissman, 2005 ^100^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin, 384 | Rosiglitazone + metformin, 382 | 1000 (esc) 2000 | 4 (esc) 8 | 0 | 2 | NR | NR
| | | | | | 1000 (fixed)
Weissman, 2005 ^100^ | RCT | Cardiovascular disease morbidity/CAD or cardiac ischemia | Metformin, 384 | Rosiglitazone + metformin, 382 | 1000 (esc) 2000 | 4 (esc) 8 | 3 + 1 withdrew | 5 | NR | NR
| | | | | | 1000 (fixed)
Bailey, 2005 ^101^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) + pulmonary edema with myocardial infarction | Metformin, 280 | Rosiglitazone + metformin, 288 | 2500 (esc) 3000 | 4 (esc) 8 | 0 | 1 | NR | NR
| | | | | | 2000 (fixed)
Gomez-Perez, 2002 ^102^ | RCT | Cardiovascular disease morbidity/ischemic heart disease + bundle branch block + tachycardia | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2500 (fixed) | 1 | 1 | NR | NR
| | | | | | 2 bid (fixed)
Gomez-Perez, 2002 ^102^ | RCT | Cardiovascular disease morbidity/ischemic heart disease + bundle branch block + tachycardia | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 2500 (fixed) | 1 | 2 | NR | NR
| | | | | | 4 bid (fixed)
Metformin vs. Metformin + Second Generation Sulfonylurea
Hermann, 1994 ^87^ | RCT | Cardiovascular disease morbidity/unclear CHD | Metformin + diet, 38 | Metformin + glyburide, 72 | 1000 (esc) 3000 | 500 (esc) 1500 | 2 (5) | 10 (14) | NR | NR
| | | | | | 1.75 (esc) 5.25
Metformin vs. Metformin XR
Fujioka, 2003 ^105^ | RCT | Cardiovascular disease morbidity/angina + angina and heart failure | Metformin + placebo + diet | Metformin XR + placebo + diet, 146 | 1000 (esc) 1500 | 1000 (esc) 1500 | 0 | 1 | NR | NR
Fujioka, 2003 ^105^ | RCT | Cerebrovascular diseases/stroke | Metformin + placebo + diet | Metformin XR + placebo + diet, 146 | 1000 (esc) 1500 | 1000 (esc) 1500 | 0 | 1 | NR | NR
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Sonnenberg, 1997 ^191^ | RCT, cross-over | Cardiovascular disease morbidity/myocardial infarction (non-fatal) + 2 symptoms + WHO clinical criteria | Glimepiride, 48 | Glimepiride, 46 | 3 (fixed) | 6 (fixed) | 0 | 1 | NR | NR
Carlson, 1993 ^108^ | RCT | Cerebrovascular diseases/stroke + brainstem infarct resulting in death | Glyburide (Micronase), 104 | Glyburide (Glynase Prestab), 102 | 3 (fixed) | 5 (fixed) | 1 | 0 | NR | NR
Second Generation Sulfonylurea vs. Meglitinide
Marbury, 1999 ^116^ | RCT | Cardiovascular disease morbidity/unclear CHD | Glyburide (no trade drug specified) + placebo, 193 | Repaglinide, 383 | 2.5 (esc) 15 | 0.5 (esc) 12 | 4 | 19 | NR | NR
Wolffenbuttel, 1999 ^117^ | RCT | Cardiac events NOS | Glyburide (no trade drug specified) + placebo, 139 | Repaglinide, 286 | 1.75 (esc) 10.5 | 1.5 (esc) 12 | | | Authors stated similar frequencies in each group, but no data given
Metformin vs. Meglitinide
Horton, 2000 ^96^ | RCT | Cardiovascular disease morbidity/electrocardiogram abnormalities | Metformin, 178 | Nateglinide, 179 | 500 tid (fixed) | 120 tid (fixed) | 0 | 0 | NR | NR
Thiazolidinedione vs. Placebo
Virtanen, 2003 ^143^ | RCT | Cardiovascular disease morbidity/ischemic heart disease | Rosiglitazone + diet, 14 | Placebo + diet, 14 | 2 bid (esc) 8 bid | NA | 0 | 0 | NR | NR
Aronoff, 2000 ^165^ | RCT | Cardiovascular disease morbidity/not stated | Pioglitazone, 329 | Placebo, 79 | 7.5 (fixed) | NA | 12 (3.6) | 5 (6.3) | NR | NR
Dormandy, 2005 ^185^ | RCT | Cerebrovascular diseases/stroke | Pioglitazone + existing diabetes medications, 2605 | Placebo + existing diabetes medications, 2633 | 15 (esc) 45 | NR (NR) | 86 | 107 | NR | NR
PROactive
Dormandy, 2005 ^185^ | RCT | Coronary heart diseases/myocardial infarction (non-fatal) + silent myocardial infarction | Pioglitazone + existing diabetes medications, 2605 | Placebo + existing diabetes medications, 2633 | 15 (esc) 45 | NR (NR) | 119 | 144 | HR 0.83 (0.65–1.06) | HR reference
PROactive
Dormandy, 2005 ^185^ | RCT | Coronary heart diseases/Acute coronary syndrome: patient received treatment in hospital for ischemic discomfort at rest that lasted at least 5 minutes and had electrocardiographic changes or raised cardiac serum markers not sufficiently high to indicate myocardial infarction or both | Pioglitazone + existing diabetes medications, 2605 | Placebo + existing diabetes medications, 2633 | 15 (esc) 45 | NR (NR) | 56 | 72 | HR 0.78 (0.55–1.11) | HR reference
PROactive
Dormandy, 2005 ^185^ | RCT | Coronary heart diseases/coronary artery bypass surgery + angioplasty + Coronary revascularization: percutaneous transluminal coronary intervention (e.g., angioplasty, stenting, atherectomy, laser ablation) or coronary artery bypass graft | Pioglitazone, 2605 | Placebo, 2633 | 15 (esc) 45 | NR (NR) | 169 | 193 | HR 0.88 (0.72–1.08) | HR reference
PROactive
Barnett, 2003 ^172^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Rosiglitazone + existing unspecified SU, 84 | Placebo + existing unspecified SU, 87 | 4 bid (fixed) | NR (NR) | 1 | 0 | NR | NR
| | | | | NR (NR)
Barnett, 2003 ^172^ | RCT | Cardiovascular disease morbidity/angina | Rosiglitazone + existing unspecified SU, 84 | Placebo + existing unspecified SU, 87 | 4 bid (fixed) | NR (NR) | 4 (5) | 0 (0) | NR | NR
| | | | | NR (NR)
Kipnes, 2001 ^166^ | RCT | Cardiovascular disease morbidity/listed as “adverse cardiac events” | Pioglitazone + existing unspecified SU, 176 | Placebo + existing unspecified SU, 181 | 15 (fixed) | NR (fixed) | 22 (6) | 10 (5) | NR | NR
| | | | | NR (fixed)
Vongthavaravat, 2002 ^170^ | RCT | Cerebrovascular diseases/unclear CBVD | Rosiglitazone + existing unspecified SU + diet, 164 | Diet + existing unspecified SU + diet, 170 | 2 bid (fixed) | NR (NR) | 2 | 2 | NR | NR
Nishio, 2006 ^151^ | RCT | Cardiovascular disease morbidity/major adverse cardiac events at 6 months - death, Q wave or non-Q wave myocardial infarction, coronary artery bypass grafting, and revascularization of the target lesion or vessel after the procedure | Pioglitazone, 26 | Control group (no placebo), 28 | 30 (fixed) | NA | (7.7) | (60.7) | NR | NR
Takagi, 2003 ^78^ | RCT | Cardiovascular disease morbidity/angioplasty | Pioglitazone + existing medications, 23 | Control group (conventional antidiabetic therapy), 21 | 30 (fixed) | NR (NR) | 5 (19) | 11 (46) | NR | NR
Choi, 2004 ^77^ | RCT | Cardiovascular disease morbidity/angioplasty | Rosiglitazone + existing medications, 38 | Uptitration of existing diabetes medications, 45 | 8 (other) 4 | NR (esc) | 9 (17.6) | 21 (38.2) | NR | NR
Metformin vs. Placebo
Teupe, 1991 ^155^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin + diet, 50 | Diet, 50 | NR (esc) 1700 | NA | 1 | 0 | NR | NR
Virtanen, 2003 ^143^ | RCT | Cardiovascular disease morbidity/ischemic heart disease | Metformin + diet, 13 | Placebo + diet, 14 | 500 bid (esc) 1000 bid | NA | 1 | 0 | NR | NR
Horton, 2000 ^96^ | RCT | Cardiovascular disease morbidity/electrocardiogram abnormalities | Metformin, 178 | Placebo, 172 | 500 tid (fixed) | NA | 0 | 1 | NR | NR
UKPDS, 1998 ^15^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Metformin + diet, 342 | Diet, 411 | 850 (esc) 2550 | NA | 24 | 40 | RR 0.69 (0.35–1.34) | RR 1 (ref)
UKPDS
UKPDS, 1998 ^15^ | RCT | Cerebrovascular diseases/nonfatal stroke | Metformin + diet, 342 | Diet, 411 | 850 (esc) 2550 | NA | 6 | 16 | RR 0.42 (0.12 – 1.45) | RR1 (ref)
UKPDS
Second Generation Sulfonylurea vs. Placebo
Luis Bautista, 2003 ^193^ | RCT | Cerebrovascular diseases/used ICD-9 codes for CBVD + probable stroke/ TIA + unclear CBVD | Glimepiride + diet + exercise, 48 | Placebo + diet + exercise, 22 | 1 (esc) 4 | NA | 0 | 1 | NR | NR
UKPDS, 1998 ^16^ | RCT | Cerebrovascular diseases/nonfatal stroke | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 34 | 38 | RR 1.30 (0.71–2.38) | RR 1 (ref)
UKPDS
UKPDS, 1998 ^16^ | RCT | Cardiovascular disease morbidity/angina | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 34 | 58 | RR 0.84 (0.48–1.47) | RR1 (ref)
UKPDS
UKPDS, 1998 ^16^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) + 2 symptoms + WHO clinical criteria | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 46 | 87 | RR 0.74 (0.46–1.19) | RR 1 (ref)
UKPDS
Meglitinide vs. Placebo
Jovanovic, 2000 ^194^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Repaglinide, 140 | Placebo, 75 | 1 tid (fixed) | NA | 1 | 0 | NR | NR
Jovanovic, 2000 ^194^ | RCT | Cardiovascular disease morbidity/myocardial infarction (non-fatal) | Repaglinide, 146 | Placebo, 75 | 4 tid (fixed) | NA | 1 | 0 | NR | NR
Horton, 2000 ^96^ | RCT | Cardiovascular disease morbidity/electrocardiogram abnormalities | Nateglinide, 179 | Placebo, 172 | 120 (fixed) | NA | 0 | 1 | NR | NR
Alpha-Glucosidase Inhibitor vs. Placebo
Hasche, 1999 ^138^ | RCT | Cardiovascular disease morbidity/angina + heart failure + cardiovascular disorder | Acarbose + diet, 36 | Placebo + diet, 38 | 50 bid (esc) 100 tid | NA | 1 | 2 | NR | NR

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; NR = not reported; ref = reference; ICD = International Classification of Diseases; CHD = coronary heart disease; CAD = coronary artery disease; CBVD = cerebrovascular disease; TIA = transienct ischemic attack; XR = extended release; WHO = World Health Organization; NOS = not otherwise specified; UKPDS = United Kingdom Prospective Diabetes Study; od = once daily; bid = twice daily; tid = three times daily; vs = versus

Table 23 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications for non-randomized trials and cohort studies: cardiovascular morbidity

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Metformin vs. Second Generation Sulfonylurea
Johnson, 2005 ^13^ | Cohort | Non-fatal cardiovascular hospitalization/used ICD-9 codes 410–414, 420–427, 429, 428, 440, 430–432, 433–434, 436–438 | Metformin, 923 | Unspecified SU, 2138 | 250 minimum dose | Various minimum doses | 53.7 | 75.3 | Adjusted HR 0.78 (0.63–0.97) | HR reference
Saskatchewan health database
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
Johnson, 2005 ^13^ | Cohort | Non-fatal cardiovascular hospitalization/used ICD-9 codes 410–414, 420–427, 429, 428, 440, 430–432, 433–434, 436–438 | Unspecified SU, 2138 | Metformin + unspecified SU, 1081 | Various minimum doses | 250 minimum dose | 75.3 | 90.2 | HR reference | Adjusted HR 1.09 (0.91–1.29)
Saskatchewan health database | | | | | | Various minimum doses
Second Generation Sulfonylurea vs. Other Oral Diabetes Medications
Garratt, 1999 ^10^ | Cohort | Cardiovascular disease morbidity/subsequent myocardial infarction | Glibenclamide, 67 | Diet, insulin, or other oral diabetes medication, 118 | NR (NR) | NR (NR) | (19.9) | (23.1) | | NSG vs. GP1
Garratt, 1999 ^10^ | Cohort | Cardiovascular disease morbidity/coronary artery bypass surgery | Glibenclamide, 67 | Diet, insulin, or other oral diabetes medication, 118 | NR (NR) | NR (NR) | (23.3) | (31.7) | | NSG vs. GP1
Garratt, 1999 ^10^ | Cohort | Cardiovascular disease morbidity/Ventricular tachycardia or fibrillation while in hospital post myocardial infarction | Glibenclamide, 67 | Diet, insulin, or other oral diabetes medication, 118 | NR (NR) | NR (NR) | (27) | (22) | | NSG vs. GP1
Garratt, 1999 ^10^ | Cohort | Cardiovascular disease morbidity/angioplasty | Glibenclamide, 67 | Diet, insulin, or other oral diabetes medication, 118 | NR (NR) | NR (NR) | (17.8) | (46.7) | | <0.05 vs. GP1
Lomuscio, 1996 ^11^ | cohort | Coronary heart diseases/sustained ventricular tachycardia only | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 5 (4.7) | 9 (7.2) | | NSG vs. GP1
Lomuscio, 1996 ^11^ | cohort | Coronary heart diseases/unclear mortality + ventricular fibrillation only | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 2 (1.9) | 6 (4.8) | | <0.05 vs. GP1
Lomuscio, 1996 ^11^ | cohort | Coronary heart diseases/Ventricular fibrillation and/or sustained ventricular tachycardia | Glibenclamide, 106 | Not glibenclamide, 126 | at minimum 10 (NR) | NR (NR) | 7 (6) | 19 (15) | | <0.05 vs. GP1
Thiazolidinedione and/or Metformin vs. Other Oral Diabetes Medications
Inzucchi, 2005 ^184^ | Cohort | Cardiovascular disease morbidity/readmission for myocardial infarction (non-fatal) + Linkage with part A Medicare data | Unspecified TZD, 819 | Non-insulin sensitizing antihyperglycemic, 6641 | NR (NR) | NR (NR) | 154 (18.8) | 1247 (18.8) | Adjusted HR 0.92 (0.77–1.10) | HR 1 (ref)
Inzucchi, 2005 ^184^ | Cohort | Cardiovascular disease morbidity/readmission for myocardial infarction (non-fatal) + Linkage with part A Medicare data | Metformin, 1273 | Non-insulin sensitizing antihyperglycemic, 6641 | NR (NR) | NR (NR) | 210 (16.5) | 1247 (18.8) | Adjusted HR 1.02 (0.86–1.20) | HR 1 (ref)
Inzucchi, 2005 ^184^ | Cohort | Cardiovascular disease morbidity/readmission for myocardial infarction (non-fatal) + Linkage with part A Medicare data | Metformin + TZD, 139 | Non-insulin sensitizing antihyperglycemic, 6641 | NR (NR) | NR (NR) | 1247 (18.8) | 21 (15.1) | Adjusted HR 0.87 (0.68–1.12) | HR 1(ref)
Thiazolidinedione vs. Thiazolidinedione
Gegick, 2001 ^192^ | Cohort | Cerebrovascular diseases/unclear CVD mortality + cerebrovascular accident | Rosiglitazone, 67 | Pioglitazone, 77 | 4 or 8 mg | 15 – 45 (fixed) | 0 | 1 | NR | NR
Second Generation Sulfonylurea vs. Placebo
Ikeda, 1994 ^195^ | Cohort | Cardiovascular disease morbidity/ prolonged QTc | Glibenclamide, 20 | Diet, 20 | 1.25–5 (dose range) | NR (NR) | 8 (0.4) | 2 (0.1) | <0.05 vs. GP2

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; TZD = Thiazolidinedione; NR = not reported; ref = reference; CVD = cardiovascular disease; ICD = International Classification of Diseases; NSG = not significant; CHD = coronary heart disease; vs = versus

Table 24 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications in randomized controlled trials: peripheral vascular disease

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
1998 ^15^ | RCT | PVD/ limb amputation or death from PVD | SU, 269 | Metformin + SU, 268 | 2.5 (esc) 20 | 500 (esc) 2550 | NR | NR | RR 1 (ref) | RR 2.12 (0.19–23.3)
UKPDS | | | | | | 2.5 (esc) 20
Metformin or Second Generation Sulfonylurea vs. Diet
1998 ^15^ | RCT | PVD/ limb amputation or death from PVD | Metformin + diet, 342 | Diet, 411 | 850 (esc) 2550 | NA | 6 | 9 | RR 0.74 (0.26–2.09) | RR 1 (ref)
UKPDS
1998 ^16^ | RCT | PVD/limb amputation or death from PVD | Glibenclamide + diet, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 0.8 | 1.6 | RR 0.48 (0.17–1.31) | RR 1(ref)
UKPDS
Thiazolidinedione vs. Placebo
Dormandy, 2005 ^185^ | RCT | PVD/limb amputation | Pioglitazone, 2605 | Placebo, 2633 | 15 (esc) 45 | NA | 26 | 26 | HR 1.01 (0.58–1.73) | HR reference
PROactive
Dormandy, 2005 ^185^ | RCT | PVD/peripheral revascularization procedure | Pioglitazone, 2605 | Placebo, 2633 | 15 (esc) 45 | NA | 80 | 65 | HR 1.25 (0.9–1.73) | HR reference
PROactive
Zhu, 2003 ^188^ | RCT | PVD/peripheral ischemia | Rosiglitazone + existing unspecified SU, 221 | Placebo + existing unspecified SU, 112 | 2 bid (fixed) | NR (fixed) | 0 | 0 | NR | NR
| | | | | NR (fixed)
Zhu, 2003 ^188^ | RCT | PVD/peripheral ischemia | Rosiglitazone + existing unspecified SU, 221 | Placebo + existing unspecified SU, 112 | 4 bid (fixed) | NR (fixed) | 1 | 0 | NR | NR
| | | | | NR (fixed)

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; IR = incidence rate; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = sulfonylurea; NR = not reported; ref = reference; NA = not applicable; bid = twice a day; PVD = peripheral vascular disease; RCT = randomized controlled trial; UKPDS = United Kingdom Prospective Diabetes Study

Table 25 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications: retinopathy

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea
Baba, 1983 ^133^ | RCT | Diabetic retinopathy/Fundoscopic examination + Scott's classification used | Glibenclamide, 95 | Gliclazide, 97 | 2.5 (esc) 10 | 40 (esc) 160 | NR | NR | Fundoscopic exam 11% aggravated cases (<0.05 vs. GP2) | Fundoscopic exam 3% aggravated cases
| | | | | | | | | Scott's classification 6% improved 10% aggravated | Scott's classification 4% improved 1% aggravated
Akanuma, 1988 ^196^ | RCT | Diabetic retinopathy/proliferative retinopathy + mild non-proliferative + 4 grade scale of severity | Glipizide, 21 | Unspecified SU, 19 | 40 (esc) 240 | NR | NR | NR | IR 47.7 (baseline); 54.8 (followup) | IR 54.0 (baseline); 67.6 (followup)
Diabetic Retinopathy Program
Second Generation Sulfonylurea vs. Metformin + Second Generation Sulfonylurea
UKPDS, 1998 ^15^ | RCT | Diabetic retinopathy/retinopathy requiring photocoagulation | Metformin + SU, 268 | SU, 269 | 500 (esc) 2550 | 2.5 (esc) 20 | NR | NR | RR 1.08 (0.41–2.66) | ref
| | | | | 2.5 (esc) 20
UKPDS, 1998 ^15^ | RCT | Diabetic retinopathy/vitreous hemorrhage | Metformin + SU, 268 | SU, 269 | 500 (esc) 2550 | 2.5 (esc) 20 | 0 | 2 | NR | NR
| | | | | 2.5 (esc) 20
UKPDS, 1998 ^15^ | RCT | Combined microvascular outcome (retinopathy and nephropathy) | Metformin + SU, 268 | SU, 269 | 500 (esc) 2550 | 2.5 (esc) 20 | NR | NR | RR 0.84 (0.43–1.66) | ref
| | | | | 2.5 (esc) 20
Metformin vs. Other Oral Diabetes Medications
Rachmani, 2002 ^150^ | RCT | Diabetic retinopathy: total retinopathy/ proliferative retinopathy | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | 63/21 (initial); 70/22 (final) | 66/22 (initial); 72/23 (final) | <0.01 vs. baseline; NSG vs. GP2 | <0.01 vs. baseline; NSG vs. GP2
Metformin or Second Generation Sulfonylurea vs. Placebo
Akanuma, 1988 ^196^ | RCT | Diabetic retinopathy/proliferative retinopathy + mild non-proliferative + 4 grade scale of severity | Glipizide, 21 | Diet, 20 | 40 (esc) 240 | NA | NR | NR | IR 47.7 (baseline); 54.8 (followup) | IR 51.3 (baseline); 73.0 (followup)
Diabetic Retinopathy Program
Akanuma, 1988 ^196^ | RCT | Diabetic retinopathy/proliferative retinopathy + mild non-proliferative + 4 grade scale of severity | Unspecified SU, 19 | Diet, 20 | NR (NR) | NA | NR | NR | IR 54.0 (baseline); 67.6 (followup) | IR 51.3 (baseline); 73.0 (followup)
Diabetic Retinopathy Program
UKPDS, 1998 ^15^ | RCT | Diabetic retinopathy/retinopathy requiring photocoagulation | Metformin, 342 | Diet, 411 | NR (esc) 2550 | NA | NR | NR | RR 0.69 (0.34–1.39) | ref
UKPDS, 1998 ^15^ | RCT | Diabetic retinopathy/vitreous hemorrhage | Metformin, 342 | Diet, 411 | NR (esc) 2550 | NA | NR | NR | RR 0.75 (0.07–7.62) | ref
UKPDS, 1998 ^15^ | RCT | Combined microvascular outcome (retinopathy and nephropathy) | Metformin, 342 | Diet, 411 | NR (esc) 2550 | NA | NR | NR | RR 0.71 (0.43–1.19) | ref
UKPDS, 1998 ^16^ | RCT | Diabetic retinopathy/retinopathy requiring photocoagulation | Glibenclamide, 615 | Diet, 896 | 2.5 (esc) 20 | NA | NR | NR | RR 0.63 (0.40–1.00) | ref
UKPDS, 1998 ^16^ | RCT | Diabetic retinopathy/vitreous hemorrhage | Glibenclamide, 615 | Diet, 896 | 2.5 (esc) 20 | NA | NR | NR | RR 0.73 (0.18–2.98) | ref
UKPDS, 1998 ^16^ | RCT | Combined microvascular outcome (retinopathy and nephropathy) | Glibenclamide, 615 | Diet, 896 | 2.5 (esc) 20 | NA | NR | NR | RR 0.66 (0.47–0.93) | ref

Comp = comparison; GP = group; IR = incidence rate; CI = confidence interval; RR = relative risk; HR = hazard ratio; OR = odds ratio; SU = Sulfonylurea; RCT= randomized controlled trial; NR= not reported; NA = not applicable; vs=versus; mg=milligrams; max = maximum; esc=escalated; ref=reference; UKPDS = United Kingdom Prospective Diabetes Study; NSG = not significant

Table 26 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications: nephropathy

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP 1, initial dose in mg (fixed or esc) max dose | GP 2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) or GP1 baseline and followup | GP2 “X”R (95% CI) or GP2 baseline and followup
Study group | | | | | | | | | p-value GP1 | p-value GP2
Thiazolidinedione vs. Second Generation Sulfonylurea
Bakris, 2003 ^66^ | RCT | Diabetic nephropathy/number with normal albuminuria at baseline who progressed to microalbuminuria by study end | Rosiglitazone, 43 | Glyburide (no trade drug specified), 47 | 4 bid (fixed) | NR (esc) 20 | 3 (7) | 5 (10.6) | NR | NR
Bakris, 2003 ^66^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Rosiglitazone, 64 | Glyburide (no trade drug specified), 57 | 4 bid (fixed) | NR (esc) 20 | NR | NR | (-45 to -4); NSG vs. GP2 | (-22 to 4)
Nakamura, 2000 ^64^ | RCT | Diabetic nephropathy/urinary albumin excretion | Pioglitazone, 15 | Glibenclamide, 15 | 30 (fixed) | 5 (fixed) | NR | NR | 142.8 ug/min (baseline); 48.4 ug/min (followup) p < 0.05 | Baseline and follow-up not reported; p > 0.05
Yanagawa, 2004 ^62^ | RCT | Diabetic nephropathy/urine albumin/creatinine | Pioglitazone, 19 | Gliclazide, 21 | NR | NR | NR | NR | F-statistic = 0.8; NSG vs. GP2
Thiazolidinedione vs. Metformin
Schernthaner, 2004 ^56^ | RCT | Diabetic nephropathy/urinary albumin/creatinine ratio | Pioglitazone + placebo + diet, 588 | Metformin + placebo + diet, 588 | 30 (esc) 45 | 850 up to 3 times/day (esc) 2550 | NR (-19) | NR ( -1) | p=0.002 vs. GP2
Hanefeld, 2004 ^60^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Pioglitazone + un-specified SU + placebo, 319 | Metformin + un-specified SU + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | NR | NR | (0.73–0.97), p=0.017 vs. GP2
QUARTET study group | | | | | NR | NR
Hanefeld, 2004 ^60^ | RCT | Diabetic nephropathy/microalbuminuria resolved | Pioglitazone + un-specified SU + placebo, 319 | Metformin + un-specified SU + placebo, 320 | 15 (esc) 45 | 850 (esc) 850 tid | (10.2) | (7.7) | NR | NR
QUARTET study group | | | | | NR | NR
Thiazolidinedione vs. Alpha-Glucosidase Inhibitor
Nakamura, 2000 ^64^ | RCT | Diabetic nephropathy/proteinuria/albuminuria | Pioglitazone, 15 | Voglibose, 15 | 30 (fixed) | 0.6 (fixed) | NR | NR | 142.8 ug/min (baseline); 48.4 ug/min (followup) p < 0.05 vs. baseline | Baseline and follow-up not reported; p > 0.05 vs. baseline
Metformin vs. Second Generation Sulfonylurea
Amador-Licona, 2000 ^85^ | RCT | Diabetic nephropathy/change in glomerular filtration rate | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | NR | NR | 138 mL/min (baseline); 134 mL/min (followup); p=0.46 vs. baseline | 136 mL/min (baseline); 151 mL/min (followup); p=0.04 vs. baseline
Amador-Licona, 2000 ^85^ | RCT | Diabetic nephropathy/change in microalbumin (mg/d) | Metformin, 28 | Glibenclamide, 23 | 850 (esc) NR | 5 (esc) NR | NR | NR | 74 mg/d (baseline); 49 mg/d (followup); p=0.008 vs. baseline | 83 mg/d (baseline); 102 mg/d (followup); p=0.09 vs. baseline
Metformin vs. Other Oral Diabetes Medications
Rachmani, 2002 ^150^ | RCT | Diabetic nephropathy/urinary albumin/creatinine ratio in mg/g | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | NR | NR | 48 mg/g (baseline); 55 mg/g (followup); p<0.001 vs. baseline; NSG vs. GP2 | 46 mg/g (baseline); 57 mg/g (followup); p<0.001 vs. baseline
Rachmani, 2002 ^150^ | RCT | Diabetic nephropathy/change serum creatinine | Metformin continued + diet, 195 | Metformin stopped + diet, 198 | NR (NR) | NR (NR) | NR | NR | 163 umol/L (baseline); 179 umol/L (followup); p<0.01 vs. baseline | 161 umol/L (baseline); 186 umol/L (followup); p<0.01 vs. baseline
Fujioka, 2003 ^105^ | RCT | Diabetic nephropathy/urinary protein | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 2 | 0 | NR | NR
Fujioka, 2003 ^105^ | RCT | Diabetic nephropathy/urinary protein | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 2 | 0 | NR | NR
Second Generation Sulfonylurea vs. Second Generation Sulfonylurea + Metformin
UKPDS, 1998 ^15^ | RCT | Diabetic nephropathy/death from renal disease | Metformin + SU, 268 | SU, 269 | 500 (esc) 2550 | 2.5 (esc) 20 | 1 | 1 | RR 1.05 (0.08–39.9) | ref
| | | | | 2.5 (esc) 20
UKPDS, 1998 ^15^ | RCT | Diabetic nephropathy/renal failure | Metformin + SU, 268 | SU, 269 | 500 (esc) 2550 | 2.5 (esc) 20 | 0 | 4 | NR | NR
| | | | | 2.5 (esc) 20
Second Generation Sulfonylurea vs. Alpha-Glucosidase Inhibitor
Nakamura, 2000 ^64^ | RCT | Diabetic nephropathy/proteinuria/albuminuria | Glibenclamide, 15 | Voglibose, 15 | 5 (fixed) | 0.6 (fixed) | NR | NR | p > 0.05 vs. baseline | p > 0.05 vs. baseline
Metformin or Second Generation Sulfonylurea vs. Placebo
UKPDS, 1998 ^15^ | RCT | Diabetic nephropathy/death from renal disease | Metformin, 342 | Diet, 411 | NR (esc) 2550 | NA | 2 | 1 | RR 2.44 (0.10–57.46) | ref
UKPDS, 1998 ^15^ | RCT | Diabetic nephropathy/ renal failure | Metformin, 342 | Diet, 411 | NR (esc) 2550 | NA | 2 | 2 | RR 1.14 (0.09–14.94) | ref
UKPDS, 1998 ^16^ | RCT | Diabetic nephropathy/death from renal disease | Glibenclamide, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 4 | 2 | RR 2.84 (0.30–26.41) | ref
UKPDS, 1998 ^16^ | RCT | Diabetic nephropathy/renal failure | Glibenclamide, 615 | Diet, 896 | 2.5 (esc) 20 | NA | 4 | 8 | RR 0.72 (0.15–3.50) | ref
Thiazolidinedione vs. Placebo
Herz, 2003 ^163^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Pioglitazone, 99 | Placebo, 99 | 45 (fixed) | NA | NR | NR | No treatment effect seen on urine albumin/creatinine ratios noted per author | No treatment effect seen on urine albumin/creatinine ratios noted per author
Herz, 2003 ^163^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Pioglitazone, 99 | Placebo, 99 | 30 (fixed) | NA | NR | NR | No treatment effect seen on urine albumin/creatinine ratios noted per author | No treatment effect seen on urine albumin/creatinine ratios noted per author
Lebovitz, 2001 ^169^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Rosiglitazone, 142 | Placebo, 132 | 2 bid (fixed) | NA | NR | NR | (-25.3 to -0.9) | (-9.1 to 18)
Lebovitz, 2001 ^169^ | RCT | Diabetic nephropathy/albumin/creatinine ratio | Rosiglitazone, 145 | Placebo, 132 | 4 bid (fixed) | NA | NR | NR | (-30.6 to -11.3) | (-9.1 to 18)

Comp = comparison; GP = group; mg=milligrams; esc = escalated; max = maximum; CI = confidence interval; RR = relative risk; SU = sulfonylurea; NA=not applicable; vs=versus; d=day; mL= milliliter; L=liter; ug=micrograms; dL = deciliter; min = minute; g = gram; umol = micromole; XR = extended release; NR=not reported; NA = not applicable; min=minute; RCT=randomized controlled trial; ref=reference group; carbs=carbohydrates; NSG=not significant; bid = twice a day; tid = three times a day; UKPDS = United Kingdom Prospective Diabetes Study

Table 27 Evidence Table. Comparative effectiveness of oral diabetes medications on distal diabetes-related complications: neuropathy

Author, year | Study design | Main/specific outcome | Comp GP1, N | Comp GP2, N | GP1, initial dose in mg (fixed or esc) max dose | GP2, initial dose in mg (fixed or esc) max dose | GP1 events, n (%) | GP2 events, n (%) | GP1 “X”R (95% CI) | GP2 “X”R (95% CI)
Study group | | | | | | | | | p-value GP1 | p-value GP2
Direct Comparisons
Gomez-Perez, 2002 ^102^ | RCT | Neuropathy/unclear neuropathy | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 2500 (fixed) | 2500 (fixed) | 1 | 0 | NR | NR
| | | | | | 2 bid (fixed)
Gomez-Perez, 2002 ^102^ | RCT | Neuropathy/unclear neuropathy | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 2500 (fixed) | 2500 (fixed) | 1 | 0 | NR | NR
| | | | | | 4 bid (fixed)
Fujioka, 2003 ^105^ | RCT | Neuropathy/unclear neuropathy | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 (esc) 1500 | 1000 (esc) 1500 | 0 | 1 | NR | NR
Fujioka, 2003 ^105^ | RCT | Neuropathy/unclear neuropathy | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 (esc) 1500 | 1000 (esc) 2000 | 0 | 0 | NR | NR
Placebo-Controlled Trials
Manzella, 2004 ^148^ | RCT | Neuropathy/autonomic assessed by mean LF/HF ratio used as an index of cardiac sympathetic/parasympathetic tone balance | Metformin + diet, 60 | Placebo + diet, 60 | 850 bid (fixed) | NA | NR | NR | 4.7 (baseline); 2.9 (followup); p<0.02 versus placebo | 4.8 (baseline); 4.5 (followup)

Comp = comparison; GP = group; mg = milligrams; esc = escalated; max = maximum; CI = confidence interval; NR = not reported; NA = not applicable; RCT = randomized controlled trial; bid = twice a day; XR = extended release; LF/HF ratio = sympathovagal balance index

Table 28 Evidence Table. Quality of randomized controlled trials evaluating comparative effectiveness of oral diabetes medications on distal diabetes-related complications

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score
Nishio, 2006 ^151^ | Yes | Not described | No | No | Yes | 2
Weissman, 2005 ^100^ | Yes | Not described | Yes | Yes | Yes | 4
Rosenstock, 2006 ^124^ | Yes | Not described | Yes | Not described | Yes | 3
Bailey, 2005 ^101^ | Yes | Yes | Yes | Not described | Yes | 4
Dormandy, 2005 ^185^ | Yes | Yes | Yes | Yes | Yes | 5
Cryer, 2005 ^176^ | Yes | Not described | No | No | Yes | 2
Schernthaner, 2004 ^56^ | Yes | Yes | Yes | Yes | Yes | 5
Choi, 2004 ^77^ | Yes | Not described | No | No | Yes | 2
Baksi, 2004 ^126^ | Yes | Not described | Yes | Not described | Yes | 3
Yanagawa, 2004 ^62^ | Yes | Not described | Nr | No | No | 1
Manzella, 2004 ^148^ | Yes | Not described | No | No | Yes | 2
Hanefeld, 2004 ^60^ | Yes | Not described | Yes | Yes | No | 3
Lawrence, 2004 ^54^ | Yes | Not described | No | No | Yes | 2
Garber, 2003 ^80^ | Yes | Yes | Yes | Yes | Yes | 5
Takagi, 2003 ^78^ | Yes | Not described | No | No | No | 1
Goldstein, 2003 ^82^ | Yes | Yes | No | No | Yes | 3
Herz, 2003 ^163^ | Yes | Not described | Yes | Not described | Yes | 3
Barnett, 2003 ^172^ | Yes | Not described | Yes | Yes | Yes | 4
Fujioka, 2003 ^105^ | Yes | Not described | Yes | Yes | Yes | 4
Luis Bautista, 2003 ^193^ | Yes | Not described | Yes | Yes | Yes | 4
Vongthavaravat, 2002 ^170^ | Yes | Yes | No | No | No | 2
Virtanen, 2003 ^143^ | Yes | Not described | Nr | Not described | Yes | 2
Hallsten, 2002 ^58^ | Yes | Not described | No | No | Yes | 2
St John Sutto, 2002 ^67^ | Yes | Not described | No | No | Yes | 2
Rachmani, 2002 ^150^ | Yes | Yes | No | No | Yes | 3
Gomez-Perez, 2002 ^102^ | Yes | Not described | Yes | Not described | Yes | 3
Kipnes, 2001 ^166^ | Yes | Not described | Yes | Not described | Yes | 3
Amador-Licona, 2000 ^85^ | Yes | Not described | No | No | Yes | 2
Lebovitz, 2001 ^169^ | Yes | Not described | No | No | No | 1
Fonseca, 2000 ^103^ | Yes | Yes | Yes | Yes | Yes | 5
Nakamura, 2000 ^64^ | Yes | Not described | No | No | No | 1
Horton, 2000 ^96^ | Yes | Not described | Yes | Yes | Yes | 4
Aronoff, 2000 ^165^ | Yes | Not described | Yes | Not described | No | 2
Hanefeld, 2000 ^190^ | Yes | Not described | Yes | Yes | No | 3
Hasche, 1999 ^138^ | Yes | Not described | Yes | Not described | Yes | 3
Jovanovic, 2000 ^194^ | Yes | Yes | Yes | Yes | Yes | 5
Marbury, 1999 ^116^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 1999 ^117^ | Yes | Not described | Yes | Yes | Yes | 4
Goldberg, 1998 ^139^ | Yes | Not described | Yes | Not described | Yes | 3
1998, ^15^ | Yes | Not described | No | No | Yes | 2
1998, ^16^ | Yes | Yes | No | No | No | 2
Rosenstock, 1996 ^189^ | Yes | Not described | Yes | Not described | Yes | 3
DeFronzo, 1995 ^88^ | Yes | Not described | Yes | Yes | Yes | 4
Hermann, 1994 ^87^ | Yes | Yes | Yes | Yes | No | 4
Carlson, 1993 ^108^ | Yes | Not described | Yes | Not described | Yes | 3
Teupe, 1991 ^155^ | Yes | Not described | No | No | Yes | 2
Akanuma, 1988 ^196^ | Yes | Not described | No | No | Yes | 2
Baba, 1983 ^133^ | Yes | Not described | Yes | Not described | Yes | 3
Lester, 2005 ^242^ | Yes | Not described | Yes | Not described | No | 2
Zhu, 2003 ^188^ | Yes | Yes | Yes | Not described | Yes | 4
Bakris, 2003 ^66^ | Yes | Not described | No | No | No | 1
Sonnenberg, 1997 ^191^ | Yes | Not described | Yes | Not described | Yes | 3
Draeger, 1996 ^112^ | Yes | Not described | Yes | Yes | Yes | 4

Table 29 Evidence Table. Study design characteristics table for studies reporting on quality of life (Key Question 3)

Author, year | Study design | Country | Pharmaceutical support | Study duration (planned/mean) | Exclusion criteria
Study group
Smith, 2005 ^161^ | RCT | US | Yes | 24 weeks (planned duration) | Age <35 or >75, any liver disease, any kidney disease, history of CVD, treatment experienced, no type 2 diabetes, other
Bailey, 2005 ^101^ | RCT | UK, 14 European Countries | Yes | 24 weeks (planned duration) | Age <18 or >70, history of CVD, no type 2 diabetes, other
Rosenstock, 2006 ^124^ | RCT | US, Canada | NR | NR | Age <60, history of CVD, no type 2 diabetes, other
Bech, 2003 ^197^ | RCT | Australia, Croatia, Czech Republic, France, Greece, Israel, Macedonia, Poland, Russia, Slovenia, Spain | Yes | NR | Age < 40 years, any liver disease, history of CVD, treatment experienced, no type 2 diabetes, other
Testa, 1998 ^198^ | RCT | US | Yes | 15 weeks (planned duration) | Age <30, no type 2 diabetes, other

RCT = Randomized controlled trial; CVD = cardiovascular disease; US = United States; UK = United Kingdom; NR = not reported

Table 30 Evidence Table. Study population table for studies reporting on quality of life (Key Question 3)

Author, year | Group, N | Mean age (age range) | Male, n (%) | Race, n (%) | Mean BMI in kg/m^2^(other measure) | Mean weight (other measure) | Mean HbA1c % | Mean duration of diabetes
Rosenstock, 2006 ^124^ | Glipizide + rosiglitazone, N=116 | 68.7 | (74.8) | NR | 30.2 | NR | 7.72 | 6.8
| Placebo + glipizide, N=111 | 68.2 | (71.8) | NR | 30.5 | NR | 7.65 | 6.6
Bech, 2003 ^197^ | Repaglinide, N=164 | 56.9 (40–81) | (57.3) | AA: 1 (0.6); C: 161 (98.2); Asian: 0 (0); H: 0; O: 2 (1.2) | 7.8 | 2.77 | NR | NR
| Placebo, N=89 | 57.3 (40–76) | (58.4) | AA: 0 (0); C: 88 (98); Asian: 0 (0); H: 0; O: 1 (1.1) | 7.6 | 2.81 | NR | NR
Smith, 2005 ^161^ | Placebo + diet, N=21 | 53.1 | 10 | AA: 0; C: 16; Asian: 0; H: 0; O: 5 | 31.9 | 91.5 | 6.46 | NR
| Diet + pioglitazone, N=21 | 56.2 | 9 | AA: 0; C: 15; Asian: 0; H: 0; O: 6 | 32.1 | 93.5 | 6.88 | NR
Bailey, 2005 ^101^ | Metformin + rosiglitazone, N=288 | 58.1 | 168 (58) | AA: 2 (1); C: 280 (97); Asian: 3 (1); H: 0; O: 3 (1) | 32.2 | 90.9 | 7.4 | 6
| Metformin, N=280 | 57.6 | 159 (57) | AA: 1 (<1); C: 273 (98); Asian: 3 (1); H: 0; O: 3 (1) | 32.1 | 89.5 | 7.5 | 6.1
Testa, 1998 ^198^ | Placebo + diet, n=192 | 58.4 (30–82) | (58.9) | AA: (15.6); C: (72.9); Asian: 0; H: 0; O: (11.5) | 30.3 | NR | 8.7 | 4.7
| Diet + glipizide GITS, N=377 | 58.7 (30–85) | (54.9) | AA: (16.7); C: (71.9); Asian: 0; H: 0; O: (11.4) | 30.1 | NR | 8.5 | 5.6

BMI = body mass index; HbA1c = hemoglobin A1c; AA = African American; C = Caucasian; H = Hispanic; O = other; NR = not reported; GITS = gastrointestinal therapeutic system

Table 31 Evidence Table. Comparative effectiveness of oral diabetes medications on quality of life

Author, year | Quality of life assessment | Comp group 1, N | Comp group 2, N | Group 1, initial dose in mg (fixed or esc) max dose | Group 2, initial dose in mg (fixed or esc) max dose | GP1 BL mean (SD) | GP2 BL mean (SD) | Mean diff BL2 - mean diff BL1 | P-value for comparisons with GP1 | P-value for comparisons with GP2
Study group | | | | | | GP1 final mean (SD) | GP2 final mean (SD)
| | | | | | Mean diff from BL1 | Mean diff from BL2
Smith, 2005 ^161^ | Visual analog scale estimation of hunger and satiety | Pioglitazone + existing medication + diet, 21 | Existing medication + placebo + diet, 21 | 30 (esc) 45 | NR | NR | NR | NR | 0.197 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Bailey, 2005 ^101^ | Diabetes treatment satisfaction questionnaire | Metformin, 258 | Rosiglitazone + metformin, 270 | 2500 (esc) 3000 | 4 (esc) 8 | NR | NR | NR | | <0.014 vs. GP1
| | | | | 2000 (fixed) | NR | NR
| | | | | | -1.1 | -0.1
Rosenstock, 2006 ^124^ | Diabetes treatment satisfaction questionnaire | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | -2.76 | | <0.001 vs. GP1
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -1.61 | 1.15
Rosenstock, 2006 ^124^ | Short Form-36 (mental health component) | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | NR | NSG vs. GP2
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -1.71 | NR
Rosenstock, 2006 ^124^ | Short Form-36 (physical health component) | Glipizide + placebo, 57 | Rosiglitazone + glipizide, 90 | 10 (esc) 20 | 4 (fixed) | NR | NR | NR | NSG vs. GP2
| | | | | 10 (esc) 20 | NR | NR
| | | | | | -2.43 | NR
Bech, 2003 ^197^ | Diabetes treatment satisfaction questionnaire | Repaglinide, 164 | Placebo, 89 | 0.5 (esc) 4 tid | NA | 75.2 | 79.2 | 7.2 | <0.05 vs. baseline | NSG vs. baseline
| | | | | | 83.9 | 80.7
| | | | | | 8.7 | 1.5
Bech, 2003 ^197^ | EuroQoL | Repaglinide, 164 | Placebo, 89 | 0.5 (esc) 4 tid | NA | 0.82 | 0.83 | NR | NSG vs. baseline | NSG vs. baseline
| | | | | | NR | NR
| | | | | | NR | NR
Bech, 2003 ^197^ | WHO Wellbeing Questionnaire | Repaglinide, 136 | Placebo, 63 | 0.5 (esc) 4 tid | NA | 74.5 | 77 | 0.3 | NSG vs. baseline | NSG vs. baseline
| | | | | | 74.3 | 76.5
| | | | | | -0.2 | -0.5
Testa, 1998 ^198^ | Visual analog scale - perceived health | Glypizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | NR | NR | 0.36 | 0.004 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Testa, 1998 ^198^ | Visual analog scale - symptom distress | Glypizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | NR | NR | 0.59 | <.001 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Testa, 1998 ^198^ | Visual analog scale - mental and emotional health | Glypizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | NR | NR | 0.16 | 0.22 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Testa, 1998 ^198^ | Visual analog scale - overall VAS | Glypizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | NR | NR | 0.24 | 0.04 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR
Testa, 1998 ^198^ | Visual analog scale - cognitive functioning | Glypizide GITS + diet, 377 | Placebo + diet, 192 | 5 (esc) 20 | NA | NR | NR | 0.34 | 0.005 vs. GP2
| | | | | | NR | NR
| | | | | | NR | NR

Comp = comparison; BL = baseline; GP = group; mg = milligrams; esc = escalated; max = maximum; SD = standard deviation; diff = difference; mmol = millimole; NR = not reported; NA = not applicable; QoL = quality of life; WHO = World Health Organization; VAS = visual analog scale; GITS = gastrointestinal therapeutic system

Table 32 Evidence Table. Quality of randomized controlled trials evaluating comparative effectiveness of oral diabetes medications on quality of life

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score
Rosenstock, 2006 ^124^ | Yes | Not Described | Yes | Not described | Yes | 3
Bailey, 2005 ^101^ | Yes | Yes | Yes | Not described | Yes | 4
Smith, 2005 ^161^ | Yes | Not Described | Yes | Yes | No | 3
Bech, 2003 ^197^ | Yes | Not Described | Yes | Not described | No | 2
Testa, 1998 ^198^ | Yes | Not Described | Yes | Not described | Yes | 3

Table 33 Evidence Table. Study Design Characteristics Table for Studies Reporting on Adverse Events (Key Question 4)

Author, year Study group | Study design | Country | Pharmaceutical support | Study duration (planned/mean) | Exclusion criteria
Kane, 2004 ^219^ | Cohort | US | No | 24 weeks (Mean follow-up) | No type 2 diabetes, Other
Ballary, 2003 ^227^ | trial without control arm | India | Yes | NR | Age <36 or >65, Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <8%, No type 2 diabetes, Other
Swislocki, 1999 ^210^ | Cohort | US | No | NR | No type 2 diabetes, Other
Rosenbaum, 2002 ^153^ | RCT | Brazil | No | 24 weeks (Planned duration) | Age <40 or >65, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
Stang, 1999 ^235^ | Cohort | US, Canada | No | NR | No type 2 diabetes, Other
Simpson, 2006 ^14^ | Cohort | Canada | No | 249.6 for 234 subjects taking lower daily doses, 234 subjects taking higher doses (Mean follow-up) | Age <30, Other
Nishio, 2006 ^151^ | RCT | Japan | No | 6 months (Planned duration) | Any liver disease, Any kidney disease, No type 2 diabetes, Other
Weissman, 2005 ^100^ | RCT | US | Yes | 24 weeks (Planned duration) | Age <18 and >75, Any liver disease, Any kidney disease, History of CVD, HbA1c <6.5 or >8.5 for patients having received prior combination treatment; <7 or >10 prior monotherapy or drug naive patients, No type 2 diabetes, Other
Rosenstock, 2006 ^124^ | RCT | US, Canada | No | NR | Age <60, History of CVD, No type 2 diabetes, Other
Bailey, 2005 ^101^ | RCT | UK, 14 European Countries | Yes | 24 weeks (Planned duration) | Age <18 or >70, History of CVD, No type 2 diabetes, Other
Kardas, 2005 ^114^ , DIACOM | RCT | Poland | No | NR | Age <40 and >75, HbA1c >9.0%, No type 2 diabetes, Other
Forst, 2005 ^145^ | RCT | Germany | Yes | 24 weeks (Planned duration) | Age < 40 or >75, Any liver disease, Any kidney disease, History of CVD, HbA1c <6.6 or >9.9, No type 2 diabetes, Other
Hartung, 2005 ^231^ | Case-control | US | No | NR | Age <18, No type 2 diabetes, Other
Bhansali, 2005 ^214^ | pre-post | UK, India | Yes | NR | Age <40, Any liver disease, Any kidney disease, History of CVD, HbA1c >8.5 or FPG>120mg/dl, No type 2 diabetes, Other
Yamanouchi, 2005 ^57^ | RCT | Japan | No | 12 months (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Neuropathy, Retinopathy, HbA1c <7.0%, No type 2 diabetes, Other
Kahara, 2005 ^234^ | Non-randomized trial | Japan | No | 3 months (Planned duration) | No type 2 diabetes, Other
Goldberg, 2005 ^52^ | RCT | US, Puerto Rico, Mexico, and Colombia | Yes | 24 weeks (Planned duration) | Age <35, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, HbA1c <7 or >11.5 if naive to anithyperglycemic therapy; <7 or >9.5 if previously treated with oral antihyperglycemic therapy, No type 2 diabetes, Other
Pfutzner, 2005 ^68^ | RCT | Germany | Yes | 26 weeks (Planned duration) | Age <40 or >75, Any liver disease, Any kidney disease, History of CVD, HbA1c <6.6% or >9.9%, Other
Derosa, 2005 ^53^ | RCT | Italy | No | NR | Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <7.5%, No type 2 diabetes, Other
Derosa, 2005 ^72^ | RCT | Italy | No | 12 months (Planned duration) | Age <18, Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <7.5, No type 2 diabetes, Other
Chalasani, 2005 ^222^ | Cohort | US | No | duration of therapy=357 days for group 1 and 423 days in group 2 (Mean follow-up) | No type 2 diabetes, Other
Langenfeld, 2005 ^146^ | RCT | Germany | Yes | 24 weeks (Planned duration) | Age <40 or age>75, Any liver disease, Any kidney disease, History of CVD, HbA1c <6.6% or >9.9%, No type 2 diabetes, Other
Rajagopalan, 2005 ^223^ | Cohort | US | Yes | 294.2, 296.1, 300.1, 321.9, 295.9, 319.9 Groups 1 and 2: Pioglitazone vs. rosiglitazone; Groups 3 and 4: Pioglitazone vs. sulfonylurea; Groups 5 and 6: Pioglitazone vs. metformin (Mean follow-up) | Age <18, Any liver disease, No type 2 diabetes, Other
Feinglos, 2005 ^104^ | RCT | US | Yes | 16 weeks (Planned duration) | Age <30 or age >81, Any liver disease, Any kidney disease, History of CVD, HbA1c <7.0% or >8.5%, No type 2 diabetes, Other
Evans, 2005 ^325^ | Case-control | Scotland | No | NR | No type 2 diabetes
Goke, 2002 ^75^ , German Pio Study Group | RCT | Germany | Yes | 26 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, HbA1c <7.5% or >11.5%, No type 2 diabetes, Other
Charbonnel, 2005 ^63^ | RCT | 14 European countries, Australia, Canada, South Africa and Israel | Yes | 52 weeks (Planned duration) | Age <35 and >75, Treatment experienced, HbA1c <7.5% and >11%, No type 2 diabetes, Other
Tan, 2005 ^61^ , this is a one yr extension study for Quartet study group (ref 11) but only half the original centers included (98/208 centers) | RCT | Canada, UK, Australia, Finland, Poland, the Slovak republic and South Africa | Yes | 104 weeks (Planned duration) | Age <35 >75, Treatment experienced, HbA1c <7.5% or >11% with diet alone, No type 2 diabetes, Other
Cryer, 2005 ^176^ , COSMICApproach Study | RCT | US | Yes | 12 months (Planned duration) | Age <18, Any liver disease, Any kidney disease, No type 2 diabetes, Other
McCluskey, 2004 ^76^ | RCT | US | Yes | 30 weeks (Planned duration) | Age <18 >80, Treatment experienced, HbA1c <7.5% & >9.5%, No type 2 diabetes, Other
Maru, 2005 ^232^ , UK General Practice Research Database | Cohort | UK | Yes | 130 (Mean follow-up) | Age <35, Treatment experienced, No type 2 diabetes, Other
Schernthaner, 2004 ^56^ | RCT | Europe | No | 12 months (Planned duration) | Age <35 or >75, Treatment experienced, HbA1c <7.5% or >11%, No type 2 diabetes,
Smith, 2005 ^161^ | RCT | US | Yes | 24 weeks (Planned duration) | Age <35 or >75, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Rajagopalan, 2004 ^327^ , PharMetrics Patient-Centered Database | Cohort | US | No | 45.9 weeks (Mean follow-up) | Age <18, No type 2 diabetes, Other
Choi, 2004 ^77^ | RCT | Korea | No | 6 months (Planned duration) | Any liver disease, Any kidney disease, Other
Matthews, 2005 ^70^ | RCT | Europe and Australia | Yes | 52 months (Planned duration) | Age <35 or >75, History of CVD, HbA1c <7.5% or >11%, No type 2 diabetes, Other
Nichols, 2005 ^230^ , Kaiser Permaneante database | Cohort | US | Yes | 144.4 total sulfonylurea monotherapy group-mean MONTHS of followup is 26.4; metformin monotherapy-mean MONTHS of followup is 23.1; sulfonylurea + metformin-mean months of followup is 28.3 (Mean follow-up) | Other
Derosa, 2004 ^90^ | RCT | Italy | No | 12 months (Planned duration) | Age <46 or >67, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Schernthaner, 2004 ^106^ | RCT | 154 clinical centres in Austria, Belgium, the Czech Republic, France, Germany, Hungary, Italy, the Netherlands, Poland, Slovakia, Spain, and the United Kingdom | No | 27 weeks (Planned duration) | Age <35, Any liver disease, Any kidney disease, HbA1c < 6.9 or > 11.5, No type 2 diabetes, Other
Tan, 2004 ^65^ | RCT | 22 centres in Denmark, Finland, Norway, and Sweden. | Yes | 52 weeks (Planned duration) | Treatment experienced, HbA1c <7.5 or > 11 for pts not receiving OAM, <7.5, > 9.5 for patients receiving OAM, No type 2 diabetes, Other
Bell, 1997 ^208^ | interview of patients over 3 months asking if they have ever experienced hypoglycemia | US | No | NR | No type 2 diabetes
Baksi, 2004 ^126^ | RCT | 7 European countries | Yes | 26 weeks (Planned duration) | Age <35 or >80, Any liver disease, History of CVD, Treatment experienced, Neuropathy, No type 2 diabetes, Other
Tan, 2004 ^69^ | RCT | Mexico | Yes | NR | Any liver disease, Any kidney disease, History of CVD, HbA1c < 7.5% to > 11% in patients who were not receiving OAMs, and <7.5% to >9.5% in patients who were receiving OAM monotherapy, No type 2 diabetes, Other
Saad, 2004 ^164^ | RCT | US | Yes | 12 weeks (Planned duration) | Age <18 or >73, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Other
Rosenstock, 2004 ^131^ | RCT | US | Yes | 16 weeks (Planned duration) | Age <18, Females, Treatment experienced, No type 2 diabetes, Other
Raskin, 2004 ^74^ | RCT | US | Yes | 12 titration and 12 maintenance weeks (Planned duration) | Age <18, HbA1c <7 or >12% during previous monotherapy with sulfonylurea or metformin at 50% or more of maximal recommended dose for at least 3 months, No type 2 diabetes, Other
Manzella, 2004 ^148^ | RCT | Italy | No | 4 months (Planned duration) | History of CVD, Treatment experienced, Neuropathy, No type 2 diabetes, Other
Feinbock, 2003 ^130^ | RCT | Austria | Yes | 26 weeks (Planned duration) | Age <36 or >80, Any liver disease, Any kidney disease, Treatment experienced, HbA1c <7.8%, No type 2 diabetes, Other
Kerenyi, 2004 ^125^ | RCT | 15 countries | Yes | 26 weeks (Planned duration) | Age <35 or >80, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Jovanovic, 2004 ^73^ | RCT | US | Yes | 12 week titration then 12 week maintenance (Planned duration) | Age <18, HbA1c <7 or >12, No type 2 diabetes, Other
Hanefeld, 2004 ^60^ , QUARTET study group | RCT | Canada, UK, Hungary, Finland, U.K., Slovak Republic, Belgium, Estonia, Lithuania, Denmark, Italy, Greece, Sweden, and the Netherlands | Yes | NR | Age <35 or >75, History of CVD, HbA1c <7.5 or >11, No type 2 diabetes, Other
Lawrence, 2004 ^54^ | RCT | UK | Yes | 12 titration, 12 maintenance weeks (Planned duration) | Age <45 or >80, Any liver disease, Any kidney disease, History of CVD, HbA1c for diet treated diabetes: <7% or >10% for low-dose oral hypoglycemic therapy: >7.5%, No type 2 diabetes, Other
Delea, 2003 ^228^ , Pharmetrics Integrated Outcomes Database | Cohort | US | Yes | 6 years (Mean follow-up) | Age 48, Other
Garber, 2003 ^80^ | RCT | US | Yes | 16 weeks (Planned duration) | NR
Takagi, 2003 ^78^ | RCT | Japan | No | NR | Any liver disease, Any kidney disease, No type 2 diabetes, Other
Tosi, 2003 ^95^ | RCT, cross-over | Italy | Yes | 6 months (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Treatment experienced, HbA1c <6.3, No type 2 diabetes, Other
Goldstein, 2003 ^82^ | RCT | US | Yes | 18 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, HbA1c <7.5 and >12.0, Other
Herz, 2003 ^163^ | RCT | Canada, Spain | Yes | 16 weeks (Planned duration) | Any liver disease, Any kidney disease, Treatment experienced, HbA1c HbA1c < 6.5% or HbA1c>9.8%, No type 2 diabetes, Other
Ko, 2003 ^328^ | Non-randomized trial | Korea | No | 12 weeks (Planned duration) | Onset of diabetes <40 old, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Derosa, 2003 ^97^ | RCT | Italy | No | 12 months (Planned duration) | Any kidney disease, History of CVD, Treatment experienced, HbA1c < 7 %, No type 2 diabetes, Other
Barnett, 2003 ^172^ | RCT | UK | No | 26 weeks (Planned duration) | Age <30 or Age > 80, Any liver disease, HbA1c < 7.5%, No type 2 diabetes, Other
Fujioka, 2003 ^105^ | RCT | US | Yes | 24 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, HbA1c >8.5% and FPG>200 mg/dL while on MIR for >=8 weeks, No type 2 diabetes, Other
Zhu, 2003 ^188^ | RCT | China | Yes | 24 weeks (Planned duration) | Age <40 or age>70, Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <7.5%, No type 2 diabetes, Other
Del Prato, 2003 ^149^ | RCT | France, Italy, Netherlands | No | 29 weeks (Planned duration) | Age <35 or age>70, HbA1c <7.5% or >10% after run-in period, No type 2 diabetes, Other
Pavo, 2003 ^59^ | RCT | Russia and Hungary | Yes | 32 weeks (Planned duration) | Age <40, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, HbA1c <7.5% or >11.0%, No type 2 diabetes, Other
Chandrasekharan, 2002 ^212^ | Cohort | India | Yes | NR | Age < 30 or > 65, Any liver disease, Any kidney disease, History of CVD, HbA1c <= 8%, No type 2 diabetes, Other
Leese, 2003 ^201^ , DARTS/MEMO | Cohort | Scotland | Yes | NR | No type 2 diabetes
Luis Bautista, 2003 ^193^ | RCT | US | Yes | NR | Age <35 or >80, HbA1c <8.0% or >10.5%, No type 2 diabetes, Other
Jun, 2003 ^233^ | Cohort | US | No | NR | Age <=18, HbA1c <8% and have not had an HbA1c measurement within one month before the start of the study medication and have not had >=2 HbA1c measurements at 3 month intervals during the 6 month study period, No type 2 diabetes, Other
Vongthavaravat, 2002 ^170^ | RCT | India, Thailand, The Philippines, Tunisia, Argentina and Brazil | Yes | 26 weeks (Planned duration) | Age <40 or >80, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Neuropathy, Retinopathy, No type 2 diabetes, Other
Virtanen, 2003 ^143^ | RCT | Finland | Yes | 26 weeks (Planned duration) | Age <45 or >75, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Neuropathy, Retinopathy, No type 2 diabetes, Other
Vakkilainen, 2002 ^122^ | RCT | Finland | Yes | 12 weeks (Planned duration) | Age <18 or >75, Any liver disease, Any kidney disease, HbA1c <6.5 or >10, No type 2 diabetes, Other
Cefalu, 2002 ^323^ | RCT | US | No | 18 weeks (Planned duration) | Age <35 or age>70, HbA1c <7%, No type 2 diabetes, Other
Hallsten, 2002 ^58^ | RCT | Finland | Yes | 26 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Scherbaum, 2002 ^141^ | RCT | Germany | Yes | 26 weeks (Planned duration) | Age <35 or age>70, Any liver disease, History of CVD, HbA1c <7.5% or >12%, No type 2 diabetes, Other
Blonde, 2002 ^81^ | RCT | US | Yes | 16 weeks (Planned duration) | Age <30 or >75, Any liver disease, Any kidney disease, History of CVD, HbA1c <7.4%, No type 2 diabetes, Other
St John Sutto, 2002 ^67^ | RCT | US | Yes | 52 weeks (Planned duration) | Age <40 or age>80, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Rachmani, 2002 ^150^ | RCT | Israel | No | 4 years (Planned duration) | Age < 40 or > 75, No type 2 diabetes, Other
Saloranta, 2002 ^241^ | RCT | 12 countries Argentina, Australia, Belgium, Canada, Finland, France, Germany, Italy, Netherlands, New Zealand, Sweden, USA | Yes | 24 weeks (Planned duration) | Age <30, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Kubo, 2002 ^225^ | Non-randomized trial | Japan | No | 12 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, No type 2 diabetes, Other
Rosenstock, 2002 ^330^ | NR | NR | No | NR | NR
Marre, 2002 ^84^ | RCT | Netherlands, Denmark, Portugal, France, Belgium | Yes | 4 months (Planned duration) | Age <18, Any liver disease, Any kidney disease, History of CVD, Other
Garber, 2002 ^79^ | RCT | US | Yes | 20 weeks (Planned duration) | Any liver disease, Any kidney disease, Treatment experienced, HbA1c <7% or >11%, No type 2 diabetes, Other
Gomez-Perez, 2002 ^102^ | RCT | Mexico | Yes | 26 weeks (Planned duration) | Age <40 or >80, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Deerochanawong, 2001 ^331^ | Trial without control arm | Thailand | Yes | NR | Age <35 or >75, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
Holstein, 2001 ^202^ | Cohort | Germany | No | NR | Other
Charpentier, 2001 ^206^ | | | No | NR | Age <35 or age>70, No type 2 diabetes, Other
Charpentier, 2001 ^89^ | RCT | France | Yes | 20 weeks (Planned duration) | Age <= 34 or >= 71, Any kidney disease, History of CVD, No type 2 diabetes, Other
Rosenblatt, 2001 ^162^ | RCT | US | Yes | 16 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Neuropathy, Retinopathy, HbA1c < 8.0%, No type 2 diabetes, Other
Emslie-Smith, 2001 ^332^ | Cohort | Scotland | No | NR | No type 2 diabetes, Other
Madsbad, 2001 ^119^ | RCT | Denmark, Scandinavia | Yes | 12 months (Planned duration) | Age <=39 or >=76, Any liver disease, Any kidney disease, HbA1c <6.5 or >10%, No type 2 diabetes, Other
Kipnes, 2001 ^166^ | RCT | US | Yes | NR | Age <30 or >75, Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <8, No type 2 diabetes, Other
Gegick, 2001 ^192^ | Cohort | US | Yes | 12.8 (Mean follow-up) | HbA1c Had not had at least two baseline determinations while receiving maintenance troglitazone therapy, No type 2 diabetes, Other
Mertes, 2001 ^213^ | Cohort | Germany | No | NR | No type 2 diabetes
Amador-Licona, 2000 ^85^ | RCT | Mexico | No | 12 weeks (Planned duration) | Age >65, Any liver disease, History of CVD, Other
Lebovitz, 2001 ^169^ | RCT | US | No | 26 weeks (Planned duration) | Age < 36 or >81, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Patel, 1999 ^167^ | RCT | US | No | 12 weeks (Planned duration) | Age < 30 or > 80, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Phillips, 2001 ^168^ | RCT | US | Yes | 26 weeks (Planned duration) | Age < 40 or >80, Any liver disease, Any kidney disease, Neuropathy, No type 2 diabetes, Other
Moses, 2001 ^218^ | RCT | 13 countries | Yes | 16 weeks (Planned duration) | Age <40, Any liver disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Einhorn, 2000 ^160^ | RCT | US | Yes | 16 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <8.0, No type 2 diabetes, Other
Fonseca, 2000 ^103^ | RCT | US | No | 26 weeks (Planned duration) | Age <40 or >80, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Neuropathy, No type 2 diabetes, Other
Abbasi, 2000 ^265^ | Cohort | US | No | NR | Any kidney disease, No type 2 diabetes, Other
Bytzer, 2001 ^216^ | Cross-sectional | Australia | No | NR | No type 2 diabetes, Other
Horton, 2000 ^96^ | RCT | US | Yes | 24 weeks (Planned duration) | Age <30, Any kidney disease, HbA1c <6.8% or >11%, No type 2 diabetes, Other
Aronoff, 2000 ^165^ | RCT | US | Yes | 26 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c <7%, No type 2 diabetes, Other
Hanefeld, 2000 ^190^ | RCT | Europe, multicenter | Yes | 12 weeks (Planned duration) | Age <30 or >75, Any kidney disease, History of CVD, Neuropathy, Retinopathy, HbA1c mean level of two tests <6.8 or >10.5, No type 2 diabetes, Other
King, 2000 ^142^ | Non-randomized trial | US | No | 4 months (Planned duration) | Other
Hasche, 1999 ^138^ | RCT | Germany | No | 104 weeks (Planned duration) | Age < 40 or >80, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, HbA1c <7.5 or >9.5%, No type 2 diabetes, Other
Wolffenbuttel, 2000 ^171^ | RCT | Italy, UK, France, Spain, Holland and Switzerland | Yes | 26 weeks (Planned duration) | Age < 30 or >80, Any liver disease, Any kidney disease, Neuropathy, HbA1c < 7.5%, No type 2 diabetes, Other
Gregorio, 1999 ^129^ | RCT | Italy | No | 18 weeks (Planned duration) | Age < 70, Any liver disease, Any kidney disease, History of CVD, HbA1c < 9%, No type 2 diabetes, Other
Klamann, 2000 ^183^ | Cohort | Germany | No | NR | No type 2 diabetes, Other
Jovanovic, 2000 ^194^ | RCT | US | Yes | 24 weeks (Planned duration) | Age <40 or > 75, Any liver disease, Any kidney disease, History of CVD, HbA1c with OHA (naive): <6.5%; with OHA-treatment: > 12%, No type 2 diabetes, Other
Willms, 1999 ^99^ | RCT | Germany | Yes | 12 weeks (Planned duration) | Age <18, Any liver disease, Any kidney disease, History of CVD, HbA1c <7% or >13%, No type 2 diabetes, Other
Lysy, 1999 ^220^ | Cross-sectional | Israel | No | NR | NR
Erle, 1999 ^127^ | RCT | US, Italy | Yes | 6 months (Planned duration) | No type 2 diabetes, Other
Landgraf, 1999 ^121^ | RCT | Germany, Austria, and Netherlands | Yes | 14 weeks (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Marbury, 1999 ^116^ | RCT | US, Canada | Yes | 12 months (Planned duration) | Age >37 or <75, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, HbA1c <6.5% or 14.6%, No type 2 diabetes, Other
Selby, 1999 ^237^ | Cohort | US | Yes | 5.6 months for HbA1c outcome only (Mean follow-up) | HbA1c <6.7, No type 2 diabetes, Other
Wolffenbuttel, 1999 ^117^ | RCT | Germany, Austria, Netherlands | No | 12 months (Planned duration) | Age <40 or >75, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, HbA1c <6.5 if treated w/diet only; >12% if treated with diet plus oral, Other
Testa, 1998 ^198^ | RCT | US | Yes | 15 weeks (Planned duration) | Age <30, No type 2 diabetes, Other
Goldberg, 1998 ^139^ | RCT | US | Yes | 18 weeks (Planned duration) | Age <40 and >75, No type 2 diabetes, Other
1998, ^15^ , UKPDS | RCT | UK | Yes | NR | Age <25 or >65, Treatment experienced, No type 2 diabetes, Other
1998, ^16^ , UKPDS | RCT | UK | Yes | NR | Age <25 or >65, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, No type 2 diabetes, Other
Schade, 1998 ^135^ | RCT | US | Yes | 12 weeks (Planned duration) | Age <30 or >75, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
1998, ^128^ , UKPDS | RCT | UK | Yes | 3 years (Planned duration) | Age <25 or >65, Any kidney disease, History of CVD, Other
Cathelineau, 1997 ^209^ | trial without control arm | France | No | NR | Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Garber, 1997 ^217^ | RCT | US | Yes | 14 weeks (Planned duration) | Age <30, Treatment experienced, No type 2 diabetes, Other
Sonnenberg, 1997 ^191^ | RCT, cross-over | US | Yes | 4 weeks (Planned duration) | Age <40 or >80, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
Simonson, 1997 ^136^ | RCT | US | Yes | 16 weeks (Planned duration) | Age < 30, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, HbA1c <6 % at the end of week 2 of placebo administration, No type 2 diabetes, Other
Rosenstock, 1996 ^189^ | NR | NR | No | NR | No type 2 diabetes, Other
Dills, 1996 ^107^ | RCT | US | Yes | 12 months (Planned duration) | Age <30 or>80, Any liver disease, Any kidney disease, No type 2 diabetes, Other
Draeger, 1996 ^112^ | RCT | UK, Europe, Asia, South Africa and South America | No | 12 months (Planned duration) | Age < 40 or > 80, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
Goldberg, 1996 ^134^ | RCT | US | Yes | NR | Age <30 or >75, Any liver disease, Any kidney disease, No type 2 diabetes, Other
Gregorio, 1996 ^221^ | pre-post | Italy | No | NR | Age <70, Any liver disease, Any kidney disease, HbA1c <9%, No type 2 diabetes, Other
Grant, 1996 ^154^ | RCT | UK | Yes | 24 weeks (Planned duration) | No type 2 diabetes, Other
Vray, 1995 ^137^ | RCT, factorial | France, China | Yes | 3 months (Planned duration) | Age <40 or >70, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
DeFronzo, 1995 ^88^ | RCT | US | No | 29 weeks (Planned duration) | Age <40 or >70, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, No type 2 diabetes, Other
Tsumura, 1995 ^333^ | | NR | No | NR | NR
1995, ^92^ , UKPDS | RCT | UK | Yes | 3 years (Planned duration) | Age <25 or >65, Any liver disease, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, No type 2 diabetes, Other
Hermann, 1994 ^87^ | RCT | Sweden | Yes | 6 months (Planned duration) | No type 2 diabetes, Other
Birkeland, 1994 ^110^ | RCT | Norway | Yes | 15 months (Planned duration) | Any liver disease, Any kidney disease, History of CVD, Treatment experienced, HbA1c <7% or >11%, No type 2 diabetes, Other
Rosenstock, 1993 ^109^ | RCT | US | Yes | 4 months (Planned duration) | Age < 65, Any liver disease, Any kidney disease, Treatment experienced, No type 2 diabetes, Other
Carlson, 1993 ^108^ | RCT | US | Yes | 12 weeks (Planned duration) | Age <30 or >75, Any liver disease, Any kidney disease, No type 2 diabetes, Other
Wolffenbuttel, 1993 ^120^ | RCT | Netherlands | Yes | 12 (4 week titration, 8 week treatment) (Planned duration) | Any liver disease, Any kidney disease, HbA1c <7.0 or >12.0%, No type 2 diabetes, Other
Aguilar, 1992 ^236^ | Cohort | Mexico | No | 4.92 years (Mean follow-up) | No type 2 diabetes, Other
Haupt, 1991 ^211^ | trial without the control arm | Germany | No | NR | Age < 40 -biologic age taken in to account for patients > 65, Any kidney disease, No type 2 diabetes, Other
Teupe, 1991 ^155^ | RCT | Germany | No | 2 years (Planned duration) | Age >70, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Noury, 1991 ^86^ | RCT | France | No | 3 months (Planned duration) | Any liver disease, Any kidney disease, No type 2 diabetes, Other
Hermann, 1991 ^94^ | RCT | Sweden | Yes | 6 months (Planned duration) | Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Hermann, 1991 ^159^ | RCT | Sweden | No | 6 months (Planned duration) | No type 2 diabetes, Other
Jennings, 1989 ^203^ | Cohort | UK | Yes | NR | Age <40 or >65, No type 2 diabetes, Other
Menzies, 1989 ^334^ | Non-randomized trial | Scotland | Yes | 3 months (Planned duration) | Any kidney disease, No type 2 diabetes, Other
Kilo, 1988 ^147^ | RCT | US | No | 3 months (Planned duration) | Treatment experienced, No type 2 diabetes, Other
Rosenstock, 1987 ^207^ | Cohort | US | No | NR | Age <20, >80, Any liver disease, Any kidney disease, History of CVD, No type 2 diabetes, Other
Baba, 1983 ^133^ | RCT | Japan | No | 24 weeks (Planned duration) | No type 2 diabetes, Other
Dandona, 1983 ^215^ | Case-control | UK | No | NR | Other
Tseng, 2005 ^140^ | RCT | Taiwan | No | 12 weeks (Planned duration) | No type 2 diabetes, Other
Inzucchi, 2005 ^184^ | Cohort | US | No | NR | Age <65, No type 2 diabetes, Other
Schofl, 2003 ^226^ | Cohort | Germany | Yes | 16.74 weeks (Mean follow-up) | Age <18, Any liver disease, No type 2 diabetes, Other
Frenchman, 2003 ^200^ | Cohort | US | Yes | | No type 2 diabetes, Other
Turner, 1998 ^93^ , UKPDS | RCT | UK | Yes | 6 years (Planned duration) | Age <25 or >/=65, Any kidney disease, History of CVD, Treatment experienced, Retinopathy, No type 2 diabetes, Other
Garber, 2006 ^71^ | RCT | US | Yes | 24 weeks (Planned duration) | Age <20 or age>78, Any liver disease, Any kidney disease, History of CVD, HbA1c <=7.0% or >=12.0%, No type 2 diabetes, Other
Manley, 2003 ^239^ | Cohort | US | No | NR | No type 2 diabetes, Other
Chan, 2003 ^224^ | Cohort | US | Yes | NR | No type 2 diabetes, Age >18 years, Other
Masoudi, 2005 ^229^ | Cohort | US | No | NR | Age< 65 years, No Type 2 Diabetes, Other
Staa, 1997 ^204^ | Cohort | UK | No | NR | Age<20 years, No Type 2 Diabetes, Other
Shorr, 1996 ^205^ | Cohort | US | No | 4 years (Planned duration) | Age<65 years, No Type 2 Diabetes, Other

RCT = Randomized controlled trial; CVD = cardiovascular disease; HbA1c = Hemoglobin A1c; FPG = fasting plasma glucose; OAM= oral antihypoglycemic medication; OHA =oral hyperglycemic agent; ODM = oral diabetes medication

Table 34 Evidence Table. Study Population Table for Studies Reporting on Adverse Events (Key Question 4)

Author, year | Group, n | Mean age in years (age range) | Male, n (%) | Race, n (%) | Mean BMI in kg/m^2^ (other measure) | Mean weight in kg (other measure) | Mean HbA1c % | Mean duration of diabetes
Study group
Kane, 2004 ^219^ | Pioglitazone, 316 | 62.9 (49.4 – 76.4) | (48.9%) | NR | 34.1 | 97.4 | 7.3 | 12.5
Ballary, 2003 ^227^ | Metformin + rosiglitazone, 189 | NR | NR | NR | NR | NR | NR | NR
Swislocki, 1999 ^210^ | Metformin + unspecified sulfonylurea, 152 | 62.4 | 147 | AA: 33 (20%); C:100 (61%); Asian: 4 (2%); H: 3 (2%); O: 24 (14%) | 31.5 | 99.5 | 9.41 | 8.5
Rosenbaum, 2002 ^153^ | Placebo, 20 | 62 | 8 | NR | 31.7 | 80.2 | 6.3 | NR
| Acarbose, 20 | 59.8 | 6 | NR | 30.3 | 75.1 | 6.4 | NR
Stang, 1999 ^235^ | Metformin, 11797 | NR | NR | NR | NR | NR | NR | NR
Simpson, 2006 ^14^ | Metformin, 769 | 63.2 | 419 (54%) | NR | NR | NR | NR | NR
| Metformin, 768 | 64.6 | 409 (53%) | NR | NR | NR | NR | NR
| Glyburide, 2071 | 66.4 | 1148 (55%) | NR | NR | NR | NR | NR
| Glyburide, 2067 | 67.8 | 1239 (60%) | NR | NR | NR | NR | NR
Nishio, 2006 ^151^ | Control group (no placebo), 28 | 67.5 | 20 (71.4%) | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 24.6 | NR | 6.9 | NR
| Pioglitazone, 26 | 66.2 | 19 (73.1%) | AA:0; C:0; Asian:0; H:0; O: (100%) | 24.6 | NR | 7.7 | NR
Weissman, 2005 ^100^ | Metformin + rosiglitazone, 358 | 55.5 | NR | NR | 34.4 | 98.2 | 8.05 | NR
| Metformin, 351 | 55.7 | NR | NR | 33.8 | 96.7 | 7.97 | NR
Rosenstock, 2006 ^124^ | Glipizide + rosiglitazone, 116 | 68.7 | (74.8%) | NR | 30.2 | NR | 7.72 | 6.8
| Placebo glipizide, 111 | 68.2 | (71.8%) | NR | 30.5 | NR | 7.65 | 6.6
Bailey, 2005 ^101^ | Metformin + rosiglitazone, 288 | 58.1 | 168 (58%) | AA: 2 (1%); C: 280 (97%); Asian: 3 (1%); H: 0; O: 3 (1%) | 32.2 | 90.9 | 7.4 | 6
| Metformin, 280 | 57.6 | 159 (57%) | AA: 1 (<1%); C: 273 (98%); Asian: 3 (1%); H: 0; O: 3 (1%) | 32.1 | 89.5 | 7.5 | 6.1
Kardas, 2005 ^114^ | Glyclazide, 55 | 60.9 | (53%) | NR | 27.1 | 79 | 7.1 | 2.2
| Glibenclamide, 50 | 62.4 | (38%) | NR | 26.3 | 75 | 7.2 | 3.5
Forst, 2005 ^145^ | Glimepiride, 84 | 63 (+/- 7.4) | 52 | NR | 31.8 | NR | 7.44 | 6.9
| Pioglitazone, 89 | 62.2 (+/- 8.4) | 55 | NR | 31.7 | NR | 7.52 | 7.4
Hartung, 2005 ^231^ | Cases (hospitalized for heart failure), 288 | 67 (NR) | 97 (33.7%) | AA: 0; C: 261 (90.6%); Asian: 0; H: 0; O: 27 (9.4%) | NR | NR | NR | NR
| Controls (not hospitalized for heart failure), 1652 | 66.4 (NR) | 544 (32.9%) | AA: 0; C: 1437 (87%); Asian: 0; H: 0; O: 215 (13%) | NR | NR | NR | NR
Bhansali, 2005 ^214^ | Diet + metformin XR, 40 | 57.3 (40–74) | NR | NR | 25.6 | NR | 6.9 | 10.3
Yamanouchi, 2005 ^57^ | Diet + exercise + pioglitazone, 38 | 55.2 (46 – 64.4) | 18 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 25.8 | NR | 10.2 | 3.2 months
| Diet + exercise + metformin, 39 | 54.7 (44.9 – 64.5) | 20 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 26.2 | NR | 9.9 | 3 months
| Diet + exercise + glimepiride, 37 | 55.6 (46.3 – 64.9) | 19 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 25.6 | NR | 9.8 | 3.3 months
Kahara, 2005 ^234^ | Pioglitazone, 49 | 64 | 34 (69.3%) | NR | 24 | 61.4 | 7.3 | NR
| Diet + pioglitazone, 369 | 55.9 | 199 (53.9%) | AA: 9 (2.4%); C: 239 (64.8%); Asian: 10 (2.7%); H: 105 (28.5%); O: 6 (1.6%) | 33.7 | 93.7 | 7.6 | 3.9
| Diet + rosiglitazone, 366 | 56.3 | 201 (54.9%) | AA: 10 (2.7%); C: 219 (59.8%); Asian: 12 (3.3%); H: 118 (32.2%); O: 7 (1.9%) | 32.6 | 92.5 | 7.5 | 4
Pfutzner, 2005 ^68^ | Pioglitazone, 89 | 62.2 | 58 (61.8%) | AA: 0; C: 88 (98.8%); Asian: 0; H: 0; O: 1 (1.1%) | 31.7 | NR | 7.52 | 7.4
| Glimepiride, 84 | 63 | 52 (61.9%) | AA: 0; C: 81 (96.4%); Asian: 0; H: 0; O: 3 (3.7%) | 31.8 | NR | 7.44 | 6.9
Derosa, 2005 ^53^ | Diet + exercise + glimepiride + pioglitazone, 45 | 53 (47 – 59) | 21 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 24.4 | 68.9 | 8.2 | 5
| Diet + exercise glimepiride + rosiglitazone, 42 | 54 (49 – 59) | 22 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | 24.3 | 67.8 | 8 | 6
Derosa, 2005 ^72^ | Diet + exercise + behavioral therapy + metformin + glimepiride, 47 | 52 (47 –57) | 23 | NR | 26.8 | NR | 7.9 | 4
| Diet + exercise + behavioral therapy + metformin + rosiglitazone, 48 | 54 (50 –58) | 25 | NR | 26.6 | NR | 8 | 5
Chalasani, 2005 ^222^ | Rosiglitazone, 210 | 53 (42 – 64) | (43%) | AA: (36%); C: (56%); Asian: 0; H: 0; O: 0 | NR | 232lb | 9.3 | NR
| Rosiglitazone, 628 | 55 (44 – 66) | (32%) | AA: (47%); C: (47%); Asian: 0; H: 0; O: 0 | NR | 229lb | 9.4 | NR
Langenfeld, 2005 ^146^ | Pioglitazone, 89 | 62 | 55 (61.8%) | AA: 0; C: 88 (98.9%); Asian: 0; H: 0; O: (1.1%) | 31.7 | NR | 7.52 | 7.4
| Glimepiride, 84 | 63 | 52 (61.9%) | AA: 0; C: 81 (96.4%); Asian: 0; H: 0; O: (3.6%) | 31.8 | NR | 7.44 | 6.9
Rajagopalan, 2005 ^223^ | Pioglitazone, 1847 | 54.3 (18–91) | (52.4%) | NR | NR | NR | NR | NR
| Rosiglitazone, 1847 | 54.3 (18–92) | (51.8%) | NR | NR | NR | NR | NR
| Pioglitazone, 1474 | 54.6 (18–91) | (54.3%) | NR | NR | NR | NR | NR
| Unspecified sulfonylurea, 1474 | 54.5 (19–94) | (52.9%) | NR | NR | NR | NR | NR
| Pioglitazone, 1137 | 52.7 (18–90) | (50%) | NR | NR | NR | NR | NR
| Metformin, 1137 | 52.5 (19–88) | (49.6%) | NR | NR | NR | NR | NR
Feinglos, 2005 ^104^ | Metformin + glipizide, 61 | 57.7 (30–80) | 28 | AA: 5 (8.2%); C: 48 (78.7%); Asian: 2 (3.3%); H: 5 (8.2%); O: 1 (1.6%) | 31.7 | 90 | 7.45 | 6.5
| Placebo + metformin, 61 | 58.8 (40–81) | 25 | AA: 10 (16.4%); C: 42 (68.9%); Asian: 2 (3.3%); H: 5 (8.2%); O: 2 (3.3%) | 32.1 | 90.8 | 7.64 | 4.6
Evans, 2005 ^325^ | Cases (admitted with malignant cancer), 923 | 73 | 488 (53%) | NR | NR | NR | NR | 8.5
| Controls (no cancer diagnosis), 1846 | NR-age-matched | NR-gender-matched | NR | NR | NR-but matched on year of diagnosis of diabetes | NR | NR
Goke, 2002 ^75^ | Pioglitazone, 129 | 58.9 | 69 (53.5%) | NR | 30.9 | NR | 8.98 | 57.0 months
| Acarbose, 136 | 58.8 | 74 (54.5%) | NR | 30.8 | NR | 9.03 | 59.1 months
Charbonnel, 2005 ^63^ | Pioglitazone, about 635 (NR) | NR | NR | NR | NR | NR | 8.7 | NR
| Glyclazide, about 635 (NR) | NR | NR | NR | NR | NR | 8.7 | NR
Tan, 2005 ^61^ | Pioglitazone, 270 | 57 | 171 (63.3%) | AA: 0; C: 253 (93.7%); Asian: 0; H: 0; O: 17 (6.3%) | 32 | 91.7 | NR | 2.7
| Glyclazide, 297 | 56 | 182 (61.3%) | AA: 0; C: 275 (92.6%); Asian: 0; H: 0; O: 22 (7.4%) | 32 | 89.2 | NR | 2.9
Cryer, 2005 ^176^ | Diet + metformin, 7227 | 58.3 | (49.3%) | AA: (16.2%); C: (78%); Asian: (2.9%); H: 0; O: (2.8%) | NR | 92.5 | NR | 4.9
| Diet+ usual care on existing medications, 1505 | 58.8 | (49.5%) | AA: (17.5%); C: (76.2%); Asian: (2.7%); H: 0; O: (3.6%) | NR | 92.2 | NR | 4.7
McCluskey, 2004 ^76^ | Glimepiride + rosiglitazone, 25 | 60.2 (46 – 76) | 11 (44%) | AA: 0; C: 24 (96%); Asian: 0; H: 0; O: NR | NR | 100.5 | 7.9 | 7.2
| Placebo + rosiglitazone, 15 | 50.8 (35 – 69) | 6 (40%) | AA: 0; C: 12 (80%); Asian: 0; H: 0; O: NR | NR | 99.4 | 8.4 | 4.6
Maru, 2005 ^232^ | No diabetes medications, 21245 | 63 | 11516 (54.2%) | NR | (BMI>=30, n=5702) | NR | NR | NR
| Unspecified sulfonylurea, 11350 | 64 | 5953 (52.5%) | NR | (BMI>=30, n=2422) | NR | NR | NR
| Metformin, 4579 | 59 | 2206 (48.2%) | NR | (BMI>=30, n=2197) | NR | NR | NR
Schernthaner, 2004 ^56^ | Placebo + diet + pioglitazone, 597 | 57 | 314 (52.6%) | 31.2 | NR | 88.2 | 8.7 | 3.4
| Placebo + diet + metformin, 597 | 56 | 345 (57.8%) | 31.4 | NR | 89.7 | 8.7 | 3.1
Smith, 2005 ^161^ | Placebo + Diet + existing oral diabetes medications, 21 | 53.1 | 10 | AA: 0; C: 16; Asian: 0; H: 0; O: 5 | 31.9 | 91.5 | 6.46 | NR
| Diet + pioglitazone + existing medications, 21 | 56.2 | 9 | AA: 0; C: 15; Asian: 0; H: 0; O: 6 | 32.1 | 93.5 | 6.88 | NR
Rajagopalan, 2004 ^327^ | Pioglitazone, 1668 | 51.1 (50.8 – 51.4) | 851 (51%) | NR | NR | NR | NR | NR
Choi, 2004 ^77^ | Rosiglitazone + existing oral diabetes medications, 38 | 60.9 | 24 | NR | 24.9 | 67.6 | 7.79 | 7.5
| Control group (existing oral diabetes medications), 45 | 59.9 | 34 | NR | 24.8 | 68.1 | 7.72 | 7.2
Matthews, 2005 ^70^ | Diet+ metformin + pioglitazone, 317 | 56 | 161 (50.8%%) | AA: 0; C: 315 (99.4%%); Asian: 2 (0.6%); H: 0; O: 0 | 32.6 | NR | 8.71 | 5.8
| Diet + metformin + gliclazide, 313 | 57 | 154 (49.2%%) | AA: 0; C: 313 (100%%); Asian: 0 (0%); H: 0; O: 0 | 32.6 | NR | 8.53 | 5.5
Nichols, 2005 ^230^ | Unspecified sulfonylurea, 1085 | 62 | (55.9%) | NR | NR | NR | 8 | 4
| Metformin, 272 | 60 | (51.1%) | NR | NR | NR | 7.8 | 4.3
| Metformin + unspecified sulfonylurea, 1834 | 61.1 | (52.4%) | NR | NR | NR | 8.3 | 5.8
Derosa, 2004 ^90^ | Placebo + diet + exercise + glimepiride, 81 | 56 | 38 | NR | 27.6 | NR | 8.5 | NR
| Placebo + diet + exercise + metformin, 83 | 58 | 42 | NR | 28.1 | NR | 8.4 | NR
Schernthaner, 2004 ^106^ | Glyclazide MR + existing oral diabetes medications, 405 | 60.5 | (51%) | NR | 30.5 | 83.1 | 8.4 | 5.6
| Glimepiride + existing oral diabetes medications, 440 | 60.6 | (52%) | NR | 30.6 | 83.8 | 8.2 | 5.8
Tan, 2004 ^65^ | Glibenclamide, 109 | 57.9 | 80 (73%) | AA: 0; C: 109 (100%); Asian: 0; H: 0; O: 0 | 29.6 | 89 | 8.5 | 62.6 months
| Pioglitazone, 91 | 60 | 56 (62%) | AA: 0; C: 90 (99%); Asian: 0; H: 0; O: 1 (1%) | 30.2 | 88.4 | 8.4 | 57.1 months
Bell, 1997 ^208^ | Unspecified sulfonylurea, 90 | 64.7 | 46 | NR | NR | NR | NR | 8.9
Baksi, 2004 ^126^ | Glyclazide, 241 | 61.9 | 151 (62.7%) | AA: 1 (0.4%); C: 235 (97.5%); Asian: 1 (0.4%); H: 0; O: 4 (1.7%) | 29.7 | NR | 8.6 | 6.9
| Glyclazide + rosiglitazone, 225 | 61.1 | 129 (57.3%) | AA: 1 (0.4%); C: 219 (97.3%); Asian: 3 (1.3%); H: 0; O: 2 (0.9%) | 30.2 | NR | 8.5 | 6.5
Tan, 2004 ^69^ | Pioglitazone, 121 | 55.1 | 54 (45%) | AA: 0; C: 0 (0%); Asian: 0; H: 121 (100%); O: 0 | 29.3 | 74.2 | 8.54 | 77.8 months
| Glimepiride, 123 | 55.7 | 65 (53%) | AA: 0; C: 1 (1%); Asian: 0; H: 122 (99%); O: 0 | 28.8 | 74.5 | 8.45 | 81.2 months
Saad, 2004 ^164^ | Placebo, 30 | 54 | 18 | NR | 31 | NR | 8.1 | NR
| Pioglitazone, 28 | 55 | 11 | NR | 31 | NR | 8.5 | NR
Rosenstock, 2004 ^131^ | Repaglinide, 76 | 50.9 | 41 | AA: 6; C: 60; Asian: 0; H: 9; O: 1 | 33 | NR | 8.9 | 3.5
| Nateglinide, 74 | 54 | 42 | AA: 3; C: 59; Asian: 1; H: 9; O: 2 | 32.9 | NR | 8.9 | 4.3
Raskin, 2004 ^74^ | Repaglinide, 63 | 58.5 | 39 | AA: 10; C: 40; Asian: 0; H: 1; O: 12 | NR | NR | 7.2 | NR
| Rosiglitazone, 62 | 56.6 | 33 | AA: 8; C: 42; Asian: 0; H: 0; O: 12 | NR | NR | 7.4 | NR
Manzella, 2004 ^148^ | Placebo + diet, 60 | 57 (all patients) | 33 | NR | 29.2 | NR | 8.1 | NR
| Diet + metformin, 60 | 57 (all patients) | 31 | NR | 29.5 | NR | 8 | NR
Feinbock, 2003 ^130^ | Glimepiride, 111 | 57.7 | 66 | AA: 0; C: 110; Asian: 1; H: 0; O: 0 | 29.2 | 85 | 9.1 | 36.3 months
| Acarbose, 108 | 57.1 | 58 | AA: 0; C: 107; Asian: 1; H: 0; O: 0 | 29.1 | 83 | 9.4 | 43.1 months
Kerenyi, 2004 ^125^ | Diet + glibenclamide, 170 | 59.9 | 105 | AA: 2; C: 163; Asian: 4; H: 0; O: 1 | 29.2 | NR | 8.1 | 6.7
| Diet + glibenclamide + rosiglitazone, 165 | 60 | 91 | AA: 1; C: 160; Asian: 3; H: 0; O: 1 | 30.7 | NR | 7.9 | 5.6
Jovanovic, 2004 ^73^ | Repaglinide, 61 | 57.8 | 36 | AA: 7; C: 46; Asian: 0; H: 3; O: 5 | 31.2 | NR | 9 | 6.9
| Pioglitazone, 62 | 56.2 | 31 | AA: 7; C: 51; Asian: 0; H: 2; O: 2 | 32.1 | NR | 9.1 | 6.1
Hanefeld, 2004 ^60^ | Placebo + unspecified sulfonylurea + pioglitazone, 31 | 60 | 171 (53.6%) | AA: 2 (0.6%); C: 317 (99.4%); Asian: 0; H: 0; O: 0 (0%) | 30.2 | 85.3 | 8.82 | 7
| Placebo + metformin + unspecified sulfonylurea, 320 | 60 | 175 (54.7%) | AA: 3 (0.9%); C: 315 (98.4%); Asian: 0; H: 0; O: 2 (0.6%) | 30 | 84.9 | 8.8 | 7.1
Lawrence, 2004 ^54^ | Metformin, 20 | 59.5 | 12 | NR | median 29.2 | NR | 8.04 | NR
| Glyclazide, 20 | 63.5 | 13 | NR | median 28.7 | NR | 7.85 | NR
| Pioglitazone, 20 | 60.4 | 14 | NR | median 30.6 | NR | 7.43 | NR
Delea, 2003 ^228^ | Thiazolidinedione, 5441 | 57.2 | (56.6%) | NR | NR | NR | NR | NR
| No thiazolidinedione, 28103 | 58.8 | (57.2%) (57.2%) | NR | NR | NR | NR | NR
Garber, 2003 ^80^ | Metformin + glyburide, 171 | 55.6 | 76 (44%) | AA: 18 (10.5%); C: 132 (77.2%); Asian: 0; H: 15 (8.8%); O: 6 (3.5%) | 31.4 | 91.9 | 8.8 | 3
| Metformin, 164 | 54.7 | 71 (43.3%) | AA: 11 (6.7%); C: 132 (80.5%); Asian: 0; H: 15 (9.1%); O: 6 (3.7%) | 31.4 | 92.8 | 8.5 | 2.6
| Glyburide, 151 | 55.3 | 66 (43.7%) | AA: 11 (7.3%); C: 123 (81.5%); Asian: 0; H: 12 (7.9%); O: 5 (3.3%) | 31.1 | 91 | 8.7 | 3
Takagi, 2003 ^78^ | pioglitazone + existing oral diabetes medications, 23 | 64 | 20 | NR | 25.6 | NR | 6.8 | NR
| Other (existing oral diabetes medications), 21 | 65 | 14 | NR | 24.5 | NR | 6.7 | NR
Tosi, 2003 ^95^ | Glibenclamide, 20 | NR | NR | NR | NR | NR | NR | NR
| Metformin + glibenclamide, 41 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 19 | NR | NR | NR | NR | NR | NR | NR
Goldstein, 2003 ^82^ | Metformin + glipizide, 87 | 54.6 | (58.6%) | AA: (11.5%); C: (72.4%); Asian: (0%); H: (16.1%); O: 0 | 31.7 | 94 | 8.7 | 5.9
| Glipizide, 84 | 57.4 | (64.3%) | AA: (11.9%); C: (71.4%); Asian: (2.4%); H: (14.3%); O: 0 | 30.6 | 89.9 | 8.9 | 6.5
| Metformin, 76 | 56.6 | (61.8%) | AA: (15.8%); C: (65.8%); Asian: (1.3%); H: (17.1%); O: 0 | 31.6 | 93.8 | 8.7 | 7.3
Herz, 2003 ^163^ | Placebo, 99 | 58 (33–85) | 49 (49.5%) | AA: 0 (0%); C: 96 (97%); Asian: 3 (3%); H: 0 (0%); O: 0 | 31.7 | 86.3 | 7.5 | NR
| Pioglitazone, 99 | 59 (24–79) | 59 (59.6%) | AA: 0 (0%); C: 97 (98%); Asian: 1 (1%); H: 1 (1%); O: 0 | 31.7 | 86.6 | 7.5 | NR
| Pioglitazone, 99 | 58.1 (24–84) | 52 (52.5%) | AA: 0 (0%); C: 93 (93.9%); Asian: 1 (3%); H: 3 (3%); O: 0 | 30.8 | 84.1 | 7.6 | NR
Ko, 2003 ^328^ | Control (existing oral diabetes medications), 69 | 60 | 25 | AA: 0 (0%); C: 0 (0%); Asian: 0 (0%); H: 0 (0%); O: 69 (100%) | 26.1 | NR | 9.6 | 6.3
| Rosiglitazone + existing oral diabetes medications, 49 | 61.6 | 15 | AA: 0 (0%); C: 0 (0%); Asian: 0 (0%); H: 0 (0%); O: 49 (100%) | 25.3 | NR | 9.4 | 9.3
Derosa, 2003 ^97^ | Diet + exercise + repaglinide, 56 | 55 | 29 | NR | 25.2 | 70.2 | 7.6 | 4
| Diet + exercise + metformin, 56 | 52 | 27 | NR | 24.7 | 72.3 | 7.4 | 5
Barnett, 2003 ^172^ | Placebo + unspecified sulfonylurea, 87 | 54.1 (32–78) | (75%) | AA: 0 (0%); C: 0 (0%); Asian: 0 (0%); H: 0 (0%); O: (100%) | 26.4 | NR | 9.06 | 6.5
| Unspecified sulfonylurea + rosiglitazone, 84 | 54.3 (28–76) | (80%) | AA: 0 (0%); C: 0 (0%); Asian: 0 (0%); H: 0 (0%); O: (100%) | 26.8 | NR | 9.21 | 6.5
Fujioka, 2003 ^105^ | Placebo + diet + metformin XR, 75 | 54 | 34 | NR | 32 | 92 | 7 | 3
| Placebo + diet + metformin XR, 71 | 55 | 28 | NR | 31 | 88 | 7 | 3
| Placebo + diet + metformin, 71 | 54 | 31 | NR | 33 | 96 | 7.1 | 3
Derosa, 2003 ^118^ | Placebo + repaglinide, 62 | 56 | 31 | NR | 26.1 | 76.4 | 8 | NR
| Placebo + glimepiride, 62 | 54 | 30 | NR | 26.4 | 77.1 | 7.8 | NR
Zhu, 2003 ^188^ | Placebo + unspecified sulfonylurea, 105 | 58.8 | (46%) | AA: 0; C: 0; Asian: (100%); H: 0; O: 0 | 25.1 | NR | 9.8 | 7.6
| Unspecified sulfonylurea + rosiglitazone, 215 | 59 | (41%) | AA: 0; C: 0; Asian: (100%); H: 0; O: 0 | 24.8 | NR | 9.8 | 7.2
| Unspecified sulfonylurea + rosiglitazone, 210 | 58.9 | (48%) | AA: 0; C: 0; Asian: (100%); H: 0; O: 0 | 24.9 | NR | 9.9 | 7.9
Del Prato, 2003 ^149^ | Placebo, 144 | 56 | 91 | NR | 29.9 | NR | NR | NR
| Placebo + metformin, 284 | 56 | 68 | NR | 29.7 | NR | NR | NR
Pavo, 2003 ^59^ | Placebo + pioglitazone, 105 | 54.2 | (43.8%) | NR | 31.3 | 86.6 | 8.6 | 0.47
| Placebo + metformin, 100 | 55.8 | (56%) | NR | 31.1 | 88.9 | 8.6 | 0.53
Chandrasekharan, 2002 ^212^ | Nateglinide, 105 | 48.44 | 70 | NR | NR | NR | 8.51 | 4.74
Leese, 2003 ^201^ | Unspecified sulfonylurea, 2823 | 65.4 | (52.2%) | NR | 29.6 | NR | 7.16 | 6.3
Luis Bautista, 2003 ^193^ | Diet + exercise + glimepiride, 48 | 48.4 | 27 (56.3%) | AA: 0; C: 0; Asian: 0; H: (100%); O: 0 | NR | 83.3 | 10 | 4.2
| Placebo + diet + exercise, 22 | 50.7 | 11 (50%) | AA: 0; C: 0; Asian: 0; H: (100%); O: 0 | NR | 76.3 | 10.5 | 5.7
Jun, 2003 ^233^ | Pioglitazone, 54 | 54.6 (27–68) | 9 (16.7%) | AA: 0; C: 0; Asian: 0; H: 54 (100%); O: 0 | 32 | NR | 10.4 | 10.3
Vongthavaravat, 2002 ^170^ | Diet + unspecified sulfonylurea + rosiglitazone, 164 | 54.6 (30–76) | 75 (45.7%) | AA: 6 (3.7%); C: 66 (40.2%); Asian: 91 (55.5%); H: 0; O: 1 (0.6%) | 27.1 | 69 | 9.1 | 5
| Diet + unspecified sulfonylurea, 170 | 57.3 (37–77) | 72 (42.4%) | AA: 4 (2.4%); C: 62 (36.5%); Asian: 101 (59.4%); H: 0; O: 3 (1.8%) | 27.1 | 68.8 | 8.9 | 6
Virtanen, 2003 ^143^ | Placebo + diet, 14 | 58 | 10 | NR | 30.3 | 88.3 | 6.3 | NR
| Diet + rosiglitazone, 14 | 58 | 10 | NR | 29.1 | 83.7 | 6.8 | NR
| Diet + metformin, 13 | 58 | 8 | NR | 29.9 | 88.8 | 6.9 | NR
Vakkilainen, 2002 ^122^ | Placebo + nateglinide, 23 | 63 | NR | AA: 0; C: (100%); Asian: 0; H: 0; O: 0 | 27.8 | NR | 7.6 | NR
| Placebo + glibenclamide, 20 | 63 | NR | AA: 0; C: (100%); Asian: 0; H: 0; O: 0 | 28.8 | NR | 7.6 | NR
Cefalu, 2002 ^323^ | Metformin + glypizide XL, 46 | 53.5 | 30 | NR | 32.5 | 94 | 10.4 | 7.7
| Metformin + glypizide XL, 45 | 55.8 | 25 | NR | 32.1 | 95 | 10 | 6.3
Hallsten, 2002 ^58^ | Placebo + diet, 14 | 57.7 | 10 | NR | 30.3 | NR | 6.3 | NR
| Diet + metformin, 13 | 57.8 | 8 | NR | 29.9 | NR | 6.9 | NR
| Diet + rosiglitazone, 14 | 58.6 | 10 | NR | 29.3 | NR | 6.8 | NR
Scherbaum, 2002 ^141^ | Placebo + diet, 84 | 59.1 | 47 | NR | 29.2 | 84.8 | 8.75 | 5.6
| Diet + pioglitazone, 89 | 58 | 56 | NR | 29.9 | 87.2 | 9.33 | 5.4
| Diet + pioglitazone, 78 | 59.6 | 32 | NR | 29.3 | 82 | 9.06 | 4.6
Blonde, 2002 ^81^ | Glyburide, 164 | 55.8 | 94 (57.3%) | AA: 20 (12.2%); C: 109 (66.5%); Asian: 0; H: 28 (17.1%); O: 7 (4.3%) | 30.3 | 88 | 9.64 | 7.01
| Metformin, 153 | 57.6 | 95 (62.1%) | AA: 16 (10.5%); C: 105 (69.3%); Asian: 0; H: 26 (17%); O: 5 (3.3%) | 30.6 | 89.5 | 9.51 | 8.18
| Metformin + glyburide, 160 | 55.4 | 89 (55.6%) | AA: 20 (12.5%); C: 112 (70%); Asian: 0; H: 25 (15.6%); O: 3 (1.9%) | 30.7 | 89.4 | 9.41 | 7.36
| Metformin + glyburide, 162 | 55.6 | 103 (63.6%) | AA: 15 (9.3%); C: 110 (67.9%); Asian: 0; H: 31 (19.1%); O: 6 (3.7%) | 30.6 | 89.6 | 9.42 | 6.97
St John Sutto, 2002 ^67^ | Glyburide, 99 | 56.1 (40–76) | (71%) | AA: (3%); C: (76%); Asian: 0; H: 0; O: (21%) | 65.7% >=27 | 9.5 | 6.2 | NR
| Rosiglitazone, 104 | 55.1 (40–77) | (75%) | AA: (5%); C: (73%); Asian: 0; H: 0; O: (22%) | 67.3% >=27 | 9.1 | 5.3 | NR
Rachmani, 2002 ^150^ | Diet + metformin stopped, 198 | 64 | 102 | NR | 28.4 | NR | 8.6 | 14
| Diet + metformin continued, 195 | 65 | 103 | NR | 28.7 | NR | 8.6 | 15
Saloranta, 2002 ^241^ | nateglinide, 166 | 61 | 105 (63.3%) | AA: 2 (1.2%); C: 162 (97.6%); Asian: 1 (0.6%); H: 0; O: 1 (0.6%) | 28.95 | NR | 6.55 | 3.8
| nateglinide, 175 | 61.1 | 107 (61.1%) | AA: 1 (0.6%); C: 163 (93.1%); Asian: 3 (4.6%); H: 0; O: 8 (4.6%) | 28.92 | NR | 6.53 | 3.6
| nateglinide, 171 | 59.6 | 112 (65.5%) | AA: 2 (1.2%); C: 163 (95.3%); Asian: 4 (1.2%); H: 0; O: 2 (1.2%) | 29.12 | NR | 6.57 | 3.7
| Placebo, 163 | 59.1 | 98 (60.1%) | AA: 2 (1.2%); C: 157 (96.3%); Asian: 1 (1.8%); H: 0; O: 3 (1.8%) | 28.78 | NR | 6.45 | 3.2
Kubo, 2002 ^225^ | Pioglitazone, 18 | 63.4 | 4 | AA: 0; C: 0; Asian: (100%); H: 0; O: 0 | 27.8 | NR | 8.6 | NR
| Glyclazide, 18 | 61.2 | 5 | NR | 26.7 | NR | 8.2 | NR
| Glyclazide + pioglitazone, 19 | 64.1 | 5 | NR | 26.7 | NR | 8.6 | NR
Marre, 2002 ^84^ | Metformin, 104 | 57.5 | 62 | NR | 29.9 | 84.9 | 8.09 | 5.4
| Glibenclamide, 103 | 58.7 | 57 | NR | 29.3 | 82.5 | 7.88 | 6.6
| Metformin + glibenclamide, 101 | 58 | 50 | NR | 30.1 | 84.7 | 7.89 | 5.9
| Metformin + glibenclamide, 103 | 60.7 | 56 | NR | 29.7 | 83.1 | 7.62 | 6.7
Garber, 2002 ^79^ | Placebo, 161 | 55.4 | 76 | AA: 16; C: 122; Asian: 0; H: 17; O: 6 | 30.2 | 86.2 | 8.21 | 2.76
| Glyburide, 161 | 56.5 | 82 | AA: 15; C: 126; Asian: 0; H: 14; O: 6 | 30.3 | 87.2 | 8.21 | 2.81
| Metformin, 161 | 56 | 93 | AA: 7; C: 130; Asian: 0; H: 20; O: 4 | 30.4 | 88.6 | 8.26 | 2.98
| Metformin + glyburide, 158 | 56.9 | 91 | AA: 20; C: 117; Asian: 0; H: 18; O: 3 | 30.1 | 88.8 | 8.25 | 3.52
| Metformin + glyburide, 165 | 58.1 | 96 | AA: 10; C: 131; Asian: 0; H: 16; O: 8 | 29.6 | 86.7 | 8.18 | 3.3
Gomez-Perez, 2002 ^102^ | Placebo + metformin, 34 | 53.4 (40–68) | 10 | AA: 0; C: 1; Asian: 0; H: 26; O: 7 | 28.5 | NR | NR | 9.1
| Metformin + rosiglitazone, 35 | 51.7 (40–73) | 10 | AA: 0; C: 0; Asian: 0; H: 28; O: 7 | 28 | NR | NR | 11.1
| Metformin + rosiglitazone, 36 | 54.2 (42–76) | 7 | AA: 0; C: 4; Asian: 0; H: 26; O: 6 | 27.6 | NR | NR | 10.7
Deerochanawong, 2001 ^331^ | Glimepiride, 89 | 52.2 | 29 | NR | 25.5 | NR | 10 | NR
Holstein, 2001 ^202^ | Glimepiride + glibenclamide, 1 | 84 | (100%) | NR | 24.8 | NR | 5.6 | 4
| Glibenclamide, 38 | 83.5 | (36.8%) | NR | 22.9 | NR | 5.25 | 6
| Glimepiride, 6 | 83.5 | (33.3%) | NR | 28.2 | NR | 4.7 | 16
Charpentier, 2001 ^206^ | Glimepiride, 980 | 57.9 | 576 (59%) | NR | 30 | NR | 8.9 | 3.7
Charpentier, 2001 ^89^ | Placebo + metformin, 75 | 56.7 (36–69) | 45 (60%) | NR | 29.2 | 82.2 | 6.8 | 7
| Placebo + glimepiride, 150 | 55.4 (35–70) | 87 (58%) | NR | 29.3 | 81 | 6.5 | 5.3
| Metformin + glimepiride, 147 | 56.8 (36–70) | 87 (59%) | NR | 29.5 | 81.2 | 6.4 | 5.6
Rosenblatt, 2001 ^162^ | Placebo, 96 | 55.2 | (46.2%) | AA: (11.5%); C: (61.5%); Asian: 0; H: (24%); O: (3.1%) | 30.7 | 87.2 | 10.42 | NR
| Pioglitazone, 101 | 53.8 | (50.5%) | AA: (8.9%); C: (69.3%); Asian: 0; H: (19.8%); O: (2%) | 31.5 | 89.8 | 10.65 | NR
Emslie-Smith, 2001 ^332^ | Metformin, 1847 | 63.4 | (47.6%) | NR | NR | NR | NR | NR
Madsbad, 2001 ^119^ | Repaglinide, 175 | 60.2 | 107 | NR | 28 | 82.9 | 7.3 | 8.1
| Placebo + glipizide, 81 | 62 | 52 | NR | 28 | 83.6 | 7.2 | 7
Kipnes, 2001 ^166^ | Placebo + unspecified sulfonylurea, 187 | 56.9 | 109 | AA: 25; C: 141; Asian: 3; H: 18; O: 0 | 32 | NR | 9.9 | 19
| Unspecified sulfonylurea + pioglitazone, 184 | 56.5 | 109 | AA: 20; C: 146; Asian: 3; H: 15; O: 0 | 31.4 | NR | 10 | 29
| Unspecified sulfonylurea + pioglitazone, 189 | 56.6 | 113 | AA: 17; C: 156; Asian: 3; H: 13; O: 0 | 32.4 | NR | 9.9 | 26
Gegick, 2001 ^192^ | Pioglitazone, 67 | 66 (57 – 75) | NR | NR | 98.3 | 7.1 | 14 | NR
| Rosiglitazone, 77 | 59 (48.6 – 69.4) | NR | NR | 103 | 6.97 | 12 | NR
Mertes, 2001 ^213^ | Acarbose, 1954 | 63 | (46%) | NR | 27.4 | 78.3 | 8.4 | 5.2
Amador-Licona, 2000 ^85^ | Glibenclamide, 23 | 48.2 | 7 | NR | 30.4 | 73.2 | 8.4 | 4
| Metformin, 28 | 49.3 | 11 | NR | 26.8 | 70.7 | 8.5 | 4.5
Lebovitz, 2001 ^169^ | Placebo, 158 | 59 | 104 | NR | 29.9 | NR | 9.0 | 4.6
| Rosiglitazone, 166 | 60 | 107 | NR | 30.2 | NR | 9.0 | 4.8
| Rosiglitazone, 169 | 61 | 113 | NR | 29.1 | NR | 8.8 | 5.4
Patel, 1999 ^167^ | Placebo, 75 | 56.8 (34–83) | 52 (69.3%) | AA: 2; C: 55; Asian: 0; H: 0; O: 18 | 28.9 | NR | 9.1 | 4.2
| Rosiglitazone, 74 | 56.7 (30–76) | 49 (66.2%) | AA: 4; C: 55; Asian: 0; H: 0; O: 15 | 29.4 | NR | 9.1 | 4.9
| Rosiglitazone, 72 | 55.8 (31–74) | 51 (70.8%) | AA: 6; C: 53; Asian: 0; H: 0; O: 13 | 28.6 | NR | 8.9 | 6.7
| Rosiglitazone, 79 | 59.8 (37–79) | 51 (64.6%) | AA: 4; C: 63; Asian: 0; H: 0; O: 12 | 29.5 | NR | 9 | 4.4
| Rosiglitazone, 80 | 59.7 (41–81) | 55 (68.8%) | AA: 5; C: 58; Asian: 0; H: 0; O: 17 | 28.4 | NR | 9 | 5.8
Phillips, 2001 ^168^ | Placebo, 173 | 57.7 | 119 (68.8%) | AA: 16 (9.2%); C: 137 (79.2%); Asian: 0; H: 0; O: 20 (11.6%) | 29.1 | NR | 8.9 | 6.6
| Rosiglitazone, 181 | 57.5 | 106 (58.6%) | AA: 23 (12.7%); C: 138 (76.2%); Asian: 0; H: 0; O: 20 (11%) | 29.9 | NR | 8.9 | 5.4
| Rosiglitazone, 186 | 56.8 | 110 (59.1%) | AA: 15 (8.1%); C: 145 (78%); Asian: 0; H: 0; O: 26 (14%) | 30 | NR | 8.9 | 5.5
| Rosiglitazone, 181 | 58.9 | 119 (65.7%) | AA: 13 (7.2%); C: 145 (80.1%); Asian: 0; H: 0; O: 23 (12.7%) | 30 | NR | 8.9 | 6.1
| Rosiglitazone, 187 | 56.5 | 122 (65.2%) | AA: 20 (10.7%); C: 133 (71.1%); Asian: 0; H: 0; O: 34 (18.2%) | 29.9 | NR | 9 | 5.9
Moses, 2001 ^218^ | Repaglinide, 260 | 57.5 | (53.5%) | AA: (0.4%); C: (98.8%); Asian: (0%); H: 0; O: (0.8%) | 30 | 84 | 7.8 | 2.99
| Placebo, 134 | 57.4 | (57.5%) | AA: (0%); C: (98.5%); Asian: (0%); H: 0; O: (1.5%) | 30.9 | 86.6 | 7.6 | 3.07
Einhorn, 2000 ^160^ | Diet + metformin + pioglitazone, 168 | 55.5 | 92 (54.8%) | AA: 14 (8.3%); C: 136 (81%); Asian: 0; H: 17 (10.1%); O: 1 (0.6%) | 32.11 | NR | 9.86 | NR
| Placebo + diet + metformin, 160 | 55.7 | 96 (60%) | AA: 10 (6.3%); C: 139 (86.9%); Asian: 0; H: 6 (3.8%); O: 5 (3.1%) | 32.12 | NR | 9.75 | NR
Fonseca, 2000 ^103^ | Placebo + metformin, 113 | 58.8 | 74.3 | AA: (3.5%); C: (81.4%); Asian: 0; H: 0; O: (15%) | 30.3 | NR | 8.6 | 7.3
| Metformin + rosiglitazone, 116 | 57.5 | 62.1 | AA: (6.9%); C: (80.2%); Asian: 0; H: 0; O: (12.9%) | 30.2 | NR | 8.9 | 7.5
| Metformin + rosiglitazone, 110 | 58.3 | 68.2 | AA: (10%); C: (77.3%); Asian: 0; H: 0; O: (12.7%) | 29.8 | NR | 8.9 | 8.3
Abbasi, 2000 ^265^ | Metformin, 110 | 60.69 (27–85) | 57 | NR | NR | NR | NR | NR
Bytzer, 2001 ^216^ | Metformin, 211 | 61.9 (51.1 – 62.7) | (54.3%) | NR | NR | NR | NR | NR
| Unspecified sulfonylurea, 206 | 63 (50.7 – 75.3) | (52.9%) | NR | NR | NR | NR | NR
Horton, 2000 ^96^ | Nateglinide, 179 | 58.6 | 110 | AA: (9.5%); C: (82.1%); Asian: (2.8%); H: 0; O: (5.6%) | 29.6 | NR | 8.3 | 4.7
| Metformin, 178 | 56.8 | 121 | AA: (9.6%); C: (79.2%); Asian: (2.2%); H: 0; O: (9%) | 29.6 | NR | 8.4 | 7.5
| Placebo, 172 | 59.6 | 104 | AA: (16.9%); C: (78.5%); Asian: (0.6%); H: 0; O: (4.1%) | 29.2 | NR | 8.3 | 4.6
Aronoff, 2000 ^165^ | Placebo, 79 | 53.7 mean (29–75) - for all groups combined | (58%) -for all groups combined | AA: (8%); C: (78%); Asian: (2%); H: (12%); O: (1%) - for all groups combined | NR | 90.4 | 10.4 | NR
| Pioglitazone, 81 | 53.7 mean (29–75) - for all groups combined | (58%) -for all groups combined | AA: (8%); C: (78%); Asian: (2%); H: (12%); O: (1%) - for all groups combined | NR | 93.5 | 10 | NR
| Pioglitazone, 81 | 53.7 mean (29–75) - for all groups combined | (58%) -for all groups combined | AA: (8%); C: (78%); Asian: (2%); H: (12%); O: (1%) - for all groups combined | NR | 91.2 | 10.2 | NR
| Pioglitazone, 87 | 53.7 mean (29–75) - for all groups combined | (58%) -for all groups combined | AA: (8%); C: (78%); Asian: (2%); H: (12%); O: (1%) - for all groups combined | NR | 90.3 | 10.2 | NR
| Pioglitazone, 80 | 53.7 mean (29–75) - for all groups combined | (58%) -for all groups combined | AA: (8%); C: (78%); Asian: (2%); H: (12%); O: (1%) - for all groups combined | NR | 90.8 | 10.3 | NR
Hanefeld, 2000 ^190^ | Placebo, 60 | 57.4 | 36 | NR | 28.3 | NR | 8.5 | 5.4
| Nateglinide, 51 | 58 | 36 | NR | 29 | NR | 8.4 | 4.5
| Nateglinide, 58 | 56.1 | 41 | NR | 28.1 | NR | 8.3 | 6.2
| Nateglinide, 63 | 54.4 | 44 | NR | 28.6 | NR | 8.3 | 4.4
| Nateglinide, 57 | 56.5 | 36 | NR | 28.8 | NR | 8.5 | 3.7
King, 2000 ^142^ | Rosiglitazone, 36 | 59.2 | (50%) | NR | NR | 92.1 | 8.73 | NR
| Pioglitazone, 30 | 60.2 | (38%) | NR | NR | 87.2 | 8.72 | NR
Hasche, 1999 ^138^ | Diet + acarbose, 36 | 63.8 | 17 | NR | 26.1 | 74.3 | 8.5 | 1
| Placebo + diet, 38 | 63.1 | 19 | NR | 26.7 | 75.5 | 8.3 | 1
Wolffenbuttel, 2000 ^171^ | Placebo + unspecified sulfonylurea, 192 | 61.9 | 110 | AA: 2; C: 186; Asian: 0; H: 0; O: 4 | 28.1 | NR | 9.21 | 8
| Unspecified sulfonylurea + rosiglitazone, 199 | 61 | 125 | AA: 2; C: 190; Asian: 0; H: 0; O: 7 | 28.0 | NR | 9.2 | 7
| Unspecified sulfonylurea + rosiglitazone, 183 | 60.6 | 101 | AA: 2; C: 180; Asian: 0; H: 0; O: 1 | 28.3 | NR | 9.23 | 7
Gregorio, 1999 ^129^ | Glibenclamide or glyclazide, 85 | 75.73 | 40 | NR | NR | 76.61 | 10.32 | 14.67
| Metformin + (glibenclamide or glyclazide), 89 | 75.42 | 42 | NR | NR | 76.44 | 10.33 | 15.11
Klamann, 2000 ^183^ | Glibenclamide, 76 | 72 | 37 | NR | 26.8 | 73 | 8.4 | 10
| Non-glibenclamide, 89 | 73 | 54 | NR | 26.8 | 71 | 7.7 | 8
Jovanovic, 2000 ^194^ | Placebo, 75 | 58.5 | 49 (65%) | AA: 11 (15%); C: 51 (68%); Asian: 1 (1%); H: 0; O: 12 (16%) | 29.8 | NR | 8.6 | 6.8
| Repaglinide, 140 | 57.9 | 96 (69%) | AA: 14 (10%); C: 107 (76%); Asian: 0 (0%); H: 0; O: 19 (14%) | 29.4 | NR | 8.9 | 6.6
| Repaglinide, 146 | 57.6 | 87 (60%) | AA: 18 (12%); C: 110 (75%); Asian: 2 (1%); H: 0; O: 16 (11%) | 29.5 | NR | 8.7 | 6.3
Willms, 1999 ^99^ | Acarbose, 31 | 60.3 | 15 | NR | NR | 86.1 | 10.6 | 134.8 months
| Placebo, 29 | 59.2 | 17 | NR | NR | 90.2 | 10.6 | 119.6 months
| Metformin, 27 | 53.4 | 13 | NR | NR | 88.6 | 10.6 | 111.9 months
Lysy, 1999 ^220^ | Metformin, 706 | 62.6 (male)/63.4 (female) | 365 | NR | NR | NR | NR | 9.4 (male)/9.2 (female)
Erle, 1999 ^127^ | Glyburide, 20 | 60 for both groups combined | 21 (for both groups combined) | NR | 30.5 (for both groups combined) | 85.2 | 7.37 | NR
| Metformin + glyburide, 20 | 60 for both groups combined | 21 (for both groups combined) | NR | 30.5 (for both groups combined) | 85.5 | 7.67 | NR
Landgraf, 1999 ^121^ | Repaglinide, 94 | 61 | 56 | AA: 0; C: 90; Asian: 0; H: 0; O: 4 | 27.6 | 80 | 7.8 | 10
| Placebo + glibenclamide, 100 | 63 | 57 | AA: 6; C: 93; Asian: 0; H: 0; O: 1 | 27.5 | 79 | 8 | 10
Marbury, 1999 ^116^ | Repaglinide, 362 | 58.3 | 242 (67%) | AA: 33 (9%); C: 279 (77%); Asian: 0; H: 0; O: 50 (14%) | 29.4 | NR | 8.7 | 7.2
| Placebo + glyburide, 182 | 58.7 | 120 (66%) | AA: 16 (9%); C: 144 (79%); Asian: 0; H: 0; O: 22 (12%) | 29.1 | NR | 8.9 | 8.3
Selby, 1999 ^237^ | Started on metformin, 9875 | NR | (47.5%) | NR | (71% >= BMI of 27) | NR | NR | NR
| Not started on metformin, 54382 | NR | (53.6%) | NR | (60% >= BMI of 27) | NR | NR | NR
Wolffenbuttel, 1999 ^117^ | Repaglinide, 286 | 61 | (62%) | NR | 28.4 | 81.5 | 7.1 | median 6
| Placebo + glyburide, 139 | 61 | (68%) | NR | 28 | 81.3 | 7 | median 6
Testa, 1998 ^198^ | Placebo + diet, 192 | 58.4 (30–82) | (58.9%) | AA: (15.6%); C: (72.9%); Asian: 0; H: 0; O: (11.5%) | 30.3 | NR | 8.7 | 4.7
| Diet + glypizide XL, 377 | 58.7 (30–85) | (54.9%) | AA: (16.7%); C: (71.9%); Asian: 0; H: 0; O: (11.4%) | 30.1 | NR | 8.5 | 5.6
Goldberg, 1998 ^139^ | Placebo, 33 | 56.4 | 25 (76%) | AA: 0; C: 29 (88%); Asian: 0; H: 0; O: 4 (12%) | 30 | NR | 8.1 | 5.1
| Repaglinide, 67 | 58.7 | 49 (74%) | AA: 0; C: 58 (88%); Asian: 0; H: 0; O: 8 (12%) | 30.6 | NR | 8.3 | 5.6
UKPDS, 1998 ^15^ | Diet, 411 | 53 | 193 (47%) | AA: 0; C: (86%); Asian: (6%); H: 0; O: (8%) | 31.8 | 87 | 7.1 | NR
| Diet + metformin, 342 | 53 | 157 (46%) | AA: 0; C: (85%); Asian: (4%); H: 0; O: (11%) | 31.6 | 87 | 7.3 | NR
| Diet + glibenclamide, 277 | 53 | 127 (46%) | AA: 0; C: (87%); Asian: (4%); H: 0; O: (9%) | 31.5 | 86 | 7.2 | NR
| Diet + unspecified sulfonylurea, 269 | 58 | 164 (61%) | AA: 0; C: (77%); Asian: (13%); H: 0; O: (10%) | 29.4 | 82 | 7.6 | NR
| Diet + metformin + unspecified sulfonylurea, 268 | 59 | 158 (59%) | AA: 0; C: (77%); Asian: (11%); H: 0; O: (12%) | 29.7 | 83 | 7.5 | NR
UKPDS, 1998 ^16^ | Diet, 896 | 54 | 555 | AA: 0; C: (83%); Asian: 0; H: 0; O: (16%) | 27.5 | 77 | 6.2 | NR
| Diet+ unspecified sulfonylurea, 619 | 54 | 359 | AA: 0; C: (79%); Asian: 0; H: 0; O: (21%) | 27 | 75 | 6.3 | NR
| Diet + glibenclamide, 615 | 54 | 381 | AA: 0; C: (84%); Asian: 0; H: 0; O: (15%) | 27.4 | 77 | 6.3 | NR
Schade, 1998 ^135^ | Glimepiride, 123 | 52 | NR | NR | NR | 86.8 | 9.1 | 3.1
| Placebo, 126 | 54 | NR | NR | NR | 87.3 | 8.9 | 3.1
UKPDS, 1998 ^128^ | Diet + metformin + glibenclamide, 291 | 59 | (59%) | AA: (14%); C: (78%); Asian: (8%); H: 0; O: 0 | 29.2 | 81 | Median 7.4 | NR
| Diet + glibenclamide, 300 | 58 | (60%) | AA: (11%); C: (78%); Asian: (11%); H: 0; O: 0 | 29.1 | 81 | Median 7.3 | NR
Lee, 1998 ^259^ | Placebo + diet + metformin, 24 | 59 (56 – 62) | 0 | NR | 40 | 112.8 | 8.3 | 4
| Placebo + diet, 24 | 61 (59 – 63) | 0 | NR | 39.6 | 108.6 | 8.1 | 3
Cathelineau, 1997 ^209^ | Diet + glyclazide, 5572 | 58.5 | 3225 | NR | 28.5 | NR | 8.7 | 1.2
Garber, 1997 ^217^ | Placebo, 79 | 55 | (56%) | AA: (22%); C: (66%); Asian: 0; H: (11%); O: (1%) | NR | 90.9 | 9.9 | NR
| Metformin, 73 | 57 | (62%) | AA: (11%); C: (62%); Asian: 0; H: (14%); O: (1%) | NR | 90 | 10.1 | NR
| Metformin, 73 | 55 | (55%) | AA: (12%); C: (55%); Asian: 0; H: (10%); O: (1%) | NR | 90 | 10 | NR
| Metformin, 76 | 59 | (63%) | AA: (12%); C: (63%); Asian: 0; H: (15%); O: (2%) | NR | 89.6 | 9.7 | NR
| Metformin, 73 | 60 | (53%) | AA: (14%); C: (53%); Asian: 0; H: (12%); O: (4%) | NR | 89.1 | 10.1 | NR
| Metformin, 77 | 59 | (65%) | AA: (10%); C: (65%); Asian: 0; H: (10%); O: (0%) | NR | 94.5 | 10 | NR
Sonnenberg, 1997 ^191^ | Glimepiride, 50 | 61 | (70%) | NR | NR | 86 | NR | 7.2
| Glimepiride, 48 | 61 | (70%) | NR | NR | 86 | NR | 7.2
| Placebo, 53 | 61 | (70%) | NR | NR | 86 | NR | 7.2
Simonson, 1997 ^136^ | Glipizide, 68 | 57.4 (33–81) | 40 | AA: 10; C: 50; Asian: 0; H: 0; O: 8 | 29 | 185lb | 8.5 | 6.9
| Glipizide, 42 | 58.7 (34–78) | 25 | AA: 4; C: 32; Asian: 0; H: 0; O: 6 | 28.4 | 181lb | 8.8 | 8.8
| Glipizide, 42 | 55.5 (130–271) | 26 | AA: 4; C: 30; Asian: 0; H: 0; O: 8 | 29.5 | 187.3lb | 8.6 | 6.5
| Glipizide, 69 | 59.3 (128–312) | 47 | AA: 7; C: 54; Asian: 0; H: 0; O: 8 | 28.8 | 186.7lb | 8.7 | 7.8
| Glipizide, 28 | 61.7 (144–267) | 17 | AA: 1; C: 25; Asian: 0; H: 0; O: 2 | 29.6 | 196.2lb | 8.4 | 6.6
| Glipizide, 29 | 56.9 (142–270) | 23 | AA: 1; C: 24; Asian: 0; H: 0; O: 4 | 30.5 | 201.1lb | 8.6 | 5.3
| Placebo, 69 | 60.2 (125–280) | 53 | AA: 8; C: 50; Asian: 0; H: 0; O: 11 | 29.78 | 191.7lb | 8.3 | 7.5
Rosenstock, 1996 ^189^ | Placebo, 79 | 61.1 | (67%) | NR | NR | 85.9 | 8 | median 6
| Glimepiride, 88 | 61.8 | (74%) | NR | NR | 82.9 | 8.1 | median 7
| Glimepiride, 81 | 58.8 | (70%) | NR | NR | 86.3 | 8.1 | median 6
| Glimepiride, 83 | 59.6 | (66%) | NR | NR | 84.2 | 8 | median 5
| Glimepiride, 85 | 61.7 | (72%) | NR | NR | 86.8 | 8.3 | median 7
Dills, 1996 ^107^ | Glimepiride, 289 | 59 | (61%) | AA: 0; C: (86%); Asian: 0; H: 0; O: (14%) | NR | 192lb | 8.5 | 5
| Glyburide, 288 | 60 | (58%) | AA: 0; C: (87%); Asian: 0; H: 0; O: (13%) | NR | 192lb | 8.5 | 5
Draeger, 1996 ^112^ | Glibenclamide, 520 | 60.7 (26–81) | 340 | AA: 0; C: 0; Asian: (74%); H: 0; O: (26%) - both groups combined | 26.5 | NR | 8.1 | 5
| Glimepiride, 524 | 59.7 (27–81) | 325 | AA: 0; C: 0; Asian: (74%); H: 0; O: (26%) - both groups combined | 26.5 | NR | 8.1 | 5
Goldberg, 1996 ^134^ | Placebo, 74 | 60.4 | 48 | AA: 0; C: 60; Asian: 0; H: 0; O: 14 | NR | 85 | 7.8 | 6
| Glimepiride, 78 | 58.9 | 56 | AA: 0; C: 65; Asian: 0; H: 0; O: 13 | NR | 83.9 | 7.8 | 7
| Glimepiride, 76 | 57.8 | 41 | AA: 0; C: 60; Asian: 0; H: 0; O: 16 | NR | 86.1 | 7.7 | 5
| Glimepiride, 76 | 59.6 | 43 | AA: 0; C: 64; Asian: 0; H: 0; O: 12 | NR | 85.3 | 7.8 | 6
Gregorio, 1996 ^221^ | Metformin + unspecified sulfonylurea, 76 | 76.44 (70–88) | 31 | NR | BMI<25: 24; BMI>25: 52 | NR | 10.38 | 15.08
Grant, 1996 ^154^ | Placebo, 23 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 25 | NR | NR | NR | NR | NR | NR | NR
| Metformin, 27 | NR | NR | NR | NR | NR | NR | NR
Vray, 1995 ^137^ | Placebo, 56 | 56.8 | (36%) | NR | F 23.7; M 23.8 | NR | 10 | 3.9
| Glibenclamide, 56 | 55.8 | (36%) | NR | F 24.5; M 23.7 | NR | 9.6 | 2.4
| Placebo, 50 | 56 | (50%) | NR | F 23.8; M 25.0 | NR | 9.6 | 2.5
| Glibenclamide, 54 | 53.3 | (65%) | NR | F 23.7; M 24.1 | NR | 9.3 | 2.2
DeFronzo, 1995 ^88^ | Metformin, 143 | 53 | 62 | NR | 29.9 | 94.4 | 8.4 | 6
| Placebo, 53 | 53 | 62 | NR | 29.2 | 92.2 | 8.2 | 6
| Placebo + metformin, 210 | 55 | 96 | NR | 29.4 | 92.6 | 8.9 | 8.4
| Placebo + glyburide, 209 | 56 | 103 | NR | 29.1 | 92.6 | 8.5 | 8.7
| metformin + glyburide, 213 | 55 | 98 | NR | 29 | 92.1 | 8.8 | 7.8
UKPDS, 1995 ^92^ | Diet, 664 | NR | NR | NR | NR | NR | NR | NR
| Diet + glibenclamide, 472 | NR | NR | NR | NR | NR | NR | NR
| Diet + metformin, 262 | NR | NR | NR | NR | NR | NR | NR
Hermann, 1994 ^87^ | Diet + metformin, 25 | NR | NR | NR | NR | 78.6 | 6.9 | NR
| Diet + glibenclamide, 21 | NR | NR | NR | NR | 82.6 | 6.7 | NR
| Diet + metformin + glibenclamide, 54 | NR | NR | NR | NR | 80.2 | 6.8 | NR
| Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR | 84.6 | 7.8 | NR
| Diet + metformin + glibenclamide, 13 | NR | NR | NR | NR | 76 | 7.8 | NR
| Diet + metformin + glibenclamide, 18 | NR | NR | NR | NR | 83.2 | 8.4 | NR
Birkeland, 1994 ^110^ | Diet + glipizide, 15 | 59 (for all groups combined) | 22 (for all groups combined) | NR | 26.4 (for all groups combined) | NR | 8 | 3.5 (for all groups combined)
| Diet + glyburide, 15 | 59 (for all groups combined) | 22 (for all groups combined) | NR | 26.4 (for all groups combined) | NR | 8 | 3.5 (for all groups combined)
| Placebo + diet, 16 | 59 (for all groups combined) | 22 (for all groups combined) | NR | 26.4 (for all groups combined) | NR | 8.1 | 3.5 (for all groups combined)
Rosenstock, 1993 ^109^ | Glyburide, 70 | 71.4 | 39 | AA: 0; C: 65; Asian: 0; H: 2; O: 3 | NR | 79.6 | 5.7 | 11
| Glyclazide, 69 | 70.2 | 48 | AA: 0; C: 64; Asian: 0; H: 2; O: 3 | NR | 80.5 | 5.8 | 11
Carlson, 1993 ^108^ | Glyburide, 104 | 59.2 (33–80) | 61 | AA: 11; C: 81; Asian: 0; H: 7; O: 5 | NR | NR | 7.6 | N=15/32/57 for <1/1–5/>5 yrs
| Glyburide, 102 | 60.3 (38–78) | 62 | AA: 13; C: 81; Asian: 0; H: 4; O: 4 | NR | NR | 7.6 | N=6/42/54 for <1/1–5/>5 yrs
Wolffenbuttel, 1993 ^120^ | Repaglinide, 29 | 62 (45–75) | 25 | NR | 26.1 | 74 | range 7.0–12.0 | 9
| Glibenclamide, 15 | 62 (45–75) | 25 | NR | 26.1 | 70.9 | range 7.0–12.0 | 9
Aguilar, 1992 ^236^ | Metformin + unspecified sulfonylurea, 157 | 48 | NR | NR | NR | NR | NR | 9.5
Haupt, 1991 ^211^ | Diet + metformin + unspecified sulfonylurea, 1823 | 59.8 (men) / 62.6 (women) | 705 | NR | NR | 78.9 | 11 | 7.7
Teupe, 1991 ^155^ | Diet, 50 | 56 | 20 | NR | NR | 86.1 | 9.6 | 6.4
| Diet + metformin, 50 | 51.5 | 20 | NR | NR | 89.1 | 10 | 8.1
Noury, 1991 ^86^ | Metformin, 30 | 55 | 16 | NR | 29.1 | 80.4 | 9.75 | 3
| Glyclazide, 27 | 54.9 | 12 | NR | 28 | 79 | 9.72 | 3
Hermann, 1991 ^94^ | Diet + metformin, 16 | 60 (38–73) (for all groups combined) | (64%) - for all groups combined | NR | 27 | 76.5 | 6.7 | NR
| Diet + glibenclamide, 17 | 60 (38–73) (for all groups combined) | (64%) - for all groups combined | NR | 29.2 | 84.1 | 6.6 | NR
| Diet + metformin + glibenclamide, 12 | 60 (38–73) (for all groups combined) | (64%) - for all groups combined | NR | 30 | 87.3 | 7.7 | NR
| Diet + metformin + glibenclamide, 11 | 60 (38–73) (for all groups combined) | (64%) - for all groups combined | NR | 26.1 | 74.4 | 7.8 | NR
Schneider, 1991 ^173^ | Placebo, 16 | 61.5 | 9 | NR | 27.1 | NR | 6.48 | NR
| Metformin, 18 | 60.4 | 8 | NR | 26.1 | NR | 6.76 | NR
Hermann, 1991 ^159^ | Diet + metformin + glibenclamide, 72 | 60 (34–74) - all groups combined | 79 | NR | 28.4 - all groups combined | 82.3 - all groups combined | NR | NR
| Diet + metformin, 38 | 60 (34–74) - all groups combined | NR | NR | 28.4 - all groups combined | 82.3 - all groups combined | NR | NR
| Diet + glibenclamide, 34 | 60 (34–74) - all groups combined | NR | NR | 28.4 - all groups combined | 82.3 - all groups combined | NR | NR
| Diet, 14 | 60 (34–74) - all groups combined | NR | NR | 28.4 - all groups combined | 82.3 - all groups combined | NR | NR
Dornan, 1991 ^260^ | Metformin, 30 | 55 | (53%) | NR | 30 | NR | 11.7 | NR
| Placebo, 30 | 55 | (30%) | NR | 30 | NR | 11.8 | NR
Jennings, 1989 ^203^ | Glyburide, 74 | NR | NR | NR | NR | NR | NR | NR
| Glyclazide, 80 | NR | NR | NR | NR | NR | NR | NR
Menzies, 1989 ^334^ | Metformin, 39 | 63.7 (both groups combined) | 26 (both groups combined) | NR | 78.3 (both groups combined) | NR | 10.28 | 8.4 (both groups combined)
| Metformin, 25 | 63.7 (both groups combined) | 26 (both groups combined) | NR | 78.3 (both groups combined) | NR | 10.83 | 8.4 (both groups combined)
Kilo, 1988 ^147^ | Glyburide, 47 | 66 (both groups combined) | NR | NR | NR | NR | NR | NR
| Glipizide, 52 | 66(both groups combined) | NR | NR | NR | NR | NR | NR
Rosenstock, 1987 ^207^ | Glipizide, 79 | 61.4 | 45 (57%) | AA: 27 (34%); C: 40 (51%); Asian: 0; H: 10 (13%); O: 2 (3%) | NR | 181.9lb | 10 | NR
Baba, 1983 ^133^ | Glyclazide, 146 | (<39 – >70) | 78 (53.42%) | NR | Obesity Index: <119%: 71.9%; >120%: 28.1% | NR | NR | N=35/25/39/47 for <1/1–4/5–9/>=10 yrs
| Glibenclamide, 131 | (<39 – >70) | 55 (41.98%) | NR | Obesity Index: <119%: 71%; >120%: 29% | NR | NR | N=30/35/31/35 for <1/1–4/5–9/>=10 yrs
Dandona, 1983 ^215^ | Metformin, 54 | NR | NR | NR | NR | NR | NR | NR
| Metformin + unspecified sulfonylurea, 45 | NR | NR | NR | NR | NR | NR | NR
| Unspecified sulfonylurea, 53 | NR | NR | NR | NR | NR | NR | NR
| Diet, 35 | NR | NR | NR | NR | NR | NR | NR
Tseng, 2005 ^140^ | Unspecified sulfonylurea + pioglitazone, 23 | 58 | 8 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | NR | 61.3 | NR
| Placebo + unspecified sulfonylurea, 25 | 54 | 9 | AA: 0; C: 0; Asian: 0; H: 0; O: (100%) | NR | 62.6 | NR | NR
Inzucchi, 2005 ^184^ | Non-insulin sensitizer, 6641 | 76.8 | 3108 (46.8%) | AA: 0; C: 5811 (87.5%); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Metformin, 1273 | 75.2 | 659 (51.8%) | AA: 0; C: 1164 (91.4%); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Unspecified TZD, 819 | 75.8 | 385 (47%) | AA: 0; C: 731 (89.3%); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
| Metformin + unspecified thiazolidinedione, 139 | 73.6 | 74 (53.2%) | AA: 0; C: 123 (88.5%); Asian: 0; H: 0; O: 0 | NR | NR | NR | NR
Schofl, 2003 ^226^ | Pioglitazone, 8760 | 61 (18 – 99) | 4600 (52.8%) | 29.4 | NR | 85.4 | 8.43 | NR
Frenchman, 2003 ^200^ | Unspecified sulfonylurea, 121 | women 80.2, men 73.7 (all groups combined) | 61 | NR | NR | Overall N=121 with greater than ideal body weight | NR | NR
| Metformin, 48 | women 80.2, men 73.7 (all groups combined) | 61 | NR | NR | Overall N=121 with greater than ideal body weight | NR | NR
| Rosiglitazone, 13 | women 80.2, men 73.7 (all groups combined) | 61 | NR | NR | Overall N=121 with greater than ideal body weight | NR | NR
| Pioglitazone, 11 | women 80.2, men 73.7 (all groups combined) | 61 | NR | NR | Overall N=121 with greater than ideal body weight | NR | NR
Turner, 1998 ^93^ | Non-obese patients in the primary diet failure group, 287 | 50 | (69%) | AA: (9%); C: (83%); Asian: (8%); H: 0; O: 0 | 22.5 | NR | 10.9 | NR
| Obese patients in the primary diet failure group, 171 | 50 | (26%) | AA: (8%); C: (89%); Asian: (3%); H: 0; O: 0 | 31.8 | NR | 10.4 | NR
| Non-obese patients in the main randomization group, 789 | 53 | (71%) | AA: (10%); C: (76%); Asian: (14%); H: 0; O: 0 | 23.8 | NR | 7 | NR
| Obese patients in the main randomization group, 831 | 52 | (42%) | AA: (9%); C: (86%); Asian: (5%); H: 0; O: 0 | 31.2 | NR | 7.1 | NR
Chalmers, 1992 ^336^ | Metformin + unspecified sulfonylurea, 70 | 63 (25–84) | 26 | NR | 30 | NR | 10.36 | 8.2
Profozic, 1987 ^337^ | Glyclazide, 467 | 56 (28–81) | 208 (44.54%) | NR | NR | 81.7 | NR | 4.7
Garber, 2006 ^71^ | Diet + metformin + glibenclamide, 160 | 56 (31–78) | 90 | AA: 8 (5%); C: 128 (80%); Asian: 4 (3%); H: 17 (11%); O: 3 (2%) | 32 | 93 | 8.5 | 5
| Diet + metformin + rosiglitazone, 158 | 56 (24–78) | 102 | AA: 9 (6%); C: 125 (79%); Asian: 4 (3%); H: 16 (10%); O: 4 (3%) | 32 | 94 | 8.4 | 6
Manley, 2003 ^239^ | Rosiglitazone, 15 | 63.79 | 26 | NR | NR | NR | 8.59 | NR
| Pioglitazone, 25 | 64.63 | NR | NR | NR | NR | NR | NR
Chan, 2003 ^224^ | Entire cohort, 171,143 (not broken down by med type) | 57.9 | (53.5%) | NR | NR | NR | NR | NR
Masoudi, 2005 ^229^ | Metformin, 1861 | 75.8 | (43%) | C: (87%); O: (13%) | NR | NR | NR | NR
| Thiazolidinedione, 2226 | 75.9 | (39%) | C: (88%); O: (12%) | NR | NR | NR | NR
| No Insulin sensitizer, 12069 | 77 | (42%) | C: (84%); O: (16%) | NR | NR | NR | NR
Staa, 1997 ^204^ | Glibenclamide, 18740 | 67.4 | (49.8%) | NR | NR | NR | NR | NR
| Glyclazide, 7418 | 68 | (49.4%) | NR | NR | NR | NR | NR
| Glipizide, 2012 | 68.2 | (49.5%) | NR | NR | NR | NR | NR
Shorr, 1996 ^205^ | Glyburide or glipizide, 8576 person-years | 78 | (16%) | C: (47%); O: (53%) | NR | NR | NR | NR

AA = African American; C = Caucasian; H = Hispanic; O = Other; BMI = Body-Mass Index; Wt = weight; n or N = number; NR=not reported; kg=kilograms; m2=meters squared; %=percent; HbA1c=hemoglobin A1c;BMI= body mass index.

Table 35 Evidence Table. Comparative effectiveness of oral diabetes medications on adverse events

Author, year | Study design | Comp GP 1, N | Comp GP 2, N | GP 1, initial dose in mg (fixed or esc) max dose | GP 2, initial dose in mg (fixed or esc) max dose | Hypoglycemia | Congestive heart failure/Edema | GI problems | Withdrawn due to unspecified adverse event | Other
Study group | | | | | | Specific outcome | Specific outcome | Specific outcome | | Specific outcome
| | | | | | N (%) | N (%) | N (%) | N (%) | N (%)
Thiazolidinedione vs Thiazolidinedione
Derosa, 2005 ^53^ | RCT | Rosiglitazone + glimepiride + diet + exercise, 42 | Pioglitazone + glimepiride + diet + exercise, 45 | 4 mg (fixed) | 15 mg (fixed) | | | Transient flatulence | | ALT>1.5 times ULN + AST>1.5 times ULN
| | | | 4 (2 bid) mg (fixed) | 4 (2 bid) mg (fixed) | | | 2 (4.8) total for GP1 | | 2 (4.8) total for GP1
| | | | | | | | 1 (2.2) total for GP2 | | 1 (2.2) total for GP2
Frenchman, 2003 ^200^ | Cohort | Rosiglitazone (none received second medication), 13 | Pioglitazone + Second medication was added in 66.7% of patients: 2 SU, 2 metformin, 2 insulin), 11 | NR (NR) | NR (NR) | Low FPG (unspecified) | Edema | Nausea + vomiting + diarrhea | | Total adverse events
| | | | | | 2 (15.4) total for GP1 | 0 (0) total for GP1 | 0 (0) withdrawn for GP1 | | 2 (15.4) total for GP1
| | | | | | 1 (9.1) total for GP2 | 1 (9.1) total for GP2 | 0 (0) total for GP1 | | 8 (72.7) total for GP2
| | | | | | | | 0 (0) withdrawn for GP2 | | Decreased dose due to unspecified adverse event
| | | | | | | | 4 (36.4) total for GP2 | | 0 (0) total for GP1
| | | | | | | | | | 1 (9.1) total for GP2
Manley, 2003 ^239^ | Cohort | Rosiglitazone, 15 | Pioglitazone, 25 | NR (NR) | NR (NR) | | | | | Anemia
| | | | | | | | | | 34.89% baseline Hct level for GP1
| | | | | | | | | | 34.00% final Hct level for GP2 (p=0.024)
King, 2000 ^142^ | Non-randomized trial | Rosiglitazone, 36 | Pioglitazone, 30 | 8 mg (fixed) | 45 mg (fixed) | | Edema not reported | | Other side effects + abdominal pain, rash, dizziness, felt bad, noncardiac chest pain. | Elevated aminotransferase levels/2 times the upper limit of normal
| | | | | | | 3 (7.9) total for GP1 | | 4 (11.1) total for GP1 | 1 (2.6) total for GP1
| | | | | | | 2 (6.7) total for GP2 | | 1(3.3) total for GP2 | 0 (0) total for GP2
Gegick, 2001 ^192^ | Cohort | Rosiglitazone, 86 | Pioglitazone, 77 | 4 or 8 mg (fixed) | 15 – 45 mg (fixed) | | Edema not reported | | Perceived medication intolerance with non-specific symptoms
| | | | | | | 3 (3.5) withdrawn for GP1 | | 3 (3.5) withdrawn for GP1
| | | | | | | 3 (3.5) total for GP1 | | 3 (3.5) total for GP1
| | | | | | | 4 (5.2) withdrawn for GP2 | | 3 (3.9) withdrawn for GP2
| | | | | | | 4 (5.2) total for GP2 | | 3 (3.9) total for GP2
Rajagopalan, 2005 ^223^ | Cohort | Pioglitazone, 1847 | Rosiglitazone, 1847 | NR (NR) | NR (NR) | | | | | Liver failure/2-year IR of liver failure or hepatitis (principal or secondary diagnosis)
| | | | | | | | | | 0.5 for GP1
| | | | | | | | | | 0.4 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure or hepatitis (prinicipal diagnosis)
| | | | | | | | | | 0.3 for GP1
| | | | | | | | | | 0.4 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure only (principal or secondary diagnosis)
| | | | | | | | | | 0.0 for GP1
| | | | | | | | | | 0.1 for GP2
Thiazolidinedione vs Metformin
Hallsten, 2002 ^58^ | RCT | Rosiglitazone + diet, 14 | Metformin + diet, 13 | 4 mg (2 mg for 2 weeks twice daily, thereafter 4 mg twice daily) 8 mg | 1000 mg (500 mg for 2 weeks twice daily, thereafter 1000 mg twice daily) 2000 mg | | | | Withdrawn due to unspecified adverse event
| | | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | | 2 (15.4) withdrawn for GP2
Yamanouchi, 2005 ^57^ | RCT | Pioglitazone + diet + exercise, 38 | Metformin + diet + exercise, 39 | 30 for women and 45 for men mg (fixed) | 750 mg (fixed) | Not reported | Edema | | | ALT>1.5 times ULN + AST>1.5 times ULN
| | | | | | 0 (0) serious for GP1 | 2 (5.3) withdrawn for GP1 | | | 0 (0) total for GP1
| | | | | | 0 (0) total for GP1 | 4 (10.5) total for GP1 | | | 0 (0) total for GP2
| | | | | | 0 (0) serious for GP2 | 0 (0) total for GP2
| | | | | | 0 (0) total for GP2
Lawrence, 2004 ^54^ | RCT | Pioglitazone, 21 | Metformin, 21 | 30 mg (esc) 45 mg od | 500 mg (esc) 1 g tid | | Ankle edema
| | | | | | | 1 (4.8) withdrawn for GP1
| | | | | | | 0 (0) withdrawn for GP2
Pavo, 2003 ^59^ | RCT | Pioglitazone + placebo, 105 | Metformin + placebo, 100 | 30 mg (esc) 45 mg | 850 mg (esc) 2550 mg | | Lower limb edema | Diarrhea | Withdrawn due to unspecified adverse events | AST
| | | | | | | 13 (12.4) total for GP1 | 4 (3) total for GP1 | 2 (1.9) withdrawn for GP1 | -2.2 mean change for GP1
| | | | | | | 4 (4.0) total for GP2 | 16 (16) total for GP2 | 0 (0) withdrawn for GP2 | 0.7 mean change for GP2
| | | | | | | | | | ALT
| | | | | | | | | | -6.8 mean change for GP1
| | | | | | | | | | 1.2 mean change for GP2
Schernthaner, 2004 ^56^ | RCT | Pioglitazone + placebo + diet, 597 | Metformin + placebo + diet, 597 | 30 mg (esc) 45 | 850 mg (esc) 2550 | | Peripheral edema | Diarrhea | | ALT> 3 times ULN + AST> 3 times ULN
| | | | | | | 5 (0.8) withdrawn for GP1 | 3 (0.5) withdrawn for GP1 | | 0 (0) withdrawn for GP1
| | | | | | | 27 (4.5) total for GP1 | 19 (3.2) total for GP1 | | 2 (0.3) serious for GP1
| | | | | | | 2 (0.3) withdrawn for GP2 | 9 (1.5) withdrawn for GP2 | | 2 (0.3) withdrawn for GP2
| | | | | | | 10 (1.7) total for GP2 | 66 (11.1) total for GP2 | | 1 (0.2) serious for GP2
| | | | | | | Edema nos | Nausea | | Hypertension nos
| | | | | | | 13 (2.2) total for GP1 | 14 (2.3) total for GP1 | | 15 (2.5) total for GP1
| | | | | | | 1 (0.2) total for GP2 | 25 (4.2) total for GP2 | | 17 (2.8) total for GP2
Hanefeld, 2004 ^60^ | RCT | Pioglitazone + unspecified sulfonylurea + placebo, 319 | Metformin + unspecified sulfonylurea + placebo, 320 | 15 mg (12 week titration, 40 week maintenance) 45 mg | 850 mg (12 week titration, 40 week maintenance) 2550 mg | Not reported | Edema not reported | Included diarrhea | Unspecified adverse events | Elevated aminotransferase levels
QUARTET study group | | | | NR (fixed) | NR (fixed) | 0 (0) serious for GP1 | 22 (6.9) total for GP1 | 9 (2.8) withdrawn for GP1 | 20 (6.3) withdrawn for GP1 | Nsg
| | | | | | 0 (0) serious for GP2 | 5 (1.6) total for GP2 | 39 (12.2) total for GP1 | 19 (5.9) withdrawn for GP2 | Anemia
| | | | | | | | 7 (2.2) withdrawn for GP2 | | Nsg
| | | | | | | | 75 (23.4) total for GP2
Frenchman, 2003 ^200^ | Cohort | Rosiglitazone (none received second med), 13 | Metformin + second med was added in 47.6% of patients: 9 sulfonylureas, and 1 insulin), 48 | NR (NR) | NR (NR) | Low fpg (unspecified) | Edema | Nausea + vomiting + diarrhea | Total adverse events
| | | | | | 2 (15.4) total for GP1 | 0 (0) total for GP1 | 0 (0) withdrawn for GP1 | 2 (15.4) total for GP1
| | | | | | 2 (4.2) total for GP2 | 2 (4.2) total for GP2 | 0 (0) total for GP1 | 21 (43.8) total for GP2
| | | | | | | | 1 (2.1) withdrawn for GP2 | Decreased dose due to unspecified adverse event
| | | | | | | | 5 (10.4) total for GP2 | 0 (0) total for GP1
| | | | | | | | | 6 (12.5) total for GP2
Frenchman, 2003 ^200^ | Cohort | Pioglitazone + second med was added in 66.7% of patients: 2 SU, 2 metformin, 2 insulin), 11 | Metformin + second med was added in 47.6% of patients: 9 sulfonylureas, and 1 insulin), 48 | NR (NR) | NR (NR) | Low FPG (unspecified) | Edema | Nausea + vomiting + diarrhea | Total adverse events
| | | | | | 1 (9.1) total for GP1 | 1 (9.1) total for GP1 | 0 (0) withdrawn for GP1 | 8 (72.7) total for GP1
| | | | | | 2 (4.2) total for GP2 | 2 (4.2) total for GP2 | 4 (36.4) total for GP1 | 21 (43.8) total for GP2
| | | | | | | | 1 (2.1) withdrawn for GP2 | Decreased dose due to unspecified adverse event
| | | | | | | | 5 (10.4) total for GP2 | 1 (9.1) total for GP1
| | | | | | | | | 6 (12.5) total for GP2
Rajagopalan, 2005 ^223^ | Cohort | Pioglitazone, 1137 | Metformin, 1137 | NR (NR) | NR (NR) | | | | | Liver failure/2-year IR of liver failure or hepatitis (principal or secondary diagnosis)
| | | | | | | | | | 0.4 for GP1
| | | | | | | | | | 0.8 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure or hepatitis (prinicipal diagnosis)
| | | | | | | | | | 0.2 for GP1
| | | | | | | | | | 0.5 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure only (principal or secondary diagnosis)
| | | | | | | | | | 0.0 for GP1
| | | | | | | | | | 0.1 for GP2
Inzucchi, 2005 ^184^ | Cohort | Unspecified TZD, 819 | Metformin, 1273 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 402 (49.1) total for GP1
| | | | | | | 435 (34.2) total for GP2
Inzucchi, 2005 ^184^ | Cohort | Unspecified TZD, 819 | Metformin + TZD, 139 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 402 (49.1) total for GP1
| | | | | | | 54 (38.8) total for GP2
Thiazolidinedione vs. Sulfonylurea
Yamanouchi, 2005 ^57^ | RCT | Pioglitazone + diet + exercise, 38 | Glimepiride + diet + exercise, 37 | 30 for women and 45 for men mg (fixed) | 1.0 mg (esc) 2.0 after 1 month in 8 cases. Rest on 1 mg | Not reported | Edema | | | ALT>1.5 times ULN + AST>1.5 times ULN
| | | | | | 0 (0) serious for GP1 | 2 (5.3) withdrawn for GP1 | | | 0 (0) total for GP1
| | | | | | 0 (0) total for GP1 | 4 (10.5) total for GP1 | | | 0 (0) total for GP2
| | | | | | 0 (0) serious for GP2 | 0 (0) total for GP2
| | | | | | 1 (2.7) total for GP2
St John Sutto, 2002 ^67^ | RCT | Rosiglitazone, 104 | Glyburide (no trade drug specified), 99 | 4 mg (fixed) | NR (titrated 1st 8 weeks then fixed) 20 mg/day | Signs and symptoms | Chf not reported | | Withdrawn due to unspecified adverse event | Anemia
| | | | | | 0 (0) withdrawn for GP1 | 1 (1.0) total for GP1 | | 8 (7.7) withdrawn for GP1 | 7 (7) total for GP1
| | | | | | 0 (0) serious for GP1 | 0 (0) total for GP2 | | 4 (4.0) withdrawn for GP2 | 2 (2) total for GP2
| | | | | | 0 (0) withdrawn for GP2 | Edema not reported | | | Elevated aminotransferase levels
| | | | | | 3 (3.0) serious for GP2 | 6 (6) total for GP1 | | | 0 (0) total for GP1
| | | | | | 7 (7.1) total for GP2 | 1 (1) total for GP2 | | | 0 (0) total for GP2
Charbonnel, 2005 ^63^ | RCT | Pioglitazone, 635 | Gliclazide, 635 | (forced titration to maximum tolerated dose during first 16 weeks) 45mg | (forced titration to maximum tolerated dose during first 16 weeks) 320mg | Not reported | Edema not reported | Diarrhea | | Elevated aminotransferase levels
| | | | | | 0 (0) serious for GP1 | 54 (8.7) total for GP1 | 18 (2.9) total for GP1 | | 3 (0.5) total for GP1
| | | | | | 22 (3.5) total for GP1 | 28 (4.5) total for GP2 | 21 (3.4) total for GP2 | | 10 (1.6) total for GP2
| | | | | | 1 (0.2) serious for GP2 | | nausea
| | | | | | 63 (10.1) total for GP2 | | 27 (4.3) total for GP1
| | | | | | | | 32 (5.1) total for GP2
Lawrence, 2004 ^54^ | RCT | Pioglitazone, 21 | Gliclazide, 22 | 30 mg (esc) 45 mg od | 80 mg (esc) 160 mg bid | | Ankle edema
| | | | | | | 1 (4.8) withdrawn for GP1
| | | | | | | 0 (0) withdrawn for GP2
Tan, 2005 ^61^ | RCT | Pioglitazone, 270 | Gliclazide, 297 | 15 mg (esc) 45 | 80 mg (esc) 320 | | | | Withdrew due to unspecified event
one year extension study for Quartet study group | | | | | | | | | 33 (12.2) withdrawn for GP1
| | | | | | | | | 33 (12.2) total for GP1
| | | | | | | | | 25 (8.4) withdrawn for GP2
| | | | | | | | | 25 (8.4) total for GP2
Tan, 2004 ^65^ | RCT | Pioglitazone, 91 | Glibenclamide, 109 | 30 mg (esc) 45mg | 1.75 mg (esc) 10.5mg | Symptoms or self monitored bg < 50mg/dl | Pedal | | Unknown
| | | | | | 4 (4) total for GP1 | 24 (26) total for GP1 | | 6 (6.6) withdrawn for GP1
| | | | | | 32 (29) total for GP2 | 9 (8) total for GP2 | | 10 (9.2) withdrawn for GP2
Forst, 2005 ^145^ | RCT | Pioglitazone + other medication, except metformin & glimepiride), 89 | Glimepiride + other medication, except g-cell stimulatory drugs & ppar-p agonists, 84 | 45 mg (fixed) | 1–6 mg (to attain bood glucose level less than 6.7mmol/l) 6mg | Unknown | Worsening of preexisting heart failure | | Withdrawn due to drug related side effects
| | | | | | 21 (23.6) total for GP1 | 2 (2.2) total for GP1 | | 1 (1.1) withdrawn for GP1
| | | | | | 26 (31.0) total for GP2 | 0 (0) total for GP2 | | 0 (0) withdrawn for GP2
| | | | | | | Edema
| | | | | | | 21 (23.6) total for GP1
| | | | | | | 2 (2.4) total for GP2
Frenchman, 2003 ^200^ | Cohort | Rosiglitazone (none received second med), 13 | Unspecified sulfonylurea + second med added in 17.7% of patients: 9 metformin, 2 insulin, 2 rosiglitazone, and 1 pioglitazone), 121 | NR (NR) | NR (NR) | Low fpg (unspecified) | Edema | Nausea + vomiting + diarrhea | Total adverse events
| | | | | | 2 (15.4) total for GP1 | 0 (0) total for GP1 | 0 (0) withdrawn for GP1 | 2 (15.4) total for GP1
| | | | | | 18 (14.9) total for GP2 | 3 (2.5) total for GP2 | 0 (0) total for GP1 | 29 (24) total for GP2
| | | | | | | | 0 (0) withdrawn for GP2 | Decreased dose due to unspecified adverse event
| | | | | | | | 3 (2.5) total for GP2 | 0 (0) total for GP1
| | | | | | | | | 6 (5) total for GP2
Frenchman, 2003 ^200^ | Cohort | Pioglitazone + second med was added in 66.7% of patients: 2 SU, 2 metformin, 2 insulin), 11 | Unspecified sulfonylurea + second med added in 17.7% of patients: 9 metformin, 2 insulin, 2 rosiglitazone, and 1 pioglitazone), 121 | NR (NR) | NR (NR) | Low FPG (unspecified) | Edema | Nausea + vomiting + diarrhea | Total adverse events
| | | | | | 1 (9.1) total for GP1 | 1 (9.1) total for GP1 | 0 (0) withdrawn for GP1 | 8 (72.7) total for GP1
| | | | | | 18 (14.9) total for GP2 | 3 (2.5) total for GP2 | 4 (36.4) total for GP1 | 29 (24) total for GP2
| | | | | | | | 0 (0) withdrawn for GP2 | Decreased dose due to unspecified adverse event
| | | | | | | | 3 (2.5) total for GP2 | 1 (9.1) total for GP1
| | | | | | | | | 6 (5) total for GP2
Rajagopalan, 2005 ^223^ | Cohort | Pioglitazone, 1474 | Unspecified sulfonylurea, 1474 | NR (NR) | NR (NR) | | | | | Liver failure/2-year IR of liver failure or hepatitis (principal or secondary diagnosis)
| | | | | | | | | | 0.6 for GP1
| | | | | | | | | | 1.0 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure or hepatitis (prinicipal diagnosis)
| | | | | | | | | | 0.3 for GP1
| | | | | | | | | | 0.7 for GP2
| | | | | | | | | | Liver failure/2-year IR of liver failure only (principal or secondary diagnosis)
| | | | | | | | | | 0.0 for GP1
| | | | | | | | | | 0.1 for GP2
Kubo, 2002 ^225^ | Non-randomized trial | Pioglitazone, 18 | Gliclazide, 18 | 30 mg (fixed) | 40 mg (fixed) | | Edema not reported | | | Elevated aminotransferase levels
| | | | | | | 3 (16.7) total for GP1 | | | 0 (0) serious for GP1
| | | | | | | | | | 0 (0) total for GP1
Thiazolidinedione + Metformin vs. Sulfonyluea + Metformin
Garber, 2006 ^71^ | RCT | Rosiglitazone + metformin + diet, 155 | Glibenclamide + metformin + diet, 159 | 4 mg (esc) 8 | 5 mg (esc) 10 | Symptoms and fbs <50 mg/dl | | Diarrhea | Withdrawn due to unspecified event
| | | | 1500 or 2000 depending on dose of metformin prior to study mg (esc) 2000 | 1000 mg (esc) 2000 | 0 (0) withdrawn for GP1 | | 5 (3) total for GP1 | 2 (1.3) withdrawn for GP1
| | | | | | 2 (1) total for GP1 | | 10 (6) total for GP2 | 9 (5.6) withdrawn for GP2
| | | | | | 7 (4.4) withdrawn for GP2 | | Abdominal pain
| | | | | | 60 (38) total for GP2 | | 2 (1.3) withdrawn for GP1
| | | | | | | | 6 (4) total for GP1
| | | | | | | | 9 (5.7) withdrawn for GP2
| | | | | | | | 10 (6) total for GP2
| | | | | | | | Diarrhea + abdominal pain + other gi symptoms
| | | | | | | | 16 (10) total for GP1
| | | | | | | | 18 (11) total for GP2
Derosa, 2005 ^72^ | RCT | Rosiglitazone + metformin + diet + exercise + behavioral therapy, 48 | Glimepiride + metformin + diet + exercise + behavioral therapy, 47 | 4 mg (fixed) | 2 mg (fixed) | | | Transient flatulence | | ALT>1.5 ULN + AST>1.5 ULN
| | | | 1500 mg (fixed) | 1500 mg (fixed) | | | 2 (4.2) total for GP1 | | 3 (6.3) total for GP1
| | | | | | | | 1 (2.1) total for GP2 | | 0 (0) total for GP2
Thiazolidinedione vs Meglitinide
Raskin, 2004 ^74^ | RCT | Rosiglitazone, 62 | Repaglinide, 63 | 2 mg bid (12 week dose titration then 12 week maintenance) 4 mg bid | 0.5 mg per meal if hba1c<=8 or 1 mg if >8 (12 week dose titration, 12 week maintenance) 4 mg per meal | Fsg<2.8 mmol/l | Peripheral | | Withdrew due to unspecified adverse event | ALT> 3 times normal + AST> 3 times normal
| | | | | | 0 (0) serious for GP1 | 2 (3) total for GP1 | | 6 (9.7) withdrawn for GP1 | 0 (0) serious for GP1
| | | | | | 1 (2) total for GP1 | 0 (0) total for GP1 | | 4 (6.3) withdrawn for GP2 | 1 (1.6) serious for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 4 (6) total for GP2
Jovanovic, 2004 ^73^ | RCT | Pioglitazone, 62 | Repaglinide, 61 | 30 mg (fixed) | 0.5 mg if hba1c<8 or 1 mg if hba1c>8 (titrated up for 12 weeks, then fixed for 12 weeks) 4 mg per meal | Symptoms only or symptoms with bg level not < 50mg/dl | Peripheral | Diarrhea | Withdrew due to unspecified adverse event | Anemia/mean changes in levels of hemoglobin
| | | | | | 4 (7) total for GP1 | 1 (2) total for GP1 | 2 (3) total for GP1 | 1 (1.6) withdrawn for GP1 | ALT> 3 times nl + AST> 3 times normal
| | | | | | 8 (13) total for GP2 | 0 (0) total for GP2 | 3 (5) total for GP2 | 3 (4.9) withdrawn for GP2 | 0 (0) total for GP1
| | | | | | Fsg<50 mg/dl | | | | 0 (0) total for GP2
| | | | | | 0 (0) serious for GP1
| | | | | | 2 (3) total for GP1
| | | | | | 0 (0) serious for GP2
| | | | | | 5 (8) total for GP2
Thiazolidinedione vs Alpha-Glucosidase Inhibitors
Goke, 2002 ^75^ | RCT | Pioglitazone, 129 | Acarbose, 136 | 45 mg (fixed) | 50 mg once daily (esc) 300 mg divided up into tid dosing | | Chf not reported | Abdominal distension/flatulence | | Elevated aminotransferase levels
German Pio Study Group | | | | | | | 0 (0) withdrawn for GP1 | 0 (0) withdrawn for GP1 | | 0 (0) withdrawn for GP1
| | | | | | | 2 (1.5) withdrawn for GP2 | NR for GP1 | | 2 (1.5) withdrawn for GP2
| | | | | | | Edema not reported | 1 (0.7) withdrawn for GP2
| | | | | | | 1 (0.8) withdrawn for GP1 | 46 (33.8) total for GP2
| | | | | | | 6 (4.7) total for GP1
| | | | | | | 0 (0) withdrawn for GP2
| | | | | | | NR for GP2
Other Thiazolidinedione Comparisons
Takagi, 2003 ^78^ | RCT | Pioglitazone + (conventional anti-diabetics therapy: insulin (22%), SU (52%), acarbosee (9%)), 23 | (conventioral anti-diabetics therapy: insulin (14%), SU (33%), acarbosee (71%)), 21 | 30 mg (fixed) | NR (NR) | | Chf not reported
| | | | NR (NR) | | | 0 (0) total for GP1
| | | | | | | 0 (0) total for GP2
| | | | | | | Edema not reported
| | | | | | | 2 (8.7) total for GP1
| | | | | | | 0 (0) total for GP2
Nishio, 2006 ^151^ | RCT | Pioglitazone, 26 | Control (no placebo), 28 | 30 mg (fixed) | NR (NR) | | Severe CHF | | | ALT>2 times ULN + AST> 2 × ULN
| | | | | | | 0 (0) serious for GP1 | | | 0 (0) total for GP1
| | | | | | | 0 (0) serious for GP2
| | | | | | | Edema not reported
| | | | | | | 0 (0) total for GP1
Choi, 2004 ^77^ | RCT | Rosiglitazone (could be on metformin + unspecified sulfonylurea + unspecified alpha-glucosidase inhibitor + insulin), 38 | Uptitration of control group (could be on metformin + unspecified sulfonylurea + unspecified alpha-glucosidase inhibitor + insulin), 45 | 8 mg (changed to 4mg/ day after catheterization) | NR (NR) | | | | | Elevated aminotransferase levels
| | | | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | | | 0 (0) total for GP1
| | | | | | | | | | 0 (0) withdrawn for GP2
| | | | | | | | | | 0 (0) total for GP2
Ko, 2003 ^328^ | Non-randomized trial | Rosiglitazone (some on insulin or unspecified SU), 60 | Existing medications (metformin + unspecified sulfonylurea (some on insulin), 72 | 4 mg (fixed) | NR (NR) | | Edema or weight gain
| | | | | | | 6 (10) withdrawn for GP1
| | | | | | | 0 (0) withdrawn for GP2
Delea, 2003 ^228^ | Cohort | Unspecified TZD, 4441 | Non-TZD, 28103 | NR (NR) | NR (NR) | | Icd-9 code for CHF
Pharmetrics Integrated Outcomes Database | | | | | | | 1.76 (1.43–2.17) HR (95% CI)
Delea, 2003 ^228^ | Cohort | Rosiglitazone, 1882 | Non-TZD, 28103 | NR (NR) | NR (NR) | | Icd-9 code for CHF
Pharmetrics Integrated Outcomes Database | | | | | | | 2.27 (1.65–3.13) hr (95% CI)
Manley, 2003 ^239^ | Cohort | Rosiglitazone, 15 | Rosiglitazone + pioglitazone | NR (NR) | NR (NR) | | | | | Anemia
| | | | | NR (NR) | | | | | 34.89% baseline hct level for GP1
| | | | | | | | | | 34.00% final hct level for GP2 (p=0.024)
Delea, 2003 ^228^ | Cohort | Pioglitazone, 1347 | Non-TZD, 28103 | NR (NR) | NR (NR) | | Icd-9 code for CHF
Pharmetrics Integrated Outcomes Database | | | | | | | 1.92 (1.24–2.97) hr (95% CI)
Inzucchi, 2005 ^184^ | Cohort | Unspecified TZD, 819 | None insulin-sensitizing antihyperglycaemic, 6641 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 402 (49.1) total for GP1
| | | | | | | 2859 (43.1) total for GP2
Inzucchi, 2005 ^184^ | Cohort | None insulin-sensitizing antihyperglycaemic, 6641 | Metformin + TZD, 139 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 2859 (43.1) total for GP1
| | | | | | | 54 (38.8) total for GP2
Chalasani, 2005 ^222^ | Cohort | Rosiglitazone (among those with abnormal liver function tests) | Rosiglitazone (among those without abnormal liver function tests) | NR | NR | | | | | Elevated aminotransferase levels (10 times ULN)
| | | | | | | | | | (0.9) serious for GP1
| | | | | | | | | | (0.6) serious for GP2
| | | | | | | | | | (10) total for GP1
| | | | | | | | | | (6.6) total for GP2
Masoudi, 2005 ^229^ | Cohort | Thiazolidinedione | Non-thiazolidinedione and non-metformin(sulfonylurea or insulin) | NR (NR) | NR(NR) | | Medicare claims data for readmission for CHF as the principal diagnosis
| | | | | | | HR 1.06 (1.0–1.09) vs GP2
Thiazolidinedione vs. Thiazolidinedione + Sulfonylurea
McCluskey, 2004 ^76^ | RCT | Rosiglitazone + placebo, 15 | Rosiglitazone + glimepiride, 24 | 4 or 8 mg (fixed) | 4 or 8 mg (fixed) | Fsg<36mg/dl | | | | Treatment failure
| | | | | 2 mg (esc) 8 | 0 (0) withdrawn for GP1 | | | | 2 (13.3) withdrawn for GP1
| | | | | | 0 (0) total for GP1 | | | | 1 (4) withdrawn for GP2
| | | | | | 0 (0) withdrawn for GP2
| | | | | | 1 (4.2) total for GP2
Kubo, 2002 ^225^ | Non-randomized trial | Pioglitazone, 18 | Pioglitazone + gliclazide, 19 | 30 mg (fixed) | 40 mg (fixed) | | Edema not reported | | | Elevated aminotransferase levels
| | | | | 30 mg (fixed) | | 3 (16.7) total for GP1 | | | 0 (0) serious for GP1
| | | | | | | | | | 0 (0) total for GP1
Metformin vs. Sulfonylurea
Marre, 2002 ^84^ | RCT | Metformin, 104 | Glibenclamide, 103 | 500 mg (esc) 2000 | 5 mg (esc) 20 | Symptoms or labs | | Not reported
| | | | | | 1 (1.0) serious for GP1 | | 15 (14.4) total for GP1
| | | | | | 1 (1.0) total for GP1 | | 2 (1.9) serious for GP2
| | | | | | 1 (1.0) serious for GP2 | | 12 (11.7) total for GP2
| | | | | | 8 (7.8) total for GP2
Amador-Licona, 2000 ^85^ | RCT | Metformin, 28 | Glibenclamide, 23 | 850 mg (dose was adjusted to reach adequate metabolic control for 3 weeks) | 5 mg (dose was adjusted to reach adequate metabolic control for 3 weeks) | | | Diarrhea + Diffuse abdominal pain
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 4 (14.3) total for GP1
Hermann, 1994 ^87^ | RCT | Metformin + diet | Glibenclamide + diet | 1000 mg (esc) 3000 | 3.5 mg (esc) 10.5 | Not reported | | Nausea + diarrhea + dyspepsia, digestive
| | | | | | 8 (21) serious for GP1 | | 24 (63) serious for GP1
| | | | | | 12 (35) serious for GP2 | | 11 (32) serious for GP2
1998, ^15^ | RCT | Metformin + diet, 342 | Glibenclamide + diet, 277 | 850 mg (esc) 2550 | 10 mg (esc) 20 | Symptoms
UKPDS (10 year results) | | | | | | 1 (0.3) serious (death) for GP1
| | | | | | Major events
| | | | | | (0% per year) for GP1
| | | | | | (2.5% per year) for GP2
| | | | | | Total events
| | | | | | (4.2% per year) for GP1
| | | | | | (17.5% per year) for GP2
1995, ^92^ | RCT | Metformin + diet, 262 | Glibenclamide + diet, 472 | 850 mg (esc) 2550 | 10 mg (esc) 20 | Not reported
UKPDS | | | | | | (0.5% mean annual % over 3 years) serious for GP1
| | | | | | (6.3% mean annual % over 3 years) total for GP1
| | | | | | (1.3% mean annual % over 3 years) serious for GP2
| | | | | | (26.8% mean annual % over 3 years) total for GP2
Yamanouchi, 2005 ^57^ | RCT | Metformin + diet + exercise, 39 | Glimepiride + diet + exercise, 37 | 750 mg (fixed) | 1.0 mg (esc) 2.0 after 1 month in 8 cases. Rest on 1 mg | Not reported | Edema | | | ALT>1.5 times ULN + AST>1.5 times ULN
| | | | | | 0 (0) serious for GP1 | 0 (0) total for GP1 | | | 0 (0) total for GP1
| | | | | | 0 (0) total for GP1 | 0 (0) total for GP2 | | | 0 (0) total for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 1 (2.7) total for GP2
Charpentier, 2001 ^89^ | RCT | Metformin + placebo, 75 | Glimepiride + placebo, 150 | 850 mg tid (fixed) | 1 mg (either fixed or increased stepwise to 2, 4, or 6 mg od depending on clinical symptoms of hypoglycemia) | Clinical symptoms | | Diarrhea | Unspecified adverse events
| | | | | | 0 (0) serious for GP1 | | 5 (7) total for GP1 | 7 (9.3) withdrawn for GP1
| | | | | | 8 (11) total for GP1 | | 2 (1) total for GP2 | 8 (5.3) withdrawn for GP2
| | | | | | 3 (2.0) serious for GP2
| | | | | | 20 (13) total for GP2
Derosa, 2004 ^90^ | RCT | Metformin + placebo + diet + exercise, 75 | Glimepiride + placebo + diet + exercise, 73 | 1000 mg (esc) 3000 | 1 mg (esc) 4 | Not reported | | Nausea + diarrhea
| | | | | | 0 (0) serious for GP1 | | 2 (2.4) withdrawn for GP1
| | | | | | 0 (0) total for GP1
| | | | | | 0 (0) serious for GP2
| | | | | | 0 (0) total for GP2
Goldstein, 2003 ^82^ | RCT | Metformin, 75 | Glipizide, 84 | 500 mg (tirated to patient glucose response) 2000 mg | 30 mg (tirated to patient glucose response) 30 mg | | | Diarrhea | | Lactic acidosis
| | | | | | | | 13 (17.3) total for GP1 | | 0 (0) serious for GP1
| | | | | | | | 11 (13.1) total for GP1 | | 0 (0) serious for GP2
Garber, 2002 ^79^ | RCT | Metformin, 159 | Glyburide (micronase), 160 | 500 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet criteria) 2000 | 2.5 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet criteria) 10 | FASTing plasma glucose <50 | | Nausea + vomiting + diarrhea + dyspepsia | Discontinuation due to adverse events
| | | | | | 0 (0) total for GP1 | | 43 IR for GP1 | 6.3 IR for GP1
| | | | | | (6.3) total for GP2 | | 24 IR for GP2 | 6.9 IR for GP2
Garber, 2003 ^80^ | RCT | Metformin, 164 | Glyburide (no trade drug specified), 151 | 500 mg (adjusted to patient response) 2000 mg | 2.5 (adjusted to patient response) 10 mg | Symptoms suggesting hypoglycemia | | Adominal pain
| | | | | | 29 (17.7) total for GP1 | | 10 (6.1) total for GP1
| | | | | | 98 (57.6) total for GP2 | | 6 (4) total for GP2
| | | | | | Fingerstick blood glucose | | nausea + vomiting
| | | | | | 1 (0.6) total for GP1 | | 17 (10.4) total for GP1
| | | | | | 16 (10.6) total for GP2 | | 10 (6.6) total for GP2
| | | | | | | | diarrhea
| | | | | | | | 30 (18.3) total for GP1
| | | | | | | | 8 (5.3) total for GP2
Blonde, 2002 ^81^ | RCT | Metformin, 153 | Glyburide (no trade drug specified), 164 | 500 mg (esc) 2000 mg | 10 mg (fixed) | Fsg<=60mg/dl + symptomatic | | Dyspepsia, heartburn | Withdrew due to unspecified adverse event | Lactic acidosis
| | | | | | 1 (<1) total for GP1 | | 7 (4.6) total for GP1 | 8 (5) withdrawn for GP1 | 0 (0) total for GP1
| | | | | | 3 (1.8) total for GP2 | | 5 (3) total for GP2 | 5 (3) withdrawn for GP2 | 0 (0) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 19 (12.4) total for GP1
| | | | | | | | 9 (5.5) total for GP2
| | | | | | | | Flatulence
| | | | | | | | 3 (2) total for GP1
| | | | | | | | 0 (0) total for GP2
DeFronzo, 1995 ^88^ | RCT | Metformin + placebo, 210 | Glyburide (no trade drug specified) + placebo, 209 | 500 mg (esc) 2500 | 10 mg /day in two divided doses (esc) 20mg per day in 2 divided doses | Not reported | | Nausea + diarrhea | | Unspecified adverse events
| | | | | | 4 (2) total for GP1 | | 3 (1.4) total for GP1 | | 4 (2) serious for GP1
| | | | | | 6 (3) total for GP2 | | 2 (1.0) total for GP2 | | 6 (3) serious for GP2
| | | | | | | | | | treatment failure + symptomatic diabetes
| | | | | | | | | | 21 (10) serious for GP1
| | | | | | | | | | 6 (3) serious for GP2
Lawrence, 2004 ^54^ | RCT | Metformin, 21 | Gliclazide, 22 | 500 mg (esc) 1 g tid | 80 mg (esc) 160 mg bid | | Ankle edema
| | | | | | | 0 (0) withdrawn for GP1
| | | | | | | 0 (0) withdrawn for GP2
Noury, 1991 ^86^ | RCT | Metformin, 30 | Gliclazide, 27 | 1700 mg (fixed) | 80 mg (esc) 240 | | | Nausea
| | | | | | | | 1 (3.3) total for GP1
| | | | | | | | 0 (0) total for GP2
Turner, 1998 ^93^ | RCT | Metformin + diet, 49 | Glyburide (diabeta) or chlorpropramide + diet, 124 | NR (esc) 2550mg | NR (esc) 20mg for glyburide 500mg for chlorpropramide | Major hypoglycemic episodes
UKPDS | | | | Sulfonylurea could be added to the regimen if still hyperglycemic (esc) 20 | Metformin could be added if had hyperglycemia (esc) 2550mg | 0 annual proportion in GP1 with event
| | | | If still hyperglycemic, insulin could be added | If still hyperglycemic, insulin could be added | 2.5 (0–6.7) annual proportion (range) in GP2
| | | | | | Any minor or major event
| | | | | | 7 (0–12) annual proportion (range) in GP1
| | | | | | 21 (18–27) annual proportion (range) in GP2
Nichols, 2005 ^230^ | Cohort | Metformin | Unspecified sulfonylurea | NR (NR) | NR (NR) | | Medical record for CHF + icd-9 code for CHF + clinical diagnosis + first record
Kaiser Permaneante database | | | | | | | 10.5 (6.7–16.2) IR & 95% CI for GP1
| | | | | | | 13.8 (11.4–16.6) IR & 95% CI for GP2
Maru, 2005 ^232^ | Cohort | Metformin, 4579 | Unspecified sulfonylurea, 11350 | NR (NR) | NR (NR) | | Chf/clinical diagnosis + validated a small sample via questionnaires to GP to confirm the diagnosis + oxmis and read codes similar to icd-9 codes
UK General Practice Research Database | | | | | | | 18.8/1000 person-years IR for GP1
| | | | | | | 26.6/1000 person-years IR for GP2
Bytzer, 2001 ^216^ | Cross-sectional | Metformin, 211 | Unspecified sulfonylurea, 206 | NR (NR) | NR (NR) | | | 1. Dysmotility-like dyspepsia
| | | | | | | | 25 (11.9) total for GP1
| | | | | | | | 19 (9.2) total for GP2
| | | | | | | | 2. Frequent abdominal pain
| | | | | | | | 18 (8.5) total for GP1
| | | | | | | | 10 (4.9) total for GP2
| | | | | | | | 3. steatorrhoea-like stools
| | | | | | | | 31 (14.6) total for GP1
| | | | | | | | 33 (15.8) total for GP2
| | | | | | | | 4. Gastroaesophageal reflux
| | | | | | | | 29 (13.7) total for GP1
| | | | | | | | 25 (12.1) total for GP2
| | | | | | | | 5. Constipation
| | | | | | | | 44 (20.9) total for GP1
| | | | | | | | 51 (24.8) total for GP2
| | | | | | | | 6. Fecal incontinence
| | | | | | | | 22 (10.4) total for GP1
| | | | | | | | 11 (5.3) total for GP2
| | | | | | | | bowel related pain
| | | | | | | | 28 (13.3) total for GP1
| | | | | | | | 24 (11.7) total for GP2
| | | | | | | | ulcer-like dyspepsia
| | | | | | | | 18 (8.5) total for GP1
| | | | | | | | 14 (6.8) total for GP2
| | | | | | | | Diarrhea
| | | | | | | | 11 (5.2) total for GP1
| | | | | | | | 4 (1.9) total for GP2
Dandona, 1983 ^215^ | Cross-sectional | Metformin, 54 | Unspecified sulfonylurea, 53 | NR (NR) | NR (NR) | | | Diarrhea
| | | | | | | | 11 (20) serious for GP1
| | | | | | | | 11 (20) total for GP1
| | | | | | | | 3 (6) serious for GP2
| | | | | | | | 3 (6) total for GP2
Frenchman, 2003 ^200^ | Cohort | Metformin + second medication was added in 47.6% of patients: 9 sulfonylureas, and 1 insulin, 48 | Unspecified sulfonylurea + second medication added in 17.7% of patients: 9 metformin, 2 insulin, 2 rosiglitazone, and 1 pioglitazone), 121 | NR (NR) | NR (NR) | Low fpg (unspecified) | Edema | Nausea + vomiting + diarrhea | | total adverse events
| | | | | | 2 (4.2) total for GP1 | 2 (4.2) total for GP1 | 1 (2.1) withdrawn for GP1 | | 21 (43.8) total for GP1
| | | | | | 18 (14.9) total for GP2 | 3 (2.5) total for GP2 | 5 (10.4) total for GP1 | | 29 (24) total for GP2
| | | | | | | | 0 (0) withdrawn for GP2 | | Decreased dose due to unspecified adverse event
| | | | | | | | 3 (2.5) total for GP2 | | 6 (12.5) total for GP1
| | | | | | | | | | 6 (5) total for GP2
Leese, 2003 ^201^ | Cohort | Metformin or diet | Unspecified sulfonylurea | NR | NR | Blood glucose <3.5 mmol/l requiring glucagon or iv dextrose or confirmation by paramedics by rapid recovery with treatment
DARTS/MEMO | | | | | | 0.9/100 patient-years (0.6–1.3) IR & 95%CI for GP2
| | | | | | 0.05/100 patient-years (0.01–0.2) IR & 95%CI for GP2
Metformin vs. Meglitinide
Horton, 2000 ^96^ | RCT | Metformin, 178 | Nateglinide, 179 | 500 mg (fixed) | 120 mg tid (fixed) | Plasma glucose measurement <=3.3 mmol or suggestive cases | | Nausea + diarrhea
| | | | | | 19 (10.1) total for GP1 | | 6 (3.4) withdrawn for GP1
| | | | | | 1 (0.6) withdrawn for GP2 | | 1 (0.6) withdrawn for GP2
| | | | | | 23 (12.8) total for GP2
Derosa, 2003 ^97^ | RCT | Metformin + diet + exercise, 56 | Repaglinide + diet + exercise, 56 | 500 mg bid (1500–2500 during 8 week titration period, then fixed) 2500 mg/day | 0.5 mg bid (2–4 mg per day during 8 week titration period, then fixed) 4 tid | Not reported | | Nausea + diarrhea
| | | | | | 0 (0) withdrawn for GP1 | | 2 (3.6) withdrawn for GP1
| | | | | | 0 (0) serious for GP1 | | 0 (0) withdrawn for GP2
| | | | | | 0 (0) total for GP1
| | | | | | 0 (0) withdrawn for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 0 (0) total for GP2
Metformin vs. Alpha-Glucosidase Inhibitor
Willms, 1999 ^99^ | RCT | Metformin, 27 | Acarbose, 31 | 850 mg bid (fixed) | 100 mg tid (fixed) | Not reported | | Not reported | Withdrawn due to unspecified adverse event
| | | | | | 5 (18.5) total for GP1 | | 37 total number of occurrences for GP1 | 4 (14.8) withdrawn for GP1
| | | | | | 3 (9.7) total for GP2 | | 42 total number of occurrences for GP2 | 18 (58.1) withdrawn for GP2
Metformin vs. Metformin + Sulfonylurea
Marre, 2002 ^84^ | RCT | Metformin, 104 | Metformin + glibenclamide, 101 | 500 mg (esc) 2000 | 500 mg (esc) 2000 | Symptoms or labs | | Not reported
| | | | | 2.5 mg (esc) 10 | 1 (1.0) serious for GP1 | | 15 (14.4) total for GP1
| | | | | | 1 (1.0) total for GP1 | | 7 (6.9) total for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 11(10.9) total for GP2
Marre, 2002 ^84^ | RCT | Metformin, 104 | Metformin + glibenclamide, 103 | 500 mg (esc) 2000 | 500 mg (esc) 2000 | Symptoms or labs | | Not reported
| | | | | 5 mg (esc) 20 | 1 (1.0) serious for GP1 | | 15 (14.4) total for GP1
| | | | | | 1 (1.0) total for GP1 | | 19 (18.4) total for GP2
| | | | | | 2 (1.9) serious for GP2
| | | | | | 14 (13.6) total for GP2
Tosi, 2003 ^95^ | RCT, cross-over | Metformin, 19 | Metformin + glibenclamide, 39 | 500 mg (esc) 3000 | 400 mg (esc) 2400 | Not reported | | Diarrhea + constipation + discomfort, abdominal pain, and anorexia | | Leukopenia
| | | | | 2.5 mg (esc) 15 | 2 (10.5) withdrawn for GP1 | | 2 (10.5) total for GP1 | | 1 (2.6) total for GP2
| | | | | | 1 (5) total for GP1 | | 1 (2.6) withdrawn for GP2
| | | | | | | | 1 (2.6) total for GP2
Hermann, 1994 ^87^ | RCT | Metformin + diet | Metformin + glibenclamide + diet | 1000 mg (esc) 3000 | 500 mg (esc) 3000 | Not reported | | Nausea + diarrhea + dyspepsia, digestive
| | | | | 1.75 mg (esc) 14.0 | 8 (21) serious for GP1 | | 24 (63) serious for GP1
| | | | | | 24 (33) serious for GP2 | | 25 (35) serious for GP2
Charpentier, 2001 ^89^ | RCT | Metformin + placebo, 75 | Metformin + glimepiride, 147 | 850 mg tid (fixed) | 850 mg tid (fixed) | Clinical symptoms | | Diarrhea | Unspecified adverse events
| | | | | 1 mg (either fixed or increased stepwise to 2, 4, or 6 mg od depending on clinical symptoms of hypoglycemia) | 0 (0) serious for GP1 | | 5 (7) total for GP1 | 7 (9.3) withdrawn for GP1
| | | | | | 8 (11) total for GP1 | | 4 (3) total for GP2 | 6 (4.1) withdrawn for GP2
| | | | | | 2 (1.4) serious for GP2
| | | | | | 32 (22) total for GP2
Feinglos, 2005 ^104^ | RCT | Metformin + placebo, 56 | Metformin + glipizide, 56 | > or = 1000/day mg (fixed) | > or = 1000/day mg (fixed) | Finger stick glucose <60 mg/dl w/symptoms or finger stick glucose <50 mg/dl w/o symptoms or fpg<55 mg/dl w/o symptoms
| | | | | 2.5 mg (fixed) | 0 (0) withdrawn for GP1
| | | | | | 0 (0) serious for GP1
| | | | | | 2 (3.3) total for GP1
| | | | | | 0 (0) withdrawn for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 9 (14.8) total for GP2
Goldstein, 2003 ^82^ | RCT | Metformin, 75 | Metformin + glipizide, 87 | 500 mg (tirated to patient glucose response) 2000 mg | 500/5 mg (tirated to patient glucose response 2000/20 mg | | | Diarrhea | | Lactic acidosis
| | | | | | | | 13 (17.3) total for GP1 | | 0 (0) serious for GP1
| | | | | | | | 16 (18.4) total for GP1 | | 0 (0) serious for GP2
Garber, 2002 ^79^ | RCT | Metformin, 159 | Metformin + glyburide (micronase), 158 | 500 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) 2000 | 250/1.25 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) | Not reported | | Nausea + vomiting + diarrhea + dyspepsia | Discontinuation due to adverse events
| | | | | | 18 (11.4) total for GP2 | | 43 IR for GP1 | 6.3 IR for GP1
| | | | | | | | 32 IR for GP2 | 3.8 IR for GP2
Garber, 2002 ^79^ | RCT | Metformin, 159 | Metformin + glyburide (micronase), 162 | 500 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) 2000 | 500/2.5 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) | Not reported | | Nausea + vomiting + diarrhea + dyspepsia | Discontinuation due to adverse events
| | | | | | 61 (37.7) total for GP2 | | 43 IR for GP1 | 6.3 IR for GP1
| | | | | | | | 38 IR for GP2 | 11.1 IR for GP2
Blonde, 2002 ^81^ | RCT | Metformin, 153 | Metformin + glyburide (no trade drug specified), 160 | 500 mg (esc) 2000 mg | 500/2.5 mg (esc) 2000/10 | Fsg<=60mg/dl + symptomatic | | Dyspepsia, heartburn | Withdrew due to unspecified adverse event | Lactic acidosis
| | | | | | 1 (<1) total for GP1 | | 7 (4.6) total for GP1 | 8 (5) withdrawn for GP1 | 0 (0) total for GP1
| | | | | | 22 (6.8) total for both metformin + Glyburide groups | | 8 (5) total for GP2 | 5 (3.4) withdrawn for for both metformin + Glyburide groups | 0 (0) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 19 (12.4) total for GP1
| | | | | | | | 16 (10) total for GP2
| | | | | | | | flatulence
| | | | | | | | 3 (2) total for GP1
| | | | | | | | 10 (6.3) total for GP2
Blonde, 2002 ^81^ | RCT | Metformin, 153 | Metformin + glyburide (no trade drug specified), 162 | 500 mg (esc) 2000 mg | 500/5 mg (esc) 2000/20 | Fsg<=60mg/dl + symptomatic | | Dyspepsia, heartburn | Withdrew due to unspecified adverse event | Lactic acidosis
| | | | | | 1 (<1) total for GP1 | | 7 (4.6) total for GP1 | 8 (5) withdrawn for GP1 | 0 (0) total for GP1
| | | | | | 22 (6.8) total for both metformin + Glyburide groups | | 6 (3.7) total for GP2 | 5 (3.4) withdrawn for for both metformin + Glyburide groups | 0 (0) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 19 (12.4) total for GP1
| | | | | | | | 11 (6.8) total for GP2
| | | | | | | | Flatulence
| | | | | | | | 3 (2) total for GP1
| | | | | | | | 4 (2.5) total for GP2
Garber, 2003 ^80^ | RCT | Metformin, 164 | Metformin + glyburide (no trade drug specified), 171 | 500 mg (adjusted to patient response) 2000 mg | 250 mg (adjusted to patient response) 1000 mg | Symptoms suggesting hypoglycemia | | Adominal pain
| | | | | 1.25 mg (esc) 5 mg | 29 (17.7) total for GP1 | | 10 (6.1) total for GP1
| | | | | | 59 (39.1) total for GP2 | | 7 (4.1) total for GP2
| | | | | | Fingerstick blood glucose | | nausea + vomiting
| | | | | | 1 (0.6) total for GP1 | | 17 (10.4) total for GP1
| | | | | | 19 (11.2) total for GP2 | | 8 (4.7) total for GP2
| | | | | | | | diarrhea
| | | | | | | | 30 (18.3) total for GP1
| | | | | | | | 13 (7.6) total for GP2
DeFronzo, 1995 ^88^ | RCT | Metformin + placebo, 210 | Metformin + glyburide (no trade drug specified), 213 | 500 mg (esc) 2500 | 500 mg (esc) 2500 | Not reported | | Nausea + diarrhea | | unspecified adverse events
| | | | | 10 mg (esc) 20 | 4 (2) total for GP1 | | 3 (1.4) total for GP1 | | 4 (2) serious for GP1
| | | | | | 38 (18) total for GP2 | | 2 (0.9) total for GP2 | | 4 (2) serious for GP2
| | | | | | | | | | treatment failure + symptomatic diabetes
| | | | | | | | | | 21 (10) serious for GP1
| | | | | | | | | | 1 (0.5) serious for GP2
Dandona, 1983 ^215^ | Cross-sectional | Metformin, 54 | Metformin + sulfonylurea, 45 | NR (NR) | NR (NR) | | | Diarrhea
| | | | | | | | 11 (20) serious for GP1
| | | | | | | | 11 (20) total for GP1
| | | | | | | | 9 (20) serious for GP2
| | | | | | | | 9 (20) total for GP2
Nichols, 2005 ^230^ | Cohort | Metformin | Metformin + unspecified sulfonylurea | NR (NR) | NR (NR) | | Medical record for CHF + icd-9 code for CHF + clinical diagnosis + first record
Kaiser Permaneante database | | | | | NR (NR) | | 10.5 (6.7–16.2) IR & 95% CI for GP1
| | | | | | | 13.4 (11.6–15.5) IR & 95% CI for GP2
Metformin vs. Thiazolidinedione + Metformin
Bailey, 2005 ^101^ | RCT | Metformin, 280 | Rosiglitazone + metformin, 288 | 2500 mg (esc) 3000 | 4/2000 mg (esc) 8/2000 | Unspecified | Edema not reported | NR but included diarrhea and abdominal pain | Withdrawn due to unspecified adverse events | ALT>3× ULN + AST>3× ULN
| | | | | | 0 (0) withdrawn for GP1 | 3 (1) total for GP1 | 15 (5.4) withdrawn for GP1 | 22 (7.9) withdrawn for GP1 | 3 (1) total for GP1
| | | | | | 0 (0) serious for GP1 | 8 (3) total for GP2 | 9 (3.2) withdrawn for GP2 | 12 (4.2) withdrawn for GP2 | 1 (<1) total for GP2
| | | | | | 1 (0.4) total for GP1
| | | | | | 0 (0) withdrawn for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 3 (1) total for GP2
Fonseca, 2000 ^103^ | RCT | Metformin + placebo, 113 | Rosiglitazone + metformin, 110 | 2500 mg (fixed) | 8 mg (fixed) | Not reported | Edema not reported | | | Anemia
| | | | | 2500 mg (fixed) | 2 (1.8) total for GP1 | 1 (0.9) total for GP1 | | | 1 (0.9) withdrawn for GP2
| | | | | | 5 (4.5) total for GP2 | 4 (3.5) total for GP2 | | | ALT>3 times the upper limit of the reference range + AST>3 times the upper limit of the reference range
| | | | | | | | | | 2 (1.8) total for GP1
Fonseca, 2000 ^103^ | RCT | Metformin + placebo, 113 | Rosiglitazone + metformin, 116 | 2500 mg (fixed) | 4 mg (fixed) | Not reported | Edema not reported | | | Anemia
| | | | | 2500 mg (fixed) | 2 (1.8) total for GP1 | 1 (0.9) total for GP1 | | | 1 (0.9) withdrawn for GP2
| | | | | | 3 (2.6) total for GP2 | 3 (2.5) total for GP2 | | | ALT>3 times the upper limit of the reference range + AST>3 times the upper limit of the reference range
| | | | | | | | | | 2 (1.8) total for GP1
Gomez-Perez, 2002 ^102^ | RCT | Metformin + placebo, 34 | Rosiglitazone + metformin, 35 | 500 mg (fixed) | 500 mg (fixed) | | Edema not reported | Nausea + vomiting + diarrhea + flatulence, abdominal pain | Withdrawn due to adverse events | Anemia/ change in hemoglobin
| | | | | 2 mg (fixed) | | 0 (0) total for GP1 | 5 (15.4) total for GP1 | 1 (2.9) withdrawn for GP1 | -0.53 mg/dl for GP1
| | | | | | | 2 (5.2) total for GP2 | 6 (16.8) total for GP2 | 2 (5.7) withdrawn for GP2 | Anemia/ change in hematocrit
| | | | | | | | | | -1.27% for GP1
Gomez-Perez, 2002 ^102^ | RCT | Metformin + placebo, 34 | Rosiglitazone + metformin, 36 | 500 mg (fixed) | 500 mg (fixed) | | Edema not reported | Nausea + vomiting + diarrhea + flatulence, abdominal pain | Withdrawn due to adverse events | Anemia/ change in hemoglobin
| | | | | 4 mg (fixed) | | 0 (0) total for GP1 | 5 (15.4) total for GP1 | 1 (2.9) withdrawn for GP1 | -0.75 mg/dl for GP1
| | | | | | | 2 (5.2) total for GP2 | 6 (16.8) total for GP2 | 3 (8.3) withdrawn for GP2 | Anemia/ change in hematocrit
| | | | | | | | | | -2.14% for GP1
Weissman, 2005 ^100^ | RCT | Metformin, 384 | Rosiglitazone + metformin, 382 | 500 bid mg (esc) 1000 bid | 500 bid mg (fixed) 500 bid | Mild or moderate | Edema not reported | Unknown | Withdrew due to unspecified adverse event | Anemia
| | | | | 4 mg (esc) 8 | 4 (1.0) total for GP1 | 0 (0) withdrawn for GP1 | 26 (6.8) withdrawn for GP1 | 37 (9.6) withdrawn for GP1 | 0 (0) total for GP1
| | | | | | 4 (1.0) total for GP2 | 5 (1.3) total for GP1 | 63 (diarrhea), 43 (abd pain) total for GP1 | 28 (7.3) withdrawn for GP2 | 6 (1.6) total for GP2
| | | | | | | 2 (0.5) withdrawn for GP2 | 12 (3.1) withdrawn for GP2 | | Elevated aminotransferase levels
| | | | | | | 18 (4.7) total for GP2 | NR total for GP2 | | 0 (0) withdrawn for GP1
| | | | | | | | | | 1 (0.3) withdrawn for GP2
Inzucchi, 2005 ^184^ | Cohort | Metformin, 1273 | Metformin + TZD, 139 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 435 (34.2) total for GP1
| | | | | | | 54 (38.8) total for GP2
Other Metformin Comparisons
Fujioka, 2003 ^105^ | RCT | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 146 (both met XR groups combined) | 1000 mg (esclated by 500mg after week 12 if not in good glycemic control; otherwise fixed) 1500 | 1000 mg (escalated by 500mg after week 12 if not in good glycemic control) 1500 | | | Selected treatment emergent gi adverse events | | Cancer/malignant neoplasm 1 (0.7) total for GP2
| | | | | | | | (39) total for GP1
| | | | | | | | (29) total for GP2
Fujioka, 2003 ^105^ | RCT | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 71 | 1000 mg (esclated by 500mg after week 12 if not in good glycemic control; otherwise fixed) 1500 | 1000 mg (escalated after 1 week to 1500 mg; could be escalated after week 12 by 500 mg if not in good glycemic control) 2000 | Not reported | | Flatulence | | Cancer/malignant neoplasm 0 (0) total for GP2
| | | | | | 1 (1.4) total for GP1 | | 1 (1) total for GP1
| | | | | | 0 (0) total for GP2 | | 2 (3) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 3 (4) total for GP1
| | | | | | | | 2 (3) total for GP2
| | | | | | | | Diarrhea
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 2 (3) total for GP1
| | | | | | | | 1 (1.4) withdrawn for GP2
| | | | | | | | 11 (15) total for GP2
| | | | | | | | Abdominal pain
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 1 (1) total for GP1
| | | | | | | | 1 (1.4) withdrawn for GP2
| | | | | | | | 1 (1) total for GP2
| | | | | | | | Dyspepsia/heartburn
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 4 (6) total for GP1
| | | | | | | | 0 (0) withdrawn for GP2
| | | | | | | | 0 (0) total for GP2
Fujioka, 2003 ^105^ | RCT | Metformin + placebo + diet, 71 | Metformin XR + placebo + diet, 75 | 1000 mg (esclated by 500mg after week 12 if not in good glycemic control; otherwise fixed) 1500 | 1000 mg (escalated by 500mg after week 12 if not in good glycemic control) 1500 | Not reported | | Flatulence
| | | | | | 1 (1.4) total for GP1 | | 1 (1) total for GP1
| | | | | | 1 (1.3) total for GP2 | | 3 (4) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 3 (4) total for GP1
| | | | | | | | 2 (3) total for GP2
| | | | | | | | Diarrhea
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 2 (3) total for GP1
| | | | | | | | 0 (0) withdrawn for GP2
| | | | | | | | 4 (5) total for GP2
| | | | | | | | Abdominal pain
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 1 (1) total for GP1
| | | | | | | | 0 (0) withdrawn for GP2
| | | | | | | | 3 (4) total for GP2
| | | | | | | | Dyspepsia/heartburn
| | | | | | | | 0 (0) withdrawn for GP1
| | | | | | | | 4 (6) total for GP1
| | | | | | | | 1 (1.3) withdrawn for GP2
| | | | | | | | 2 (3) total for GP2
Rachmani, 2002 ^150^ | RCT | Metformin + diet, 195 | No metformin + diet, 198 | NR (NR) | NR (NR) | | | Not reported | | Lactic acidosis/mean change in lactate levels
| | | | | | | | 6 (3.1) withdrawn for GP1 | | 11% for GP1
| | | | | | | | NR (0) withdrawn for GP2 | | 9% for GP2
| | | | | | | | | | Withdrawn from metformin use due to creatinine>200umol/l
| | | | | | | | | | 28 (14.4) withdrawn for GP1
| | | | | | | | | | NR (0) withdrawn for GP2
Cryer, 2005 ^176^ | RCT | Metformin + existing sulfonylurea + diet or metformin + existing other non-SU oral agent + diet, 7227 | Usual care (non-metformin oral agent or insulin + non-metformin oral agent, oral combination) + diet, 1505 | 500 mg (esc) 2500 mg/day in three divided doses with meals | NR (NR) | | Chf not reported | Not reported | | Cancer/benign, malignant (including cysts and polyps)
COSMIC Approach Study | | | | NR (NR) | | | 51 (0.7) total for GP1 | 88 (1.2) total for GP1 | | 92 (1.3) total for GP1
| | | | | | | 9 (0.6) total for GP2 | 18 (1.2) total for GP2 | | 20 (1.3) total for GP2
| | | | | | | | | | Lactic acidosis
| | | | | | | | | | 0 (0) serious for GP1
| | | | | | | | | | 289 (4) total for GP1
| | | | | | | | | | 0 (0) serious for GP2
| | | | | | | | | | 15 (1) total for GP2
Inzucchi, 2005 ^184^ | Cohort | Metformin, 1273 | None insulin-sensitizing antihyperglycaemic, 6641 | NR (NR) | NR (NR) | | Medical record for CHF
| | | | | | | 435 (34.2) total for GP1
| | | | | | | 2859 (43.1) total for GP2
Selby, 1999 ^237^ | Cohort | Metformin + (could be on oral hypoglycemics, insulin), 9875 | Not on metformin | NR (NR) 2,550mg | NR (NR) | | | | | Lactic acidosis/icd-9-cm code 276.2 + diagnosis of acidosis + chart review to determine metformin associated lactic acidosis 1 (0) serious for GP1
| | | | NR (NR)
Masoudi, 2005 ^229^ | Cohort | Metformin | Non-thiazolidinedione and non-metformin(sulfonylurea or insulin) | NR (NR) | NR(NR) | | Medicare claims data for readmission for CHF as the principal diagnosis
| | | | | | | HR 0.92 (0.92–0.99) vs GP2
Chan, 2003 ^224^ | Cohort | Metformin | No metformin | NR (NR) | NR(NR) | | | | | Acute liver failure or injury
| | | | | | | | | | Using claims data from 5 hmos
| | | | | | | | | | HR 1.37 (0.49–3.78) vs GP2
Sulfonylurea vs. Sulfonylurea
Draeger, 1996 ^112^ | RCT | Glimepiride, 524 | Glibenclamide, 520 | 1 mg (esc) 8 | 2.5 mg (esc) 20 | Fsg<70 mg/dl + reported by the patient, or a blood glucose of <= 50 mg/dl | | | | total adverse events
| | | | | | 3 (0.6) serious for GP1 | | | | 5 (1.0) serious for GP1
| | | | | | 74 (14.1) total for GP1 | | | | 90 (17.2) total for GP1
| | | | | | 1 (0.2) serious for GP2 | | | | 8 (1.5) serious for GP2
| | | | | | 60 (11.5) total for GP2 | | | | 100 (19.2) total for GP2
Sonnenberg, 1997 ^191^ | RCT, cross-over | Glimepiride, NR | Glimepiride, 53 | 6 mg (fixed) | 3 mg (fixed) | | | | Withdrawn due to unspecified adverse event
| | | | | | | | | 4 withdrawn for all groups
Kardas, 2005 ^114^ | RCT | Glibenclamide (could be on metformin if taking it prior to study start), 50 | Gliclazide(could be on metformin if taking it prior to study start), 55 | 10 mg (esc) 15 | 60 mg (esc) 90 | Not reported
DIACOM | | | | | | 0 (0) total for GP1
| | | | | | 0 (0) total for GP2
Baba, 1983 ^133^ | RCT | Glibenclamide, 131 | Gliclazide, 146 | 2.5 mg (esc) 10mg | 40 mg (esc) 160mg | Not reported | | | | Anemia/slight
| | | | | | 20 (15) total for GP1 | | | | 4 (3) total for GP1
| | | | | | 10 (7) total for GP2 | | | | 4 (3) total for GP2
| | | | | | | | | | aminotransferase not reported
| | | | | | | | | | 4 (3) for GP1
| | | | | | | | | | 4 (3) for GP2
Dills, 1996 ^107^ | RCT | Glyburide (micronase), 288 | Glimepiride, 289 | 1.25 mg (esc) 20 | 1 mg (esc) 16 | Suggestive symptoms | | | | Total adverse events
| | | | | | 48 (16.7) total for GP1 | | | | 92 IR for GP1
| | | | | | 34 (11.8) total for GP2 | | | | 93 IR for GP2
Kilo, 1988 ^147^ | RCT | Glyburide (no trade drug specified), 47 | Glipizide, 52 | 1.25 or 2.5 or 5 mg (esc) 20 | 5 or 10 mg (esc) 40 | Not reported | | | | Unspecified adverse events
| | | | | | 5 episodes for GP1 | | | | 10 total episodes for GP1
| | | | | | 3 episodes for GP2 | | | | 9 total episodes for GP2
Birkeland, 1994 ^110^ | RCT | Glyburide (no trade drug specified) + diet, 15 | Glipizide + diet, 15 | 1.75 mg (esc) 10.5 | 2.5 mg (esc) 15 | Not reported
| | | | | | 0 (0) serious for GP1
| | | | | | 2 (13.3) withdrawn for GP1
| | | | | | 0 (0) serious for GP2
Carlson, 1993 ^108^ | RCT | Glyburide (micronase), 104 | Glyburide (glynase prestab), 102 | 3 mg (fixed) | 5 mg (fixed) | Not reported | | | Withdrawn due to adverse event
| | | | | | 2 (2) total for GP1 | | | 1 (0.96) withdrawn for GP1
| | | | | | 1 (1) total for GP2 | | | 2 (1.96) withdrawn for GP2
Rosenstock, 1993 ^109^ | RCT | Glyburide (no trade drug specified), 70 | Gliclazide, 69 | 0.5 mg (esc) 20 | 5 mg (esc) 40 | Fsg<3.3 mmol/l or random plasma glucose <2.8 mmol/l or | | Nausea + diarrhea + dry mouth, upset stomach, or epigASTric burning | Adverse events + pruitus, neck ache, tinnitus, headache, and chest pain
| | | | | | 3 (4.3) total for GP1 | | 5 (7) total for GP1 | 3 (4) total for GP1
| | | | | | 1 (1.4) total for GP2 | | 4 (6) total for GP2 | 2 (3) total for GP2
Schernthaner, 2004 ^106^ | RCT | Glimepiride + existing meds (metformin unspecified alpha-glucosidase inhibitor + diet), 439 | Gliclazide + existing meds (unspecified alpha-glucosidase inhibitor + diet), 403 | 1 mg (esc) 6 | 30 mg (esc) 120mg | Blood glucose level < 3 mmol | | | Withdrawals due to adverse events that were not hypoglycemia
| | | | Pre-trial dosage not specified (fixed) | Pre-trial dosage not specified (fixed) | 9 (2.1) withdrawn for GP1 | | | 11 (2.5) withdrawn for GP1
| | | | Pre-trial dosage not specified (fixed) | Pre-trial dosage not specified (fixed) | 39 (8.9) total for GP1 | | | 12 (3.0) withdrawn for GP2
| | | | | | 1 (0.2) withdrawn for GP2
| | | | | | 15 (3.7) total for GP2
Holstein, 2001 ^202^ | Cohort | Glimepiride, 6 | Glibenclamide, 38 | NR (NR) | NR (NR) | Fbs<2.8 mmol/l
| | | | | | 0.86/1000 person-years IR for GP1
| | | | | | 5.6/1000 person-years IR for GP2
Jennings, 1989 ^203^ | Cohort | Glyburide (no trade drug specified), 74 | Gliclazide, 80 | NR (NR) | NR (NR) | Sweating, tremor, dizziness, or visual disturbance
| | | | | | 23 (31.5) total for GP1
| | | | | | 11 (13.8) total for GP2
Staa, 1997 ^204^ | Cohort | Glibenclamide, 18740 | Gliclazide, 7418 | NR (NR) | NR (NR) | OXMIS codes for hypoglycemia (similar to icd-9 codes)
| | | | | | HR 0.74 (0.59–0.92) vs GP1
Staa, 1997 ^204^ | Cohort | Glibenclamide, 18740 | Glipizide, 2012 | NR (NR) | NR (NR) | OXMIS codes for hypoglycemia (similar to icd-9 codes)
| | | | | | HR 0.60 (0.40–0.92) vs GP1
Shorr, 1996 ^205^ | Cohort | Glyburide, NR | Glipizide, NR | | | Not specified
| | | | | | IR 94/5669 person-years total for GP1
| | | | | | IR 25/2907 person-years total for GP2
| | | | | | RR 1.9 (1.2–2.9) vs GP2 for serious hypoglycemia
Sulfonylurea vs. Meglitinide
Wolffenbuttel, 1993 ^120^ | RCT | Glibenclamide, 15 | Repaglinide, 29 | 5 mg (esc) 15 | 0.5 mg (esc) 4 tid | Not reported
| | | | | | 1 (6.7) total for GP1
| | | | | | 0 (0) total for GP2
Landgraf, 1999 ^121^ | RCT | Glibenclamide + placebo, 100 | Repaglinide, 94 | 1.75, 3.5, 7.0, 10.5 mg (esc) 10.5 | 0.5, 1.0, 2.0, 4.0 mg (esc) 4.0 tid | Not reported | | | Other not reported
| | | | | | 9 (9.0) total for GP1 | | | 4 (4) withdrawn for GP1
| | | | | | 9 (9.6) total for GP2 | | | 2 (2.1) withdrawn for GP2
| | | | | | | | | Total adverse event
| | | | | | | | | 61 (61.0) total for GP1
| | | | | | | | | 57 (60.6) total for GP2
Vakkilainen, 2002 ^122^ | RCT | Glibenclamide + placebo, 24 | Nateglinide + placebo, 24 | 5 mg (esc) 10 | 120 tid mg (fixed) | Not reported
| | | | | | 3 (12.5) withdrawn for GP1
| | | | | | 0 (0) withdrawn for GP2
Madsbad, 2001 ^119^ | RCT | Glipizide + placebo, 81 | Repaglinide, 175 | 5 mg (esc) 15 | 0.5 mg (esc) 4.0 tid | Not reported | | | | Adverse events other than hypoglycemia
| | | | | | 0 (0) withdrawn for GP1 | | | | 9 (11.1) total for GP1
| | | | | | 0 (0) serious for GP1 | | | | 20 (11.4) total for GP2
| | | | | | 0 (0) withdrawn for GP2
| | | | | | 0 (0) serious for GP2
Wolffenbuttel, 1999 ^117^ | RCT | Glyburide (no trade drug specified) + placebo, 139 | Repaglinide, 286 | 1.75 mg (titration for 6–8 weeks then stabilized dose for 12 months) 10.5mg | 1.5 mg (titration for 6–8 weeks then stabilized dose for 12 months) 12.0 mg | Frequency of hypoglycemic reactions
| | | | | | 13 (9) total for GP1
| | | | | | 26 (9) total for GP2
Marbury, 1999 ^116^ | RCT | Glyburide (no trade drug specified) + placebo, 193 | Repaglinide, 383 | 2.5 mg (esc) 15mg | 0.5 mg (esc) 12 mg | Fsg<45mg/dl + milld-to-moderate events | | | Discontinued due to adverse events
| | | | | | 2 (1.0) withdrawn for GP1 | | | 19 (9.8) withdrawn for GP1
| | | | | | 37 (19) total for GP1 | | | 39 (10.2) withdrawn for GP2
| | | | | | 5 (1.3) withdrawn for GP2 | | | Total serious adverse events
| | | | | | 59 (15) total for GP2 | | | 12 (6) serious for GP1
| | | | | | | | | 39 (10) serious for GP2
Sulfonylurea vs. Alpha-Glucosidase Inhibitor
Feinbock, 2003 ^130^ | RCT | Glimepiride, 111 | Acarbose, 108 | 1 mg (esc) 6 | 50 mg (esc) 200 | Not reported | | Not reported
| | | | | | 20 (18) total for GP1 | | 20 (18.0) total for GP1
| | | | | | 2 (1.9) total for GP2 | | 55 (50.9) total for GP2
Sulfonylurea vs. Metformin + Sulfonylurea
Charpentier, 2001 ^89^ | RCT | Glimepiride + placebo, 150 | Metformin + glimepiride, 147 | 1 mg (either fixed or increased stepwise to 2, 4, or 6 mg od depending on clinical symptoms of hypoglycemia) | 850 mg tid (fixed) | Clinical symptoms | | Diarrhea | Unspecified adverse events
| | | | | 1 mg (either fixed or increased stepwise to 2, 4, or 6 mg od depending on clinical symptoms of hypoglycemia) | 3 (2.0) serious for GP1 | | 2 (1) total for GP1 | 8 (5.3) withdrawn for GP1
| | | | | | 20 (13) total for GP1 | | 4 (3) total for GP2 | 6 (4.1) withdrawn for GP2
| | | | | | 2 (1.4) serious for GP2
| | | | | | 32 (22) total for GP2
1998, ^128^ | RCT | Glibenclamide or chlorpropramide, 200 | Metformin + (glibenclamide or chlorpropramide), 203 | 10 bid mg (fixed) | 500 mg (titrated up to max dose) 2550 mg | Not reported | | Nausea + diarrhea + flatulence
UKPDS | | | | 500 mg (fixed) | 10 mg (fixed) | 0 (0) serious for GP1 | | 12 (6) total for GP1
| | | | | | 1 (0.3) serious for GP2 | | 53 (26) total for GP2
Marre, 2002 ^84^ | RCT | Glibenclamide, 103 | Metformin + glibenclamide, 101 | 5 mg (esc) 20 | 500 mg (esc) 2000 | Symptoms or labs | | Not reported
| | | | | 2.5 mg (esc) 10 | 1 (1.0) serious for GP1 | | 2 (1.9) serious for GP1
| | | | | | 8 (7.8) total for GP1 | | 12 (11.7) total for GP1
| | | | | | 0 (0) serious for GP2 | | 7 (6.9) total for GP2
| | | | | | 11 (10.9) total for GP2
Marre, 2002 ^84^ | RCT | Glibenclamide, 103 | Metformin + glibenclamide, 103 | 5 mg (esc) 20 | 500 mg (esc) 2000 | Symptoms or labs | | Not reported
| | | | | 5 mg (esc) 20 | 1 (1.0) serious for GP1 | | 2 (1.9) serious for GP1
| | | | | | 8 (7.8) total for GP1 | | 12 (11.7) total for GP1
| | | | | | 2 (1.9) serious for GP2 | | 19 (6.9) total for GP2
| | | | | | 14 (13.6) total for GP2
Tosi, 2003 ^95^ | RCT, cross-over | Glibenclamide, 20 | Metformin + glibenclamide, 39 | 5 mg (esc) 15 | 400 mg (esc) 2400 | Not reported | | Diarrhea + constipation + discomfort, abdominal pain, and anorexia | | ALT> 35 u/l
| | | | | 2.5 mg (esc) 15 | 1 (5) withdrawn for GP1 | | 1 (2.6) withdrawn for GP2 | | 1 (5.0) total for GP1
| | | | | | 1 (5) total for GP1 | | 1 (2.6) total for GP2 | | 0 (0) total for GP2
| | | | | | | | | | Leukopenia
| | | | | | | | | | 1 (2.6) total for GP2
Hermann, 1994 ^87^ | RCT | Glibenclamide + diet | Metformin + glibenclamide + diet | 3.5 mg (esc) 10.5 | 500 mg (esc) 3000 | Not reported | | Nausea + diarrhea + dyspepsia, digestive
| | | | | 1.75 mg (esc) 14.0 | 12 (35) serious for GP1 | | 11 (32) serious for GP1
| | | | | | 24 (33) serious for GP2 | | 25 (35) serious for GP2
Goldstein, 2003 ^82^ | RCT | Glipizide, 84 | Metformin + glipizide, 87 | 30 mg (tirated to patient glucose response) 30mg | 500/5 mg (tirated to patient glucose response 2000/20 mg | | | Diarrhea | | Lactic acidosis
| | | | | | | | 11 (13.1) total for GP1 | | 0 (0) serious for GP1
| | | | | | | | 16 (18.4) total for GP1 | | 0 (0) serious for GP2
Garber, 2002 ^79^ | RCT | Glyburide (micronase), 160 | Metformin + glyburide (micronase), 158 | 2.5 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) 10 | 250/1.25 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) | Not reported | | Nausea + vomiting + diarrhea + dyspepsia | Discontinuation due to adverse events
| | | | | | 34 (21.3) total for GP1 | | 24 IR for GP1 | 6.9 IR for GP1
| | | | | | 18 (11.4) total for GP2 | | 32 IR for GP2 | 3.8 IR for GP2
Garber, 2002 ^79^ | RCT | Glyburide (micronase), 160 | Metformin + glyburide (micronase), 162 | 2.5 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) 10 | 500/2.5 mg (increase by 1 tablet at weeks 4, 6, 8 if patients meet some criteria) | Not reported | | Nausea + vomiting + diarrhea + dyspepsia | Discontinuation due to adverse events
| | | | | | 34 (21.3) total for GP1 | | 24 IR for GP1 | 6.9 IR for GP1
| | | | | | 61 (37.7) total for GP2 | | 38 IR for GP2 | 11.1 IR for GP2
Blonde, 2002 ^81^ | RCT | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 160 | 10 mg (fixed) | 500/2.5 mg (esc) 2000/10 | Fsg<=60mg/dl + symptomatic | | Dyspepsia, heartburn | Withdrew due to unspecified adverse event | Lactic acidosis 0 (0) total for GP1
| | | | | | 3 (1.8) total for GP1 | | 5 (3) total for GP1 | 5 (3) withdrawn for GP1 | 0 (0) total for GP2
| | | | | | 22 (6.8) total for both metformin + Glyburide groups | | 8 (5) total for GP2 | 5 (3.4) withdrawn for for both metformin + Glyburide groups
| | | | | | | | Nausea + vomiting
| | | | | | | | 9 (5.5) total for GP1
| | | | | | | | 16 (10) total for GP2
| | | | | | | | Flatulence
| | | | | | | | 0 (0) total for GP1
| | | | | | | | 10 (6.3) total for GP2
Blonde, 2002 ^81^ | RCT | Glyburide (no trade drug specified), 164 | Metformin + glyburide (no trade drug specified), 162 | 10 mg (fixed) | 500/5 mg (esc) 2000/20 | Fsg<=60mg/dl + symptomatic | | Dyspepsia, heartburn | Withdrew due to unspecified adverse event | Lactic acidosis
| | | | | | 3 (1.8) total for GP1 | | 5 (3) total for GP1 | 5 (3) withdrawn for GP1 | 0 (0) total for GP1
| | | | | | 22 (6.8) total for both metformin + Glyburide groups | | 6 (3.7) total for GP2 | 5 (3.4) withdrawn for for both metformin + Glyburide groups | 0 (0) total for GP2
| | | | | | | | Nausea + vomiting
| | | | | | | | 9 (5.5) total for GP1
| | | | | | | | 11 (6.8) total for GP2
| | | | | | | | Flatulence
| | | | | | | | 0 (0) total for GP1
| | | | | | | | 4 (2.5) total for GP2
Garber, 2003 ^80^ | RCT | Glyburide (no trade drug specified), 151 | Metformin + glyburide (no trade drug specified), 171 | 2.5 (adjusted to patient response) 10 mg | 250 mg (adjusted to patient response) 1000 mg | Suggestive symptoms | | Adominal pain | | At leAST one adverse event
| | | | | 1.25 mg (esc) 5 mg | 59 (39.1) total for GP1 | | 6 (4) total for GP1 | | 114 (75.5) total for GP1
| | | | | | 98 (57.6) total for GP2 | | 7 (4.1) total for GP2 | | 134 (78.8) total for GP2
| | | | | | Fingerstick blood glucose | | nausea + vomiting
| | | | | | 16 (10.6) total for GP1 | | 10 (6.6) total for GP1
| | | | | | 19 (11.2) total for GP2 | | 8 (4.7) total for GP2
| | | | | | | | diarrhea
| | | | | | | | 8 (5.3) total for GP1
| | | | | | | | 13 (7.6) total for GP2
DeFronzo, 1995 ^88^ | RCT | Glyburide (no trade drug specified) + placebo, 209 | Metformin + glyburide (no trade drug specified), 213 | 10 mg /day in two divided dose (esc) 20mg per day in 2 divided doses | 500 mg (esc) 2500 | Not reported | | Nausea + diarrhea | | Unspecified adverse events
| | | | | 10 mg (esc) 20 | 6 (3) total for GP1 | | 2 (1.0) total for GP1 | | 6 (3) serious for GP1
| | | | | | 38 (18) total for GP2 | | 2 (1.9) total for GP2 | | 4 (2) serious for GP2
| | | | | | | | | | Treatment failure + symptomatic diabetes
| | | | | | | | | | 6 (3) serious for GP1
| | | | | | | | | | 1 (0.5) serious for GP2
1998, ^15^ | RCT | Unspecified sulfonylurea + diet, 269 | Metformin + unspecified sulfonylurea + diet, 268 | NR (NR) | NR (NR) | Death
UKPDS | | | | | NR (NR) | 0 (0) serious for GP1
| | | | | | 0 (0) serious for GP2
Gregorio, 1999 ^129^ | RCT | Metformin + glibenclamide + gliclazide, 89 | Glibenclamide + gliclazide, 85 | 850 mg (esc) 1700 | 10 mg (esc) 15 | Blood glucose <=60mg/dl or reversed by a carbohydrate snack | | Nausea + abdominal discomfort
| | | | 10 mg (esc) 15 | 120 mg (esc) 240 | 2 (2.2) total for GP1 | | 10 (11.2) total for GP1
| | | | 120 mg (esc) 240 | | 7 (8.2) total for GP2 | | 1 (1.2) total for GP2
Nichols, 2005 ^230^ | Cohort | Unspecified sulfonylurea | Metformin + unspecified sulfonylurea | NR (NR) | NR (NR) | | Medical record for CHF + icd-9 code for CHF + clinical diagnosis + first record
Kaiser Permaneante database | | | | | NR (NR) | | 13.8 (11.4–16.6) IR & 95% CI for GP1
| | | | | | | 13.4 (11.6–15.5) IR & 95% CI for GP1
Dandona, 1983 ^215^ | Cross-sectional | Unspecified sulfonylurea, 53 | Metformin + sulfonylurea, 45 | NR (NR) | NR (NR) | | | Diarrhea
| | | | | | | | 3 (6) serious for GP1
| | | | | | | | 3 (6) total for GP1
| | | | | | | | 9 (20) serious for GP2
| | | | | | | | 9 (20) total for GP2
Sulfonylurea vs. Thiazolidinedione + Sulfonylurea
Kerenyi, 2004 ^125^ | RCT | Glibenclamide + diet, 170 | Rosiglitazone + glibenclamide + diet, 165 | 7.5 mg (esc) 15 mg | 4 bid mg (fixed) | Fsg<3.1mmol/l | Chf not reported | | Withdrew due to unspecified adverse event | Elevated aminotransferase levels + liver failure + anemia
| | | | | 7.5 mg (fixed) | 0 (0) withdrawn for GP1 | 0 (0) total for GP1 | | 10 (6) withdrawn for GP1 | No clinically relevant anemia or adverse effects on liver or renal function
| | | | | | 0 (0) serious for GP1 | 2 (1.2) total for GP2 | | 17 (10) withdrawn for GP2
| | | | | | 7 (4.1) total for GP1 | Edema not reported
| | | | | | 6 (3.6) withdrawn for GP2 | 0 (0) withdrawn for GP1
| | | | | | 1 (0.6) serious for GP2 | 5 (2.9) total for GP1
| | | | | | 31 (18.5) total for GP2 | 3 (1.8) withdrawn for GP2
| | | | | | | 16 (9.5) total for GP2
Rosenstock, 2006 ^124^ | RCT | Glipizide + placebo, 111 | Rosiglitazone + glipizide, 116 | 10 mg (esc) 20 | 4 mg (fixed) | Symptomatic by patient report | Chf not reported | | Withdrawn due to unspecified adverse event | Anemia
| | | | | 10 mg (esc) 20 | 30 (27) total for GP1 | 2 (1.8) serious for GP1 | | 8 (7.2) withdrawn for GP1 | 0 (0) withdrawn for GP1
| | | | | | 1 (0.9) serious for GP2 | 3 (2.7) total for GP1 | | 11 (9.5) withdrawn for GP2 | 0 (0) withdrawn for GP2
| | | | | | 37 (32) total for GP2 | 1 (0.9) serious for GP2 | | | Hepatic enzymes >3 times the upper limit of normal level at any visit
| | | | | | | 4 (3.4) total for GP2 | | | 0 (0) total for GP1
| | | | | | | Edema not reported | | | 0 (0) total for GP2
| | | | | | | 1 (0.9) serious for GP2
Baksi, 2004 ^126^ | RCT | Gliclazide, 241 | Rosiglitazone + gliclazide, 225 | 160 mg (esc) 320 | 4 mg (fixed) | Signs or symptoms | Chf | | Total adverse events | Anemia/normal hct cut-off
| | | | | 160 mg (fixed) | 0 (0) withdrawn for GP1 | 0 (0) total for GP1 | | 15 (6.2) withdrawn for GP1 | 0 (0) withdrawn for GP1
| | | | | | 1 (0.4) serious for GP1 | 2 (0.9) total for GP2 | | 143 (59) total for GP1 | 0 (0) serious for GP1
| | | | | | 5 (2) total for GP1 | Edema | | 19 (8.4) withdrawn for GP2 | 0 (0) withdrawn for GP2
| | | | | | 1 (0.4) withdrawn for GP2 | 0 (0) withdrawn for GP1 | | 164 (71) total for GP2 | 0 (0) serious for GP2
| | | | | | 2 (1) serious for GP2 | 0 (0) serious for GP1 | | | ALT> 3 times normal
| | | | | | 14 (6) total for GP2 | 7 (3) total for GP1 | | | 1 (0.4) total for GP1
| | | | | | | 3 (1.3) withdrawn for GP2 | | | 0 (0) total for GP2
| | | | | | | 2 (1) serious for GP2
| | | | | | | 25 (11) total for GP2
Other Sulfonylurea Comparisons
Lomuscio, 1996 ^11^ | Cohort | Glibenclamide | Not glibenclamide | NR | NR | | In-hospital deaths
| | | | | | | (50) total for GP1
| | | | | | | (85) total for GP2
Chan, 2003 ^224^ | Cohort | Sulfonylurea | No sulfonylurea | NR (NR) | NR(NR) | | | | | Acute liver failure or injury
| | | | | | | | | | using claims data from 5 HMOs
| | | | | | | | | | HR 1.44 (0.59–3.50) vs GP2
Meglitinide vs. Meglitinide
Rosenstock, 2004 ^131^ | RCT | Nateglinide, 69 | Repaglinide, 71 | 60 mg (esc) 360 | 0.5 mg (esc) 16 | Fsg<50 mg/dl | | diarrhea | Withdrawn due to unspecified adverse event
| | | | | | 0 (0) serious for GP1 | | 0 (0) withdrawals for GP1 | 0 (0) withdrawn for GP1
| | | | | | 0 (0) total for GP1 | | 1 (<1) withdrawals for GP2 | 2 (2.6) withdrawn for GP2
| | | | | | 0 (0) serious for GP2
| | | | | | 5 (7) total for GP2
Thiazolidinedione vs. Placebo
Lebovitz, 2001 ^169^ | RCT | rosiglitazone, 166 | placebo, 158 | 2 mg (fixed) | NR (NR) | | edema | | | anemia/hemoglobin
| | | | | | | 10 (6.0) total for GP1 | | | -10.0g/L Hb for GP1
| | | | | | | 3 (1.9) total for GP2 | | | -2.1% Hct for GP1
Lebovitz, 2001 ^169^ | RCT | rosiglitazone, 169 | placebo, 158 | 4 mg (fixed) | NR (NR) | | edema | | | anemia/hemoglobin
| | | | | | | 18 (10.7) total for GP1 | | | -6.0g/L Hb for GP1
| | | | | | | 3 (1.9) total for GP2 | | | -0.8% Hct for GP1
| | | | | | | | | | ALT> 48 U/L
| | | | | | | | | | 1 (0.6) total for GP1
Einhorn, 2000 ^160^ | RCT | pioglitazone + existing metformin + diet, 168 | Placebo + existing metformin + diet, 160 | 30 mg (fixed) | NR (NR) | not reported | edema not reported | | | ALT exceed the upper limit of normal
| | | | NR (NR) | | 1 (0.6) total for GP1 | 10 (5.9) total for GP1 | | | 7 (4) total for GP1
| | | | | | 1 (0.6) total for GP2 | 4 (2.5) total for GP2 | | | 19 (12) total for GP2
Phillips, 2001 ^168^ | RCT | Rosiglitazone, 181 | placebo, 137 | 4 mg (fixed) | NR (NR) | | edema not reported | | | anemia/Hct + Hb
| | | | | | | 10 (5.2) total for GP1 | | | -0.5 to -0.9 g/dl Hb
| | | | | | | 1 (0.6) withdrawn for GP2 | | | -1.6 to -2.5% Hct for all rosiglitazone groups (p<0.0001)
| | | | | | | 3 (1.6) total for GP2 | | | ALT> more than three times the upper limit of the reference range
| | | | | | | | | | 0 (0) total for GP1
| | | | | | | | | | 1 (0.6) total for GP2
Phillips, 2001 ^168^ | RCT | rosiglitazone, 181 | placebo, 137 | 8 mg (fixed) | NR (NR) | | edema not reported | | | anemia/Hct + Hb
| | | | | | | 8 (4.1) total for GP1 | | | -0.5 to -0.9 g/dl Hb
| | | | | | | 1 (0.6) withdrawn for GP2 | | | -1.6 to -2.5% Hct for all rosiglitazone groups (p<0.0001)
| | | | | | | 3 (1.6) total for GP2 | | | ALT> more than three times the upper limit of the reference range
| | | | | | | | | | 0 (0) total for GP1
| | | | | | | | | | 1 (0.6) total for GP2
Phillips, 2001 ^168^ | RCT | rosiglitazone, 186 | placebo, 137 | 2 mg (fixed) | NR (NR) | | edema not reported | | | anemia/Hct + Hb
| | | | | | | 12 (6.4) total for GP1 | | | -0.5 to -0.9 g/dl Hb
| | | | | | | 1 (0.6) withdrawn for GP2 | | | -1.6 to -2.5% Hct for all rosiglitazone groups (p<0.0001)
| | | | | | | 3 (1.6) total for GP2 | | | ALT> more than 3 times the upper limit of the reference range
| | | | | | | | | | 0 (0) total for GP1
| | | | | | | | | | 1 (0.6) total for GP2
Phillips, 2001 ^168^ | RCT | rosiglitazone, 187 | placebo, 137 | 4 mg (fixed) | NR (NR) | | edema not reported | | | anemia/Hct + Hb
| | | | | | | 13 (6.6) total for GP1 | | | -0.5 to -0.9 g/dl Hb
| | | | | | | 1 (0.6) withdrawn for GP2 | | | -1.6 to -2.5% Hct for all rosiglitazone groups (p<0.0001)
| | | | | | | 3 (1.6) total for GP2 | | | ALT> more than three times the upper limit of the reference range
| | | | | | | | | | 1 (0.5) total for GP1
| | | | | | | | | | 1 (0.6) total for GP2

Table 36 Evidence Table. Quality of randomized controlled trials evaluating comparative effectiveness of oral diabetes medications on adverse events

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score
Rosenbaum, 2002 ^153^ | Yes | Not described | Yes | Not described | Yes | 3
Nishio, 2006 ^151^ | Yes | Not described | No | No | Yes | 2
Weissman, 2005 ^100^ | Yes | Not described | Yes | Yes | Yes | 4
Rosenstock, 2006 ^124^ | Yes | Not described | Yes | Not described | Yes | 3
Bailey, 2005 ^101^ | Yes | Yes | Yes | Not described | Yes | 4
Kardas, 2005 ^114^ | Yes | Not described | No | No | Yes | 2
Forst, 2005 ^145^ | Yes | Not described | No | No | No | 1
Yamanouchi, 2005 ^57^ | Yes | Yes | No | No | Yes | 3
Goldberg, 2005 ^52^ | Yes | Not described | Nr | Not described | No | 1
Pfutzner, 2005 ^68^ | Yes | Not described | No | No | No | 1
Derosa, 2005 ^53^ | Yes | Yes | Yes | Yes | Yes | 5
Derosa, 2005 ^72^ | Yes | Yes | Yes | Yes | Yes | 5
Langenfeld, 2005 ^146^ | Yes | Inappropriate | No | No | Yes | 1
Feinglos, 2005 ^104^ | Yes | Not described | Yes | Not described | Yes | 3
Goke, 2002 ^75^ | Yes | Not described | No | No | Yes | 2
Charbonnel, 2005 ^63^ | Yes | Not described | Yes | Yes | No | 3
Tan, 2005 ^61^ | Yes | Not described | Yes | Yes | Yes | 4
Cryer, 2005 ^176^ | Yes | Not described | No | No | Yes | 2
McCluskey, 2004 ^76^ | Yes | Not described | Yes | Not described | Yes | 3
Schernthaner, 2004 ^56^ | Yes | Yes | Yes | Yes | Yes | 5
Smith, 2005 ^161^ | Yes | Not described | Yes | Yes | No | 3
Choi, 2004 ^77^ | Yes | Not described | No | No | Yes | 2
Matthews, 2005 ^70^ | Yes | Not described | Yes | Yes | Yes | 4
Derosa, 2004 ^90^ | Yes | Not described | No | No | Yes | 2
Schernthaner, 2004 ^106^ | Yes | Yes | Nr | Not described | Yes | 3
Tan, 2004 ^65^ | Yes | Not described | Nr | Not described | Yes | 2
Baksi, 2004 ^126^ | Yes | Not described | Yes | Not described | Yes | 3
Tan, 2004 ^69^ | Yes | Not described | Yes | Not described | Yes | 3
Saad, 2004 ^164^ | Yes | Not described | No | No | Yes | 2
Rosenstock, 2004 ^131^ | Yes | Not described | No | No | Yes | 2
Raskin, 2004 ^74^ | Yes | Not described | Nr | No | Yes | 2
Manzella, 2004 ^148^ | Yes | Not described | No | No | Yes | 2
Feinbock, 2003 ^130^ | Yes | Not described | No | No | Yes | 2
Kerenyi, 2004 ^125^ | Yes | Not described | Yes | Yes | Yes | 4
Jovanovic, 2004 ^73^ | Yes | Not described | No | No | Yes | 2
Hanefeld, 2004 ^60^ | Yes | Not described | Yes | Yes | No | 3
Lawrence, 2004 ^54^ | Yes | Not described | No | No | Yes | 2
Garber, 2003 ^80^ | Yes | Yes | Yes | Yes | Yes | 5
Takagi, 2003 ^78^ | Yes | Not described | No | No | No | 1
Tosi, 2003 ^95^ | Yes | Not described | Yes | Yes | Yes | 4
Goldstein, 2003 ^82^ | Yes | Yes | No | No | Yes | 3
Herz, 2003 ^163^ | Yes | Not described | Yes | Not described | Yes | 3
Derosa, 2003 ^97^ | Yes | Not described | No | No | Yes | 2
Barnett, 2003 ^172^ | Yes | Not described | Yes | Yes | Yes | 4
Fujioka, 2003 ^105^ | Yes | Not described | Yes | Yes | Yes | 4
Del Prato, 2003 ^149^ | Yes | Not described | Yes | Yes | Yes | 4
Pavo, 2003 ^59^ | Yes | Not described | Yes | Not described | Yes | 3
Luis Bautista, 2003 ^193^ | Yes | Not described | Yes | Yes | Yes | 4
Vongthavaravat, 2002 ^170^ | Yes | Yes | No | No | No | 2
Virtanen, 2003 ^143^ | Yes | Not described | Nr | Not described | Yes | 2
Vakkilainen, 2002 ^122^ | Yes | Not described | Yes | Yes | Yes | 4
Cefalu, 2002 ^323^ | Yes | Not described | No | No | Yes | 2
Hallsten, 2002 ^58^ | Yes | Not described | No | No | Yes | 2
Scherbaum, 2002 ^141^ | Yes | Not described | Yes | Not described | Yes | 3
Blonde, 2002 ^81^ | Yes | Not described | Yes | Not described | Yes | 3
St John Sutto, 2002 ^67^ | Yes | Not described | No | No | Yes | 2
Rachmani, 2002 ^150^ | Yes | Yes | No | No | Yes | 3
Saloranta, 2002 ^241^ | Yes | Not described | Yes | Yes | Yes | 4
Marre, 2002 ^84^ | Yes | Not described | Yes | Not described | Yes | 3
Garber, 2002 ^79^ | Yes | Not described | Yes | Yes | Yes | 4
Gomez-Perez, 2002 ^102^ | Yes | Not described | Yes | Not described | Yes | 3
Charpentier, 2001 ^89^ | Yes | Not described | Yes | Not described | Yes | 3
Rosenblatt, 2001 ^162^ | Yes | Yes | Yes | Not described | Yes | 4
Madsbad, 2001 ^119^ | Yes | Not described | Yes | Not described | Yes | 3
Kipnes, 2001 ^166^ | Yes | Not described | Yes | Not described | Yes | 3
Amador-Licona, 2000 ^85^ | Yes | Not described | No | No | Yes | 2
Lebovitz, 2001 ^169^ | Yes | Not described | No | No | No | 1
Patel, 1999 ^167^ | Yes | Inappropriate | Yes | Not described | Yes | 2
Phillips, 2001 ^168^ | Yes | Not described | Yes | Not described | Yes | 3
Moses, 2001 ^218^ | Yes | Not described | Yes | Not described | Yes | 3
Einhorn, 2000 ^160^ | Yes | Not described | Yes | Not described | Yes | 3
Fonseca, 2000 ^103^ | Yes | Yes | Yes | Yes | Yes | 5
Horton, 2000 ^96^ | Yes | Not described | Yes | Yes | Yes | 4
Aronoff, 2000 ^165^ | Yes | Not described | Yes | Not described | No | 2
Hanefeld, 2000 ^190^ | Yes | Not described | Yes | Yes | No | 3
King, 2000 ^142^ | Yes | Inappropriate | No | No | No | 0
Hasche, 1999 ^138^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 2000 ^171^ | Yes | Not described | Yes | Not described | No | 2
Gregorio, 1999 ^129^ | Yes | Yes | No | No | Yes | 3
Jovanovic, 2000 ^194^ | Yes | Yes | Yes | Yes | Yes | 5
Willms, 1999 ^99^ | Yes | Not described | Yes | Yes | Yes | 4
Erle, 1999 ^127^ | Yes | Not described | Yes | Not described | Yes | 3
Landgraf, 1999 ^121^ | Yes | Not described | Yes | Yes | Yes | 4
Marbury, 1999 ^116^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 1999 ^117^ | Yes | Not described | Yes | Yes | Yes | 4
Testa, 1998 ^198^ | Yes | Not described | Yes | Not described | Yes | 3
Goldberg, 1998 ^139^ | Yes | Not described | Yes | Not described | Yes | 3
1998, ^15^ | Yes | Not described | No | No | Yes | 2
1998, ^16^ | Yes | Yes | No | No | No | 2
Schade, 1998 ^135^ | Yes | Not described | Yes | Not described | Yes | 3
1998, ^128^ | Yes | Not described | No | No | No | 1
Lee, 1998 ^259^ | Yes | Not described | Yes | Yes | Yes | 4
Simonson, 1997 ^136^ | Yes | Not described | Yes | Not described | Yes | 3
Rosenstock, 1996 ^189^ | Yes | Not described | Yes | Not described | Yes | 3
Dills, 1996 ^107^ | Yes | Not described | Yes | Not described | Yes | 3
Goldberg, 1996 ^134^ | Yes | Not described | Yes | Not described | Yes | 3
Grant, 1996 ^154^ | Yes | Not described | Yes | Not described | No | 2
Vray, 1995 ^137^ | Yes | Not described | Yes | Not described | Yes | 3
DeFronzo, 1995 ^88^ | Yes | Not described | Yes | Yes | Yes | 4
1995, ^92^ | Yes | Not described | No | No | No | 1
Hermann, 1994 ^87^ | Yes | Yes | Yes | Yes | No | 4
Birkeland, 1994 ^110^ | Yes | Not described | Yes | Yes | Yes | 4
Rosenstock, 1993 ^109^ | Yes | Not described | No | No | Yes | 2
Carlson, 1993 ^108^ | Yes | Not described | Yes | Not described | Yes | 3
Wolffenbuttel, 1993 ^120^ | Yes | Yes | No | No | Yes | 3
Teupe, 1991 ^155^ | Yes | Not described | No | No | Yes | 2
Noury, 1991 ^86^ | Yes | Not described | Nr | No | Yes | 2
Hermann, 1991 ^94^ | Yes | Yes | Yes | Yes | No | 4
Schneider, 1991 ^173^ | Yes | Inappropriate | Yes | Not described | Yes | 2
Hermann, 1991 ^159^ | Yes | Not described | Yes | Not described | Yes | 3
Dornan, 1991 ^260^ | Yes | Not described | Yes | Not described | No | 2
Kilo, 1988 ^147^ | Yes | Not described | No | No | No | 1
Baba, 1983 ^133^ | Yes | Not described | Yes | Not described | Yes | 3
Tseng, 2005 ^140^ | Yes | Not described | Yes | Not described | No | 2
Turner, 1998 ^93^ | Yes | Not described | No | No | Yes | 2
Garber, 2006 ^71^ | Yes | Not described | Yes | Yes | Yes | 4
Ko, 2003 ^328^ | Yes | Inappropriate | Yes | Not described | Yes | 2
Derosa, 2003 ^118^ | Yes | Yes | Yes | Yes | Yes | 5
Zhu, 2003 ^188^ | Yes | Yes | Yes | Not described | Yes | 4
Rosenstock, 2002 ^330^ | Yes | Not described | Yes | Yes | Yes | 4
Garber, 1997 ^217^ | Yes | Not described | Yes | Yes | Yes | 4
Sonnenberg, 1997 ^191^ | Yes | Not described | Yes | Not described | Yes | 3
Draeger, 1996 ^112^ | Yes | Not described | No | No | Yes | 2