# Appendix E Sample Forms

SRS Form