# Appendix D Excluded Articles

## List of Excluded Articles

### Systematic Reviews

Aronow W S. Oral sulfonylureas and CV mortality. Geriatrics 2004;59(9):45–6, 49. Does not include a systematic review/meta-analysis
Baba S. (2001). Pioglitazone: a review of Japanese clinical studies. Curr Med Res Opin.
Bailey CJ, Turner RC. (1996). Metformin. N Engl J Med.
Bailey C J. Antidiabetic drugs. Br. J. Cardiol. 2000;7(6):350+352, 353+356–360. Does not include a systematic review/meta-analysis
Bailey CJ. (88). Metformin revisited: its actions and indications for use. Diabet Med.
Baynes C, Feher MD, Elkeles RS. (89). The effect of treatment of non-insulin-dependent diabetes mellitus (NIDDM) on serum lipids and lipoproteins. Q J MED.
Belcher G, Lambert C, Goh KL, et al. (2004). Cardiovascular effects of treatment of type 2 diabetes with pioglitazone, metformin and gliclazide. Int J Clin Pract.
Bell DSH. (2002). Current status of diabetes treatment. South Med J.
Bell DSH. (1997). Diabetes mellitus and coronary artery disease. J CARDIOVASC RISK.
Bell DSH. (2004). Secretagogues and Cardiac Risk. Endocrinologist.
Bell DS. (2004). Practical considerations and guidelines for dosing sulfonylureas as monotherapy or combination therapy. Clin Ther.
Binder C, Bendtson I. (1992). Hypoglycaemia. BAILLIERE''S CLIN ENDOCRINOL METAB.
Bloomgarden ZT. (2004). Glycemic treatment: Control of glycemia. Diabetes Care.
Bloomgarden ZT. (1996). New and traditional treatment of glycemia in NIDDM. DIABETES CARE.
Bloomgarden ZT. (2003). Pharmacologic treatment of type 2 diabetes. Diabetes Care.
Bloomgarden ZT. (2005). Thiazolidinediones. Diabetes Care.
Braunstein S. (2003). New developments in type 2 diabetes mellitus: combination therapy with a thiazolidinedione. Clin Ther.
Bressler R, Johnson DG. (1997). Pharmacological regulation of blood glucose levels in non-insulin-dependent diabetes mellitus. Arch Intern Med.
Brown DL, Brillon D. (1999). New directions in type 2 diabetes mellitus: an update of current oral antidiabetic therapy. J Natl Med Assoc.
Burge MR, Sood V, Sobhy TA, et al. (1999). Sulphonylurea-induced hypoglycaemia in type 2 diabetes mellitus: a review. Diabetes Obes Metab.
Campbell IW. (2004). Long-term glycaemic control with pioglitazone in patients with type 2 diabetes. Int J Clin Pract.
Carlsen SM, Folling I. (1994). Metformin reevaluated - Time for rehabilitation?: METFORMIN REVURDERT - TID FOR REHABILITERING?. TIDSSKR NOR LAEGEFOREN.
Cerveny JD, Leder RD, Weart CW. (1998). Issues surrounding tight glycemic control in people with type 2 diabetes mellitus. Ann Pharmacother.
Chang CT, Chen YC, Fang JT, et al. (2002). Metformin-associated lactic acidosis: case reports and literature review. J Nephrol.
Cheng-Lai A, Levine A. (2000). Rosiglitazone: an agent from the thiazolidinedione class for the treatment of type 2 diabetes. Heart Dis.
Chilton R, Chiquette E. (2005). Thiazolidinediones and cardiovascular disease. Curr Atheroscler Rep.
Clark CM, Helmy AW. (1998). Clinical trials with glimepiride. Drugs Today.
Coniff R, Krol A. (1997). Acarbose: a review of US clinical experience. Clin Ther.
Conn J, Betteridge DJ. (1998). Insulin resistance in cardiovascular disease. Br J Cardiol.
Cox SL. (2004). Rosiglitazone maleate/metformin hydrochloride: a new formulation therapy for type 2 diabetes. Drugs Today (Barc).
Dandona P, Aljada A. (2002). A rational approach to pathogenesis and treatment of type 2 diabetes mellitus, insulin resistance, inflammation, and atherosclerosis. Am J Cardiol.
Davidson JA, Scheen AJ, Hewlett HCS. (2004). Tolerability profile of metformin/glibenclamide combination tablets (Glucovance(registered trademark)): A new treatment for the management of type 2 diabetes mellitus. Drug Saf.
Del Prato S, Aragona M, Coppelli A. (2002). Sulfonylureas and hypoglycaemia. Diabetes Nutr Metab.
Del Prato S, Heine RJ, Keilson L, et al. (2003). Treatment of patients over 64 years of age with type 2 diabetes: experience from nateglinide pooled database retrospective analysis. Diabetes Care.
Delorme S, Chiasson JL. (2005). Acarbose in the prevention of cardiovascular disease in subjects with impaired glucose tolerance and type 2 diabetes mellitus. Curr Opin Pharmacol.
Ebell MH. (2005). Insulin monotherapy vs. combination therapy. Am Fam Physician.
Edelman SV. (1998). Importance of glucose control. Med Clin North Am.
Feldman JM. (85). Glyburide: a second-generation sulfonylurea hypoglycemic agent. History, chemistry, metabolism, pharmacokinetics, clinical use and adverse effects. Pharmacotherapy.
Fisman EZ, Tenenbaum A, Motro M, et al. (2004). Oral antidiabetic therapy in patients with heart disease. A cardiologic standpoint. Herz.
Freemantle N. (2005). How well does the evidence on pioglitazone back up researchers'' claims for a reduction in macrovascular events?. BMJ.
Fuchtenbusch M, Standl E, Schatz H. (2000). Clinical efficacy of new thiazolidinediones and glinides in the treatment of type 2 diabetes mellitus. Exp Clin Endocrinol Diabetes.
Gale E. (1999). Glimepiride: Review of the first available 3rd generation sulphonylurea. Pract Diabetes Int.
Gan SC, Barr J, Arieff AI, et al. (1992). Biguanide-associated lactic acidosis. Case report and review of the literature. Arch Intern Med.
Garber A, Marre M, Blonde L, et al. (2003). Influence of initial hyperglycaemia, weight and age on the blood glucose lowering efficacy and incidence of hypoglycaemic symptoms with a single-tablet metformin-glibenclamide therapy (Glucovance) in type 2 diabetes. Diabetes Obes Metab.
Gerich JE. (89). Oral hypoglycemic agents. NEW ENGL J MED.
Ghosh J, Weiss MB, Kay RH, et al. (2003). Diabetes mellitus and coronary artery disease: Therapeutic considerations. Heart Dis.
Gillies PS, Dunn CJ. (2000). Pioglitazone. Drugs.
Goldenberg MM. (2000). Rosiglitazone for the treatment of type 2 diabetes mellitus. P T.
Goldstein BJ. (2002). Differentiating members of the thiazolidinedione class: a focus on efficacy. Diabetes Metab Res Rev.
Goldstein BJ. (2000). Rosiglitazone. Int J Clin Pract.
Goodarzi MO, Bryer-Ash M. (2005). Metformin revisited: re-evaluation of its properties and role in the pharmacopoeia of modern antidiabetic agents. Diabetes Obes Metab.
Grant PJ. (1995). The effects of metformin on cardiovascular risk factors. Diabetes Metab Rev.
Grossman LD. (2002). New solutions for type 2 diabetes mellitus: the role of pioglitazone. Pharmacoeconomics.
Guthrie R. (1997). Treatment of non-insulin-dependent diabetes mellitus with metformin. J Am Board Fam Pract.
Hanefeld M, Belcher G. Safety profile of pioglitazone. Int. J. Clin. Pract. Suppl. 2001;-(121):27–31. Does not include a systematic review/meta-analysis
Hanefeld M, Cagatay M, Petrowitsch T, et al. (2004). Acarbose reduces the risk for myocardial infarction in type 2 diabetic patients: meta-analysis of seven long-term studies. Eur Heart J.
Hanefeld M, Temelkova-Kurktschiev T, Kohler C. Effect of oral antidiabetics and insulin on lipids and coronary heart disease in non-insulin-dependent diabetes mellitus. Ann N Y Acad Sci 1997;827246–68. Does not include a systematic review/meta-analysis
Hanefeld M. (2005). Outcome studies in type 2 diabetes. Curr Med Res Opin.
Hanefeld M. (1998). The role of acarbose in the treatment of non-insulin-dependent diabetes mellitus. J Diabetes Complications.
Hermann LS, Lindberg G, Lindblad U, et al. (2002). Efficacy, effectiveness and safety of sulphonylurea-metformin combination therapy in patients with type 2 diabetes. Diabetes Obes Metab.
Isley WL, Oki JC. (2001). Hepatotoxicity of thiazolidinediones. Diab Obesity Metabol.
Jones TA, Sautter M, Van Gaal LF, et al. (2003). Addition of rosiglitazone to metformin is most effective in obese, insulin-resistant patients with type 2 diabetes. Diabetes Obes Metab.
Kanzer-Lewis G. Early combination therapy with a thiazolidinedione for the treatment of type 2 diabetes. Diabetes Educ 2003;29(6):954–8, 961. Does not include a systematic review/meta-analysis
Killilea T. (2002). Long-term consequences of type 2 diabetes mellitus: economic impact on society and managed care. Am J Manag Care.
Kilo C. (1997). Metformin: a safe and effective treatment in the management of NIDDM. Mo Med.
Kirpichnikov D, McFarlane SI, Sowers JR. (2002). Metformin: an update. Ann Intern Med.
Kirwin J, Van Amburgh J. (2005). Muraglitazar: A dual peroxisome proliferator-activated receptor agonist. Formulary.
Klepser TB, Kelly MW. (1997). Metformin hydrochloride: an antihyperglycemic agent. Am J Health Syst Pharm.
Klonoff DC, Barrett BJ, Nolte MS, et al. (1995). Hypoglycemia following inadvertent and factitious sulfonylurea overdosages. DIABETES CARE.
Klonoff DC. (88). Association of hyperinsulinemia with chlorpropamide toxicity. Am J Med.
Krentz AJ, Ferner RE, Bailey CJ. (1994). Comparative tolerability profiles of oral antidiabetic agents. Drug Saf.
Lalau JD, Race JM. (2000). Metformin and lactic acidosis in diabetic humans. Diabetes Obes Metab.
Laube H. (2002). Acarbose: An update of its therapeutic use in diabetes treatment. Clin Drug Invest.
Lawrence JM, Reckless JP. (2000). Pioglitazone. Int J Clin Pract.
Lebovitz HE. (2002). Differentiating members of the thiazolidinedione class: a focus on safety. Diabetes Metab Res Rev.
Leonhardt W, Hanefeld M, Fischer S, et al. (1994). Efficacy of alpha-glucosidase inhibitors on lipids in NIDDM subjects with moderate hyperlipidaemia. Eur J Clin Invest.
Lester JW, Fernandes AW. (2005). Pioglitazone in a subgroup of patients with type 2 diabetes meeting the criteria for metabolic syndrome. Int J Clin Pract.
Lester JW, Fernandes AW. (2005). Pioglitazone in a subgroup of patients with type 2 diabetes meeting the criteria for metabolic syndrome. Int J Clin Pract.
Lynch JC. (1999). Drug therapy for type 2 diabetes. J Pharm Pract.
Malinowski JM, Bolesta S. (2000). Rosiglitazone in the treatment of type 2 diabetes mellitus: a critical review. Clin Ther.
Massi-Benedetti M. (2003). Glimepiride in type 2 diabetes mellitus: a review of the worldwide therapeutic experience. Clin Ther.
Meta-analysis shows: insulin sensitizer is safe for the liver: METAANALYSE ZEIGT: INSULINSENSITIZER SICHER FUR DIE LEBER.. MMW Fortschr Med 2002;144(40):47. Not in English
Metelko Z, Pavlic-Renar I, Novak B, et al. (2000). Prandial regulation of glycemia. Diabetol Croat.
Metformin. PHASE III DRUG PROFILES 1994;4(2):1–15. Does not include a systematic review/meta-analysis
Moses R. (2002). Repaglinide in combination therapy. Diabetes Nutr Metab.
Mudaliar S, Chang AR, Henry RR. (2003). Thiazolidinediones, peripheral edema, and type 2 diabetes: incidence, pathophysiology, and clinical implications. Endocr Pract.
Mudaliar S, Henry RR. (1999). Combination therapy for type 2 diabetes. Endocr Pract.
Nathan DM. (2002). Initial management of glycemia in type 2 diabetes mellitus. New Engl J Med.
Neeser K, Lubben G, Siebert U, et al. (2004). Cost effectiveness of combination therapy with pioglitazone for type 2 diabetes mellitus from a german statutory healthcare perspective. Pharmacoeconomics.
Noble J, Baerlocher M O, Silverberg J. Management of type 2 diabetes mellitus. Role of thiazolidinediones. Can Fam Physician 2005;51683–7. Other (no inclusion/exclusion criteria). Does not include a systematic review/meta-analysis
O'Connor PJ, Spann SJ, Woolf SH. (1998). Care of adults with type 2 diabetes mellitus. A review of the evidence. J Fam Pract.
Oliver A, Pritchard C. (2000). Economic evaluations relating to diabetes: A descriptive review and their compliance with guidance. Value Health.
Oliver A, Pritchard C. (2000). Economic evaluations relating to diabetes: A descriptive review and their compliance with guidance. Value Health.
Omari A, Yue DK, Twigg SM. (2005). Exercise, metformin and hypoglycaemia: A neglected entity. Br J Diabetes Vasc Dis.
O'Meara NM, Shapiro ET, Van Cauter E, et al. (1990). Effect of glyburide on beta cell responsiveness to glucose in non-insulin-dependent diabetes mellitus. Am J Med.
Owens DR, McDougall A. (2000). Repaglinide: prandial glucose regulation in clinical practice. Diabetes Obes Metab.
Owens DR. (1998). Repaglinide—prandial glucose regulator: a new class of oral antidiabetic drugs. Diabet Med.
Page RL, Gozansky WS, Ruscin JM. (2003). Possible heart failure exacerbation associated with rosiglitazone: case report and literature review. Pharmacotherapy.
Palmer AJ, Valentine WJ, Ray JA. (2004). Thiazolidinediones for diabetes mellitus: Considerations for reimbursements by third-party payers. Dis Manage Health Outcomes.
Parulkar AA, Pendergrass ML, Granda-Ayala R, et al. (2001). Nonhypoglycemic effects of thiazolidinediones. Ann Intern Med.
Patel C, Wyne KL, McGuire DK. (2005). Thiazolidinediones, peripheral oedema and congestive heart failure: What is the evidence?. Diabets Vasc Dis Res.
Pendergrass M, Johnson J. (2001). Pathophysiology and management of type 2 diabetes. Cardiovasc Rev Rep.
Plosker GL, Figgitt DP. (2004). Repaglinide: a pharmacoeconomic review of its use in type 2 diabetes mellitus. Pharmacoeconomics.
Pontiroli AE, Calderara A, Pozza G. (1994). Secondary failure of oral hypoglycaemic agents: frequency, possible causes, and management. Diabetes Metab Rev.
Prendergast BD. (84). Glyburide and glipizide, second-generation oral sulfonylurea hypoglycemic agents. Clin Pharm.
Raikou M, McGuire A. (2003). The economics of screening and treatment in type 2 diabetes mellitus. Pharmacoeconomics.
Rendell MS, Kirchain WR. (2000). Pharmacotherapy of type 2 diabetes mellitus. Ann Pharmacother.
Reusch JE, Gadsby R. (2003). Thiazolidinedione therapy: the benefits of aggressive and early use in type 2 diabetes. Diabetes Technol Ther.
Rosskamp R. (1996). Safety aspects of oral hypoglycaemic agents. Diabetologia.
Saenz Calvo A, Fernandez Esteban I, Mataix Sanjuan A, et al. (2005). [Metformin for type-2 diabetes mellitus. Systematic review and meta-analysis]. Aten Primaria.
Salpeter SR, Greyber E, Pasternak GA, et al. (2004). Review: Metformin does not increase risk of lactic acidosis or increase lactate levels in type 2 diabetes. Evid-Based Med.
Schafers RF. (2003). Do effects on blood pressure contribute to improved clinical outcomes with metformin?. Diabetes Metab.
Schatz H. (2005). Glitazone outcome studies on progression of type 2 diabetes and cardiovascular endpoints: STUDIEN ZUR WIRKUNG VON GLITAZONEN AUF DIE PROGRESSION DES TYP-2-DIABETES UND AUF KARDIOVASKULARE ENDPUNKTE. Dtsch Med Wochenschr.
Schatz H. (1999). Preclinical and clinical studies on safety and tolerability of repaglinide. Exp Clin Endocrinol Diabetes.
Scheen AJ. (1998). Clinical efficacy of acarbose in diabetes mellitus: a critical review of controlled trials. Diabetes Metab.
Scheen AJ. (2001). Hepatotoxicity with thiazolidinediones: is it a class effect?. Drug Saf.
Scheen AJ. (2001). Thiazolidinediones and liver toxicity. Diabetes Metab.
Schernthaner G. (1994). Clinical importance of metformin in the treatment of type-2 diabetes mellitus: Effect on insulin resistance, diabetes control, and cardiovascular risk factors: DIE BEDEUTUNG VON METFORMIN IN DER THERAPIE DES TYP-2-DIABETES: EFFEKT AUF INSULINRESISTENZ, DIABETESEINSTELLUNG UND KARDIOVASKULARE RISIKOFAKTOREN. WIEN KLIN WOCHENSCHR.
Schneider HL, Hornbach KD, Kniaz JL, et al. (84). Chlorpropamide hepatotoxicity: report of a case and review of the literature. Am J Gastroenterol.
Schneider J. (1996). An overview of the safety and tolerance of glimepiride. Horm Metab Res.
Setter SM, Iltz JL, Thams J, et al. (2003). Metformin hydrochloride in the treatment of type 2 diabetes mellitus: a clinical review with a focus on dual therapy. Clin Ther.
Seufert J, Lubben G, Dietrich K, et al. (2004). A comparison of the effects of thiazolidinediones and metformin on metabolic control in patients with type 2 diabetes mellitus. Clin Ther.
Shaughnessy AF, Slawson DC. (2003). What happened to the valid POEMs? A survey of review articles on the treatment of type 2 diabetes. BMJ.
Sirtori CR, Pasik C. (1994). Re-evaluation of a biguanide, metformin: mechanism of action and tolerability. Pharmacol Res.
Smith SI. (2004). PPAR-gamma receptor agonists—a review of their role in diabetic management in Trinidad and Tobago. Mol Cell Biochem.
Sood V, Colleran K, Burge MR. (2000). Thiazolidinediones: a comparative review of approved uses. Diabetes Technol Ther.
Stamm PL, Kelley KW, Donaldson AR. (2005). Minimizing cardiovascular morbidity and mortality in patients with type 2 diabetes mellitus: A literature review. Adv Pharm.
Stolar MW, Chilton RJ. (2003). Type 2 diabetes, cardiovascular risk, and the link to insulin resistance. Clin Ther.
Tan MH. (2003). Thiazolidinediones: Effect of the pioglitazone on hyperglycemia, dyslipidemia and cardiovascular risk: TIAZOLIDINADIONAS: EFECTO DE LA PIOGLITAZONA SOBRE LA HIPERGLUCEMIA, LA DISLIPIDEMIA Y EL RIESGO CARDIOVASCULAR. Rev Clin Esp.
Tessier D. (2005). Stepwise Approach to the treatment of diabetes in the older adult. Geriatr Aging.
The pharmacological treatment of hyperglycemia in NIDDM. American Diabetes Association. Diabetes Care 1995;18(11):1510–8. Does not include a systematic review/meta-analysis
Tolman KG, Chandramouli J. (2003). Hepatotoxicity of the thiazolidinediones. Clin Liver Dis.
Van Basten JP, Van Hoek B, Zeijen R, et al. (1992). Glyburide-induced cholestatic hepatitis and liver failure. Case-report and review of the literature. NETH J MED.
Verges B. (2005). Diabetic dyslipidaemia: insights for optimizing patient management. Curr Med Res Opin.
Vijan S, Stevens DL, Herman WH, et al. (1997). Screening, prevention, counseling, and treatment for the complications of type II diabetes mellitus: Putting evidence into practice. J GEN INTERN MED.
Wagstaff AJ, Goa KL. (2002). Rosiglitazone: a review of its use in the management of type 2 diabetes mellitus. Drugs.
Wallace TM, Matthews DR. (2000). Assessment of the effects of insulin secretagogues in humans. Diabetes Obes Metab.
Wang CH, Weisel RD, Liu PP, et al. (2003). Glitazones and heart failure: Critical appraisal for the clinician. Circulation.
Wang F, Aleksunes LM, Reagan LA, et al. (2002). Management of rosiglitazone-induced edema: two case reports and a review of the literature. Diabetes Technol Ther.
Wang F. (1998). Focus on repaglinide: An oral hypoglycemic agent with a more rapid onset and shorter duration of action than the sulfonylureas. Formulary.
Ward A, O'Brien J, Salas M. (2005). Cost-effectiveness of oral hypoglycaemic agents for the treatment of type 2 diabetes mellitus. Expert Opin Pharmacother.
Werner AL, Travaglini MT. (2001). A review of rosiglitazone in type 2 diabetes mellitus. Pharmacotherapy.
Wiles PG, Pyke DA. (84). The chlorpropamide alcohol flush. Clin Sci (Lond).
Williams G. (1994). Management of non-insulin-dependent diabetes mellitus. Lancet.
Wolffenbuttel BH, Sels JP, Huijberts MS. (2001). Rosiglitazone. Expert Opin Pharmacother.
Yates S W. Comparative effects of available thiazolidinediones: A review of the literature. P T 2004;29(9):584–588+590. Does not include a systematic review/meta-analysis
Yki-Jarvinen H. (2004). Thiazolidinediones. N Engl J Med.
Zhao HL, Thomas GN, Leung W, et al. (2003). An update on the management of nephropathy in type 2 diabetes. J Chin Med Assoc.
Zinman B. (2001). PPAR gamma agonists in type 2 diabetes: how far have we come in “preventing the inevitable”? A review of the metabolic effects of rosiglitazone. Diabetes Obes Metab.

### Primary Data

Abbasi F, Kamath V, Rizvi AA, et al. (97). Results of a placebo-controlled study of the metabolic effects of the addition of metformin to sulfonylurea-treated patients. Evidence for a central role of adipose tissue. Diabetes Care.
Actos(registered trademark) may reduce heart attack and stroke in patients with type diabetes. Exp. Rev. Cardiovasc. Ther. 2005;3(6):981–982 Not an original article
Agardh E, Agardh CD, Koul S, et al. (94). A four-year follow-up study on the incidence of diabetic retinopathy in older onset diabetes mellitus. Diabet Med.
Aguilar C, Reza A, Garcia JE, et al. (92). Biguanide related lactic acidosis: incidence and risk factors. Arch Med Res.
Allen BT, Feinglos MN, Lebovitz HE. (85). Treatment of poorly regulated non-insulin-dependent diabetes mellitus with combination insulin-sulfonylurea. Arch Intern Med.
Bastyr EJ, Stuart CA, Brodows RG. (2001). Targeting postprandial blood glucose concentrations reduced haemoglobin A1c concentrations in type 2 diabetes mellitus. Evid-Based Med.
Belcher G, Lambert C, Goh KL, et al. (2004). Cardiovascular effects of treatment of type 2 diabetes with pioglitazone, metformin and gliclazide. Int J Clin Pract.
Ben-Ami H, Nagachandran P, Mendelson A, et al. (99). Glibenclamide-induced hypoglycemic coma in 51 older patients with type 2 diabetes mellitus. J Am Geriatr Soc.
Berger M, Muhlhauser I, Sawicki PT. (98). Possible risk of sulphonylureas in the treatment of non-insulin- dependent diabetes mellitus and coronary artery disease [5]. Diabetologia.
Berger W. Incidence of severe sideeffects during therapy with sulfonylureas and biguanides. Horm Metab Res Suppl 85;15111–5 Not an original article
Blickle JF, Brogard JM. (91). (alpha)-Glucosidase inhibitors - A new approach to the treatment of diabetes. EUR J INTERN MED.
Blonde L, Joyal S, Henry D, et al. (2004). Durable efficacy of metformin/glibenclamide combination tablets (Glucovance) during 52 weeks of open-label treatment in type 2 diabetic patients with hyperglycaemia despite previous sulphonylurea monotherapy. Int J Clin Pract.
Brady PA, Al-Suwaidi J, Kopecky SL, et al. (98). Sulfonylureas and mortality in diabetic patients after myocardial infarction. Circulation.
Brown JB, Pedula K, Barzilay J, et al. (98). Lactic acidosis rates in type 2 diabetes. Diabetes Care.
Brown RR. (98). Cost-effectiveness and clinical outcomes of metformin or insulin add-on therapy in adults with type 2 diabetes. Am J Health Syst Pharm.
Burge MR, Schmitz-Fiorentino K, Sood V, et al. (99). Effect of immediate-release glipizide on hypoglycemic vulnerability in fasted, elderly patients with type 2 diabetes. JAMA.
Buse JB, Rubin CJ, Frederich R, et al. (2005). Muraglitazar, a dual (alpha/gamma) PPAR activator: A randomized, double-blind, placebo-controlled, 24-week monotherapy trial in adult patients with type 2 diabetes. Clin Ther.
Buse J, Hart K, Minasi L. (98). The PROTECT Study: final results of a large multicenter postmarketing study in patients with type 2 diabetes. Precose Resolution of Optimal Titration to Enhance Current Therapies. Clin Ther.
Campbell IW, Chalmers J, Herlihy OM. (94). Sulphonylurea-induced hypoglycaemia in elderly people with diabetes. PRACT DIABETES.
Cardiovascular risk reduction with pioglitazone. Cardiovasc J S Afr 2002;13(4):218 Not an original article
Chan NN, Feher MD. (99). Metformin and perioperative risk [9]. Br J Anaesth.
Choe HM, Cornish L, Townsend K, et al. (2004). Monitoring safety and effectiveness in patients receiving metformin. Am J Health Syst Pharm.
Clarke BF, Campbell IW. (75). Long-term comparative trial of glibenclamide and chlorpropamide in diet-failed, maturity-onset diabetics. Lancet.
Clarke PM, Gray AM, Briggs A, et al. (2005). Cost-utility analyses of intensive blood glucose and tight blood pressure control in type 2 diabetes (UKPDS 72). Diabetologia.
Corsonello A, Pedone C, Corica F, et al. (99). Antihypertensive drug therapy and hypoglycemia in elderly diabetic patients treated with insulin and/or sulfonylureas. Gruppo Italiano di Farmacovigilanza nell'Anziano (GIFA). Eur J Epidemiol.
Crandall J, Barzilai N. (2003). Treatment of diabetes mellitus in older people: oral therapy options. J Am Geriatr Soc.
Dailey GE, Noor MA, Park JS, et al. (2004). Glycemic control with glyburide/metformin tablets in combination with rosiglitazone in patients with type 2 diabetes: a randomized, double-blind trial. Am J Med.
Dasgupta K, Grover SA, Lowensteyn I, et al. (2005). Sulfonylurea use associated with reduction in blood glucose levels during exercise stress testing. J Cardiopulm Rehabil.
Davidson J, Howlett H. (2004). New prolonged-release metformin improves gastrointestinal tolerability. Br J Diabetes Vasc Dis.
Davis TM, Cull CA, Holman RR. (2001). Relationship between ethnicity and glycemic control, lipid profiles, and blood pressure during the first 9 years of type 2 diabetes: U.K. Prospective Diabetes Study (UKPDS 55). Diabetes Care.
Davis TM, Jackson D, Davis WA, et al. (2001). The relationship between metformin therapy and the fasting plasma lactate in type 2 diabetes: The Fremantle Diabetes Study. Br J Clin Pharmacol.
Deerochanawong C, Serirat S, Kornthong P. (96). Efficacy of acarbose as monotherapy in NIDDM patients. J Med Assoc Thai.
DeFronzo RA, Reasner CA. (2001). Treatment of type 2 diabetes mellitus: A rational approach based on its pathophysiology. Am Fam Phys.
Drouin P, Standl E. (2004). Gliclazide modified release: results of a 2-year study in patients with type 2 diabetes. Diabetes Obes Metab.
Erratum: Long-term glycaemic control with pioglitazone in patients with type 2 diabetes (International Journal of Clinical Practice (2004) vol. 58 (192–200)). Int. J. Clin. Pract. 2004;58(10):993 Not an original article. Other (follow-up on error).
Escobar-Jimenez F, Barajas C, De Leiva A, et al. (95). Efficacy and tolerability of miglitol in the treatment of patients with non-insulin-dependent diabetes mellitus. CURR THER RES CLIN EXP.
Fanghanel G, Sanchez-Reyes L, Trujillo C, et al. (96). Metformin's effects on glucose and lipid metabolism in patients with secondary failure to sulfonylureas. Diabetes Care.
Faure E, Pallardo LF, Mesa J, et al. (2002). HbA(1c) and glycemic profile, basal- and post-treatment with Miglitol, in an area with a Mediterranean diet. Diabetes Care.
Feinglos MN, Bethel MA. (99). Therapy of type 2 diabetes, cardiovascular death, and the UGDP. Am Heart J.
Feinglos MN, Lebovitz HE. (83). Long-term safety and efficacy of glipizide. Am J Med.
Filioussi K, Bonovas S, Katsaros T. (2003). Should we screen diabetic patients using biguanides for megaloblastic anaemia?. Aust Fam Physician.
Freed MI, Ratner R, Marcovina SM, et al. (2002). Effects of rosiglitazone alone and in combination with atorvastatin on the metabolic abnormalities in type 2 diabetes mellitus. Am J Cardiol.
Gerber P, Lubben G, Heusler S, et al. (2003). Effects of pioglitazone on metabolic control and blood pressure: a randomised study in patients with type 2 diabetes mellitus. Curr Med Res Opin.
Gerich J, Raskin P, Jean-Louis L, et al. (2005). PRESERVE-beta: two-year efficacy and safety of initial combination therapy with nateglinide or glyburide plus metformin. Diabetes Care.
Gill GV, Huddle KR. (93). Hypoglycaemic admissions among diabetic patients in Soweto, South Africa. DIABETIC MED.
Giugliano D, Quatraro A, Consoli G, et al. (93). Metformin for obese, insulin-treated diabetic patients: improvement in glycaemic control and reduction of metabolic risk factors. Eur J Clin Pharmacol.
Glazer NB, Wishner W. (2000). Thiazolidinedione side effects comparison elicits clarification. Formulary.
Glimepiride—well tolerated in daily practice. Cardiovasc J S Afr 2002;13(4):214–5 Not an original article
Goddijn PP, Bilo HJ, Feskens EJ, et al. (99). Longitudinal study on glycaemic control and quality of life in patients with Type 2 diabetes mellitus referred for intensified control. Diabet Med.
Golay A, Guillet-Dauphine N, Fendel A, et al. (95). The insulin-sparing effect of metformin in insulin-treated diabetic patients. DIABETES METAB REV.
González-Ortiz M, Martínez-Abundis E, Grupo para, et al. (2004). Efficacy and safety of glimepiride plus metformin in a single presentation, as combined therapy, in patients with type 2 diabetes mellitus and secondary failure to glibenclamide, as monotherapy. Revista de investigacion clinica; organo del Hospital de Enfermedades de la Nutricion.
Groop L, Widen E, Franssila-Kallunki A et al. Sulfonylureas and/or insulin in Type 2 diabetes. Not an original article
Groop PH, Groop L, Totterman KJ, et al. (82). Metabolic effects of glibenclamide and glipizide in patients with type 2 diabetes. ACTA ENDOCRINOL SUPPL.
Grossman E. (2003). Rosiglitazone reduces blood pressure and urinary albumin excretion in type 2 diabetes: G Bakris et al. J Hum Hypertens.
Grunberger G. (93). Continuous versus intermittent sulphonylurea therapy in non-insulin-dependent diabetes mellitus. Drug Saf.
Hae MC, Cornish L, Townsend K, et al. (2004). Monitoring safety and effectiveness in patients receiving metformin [1]. Am J Health-Syst Pharm.
Harrower AD. (91). Efficacy of gliclazide in comparison with other sulphonylureas in the treatment of NIDDM. Diabetes Res Clin Pract.
Hayakawa T, Noda A, Kondo T, et al. (85). Effects of acarbose, an alpha-glucosidase inhibitor (Bay G 5421), on orally loaded glucose, maltose and sucrose and on blood glucose control in non-insulin-dependent diabetics. Nagoya J Med Sci.
Hayakawa T, Yoneshima M, Abe T, et al. (99). Pneumatosis cystoides intestinalis after treatment with an (alpha)- glucosidase inhibitor [6]. Diabetes Care.
Herman WH, Dirani RG, Horblyuk R, et al. (2005). Reduction in use of healthcare services with combination sulfonylurea and rosiglitazone: findings from the Rosiglitazone Early vs SULfonylurea Titration (RESULT) study. Am J Manag Care.
Honisett SY, Stojanovska L, Sudhir K, et al. (2003). Rosiglitazone lowers blood pressure and increases arterial compliance in postmenopausal women with type 2 diabetes. Diabetes Care.
Hristov V, Sheinkova G, Simeonov S, et al. (2002). Clinical assessment of glimepiride (Amaril(registered trademark)) in the treatment of type 2 diabetes mellitus patients (results of a multicenter study). Endocrinologia (Bulgaria).
Hussein Z, Wentworth JM, Nankervis AJ, et al. (2004). Effectiveness and side effects of thiazolidinediones for type 2 diabetes: real-life experience from a tertiary hospital. Med J Aust.
Ikeda T, Murakami I, Tokumori Y. (2003). Comparison of the clinical effects of acarbose and voglibose on glycemic control in subjects with type 2 diabetes mellitus. Therapeutic Research.
Ina K. (2004). How about the effect of thiazolidinediones in diabetic nephropathy?. Med Sci Monit.
Inzucchi SE. (2005). Metformin and heart failure: innocent until proven guilty. Diabetes Care.
Jackson JE, Bressler R. (88). Use oral hypoglycemics with caution. Geriatrics.
Jackson M, Nussey S, Mudan S. (2000). Metformin induced lactic acidosis. Clin Intensive Care.
Jerums G, Murray RML, Seeman E. (87). Lack of effect of gliclazide on early diabetic nephropathy and retinopathy: A two-year controlled study. DIABETES RES CLIN PRACT.
Jick SS, Stender M, Myers MW. (99). Frequency of liver disease in type 2 diabetic patients treated with oral antidiabetic agents. Diabetes Care.
Kane JP. (2002). Does hypertriglyceridemia present an indication for pioglitazone therapy in diabetes?. Diabetes Technol Ther.
Katakami N, Yamasaki Y, Gorogawa S, et al. (2002). Additive metformin attenuates progression of carotid Intima-Media Thickness in subjects with Type 2 diabetes treated with sulfonylureas. Diabetologia.
Kemp TM, Barr EL, Zimmet PZ, et al. (2005). Glucose, lipid, and blood pressure control in Australian adults with type 2 diabetes: the 1999-2000 AusDiab. Diabetes Care.
Kennedy FP. (2003). Do thiazolidinediones cause congestive heart failure?. Mayo Clin Proc.
Kennedy L, Herman WH. (2005). Renal status among patients using metformin in a primary care setting. Diabetes Care.
King JE. (2004). Why hold the metformin?. Nursing.
King KA, Levi VE. (2004). Prevalence of edema in patients receiving combination therapy with insulin and thiazolidinedione. Am J Health-Syst Pharm.
Kirby M. (2005). Diabetes in the new General Medical Services contract: targets and adherence to metformin therapy. Int J Clin Pract.
Ko GTC, Tsang CC, Ng CW, et al. (2001). Use of acarbose or bedtime insulin after failure of treatment with conventional oral antidiabetics: A one-year randomised clinical trial. Clin Drug Invest.
Ko GT, Chan WB, Chan JC, et al. (99). Gastrointestinal symptoms in Chinese patients with Type 2 diabetes mellitus. Diabet Med.
Koppel H, Horn S, Pieber T, et al. (98). Observations on the effect of glibenclamide on noninvasive clinical parameters of myocardial ischemia. Cardiovasc Drugs Ther.
Kordella T. (2004). Research profile. Is there a link? TZDs and congestive heart failure. Andrew Karter, PhD. Diabetes Forecast.
Koro CE, Bowlin SJ, Weiss SR. (2005). Antidiabetic therapy and the risk of heart failure in type 2 diabetic patients: an independent effect or confounding by indication. Pharmacoepidemiol Drug Saf.
Kure J. (86). Glipizide and glyburide. N C Med J.
Laube H, Federlin K, Hillebrand I. Effect of alpha-inhibitors on blood glucose and insulin levels. Adv Exp Med Biol 88;246287–93. N<40.
Levin F, Kazim M, Smith TJ, et al. (2005). Rosiglitazone-induced proptosis. Arch Ophthalmol.
Lipid effects of pioglitazone studied. Br. J. Diabetes Vasc. Dis. 2004;4(3):209 Not an original article. Evaluates nateglinide or repaglinide added to any other oral medication in one arm. Evaluates combinations of greater than 2 oral medications in one arm. Oral medication is compared or added to insulin.
Lopez-Garcia F, Borras J, Verdu C, et al. (2005). Cholestatic hepatitis associated with repaglinide. Diabetes Care.
Maaravi Y, Stessman J. (2005). Mild, reversible pancytopenia induced by rosiglitazone. Diabetes Care.
Manalo GG, Villareal DT, Anel-Quimpo J, et al. (93). Body weight as a predictor of response to sulfonylurea therapy. PHILIPP J INTERN MED.
Masud F, Hasan M, Abaidullah S, et al. (92). Assessment of metabolic profile and body mass index (BMI) in type II diabetics treated with metformin and insulin. SPECIALIST.
Mayou R, Bryant B, Turner R. (90). Quality of life in non-insulin-dependent diabetes and a comparison with insulin-dependent diabetes. J PSYCHOSOM RES.
Mazze RS, Simonson G, Strock E, et al. (2001). Staged Diabetes Management: A systematic evidence-based approach to the prevention and treatment of diabetes and its co-morbidities: Proceedings of Staged Diabetes Management: Worldwide Outcomes 2000 November 2000, Puebla, Mexico. Pract Diabetes Int.
McBain AM, Brown IR, Menzies DG, et al. (88). Effects of improved glycaemic control on calcium and magnesium homeostasis in type II diabetes. J Clin Pathol.
Meier JJ, Deifuss S, Klamann A, et al. (2005). Plasma glucose at hospital admission and previous metabolic control determine myocardial infarct size and survival in patients with and without type 2 diabetes: The Langendreer Myocardial Infarction and Blood Glucose in Diabetic Patients Assessment (LAMBDA). Diabetes Care.
Mertes G. (98). Efficacy and safety of acarbose in the treatment of type 2 diabetes: data from a 2-year surveillance study. Diabetes Res Clin Pract.
Metaglip and Avandamet for type 2 diabetes. Med Lett Drugs Ther 2002;44(1146):107–9. Not an original article
Mitra PK, Dutta SK. (87). Microvascular changes in diabetes mellitus—relation to control of diabetes and oral hypoglycaemic agents. Indian J Pathol Microbiol.
Mitra PK, Dutta SK. (87). Microvascular changes in diabetes mellitus—relation to control of diabetes and oral hypoglycaemic agents. Indian J Pathol Microbiol.
Monsaert RP. (2004). An ounce of prevention. Diabetes Forecast.
Morton AP, McIntyre HD. (2005). Effectiveness and side effects of thiazolidinediones for type 2 diabetes. Med J Aust.
Mullen KD, Howard R. (2005). Is acarbose an effective drug for treating patients with cirrhosis and hepatic encephalopathy?. Nat Clin Pract Gastroenterol Hepatol.
Nakamura T, Ushiyama C, Osada S, et al. (2001). Effect of pioglitazone on dyslipidemia in hemodialysis patients with type 2 diabetes. Ren Fail.
Nakamura T, Ushiyama C, Osada S, et al. (2001). Pioglitazone reduces urinary podocyte excretion in type 2 diabetes patients with microalbuminuria. Metabolism.
Nan DN, Hernandez JL, Fernandez-Ayala M, et al. (2004). Acute hepatotoxicity caused by repaglinide. Ann Intern Med.
Nateglinide improves postprandial glucose as monotherapy or in combination with metformin. Geriatrics 2002;57(8):35 Not an original article
Nielsen NV. (84). Diabetic retinopathy II. The course of retinopathy in diabetics treated with oral hypoglycaemic agents and diet regime alone. A one year epidemiological cohort study of diabetes mellitus. The Island of Falster, Denmark. Acta Ophthalmol (Copenh).
Nissen SE, Wolski K, Topol EJ. (2005). Effect of muraglitazar on death and major adverse cardiovascular events in patients with type 2 diabetes mellitus. JAMA.
Noyon R, Pagano Mirani-Oostdijk C, van Gent CM, et al. (86). Long-term effect of acarbose on diurnal serum triglyceride, glucose, insulin and adipose tissue lipoprotein lipase levels in patients with primary endogenous hypertriglyceridaemia, with or without type II diabetes. Neth J Med.
Ose H, Fukui M, Kitagawa Y, et al. (2005). Efficacy of glimepiride in patients with poorly controlled insulin-treated type 2 diabetes mellitus. Endocr J.
Palmer AJ, Roze S, Lammert M, et al. (2004). Comparing the long-term cost-effectiveness of repaglinide plus metformin versus nateglinide plus metformin in type 2 diabetes patients with inadequate glycaemic control: an application of the CORE Diabetes Model in type 2 diabetes. Curr Med Res Opin.
Parra D, Legreid AM, Beckey NP, et al. (2004). Metformin monitoring and change in serum creatinine levels in patients undergoing radiologic procedures involving administration of intravenous contrast media. Pharmacotherapy.
Peacock I, Hawkins M, Heptinstall S. (86). Platelet behaviour in non-insulin-dependent diabetes—influence of vascular complications, treatment and metabolic control. Thromb Haemost.
Perez A, Khan M, Johnson T, et al. (2004). Pioglitazone plus a sulphonylurea or metformin is associated with increased lipoprotein particle size in patients with type 2 diabetes. Diab Vasc Dis Res.
Pitale S, Kernan-Schroeder D, Emanuele N, et al. (2005). Health-related quality of life in the VA Feasibility Study on glycemic control and complications in type 2 diabetes mellitus. J Diabetes Complications.
Quesada-Gomez JM, Serrano-Alferez I. (2001). Nonhypoglycemic effects of thiazolidinediones [3]. Ann Intern Med.
Quevedo SF, Westrick E. (98). Glycemic control in type 2 diabetes mellitus. Med Health R I.
Rakovac I, Jeitler K, Gfrerer RJ, et al. (2005). Patients with Type 2 diabetes treated with metformin: prevalence of contraindications and their correlation with discontinuation. Diabet Med.
Ramachandran A. (2003). Monotherapy of type 2 diabetes with once-daily gliclazide modified release in primary care. Diabetes Res Clin Pract.
Raz I, Gilhar D, Hoffman A. (94). Prolonged response to glibenclamide in NIDDM patients in a normoglycemic state. Isr J Med Sci.
Reaven GM. (95). Effect of metformin on various aspects of glucose, insulin and lipid metabolism in patients with non-insulin-dependent diabetes mellitus with varying degrees of hyperglycemia. Diabetes Metab Rev.
Rendell MS, Glazer NB, Ye Z. (2003). Combination therapy with pioglitazone plus metformin or sulfonylurea in patients with Type 2 diabetes: influence of prior antidiabetic drug regimen. J Diabetes Complications.
Rosak C, Haupt E, Walter T, et al. (2002). The effect of combination treatment with acarbose and glibenclamide on postprandial glucose and insulin profiles: additive blood glucose lowering effect and decreased hypoglycaemia. Diabetes Nutr Metab.
Roy R, Navar M, Palomeno G, et al. (2004). Real world effectiveness of rosiglitazone added to maximal (tolerated) doses of metformin and a sulfonylurea agent: a systematic evaluation of triple oral therapy in a minority population. Diabetes Care.
Schneider J, Erren T, Zofel P, et al. (90). Metformin-induced changes in serum lipids, lipoproteins, and apoproteins in non-insulin-dependent diabetes mellitus. Atherosclerosis.
Schofl C, Luebben G. (2005). Pioglitazone improves diabetic dyslipidaemia in patients with type 2 diabetes mellitus with or without lipid-lowering therapy. Clin Drug Invest.
Schwarzbeck A, Hastka J, Kuhnle F, et al. (95). Metformin-associated lactic acidosis in diabetic patients with acute renal failure. Nephrol Dial Transplant.
Sclar D A, Robison L M, Skaer T L et al. Sulfonylurea pharmacotherapy regimen adherence in a Medicaid population: influence of age, gender, and race. Diabetes Educ 99;25(4):531–2, 535, 537–8. Does not apply to the key questions.
Shimizu H, Monden T, Nagai T, et al. (2005). Insulin resistance determines efficacy of glimepiride in Type 2 diabetic patients not well controlled by diet alone. Diabet Med.
Soegondo S, Subekti I, Luthariana L. (2004). The efficacy of repaglinide monotherapy and in combination with metformin in Indonesian type 2 diabetes mellitus patients. Acta Med Indones.
Spengler M, Cagatay M. (95). The use of acarbose in the primary-care setting: evaluation of efficacy and tolerability of acarbose by postmarketing surveillance study. Clin Invest Med.
Sugarman JR. (91). Hypoglycemia associated hospitalizations in a population with a high prevalence of non-insulin-dependent diabetes mellitus. Diabetes Res Clin Pract.
Takagi T, Yamamuro A, Tamita K, et al. (2005). Thiazolidinedione treatment attenuates diffuse neointimal hyperplasia in restenotic lesions after coronary stent implantation in type 2 diabetic patients: an intravascular ultrasound study. J Cardiol.
Tan GD, Fielding BA, Currie JM, et al. (2005). The effects of rosiglitazone on fatty acid and triglyceride metabolism in type 2 diabetes. Diabetologia.
Tang WH, Francis GS, Hoogwerf BJ, et al. (2003). Fluid retention after initiation of thiazolidinedione therapy in diabetic patients with established chronic heart failure. J Am Coll Cardiol.
Taylor KG, Wright AD, John WG. (81). A prospective study of sulphonylurea therapy and serum HDL-cholesterol in type 2 (insulin independent) diabetics. DIABETOLOGIA.
Taylor R, Isles TE, McLaren S, et al. (81). A comparison of the metabolic profiles in type 2 diabetics during glipizide and glibenclamide treatment. DIABETOLOGIA.
Testa MA, Simonson DC, Turner RR. (98). Valuing quality of life and improvements in glycemic control in people with type 2 diabetes. Diabetes Care.
Tomino Y, Shirato I, Horikoshi S, et al. (2000). Effect of acarbose on blood glucose and proteinuria in patients with diabetic nephropathy. Nephron.
Trischitta V, Italia S, Mazzarino S, et al. (92). Addition of insulin or metformin after secondary failure to glyburide. ANN INTERN MED.
Turner RC, Cull CA, Frighi V, et al. (99). Glycemic control with diet, sulfonylurea, metformin, or insulin in patients with type 2 diabetes mellitus: progressive requirement for multiple therapies (UKPDS 49). UK Prospective Diabetes Study (UKPDS) Group. JAMA.
Turner RC, Holman RR. (99). Metformin and risk of cardiovascular disease. Cardiology.
U.K. prospective diabetes study. II. Reduction in HbA1c with basal insulin supplement, sulfonylurea, or biguanide therapy in maturity-onset diabetes. A multicenter study. Diabetes 85;34(8):793–8. Other ().
Udezue E. (90). Flexible glibenclamide dosage in Nigerian diabetic patients. Trop Doct.
Vidhya S, Mohan V. Rosiglitazone—useful drug but has side effects. J Assoc Physicians India 2002;50615 Not an original article
Vrijlandt PJWS, Huisman J. Acarbose imrpoves glycaemic controll and insulin sensitivity in obese type 2 diabetes patients with secondary failure on sulphonylureas. The Netherlands Journal of Medicine 2001;58A17 Not an original article
Wagstaff AJ, Goa KL. (2002). Spotlight on rosiglitazone in the management of type 2 diabetes mellitus. Treat Endocrinol.
Wagstaff AJ, Goa KL. (2002). Spotlight on rosiglitazone in the management of type 2 diabetes mellitus. Treat Endocrinol.
Wajchenberg B J, Santomaruo A T, Cherem J J et al. Effect of gliclazide on non-insulin dependent diabetes mellitus. Adv Exp Med Biol 88;246313–9. Does not evaluate medications in this study. N<40.
Waters AK, Morgan DB, Wales JK. (78). Blood lactate and pyruvate levels in diabetic patients treated with biguanides with and without sulphonylureas. Diabetologia.
Weaver JU, Robertson D, Atkin SL. (2004). Nateglinide alone or with metformin safely improves glycaemia to target in patients up to an age of 84. Diabetes Obes Metab.
Weitzman S, Maislos M, Bodner-Fishman B, et al. (97). Association of diabetic retinopathy, ischemic heart disease, and albuminuria with diabetic treatment in type 2 diabetic patients. A population-based study. Acta Diabetol.
Weitzman S, Maislos M, Bodner-Fishman B, et al. (97). Association of diabetic retinopathy, ischemic heart disease, and albuminuria with diabetic treatment in type 2 diabetic patients. A population-based study. Acta Diabetol.
Wolever TM, Radmard R, Chiasson JL, et al. (95). One-year acarbose treatment raises fasting serum acetate in diabetic patients. Diabet Med.
Yang J, Di F, He R, et al. (2003). Efffect of addition of low-dose rosiglitazone to sulphonylurea therapy on glycemic control in type 2 diabetic patients. Chin Med J (Engl).
Yang JK, Di FS, He RH, et al. (2002). Clinical study on rosiglitazone monotherapy of early type 2 diabetes. China Pharmacy.
Yki-Jarvinen H, Nikkila K, Makimattila S. (99). Metformin prevents weight gain by reducing dietary intake during insulin therapy in patients with type 2 diabetes mellitus. Drugs.
Yudkin JS, Smits P. (97). Effects of hypoglycemic agents on patients with diabetes [17]. CIRCULATION.
Zargar A H, Laway B A, Masoodi S R et al. Use of sulfonylureas during pregnancy: some incidental observations. J Assoc Physicians India 2004;52168–9. Evaluates only pregnant women with diabetes. Does not apply to the key questions.
Zimmerman BR, Espenshade J, Fujimoto WY, et al. (96). The pharmacological treatment of hyperglycemia in NIDDM. DIABETES CARE.