# Appendix C Detailed Electronic Database Search Strategies for Systematic Reviews

## Detailed Electronic Database Search Strategies for Systematic Reviews

Terms | Returns
MEDLINE Strategy
For systematic reviews: (“diabetes mellitus, type 2”[mh] or “type 2 diabetes”[tiab] or (diabetes[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab]))) AND (“hypoglycemic agents”[mh] or “thiazolidinediones”[mh] or “sulfonylurea compounds”[mh] or “chlorpropamide”[mh] or “glipizide”[mh] or “glyburide”[mh] or “biguanides”[mh] or “metformin”[mh] or “benzamides” or “carbamates”[mh] or “piperidines”[mh] or “cyclohexanes”[mh] or “phenylalanine”[mh] or “acarbose”[mh] or “alpha-glucosidases”[mh] or “thiazoles”[mh] or “drug combinations”[mh] or “antidiabetic drugs”[tiab] or hypoglycemic[tiab] or anti-hyperglycemic[tiab] or thiazolidinedione*[tiab] or pioglitazone[tiab] or rosiglitazone[tiab] or muraglitazar[tiab] or sulfonylurea[tiab] or chlorpropamide [tiab] or glipizide[tiab] or glyburide[tiab] or glimepiride[tiab] or biguanide*[tiab] or metformin[tiab] or “insulin secretagogues”[tiab] or meglitinide*[tiab] or repaglinide[tiab] or nateglinide[tiab] or “alpha-glucosidase inhibitors”[tiab] or “alpha-glucosidase inhibitor”[tiab] or acarbose[tiab] or avandamet[tiab] or glucovance[tiab] or metaglip[tiab]) AND ((“review”[tiab] or review[pt] or “meta-analysis”[tiab] or meta-analysis[pt]) NOT (letter[pt] or comment[pt] or editorial[pt])) NOT (animal[mh] NOT human [mh]) | 2186
For primary studies: (“diabetes mellitus, type 2”[mh] or “type 2 diabetes”[tiab] or (diabetes[tiab] and (“non-insulin dependent”[tiab] or type-2[tiab] or “type II”[tiab]))) AND (“hypoglycemic agents”[mh] or “thiazolidinediones”[mh] or “sulfonylurea compounds”[mh] or “chlorpropamide”[mh] or “glipizide”[mh] or “glyburide”[mh] or “biguanides”[mh] or “metformin”[mh] or “benzamides” or “carbamates”[mh] or “piperidines”[mh] or “cyclohexanes”[mh] or “phenylalanine”[mh] or “acarbose”[mh] or “alpha-glucosidases”[mh] or “thiazoles”[mh] or “drug combinations”[mh] or “antidiabetic drugs”[tiab] or hypoglycemic[tiab] or anti-hyperglycemic[tiab] or thiazolidinedione*[tiab] or pioglitazone[tiab] or rosiglitazone[tiab] or muraglitazar[tiab] or sulfonylurea[tiab] or chlorpropamide [tiab] or glipizide[tiab] or glyburide[tiab] or glimepiride[tiab] or biguanide*[tiab] or metformin[tiab] or “insulin secretagogues”[tiab] or meglitinide*[tiab] or repaglinide[tiab] or nateglinide[tiab] or “alpha-glucosidase inhibitors”[tiab] or “alpha-glucosidase inhibitor”[tiab] or acarbose[tiab] or avandamet[tiab] or glucovance[tiab] or metaglip[tiab]) AND English[lang] NOT (animal[mh] NOT human [mh])
EMBASE Strategy
For systematic reviews: ‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ OR ‘type 2’ AND (‘diabetes’/exp OR ‘diabetes’)) AND (‘muraglitazar’/exp OR ‘muraglitazar’ OR ‘thiazolidinedione’/exp OR ‘thiazolidinedione’ OR ‘rosiglitazone’/exp OR ‘rosiglitazone’ OR ‘pioglitazone’/exp OR ‘pioglitazone’ OR ‘meglitinide’/exp OR ‘meglitinide’ OR ‘nateglinide’/exp OR ‘nateglinide’ OR ‘repaglinide’/exp OR ‘repaglinide’ OR ‘biguanide’/exp OR ‘biguanide’ OR ‘metformin’/exp OR ‘metformin’ OR ‘alpha glucosidase inhibitor’/exp OR ‘alpha glucosidase inhibitor’ OR ‘acarbose’/exp OR ‘acarbose’ OR ‘chlorpropramide’/exp OR ‘chlorpropramide’ OR ‘sulfonylurea derivative’/exp OR ‘sulfonylurea derivative’ OR ‘sulfonylurea’/exp OR ‘sulfonylurea’ OR ‘glimepiride’/exp OR ‘glimepiride’ OR ‘glipizide’/exp OR ‘glipizide’ OR ‘glyburide’/exp OR ‘glyburide’ OR ‘avandamet’/exp OR ‘avandamet’ OR ‘metformin plus rosiglitazone’/exp OR ‘metformin plus rosiglitazone’ OR ‘glucovance’/exp OR ‘glucovance’ OR ‘glibenclamide plus metformin’/exp OR ‘glibenclamide plus metformin’ or metaglip) AND (review:ti,ab,it OR ‘meta analysis’:ti,ab,it OR metaanalysis:ti,ab,it) NOT (letter:it OR comment:it OR editorial:it) | 2616
For primary studies: (‘non insulin dependent diabetes mellitus’/exp OR ‘non insulin dependent diabetes mellitus’ OR ‘type 2’ AND (‘diabetes’/exp OR ‘diabetes’)) AND (‘muraglitazar’/exp OR ‘muraglitazar’ OR ‘thiazolidinedione’/exp OR ‘thiazolidinedione’ OR ‘rosiglitazone’/exp OR ‘rosiglitazone’ OR ‘pioglitazone’/exp OR ‘pioglitazone’ OR ‘meglitinide’/exp OR ‘meglitinide’ OR ‘nateglinide’/exp OR ‘nateglinide’ OR ‘repaglinide’/exp OR ‘repaglinide’ OR ‘biguanide’/exp OR ‘biguanide’ OR ‘metformin’/exp OR ‘metformin’ OR ‘alpha glucosidase inhibitor’/exp OR ‘alpha glucosidase inhibitor’ OR ‘acarbose’/exp OR ‘acarbose’ OR ‘chlorpropramide’/exp OR ‘chlorpropramide’ OR ‘sulfonylurea derivative’/exp OR ‘sulfonylurea derivative’ OR ‘sulfonylurea’/exp OR ‘sulfonylurea’ OR ‘glimepiride’/exp OR ‘glimepiride’ OR ‘glipizide’/exp OR ‘glipizide’ OR ‘glyburide’/exp OR ‘glyburide’ OR ‘avandamet’/exp OR ‘avandamet’ OR ‘metformin plus rosiglitazone’/exp OR ‘metformin plus rosiglitazone’ OR ‘glucovance’/exp OR ‘glucovance’ OR ‘glibenclamide plus metformin’/exp OR ‘glibenclamide plus metformin’ or metaglip) AND [english]/lim | 773
Cochrane Database of Systematic Reviews Strategy
For systematic reviews: (diabetes near type-2) and (muraglitazar or thiazolidinediones or rosiglitazone or pioglitasone or meglitinide or nateglinide or repaglinide or biguanide or metformin or (alpha and glucosidase and inhibitor) or acarbose or chlorpropramide or sulfonulurea or glimepiride or glipizide or glyburide or avandamet or glucovance or metaglip) | 17
Restricted to reviews
Cochrane Central Register of Controlled Trials
For primary studies: diabetes near type-2) and (muraglitazar or thiazolidinediones or rosiglitazone or pioglitasone or meglitinide or nateglinide or repaglinide or biguanide or metformin or (alpha and glucosidase and inhibitor) or acarbose or chlorpropramide or sulfonylurea or glimepiride or glipizide or glyburide or avandamet or glucovance or metaglip) | 877