# Appendix A Technical Experts and Peer Reviewers

## Technical Experts and Peer Reviewers

- Eugene Barrett, MD, PhD
- Professor of Internal Medicine
- University of Virginia

- John Buse MD, PhD
- UNC School of Medicine

- Helena Rodbard, MD, FACE
- American Academy of Clinical Endocrinology

- Nathaniel Clark, MD, MS, RD
- American Diabetes Association

- Susan Norris, MD, MPH, MSc
- Oregon Health & Science Center

- Leonard Pogach, MD
- Office of Patient Care Services, Veterans Health Administration
- Veterans Administration Health Care System

- Saul Malozowski, MD, PhD
- Senior Advisor for Endocrine Physiology
- Division of Diabetes, Endocrinology, and Metabolic Diseases
- National Institute of Diabetes and Digestive and Kidney Diseases, National Institute of Health

- Sheila H. Roman, MD, MPH
- Johns Hopkins Medical Institutions
- Centers for Medicare & Medicaid Services

## Internal Technical Experts

- Chris Saudek, MD
- Professor
- School of Medicine
- Department of Endocrinology

- Sherita Golden, MD
- Assistant Professor
- School of Medicine
- Department of Endocrinology
- Johns Hopkins School of Medicine