# List of Acronyms/Abbreviations

AHRQ | Agency for Healthcare Research and Quality
BMI | body mass index
CABG | coronary artery bypass graft
CHF | congestive heart failure
CI | confidence interval
DBP | diastolic blood pressure
dL | deciliter
DPP-IV | dipeptidyl peptidase-IV
EPC | Evidence-based Practice Center
FDA | Food and Drug Administration
g | grams
GFR | glomerular filtration rate
GI | gastrointestinal
GITS | gastrointestinal therapeutic system
GRADE | Grading of Recommendations Assessment, Development and Evaluation
HbA1 | hemoglobin A1
HbA1c | hemoglobin A1c
HDL | high density lipoprotein
HR | hazard ratio
HR | hazard ration
IU | International unit
kg | kilogram
LDL | low density lipoprotein
m | meter
mg | milligrams
mmHg | millimeter mercury
mmol | millimole
NHANES III | Third National Health and Nutrition Survey
NYHA | New York Heart Association
PPAR | peroxisome proliferators-activated receptor
PPG | postprandial glucose
PROactive | PROspecitive pioglitAzone clinical Trial in macroVascular Events
PVD | peripheral vascular disease
RCT | randomized controlled trial
RR | relative risk
RR | relative risk
sd | standard deviation
se | standard error
SPB | systolic blood pressure
SU | sulfonylurea
TG | triglycerides
TZD | thiazolidinedione
UKPDS | United Kingdom Prospective Diabetes Study
VAS | visual analog scales
XL | extended release
XR | extended release