# 4 Conclusions

## Summary

The main conclusions for each of the Key Questions are reported in Table 24. The table includes our assessment of the strength of the body of evidence on each Key Question, broken down by the medication comparisons for which data were reported.

Table 24 Evidence of Comparative Effectiveness of Oral Diabetes Medications

Key Question | Level of Evidence* | Conclusions
1. Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to affect the following proximal clinical measures?
1a. glycated hemoglobin (HbA1c) | Moderate to high | Most oral diabetes medications (thiazolidinediones, second generation sulfonylureas, metformin, and repaglinide) had similar absolute reductions in HbA1c (~ 1%) when compared with one another as monotherapy.
| Low | Indirect data, in addition to a few head-to-head trials, showed that nateglinide and alpha-glucosidase inhibitors were less efficacious in reducing HbA1c (~ 0.5–1% absolute difference) than were other oral diabetes medications.
| Moderate to High | Combination therapies were better than monotherapy at reducing HbA1c, by about 1% (absolute difference).
1b. weight | High to moderate | Metformin consistently caused weight loss (~ 1–5 kg) when compared with thiazolidinediones, second generation sulfonylureas, and combinations of metformin plus second generation sulfonylureas, all of which generally increased weight.
| Low | Thiazolidinediones and second generation sulfonylureas caused similar weight gain (~ 3 kg) when used in monotherapy or in combination therapy with other oral diabetes medications.
| Low | Thiazolidinediones caused weight gain (~3 kg) when compared with acarbose and repaglinide, based on indirect comparisons of placebo-controlled trials as well as a few direct comparisons.
| Low | When compared with sulfonylureas, acarbose showed no significant differences in weight, but there was a suggestion of differences between groups in the direct comparisons. The indirect comparisons showed that sulfonylureas were associated with weight gain when compared with acarbose, which was weight-neutral.
| Low | Based on a few head-to-head comparisons and indirect comparisons, acarbose and metformin had similar weight effects.
| Moderate | Repaglinide and second generation sulfonylureas had similar effects on weight. There were too few comparisons of repaglinide with other oral diabetes medications.
| Insufficient | There were too few comparisons of nateglinide with any other oral diabetes medication in terms of their effects on weight.
1c. systolic and diastolic blood pressure | Moderate to low for most comparisons^†^ | All oral diabetes medications had similarly minimal effects on systolic and diastolic blood pressure (<5 mm Hg).
| Insufficient | Too few studies compared meglitinides with other oral diabetes medications (besides sulfonylureas) to allow us to draw firm conclusions.
1d. low density lipoprotein (LDL) | Moderate for monotherapy comparisons and moderate to low for combinations compared with monotherapy | Thiazolidinedione monotherapy and rosiglitazone in combination with metformin or sulfonylurea increased LDL (~ 10–12 mg/dL), when compared with metformin or second generation sulfonylurea monotherapy, which generally decreased LDL.
| Moderate | Rosiglitazone increased LDL more than did pioglitazone (~10–15 mg/dL), based on indirect comparisons and a few head-to-head comparisons.
| Low to very low | Based on one head-to-head trial and mainly indirect comparisons, rosiglitazone increased LDL more than did acarbose (~ 10–15 mg/dL).
| Moderate | Metformin decreased LDL when compared with second generation sulfonylureas (~ 10 mg/dL).
| Low | The effects of metformin monotherapy on LDL were similar to those of metformin plus a sulfonylurea.
| Low to very low | Indirect comparisons showed similar effects of acarbose and metformin on LDL. The one direct comparison favored maximally dosed acarbose over sub-maximally dosed metformin.
| Low | Second generation sulfonylureas and repaglinide had similar effects on LDL.
| Moderate | The combination of metformin plus sulfonylurea decreased LDL, when compared with second generation sulfonylurea monotherapy (~ 8 mg/dL).
| Low | Alpha-glucosidase inhibitors and second generation sulfonylureas had similar effects on LDL.
| Insufficient | There were too few studies comparing meglitinides with other oral diabetes medications besides sulfonylureas to allow firm conclusions to be drawn.
1e. high density lipoprotein (HDL) | Moderate | Pioglitazone increased HDL more than did rosiglitazone, based on indirect and a few direct comparisons (~ 1–3 mg/dL).
| Moderate | Pioglitazone increased HDL when compared with metformin or second generation sulfonylureas (~ 3–5 mg/dL).
| Moderate to low | The combination of rosiglitazone with metformin or a second generation sulfonylurea increased HDL slightly more than did metformin or second generation sulfonylureas alone (~ 3 mg/dL).
| Moderate to low | Metformin, second generation sulfonylureas, acarbose, and meglitinides had similarly minimal or no effects on HDL.
| Moderate to low | Combination therapy with metformin plus a second generation sulfonylurea was not different in its effect on HDL from monotherapy with either of the two classes.
1f. triglycerides (TG) | Moderate | Based on indirect comparisons and a few head-to-head comparisons, pioglitazone decreased TG (range 15–52 mg/dL) when compared with rosiglitazone, which increased TG (range 6–13 mg/dL).
| Moderate to low | Pioglitazone decreased TG more than did metformin (~ 26 mg/dL), and pioglitazone and sulfonylureas showed similar decreases in TG. However, the pooled estimate suggested a potential difference between pioglitazone and sulfonylureas of -28.8 mg/dL.
| Low | Indirect comparisons and one direct comparison showed that pioglitazone decreased TG more than did acarbose (~ 30 mg/dL).
| Low | Rosiglitazone increased TG when compared indirectly with metformin and acarbose, yet showed similar effects on TG when compared directly with metformin.
| Moderate to low | Metformin decreased TG more than did second generation sulfonylureas or metformin plus rosiglitazone (~ 10 mg/dL).
| Moderate to low | Metformin plus a second generation sulfonylurea decreased TG more than did sulfonylurea monotherapy (~ 30 mg/dL), and it showed non-significant decreases in TG when compared with metformin monotherapy.
| Low to very low | Based on indirect and a few direct comparisons, metformin and acarbose had similar effects on TG.
| Moderate to low | Second generation sulfonylureas, repaglinide, and acarbose had similar effects on TG. There were too few comparisons to nateglinide to allow us to draw any conclusions.
2: Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to affect distal diabetes-related complications of mortality and microvascular and macrovascular outcomes?
2a. all-cause mortality | Low to very low | It was unclear whether mortality differed when the combination of metformin and a sulfonylurea was compared with sulfonylurea or metformin monotherapy, or when metformin and sulfonylureas were compared.
| Very low | Not enough data existed to compare other oral diabetes medications.
2b. cardiovascular disease mortality | Low to very low | It was unclear whether cardiovascular mortality differed when comparing the combination of metformin and a sulfonylurea with sulfonylurea or metformin monotherapy.
| Low to very low | It was unclear whether the effects on cardiovascular mortality differed between metformin and sulfonylureas.
| Very low | Not enough data existed to compare other oral diabetes medications.
2c. cardiovascular morbidity | Low to very low | There were too few studies to support any conclusions about how cardiovascular morbidity differed among the medications.
2d. peripheral vascular disease | Low to very low | No evidence existed that showed a difference among oral diabetes medications with regard to effects on peripheral vascular disease.
2e. microvascular outcomes (retinopathy, nephropathy, neuropathy) | Low to very low | Too few comparisons were made to allow any firm comparative conclusions regarding microvascular outcomes.
| Low to very low | Pioglitazone and sulfonylureas showed similar effects on nephropathy in 3 RCTs lasting less than a year and showed greater improvement in proteinuria when compared with metformin in 2 RCTs lasting less than a year.
3. Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to influence other health outcomes, including quality of life and functional status?
3a. Quality of life and functional status | Very low | Too few studies existed to allow any comparative conclusions to be drawn.
4&5. Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in terms of risk of the following life-threatening and non-life-threatening adverse events?
4&5a. hypoglycemia | NA | Second generation sulfonylureas had a higher percentage of subjects with hypoglycemic episodes (range 0–58%) than did metformin (range 0–21%) or thiazolidinediones (range 0–24%). The absolute risk differences between groups were ~5–10%.
| NA | Based on indirect comparisons, metformin (range 0–21%) and thiazolidinediones (range 0–24%) had a similar incidence of subjects with hypoglycemia, consistent with the few head-to-head trials.
| NA | Glyburide/glibenclamide had a higher incidence of subjects with hypoglycemia (range 0–32%), when compared with other second generation sulfonylureas (range 0–14%). The absolute risk difference between groups was ~2%.
| NA | Repaglinide had an incidence of subjects with hypoglycemia (range 0–15%) that was similar to that of second generation sulfonylureas (range 7–19%).
| NA | Data were sparse on the comparisons of hypoglycemia between acarbose and other oral diabetes medications, and between nateglinide and other oral diabetes medications.
| NA | Combinations of metformin plus sulfonylurea (range 5–58%) and sulfonylurea plus thiazolidinedione (range 6–32%) had a higher incidence of subjects with hypoglycemia than did metformin (range 0–21%) or sulfonylurea monotherapy (range 2–39%). The absolute risk differences were ~8–14%.
| NA | A combination of metformin plus rosiglitazone had a similar percentage of subjects with hypoglycemia (range 1–5%) to that for metformin monotherapy (range 0–2%). No serious events occurred in either group in these RCTs.
4&5b. gastrointestinal (GI) problems/adverse events | NA | Metformin was associated with a greater percent of subjects with GI adverse events (range 2–63%) when compared with thiazolidinediones (range 0–36%) and second generation sulfonylureas (range 0–32%). The between-group absolute risk differences were ~ 5–15%.
| NA | Metformin monotherapy was associated with more frequent adverse events (range 2–63%) than was the combination of metformin plus a second generation sulfonylurea (range 1–35%) or metformin plus thiazolidinediones (17%) if the metformin component was at a lower dose than the metformin monotherapy arm.
| NA | There was a suggestion from a few placebo-controlled and head-to-head trials that metformin and acarbose have a similar incidence of subjects with GI adverse events (range 8–29% vs 15–30%, respectively).
| NA | There was a suggestion from a few placebo-controlled and head-to-head trials that meglitinides have a lower incidence of subjects with GI adverse events (range 8–11%) than does metformin (range 8–29%) (between-group absolute differences of ~ 5–15%).
4&5c. elevated aminotransferase levels/liver failure | NA | Several oral diabetes medications (thiazolidinediones, second generation sulfonylureas, and metformin) appeared to have similarly low rates (<1%) of clinically relevant elevated aminotransferase levels (> 1.5 to 2 times the upper limit of normal or liver failure).
| NA | Insufficient studies evaluated or reported on the effects of meglitinides and acarbose on serum aminotransferase levels, but they appeared to be similar to the effects of other oral diabetes medications.
4&5d. congestive heart failure (CHF) | NA | Thiazolidinediones had a greater risk of CHF than did metformin or sulfonylureas (2 RCTs with absolute between-group risk differences of 1–2%; cohort studies had a range in odds ratios of 1.06–2.27, which was significant in 4 of 5 studies).
| NA | Metformin and second generation sulfonylureas had similarly little impact on incident CHF.
4&5e. edema/hypervolemia | NA | Thiazolidinediones had a greater percentage of subjects with edema (range 0–26%) than did second generation sulfonylureas (range 0–8%) or metformin (range 0–4%). The range of between-group absolute risk differences was 2–21%. Of note, no cases of macular edema were reported.
| NA | Data were too sparse to allow us to draw conclusions about comparisons of the incidence of edema with other oral diabetes medications.
4&5f. lactic acidosis | NA | The rate of lactic acidosis was similar between metformin and other oral diabetes medications or placebo (8.4 vs 9 cases per 100,000 patient-years).
4&5g. anemia, thrombocytopenia, and leucopenia | NA | Thiazolidinediones may be associated with a greater percent of subjects with anemia (range 3–7%) than are other oral diabetes medications (range 2–3%). The absolute between-group differences were ~ 1–5%.
4&5h. cancer | NA | There were too few studies and too few cancer cases to draw comparative conclusions.
4&5i. allergic reactions requiring hospitalization | NA | No serious allergic reactions requiring hospitalization were reported.
4&5j. withdrawals due to unspecified adverse events | NA | There were no significant differences among oral diabetes medications in withdrawals due to unspecified adverse events.
4&5k. Food and Drug Administration (FDA) data | NA | Pioglitazone was associated with an increased rate of hospitalization for acute cholecystitis in a pooled analysis compared with placebo.
| NA | FDA data were consistent with the adverse event findings reported above.
6. Do the safety and effectiveness of oral diabetes medications for the treatment of adults with type 2 diabetes differ across particular adult populations, such as those based on demographic factors (e.g., race/ethnicity, age>65 years, or gender) or co-morbidities (e.g., renal insufficiency, congestive heart failure, liver disease, obesity, depression, schizophrenia)?
| NA | Studies had too few analyses to allow us to draw comparative conclusions for this question.

* Definitions of levels of evidence: High = further research is very unlikely to change our confidence in the estimates; Moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; Low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; Very low = any estimate of effect is very uncertain; Insufficient = not graded if too few comparisons (<3 studies) and not a key comparison of interest; NA=not applicable since there was no validated grading system to determine level of evidence for adverse events.

† The evidence was graded very low for the following comparisons related to blood pressure effects: metformin versus metformin plus sulfonylurea, sulfonylurea versus sulfonylurea plus thiazolidinedione, meglitinides versus sulfonylureas, and alpha-glucosidase inhibitors versus all other oral diabetes medications.

TG = triglycerides; FDA = Food and Drug Administration; CHF = congestive heart failure; GI = gastrointestinal; LDL = low density lipoprotein; HDL = high density lipoprotein; HbA1c = hemoglobin A1c; RCT = randomized controlled trial.

## Discussion

This report addresses the comparative effectiveness and safety of the oral diabetes medications used most frequently in the United States. As expected, short-term or proximal outcomes such as HbA1c levels were studied more frequently in RCTs than were distal outcomes such as long-term complications of diabetes. HbA1c is unequivocally linked to the risk of microvascular disease, making it a good proximal outcome measure; in addition, it may also be linked to macrovascular disease. We found that most oral diabetes medications reduced HbA1c to a similar degree, except for nateglinide and acarbose, which appeared less effective in indirect comparisons. Inzucchi and coworkers have conducted a systematic review evaluating HbA1c among the oral diabetes medications and have drawn similar conclusions. ^266^ Our study has added to this body of work by including more recent articles, especially on the meglitinides, and by conducting meta-analyses. Also, Inzucchi et al. only included articles in which HbA1c was listed as the major endpoint, while we evaluated articles that reported HbA1c even if it was not a major endpoint of the study. ^266^

Oral diabetes medications varied in their effects on body weight/BMI, with metformin and acarbose being the only medications associated with weight loss, as compared to other oral diabetes medications that increase weight. Our results are consistent with those of other reviews; ^17,^ ^266,^ ^267^ however, no other systematic review to date has included meta-analyses of the effects on weight of as many different types of oral diabetes medications. One might argue that the weight loss seen with metformin and acarbose was only as a result of the removal of medications that increase weight in the run-in and that, in general, metformin and acarbose are associated with weight neutrality, rather than weight loss. This interpretation appears particularly reasonable because the published placebo-controlled trials have shown no weight change for acarbose and metformin. These findings suggest that any weight loss becomes significant in direct comparisons between medications only when the two medications have contrasting effects on weight.

Generally, the reported weight gain was small to moderate, even in the longer-duration RCTs such as the UKPDS (<5 kg). However, even small amounts of weight gain (5–10% of body weight) may be associated with increased morbidity because they worsen insulin resistance and lipid levels, decrease patient adherence, and can cause CHF exacerbations, ^268,^ ^269^ – ^271^ while weight loss improves control of diabetes. ^272^ – ^274^ Also, different types of weight gain (central versus peripheral) may have different effects on morbidity, with central adiposity being considered to be more predictive of cardiovascular outcomes. ^275,^ ^276^ Few studies have evaluated whether weight gain is related to increases in visceral adipose tissue, subcutaneous fat, or plasma volume; however, a few recent studies have suggested that different medications affect weight through different mechanisms. Sulfonylureas are thought to increase weight by increasing insulin release, which increases glucose uptake by cells and leads to increased storage of glucose as fat. ^277^ In two clinical studies, ^277,^ ^278^ pioglitazone has been associated with an increase in total body water and subcutaneous fat and a decrease in visceral fat, most likely reflecting its effect on peroxisome proliferators-activated receptor (PPAR) gamma. A larger number of studies of more oral diabetes medications are needed to allow us to establish conclusively the existence of such differences and their potential impact on long-term outcomes.

Blood pressure control is extremely important in patients with diabetes. ^279^ – ^285^ The UKPDS showed that for every decrease in blood pressure of 10 mmHg, there is a 15% decrease in diabetes-related deaths, with no threshold effect. ^283^ Oral diabetes medications generally had minimal effects on blood pressure. Two systematic reviews have evaluated thiazolidinediones' effects on blood pressure when compared with placebo and reported a slight but significant reduction in blood pressure of 2 to 4 mmHg; ^286^ however, no one has compared the blood pressure effects of thiazolidinediones with other oral diabetes medications. Thiazolidinediones are thought to affect blood pressure through a variety of potential mechanisms, including intracellular increases in calcium, increased production of angiotensin II type I receptor in vascular smooth muscle cells, and inhibition of the production of various vascular cell types, to name only a few. ^287^ A suggestion that blood pressure is decreased in the thiazolidinedione group when compared with second generation sulfonylureas and acarbose has been made and requires further exploration. Given the small non-significant between-group differences of 3–5 mmHg, the clinical relevance of these differences is questionable, especially since these RCTs were of short duration.

Effects on lipid levels have been found to vary across medication type, but most effects were small to moderate. For instance, pooled analyses showed between-group differences of about 5 to 10 mg/dL in LDL and 10 to 30 mg/dL in TGs, and summary data for HDL showed differences of about 3 mg/dL. Buse et al. published a systematic review on lipid levels in 2002 that reported similar results. ^25^ Our review updates theirs; we were also able to add more detail on specific differences, since we presented meta-analyses for LDL and TGs, whereas Buse and colleagues derived their results by totaling the numbers of studies with statistically significant differences.

In our evaluation of lipids, we noted that a single medication can have favorable effects on one lipid outcome and unfavorable effects on another lipid outcome. For instance, most oral diabetes medications decreased TGs, yet only thiazolidinediones increased HDL and LDL. Elevated LDL, elevated TGs, and low HDL are associated with cardiovascular morbidity in epidemiologic studies. ^288^ In addition, treatment of lipids (especially LDL) has also been associated with improved cardiovascular outcome. ^288^ While lipid-lowering treatments exist, patients do not reach adequate treatment goals for lipids for a multitude of reasons. ^289,^ ^290^ Therefore, decisions regarding medications that may adversely affect lipids carry a higher relative importance. Few trials in our review evaluated the effects on lipid sub-fractions, an analysis that is thought by some to confer important additional information on cardiovascular risk. This topic may be an area for future research once more data have been acquired with regard to the effects of lipid sub-fractionations on cardiovascular outcomes.

Several caveats deserve mention regarding the proximal outcomes. First, a study's results may have been influenced by the baseline levels obtained. For instance, lower baseline levels for particular outcomes would generally be associated with smaller between-group differences, and vice versa. We were limited in our assessment of heterogeneity based on baseline levels. Because of concerns regarding ecologic fallacy, we did not use individual level characteristics in our metaregression. However, although baseline levels might contribute to between-study variance, they would not influence the direction of the point estimates, and so would not be expected to markedly influence the results.

Second, many studies failed to report the significance of between-group differences and their measures of dispersion, thereby hindering efforts to estimate effect size across trials. We used a conservative estimate of 0.5 for the correlation between baseline and final values when calculating variance. As a result, studies with calculated variances had less weight than studies that reported variance in the publication, a difference that may have influenced our results.

Third, many trials were industry-sponsored, raising the possibility of publication bias. ^291^ While obvious publication bias was generally not observed, these analyses had only limited power to detect publication bias because of the small numbers of studies available for many of the drug comparisons.

Fourth, the indirect comparison results must be viewed with caution, since indirect comparisons tend to overestimate effects. ^175^ In addition, we were unable to fully assess the heterogeneity in the placebo groups. Furthermore, we indirectly compared pooled estimates of acarbose versus placebo from another systematic review with our own pooled estimates, creating further heterogeneity. However, these trial results were similar to the placebo-controlled trial results in our review. Finally, few of these RCTs, with the exception of the UKPDS, were long-term studies, making it difficult to assess potential attenuation or exacerbation of effects over time. For instance, in UKPDS, HbA1c initially was reduced in the first few years, then began to rise in both the metformin and sulfonylurea groups. ^15,^ ^16^

Very few published studies have compared oral diabetes medications in terms of clinically important distal outcomes, such as cardiovascular events, mortality, and microvascular outcomes. We found that metformin, sulfonylureas, and pioglitazone were the only medications associated with long-term reductions in vascular risk. Inzucchi and colleagues reported similar findings in 2003. ^266^ However, we were able to add pioglitazone to their list, since the PROactive study had been published since their review. The UKPDS has provided the bulk of the relevant data on distal outcomes, along with several cohort studies.

Several caveats deserve mention here: First, long-term events such as renal failure or death and amputations from peripheral vascular disease were generally rare, limiting statistical power to detect differences between medications for these outcomes. Second, study end-points and populations varied greatly. For instance, some studies evaluated primary prevention of cardiovascular disease, while others evaluated secondary prevention. Cardiovascular outcomes ranged from electrocardiogram abnormalities to in-stent re-stenosis rates to nonfatal and fatal myocardial infarction or stroke. Nephropathy outcomes were reported as urinary albumin to creatinine ratios, microalbuminuria, proteinuria, change in glomerular filtration rate, and renal failure. Third, all-cause mortality was difficult to assess across studies, since many smaller shorter-duration trials failed to report mortality, even when no deaths occurred. Fourth, methods to assess and classify outcomes varied across studies: Some used vital statistics, others used claims data, and others used medical record review. Fifth, cohort studies often failed to adjust for potentially important confounders such as the duration of diabetes, HbA1c level, or blood pressure level. Confounding by indication was a large concern, since many patients who have more serious disease or have a longer duration of diabetes are put on sulfonylureas or combinations of sulfonylurea and metformin. These limitations made it difficult to draw firm conclusions about differing effects of the oral diabetes medications on distal outcomes.

Finally, we evaluated the comparative safety of the oral diabetes medications. Our conclusions were consistent with other systematic reviews that have analyzed specific adverse events associated with a single oral diabetes medication. ^22,^ ^292,^ ^293^ However, no previous systematic review has systematically assessed all serious adverse events of all oral diabetes medications in one report.

Minor and major hypoglycemia was more common among sulfonylureas (especially glyburide) and combinations including sulfonylureas than for other oral diabetes medications except repaglinide, which resembled the sulfonylureas. However, repaglinide may be associated with less serious hypoglycemia than the sulfonylureas, as indicated in one randomized crossover study in the elderly, ^199^ or with less overall hypoglycemia than glyburide (0 vs 6 events) in patients who skip meals, as seen in one RCT. This last trial was not included in our review because it lasted less than 3 months. ^294^ Few studies stratified minor or major hypoglycemia according to glycemic control, although these data would be important for subjects with serious hypoglycemia. Despite this omission, little heterogeneity was found in many of these meta-analyses.

Lactic acidosis is the adverse effect most commonly mentioned as a specific concern for patients taking metformin. Because of this concern, metformin is contraindicated in patients with impaired renal function and congestive heart failure. However, neither our review nor the systematic review by Salpeter et al. ^49^ produced consistent evidence of an elevated risk of lactic acidosis in patients taking metformin, when compared with other oral diabetes medications. The concern with regard to lactic acidosis mainly represents a response to about 300 case reports that we did not evaluate in our review. The problem with using case report data is that it is difficult to determine cause and effect, and the effects reported may reflect underlying disease rather than medication effects. In fact, most of the reported cases have occurred in patients with severe acute conditions, such as myocardial infarction or acute renal failure, that could have caused the lactic acidosis. ^295,^ ^296^ We did not have enough information on subjects who were taking metformin and had chronic conditions such as chronic renal insufficiency, chronic liver disease, congestive heart failure, or severe pulmonary disease; therefore, we were unable to determine the safety of taking metformin in patients with co-morbidities that predispose subjects to lactic acidosis.

In our review of published studies, thiazolidinediones were consistently associated with an increase in the number of episodes of self-reported edema; unpublished FDA data corroborate this finding. An advisory letter was issued by GlaxoSmithKline in December 2005, reporting that macular edema had been reported post-marketing by subjects taking rosiglitazone or thiazolidinediones; ^297^ most of these patients also had peripheral edema. We did not, however, find any reports of macular edema in our review, since most of the reported events came from case reports. This potential adverse effect will need further investigation in observational studies. Thiazolidinediones were also associated with anemia, with an average drop in hematocrit of 1–3% that is likely not clinically relevant unless the individual already has moderate to severe anemia. Thiazolidinediones are thought to cause edema and anemia by increasing the plasma volume. ^277^ The FDA data indicated that hematocrit decreased by more than 10% in fewer than 1 in 100 subjects. However, although the anemia develops infrequently, it seems reasonable to check for anemia after starting thiazolidinediones.

CHF is an adverse event that is mentioned on the product label for the thiazolidinediones; the label cites two different studies: One compared pioglitazone with glyburide, and the other was a study of rosiglitazone plus insulin, showing increased CHF in the thiazolidinedione arms. ^298,^ ^299^ Rosiglitazone is also currently contraindicated in patients with New York Heart Association (NYHA) class III or IV CHF. ^299^ In our review, thiazolidinediones also conferred a greater risk of congestive heart failure than did metformin or second generation sulfonylureas. We found several RCTs that reported on CHF as an adverse event, including PROactive, a one-year, large randomized, double-blind trial. ^185^ However, many studies did not report on this adverse event, even to state that there were no events. Although a few observational studies have evaluated this outcome, they were limited by their ability to address key confounders such as HbA1c control, duration of diabetes, blood pressure level, adherence to medications, and medication dosing.

Summaries of data with regard to withdrawals due to unspecified adverse events were included in many studies, but these data have limited usefulness because the authors did not identify specific reasons for the withdrawals. Eighteen percent of trials did not report on withdrawals or losses to follow-up, and it would be important to know whether the withdrawals that were reported were due to specific adverse events. If trials reported this information consistently, comparative data would be more meaningful for this outcome.

Several caveats deserve mention with regard to adverse events. First, while almost all studies reported the incidence of hypoglycemia, they were inconsistent in terms of reporting on other adverse events. Second, the definitions of adverse events varied across studies and were often aggregated. For instance, GI events could be defined as nausea, vomiting, abdominal pain, flatulence, or a mixture of the above, making it difficult to compare across studies. Third, as expected, the incidence of adverse events was generally higher in cohort studies, which were of longer duration, than in the short-duration RCTs. The estimates from the RCTs (with the exception of the longer-duration UKPDS) are therefore likely to be lower than what one would expect in diabetic subjects over time. Also, because of potential publication bias, cohort studies may be more likely to get published if a difference between medications is shown. However, the cohort studies have generally shown between-group differences that were similar to those in the RCTs. Fourth, few RCTs evaluated certain outcomes, such as elevated liver transaminases, CHF, anemia, cancer, and allergic reactions; therefore, we relied on a small number of cohort studies for many of these outcomes. The available cohort studies, however, were limited by their ability to adjust for key confounders such as HbA1c levels, blood pressure, lab data, duration of diabetes, adherence to medications, and doses of medications. Finally, most studies occurred in patients without contraindications, such as renal or hepatic insufficiency; therefore, we cannot generalize these findings to those specific co-morbidities.

Several general limitations to this systematic review should also be kept in mind. First, we did find that the study populations were fairly similar to the general population of adults with type 2 diabetes. However, many studies excluded individuals with complications of diabetes or other co-morbidities, as well as less adherent subjects, thereby limiting the generalizability of the findings.

Second, we excluded articles comparing oral diabetes medications with insulin, since insulin was not part of this review. Therefore, we may have missed some relevant information regarding the oral diabetes medications of interest. However, these data would have been indirect comparison data and less strong than the head-to-head data we present. We also did not study the oral diabetes medications in combination with injectable diabetes medications such as insulin, amylin, or exenatide, another potential limitation to the generalizability. In the UKPDS, 22–40% of subjects had insulin added to their regimen after 6 years of follow-up; ^93^ such addition of insulin could lead to new adverse events or exacerbation of existing adverse events. Also, a systematic review already exists that evaluated insulin in combination with oral medications, as well as insulin monotherapy. ^300^

Third, we only included articles that had more than 20 participants in each arm or a total of 40 participants or more in the study. We felt that very small studies were unlikely to influence our conclusions, given the large number of studies that were available for inclusion in this systematic review. Fourth, we only evaluated specific safety issues for which there was an a priori hypothesis of potential harm. However, we did abstract data on all serious adverse events as well as all the well-known side effects. We also evaluated FDA data, paying particular attention to safety concerns. Therefore, we do not feel we have missed any clinically relevant concerns.

In conclusion, oral diabetes medications had similar effects on glycemic control and slightly different effects on other proximal outcomes. We were unable to draw firm conclusions about the differences among oral diabetes medications in terms of their effects on distal outcomes. Safety differences did exist among the oral diabetes medications and deserve further investigation.

## Future Research

This review of existing evidence identified a number of issues requiring further research. These remaining issues are grouped by key question below.

### For Key Question 1 (Short-term Outcomes)

1 Future studies should examine the effects of medications on glycemic variability in more depth, using standardized methods to allow better comparison of effects across medications. Consistently reporting 2-hour PPG, as well as measuring 2-hour PPG over time pre- and post-treatment, would help with these comparisons.
2 There were few extended studies that characterized the persistence of effects on glycemic control, weight, and lipids over time. Evaluating the durability of effects on proximal outcomes will be helpful in determining the clinical relevance of the various effects on lipids, weight, and glycemic control. Linking these effects to cardiovascular outcomes will also help clarify their clinical relevance.
3 More head-to-head monotherapy trials of rosiglitazone with metformin and sulfonylurea monotherapy are needed to make it possible to better assess potential differences in lipid outcomes.
4 Future studies on body weight changes should attend to effects on body composition, in order to partition effects on weight or BMI in terms of increases in fluid, subcutaneous tissue, or visceral adipose tissue, as these differing effects may have different effects on health. If possible, investigators should then link these changes with long-term outcomes, such as mortality. Furthermore, since sulfonylureas and thiazolidinediones caused weight gain when used as monotherapy, future studies need to identify whether there is an additive or synergistic effect on weight if sulfonylureas are combined with thiazolidinediones.

### For Key Question 2 (Long-term Outcomes)

1 More RCTs and prospective cohort studies should examine the effects of oral diabetes medications on the long-term outcomes of all-cause and cardiovascular mortality, cardiovascular disease morbidity, microvascular disease, and peripheral vascular disease.
2 We recommend continued investigation of surrogate markers of cardiovascular disease, such as carotid intimal media thickness using ultrasound imaging, as well as further evaluation of re-stenosis rates and arrhythmias among different oral diabetes medications.
3 To determine whether oral diabetes medications differ in their effects on mortality and cardiovascular morbidity, a long-term head-to-head RCT should be conducted to compare thiazolidinediones, metformin, sulfonylurea, and metformin plus a sulfonylurea in subjects with a history of mild macrovascular disease.
4 To improve our understanding of the effects of oral diabetes medications on peripheral vascular disease, studies should use earlier, clinically relevant outcomes such as ankle brachial index, distance to onset of pain, stopping time during standardized walking, and symptoms of PVD as well as outcomes of amputation and death from peripheral vascular disease.
5 To improve our understanding of the effects of oral diabetes medications on nephropathy, studies should evaluate long-term clinically relevant outcomes, such as time to dialysis as well as shorter-term outcomes such as proteinuria.

### For Key Question 3 (Quality of Life)

1 More studies using standardized, validated questionnaires should be conducted to examine the effects of oral diabetes medications on health-related quality of life.

### For Key Question 4&5 (Adverse Effects)

1 Studies on oral diabetes medications need to consistently report withdrawals and reasons for withdrawals in order to improve our understanding of potential differences in adverse effects.
2 Studies on oral diabetes medications need to report their definitions of adverse events more thoroughly and consistently report on all adverse events (rather than use aggregated events).
3 Additional observational studies of metformin compared with other oral diabetes medications in subjects prone to lactic acidosis would help determine the safety of using this medication in co-morbid populations.
4 Further observational studies should evaluate the incidence of macular edema and of anemia requiring transfusion or hospital admission for thiazolidinediones as compared with analogous results for other oral agents, and they should evaluate cancer and allergic reactions in all oral diabetes medications.

### For Key Question 6 (Differences Across Specific Populations)

1 To determine differences based on co-morbidities or demographics, stratified analyses of outcomes would be extremely helpful. Specific areas to focus on would be the effects of medications in subjects with and without renal disease, congestive heart failure, liver disease, psychiatric diseases, and studies focusing on the elderly.

### Other General Issues

1 Future observational studies could improve our understanding of the effects of oral diabetes medications on adverse events and distal outcomes if they carefully assess key confounders, such as duration of diabetes, adherence to medications, dosing of medications, HbA1c levels, and blood pressure levels.
2 Studies need to consistently report between-group changes from baseline, as well as measures of dispersion such as standard errors.
3 For all outcomes, further head-to-head comparisons of nateglinide with other oral diabetes medications and of repaglinide with other oral diabetes medications besides sulfonylureas are needed.
4 More studies are needed to compare one combination of medication directly with another combination (specifically metformin, sulfonylureas, and thiazolidinediones in dual combinations as starting therapy) for all outcomes, as many clinicians have started using combinations as initial treatment in patients with diabetes.
5 Future studies comparing oral diabetes medications must consider any new oral diabetes medications that may be placed on the market, such as the dipeptidyl peptidase IV (DPP-IV) inhibitor sitagliptin, which has just been approved by the Food and Drug Administration.
6 More easily accessible and understandable FDA data for clinicians, investigators, and the public should be a priority, as their data were difficult to sift through, yet can be quite important.
7 Further research is also needed on the effects of oral diabetes medications on beta cell function over a 3–5 year period or longer, using standardized outcomes such as C-peptide and insulin levels and time to requiring insulin.
8 A systematic review on drug-drug interactions in persons with diabetes would help clinicians with treatment decisions.
9 Studies comparing combinations of older diabetes medications, such as sulfonylureas and metformin, with combinations of newer oral diabetes medications, such as thiazolidinediones in combination with DPP-IV inhibitors or meglitinides, would be interesting, especially given the cost associated with newer oral diabetes medications.