# 2 Methods

In response to Section 1013 of the Medicare Modernization Act, AHRQ requested an evidence report to synthesize the evidence on the comparative effectiveness of oral diabetes medications. Our EPC established a team and a work plan to develop the evidence report. The project consisted of recruiting technical experts, formulating and refining the specific questions, performing a comprehensive literature search, summarizing the state of the literature, constructing evidence tables, synthesizing the evidence, and submitting the report for peer review.

## Topic Development

The topic for this report was nominated in a public process. At the beginning of the project, we recruited a panel of internal and external technical experts to give input on key steps including the selection and refinement of the questions to be examined. The panel included two internal technical experts from the Johns Hopkins University who have strong expertise in various aspects of the efficacy and/or safety of oral diabetes medications, and external experts who have expertise in diabetes research (see Appendix A).

We worked with the technical experts and representatives of AHRQ to develop the Key Questions that are presented in the Scope and Key Questions section of the Introduction. The final Key Questions focus on the differences among oral diabetes medications in their ability to affect proximal clinical measures, distal diabetes-related complications, quality of life, and adverse events. Draft Key Questions were posted to a public website for additional feedback.

## Search Strategy

We searched the following databases for primary studies for the periods in parentheses: MEDLINE^®^ (1966 to January 2006), EMBASE^®^(1974 to January 2006), and the Cochrane Central Register of Controlled Trials (1966 to January 2006). We also searched for systematic reviews until November 2005. Our search strategy combined terms for type 2 diabetes and oral diabetes medications. The search for systematic reviews also included terms for study design, but the search strategy for primary studies did not include these types of terms.

In addition, we received the following material from the Scientific Resource Center that gives support to AHRQ's EPCs:

- Statistical and medical reviews of rosiglitazone, pioglitazone, nateglinide, metformin, the combination of rosiglitazone plus second generation sulfonylureas, the combination of metformin plus glyburide, the combination of metformin plus glipizide, and extended release metformin obtained from the website of the United States Food and Drug Administration (FDA).
- Public registries of clinical trials, such as Clinical Study Results website (www.clinicalstudyresults.org) and ClinicalTrials.gov (www.clinicaltrials.gov).
- Unpublished trials on glipizide gastrointestinal therapeutic system (GITS) from Pfizer Inc. (New York, NY), on rosiglitazone and the combination of rosiglitazone plus metformin from GlaxoSmithKline (Triangle Park, NC), and on the combination of metformin plus glyburide from Bristol-Myers Squibb (New York, NY).

We hand searched 15 journals that were most likely to publish articles on this topic (see Appendix B), scanning the table of contents of each issue for relevant citations from December 2005 through February 2006. We also reviewed the reference lists of included articles.

We developed a search strategy for MEDLINE, accessed via PubMed, based on an analysis of the medical subject headings (MeSH) terms and text words of key articles identified a priori. The PubMed strategy formed the basis for the strategies developed for the other electronic databases (see Appendix C).

The results of the searches were downloaded and imported into ProCite^®^ version 5 (ISI ResearchSoft, Carlsbad, CA). From ProCite, the articles were uploaded to SRS 3.0 (TrialStat! Corporation, Ottawa, Ontario, Canada), a web-based software package developed for systematic review data management. We scanned for exact article duplicates, author/title duplicates, and title duplicates using the duplication check feature in both ProCite® and SRS 3.0. Additionally, this database was used to track the search results at title review, abstract review, article inclusion/exclusion, and data abstraction levels. A list of excluded articles is presented in Appendix D.

## Study Selection

Study selection proceeded in two phases: title review and abstract review. Two independent reviewers conducted title scans in a parallel fashion. For a title to be eliminated at this level, both reviewers had to indicate that it was ineligible. If the two reviewers did not agree on the eligibility of an article, it was promoted to the next level (see Appendix E, Title Review Form). The title review phase was designed to capture as many studies as possible reporting on the efficacy or safety of oral diabetes medications. All titles that were thought to address efficacy, effectiveness, or safety were promoted to the abstract review phase.

The abstract review phase was designed to identify studies reporting on the effects of oral diabetes medications on proximal clinical outcomes, distal diabetes-related complications, quality of life, or adverse events. Abstracts were reviewed independently by two investigators, and were excluded if both investigators agreed that the article met one or more of the exclusion criteria (see inclusion and exclusion criteria listed in Table 2). Differences in opinions regarding abstract inclusion or exclusion were resolved through consensus adjudication.

Table 2 Inclusion and exclusion criteria

Population and condition of interest | - All studies included patients with type 2 diabetes, non-insulin dependent diabetes mellitus, or adult-onset diabetes. We excluded studies that evaluated only patients with type I diabetes, impaired glucose tolerance, metabolic syndrome, maturity onset diabetes of youth, and gestational diabetes.; - All studies included human subjects.; - We excluded studies if they included only pregnant women or only subjects less than or equal to 18 years of age.
Interventions | - All studies must have evaluated an oral diabetes medication or drug combination of interest.; - Oral diabetes medications included thiazolidinediones (rosiglitazone and pioglitazone), biguanides (metformin and metformin XR), second generation sulfonylureas (glibenclamide, gliclazide, glipizide, glipizide GITS, glyburide, and glimepiride), meglitinides (nateglinide and repaglinide), and alpha-glucosidase inhibitors (acarbose, miglitol, and voglibose).; - We only included medications not used in the United States (gliclazide and voglibose) in head-to-head trials with oral diabetes medications that were used in the United States.; - Glibenclamide, while not used in the United States, is the chemical equivalent of glyburide, and was included in the same way as the other oral diabetes medications used in the United States.; - Drug combinations included are Avandamet^®^, Glucovance^®^, Metaglip^™^, and combinations of 2 oral medications that include a thiazolidinedione, metformin, or a second generation sulfonylurea.; - We excluded studies that evaluated troglitazone, first generation sulfonylureas, insulin, combinations of oral diabetes medications added to insulin or specific combinations of oral diabetes medications that included acarbose, miglitol, nateglinide, or repaglinide and did not include at least two other study arms that would otherwise have been included in the review.
Comparisons of interest | - We included studies that compared oral diabetes medications or drug combinations to another oral diabetes medication or drug combination of interest, placebo, or other non-drug intervention (e.g., diet and exercise).; - We excluded studies with comparisons to insulin or comparisons to medications or drug combinations that are not included in the review.; - We excluded dosing studies that did not have a placebo or control arm.
Outcomes | - We excluded studies that did not apply to the key questions.; - For Key Question 1, we included the following outcomes: glycated hemoglobin, HbA1c, HbA1, weight, BMI, SBP, DBP, serum lipid levels (HDL, LDL, TG), and 2 hour PPG.; - We did not include data on total cholesterol or other measures of glycemic variability.; - For Key Question 2, we included the following outcomes: mortality, coronary artery disease, myocardial infarction, stroke, transient ischemic attack, retinopathy, nephropathy (including microalbuminuria, urine albumin/creatinine ratio, serum creatinine, glomerular filtration rate, creatinine clearance, proteinuria/albuminuria, end stage renal disease, and renal replacement therapy or transplant), neuropathy, peripheral arterial disease or amputations.; - We excluded biologic markers of outcomes, such as vascular endothelial function or carotid intima medial thickness.; - We included serious cardiovascular outcomes such as ventricular fibrillation, restenosis rates, or serious EKG abnormalities (i.e., life-threatening arrhythmias or prolongued QTc interval) as part of cardiovascular disease morbidity. We excluded left ventricular hypertrophy since this was considered a less serious outcome.; - For Key Question 3, we included quality of life and functional status.; - For Key Questions 4 and 5, we included the following outcomes: hypoglycemia, liver failure, CHF, lactic acidosis, cancer, anemia, thrombocytopenia, leucopenia, allergic reactions requiring hospitalization or death, elevated aminotransferase levels, edema, hypervolemia, GI problems, and withdrawals due to unspecified adverse events.
Type of study | - We excluded articles not written in English, studies less than 3 months in duration, studies with less than 40 total subjects, editorials, comments, letters, and abstracts.; - For Key Question 1, we included only RCTs.; - For Key Questions 2 and 3, we included only RCTs, non-RCTs, and retrospective or prospective cohort studies with a comparison group.; - For Key Questions 4 and 5, we included randomized and non-randomized trials, retrospective or prospective cohort studies with or without a comparison group, and case-control studies.; - For all the key questions, we excluded case reports and case series.

Hb = hemoglobin; BMI = body mass index; HDL = high density lipoprotein; LDL = low density lipoprotein; TG = triglycerides; CHF = congestive heart failure; EKG = electrocardiogram; XR = extended release; GITS = gastrointestinal therapeutic system; GI = gastrointestinal; RCT = randomized controlled trial

Full-text articles initially selected on the basis of abstract review underwent another independent parallel review by investigators to determine if they should be included for full data abstraction. At this phase of the review, investigators determined which of the Key Questions each article addressed (see Appendix E, Article Inclusion/Exclusion Form). Differences in opinions regarding article inclusion were resolved through consensus adjudication.

## Data Abstraction

We used a systematic approach for extracting data to minimize the risk of bias in this process. By creating standardized forms for data extraction, we sought to maximize consistency in identifying all pertinent data available for synthesis. If reviewers determined that an article addressed both efficacy and safety, multiple data abstraction forms were used.

Each article underwent double review by study investigators of data abstraction and assessment of study quality. The second reviewer confirmed the first reviewer's data abstraction forms for completeness and accuracy. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer re-reviewed a random sample of articles by the first two reviewers to ensure consistency in the data abstraction of the articles. Reviewers were not masked to the articles' authors, institution, or journal. ^37^ In most instances, data were directly abstracted from the article. If possible, relevant data were also abstracted from figures. Differences in opinion were resolved through consensus adjudication. For assessments of study quality, each reviewer independently judged study quality and rated items on quality assessment forms (see Appendix E, Data Abstraction Review Forms).

For all articles containing original data, reviewers extracted information on general study characteristics (e.g., study design, study period and followup), study participants (e.g., age, gender, race, weight/body mass index (BMI), HbA1c levels, and duration of diabetes), eligibility criteria, interventions (e.g., initial, maximum, and mean doses, frequency of use, and duration of use), outcome measures and the method of ascertainment, and the results of each outcome, including measures of variability (see Appendix E, Data Abstraction Review Forms).

We also abstracted data from systematic reviews that specifically applied to our Key Questions (see Appendix E, Data Abstraction Review Forms). Several recent systematic reviews have been published to address the efficacy and safety of oral diabetes medications. ^1,^ ^7,^ ^19,^ ^38,^ ^39^ Data from systematic review articles were abstracted including: 1) the types of medications and comparisons included in the review, 2) exclusion criteria, 3) search strategies (databases, search terms), 4) range of publication dates of reviewed articles, 5) number of articles in the review, 6) assessment of publication bias, 7) outcomes evaluated, and 8) main conclusions.

All information from the article review process was entered into the SRS 3.0 database by the individual completing the review. Reviewers entered comments into the system whenever applicable. The SRS 3.0 database was used to maintain and clean the data, as well as to create detailed evidence tables and summary tables (see Appendix F and Summary Tables).

## Quality Assessment

Article quality was assessed differently for RCTs and systematic reviews. For RCTs the dual, independent review of article quality was based on the Jadad criteria: ^40^ 1) appropriateness of the randomization scheme, 2) appropriateness of the blinding, and 3) description of withdrawals and drop-outs. For each RCT, we created a score between 5 (high quality) to 0 (low quality). We had 85 percent consistency between the primary and secondary reviewer; therefore, we report only the second reviewers' quality scores (the second reviewers generally had more research experience than the primary reviewers). We used study quality to help assess differences between study results.

The quality of each systematic review was assessed using the following criteria: 1) whether the question being addressed by the review was clearly stated; 2) comprehensiveness of search methods used and described in the report; 3) whether inclusion/exclusion criteria were clearly defined and appropriate; 4) whether analyses were conducted to measure variability in efficacy; 5) whether study quality was assessed and done appropriately (using validated instruments); 6) whether differences in how outcomes were reported and analyzed across studies were taken into consideration; 7) whether the study methodology was reproducible; and 8) whether conclusions were supported by the data presented. ^41^

We did not assess the quality of observational studies or non-randomized trials. There is little agreement on the methods for assessing study quality of observational studies. ^42^ Because observational studies and non-randomized trials are inherently weaker study designs than RCTs, we synthesized these results separately from the RCT results. The results of these studies were assessed for congruence with the RCTs. If results were inconsistent with RCTs or there were few RCTs, we then described these studies in more depth including any adjustments for confounding.

## Applicability

Throughout the report, we discuss the applicability of studies in terms of how well the study population seems consistent with the type 2 diabetes general population. Additionally, we report on dosing and study duration in the text, and use metaregression to identify potential differences in results based on these characteristics. We then discuss these applicability issues in our limitations sections.

## Data Analysis and Synthesis

For each Key Question, we created a set of detailed evidence tables containing all information extracted from eligible studies. For the proximal clinical measures (Key Question 1), we conducted meta-analyses for the following higher priority outcomes when there were sufficient data (> 2 or 3 trials) and studies were homogenous with respect to key variables (population characteristics, study duration, and drug dose): HbA1c, weight, systolic blood pressure (SBP), LDL, and TG. The outcomes of 2 hour PPG, diastolic blood pressure (DBP), and HDL were similar to other outcome measures (HbA1c, SBP, and LDL respectively), and we did not conduct meta-analyses since they were generally redundant.

We recorded the mean difference between groups along with its measure of dispersion. If this was not reported, we calculated the point estimate using the mean difference from baseline for each group. If the mean difference from baseline was not reported, we calculated this from the baseline and final values for each group. If no measure of dispersion was reported for the between-group difference, we then calculated it using the sum of the variances for the mean difference from baseline for each group. If there were no measures of dispersion for the mean difference from baseline for each group, we then calculated the variance using the standard deviation of the baseline and final values, assuming a correlation between baseline and final values of 0.5. If data were only presented in graphical form, we abstracted data from the graphs. For trials that had more than one dosing arm, we chose the arm that was most consistent with dosing in the other trials. When more than one follow-up interval was reported in the UKPDS we used the data from the followup most similar to the other trials. We then reported the rest of the UKPDS results in a narrative fashion.

Pooled estimates (weighted mean differences) of the RCTs were determined using a random effects model with the DerSimonian and Laird formula for calculating between-study variance. ^43^ The random effects model was used due to unmeasured heterogeneity that likely exists among trials, and the 95 percent confidence interval (CI) reports the range of potential point estimates. When data were not sufficient to combine studies in a meta-analysis, we summarized the outcomes by reporting the ranges of values for mean differences from baseline or mean differences between groups (when possible).

For diabetes-related complications and quality of life (Key Questions 2 and 3) there were too few similar trials for each drug comparison to combine these results in a meta-analysis.

For Key Questions 4 and 5, we were unable to conduct meta-analyses on most of the adverse events due to methodologic diversity among the trials such as differences in definitions of selected adverse events or lack of sufficient numbers of trials to combine. When there were sufficient data on one of the primary adverse events (e.g., hypoglycemia) and the studies were considered to be similar with respect to important variables (population characteristics, drug comparisons, drug dosage, definition of adverse event, and followup time), we performed meta-analyses. Almost all the trials were less than one year. UKPDS was described separately since this RCT was very different from the other trials, and had a much longer study duration (mean followup 10.7 years). ^15^ ^16^ For trials that had more than one dosing arm, we chose the arm that was most consistent with dosing in the other trials.

We represented the pooled data using absolute risk differences since this may be more easily interpreted than a relative risk in the clinical setting. We calculated pooled effect estimates of the absolute risk difference between trial arms from the RCTs, with each study weighted by the inverse of the study variance, using a random effects model with the DerSimonian and Laird formula for calculating between-study variance. ^43^

Heterogeneity among the trials in all the meta-analyses was tested using a standard chi-squared test using a significance level of alpha less than or equal to 0.10. We also examined heterogeneity among studies with an I^2^ statistic, which describes the variability in effect estimates that is due to heterogeneity rather than random chance. ^44^ A value greater than 50 percent may be considered to have substantial variability. If heterogeneity was found, we attempted to determine potential reasons by conducting metaregression using study level characteristics such as double-blinding, study duration, and dose ratio (dose ratio of drug 1 divided by dose ratio of drug 2). The dose ratio for each drug was calculated as the dose given in the study divided by the maximum approved dose of drug. We conducted sensitivity analyses by omitting one study at a time to assess the influence of any single study on the pooled estimate.

Additionally, we conducted indirect comparisons when there were too few direct comparison results (<3 trials), and there were sufficient placebo-controlled trials (>2 trials) for each drug being compared. The indirect comparison point estimates were calculated as the difference between the placebo-controlled trial pooled estimates, and the measures of variability were calculated using the sum of the variances from the placebo-controlled trial meta-analyses. ^45^

Because statistically significant findings are more likely to be published than studies without statistically significant results (publication bias), we examined whether there was evidence that smaller, negative studies appeared to be missing from the literature. We therefore conducted formal tests for publication bias using Begg's ^46^ and Eggers tests ^47^ including evaluation of the asymmetry of funnel plots for each comparison of interest for the following outcomes where meta-analyses were conducted: A1c, weight, SBP, LDL, TGs, and hypoglycemia.

All statistical analyses were conducted using STATA (Intercooled, version 8.0, StataCorp, College Station, TX).

## Data Entry and Quality Control

After a second reviewer reviewed data that had been entered into SRS^®^ 3.0, adjudicated data were re-entered into web-based data collection forms by the second reviewer. Second reviewers were generally more experienced members of the research team. In addition, a lead investigator examined a random sample of the reviews to identify problems with data abstraction. If problems were recognized in a reviewer's data abstraction, the problems were discussed at a meeting with the reviewers. In addition, research assistants used a system of random data checks to assure data abstraction accuracy.

## Rating the Body of Evidence

At the completion of our review, we graded the quantity, quality and consistency of the best available evidence addressing Key Questions 1, 2 and 3 by adapting an evidence grading scheme recommended by the GRADE Working Group. ^48^ We applied evidence grades to bodies of evidence on each type of intervention comparison for each major type of outcome. We assessed the strength of the study designs with RCTs considered best, followed by non-RCTs, and observational studies. To assess the quantity of evidence, we focused on the number of studies with the strongest design. We also assessed the quality and consistency of the best available evidence, including assessment of limitations to individual study quality (using individual quality scores), certainty regarding the directness of the observed effects in studies, precision and strength of findings, and availability (or lack thereof) of data to answer the Key Question.

We classified evidence bodies pertaining to Key Questions 1–3 into four basic categories: 1) “high” grade (indicating confidence that further research is very unlikely to change our confidence in the estimated effect in the abstracted literature); 2) “moderate” grade (indicating that further research is likely to have an important impact on our confidence in the estimates of effects and may change the estimates in the abstracted literature); 3) “low” grade (indicating further research is very likely to have an important impact on confidence in the estimates of effects and is likely to change the estimates in the abstracted literature); and 4) “very low” grade (indicating any estimate of effect is very uncertain). We graded the body of evidence as “insufficient” if a drug comparison had less than 3 studies.

We did not grade the body of evidence for Key Questions 4, 5 and 6 since the system for grading of the body of evidence was developed for questions of efficacy not safety.

## Peer Review and Public Commentary

A draft of the completed report was sent to the technical experts and peer reviewers, as well as to the representatives of AHRQ and the Scientific Resource Center. Based on comments from AHRQ, revisions were made to the draft report and posted to a website for public comment. In response to the comments of the technical experts, peer reviewers, and the public, revisions were made to the evidence report, and a summary of the comments and their disposition was submitted to AHRQ.