# 1 Introduction

## Background

Type 2 diabetes is characterized by insulin resistance, which is accompanied by a progressive deficiency in insulin secretion. Type 2 diabetes is an increasingly common disease that is closely associated with obesity. ^1,^ ^2^ In 2005, the prevalence of Americans with diagnosed type 2 diabetes was 2.4% in the United States for adults aged 20 to 39 years, 10% for adults aged 40 to 59 years, and 21% in adults aged 60 years or over. ^3^ From 1980 through 2004, the number of Americans with diagnosed diabetes more than doubled, from 5.8 million to 14.7 million. ^4^ There were similar incidence rates of diabetes for men and women in the Third National Health and Nutrition Survey (NHANES III), but the rates for non-Hispanic blacks and Mexican-Americans were 1.6 and 1.9 times the rate for non-Hispanic whites. ^1^

Randomized controlled trials (RCTs) and observational studies have shown that improved glycemic control reduces microvascular complications and may reduce macrovascular complications; ^5^ – ^9^ however, the effects of specific oral diabetes medications on these outcomes are less certain. As oral diabetes medications such as the thiazolidinediones and meglitinides have become available for the treatment of diabetes, clinicians and patients have been forced to choose from a bewildering array of medications. Confusion has increased because of emerging concerns that particular medications confer excess cardiovascular risks when compared to other oral diabetes medications or placebo. ^10^ – ^14^

The well-known results of the United Kingdom Prospective Diabetes Study (UKPDS) indicated that when oral diabetes medications have similar effects on glycemic control, these medications have similar effects on cardiovascular morbidity and mortality. ^15,^ ^16^ However, the UKPDS was conducted prior to the emergence of thiazolidinediones. ^7^ In addition, several systematic reviews of oral diabetes medications have shed light on differences in short-term and long-term outcomes of different oral diabetes medications. ^17^ – ^25^ However, only two reviews have compared all of the oral diabetes medications commonly used in the United States. ^24,^ ^25^ A systematic review by Inzucchi et al., in 2002, found that: 1) with the exception of the alpha-glucosidase inhibitors, which decrease hemoglobin A1c (HbA1c) by 0.5–1%, most diabetes medications lower HbA1c to a similar extent, producing an absolute reduction of about 1–2%; 2) when medications are used in combination, additional glucose-lowering benefits are seen; and 3) long-term vascular risk reduction can be demonstrated only with sulfonylureas and metformin. ^24^ In 2004, Buse et al. compared the effects on serum lipid levels of all the oral diabetes medications. They found that only metformin, acarbose, voglibose, rosiglitazone, and pioglitazone had significant effects on serum lipid levels. Metformin at high doses and pioglitazone both reduced triglycerides (TGs), while acarbose, rosiglitazone, and pioglitazone increased high density lipoproteins (HDLs). Finally, acarbose decreased low density lipoprotein (LDL), while rosiglitazone increased LDL. ^25^

Many other outcomes in addition to HbA1c and lipid levels are important to consider when oral diabetes medications are being compared. These outcomes include blood pressure, weight, microvascular and macrovascular disease, and mortality. Evaluation of adverse events is critical because adverse events affect adherence as well as morbidity and mortality. Certain diabetes medications may be less safe for persons with comorbid conditions. For instance, biguanides such as metformin are contraindicated in patients with renal or liver failure because of a potentially higher risk of lactic acidosis. ^26^ To date, no study has comprehensively evaluated all of the major short-term and long-term clinical effects of all the oral diabetes medications used in the United States.

We have therefore performed a systematic review of published studies on the comparative effectiveness and safety of all oral diabetes medications. By comparing the short-term and long-term clinical effects of these medications, clinicians may have a better sense of how to choose among the oral diabetes medications. This review should be helpful as new classes of oral diabetes medications come on the market, such as the dipeptidyl peptidase-IV (DPP-IV) inhibitors. In addition, the results presented here may provide policymakers and insurers with better insight as they consider policies relating to medication coverage.

## Conceptual Model

Our conceptual model (see Figure 1) summarizes the oral diabetes medications, their main physiologic actions, and their effects on proximal clinical measures and distal clinical outcomes, including potential adverse effects. Thiazolidinediones' main physiologic action is increased uptake of glucose by cells. Sulfonylureas and insulin secretagogues both work on the pancreatic beta cell to release insulin. Metformin works by inhibiting glucose production by the liver, and alpha-glucosidase inhibitors decrease the absorption of glucose in the gut.

Figure 1 Conceptual framework of medication activity for adults with type 2 diabetes (bold lettering indicates outcomes evaluated in this systematic review)

These medications were developed to affect proximal clinical measures, such as glycated hemoglobin or glycemic variability, that are associated with important distal clinical outcomes. They may also affect other proximal clinical measures, such as blood pressure and lipid levels, which have been associated with distal outcomes, including mortality and complications of diabetes. ^27,^ ^28^ Glycated hemoglobin is a way to measure glucose control over the past 3 months in persons with diabetes. Glycated hemoglobin is a general term for any hemoglobin that has glucose bound to it, and it can refer either to HbA1c or hemoglobin A1 (HbA1), an older way to measure hemoglobin with bound glucose. These laboratory measures have been used to measure glycemic control. Most studies report HbA1c in both the research and clinical setting. Clinical guidelines in the U.S. suggest that in order to minimize morbidity and mortality in patients with diabetes, the HbA1c should be less than 6.5% or less than 7%, depending on the organization issuing the guideline. ^29^ – ^31^ Another measure, 2-hour postprandial glucose (PPG), a measure of glycemic variability, is an independent predictor of cardiovascular disease and is of special importance in patients with normal or near-normal HbA1c. ^32^

Hyperglycemia has been linked to microvascular and macrovascular complications through a variety of mechanisms: 1) increased glycosylation of proteins, which adversely affects organs such as the kidney, vascular beds, and connective tissue; 2) increased production of sorbitol, which generates reactive oxygen species and causes cellular and enzyme dysfunction that can affect vessels and organs; 3) increased formation of diacylglycerol, which not only increases protein kinase C, thereby altering the transcription of genes for proteins involved in endothelial cells and neurons, but may also increase growth factors that play a role in microvascular disease; and 4) increased production of fructose-6-phosphate, which increases growth factor levels and glycosylation of proteins, both of which in turn adversely affect vessels and organs. ^33^ These effects on cells, tissues, and organs lead to the macrovascular and microvascular complications seen in diabetes.

We did not evaluate the proximal clinical measures of insulin and C-peptide levels in this report. The clinical question addressed here is whether different pharmaceutical agents affect the rate of decline in beta cells that occurs with type 2 diabetes. To answer this question, there is a need for a long-term (5–10 year) controlled study evaluating C-peptide and insulin levels at multiple points in time using glucose clamp tests, not just fasting C-peptide and insulin levels measured once after 3 months. Currently, no studies exist to answer this clinically relevant question; therefore, we excluded this clinical measure from our review. Also, proximal measures of inflammatory markers such as C-reactive protein were excluded from our review. Although this is an interesting area that is currently being explored, it would be premature to suggest that decreasing inflammation improves diabetes-related morbidity and mortality.

We have included an evaluation of potential adverse effects of oral diabetes medications, such as hypoglycemia, congestive heart failure (CHF), and lactic acidosis. All diabetes medications may cause hypoglycemia, since each one has a mechanism of action that is designed to reduce hyperglycemia. Some adverse events, such as CHF or lactic acidosis, may be a complication of diabetes or a side-effect of a medication.

We also sought to evaluate the effects of oral diabetes medications on health-related quality of life and functional status, since the macrovascular and microvascular complications of diabetes and the adverse effects of treatment can affect quality of life or functional status. While all of these complications have an economic impact, we did not evaluate the effect of treatment on costs. Instead, we provide limited information on the cost of medications, so that readers can make indirect determinations related to economic impact (see Table 1). We have not assessed the data on adherence to oral diabetes medications, since this subject is beyond the scope of the present report. In general, adherence is improved with lowered pill burdens and fewer doses per day of medication, and we can assume that this relationship holds true for diabetes medications. ^34^

Table 1 Characteristics of selected oral diabetes medications evaluated

Drug | Trade name | Dosing | Half-life | Labeled indications | Dose adjustments, monitoring, precautions | Cost in US dollars*
Thiazolidinediones
Pioglitazone | Actos | 15–30 mg od; max: 45 mg od | 3–7 hours | Management type 2 diabetes | 1) Do not initiate if active liver disease or increased transaminases (>2.5 times the upper limit of normal); 2) Not recommended in Class III or IV heart failure; 3) Monitor liver enzymes prior to initiation and periodically during treatment | 15 mg (30): $102.55
| | | | | | 30 mg (30): $162.99
| | | | | | 45 mg (30): $179.99
Rosiglitazone | Avandia | 4–8 mg od or 2–4 mg bid; max: 8 mg od usually or 4 mg od with insulin or sulfonylurea | 3–4 hours | Management type 2 diabetes | 1) Do not initiate if active liver disease or increased transaminases (>2.5 times the upper limit of normal); 2) Not recommended in Class III or IV heart failure; 3) Monitor liver enzymes prior to initiation and periodically during treatment | 2 mg (60): $133.31
| | | | | | 4 mg (30): $105.53
| | | | | | 8 mg (30): $175.08
Biguanides
Metformin | Glucophage, Glucophage XR | 500–2550 mg divided doses (od-tid); max: 2550 mg; 2000 mg for XR | 6.2 hours | Management type 2 diabetes | 1) Contraindicated in the presence of renal dysfunction (Cr >1.5 mg/dL in males, or >1.4 mg/dL in females); 2) Avoid in liver disease; 3) In elderly, dose with caution and titrate slowly; 4) Discontinue prior to contrast studies; 5) Initial and periodic monitoring of hematologic parameters and renal function at least annually Check vitamin B12 and folate if anemic | Tablets (Metformin HCl)
| | | | | | 500 mg (60): $33.99
| | | | | | 850 mg (60): $51.99
| | | | | | 1000 mg (60): $55.99
| | | | | | Tablet, 24-hour (Metformin HCl)
| | | | | | 500 mg (60): $39.99
Second generation sulfonylureas
Glimepiride | Amaryl | 1–8 mg od. max: 8 mg od | 5–9 hours | Management type 2 diabetes | 1) In elderly and renal dysfunction (CrCl<22mL/min), start dose at 1 mg and titrate slowly due to concern of hypoglycemia; 2) Watch for symptoms of hypoglycemia | 1 mg (30): $9.99
| | | | | | 2 mg (30): $13.99
| | | | | | 4 mg (30): $14.99
Glipizide | Glucotrol, Glucotrol XL or GITS | 5 – 15 mg od or 5 – 20 mg bid; max dose: 20 mg bid. 20 mg od XL | 2–4 hours | Management type 2 diabetes | 1) In elderly, hepatic, and renal dysfunction, start dose at 2.5 mg od and titrate slowly; 2) Watch for symptoms of hypoglycemia | Tablet, 24-hour
| | | | | | 2.5 mg (30): $10.99
| | | | | | 5 mg (30): $10.99
| | | | | | 10 mg (30): $19.99
| | | | | | Tablets
| | | | | | 5 mg (60): $9.99
| | | | | | 10 mg (60): $10.99
Glyburide | Micronase, Diabeta, Glynase Prestab | 2.5–20 mg od or bid; max dose: 20 mg od | 5–16 hours | Management type 2 diabetes | 1) Not recommended for patients with renal dysfunction (CrCl<50 mL/min); 2) Avoid use in severe hepatic impairment; 3) In elderly, start at 1.25 mg and titrate slowly. Watch for hypoglycemia | Tablets
| | | | | | 1.25 mg (30): $7.99
| | | | | | 2.5 mg (30): $7.99
| | | | | | 5 mg (30): $7.99
Meglitinides
Repaglinide | Prandin | 0.5–4 mg before meals; max:16 mg | 1 hour | Management type 2 diabetes *Not indicated for use in combination with NPH insulin due to potential cardiovascular events | 1) Use with caution in patients with severe renal and hepatic impairment. Start at lowest dose and titrate slowly | 0.5 mg (90): $104.77
| | | | | | 1 mg (90): $111.10
| | | | | | 2 mg (90): $111.10
Nateglinide | Starlix | 60–120 mg before meals | 1.5 hours | Management type 2 diabetes | 1) Use with caution in patients with severe renal and hepatic impairment as well as the elderly. Start at lowest dose and titrate slowly | 60 mg (30): $39.51
| | | | | | 120 mg (30): $43.20
Alpha-glucosidase inhibitors
Acarbose | Precose | 25–100 mg tid; max: 100 mg tid | 2 hours | Management type 2 diabetes | 1) Serum transaminase levels should be checked every 3 months during the first year of treatment and periodically thereafter; 2) Not recommended for severe renal impairment (CrCl<25 mL/min) | 25 mg (90): $67.87
| | | | | | 50 mg (90): $70.25
| | | | | | 100 mg (90): $80.97
Miglitol | Glyset | 25–100 mg tid. max: 100 mg tid | 2 hours | Management type 2 diabetes | 1) Not recommended for severe renal impairment (CrCl<25 mL/min) | 25 mg (90): $63.02
| | | | | | 50 mg (90): $69.07
| | | | | | 100 mg (90): $81.20

od=once daily, bid=twice a day, tid=three times a day, CrCl = creatinine clearance, max=maximum daily dosage, mg = milligrams, dL = deciliter, XR = extended release, HCl = hydrogen chloride, mL = milliliter; min = minute, XL = extended release, GITS = gastrointestinal therapeutic system, NPH = neutral protamine Hagedorn

Used www.uptodate.com for pharmaceutical information. ^35^

* Information provided includes dose, pill count, and cost in US dollars. ^36^

Finally, we sought to determine the extent to which comorbid conditions such as renal and liver disease may alter the effects of oral diabetes medications. For instance, if a medication is cleared by the kidney, its effects may be potentiated in a person with kidney disease.

## Scope and Key Questions

This systematic review was commissioned by the Agency for Healthcare Research and Quality (AHRQ) to address the following key questions:

1 Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to affect the following proximal clinical outcomes: glycated hemoglobin, weight, blood pressure, serum lipid levels, and 2-hour PPG levels?
2 Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to affect distal diabetes-related complications, including mortality and the following macrovascular and microvascular complications: coronary artery disease, myocardial infarction, stroke, transient ischemic attack, arrhythmia, coronary artery stenosis and in-stent re-stenosis, retinopathy, nephropathy, neuropathy, and peripheral arterial disease?
3 Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their ability to influence other health outcomes, including quality of life and functional status?
4 Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in terms of risk of the following life-threatening adverse events: life-threatening hypoglycemia leading to emergency care or death; liver failure; CHF; severe lactic acidosis; cancer; anemia, thrombocytopenia, or leucopenia requiring transfusion; and allergic reactions leading to hospitalization or death?
5 Do oral diabetes medications for the treatment of adults with type 2 diabetes differ in their safety with regard to the following adverse events that are not life-threatening: hypoglycemia requiring any assistance; elevated aminotransferase levels; pedal edema; hypervolemia; anemia, thrombocytopenia, and leucopenia not requiring transfusion; mild lactic acidosis; and gastrointestinal (GI) problems?
6 Do the safety and effectiveness of oral diabetes medications for the treatment of adults with type 2 diabetes differ across particular adult populations, such as those based on demographic factors (e.g., race/ethnicity, age greater than 65 years, or gender) or comorbid conditions (e.g., renal insufficiency, CHF, liver disease, obesity, depression, or schizophrenia)?