# Acknowledgments

The Evidence-based Practice Center thanks Karen Robinson for her assistance in developing the search strategies; Tina Hai, Kayla Cunningham, Mohan Kumar, Gabriel Lai, Stephanie Chang, and Lori Bash for their assistance with article reviewing and data entry; Mark Newgent for his help formatting and editing the report; Brenda Zacharko for her assistance with final preparations of the report; and Eliseo Guallar for his help with the meta-analyses and methodology of the report.

## Technical Expert Panel

- Nathaniel Clark, M.D., M.S., R.D.
- American Diabetes Association
- Alexandria, VA

- Susan Norris, M.D., M.P.H., M.Sc.
- Oregon Health and Science University
- Portland, OR

- Sheila Roman, M.D., M.P.H.
- Johns Hopkins Medical Institutions
- Centers for Medicare & Medicaid Services
- Baltimore, MD

- Leonard Pogach, M.D.
- Office of Patient Care Services, Veterans
- Health Administration
- Veterans Administration Health Care System
- East Orange, NJ

- Chris Saudek, M.D.
- Johns Hopkins School of Medicine
- Baltimore, MD

- Sherita Golden, M.D.
- Johns Hopkins School of Medicine
- Baltimore, MD

## AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Steven Fox, M.D., M.P.H.
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD