# Results

## Introduction

This chapter is organized by Key Question (KQ) and then grouped by intervention/exposure category. Briefly, we wanted to compare the effectiveness of organizational characteristics, structures, and processes of care in nursing homes (NHs) and other residential long-term care settings on four types of outcomes: health outcomes for people with dementia (KQ 1), psychosocial outcomes for people with dementia (KQ 2), health outcomes for informal caregivers of people with dementia (KQ 3), and psychosocial outcomes for informal caregivers of people with dementia (KQ 4). KQ 5 assessed whether the effect of organizational characteristics, structures, or processes of care on health and psychosocial outcomes varied by the characteristics of the person with dementia (e.g., severity of dementia, functional status) or of the informal caregiver (e.g., age, relationship, health status); we report on relevant KQ 5 studies only in the context of KQs 1 to 4.

People who reside in long-term care settings are often referred to as residents; generally speaking, the term “residents” refers to people who do and do not have dementia. For ease of reading, we refer to people with dementia as residents; unless otherwise noted, however, our comments are relevant only to those residents who have dementia.

## Results of Literature Searches

Results of our literature searches appear in Figure 2. We ultimately included 14 published articles: 9 randomized controlled trials (RCTs), 1 nonrandomized controlled trial, and 4 prospective cohort studies. We recorded the reason that each excluded full-text publication did not satisfy the eligibility criteria and compiled a comprehensive list of such studies (Appendix B). Evidence tables for included studies can be found in Appendix C.

Figure 2 Disposition of articles

CINAHL = Cumulative Index to Nursing and Allied Health Literature; No = number; PICOTS = populations, interventions/exposures, comparators, outcomes, timing, settings

Figure 2 is titled “Disposition of articles.” The figure is a flow chart that summarizes the search and selection of articles: There were 5,868 citations identified by searching MEDLINE®, Embase, the Cochrane Library, CINAHL®, AgeLine® and PsycINFO®. In addition, 341 references were identified by searching reference lists of selected articles. After removal of duplicate citations, titles and abstracts of 6,209 references were screened for potential inclusion. Of these, 786 were deemed appropriate for full-text review in order to determine eligibility. After full-text review, 772 were excluded: 301 failed to meet at least one PICOTS element; 289 were the wrong type of publication or wrong study design; 132 were conducted in a country other than the United States, 28 had a sample size that was too small, 7 reported on data collected prior to 1990, and 15 were deemed poor quality. Fourteen articles are included in this report's qualitative synthesis.

## Description of Included Studies

Table 5 outlines the characteristics of the 14 included studies. Half the studies examined the effectiveness of an intervention/exposure among a population ranging in dementia severity from mild to severe.25, 34-39 One study included a population with moderate to severe dementia severity40 and two studies focused on populations with severe dementia.41, 42 A few studies did not report enough information (e.g., range on the Mini-Mental State Examination, Minimum Data Set Cognition Scale, or Global Deterioration Scale) to determine the extent of cognitive impairment or dementia severity of the population.43-46

Table 5 Characteristics of all included studies

Characteristics | Author, Year, Design Duration Quality | Dementia Severity^a^ | Baseline Cognitive Impairment | Sample Size | Setting | Interventions/Exposures
Organizational | Leon and Ory, 1999^36^ Prospective cohort 6 months Fair | Mild to severe | MDS-COGS Overall: 6.03 G1: 6.23 G2: 5.49 | G1: 495 G2: 200 | SCU, Non-SCU | G1: SCU within NH G2: Non-SCU within NH
Organizational | Sloane et al., 2005^39^ Prospective cohort 12 months Good | Mild to severe | MDS-COGS G1: 5.3 G2: 5.7 | G1: 773 G2: 479 G3: 164 G4: 607 G5: 94 G6: 385 | RC/AL, NH | G1: RC/AL G2: NH G3: SCU within RC/AL G4: Non-SCU within RC/AL G5: SCU within NH G6: Non-SCU within NH
Organizational | Sloane et al., 2008^44^ Prospective cohort 1 month Good | NR | NR | G1: 175 G2: 247 | RC/AL, NH | G1: RC/AL G2: NH
Organizational | Zimmerman et al., 2005^25,b^ Prospective cohort 6 months Fair | Mild to severe | MMSE or MDS-COGS Mild to moderate: 152 Severe to very severe: 259 | G1: 48 G2: 101 G3: 135 G4: 137 | RC/AL, NH | G1: RC/AL – settings with <16 beds G2: RC/AL traditional – settings with ≥16 beds, not meeting new-model criteria G3: New-Model: RC/AL settings with ≥16 beds of the “new-model” type G4: NH
Structures of Care | Dowling et al., 2005^34^ RCT 10 weeks Fair | Mild to severe | MMSE Overall: 6.7; range 0 to 23 | G1: 29 G2: 17 | NH | G1: Morning bright light exposure (9:30–10:30 a.m., >2,500 lux in gaze direction) G2: Control - Usual indoor light levels (150–200 lux)
Structures of Care | Hickman et al., 2007^35^ RCT 3 weeks Fair | Mild to very severe | MDS-COGS^c^ Mild to Moderate Men: 34.3% Women: 29.0% Severe Men: 42.9% Women: 51.6% Very Severe Men: 22.9% Women: 19.4% | G1: 32 G2: 46 G3: 47 G4: 48 | Geriatric unit and SCU | G1: Morning bright light (7 a.m.–11 a.m.) G2: Evening bright light (4 p.m.–8 p.m.) G3: All-day bright light (7 a.m.–8 p. m.) G4: Standard light (7 a.m.–8 p. m.)
Structures of Care | Zimmerman et al., 2005^25,b^ Prospective cohort 6 months Fair | Mild to severe | MMSE or MDS-COGS Mild to moderate: 152 Severe to very severe: 259 | G5: NR G6: NR | RC/AL, NH | G5: Use of specialized workers (staff fill specialized roles) G6: No use of specialized workers
Processes of Care | Fritsch et al., 2009^43^ RCT 10 weeks Fair | NR | NR | G1: 10 SCUs G2: 10 SCUs | SCU in NHs | G1: TimeSlips – group storytelling program that encourages creative expression among people with dementia G2: Control – no intervention
Processes of Care | Kovach et al., 2006^41^ RCT 4 weeks Good | Severe | MMSE G1: 7.35 G2: 8.26 Overall: 7.81 | G1: 57 G2: 57 | NH | G1: Serial trial intervention – multistep clinical protocol for assessment and management of unmet needs in people with late-stage dementia G2: Control – curricula included common misconceptions about aging, reversible and irreversible causes of dementia, stages of AD, approaches to treating behaviors, and physical conditions associated with dementia
Processes of Care | Remington, 2002^37^ RCT 10 minutes Fair | Mild to severe | NR | G1: 17 G2: 17 G3: 17 G4: 17 | NH | G1: Calm music (10 minutes) G2: Hand massage (10 minutes) G3: Calm music and hand massage (10 minutes simultaneously) G4: Control – no intervention
Processes of Care | Rosswurm, 1990^38^ RCT 3 weeks Good | Mild to severe | MMSE G1: 9.86 G2: 11.1 | G1: 15 G2: 15 | NH | G1: Attention-focusing group – welcoming and relaxation exercises; perceptual-matching exercises; reinforcement with refreshments G2: Control – refreshments and the opportunity for social interaction
Processes of Care | Sloane et al., 2004^40^ RCT 2 weeks Fair | Moderate to severe | MDS-COGS G1 and G2: 7.7 G3: 6.5 | G1: 24 G2: 25 G3: 24 | NH | G1: Patient-centered showering – patient-centered techniques: providing choices, covering with towels to maintain warmth, distracting attention, using family- or staff-recommended bathing products, using no-rinse soap, modifying shower spray G2: Towel bath – patient-centered techniques: using two bath blankets, two bath towels, a no-rinse soap, and 2 quarts of warm water; keeping the resident covered at all times; cleansing the body using gentle massage G3: Control – showering without patient-centered training
Processes of Care | Tappen, 1994^45^ RCT 20 weeks Fair | NR | MMSE Overall: 6.4 | G1: 21 G2: 21 G3: 21 | NH | G1: Functional skill training – regain function in basic activities of daily living through repeated practice in group setting 5 days/week for 2.5 hours per day G2: General stimulation – recreationally oriented group activities provided for dementia patients in therapeutically oriented settings 5 days/week for 2.5 hours per day G3: Control – regular care
Processes of Care | Toseland et al., 1997^46^ RCT 52 weeks Fair | NR | SPMSQ G1: 7.43 G2: 7.46 G3: 7.15 | G1: 31 G2: 29 G3: 28 | NH | G1: Validation group therapy – encourage residents with dementia to continue communicating using memory fragments and other aspects of cognitive, affective, and motoric functioning G2: Social contact – one activity each meeting in the 8 categories of music, art, literature and writing, dance/exercise, games/trivia, holiday and event planning, discussion, and other activities G3: Usual care – participation in regular social and recreational programming offered by each NH
Processes of Care | Whall et al., 1997^42^ Non-RCT 1 week Fair | Severe | NR | G1: 15 G2: 16 | NH | G1: Shower room – recorded songs of birds, sounds of babbling brooks, and sounds of other small animals; large bright pictures coordinated with audio; offering foods such as banana pudding or soda G2: Usual care
Processes of Care | Zimmerman et al., 2005^25,b^ Prospective cohort 6 months Fair | Mild to severe | MMSE or MDS-COGS Mild to moderate: 152 Severe to very severe: 259 | G7: NR G8: NR | RC/AL, NH | G7: Encourage activities^d^ ≥ once a day G8: Encourage activities^d^<once a day

AD = Alzheimer's disease; G = group; MDS-COGS = Minimum Data Set Cognition Scale; MMSE = Mini-Mental State Examination; NH = nursing home; NR = not reported; RC/AL = residential care/assisted living; RCT = randomized controlled trial; SCU = special care unit; SPMSQ = Short Portable Mental Status Questionnaire

a Investigators used the following scales and measurement to determine the level of dementia severity: mild, scores of 17-23 on the MMSE, 0-1 on the MDS-COGS, or stage 4 on the Global Deterioration Scale; moderate, scores of 11-16 on the MMSE, 2-4 on the MDS-COGS, or stage 5 on the Global Deterioration Scale; and severe, scores of ≤ 10 on the MMSE, ≥ 5 on the MDS-COGS, or stage 6 and stage 7 on the Global Deterioration Scale.

b Zimmerman et al.25 examined interventions/exposures within all three categories – organizational characteristics, structures of care, and processes of care. It has thus been listed 3 times in Table 5.

c For four residents missing MDS-COGS scores, dementia severity was based on MMSE, education, and activities of daily living score.

d Activities included exercise, personal care, social activities, housekeeping, meal preparation, crafts/handiwork, special event, sensory activities, and intellectual activities.

Ten studies addressed health outcomes for people with dementia (KQ 1);34, 35, 38-41, 43-46 10 studies examined psychosocial outcomes for people with dementia (KQ 2).25, 36, 37, 39-44, 46 No eligible studies of fair or better quality examined either health or psychosocial outcomes (respectively, KQ 3 and KQ 4) for informal caregivers of people with dementia. One study addressed whether effects of organizational characteristics differed by dementia severity but not by other characteristics (KQ 5),39 and one study examined whether effects of a structure of care differed by sociodemographic characteristics (i.e., sex).35

One study took place in multiple special care units.36 Two studies took place in a dementia care unit within an NH.35, 43 Three additional studies occurred in RC/AL settings and NHs.25, 39, 44 The remaining eight studies examined characteristics within NHs.34, 37, 38, 40-42, 45, 46

Four prospective cohort studies examined the effectiveness of organizational characteristics.25, 36, 39, 44 Two RCTs and one prospective cohort study assessed the effectiveness of structures of care.25, 34, 35 The remaining studies examined processes of care. Five of these process of care studies (four RCTs and one prospective cohort) assessed group activity interventions;25, 38, 43, 45, 46 two trials related to pleasant sensory stimulation;37, 42 and two RCTs were protocols for individualized care.40, 41

We rated 4 studies as good quality38, 39, 41, 44 and the remaining 10 studies as fair quality.25, 34-37, 40, 42, 43, 45, 46 We excluded studies that we rated poor quality from further analyses; they are listed in Appendix D.

## KQ 1 Health Outcomes for People With Dementia

KQ 1 compares the effectiveness of organizational characteristics, structures, or processes of care in NHs and other residential long-term care settings for improving health outcomes for people with dementia. Health outcomes measured in at least one included study include discomfort from pain, functional decline, cognitive decline, symptoms of depression, morbidities (e.g., skin ulcers), hospitalization, mortality, and sleep quality. Another health outcome on which we sought but did not identify evidence from included studies was falls. We also assessed whether effects differed by dementia severity and other characteristics of the person with dementia.

Of the 10 studies reviewed, 8 interventions showed statistically significant effects on health outcomes, with insufficient to low SOE. Process of care interventions provided more evidence than did interventions focusing on organizational characteristics or structures of care. Only one study addressed whether effects differed by dementia severity (but not by other characteristics) and found hospitalization was more likely in RC/AL settings than in NH settings for residents with mild dementia (low SOE). Another found the effects of a lighting intervention differed by sex.

### Key Points of Organizational Characteristics

- Two studies addressed organizational attributes but found few differences between RC/AL settings and NH settings on a range of health outcomes, with some differences occurring between dementia special care units (SCUs) and non-SCUs located within either RC/AL settings or NH settings, with insufficient to low SOE.
- Evidence from one study did not show a difference in mortality rates for residents in RC/AL compared with those in NHs (low SOE).
- Some evidence suggested higher hospitalization rates (low SOE) but little difference in multiple morbidity measures (insufficient to low SOE) in RC/AL settings than in NH settings.
- Evidence on dementia SCUs was inconsistent. Residents of dementia SCUs, when compared with no SCU, had greater decline in functioning over time (low SOE), and lower rates of both hospitalization and new or worsening morbidity (low SOE).

### Key Points of Structures of Care

- One RCT found no effect for lighting interventions on sleep quality and another RCT found no effect on depressive symptoms for the overall populations studied, but benefit in both trials for some subgroups (insufficient SOE; single studies with imprecise results and no power calculations).

### Key Points of Processes of Care

Evidence for group activity interventions was mixed:

- A functional skills training intervention produced modest effect sizes for improving ADLs, with effect sizes being equivalent to moving from major to moderate or from moderate to minor assistance in performing the ADLs (low SOE).
- A storytelling intervention improved cognitive alertness by about 3 percentage points (low SOE).
- Two interventions had no benefits. A validation group therapy intervention did not improve functional self-care or depressive symptoms. An attention-focusing intervention did not improve cognitive impairment (insufficient SOE; single studies with imprecise results and no power calculations).

Evidence for personalized care interventions was modest:

- A personalized assessment and treatment intervention reduced resident discomfort with an effect size of 0.89 (low SOE).
- Both personalized showering and towel bath interventions reduced resident discomfort on an Alzheimer's discomfort scale by 0.32 and 0.57 points, respectively, compared with a control group score of 2.14 (low SOE).

### Detailed Synthesis of Organizational Characteristics

Two studies considered organizational characteristics and their effects on health outcomes (Tables 6 and 7).39, 44 Both studies39, 44 evaluated the effects of care in RC/AL settings versus NH settings. The first study also analyzed a second exposure of interest, separately testing whether dementia SCUs within each setting improved health outcomes when compared with no SCU within each setting.39 These results from this one study are provided separately. The second study focused on outcomes for people who died.

Table 6 Effect of organizational characteristics on functioning, discomfort, depressive symptoms, cognitive impairment, mortality, and hospitalization

Author, Year Design | Interventions/Exposures | Change in ADL Functioning^a^ | Discomfort | Increase in Depressive Symptoms^b^ | Cognitive Impairment | Mortality^c^ | Hospitalization^c^ | Life-Sustaining Hospitalization in Last Month of Life
Sloane et al., 2005^39^ Prospective cohort | G1: RC/AL G2: NH | Mild dementia G1: 4.29 G2: 5.80 p=0.059 Moderate to severe dementia G1: 0.87 G2: 1.13 p=0.807 | Pain not effectively treated during last month of life^d^ G1: 10.2% G2: 5.5% p= 0.186 | Mild dementia G1: 1.33 G2: 1.53 p=0.753 Moderate to severe dementia G1: 1.52 G2: 0.85 p=0.409 | Mild dementia G1: 0.41 G2: 0.71 p=0.181 Moderate to severe dementia G1: -0.13 G2: 0.45 p=0.93 | Mild dementia G1: 3.2 G2: 4.2 p=0.409 Moderate or severe dementia G1: 3.7 G2: 4.2 p=0.682 | Mild dementia G1: 14.2 G2: 8.4 p=0.009 Moderate or severe dementia G1: 14.2 G2: 10.0 p=0.115 | NR
Sloane et al., 2005^39^ Prospective cohort | G3: SCU in RC/AL G4: Non-SCU in RC/AL G5: SCU in NH G6: Non-SCU in NH | Any dementia G3: 5.64 G4: 2.91 G5: 3.00 G6: 3.19 G3 vs. G4: p=0.029 G5 vs. G6: p=0.886 | NR | Any dementia G3: 1.59 G4: 1.32 G5: 0.89 G6: 1.25 G3 vs. G4: p=0.823 G5 vs. G6: p=0.630 | Any dementia G3: 0.33 G4: 0.30 G5: 0.58 G6: 0.61 G3 vs. G4: p=0.943 G5 vs. G6: p=0.903 | Any dementia G3: 7.0 G4: 4.0 G5: 3.4 G6: 4.0 G3 vs. G4: p =0.116 G5 vs. G6: p= 0.540 | Any dementia G3: 17.3 G4: 14.4 G5: 3.9 G6: 9.6 G3 vs. G4: p=0.430 G5 vs. G6: p=0.006 | NR
Sloane et al., 2008^44^ Prospective cohort | G1: RC/AL G2: NH | NR | NR | NR | NR | NR | NR | Any dementia G1: 39.7% G2: 23.6% p=0.149

ADL = activities of daily living, CSDD = Cornell Scale for Depression in Dementia; G = group; MDS-ADL = Minimum Data Set – Activities of Daily Living; NH = nursing home; NR = not reported; RC/AL = residential care/assisted living; SCU = special care unit

a Mean change in ADL dependency per 12 months using the MDS-ADL scale.

b Measured by Cornell Scale for Depression in Dementia (CSDD) scale.

c Incidence rate per 100 participants per quarter.

d Study also reported pain never an issue during the last month of life, G1: 48.5% vs. G2: 38.7%, p = 0.249.

Table 7 Effect of organizational characteristics on morbidity

Author, Year Design | Interventions/Exposures | New or Worsening Morbidity^a,b^ | Stable Health^c^ | Steady Decline in Health^c^ | Series of Ups and Downs in Health^c^ | One or More Skin Ulcers^c^
Sloane et al., 2005^39^ Prospective cohort | G1: RC/AL G2: NH | Mild dementia G1: 23.5 G2: 21.8 p=0.574 Moderate to severe dementia G1: 21.1 G2: 21.7 p=0.865 | NR | NR | NR | NR
Sloane et al., 2005^39^ Prospective cohort | G3: SCU in RC/AL G4: Non-SCU in RC/AL G5: SCU in NH G6: Non-SCU in NH | Any dementia G3: 26.7 G4: 25.3 G5: 15.0 G6: 22.0 G3 vs. G4: p=0.772 G5 vs. G6: p=0.043 | NR | NR | NR | NR
Sloane et al., 2008^44^ Prospective cohort | G1: RC/AL G2: NH | NR | Any dementia, % G1: 12.6 G2: 8.1 p=0.136 | Any dementia, % G1: 53.4 G2: 71.7 p=NR | Any dementia, % G1: 33.9 G2: 20.2 p<0.001 | Any dementia, % G1: 26.9 G2: 22.6 p=0.566

G = group; NH = nursing home; NR = not reported; RC/AL = residential care/assisted living; SCU = special care unit

a Incidence rate per 100 participants per quarter.

b New or worsening morbidity defined as the incidence or worsening of fracture, infection, stroke or paralysis, bleeding from the stomach or bowel, diabetes, heart condition, or skin ulcer.

c Health change in last 12 months of life.

Both cohort studies reported few differences between RC/AL settings versus NH settings on a range of outcomes for which study authors controlled for differences in resident baseline demographic, health and cognitive characteristics. In the first study, RC/AL settings had a slightly higher hospitalization rate than NH settings for residents with mild dementia.39 In addition, residents on dementia SCUs versus no SCU within each setting differed on some measures. First, residents of dementia SCUs within RC/AL settings had more decline in ADL functioning over time than residents who were not in SCUs.

Second, residents in dementia SCUs within NHs had lower rates of hospitalization and new or worsening morbidity than those who were not in SCUs. All differences reported were small in magnitude. This study found no differences across either settings or dementia SCUs on outcome measures for discomfort, depressive symptoms, cognitive impairment, or mortality.

In the second study, morbidity differed little between RC/AL settings and NH settings.44 When compared with NH settings on five different morbidity measures, RC/AL settings differed only by having a much larger proportion of residents who experienced a series of ups and downs in resident health compared with a steady decline in the last months of life. The rate of hospitalization did not differ between settings.

Taken together, these two studies suggest that residents in RC/AL settings and NH settings differ little on the health outcomes measured (low to insufficient SOE; Table 8). However, the findings of no difference concerning RC/AL and NHs on life-sustaining hospitalization in the last month of life, stable health, steady decline in health, and skin ulcers was insufficient. This was a single study that had imprecise results and no power calculations provided to justify sample size. No studies considering organizational characteristics provided evidence on falls and sleep quality, thus the evidence was insufficient.

Table 8 Effect of organizational characteristics comparing residential care/assisted living settings versus nursing homes on health outcomes: strength of evidence

Outcomes | Number of Studies; Number of Subjects | Risk of Bias; Design; Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Change in ADL functioning | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | Favors non-SCU vs. SCU in RC/AL | Low
Discomfort | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | RC/AL vs. NH no difference | Low
Change in depressive symptoms | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | RC/AL vs. NH and SCU vs. non-SCU no difference | Low
Cognitive impairment | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | RC/AL vs. NH and SCU vs. non-SCU no difference | Low
Mortality | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | RC/AL vs. NH and SCU vs. non-SCU no difference | Low
Hospitalization | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | Favors NH vs. RC/AL; favors NH SCU vs. NH non-SCU | Low
Life-sustaining hospitalization in last month of life | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^
New or worsening morbidity | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | Favors NH SCU vs. NH non-SCU | Low
Stable health | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^
Steady decline in health | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^
Series of ups and downs in health | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Precise | Favors NH vs. RC/AL | Low
One or more skin ulcers | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^

ADL = activities of daily living; NA = not applicable; NH = nursing home; RC/AL = residential care/assisted living; SCU = special care unit

a No power calculations provided to justify sample size.

For KQ 5, only one study39 addressed whether effects differed by dementia severity (but not by other characteristics) and found no differences in health outcomes based on residence in an NH versus RC/AL (low SOE).

### Detailed Synthesis of Structures of Care

Two RCTs considered structures of care, specifically lighting interventions, and their effects on two health outcomes (sleep quality and depressive symptoms) (Table 9).34, 35 One intervention was conducted in NHs either outdoors or in an indoor space with expansive surrounding windows.34

Table 9 Effect of lighting interventions on depressive symptoms and sleep quality

Author, Year Design | Interventions | Depressive Symptoms^a^ | Sleep Time | Awake Time
Dowling et al., 2005^34^ RCT | G1: Morning bright light exposure G2: Control - Usual indoor light levels | NR | Proportion of night asleep,% G1: 66.64 G2: 71.14 p=NR^b^ Sleep time, hours: minutes G1: 7:59 G2: 8:32 p=NR^b^ | Night wake time, hours: minutes G1: 3:59 G2: 3:27 p=NR^b^ Number of awakenings at night when asleep G1: 42.88 G2: 37.99 p=NR^b^ Day wake time, hours: minutes G1 6:24 G2: 6:34 p=NR^b^
Hickman et al., 2007^35^ RCT | G1: Morning bright light G2: Evening bright light G3: Standard light G4: All-day light | Subanalyses by men G1 vs.G3: 2.62, p=0.007 G2 vs.G3: 1.13, p=0.23 G4 vs.G3: 1.64, p=0.08 G1 vs.G2: 1.50, p= 0.16 G1 vs.G4: 0.98, p=0.33 G2 vs. G4: −0.52, p=0.60 Subanalyses by women G1 vs.G3: −1.61, p=0.09 G2 vs.G3: 0.09, p=0.94 G4 vs. G3: 1.41, p=0.16 G1 vs. G2: −1.70, p=0.08 G1 vs. G4: −3.02, p=0.01 G2 vs. G4: −1.32, p=0.24 | NR | NR

G = group; NR = not reported; RCT = randomized controlled trial

a Cornell Scale for Depression in Dementia (negative change scores mean less depressed).

b Analysis of Variance was not significant.

The other intervention was conducted in a State-operated psychiatric hospital or a dementia-specific residential care setting in both the activity and dining areas of both sites.35

These trials did not find an overall effect of either morning bright light on sleep34 or morning, evening, or all-day light on depressive symptoms.35 One trial found that bright morning light improved the start of the sleep and wake cycles of those people with aberrant cycle timing; it found no effect on residents with nonaberrant sleep/wake cycle timing. No other effects were found on people with aberrant sleep/wake cycle timing. Subgroup analyses in the other trial found better depressive symptom scores for women for morning bright light compared with all-day light. Neither study assessed measures for functioning, discomfort, cognitive impairment, morbidity, mortality, or hospitalization.

Taken together, these studies provide insufficient SOE that lighting interventions improve sleep quality and depressive symptoms due to imprecise results and no power calculations provided to justify sample size (Table 10).

Table 10 Effect of lighting interventions on health outcomes: strength of evidence

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Sleep Quality | 1; 46 | Medium; RCT; Fair | NA | Direct | Imprecise | No difference | Insufficient^a^
Depressive Symptoms | 1; 155 | Medium; RCT; Fair | NA | Direct | Imprecise | No difference | Insufficient^a^

NA = not applicable; RCT = randomized controlled trial

a No power calculations provided to justify sample size.

For KQ 5, one study on structures of care related to health outcomes for people with dementia differentiated findings by dementia severity or other characteristics of the person with dementia.35 This study found that the lighting intervention produced better depressive symptom outcomes for women exposed to morning bright light compared with all-day light but worse outcomes for men exposed to morning bright light compared with standard light. However, the evidence was insufficient regarding the effectiveness of lighting interventions for these subgroups. This was a single study that had imprecise results and no reported power calculation.

### Detailed Synthesis of Processes of Care

Six RCTs evaluated the effects of process of care interventions on five health outcomes. Four studies evaluated the effects of various group activity interventions on functioning, self-care, depressive symptoms, and cognitive impairment.38, 43, 45, 46 Two studies assessed effects of personalized care interventions on discomfort.40, 41 The interventions in these studies were dissimilar so evidence on each intervention is graded separately. All trials were conducted in NHs, although one was conducted on a dementia SCU within an NH.43

#### Group Activity Interventions

Four trials employed group activity interventions. Tappen45 used functional skill training to improve basic ADLs; Toseland et al.46 used validation group therapy to improve self-care and depressive symptoms (Table 11). Fritsch et al.43 employed a storytelling intervention designed to improve cognition, while Rosswurm38 sought to improve cognition through an attention-focusing intervention (Table 12).

Table 11 Effect of group activity interventions on ADL functioning, self-care, and depressive symptoms

Author, Year Design | Interventions | ADL Goal Attainment^a^ | ADL Test^b^ | Self-Care^c^ | Depressive Symptoms^c^
Tappen, 1994^45^ RCT | G1: Functional skill training G2: General stimulation G3: Control group | Adjusted post-test means score G1: 26.17 G2: 24.10 G3: 22.63 G1 vs. G3 p=0.01 G2 vs. G1 or G3: p=NS Mean achieved score G1: 1.75 G2: 1.43 G3: 1.10 G1 vs. G3, p=0.05 G2 vs. G1 or G3: p=NS | Within-group mean change G1: -3.01 G2: -0.86 G3: +1.14 p=0.12 | NR | NR
Toseland et al., 1997^46^ RCT | G1: Validation group therapy G2: Social contact G3: Usual care | NR | NR | Change at endpoint G1: 0.02 G2: -0.59 G3: -1.07 | Change at endpoint G1: 1.45 G2: -2.56 G3: 0.6 p=NR, stated difference NS

ADL = activities of daily living; G = group; NR = not reported; NS = not significant; RCT = randomized controlled trial

a Physical Self Maintenance Scale (higher scores show greater goal attainment)

b Performance Test of Activities of Daily Living

c Multidimensional Observation Scale for Elderly Subjects Self-Care Subscale

Table 12 Effect of group activity interventions on cognitive impairment

Author, Year | Interventions | Cognitive Alertness^a^ | Cognitive Improvement^b^ | Cognitive Function^b^
Fritsch et al., 2009^43^ RCT | G1: TimeSlips G2: Control | G1: 1512/1647 G2:1111/1245 G1 vs. G2: 1.028 times greater number of general alertness events p<0.05 | NR | NR
Rosswurm, 1990^38^ RCT | G1: Attention-focusing group G2: Control group | NR | Mean gain score at endpoint G1: 1.33 G2: -0.33 t value=1.36, NS | Mean gain score at endpoint G1: 0.33 G2: -0.33 t value=0.32, NS

G = group; NR = not reported; NS = not significant; RCT = randomized controlled trial

a General Alertness Subscale.

b Mini Mental State Examination.

These four RCTs produced mixed results (Table 13). A functional skills training intervention comprising repeated practice of five ADLs in a group setting 5 days per week for 2.5 hours per day over 20 weeks versus a control group providing usual nursing care produced a strong effect on both a scale measure of functional performance and a personal goal attainment measure.45 The effect size was reported to be the equivalent of moving from major to moderate or from moderate to minor assistance in performing ADLs. A third group participating in recreationally oriented group activities in a therapeutic setting with the same intensity and performance period experienced no effect (low SOE).

Table 13 Effect of processes of care on health outcomes: strength of evidence

Process of Care | Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Functional Skill Training | Goal attainment | 1; 63 | Low; RCT; Fair | NA | Direct | Precise | Favors functional skill training | Low
Functional Skill Training | Activities of daily living | 1; 63 | Low; RCT; Fair | NA | Direct | Imprecise | No difference | Insufficient^a^
Validation Group Therapy | Self-care | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | No difference | Insufficient^a^
Validation Group Therapy | Depressive symptoms | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | No difference | Insufficient^a^
Storytelling Intervention | Cognitive alertness | 1; NR; 20 NHs | Medium; RCT; Fair | NA | Direct | Precise | Favors storytelling | Low
Attention-focusing Group | Cognitive improvement | 1; 30 | Low; RCT; Good | NA | Direct | Imprecise | No difference | Insufficient^a^
Attention-focusing Group | Cognitive function | 1; 30 | Low; RCT; Good | NA | Direct | Imprecise | No difference | Insufficient^a^

NA = not applicable; NH = nursing home, NR = not reported; RCT = randomized controlled trial

a No power calculations provided to justify sample size.

Another trial found a modest (approximately 3 percentage point) effect of a 10-week storytelling intervention designed to improve general alertness as a measure of cognitive impairment.43 Residents were asked to comment on a picture, and staff then wove resident contributions into a story that was retold frequently. The intervention group was more alert in a larger proportion of events than the control group receiving usual care (low SOE).

Two other interventions found no effect. An attention-focusing group using perceptual-matching exercises for 30 minutes 3 times weekly over 4 weeks produced no improvement on two measures of cognitive status.38 The evidence of the effect of the attention-focusing group was insufficient for both outcomes. This was a single study that had imprecise results and did not report power calculations. A validation group therapy intervention versus a social interaction intervention for four 30-minute weekly sessions over 1 year versus usual care yielded no effect on measures of functioning and depressive symptoms.46 The evidence of the effect of validation group therapy on functioning and depressive symptoms is also insufficient. This was a single study that had imprecise results and provided no power calculations.

Half of the RCTs assessed yielded some benefits across a variety of outcomes. For all interventions/exposures, we found no evidence for the following health outcomes: falls, discomfort, hospitalization, morbidity, mortality, and sleep quality. We found no evidence for depressive symptoms except for validation group therapy, no evidence for functional decline except for functional skill training, and no evidence for cognitive impairment measures except for a storytelling intervention and an attention-focusing intervention. We graded SOE for interventions that did not measure or report on the outcomes below as insufficient.

For KQ 5, none of the four studies on group activity interventions related to health outcomes for people with dementia differentiated findings by dementia severity or other characteristics of the person with dementia (insufficient SOE).

#### Personalized Care Interventions

Two trials designed to reduce discomfort were individualized to each resident (Table 14). Kovach et al.41 provided assessment and treatment customized to each resident in the experimental group. Sloane et al.40 used a patient-centered showering protocol for one intervention group and a towel bath protocol for a second intervention group.

Table 14 Effect of personalized care interventions on discomfort

Author, Year Design | Interventions | Change in Discomfort^a^
Kovach et al., 2006^41^ RCT | G1: Serial Trial Intervention G2: Control | Change at endpoint G1: 40.74 G2: -39.53 G1 vs. G2: p<0.001
Sloane et al., 2004^40^ RCT | G1: Patient-centered showering G2: Towel bath G3: Showering without patient-centeredness | Change at endpoint G1: 0.32 G2: 0.57 G3: -0.02 G1 vs. G3: p<0.001 G2 vs. G3: p=0.001 G1 vs. G2: p=0.003

G = group; RCT = randomized controlled trial; vs. = versus

a Modified Discomfort Scale for dementia of the Alzheimer type. Possible scores ranged from 0 to 900, with higher scores indicating more discomfort.

Kovach et al.41 evaluated a clinical protocol called the Serial Trial Intervention for assessment and management of unmet needs over a 4-week period designed to create a customized care plan for each resident. Intervention group members were compared with residents whose care staff received general instruction on how to care for all residents but not an individualized care plan for each resident. Residents receiving Serial Trial Intervention had 0.89 times lower discomfort score than the control group.

Sloane et al.40 evaluated two different showering/bathing interventions to reduce discomfort. The first intervention employed person-centered showering using a wide variety of techniques to calm residents. The second intervention used a towel bath, which encloses and covers the resident while care staff used massage and a no-rinse soap to bathe the resident. A third group received non-person-centered showering. The towel bath and person-centered showering intervention reduced resident discomfort by 26 percent and 14 percent, respectively.

These two trials showed substantial improvements on measures of discomfort (Table 15; low SOE). We found no evidence for the following health outcomes: falls, functioning, pain, depressive symptoms, hospitalization, morbidity, mortality, and sleep quality. We graded SOE for interventions that did not measure or report on these outcomes as insufficient.

Table 15 Effect of personalized care interventions on health outcomes: strength of evidence

Process of Care | Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Serial Trial Intervention | Change in discomfort | 1;114 | Low; RCT; Good | NA | Direct | Precise | Favors STI | Low
Bathing | Change in discomfort | 1;73 | Low; RCT; Fair | NA | Direct | Precise | Favors both showering and towel bath | Low

NA = not applicable; RCT = randomized controlled trial; STI = Serial Trial Intervention

For KQ 5, neither study using personalized care interventions differentiated findings by dementia severity or other characteristics of the person with dementia (insufficient SOE).

## KQ 2 Psychosocial Outcomes for People With Dementia

KQ 2 compares the effectiveness of organizational characteristics, structures, or processes of care in NHs and other residential long-term care settings for improving psychosocial outcomes for people with dementia. Psychosocial outcomes measured in at least one included study include behavioral symptoms (e.g., agitation, aggression), engagement (e.g., social function, withdrawal), affect other than depressive symptoms (e.g., anxiety, pleasure), quality of life in Alzheimer's disease, quality of dying, use of restraints, and use of psychoactive medications. Other psychosocial outcomes on which we sought but did not identify evidence from included studies were spiritual well-being, control, autonomy, choice, and satisfaction. We also assessed whether effects differed by dementia severity and other characteristics of the person with dementia.

Ten studies (five RCTs) addressed psychosocial outcomes, with almost all showing some statistically significant effects on outcomes (low to moderate SOE). Only one study addressed whether effects differed by dementia severity (but not by other characteristics) and found no differences in behavioral symptoms or engagement based on residence in an NH versus RC/AL (low SOE).

### Key Points of Organizational Characteristics

- Two studies found that, with one exception (restraint use), psychosocial outcomes did not differ between NH settings and RC/AL settings.
  ○ Behavioral symptoms and engagement did not differ by setting (low SOE).
  ○ Quality of dying, quality of life, and psychoactive medication use did not differ by setting (insufficient SOE; single studies with imprecise results and no power calculations).
  ○ Restraints were used more often in imminently dying residents in NH settings than in RC/AL settings (any restraints, 92% vs. 66%; any restraints other than partial bedrails, 68% vs. 46%; low SOE).
- One study found that quality of life did not differ based on proprietary status, chain affiliation, size, age, percentage of dementia beds, or resident case-mix (insufficient SOE; one study with imprecise results and no power calculation).
- Two studies found that behavioral symptoms did not differ based on residence in an SCU (low SOE).
- One study found that engagement did not differ based on residence in an SCU (low SOE).

### Key Points of Structures of Care

- Based on one study, with one exception, quality of life did not differ based on many structures of care.
  ○ Quality of life did not differ based on the following structures: registered nurse (RN), licensed practical nurse (LPN), and aide full-time equivalents (FTEs) and number of contract staff per type; administrator, RN, LPN, and aide turnover; environmental quality; consistent staffing; or use of universal workers (insufficient SOE; one study with imprecise results and no power calculation).
  ○ Quality of life was statistically but not clinically better in settings that used specialized care workers (mean raw change over 6 months was 1.7 points worse when specialized workers were not used; low SOE).

### Key Points of Processes of Care

- Group activity:
  ○ A creative expression storytelling group resulted in more challenging behaviors, anxiety, and sadness, and also less disengagement, neutral affect, and more engagement (low SOE).
  ○ A validation therapy group was superior to social control and usual care control groups in regard to nurse-reported (but not observer-reported) physically and verbally aggressive behavior at 1 year, and also resulted in more physically nonaggressive behaviors (low SOE). Validation therapy did not produce significant changes in engagement, irritability, restraint use, psychoactive medication use, or positive behaviors (insufficient SOE; one study with imprecise results and no power calculation).
  ○ More frequent encouragement of activity participation resulted in statistically but not clinically better quality of life (mean raw change over 6 months was 0.9 times worse when activities were encouraged less than once a day; low SOE).
- Based on two studies, pleasant sensory stimulation produced a clinically significant decrease in agitation (75% to 83% compared with control in one study; moderate SOE).
- Protocols for individualized care:
  ○ Individualized assessment and management of discomfort and behavioral symptoms did not result in behavioral change but did increase return of behavior to baseline levels (70% vs. 40% in the control group; low SOE).
  ○ Person-centered protocols for showering and bathing reduced behavioral symptoms (agitation and aggression) more in the intervention group than control group (mean time agitated or aggressive 24% and 26% in the intervention groups vs. 36% in the control group; low SOE).
- In one prospective cohort study, various processes of care (including policies and practices; staff involvement in care planning; assessments; treatment; use of medications; and use of stimuli such as craft or household items) did not improve quality of life (insufficient SOE; one study with imprecise results and no power calculation).

### Detailed Synthesis of Organizational Characteristics

Three prospective cohort studies examined organizational characteristics and their effect on psychosocial outcomes, comparing NHs with RC/AL.25, 39, 44 One study39 (1,252 residents across 146 settings) differentiated 1-year outcomes by degree of dementia severity and residence on an SCU (Table 16);39 it examined the effect of these organizational characteristics on behavioral symptoms and engagement, using standardized measures administered by interview to nursing staff. Another study, of 422 residents who died in 230 settings, investigated whether four components of the death experience (appeared to be at peace, received compassionate touch daily, maintained dignity, and had close attachment to staff) and the use of restraints and sedative medications differed by residence in an NH or RC/AL based on interviews with staff (Table 17).44 The third study25 focused on change in quality of life over 6 months (Table 17), examining outcomes for 421 residents across 45 NH settings and RC/AL settings using a standardized measure of quality of life in Alzheimer's disease administered to staff; it additionally examined proprietary status and chain affiliation in relation to change in quality of life.25

Table 16 Effect of organizational characteristics on behavioral symptoms and engagement

Author, Year, Design | Intervention/Exposures | CMAI Mild Dementia | CMAI Moderate or Severe Dementia | CMAI | Decrease in Social Function Mild Dementia | Decrease in Social Function Moderate or Severe Dementia | Decrease in Social Function | MOSES Increased Withdrawal From Activities Mild Dementia | MOSES Increased Withdrawal From Activities Moderate or Severe Dementia | MOSES Increased Withdrawal From Activities
Leon and Ory, 1999^36^ Prospective cohort | G1: SCU in NH G2: Non-SCU in NH | NR | NR | Physically aggressive behaviors Baseline (unadjusted) G1: 4.84 G2: 4.10 p=NS Adjusted Beta Coefficient SCU placement=0.31 p=NS | NR | NR | NR | NR | NR | NR
Sloane^a^ et al., 2005^39^ Prospective cohort | G1: RC/AL G2: NH G3: SCU in RC/AL G4: Non-SCU in RC/AL G5: SCU in NH G6: Non-SCU in NH | G1: 1.08 G2: 0.69 p=0.604 | G1: 1.72 G2: 1.49 p=0.809 | G3: -1.53 G4: -1.14 p=0.763 G5: -2.18 G6: -0.72 p=0.168 | G1: 1.55 G2:1.76 p=0.568 | G1: 0.91 G2: 1.44 p=0.110 | G3: 1.58 G4: 1.34 p=0.681 G5: 1.88 G6: 1.46 p=0.303 | G1: 2.84 G2: 2.24 p=0.364 | G1: 2.55 G2: 1.78 p=0.307 | G3: 3.48 G4: 2.58 p=0.409 G5: 2.22 G6: 1.77 p=0.604

CMAI = Cohen-Mansfield Agitation Inventory; G = group; MOSES = Multidimensional Observation Scale for Elderly Subjects; NH = nursing home; NR = not reported; NS = not significant; RC/AL = residential care/assisted living; SCU = special care unit

a Outcomes are adjusted for baseline age, gender, race, education, marital status, length of stay, cognition, and number of comorbid conditions.

Table 17 Effect of organizational characteristics on quality of dying, quality of life, restraint use, and psychoactive medication use

Author, Year, Design | Interventions/Exposures | Appeared To Be at Peace^a^ | Received Compassionate Touch Daily^a^ | Dignity Maintained^a^ | One Staff Had Close Attachment to Resident^a^ | QOL-AD Adjusted Change | Any Restraints Used | Any Restraints Other Than Partial Bed Rails | Sedative Used Frequently | Sedative Used at Least Sometime
Sloane et al., 2008^44^ Prospective cohort | G1: RC/AL G2: NH | G1: 70.1% G2: 64.2% p=0.304 | G1: 96.6% G2: 95.1% p=0.399 | G1: 90.2% G2: 89.4% p=0.847 | G1: 82.8% G2: 72.1% p=0.528 | NR | G1: 65.7% G2: 91.5% p<0.001 | G1: 46.3% G2: 67.6% p=0.031 | G1: 21.0% G2: 29.2% p=0.592 | G1: 29.9% G2: 37.3% p=0.792
Zimmerman et al., 2005^25^ Prospective cohort | G1: RC/AL: <16 Beds G2: RC/AL traditional: ≥ 16 beds G3: RC/AL new model: ≥ 16 beds G4: NH | NR | NR | NR | NR | G1: +0.54 G2: +0.48 G3: -0.38 G4: -0.18 p=0.206 | NR | NR | NR | NR

G = group; NH = nursing home; NR = not reported; QOL-AD = Quality of Life in Alzheimer's disease; RC/AL = residential care/assisted living

a The outcome is a variable related to quality of dying during the last month of life.

With one exception for one outcome, none of the three studies found differences in outcomes (i.e., behavioral symptoms, engagement [low SOE], quality of dying, quality of life, psychoactive medication use [insufficient SOE]) according to residence in an NH or RC/AL (Table 18). Evidence was insufficient for the effect of residence in an NH or RC/AL on quality of dying, quality of life, and psychoactive medication use. These were single studies that had imprecise results and no reported power calculations to justify sample sizes.

Table 18 Effect of organizational characteristics on psychosocial outcomes: strength of evidence

Outcomes | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Behavioral Symptoms | 2; 1,848 | Low; Prospective cohort; Good (1 study); Fair (1 study) | NA | Direct | Precise | RC/AL vs. NH no difference (1 study) SCU vs. non-SCU no difference (2 studies) | Low
Engagement | 1; 1,252 | Low; Prospective cohort; Good | NA | Direct | Precise | RC/AL vs. NH no difference SCU vs. non-SCU no difference | Low
Quality of Dying | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^
Quality of Life | 1; 421 | Low; Prospective cohort; Fair | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^
Restraint Use (before death) | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Precise | Favors RC/AL vs. NH | Low
Psychoactive Medication Use | 1; 422 | Low; Prospective cohort; Good | NA | Direct | Imprecise | RC/AL vs. NH no difference | Insufficient^a^

NA = not applicable; NH = nursing home; RC/AL = residential care/assisted living; SCU = special care unit

a No power calculations provided to justify sample size.

However, use of restraints in imminently dying residents was more frequent in NHs than in RC/AL (any restraints used, 92% vs. 66%, p<0.001; any restraints other than partial bedrails, 68% vs. 46%, p=0.031; low SOE).44

Quality of life over 6 months also did not differ by different types of RC/AL settings (smaller, traditional, new-model) or by other variables (not shown in Table 17 because no statistics were provided) including proprietary status, chain affiliation, size, age, percentage of dementia beds, and resident case-mix.25 Because no statistics were provided, we graded the SOE for the effect of these structures on quality of life as insufficient. This was a single study that had imprecise results and no reported power calculation.

Behavior and engagement outcomes did not differ by residence on an SCU within an NH or RC/AL (low SOE).36, 39

Taken together, most residents' outcomes did not differ by organizational characteristics of settings, except for use of restraints (low SOE). However, evidence concerning the effects of organizational characteristics on quality of dying, quality of life, or psychoactive medication use was insufficient. These are single studies that had imprecise results; no power calculations were provided to justify the sample size. Evidence about effects of organizational characteristics was insufficient on numerous other outcomes not included in the studies (e.g., affect, spiritual well-being, control, autonomy, choice, satisfaction).

For KQ 5, only one study39 addressed whether effects differed by dementia severity (but not by other characteristics); it found no differences in behavioral symptoms or engagement based on residence in an NH versus RC/AL (low SOE).

### Detailed Synthesis of Structures of Care

One prospective cohort study described above examined change in quality of life over 6 months for 421 residents across 45 NH and RC/AL settings in relation to the following structures of care: FTEs for RNs, LPNs, and aides; number of contract staff per type; administrator, RN, LPN, and aide turnover; environmental quality; and use of universal and specialized workers (i.e., staff who fill specialized roles; Table 19).25

Table 19 Effect of structures of care on quality of life

Author, Year Design | Interventions | QOL-AD Mean Raw Change
Zimmerman et al., 2005^25^ Prospective cohort | G5: Use specialized workers (staff fill specialized roles) G6: No use of specialized workers | G5: -1.3 G6: -3.0 p=0.036

G = group; QOL-AD = Quality of Life in Alzheimer's Disease

The mean raw change in quality of life over 6 months was 1.7 points worse when specialized workers were not used (adjusted change p<0.05; low SOE) (Tables 19 and 20),25 a difference not considered to be clinically significant.47 Other than use of specialized workers, the structure of care variables and change in quality of life were not related. Because the authors did not provide the related data, we graded the strength of evidence of this single study as insufficient. This information is not shown in Table 19. Also, evidence about effects of structures of care was insufficient for numerous other outcomes not included in the studies (e.g., behavioral symptoms, engagement, affect, quality of dying, spiritual well-being, control, autonomy, choice, satisfaction, use of restraints, use of psychoactive medications).

Table 20 Effect of structures of care on psychosocial outcomes: strength of evidence

Outcomes | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Quality of Life | 1; 421 | Medium; Prospective cohort; Fair | NA | Direct | Precise | Favors specialized workers vs. not | Low

NA = not applicable

For KQ 5, one study conducted of structures of care related to psychosocial outcomes for people with dementia did not differentiate findings by dementia severity or other characteristics of the person with dementia (insufficient SOE).

### Detailed Synthesis of Processes of Care

Seven studies examined processes of care and their effect on psychosocial outcomes. Three studies related to group activity interventions, two studied pleasant sensory stimulation, and two studied individualized care. One of the seven additionally examined other processes of care.

#### Group Activity Interventions

Three studies examined group activity interventions. Two were RCTs that examined behavioral symptoms and engagement (Table 21). One trial (in dementia care units) employed a creative expression storytelling intervention;43 the other trial examined the effects of validation group therapy in NHs compared with a social contact comparison group and a usual care group.46 In the first trial, research staff coded outcomes for 2,088 10-minute observations of staff-resident interactions. In the second, behavior was assessed through a standardized measure completed by blinded nursing staff and nonparticipant observers (the Cohen-Mansfield Agitation Inventory-Nursing Staff Derived [CMAI-N] and the Cohen-Mansfield Agitation Inventory-Observer Derived [CMAI-O]), respectively, in Table 21), and engagement was assessed through interviews with nursing staff using a standardized measure.

Table 21 Effect of group activity interventions on behavioral symptoms and engagement

Author, Year, Design | Interventions | Challenging Behaviors # of Observations | CMAI-N | CMAI-O | Types of Engagement # of Observations | MOSES Withdrawal Subscale
Fritsch et al., 2009^43^ RCT | G1: TimeSlips G2: Control | G1: 9/1,651 G2: 1/1,250 6.80 times more for G1 p=0.034 | NR | NR | Disengaged G1: 68/1,651 G2:107/1,250 0.481 times less disengaged for G1 p<0.001 Nonsocial engagement G1: 174/1,651 G2:135/1,250 0.976 times less nonsocial engagement for G1 p=0.822 Engagement G1: 1,400/1,651 G2:1,007/1,250 1.053 times more engaged for G1 p=0.003 | NR
Toseland et al., 1997^46^ RCT | G1: Validation group therapy G2: Social contact group G3: Usual care | NR | Physically Aggressive Behavior χ^2^=14.90 p=0.001 G1 vs. G2 and G3 showed significant reduction in physically aggressive behaviors Verbally Aggressive Behavior χ^2^=5.88 p=0.053 G1 and G2 vs. G3 showed significant reduction in verbally aggressive behaviors Physically Nonaggressive Behaviors χ^2^=6.76 p=0.034 G2 and G3 reduced | Physically Aggressive Behavior χ^2^=1.41 p=0.590 Verbally Aggressive Behavior χ^2^=12.46 p=0.002 G2 vs. G1 and G3 showed significantly lower scores in verbally aggressive behaviors Physically Nonaggressive Behaviors χ^2^ =1.52 p=0.47 | NR | Baseline^a^ G1: 14.05 G2:13.05 G3:14.43 Endpoint G1: 13.95 G2: 13.67 G3: 14.91

CMAI-N = Nurse-derived Cohen-Mansfield Agitation Inventory; CMAI-O = Observer-derived Cohen-Mansfield Agitation Inventory score; G = group; MOSES = Multidimensional Observation Scale for Elderly Subjects; NR = not reported; RCT = randomized controlled trial; X^2^ = chi-square statistic

Note: Toseland, 1997^46^ found among the Geriatric Indices of Positive Behavior— no significant changes in positive social interactions with family, staff, or other residents.

a No effect by Condition X Time.

These two RCTs also examined results related to affect (Table 22). One used observations coded according to an established affect rating scale,43 and the other used nurse interview with a standardized measure.46 The latter trial additionally examined restraint and psychoactive medication use.

Table 22 Effect of group activity interventions on affect, quality of life, restraint use, and psychoactive medication use

Author, Year, Design | Interventions | PGCARS Other Subscale (Neutral Affect) | PGCARS Anxiety Subscale # of Observations | PGCARS Anger Subscale # of Observations | PGCARS Sadness Subscale # of Observations | PGCARS Pleasure Subscale # of Observations | MOSES Irritability Subscale | QOL-AD Mean Raw Change | Restraint Use | Psychoactive Medication Use
Fritsch et al., 2009^43^ RCT | G1:Time-Slips G2: Control | G1: 30/1,647 G2: 75/1,245 0.302 times less neutral for G1 p=0.001 | G1: 39/1,647 G2: 11/1,245 2.68 times more events for G1 p=0.002 | G1: 6/1,647 G2: 1/1,245 4.54 times more events for G1 p=0.124 | G1: 7/1,647 G2: 0/1,245 >7 times more events for G1 p=0.021 | G1: 54/1,647 G2: 47/1,245 0.869 times less pleasure for G1 p=0.472 | NR | NR | NR | NR
Toseland et al., 1997^46^ RCT | G1: Validation group therapy G2: Social contact group G3: Usual care | NR | NR | NR | NR | NR | Baseline^a^ G1: 5.36 G2: 5.64 G3: 5.22 Endpoint G1: 4.81 G2: 6.10 G3: 5.36 | NR | No significant changes in frequency of restraint use in the 3 groups | No significant differences in the 3 groups with regard to use of antipsychotic, antianxiety, or antidepressant medications
Zimmerman et al., 2005^25^ Prospective cohort | G7: Encourage activities ≥ once a day G8: Encourage activities <once a day | NR | NR | NR | NR | NR | NR | G1: -1.9 G2: -2.6 p=0.043 | NR | NR

G = group; MOSES = Multidimensional Observation Scale for Elderly Subjects; NR = not reported; PGCARS = Philadelphia Geriatric Center Affect Rating Scale; QOL-AD = Quality of Life in Alzheimer's Disease; RCT = randomized controlled trial

a No effect by condition X time.

Finally, one prospective cohort study examined the extent to which encouraging participation in activities related to quality of life.25 It also investigated numerous other processes of care, including policies and practices, professional and paraprofessional involvement in care planning, assessments conducted (professional or standardized), treatment provided (professional or informal), use of antipsychotic or sedative hypnotic medications, and use of stimuli such as craft or household items.

The creative expression group activity43 resulted in more challenging behaviors (9 vs. 1 event in more than 1,000 observations per group, p=0.034), anxiety (39 vs. 11 events, p=0.002), and sadness (7 vs. 0 events, p=0.021);43 it also produced less disengagement (68 vs. 107 events, p<0.001), more engagement (1,400 vs. 1,007 events, p=0.003), and less neutral affect (30 vs. 75 events, p<0.001) (low SOE) (Table 23). Effects related to nonsocial engagement, anger, or pleasure were not statistically significant.

Table 23 Effect of group activity interventions on psychosocial outcomes: strength of evidence

Process of Care | Outcomes | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Creative Expression Storytelling Intervention | Behavioral symptoms | 1; NR | Medium; RCT; Fair | NA | Direct | Precise | Favors control vs. storytelling | Low
Creative Expression Storytelling Intervention | Engagement | 1; NR | Medium; RCT; Fair | NA | Direct | Precise | Favors storytelling vs. control for engagement Storytelling vs. control no difference for nonsocial engagement | Low
Creative Expression Storytelling Intervention | Affect | 1; NR | Medium; RCT; Fair | NA | Direct | Precise | Favors control vs. storytelling for anxiety and sadness; Storytelling vs. control no difference for anger or pleasure | Low
Validation Group Therapy | Behavioral symptoms | 1; 88 | Medium; RCT; Fair | NA | Direct | Precise | Nurse rating: Favors validation vs. control for physical and verbal aggression; favors control vs. validation for physical nonaggression Observer rating: Favors comparison vs. validation for verbal aggression; validation vs. control no difference for physical aggression or physical nonaggression | Low
Validation Group Therapy | Engagement | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | Validation vs. control no difference | Insufficient^a^
Validation Group Therapy | Affect | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | Validation vs. control no difference | Insufficient^a^
Validation Group Therapy | Restraint use | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | Validation vs. control no difference | Insufficient^a^
Validation Group Therapy | Psychoactive medication use | 1; 88 | Medium; RCT; Fair | NA | Direct | Imprecise | Validation vs. control no difference | Insufficient^a^
Encouragement of Activities | Quality of life | 1; 421 | Medium; Prospective cohort; Fair | NA | Direct | Precise | Favors encouragement vs. not | Low

NA = not applicable; NR = not reported; RCT = randomized controlled trial; vs. = versus

a No power calculations provided to justify sample size.

A validation therapy group46 was superior to social control and usual care control groups in regard to blinded nurse report of physically aggressive behavior (p<0.001) and verbally aggressive behavior (p<0.01) at 1 year, but it resulted in more physically nonaggressive behaviors (p=0.034) (low SOE; Table 23).46

Blinded observers did not favor validation therapy, and rated social contact as superior in relation to verbally aggressive behavior (low SOE). Validation group therapy did not produce significant changes in engagement or positive social interactions, irritability, restraint use, or psychoactive medication use. However, the evidence was insufficient regarding the effects of validation therapy on these outcomes. This was a single study that had imprecise results and no reported power calculation.

In the prospective cohort study, the mean raw change in quality of life over 6 months was 0.9 points worse when activities were encouraged less than once a day (p=.043; adjusted change p<0.05)25 (low SOE), a difference not considered to be clinically significant.47 No other processes of care (policies and practices, staff involvement in care planning, assessments, treatment, medications, and use of stimuli) had a statistically significant relationship to change in quality of life (data not reported by authors and so not included in Table 22).

These studies indicate that group activity interventions may have both positive and negative effects on psychosocial outcomes (low SOE). Evidence about effects of group activity interventions was insufficient on numerous other outcomes not included in the studies (e.g., spiritual well-being, control, autonomy, choice, quality of dying, or satisfaction).

For KQ 5, the three studies of group activity interventions related to psychosocial outcomes for people with dementia did not differentiate findings by dementia severity or other characteristics of the person with dementia (insufficient SOE).

#### Pleasant Sensory Stimulation Interventions

Two studies were related to the use of pleasant sensory stimulation to reduce agitation and aggression in NH residents who displayed agitated behavior (Table 24). One RCT compared outcomes of calm music, hand massage, and a combination of the two with those of a control group in terms of agitated behavior displayed over 1 hour.37 The other, a nonrandomized controlled trial, administered pleasant sensory stimulation during shower-bath time and measured agitation over 1 and 2 weeks (i.e., time one and time two).42 Both sets of investigators measured agitation using an existing observational instrument completed by research staff.

Table 24 Effect of pleasant sensory stimulation interventions on behavioral symptoms

Author, Year, Design | Interventions | CMAI–Agitation (Mean Difference in Score) | CMAI–Aggression
Remington, 2002^37^ RCT | G1: Calm music G2: Hand massage G3: Calm music and hand massage G4: Control | G1: 13.76 (75% change)^a^ G2: 13.41 (81% change)^a^ G3: 18.24 (83% change)^a^ G4:1.29 (0.06% change)^a^ p<0.01^b^ | Physically aggressive behaviors: G1: NR G2: NR G3: NR G4: NR p=0.09^c^
Whall et al., 1997^42^ Non-RCT | G1: Pleasant sensory stimulation shower room G2: Usual care | Mean baseline to time two: -6.73^d^ p<0.004 | Mean baseline to time two: -1.47 p<0.19

CMAI = Cohen-Mansfield Agitation Inventory; G = group; NR = not reported; RCT = randomized controlled trial

a These are measures of the within-group mean reduction in score. Mean baseline scores: G1: 18.41; G2: 16.47; G3: 22.00; G4: 21.76.

b Repeated measures analysis of variance yielded significant difference among the four groups.

c Repeated measures ANOVA yielded no significant differences in physically aggressive behavior among the four groups.

d T-test mean difference scores between G1 and G2.

Both pleasant sensory stimulation interventions resulted in a decrease in agitation. Specifically, the study of music and hand massage found a decrease in agitation 1 hour after the intervention to be between 12.12 points (hand massage) and 16.95 (music plus hand massage) greater than the control group (p<0.01);37 compared with their own baseline values, the decrease in agitation for the three intervention groups ranged from 75 percent to 83 percent. The pleasant sensory stimulation during the shower-bath found a decrease in agitation over 2 weeks to be 6.73 points greater in the intervention group.42 Because a 30 percent reduction in agitation has been determined to be of clinical significance,48 we graded the SOE that pleasant sensory stimulation interventions may reduce agitation as moderate (Table 25).

Table 25 Effect of pleasant sensory stimulation interventions on psychosocial outcomes: strength of evidence

Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Behavioral Symptoms: Agitation | 2;99 | Medium; 1 RCT, 1 non-RCT; both fair | Consistent | Direct | Precise | Favors stimulation vs. control | Moderate
Behavioral Symptoms: Aggression | 2;99 | Medium; 1 RCT, 1 non-RCT; both fair | Consistent | Direct | Imprecise | Stimulation vs. control no difference | Insufficient^a^

RCT = randomized controlled trial; vs. = versus

a No power calculations provided to justify sample size.

Neither of the pleasant sensory stimulation interventions resulted in a statistically significant decrease in physical aggression. However, evidence was insufficient regarding the effects of these processes of care on this outcome. Neither of these single studies provided power calculations to justify sample size nor were their results precise. The authors of both studies commented that the lack of significance was likely the result of either measurement error or low levels of aggressive behaviors overall. Also, evidence about effects of pleasant sensory stimulation was insufficient on numerous other outcomes not included in the studies (e.g., engagement, affect, quality of life, quality of dying, spiritual well-being, control, autonomy, choice, satisfaction, use of restraints, use of psychoactive medications).

For KQ 5, the two studies of pleasant sensory stimulation related to psychosocial outcomes for people with dementia did not differentiate findings by dementia severity or other characteristics of the person with dementia (insufficient SOE). One study commented on the distribution of residents by level of dementia (mild, 4 %; moderate, 43%; severe, 53%); the other noted that all residents had late-stage Alzheimer's disease or Alzheimer's disease with multi-infarct dementia.

#### Protocols for Individualized Care Interventions

Two trials tested protocols for individualized care (Table 26). One focused on assessment and management of discomfort and behavioral symptoms for NH residents with late-stage dementia; staff used a standardized scale of behavioral symptoms at baseline and over 4 weeks and also recorded return of behavioral symptoms to baseline by marking a visual analog scale.41 The other trial focused on agitation and aggression during bathing for NH residents with moderate or severe cognitive impairment who demonstrated these types of behaviors during bathing.40 Research staff masked to the intervention coded behavioral observations 2 weeks after the intervention and noted the percentage of time residents displayed agitation or aggression using a coding tool (the Care Recipient Behavior Assessment) based on the CMAI.40

Table 26 Effect of protocols for individualized care interventions on behavioral symptoms

Author, Year Design | Interventions | BEHAVE-AD (Within-Group Mean Change)^a^ | Return of Behavior to Baseline: Number of Subjects (%) | CAREBA (Endpoint Scores, Percent Time)
Kovach et al., 2006^41^ RCT | G1: Serial Trial Intervention G2: Control | G1: 2.75 G2: 1.84 p=0.50^b^ | G1: 40/57 (70%) G2: 23/57 (40%) p=0.002 | NR
Sloane et al., 2004^40^ RCT | G1: Person-centered showering G2: Towel bath G3: Control | NR | NR | G1: 25.84 G2: 23.51 G3: 35.65 G1 vs.G3: p=0.02 G2 vs.G3: p=0.01 G1 vs.G2 change from baseline: p=0.4

BEHAVE-AD = Behavioral Pathology in Alzheimer's Disease Rating Scale; CAREBA = Care Recipient Behavior Assessment; G = group; NR = not reported; RCT = randomized controlled trial

a Baseline scores were as follows, G1:7.43, G2:6.80.

b Measures the Time X Group Interaction.

The trial that individualized assessment and management of discomfort and behavioral symptoms found no change in behaviors compared with those for the control group using the standardized measure of behavioral symptoms, but found a significant difference in return of behavior to baseline levels (a good outcome) for residents in the intervention group (70% vs. 40% in the control group, p=0.002) (low SOE; Table 27).41 This apparent contradiction may relate to a difference in measurement.

Table 27 Effect of protocols for individualized care interventions on psychosocial outcomes: strength of evidence

Process of Care | Outcome | Number of Studies; Number of Subjects | Risk of Bias; Design/Quality | Consistency | Directness | Precision | Results | Strength of Evidence
Serial Trial Intervention | Behavioral symptoms | 1;114 | Medium; RCT; Good | NA | Direct | Precise | Individualized care vs. control no difference | Low
Serial Trial Intervention | Behavioral symptoms: Return to baseline | 1;114 | Medium; RCT; Good | NA | Direct | Precise | Favors individualized care vs. control | Low
Bathing | Behavioral symptoms | 1;73 | Medium; RCT: Fair | NA | Direct | Precise | Favors individualized care vs. control | Low

NA = not applicable; RCT = randomized controlled trial

The trial of protocols for showering and bathing found a significant reduction in overall agitation and aggression for both groups compared with outcomes in the control group condition (mean time agitated or aggressive 24 to 26% in the intervention groups compared with 36% in the control group, p=0.01 and p=0.02, respectively; low SOE).40

Evidence about effects of protocols for individualized care interventions was insufficient on numerous other outcomes not included in the studies (e.g., engagement, affect, quality of life, quality of dying, spiritual well-being, control, autonomy, choice, satisfaction, use of restraints, use of psychoactive medications).

For KQ 5, the two studies of protocols for individualized care related to psychosocial outcomes for people with dementia did not differentiate findings by dementia severity or other characteristics of the person with dementia (insufficient SOE).

## KQ 3 Health Outcomes for Informal Caregivers of People With Dementia

No studies met inclusion criteria for KQ 3 about the impact of organizational characteristics, structures of care, or processes of care on caregiver health outcomes.

## KQ 4 Psychosocial Outcomes for Informal Caregivers of People With Dementia

No studies met inclusion criteria for KQ 4 about the impact of organizational characteristics, structures of care, or processes of care on caregiver psychosocial outcomes.

## KQ 5 Dementia Severity and Other Characteristics of the Person With Dementia

KQ 5 assessed whether the effect of organizational characteristics, structures, or processes of care on health and psychosocial outcomes varied by the characteristics of the person with dementia (e.g., severity of dementia, functional status) or of the informal caregiver (e.g., age, relationship, health status); we report on relevant KQ 5 studies in the context of KQs 1 to 4.