# References

1 Sloane PD, Zimmerman S, Suchindran C, et al. The public health impact of Alzheimer's disease, 2000-2050: potential implication of treatment advances. Annu Rev Public Health. 2002;23:213-31. [pmid: 11910061].
2 Alzheimer's Association. 2010. Alzheimer's Disease Facts and Figures. 2010. www.alz.org/documents_custom/report_alzfactsfigures2010.pdf. January 19, 2010.
3 American Psychiatric Association and American Psychiatric Association Task Force on DSM-IV. Diagnostic and statistical manual of mental disorders: DSM-IV-TR. Washington, DC. American Psychiatric Association. 2000.
4 Ferri CP, Prince M, Brayne C, et al. Global prevalence of dementia: a Delphi consensus study. Lancet. Dec. 17. 2005;366(9503):2112-7. [pmid: 16360788].
5 Daviglus ML, Bell CC, Berrettini W, et al. NIH State-of-the-Science Conference statement: preventing Alzheimer's disease and cognitive decline. NIH Consens State Sci Statements. Apr. 28. 2010;27(4). [pmid: 20445638].
6 Centers for Medicare & Medicaid Services. Guide to choosing a nursing home: to help you make important decisions for yourself or for someone you care for. U.S. Dept. of Health and Human Services. Washington, DC. 2002. dss.sd.gov/elderlyservices/docs/02174.pdf.
7 Zimmerman S, Sloane PD, Williams CS, et al. Residential care/assisted living staff may detect undiagnosed dementia using the minimum data set cognition scale. J Am Geriatr Soc. Sep. 2007;55(9):1349-55. [pmid: 17767676].
8 National Center for Health Statistics. 2010 National Survey of Residential Care Facilities Data Dictionary: Facility Public-Use File. Atlanta, GA. Centers for Disease Control and Prevention. 2010.
9 Zimmerman S, Sloane PD, Eckert JK. Assisted living: needs, practices, and policies in residential care for the elderly. Baltimore, MD. Johns Hopkins University Press. 2001.
10 Centers for Disease Control and Prevention. FastStats: Nursing Home Care. Atlanta, GA. National Center for Health Statistics. 2011. www.cdc.gov/nchs/fastats/nursingh.htm. January 25 2012.
11 U. S. Dept. of Health and Human Services. National study of assistedl living for the frail elderly: Literature review update. Office of the Assistant Secretary for Planning and Evaluation. 1996. aspe.hhs.gov/daltcp/reports/litrev.pdf. January 25 2012.
12 Park-Lee E, Caffrey C, Sengupta M, et al. Residential care facilities: A key sector in the spectrum of long-term care providers in the United States. National Center for Health Statistics. Hyattsville, MD. 2011. NCHS data brief, no 78.
13 Zimmerman S, Sloane PD, Heck E, et al. Introduction: dementia care and quality of life in assisted living and nursing homes. Gerontologist. Oct. Spec No 1. 2005;45(1):5-7. [pmid: 16230743].
14 Family Caregiver Alliance. Family Caregiver Alliance: National Center on Caregiving. San Francisco, CA. n.d. www.caregiver.org/caregiver/jsp/home.jsp. January 06 2012.
15 U. S. Dept. of Health and Human Services. Informal caregiving: compassion in action. Office of the Assistant Secretary for Planning and Evaluation, U.S. Department of Health and Human Services. Washington, DC. June. 1998.
16 Dempsey NP, Pruncho RA. The family's role in the nursing home: predictors of technical and non-technical assistance. J Gerontol Soc Work. 1994;21(1 & 2):127-46.
17 Hopp F. Patterns and predictors of formal and informal care among elderly persons living in board and care homes. Gerontologist. April. 1. 1999;39(2):167-76. [pmid: 10224713].
18 Stephens MA, Ogrocki PK, Kinney JM. Sources of stress for family caregivers of institutionalized dementia patients. J Appl Gerontol. Sep. 1991;10(3):328-42. [pmid: 10170818].
19 Janzen W. Long-term care for older adults. The role of the family. J Gerontol Nurs. Feb. 2001;27(2):36-43. quiz 54-5. [pmid: 11915264].
20 Yamamoto-Mitani N, Aneshensel CS, Levy-Storms L. Patterns of family visiting with institutionalized elders: the case of dementia. J Gerontol B Psychol Sci Soc Sci. Jul. 2002;57(4):S234-46. [pmid: 12084793].
21 George L, Maddox G. Social and behavioral aspects of institutional care. New York. Routledge. 1989.
22 Centers for Medicare & Medicaid Services. Nursing home compare. n.d. www.medicare.gov/NHCompare/. May 25 2012.
23 Institute of Medicine. Improving the quality of long-term care. Washington, DC. National Academy Press. 2001.
24 Donabedian A. The quality of care. How can it be assessed?. JAMA. Sep. 23-30. 1988;260(12):1743-8. [pmid: 3045356].
25 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. Oct. Spec No 1. 2005;45(1):133-46. [pmid: 16230760].
26 The Green House Project. Arlington, VA. 2011. thegreenhouseproject.org/. February 2, 2012.
27 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. PLoS medicine. Jul. 21. 2009;6(7):e1000097. [pmid: 19621072].
28 Kasuya RT, Polgar-Bailey P, Takeuchi R. Caregiver burden and burnout. A guide for primary care physicians. Postgrad Med. Dec. 2000;108(7):119-23. [pmid: 11126138].
29 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
30 Centre for Reviews and Dissemination. Systematic Reviews: CRD's Guidance for Undertaking Reviews in Healthcare. University of York. 2009.
31 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity, Methods Research Report. Prepared by RTI International -- University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-10056-I. Agency for Healthcare Research and Quality. Rockville, MD. Sep. September. 2010. www.ncbi.nlm.nih.gov/entrez/query.fcgi?cmd=Retrieve&db=PubMed&dopt=Citation&list_uids=21433337. 10-EHC070-EF.
32 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health-care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
33 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. Publication No. 11-EHC019-EF. Rockville, MD. Jan. 2011.
34 Dowling GA, Hubbard EM, Mastick J, et al. Effect of morning bright light treatment for rest-activity disruption in institutionalized patients with severe Alzheimer's disease. Int Psychogeriatr. Jun. 2005;17(2):221-36. [pmid: 16050432].
35 Hickman SE, Barrick AL, Williams CS, et al. The effect of ambient bright light therapy on depressive symptoms in persons with dementia. J Am Geriatr Soc. Nov. 2007;55(11):1817-24. [pmid: 17944896].
36 Leon J, Ory MG. Effectiveness of Special Care Unit (SCU) placements in reducing physically aggressive behaviors in recently admitted dementia nursing home residents. Am J Alzheimers Dis Other Demen. 1999;14(5):270-7.
37 Remington R. Calming music and hand massage with agitated elderly. Nurs Res. Sep-Oct. 2002;51(5):317-23. [pmid: 12352780].
38 Rosswurm MA. Attention-focusing program for persons with dementia. Clin Gerontol. 1990;10(2):3-16.
39 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Oct. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
40 Sloane PD, Hoeffer B, Mitchell CM, et al. Effect of person-centered showering and the towel bath on bathing-associated aggression, agitation, and discomfort in nursing home residents with dementia: a randomized, controlled trial. J Am Geriatr Soc. Nov. 2004;52(11):1795-804. [pmid: 15507054].
41 Kovach CR, Logan BR, Noonan PE, et al. Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Jun-Jul. 2006;21(3):147-55. [pmid: 16869334].
42 Whall AL, Black ME, Groh CJ, et al. Effect of natural environments upon agitation and aggression in late stage dementia patients. AJA. 1997;12(5):216-20.
43 Fritsch T, Kwak J, Grant S, et al. Impact of TimeSlips, a creative expression intervention program, on nursing home residents with dementia and their caregivers. Gerontologist. Feb. 2009;49(1):117-27. [pmid: 19363009].
44 Sloane PD, Zimmerman S, Williams CS, et al. Dying with dementia in long-term care. Gerontologist. Dec. 2008;48(6):741-51. [pmid: 19139248].
45 Tappen RM. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. Jun. 1994;17(3):159-65. [pmid: 8184127].
46 Toseland RW, Diehl M, Freeman K, et al. The impact of validation group therapy on nursing home residents with dementia. J Appl Gerontol. 1997;16(1):31-50.
47 Orrell M, Hancock G, Hoe J, et al. A cluster randomised controlled trial to reduce the unmet needs of people with dementia living in residential care. Int J Geriatr Psychiatry. Nov. 2007;22(11):1127-34. [pmid: 17394129].
48 Ballard CG, O'Brien JT, Reichelt K, et al. Aromatherapy as a safe and effective treatment for the management of agitation in severe dementia: the results of a double-blind, placebo-controlled trial with Melissa. J Clin Psychiatry. Jul. 2002;63(7):553-8. [pmid: 12143909].
49 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
50 Maas ML, Reed D, Park M, et al. Outcomes of family involvement in care intervention for caregivers of individuals with dementia. Nurs Res. Mar-Apr. 2004;53(2):76-86. [pmid: 15084992].
51 Robison J, Curry L, Gruman C, et al. Partners in caregiving in a special care environment: cooperative communication between staff and families on dementia units. Gerontologist. Aug. 2007;47(4):504-15. [pmid: 17766671].
52 Lai CK, Yeung JH, Mok V, et al. Special care units for dementia individuals with behavioural problems. Cochrane Database Syst Rev. 2009;(4):CD006470. [pmid: 19821370].
53 Luo H, Fang X, Liao Y, et al. Associations of special care units and outcomes of residents with dementia: 2004 national nursing home survey. Gerontologist. Aug. 2010;50(4):509-18. [pmid: 20462932].
54 Gruneir A, Miller SC, Intrator O, et al. Hospitalization of nursing home residents with cognitive impairments: the influence of organizational features and state policies. Gerontologist. Aug. 2007;47(4):447-56. [pmid: 17766666].
55 Gruneir A, Lapane KL, Miller SC, et al. Is dementia special care really special? A new look at an old question. J Am Geriatr Soc. 2008;56(2):199-205. [pmid: 18179483].
56 Nobili A, Piana I, Balossi L, et al. Alzheimer special care units compared with traditional nursing home for dementia care: are there differences at admission and in clinical outcomes?. Alzheimer Dis Assoc Disord. Oct-Dec. 2008;22(4):352-61. [pmid: 18978601].
57 Miller SC, Miller EA, Jung HY, et al. Nursing home organizational change: the “Culture Change” movement as viewed by long-term care specialists. Med Care Res Rev. Aug. 2010;67(4 Suppl):65S-81S. [pmid: 20435790].
58 Jones CS. Person-centered care. The heart of culture change. J Gerontol Nurs. Jun. 2011;37(6):18-23. quiz 4-5. [pmid: 21417195].
59 Ekman I, Swedberg K, Taft C, et al. Person-centered care--ready for prime time. Eur J Cardiovasc Nurs. Dec. 2011;10(4):248-51. [pmid: 21764386].
60 Littbrand H, Lundin-Olsson L, Gustafson Y, et al. The effect of a high-intensity functional exercise program on activities of daily living: a randomized controlled trial in residential care facilities. J Am Geriatr Soc. Oct. 2009;57(10):1741-9. [pmid: 19702617].
61 Rogers JC, Holm MB, Burgio LD, et al. Improving morning care routines of nursing home residents with dementia. J Am Geriatr Soc. Sep. 1999;47(9):1049-57. [pmid: 10484245].
62 Alzheimer's Reading Room. The 2011 MetLife market survey of nursing home, assisted living, adult day services, and home care costs. 2011. www.alzheimersreadingroom.com/2011/10/2011-metlife-market-survey-of-nursing.html. January 28 2012.
63 Algase DL, Beattie ER, Antonakos C, et al. Wandering and the physical environment. Am J Alzheimers Dis Other Demen. Jun. 2010;25(4):340-6. [pmid: 20378834].
64 Beattie ER, Song J, LaGore S. A comparison of wandering behavior in nursing homes and assisted living facilities. Res Theory Nurs Pract. Summer. 2005;19(2):181-96. [pmid: 16025697].
65 Bicket MC, Samus QM, McNabney M, et al. The physical environment influences neuropsychiatric symptoms and other outcomes in assisted living residents. Int J Geriatr Psychiatry. Oct. 2010;25(10):1044-54. [pmid: 20077498].
66 Boustani M, Zimmerman S, Williams CS, et al. Characteristics associated with behavioral symptoms related to dementia in long-term care residents. Gerontologist. Oct. Spec No 1. 2005;45(1):56-61. [pmid: 16230750].
67 Buchanan RJ, Choi M, Wang S, et al. Nursing home residents with Alzheimer's disease in special care units compared to other residents with Alzheimer's disease. Dementia. 2005;4(2):249-67.
68 Carter MW, Porell FW. Vulnerable populations at risk of potentially avoidable hospitalizations: the case of nursing home residents with Alzheimer's disease. Am J Alzheimers Dis Other Demen. Nov-Dec. 2005;20(6):349-58. [pmid: 16396440].
69 Chen CK, Zimmerman S, Sloane PD, et al. Assisted living policies promoting autonomy and their relationship to resident depressive symptoms. Am J Geriatr Psychiatry. Feb. 2007;15(2):122-9. [pmid: 17272732].
70 Dobbs D, Munn J, Zimmerman S, et al. Characteristics associated with lower activity involvement in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):81-6. [pmid: 16230754].
71 Edelman P, Kuhn D, Fulton BR. Influence of cognitive impairment, functional impairment and care setting on dementia care mapping results. Aging Ment Health. Nov. 2004;8(6):514-23. [pmid: 15724833].
72 Engel SE, Kiely DK, Mitchell SL. Satisfaction with end-of-life care for nursing home residents with advanced dementia. J Am Geriatr Soc. Oct. 2006;54(10):1567-72. [pmid: 17038076].
73 Givens JL, Kiely DK, Carey K, et al. Healthcare proxies of nursing home residents with advanced dementia: decisions they confront and their satisfaction with decision-making. J Am Geriatr Soc. Jul. 2009;57(7):1149-55. [pmid: 19486200].
74 Gonzalez-Salvador T, Lyketsos CG, Baker A, et al. Quality of life in dementia patients in long-term care. Int J Geriatr Psychiatry. Feb. 2000;15(2):181-9. [pmid: 10679850].
75 Gruber-Baldini AL, Zimmerman S, Boustani M, et al. Characteristics associated with depression in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):50-5. [pmid: 16230749].
76 Kamble P, Chen H, Sherer JT, et al. Use of antipsychotics among elderly nursing home residents with dementia in the US: an analysis of National Survey Data. Drugs Aging. 2009;26(6):483-92. [pmid: 19591523].
77 Kim H, Whall AL. Factors associated with psychotropic drug usage among nursing home residents with dementia. Nurs Res. Jul-Aug. 2006;55(4):252-8. [pmid: 16849977].
78 Kuhn D, Kasayka RE, Lechner C. Behavioral observations and quality of life among persons with dementia in 10 assisted living facilities. Am J Alzheimers Dis Other Demen. 2002;17(5):291-8. [pmid: 12392266].
79 Mitchell SL, Teno JM, Intrator O, et al. Decisions to forgo hospitalization in advanced dementia: a nationwide study. J Am Geriatr Soc. Mar. 2007;55(3):432-8. [pmid: 17341248].
80 Phillips CD, Spry KM, Sloane PD, et al. Use of physical restraints and psychotropic medications in Alzheimer special care units in nursing homes. Am J Public Health. Jan. 2000;90(1):92-6. [pmid: 10630143].
81 Port CL, Zimmerman S, Williams CS, et al. Families filling the gap: comparing family involvement for assisted living and nursing home residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):87-95. [pmid: 16230755].
82 Reed PS, Zimmerman S, Sloane PD, et al. Characteristics associated with low food and fluid intake in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):74-80. [pmid: 16230753].
83 Samus QM, Rosenblatt A, Steele C, et al. The association of neuropsychiatric symptoms and environment with quality of life in assisted living residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):19-26. [pmid: 16230746].
84 Sand BJ, Yeaworth RC, McCabe BW. Alzheimer's disease. Special care units in long-term care facilities. J Gerontol Nurs. Mar. 1992;18(3):28-34. [pmid: 1556394].
85 Sloane PD, Mitchell CM, Preisser JS, et al. Environmental correlates of resident agitation in Alzheimer's disease special care units. J Am Geriatr Soc. Jul. 1998;46(7):862-9. [pmid: 9670873].
86 Tornatore JB, Grant LA. Burden among family caregivers of persons with Alzheimer's disease in nursing homes. Gerontologist. Aug. 2002;42(4):497-506. [pmid: 12145377].
87 Tornatore JB, Grant LA. Family caregiver satisfaction with the nursing home after placement of a relative with dementia. J Gerontol B Psychol Sci Soc Sci. Mar. 2004;59(2):S80-8. [pmid: 15014095].
88 Whitlatch CJ, Schur D, Noelker LS, et al. The stress process of family caregiving in institutional settings. Gerontologist. Aug. 2001;41(4):462-73. [pmid: 11490044].
89 Williams CS, Zimmerman S, Sloane PD, et al. Characteristics associated with pain in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):68-73. [pmid: 16230752].
90 Zeisel J, Silverstein NM, Hyde J, et al. Environmental correlates to behavioral health outcomes in Alzheimer's special care units. Gerontologist. Oct. 2003;43(5):697-711. [pmid: 14570966].
91 Harrington C, Chapman S, Miller E, et al. Trends in the Supply of Long-Term-Care Facilities and Beds in the United States. J Appl Gerontol. August. 1. 2005;24(4):265-82.
92 Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. Oct. 2007;52(4):321-9. [pmid: 18232242].
93 Holmes D, Teresi JA, Ramirez M, et al. An evaluation of a monitoring system intervention: falls, injuries, and affect in nursing homes. Clin Nurs Res. Nov. 2007;16(4):317-35. [pmid: 17991911].
94 Moyer DM, Gilson A. Theoretical perspective concerning effects of environment on SDAT patients as a function of cognitive and behavioral functioning. AJA. 1996;11(5):32-8.
95 Cohen CI, Hyland K, Devlin M. An evaluation of the use of the natural helping network model to enhance the well-being of nursing home residents. Gerontologist. Aug. 1999;39(4):426-33. [pmid: 10495580].
96 Cohen CI, Hyland K, Kimhy D. The utility of mandatory depression screening of dementia patients in nursing homes. Am J Psychiatry. Nov. 2003;160(11):2012-7. [pmid: 14594749].
97 Lord TR, Garner JE. Effects of music on Alzheimer patients. Percept Mot Skills. Apr. 1993;76(2):451-5. [pmid: 8483655].
98 Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. [pmid: 7490386].
99 Dowling GA, Graf CL, Hubbard EM, et al. Light treatment for neuropsychiatric behaviors in Alzheimer's disease. West J Nurs Res. Dec. 2007;29(8):961-75. [pmid: 17596638].
100 Reichenbach VR, Kirchman MM. Effects of a multi-strategy program upon elderly with organic brain syndrome. Phys Occup Ther Geriatr. 1991;9(3-4):131-51.
101 Jablonski RA, Reed D, Maas ML. Care intervention for older adults with Alzheimer's disease and related dementias: effect of family involvement on cognitive and functional outcomes in nursing homes. J Gerontol Nurs. Jun. 2005;31(6):38-48. [pmid: 16138529].
102 Lawton MP, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. Int Psychogeriatr. Dec. 1998;10(4):379-95. [pmid: 9924833].
103 Volicer L, Collard A, Hurley A, et al. Impact of special care unit for patients with advanced Alzheimer's disease on patients' discomfort and costs. J Am Geriatr Soc. Jun. 1994;42(6):597-603. [pmid: 7515405].