# Methods

The methods for this comparative effectiveness review (CER) follow the methods suggested in the ARHQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The main sections in this chapter reflect the elements of the protocol established for the CER; certain methods map to the PRISMA checklist.27 All methods and analyses were determined a priori.

## Topic Refinement and Review Protocol

The topic of this report arose through a public process involving the public, the Scientific Resource Center (SRC), and various stakeholder groups (http://effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/what-is-the-research-process/). Investigators from the RTI-UNC Evidence-based Practice Center then generated an analytic framework, preliminary Key Questions (KQs), and preliminary inclusion/exclusion criteria in the form of PICOTS (populations, interventions/exposures, comparators, outcomes, timing, settings) framework and study design. The processes were guided by the information provided by the topic nominator, a scan of the literature, methods and content experts, and Key Informants. We worked with 8 Key Informants during the topic refinement, and 10 additional individuals participated in the Technical Expert Panel (TEP) (listed in the front matter of this report). Key Informants and TEP members participated in conference calls and discussions through email to review the analytic framework, KQs, and PICOTS at the beginning of the project. Disciplines represented by the Key Informants and TEP included clinicians and researchers in long-term care settings, policy, caregiver advocacy, health care provision, palliative and end-of-life care, minority health issues, dementia care, and consumer advocacy.

TEP members suggested including sleep quality, activity engagement, positive and negative effect, pleasure, use of psychoactive medications, and use of restraints as outcomes of interest for people with dementia. They also suggested including emotional stress, psychosocial stress, family conflict, and self-efficacy as outcomes for informal caregivers. TEP members also provided input on the inclusion and exclusion criteria for the report.

Our KQs were posted for public comment on AHRQ's Effective Health Care Web site from June 27, 2011, to July 25, 2011; the EPC put them into final form after review of the comments and discussion with the TEP.

## Literature Search Strategy

### Search Strategy

To identify articles relevant to each KQ, we searched MEDLINE,^®^ Embase,^®^ the Cochrane Library, the Cumulative Index to Nursing and Allied Health Literature (CINAHL^®^), AgeLine,^®^ and PsycINFO.^®^ We focused our search on long-term care settings, dementia, and informal caregivers by using a variety of terms, medical subject headings (MeSH^®^), and key words. The full search strategy is presented in Appendix A. We reviewed our search strategy with the TEP and incorporated their input into our search strategy.

We limited the electronic searches to English language (consistent with our focus on characteristics, structures, and processes in the United States) and humans. Sources were searched for articles published from 1990 through March 23, 2012, to reflect the changing nature and evolution of nursing homes (NHs) and other residential long-term care settings, especially after the Omnibus Budget Reconciliation Act (OBRA) of 1987 (Public Law 100-203), which established new regulatory standards of NH care. The landmark Nursing Home Reform Act (amendment to Public Law 100-203), which introduced sweeping change in the way NHs were operated and regulated, was passed by the U.S. Congress as part of OBRA 1987; most of its provisions were implemented under regulations promulgated in 1991-1992 (www.access.gpo.gov/nara/cfr/waisidx_02/42cfr483_02.html). Therefore, the investigative team chose 1990 as the beginning date for its literature review, because publications before that date would reflect pre-OBRA status and be of limited relevance to today's long-term care settings.

We manually searched reference lists of reviews, including trials and background articles on this topic, to look for any relevant citations that our searches might have missed and that addressed our KQs. We imported all citations into an electronic database (EndNote^®^ X4).

We conducted an updated literature search (of the same databases searched initially) concurrently with the peer review process. Any literature suggested by peer reviewers or the public was investigated and, if appropriate, incorporated into the final review. We determined the appropriateness of all additional literature by the same methods described in this chapter.

### Inclusion and Exclusion Criteria

We developed eligibility (inclusion and exclusion) criteria with respect to the PICOTS framework (Table 3). Because many studies have not required a formal diagnosis of dementia for subject inclusion, we did not require that the dementia be specified as formally diagnosed dementia. Instead, dementia could be determined by formal diagnosis, signs or symptoms (e.g., cognitive status assessment), or report by staff or an informal caregiver.

Table 3 Study eligibility criteria

Category | Inclusion Criteria | Exclusion Criteria
Population | People with dementia residing within a long-term residential setting with or without coexisting disease Informal caregivers of people with dementia | - No indication of dementia; - People with mild cognitive impairment; - Studies in which the case-mix proportion of the population with dementia is unspecified or <80% or in which analyses have not been conducted specific to the subgroup of people with dementia
Interventions/exposures (described in the Introduction) | Organizational characteristics Structures of care Processes of care | - Interventions/exposures delivered at the person level^a^; - Prescribed therapies (e.g., medication trials, nutritional supplements); - Staff training interventions; - In-home care; - Community services; - Interventions/exposures that require the individual to leave the long-term care setting to receive the intervention
Comparators | Various types or amounts of the intervention/exposure element Combination of certain intervention/exposure elements | - Studies with no comparator
Outcomes | Health outcomes for people with dementia: Pain or discomfort; symptoms of depression; sleep quality; health decline/morbidities (including skin ulcers); decline in functioning, self-care or maintenance; decline in cognitive functioning; falls; mortality; hospitalizations Psychosocial outcomes for people with dementia: Positive and negative affect (e.g., pleasure, anxiety); behavioral symptoms; engagement; quality of life; quality of dying; spiritual well-being; control, autonomy, choice; satisfaction; use of psychoactive medications; use of restraints Health outcomes for informal caregivers of people with dementia: Symptoms of depression; sleep quality; morbidities (e.g., cardiovascular disease) Psychosocial outcomes for informal caregivers of people with dementia: Anxiety; quality of life; caregiver burden; emotional stress; psychosocial stress; quality of relationship with person who has dementia; self-efficacy; guilt; grief reactions; perception of suffering; satisfaction; financial burden; family conflict | - Biomarkers
Timing | No minimum study duration limit | Not applicable
Settings | Nursing homes Residential care / assisted living (and similar settings with a different name, such as board and care homes) Green House homes Alzheimer's special care units Residential long-term hospice care Continuing care retirement communities | - Adult day centers; - PACE; - In-home; - Accessory dwelling units; - Hospitals
Geography | United States | - All other countries
Sample size | Trials with an N≥30 Observational studies with an N≥100 | - Trials with an N<30; - Observational studies with an N<100
Time period | 1990 to March 23, 2012 | - Articles published before 1990
Publication language | English | - All other languages
Admissible evidence (study design and other criteria) | Eligible study designs include the following:; - Randomized controlled trials; - Nonrandomized controlled trials with concurrent eligible controls; - Systematic reviews with or without meta-analyses; - Subgroup and post hoc analyses of data from relevant controlled trials; - Case-control studies; - Prospective-cohort studies | - Case series; - Case reports; - Nonsystematic/narrative reviews; - Editorials; - Letters to the editor; - Pre/post designs without a comparison group; - Focus groups; - Qualitative interviews; - Cross-sectional designs; - Articles rated as poor quality (a high risk of bias)

N = number; PACE = Program of All-Inclusive Care for the Elderly

a Given the intent of this comparison to inform the selection of a setting for individuals with dementia based on organizational characteristics, structures, and processes of care, we restricted interventions to those at the setting/system level (e.g., dementia care unit, something to which all people are exposed) rather than at the person level (e.g., tube feeding, something to which not everyone is exposed).

Through an iterative process, we determined that a study must have explicitly stated that at least 80 percent of the population had dementia or that some analyses were specific to the subgroup of those with dementia. The rationale for this decision was to ensure that the findings were relevant and applicable to the population of interest. Of note, no excluded studies reached even a 70 percent cut-point. In addition, we examined informal caregivers as a population of interest (in KQs 3 and 4).

Interventions/exposures of interest included organizational characteristics, structures of care, or processes of care as defined in the Introduction. Organizational characteristics, structures, and processes of care could either be those inherent to the setting to which people were exposed (e.g., NH vs. RC/AL) or new interventions being implemented. Staff training interventions are not included in this review because they are a proxy for and a presumed indicator of care. Level of training in the context of staff role (i.e., certified nursing assistant, registered nurse, licensed practical nurse, licensed vocational nurse, medical technologist, and other direct-care workers) was considered in this review.

We sought to compare the effectiveness of elements of interventions/exposures with one another and combinations of interventions/exposures. Comparators included various types and amounts (e.g., consistent vs. rotating staffing) of the elements or combinations of certain elements, as exhibited in particular models (e.g., the Green House model). Studies without a comparator were not included in this review. We excluded studies judged to be of poor quality.

In categorizing outcomes, we considered symptoms of depression as health outcomes but other components of affect (e.g., anxiety, pleasure) as psychosocial outcomes. Quality of life could be considered as either a psychosocial outcome or a health outcome. For the purpose of this review, we have categorized it within the psychosocial outcomes (KQ 2 and KQ 4). Caregiver burden, a psychosocial outcome, is defined as “the strain or load borne by a person who cares for an elderly, chronically ill, or disabled family member or other person. It is a multidimensional response to physical, psychological, emotional, social, and financial stressors associated with the caregiving experience.”28

The time period of interest in choosing studies to review was any duration of time beginning after the admission of the person with dementia to a residential long-term care setting until permanent transfer to another setting or death.

We confined our review to studies done in the United States so that the evidence examined would be relevant to care in this country. The health care systems and approaches to long-term care in other countries differ substantially from those here (and from each other), so that research from other countries will be less applicable to the United States than studies done in this country.

### Study Selection

Two people independently reviewed article abstracts using the inclusion/exclusion criteria presented in Table 3. If both reviewers agreed that the study did not meet eligibility criteria, we excluded it; otherwise, two reviewers then independently reviewed the full-text article. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team. A reviewer who was also an author of a specific study was not permitted to make the final determination as to whether the study was included or excluded. Studies excluded at the full-text stage, along with reasons for exclusion, are listed in Appendix B.

### Data Abstraction

For studies that met our inclusion criteria, we abstracted important information into evidence tables. We designed and used structured data abstraction forms to gather pertinent information from each article, including characteristics of study populations, settings, interventions/ exposures, comparators, study designs, methods, and results. Trained reviewers abstracted the relevant data from each included article into the evidence tables. A second member of the team reviewed all data abstractions against original articles for completeness and accuracy. We recorded intention-to-treat results if available. All data abstraction was performed using Microsoft Excel^®^ software. Evidence tables containing all abstracted data of included studies are presented in Appendix C. Evidence tables are organized by study characteristics, study population characteristics, intervention/exposure components, and outcomes.

## Quality Assessment of Individual Studies

To assess the quality (internal validity) of studies, we used predefined criteria based on those developed by the U.S. Preventive Services Task Force (USPSTF) (ratings: good, fair, poor)29 and the University of York Centre for Reviews and Dissemination.30 In general terms, a “good” study has the least risk of bias and its results are considered to be valid. To be rated “good” for the purpose of this review, a trial must have fulfilled all of the following criteria: adequate randomization of patients; adequate allocation concealment; blinded outcome assessors; similar baseline characteristics across treatment arms; overall attrition less than 20 percent; differential attrition less than 15 percent (i.e., there is less than a 15 percentage point difference between attrition in one group and attrition in another); intention-to-treat analysis; and use of equal (across comparison groups), valid, and reliable outcome measures. An observational study receiving the quality rating of “good” must have fulfilled all of the following criteria: prospective design; recruitment from the same source population and during the same time period for the control and intervention subjects; similar inclusion and exclusion criteria across treatment arms; similar length of follow-up; adequate accounting for confounding in statistical analyses or study design; overall attrition less than 20 percent; differential attrition less than 15 percent; and the use of equal, valid, and reliable outcome measures. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. A “poor” study has significant risk of bias (e.g., stemming from serious errors in design or analysis) that may invalidate its results.

Two independent reviewers assigned quality ratings for each study. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team. We gave poor-quality ratings to studies that had a fatal flaw (defined as a methodological shortcoming that leads to a very high risk of bias) in one or more categories. We excluded poor-quality studies from our analyses which could in turn affect the strength of the evidence of the body of literature. Appendix D details the criteria used for evaluating the quality of all included studies. Articles excluded because of a quality rating of poor can be found in Appendix D along with an explanation for the poor-quality rating. A reviewer who was also an author on an included study was not permitted to rate the quality of the study in question.

## Data Synthesis

To determine whether quantitative analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.31 We examined the PICOTS of the included studies, looking for similarities and differences. Because we determined that quantitative analyses were not appropriate (because of clinical heterogeneity, insufficient numbers of similar studies, or insufficiency or variation in outcome reporting), we synthesized the data qualitatively. All syntheses were evaluated by multiple coauthors of this report. A list of outcome measures, their acronyms, and their descriptions can be found in Appendix E.

More specifically, we individually reviewed all articles of good or fair quality to articulate clearly whether the intervention/exposure under study was an organizational characteristic, structure of care, and/or process of care; whether the population under study was people with dementia and/or their informal caregivers; and whether the intervention/exposure was examined in the context of health and/or psychosocial outcomes. Then, the research team evaluated articles in terms of their bias, design, quality, directness, precision, and strength of evidence.

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) based on the guidance established for the Evidence-based Practice Center Program.32 Developed to grade the overall strength of a body of evidence, this approach incorporates four key domains: risk of bias (includes study design and aggregate quality), consistency, directness, and precision of the evidence. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, strength of association (magnitude of effect), and publication bias.

Table 4 describes the grades of evidence that can be assigned. We graded the SOE for a wide array of outcomes relating to KQ 1 and KQ 2:

- Health outcomes for people with dementia, such as pain or discomfort; depressive symptoms; sleep quality; health decline/morbidities including skin ulcers; decline in functioning, self-care, or maintenance; decline in cognitive functioning; falls; mortality; and hospitalizations;
- Psychosocial outcomes for people with dementia, such as positive and negative affect including pleasure and anxiety; behavioral symptoms; engagement; quality of life; quality of dying; spiritual well-being; control; autonomy; choice; satisfaction; use of psychoactive medications; and use of restraints.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition^*^
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

* Owens et al., 2010^32^

At a minimum, two reviewers assessed each domain for each key outcome and resolved any differences by consensus. We used a qualitative process, considering each of the domains, to determine the overall SOE grade for each relevant outcome. Differences in overall SOE grades were resolved by discussion with the research team until reaching consensus. Given that most outcomes had only a single study to provide evidence, consistency would be considered not applicable; when the study had estimates of effects that were not statistically significant or had wide confidence intervals, we rated that domain as imprecise. For outcomes with a single study with imprecise results and for which power was not ensured, we generally graded the SOE as insufficient; for a single study with precise results, we graded it as low. Therefore, although effectiveness is not synonymous with precision nor with SOE, individual studies that showed an effect generally merited a rating of low SOE.

## Applicability

We assessed the applicability of the evidence following guidance from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.33 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence included the following: differences between study resident populations and general resident populations with respect to race, ethnicity, sex, comorbidity, extent of cognitive impairment, and functional status; intensity and delivery of interventions; years in which the studies were performed; and standards of care that differ markedly from settings of interest (e.g., practice standards that vary from State to State).

## Peer Review and Public Commentary

Experts in the field and individuals representing stakeholder and user communities were invited to provide external peer review of this CER. They were charged with commenting on the content, structure, and format of the evidence report, providing additional relevant citations, and pointing out issues related to how we conceptualized the topic and analyzed the evidence. Our peer reviewers (listed in the front matter) gave us permission to acknowledge their review of the draft. AHRQ staff and an associate editor also provided comments. In addition, the Scientific Resource Center posted the draft report on the AHRQ Web site (http://effectivehealthcare.ahrq.gov/) for 4 weeks to elicit public comment. We addressed all peer reviewer and TEP comments, revising the text as appropriate, and documented everything in a “disposition of comments report” that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site. No public comments were received for this report.