# Introduction

## Background

Dementia is a group of neurological conditions that lead to gradual decline in mental function. It is the most common reason for entry into long-term care settings such as nursing homes (NHs) and residential care/assisted living (RC/AL).1 The majority of care for people with dementia is provided in the community by family members; however, increasing care needs in later stages of the illness often lead to placement in a long-term care setting. Because long-term care settings are highly varied, people with dementia and their families who must make a decision regarding placement would benefit from evidence-based guidance on what to choose from the available options. The purpose of this review is to identify and summarize the current evidence regarding which long-term care setting characteristics, structures, or processes are effective for improving health and psychosocial outcomes both for people with dementia and for their family caregivers, so as to provide better guidance to families making placement decisions.

## Definition of Dementia

Dementia is a syndrome with multiple causes characterized by a decline in mental function, marked most commonly by memory impairment and a reduction in at least one other area of cognitive function, such as reasoning, judgment, abstract thought, registration, comprehension, learning, task execution, and use of language.2 The most common type of dementia is Alzheimer's disease; other types include vascular dementia, mixed dementia, dementia with Lewy bodies, and frontotemporal dementia. The Diagnostic and Statistical Manual of Mental Disorders, 4th Edition, Text Revision (DSM-IV-TR) provides a commonly accepted definition of dementia (Table 1).

Table 1 Definitions relating to dementia

Term | Definition
Dementia | “The development of multiple cognitive deficits that include memory impairment and at least one of the following cognitive disturbances: aphasia, apraxia, agnosia, or a disturbance in executive functioning. The cognitive deficits must be sufficiently severe to cause impairment in occupational or social functioning and must represent a decline from a previously higher level of functioning.” (http://dsm.psychiatryonline.org/content.aspx?bookid=22&sectionid=1889063#8455)3
Apraxia | The “impaired ability to execute motor activities despite intact motor abilities, sensory function, and comprehension of the required task.”3
Agnosia | The “failure to recognize or identify objects despite intact sensory function.”3
Executive functioning | “Involves the ability to think abstractly and to plan, initiate, sequence, monitor, and stop complex behavior.”3

## Prevalence of Dementia

More than 5 million Americans—as many as one in every eight individuals ages 65 years or older—have dementia.2 This number may rise to as high as 13 million by 2050.^1^ Dementia increases dramatically with age; the frequency of dementia among people ages 65 to 70 is approximately 2 percent, whereas for people older than 85 it is more than 30 percent.4 The prevalence of dementia differs according to stage of dementia, such that by 2050 approximately 7 million people will have mild dementia, and 6 million will have moderate/severe dementia.1 The impact of dementia relates to its stage.

## Impact of Dementia

Dementia causes significant morbidity and mortality and creates a substantial burden on the people affected, as well as caregivers, health systems, and society.2 Dementia gradually takes away the individual's ability to make decisions, manage personal affairs, and eventually to do even simple tasks such as dressing, toileting, and eating. Late stages are characterized by weight loss, limited mobility, and frequent infections, so that, unless some other illness is fatal sooner, dementia will lead to death. The course from diagnosis to death is variable but is typically from 8 to 12 years. This longevity places a tremendous burden on family caregivers, on personal savings, and on the health care system.2 Costs of dementia care, including both medical care and informal caregiver time, are estimated at more than $148 billion in the United States annually.5

## Dementia in Long-Term Care Settings

Although about 70 percent of people with dementia are cared for at home, the duration and intensity of care needs cause many families to place people affected with dementia into residential long-term care settings as care needs increase.2 Residential settings that provide care for people with dementia are numerous and differ in their organizational characteristics, structures, and processes of care. The four principal categories of setting include the following:2, 6

- Nursing homes. NH settings are federally licensed and regulated settings that provide room, board, 24-hour oversight, health monitoring, assistance with activities of daily living (ADLs), health services, recreational activities, and skilled nursing services. In June 2008, 47 percent of all NH residents had a diagnosis of dementia in their NH record;2 however, many more have dementia without a recorded diagnosis, so the true proportion of residents with dementia may be as high as 80 percent.
- Residential care/assisted living. RC/AL settings are residences that provide room, board, 24-hour oversight, and assistance with ADLs. They vary widely in size, structure, and services, and are licensed by the States under various names, including sheltered housing, domiciliary care, intermediate care housing, adult foster care, assisted living, congregate care, and other labels. Estimates indicate that, depending on the type of RC/AL setting, between 45 percent and 67 percent of residents have dementia.7
- Alzheimer's (or dementia) special care units (SCUs) in RC/AL settings and NH settings. During the past 2 decades, specialized dementia care units have become increasingly common in NH settings and RC/AL settings. As of June 2008, NHs had a total of 86,669 beds in SCUs, accounting for 5 percent of all NH beds. More recently, the growth in SCUs has been largely in RC/AL settings; however, as of 2010 only 11 percent of RC/AL settings had a distinct dementia unit, wing, or floor; of these, the majority had less than 40 percent of their residents in the dementia unit.8 Given that more than 50 percent of residents in both settings have dementia, the majority of NH and RC/AL residents with dementia are clearly not in SCUs.9
- Continuing care retirement communities (CCRCs). CCRCs are retirement communities with different housing and level-of-care options. The area in which a person lives depends on the level of care that he or she needs at a given time. Residents may move from one area to another depending on care needs but stay within the same CCRC. Most CCRCs have both NH and RC/AL beds.

Nationally, 2.36 million older adults reside in long-term care settings. Almost two-thirds (1.5 million) are in one of the country's 16,100 NHs (based on an occupancy rate of 86%), and the remainder (855,000) are in one of 31,100 RC/AL residences (based on an occupancy rate of 88%).10-12 More than one million of these are people with dementia.13

## Critical Role of Family Caregivers in Dementia

People with dementia typically need an increasing amount of assistance as progression occurs, and these care needs extend over many years. Families, not long-term care settings, provide the majority of care to individuals with Alzheimer's disease and related dementias (www.caregiver.org).14 Relatives or friends who provide unpaid care are known as informal caregivers.15

When someone with dementia enters a long-term care setting, family caregivers tend to be intimately involved in the placement decision and remain active after placement.16-18 Families visit long-term care residents an average of 1.9 times a week, for approximately 4.0 to 4.2 hours a week. They are important to the resident to maintain emotional connectedness and psychosocial health. Also, they constitute an important resource to staff because they have knowledge of the resident's history and provide support for ADLs, thereby augmenting the care provided by staff.16-18 Indeed, family presence improves resident psychological and psychosocial well-being, the accuracy of diagnosis, and the resultant care.19 Family members are called on to make decisions regarding care for cognitively impaired residents and to provide continuity that may otherwise be lacking because of staff turnover.20, 21

## Need for Evidence-Based Guidance for Consumers Who Wish To Select a Long-Term Care Setting

Numerous consumer/patient guides are available to help the public choose the type of long-term care setting that may be best for their family member. However, it is unclear whether any of these guides are based on evidence. Instead, most guides focus on geographic factors (such as proximity to family), regulatory criteria (such as level of care needed), financial issues (such as whether a long-term care setting accepts Medicaid, or the overall cost per month for residents who pay privately), or some combination of these considerations. Furthermore, many guides have been developed by one or more organizations with a financial interest in a certain long-term care product.

In addition to these guides, other sources such as quality of care ratings on the Web site of the Centers for Medicare and Medicaid Services offer publicly available information to help families choose among NHs, most notably quality of care ratings on the Web site of the Centers for Medicare and Medicaid Services.22

Despite the potential value of these sources, and inspired by a consumer request, the Agency for Healthcare Research and Quality (AHRQ) identified a need for an unbiased, evidence-based review on factors in long-term care settings themselves that affect the quality of care for individuals with dementia. The topic of our review—the comparison of characteristics of NHs and other residential long-term care settings for people with dementia—addresses this issue, with the goal of reducing the uncertainty of families who are trying to make the best decision regarding a setting of care for a family member with dementia.

## Characteristics of Long-Term Care Settings

One relevant question to ask is whether one type of long-term care setting is superior to another for dementia overall or for certain subgroups of people with dementia, such as those with mild, moderate, or severe dementia. Long-term care settings are complex and vary widely within licensure categories, as was highlighted in the 2001 report of the Institute of Medicine Committee on Improving the Quality of Long-Term Care.23 Therefore, an especially relevant question for family members seeking to select a site is whether certain characteristics are critical in providing quality care for all people with dementia or certain subgroups.

Key characteristics of long-term care settings can be conceptualized in three categories: organizational characteristics, structures of care, and processes of care. Models of health care quality posit that good characteristics and structures increase the likelihood of good processes, which increase the likelihood of good outcomes.24 Table 2 displays definitions and provides examples of each of these key categories of setting characteristics.

Table 2 Organizational characteristics, structures of care, and processes of care

Characteristics | Definitions and Examples
Organizational | Demographic, community, and licensure characteristics of long-term care settings. Includes proprietary status, affiliation (e.g., chain, hospital, CCRC), location (urban vs. rural), size of setting or unit, cost, and resident case-mix (e.g., dementia, Medicaid, race/ethnicity), as well as the overall model of care (e.g., NH, assisted living, Alzheimer's/dementia special care units).
Structures of Care | Attributes of the setting. Includes material resources (e.g., private rooms, familiar homelike components, access to outdoors), human resources (e.g., level of staffing, expertise of staff), and their operation (e.g., hours of care per resident per day by type of worker, consistency of assignment, universal worker perspective).
Processes of Care | What is actually done in giving and receiving care. Includes programs and services implemented at the system/setting level in the context of care provision (e.g., assistance with ADLs, involvement of informal caregivers, activity programs).

ADL = activities of daily living; CCRC = continuing care retirement center; NH = nursing home

Numerous organizational characteristics, structures, and processes of care have been identified as potentially affecting quality of life of people in residential long-term care settings.25 Among those most commonly suggested are the following:

- Organizational characteristics: residence type, age, profit status, affiliation with another level of care, number of beds, presence of a dementia SCU, and resident case-mix (related to dementia diagnosis).
- Structures of care: aspects of staffing (stability of care provider-resident assignment, universal worker perspective [where staff fill multiple roles] vs. specialized worker perspective [where staff have specialized roles], number of nurses and nursing or personal care aides, staff turnover, previous experience in dementia care) and physical structure (lighting, cleanliness).
- Processes of care: care planning (professional staff involvement and aide involvement), policies and practices (admission, discharge, acceptance of behavioral symptoms, policy choice), assessments and treatments conducted, and activities.

## Scope and Key Questions

### Scope of This Review

Considering the central role of family caregivers in deciding which NH or other residential long-term care setting to choose when home care is no longer feasible, information on which components of these settings relate to better outcomes would be very helpful. The above settings offer different levels of care and different services, and to date no comprehensive evidence-based guidance exists that identifies which characteristics or settings are best for which type of resident based on age, severity, or other characteristics. Further, settings that are better for the person with dementia may also be better for the family caregiver, such as by bringing the family peace of mind. The objective of this review, therefore, is to provide information that would help families who are trying to decide where to place a family member who has dementia and who can no longer be cared for at home.

### Key Questions

This review sought to address the following five Key Questions (KQs):

- KQ 1. What is the effectiveness of organizational characteristics, structures, or processes of care in nursing homes and other residential long-term care settings for improving health outcomes for people with dementia?
- KQ 2. What is the effectiveness of organizational characteristics, structures, or processes of care in nursing homes and other residential long-term care settings for improving psychosocial outcomes for people with dementia?
- KQ 3. What is the effectiveness of organizational characteristics, structures, or processes of care in nursing homes and other residential long-term care settings for improving health outcomes for informal caregivers of people with dementia?
- KQ 4. What is the effectiveness of organizational characteristics, structures, or processes of care in nursing homes and other residential long-term care settings for improving psychosocial outcomes for informal caregivers of people with dementia?
- KQ 5. Does the effect of organizational characteristics, structures, or processes of care on health and psychosocial outcomes vary by the characteristics of the person with dementia (e.g., severity of dementia, functional status) or of the informal caregiver (e.g., age, relationship, health status)?

The population of interest for KQs 1, 2, and 5 included people with dementia (i.e., Alzheimer's disease or a related disorder). Wording KQ 1 and KQ 2 in terms of “improving” outcomes for people with dementia recognizes that improvement may be relative; it includes change to a better state of well-being, maintenance of the current state of well-being rather than decline, and also less as opposed to more decline in the current state of well-being. The population of interest for KQs 3, 4, and 5 included informal caregivers of people with dementia of any age, sex, or relationship to the person with dementia. Intervention/exposure elements of interest included organizational characteristics, structures, and processes of care in NHs and other residential long-term care settings for people with dementia. In addition, combinations of certain organizational characteristics, structures, and processes of care as exhibited in particular models of care (e.g., traditional NHs, “Green House” NHs,26 RC/AL settings) were also of interest. Some examples of comparisons of organizational characteristics, structures, and processes of care include not-for-profit versus for-profit, smaller size versus larger size (setting or unit), consistent staffing versus rotating staffing, larger proportion of care paid by Medicaid versus private pay, urban versus rural location, specialized dementia care versus nondementia care, more versus fewer hours of care per resident per day by type of worker, private versus nonprivate rooms and bathrooms, neighborhood versus non-neighborhood designs, centralized versus noncentralized nursing desk, and access to outdoors versus no access to outdoors. Examples of comparisons of combinations of organizational characteristics, structures, and processes of care with other combinations include NH settings versus RC/AL settings, and Green House NHs versus traditional NHs.

We developed an analytic framework to guide the systematic review process (Figure 1).

Figure 1 Analytic framework for comparisons of characteristics of nursing homes and other residential long-term care settings for people with dementia

KQ = Key Question

Figure 1 is titled, “Analytic framework for comparisons of nursing homes and other residential long-term care settings for people with dementia.” This figure depicts the key questions (KQs) within the context of the populations, interventions, comparisons, outcomes, and settings (PICOTS) framework described in this and the Methods section of the report. In general, the figure illustrates how organizational characteristics, structures, or processes of care of nursing homes (NHs) and other residential long-term care (LTC) settings affect mental health and psychosocial outcomes of people with dementia (KQ 1 and KQ 2) as well as informal caregivers of people with dementia (KQ3 and KQ 4). Key Question 5 asks whether there are characteristics of the person with dementia or informal caregiver for which the organizational characteristics, structures, or processes of care differ in how they relate to health and psychosocial outcomes.

Outcome measures for each KQ included health and psychosocial outcomes for people with dementia (KQ 1 and KQ 2, respectively) and informal caregivers (KQ 3 and KQ 4, respectively). KQ 5 assessed whether the effect of organizational characteristics, structures, or processes of care on health and psychosocial outcomes varied by the characteristics of the person with dementia (e.g., severity of dementia, functional status) or of the informal caregiver (e.g., age relationship, health status). This review focused on residential long-term care—that is, settings that provide room and board, 24-hour oversight, health monitoring, and support for ADLs and are licensed by the Federal government and the States as NHs, RC/AL settings, or other similar names that are subsumed within these categories.