# Technical Expert Panel

Technical Experts comprise a multidisciplinary group of clinical, content, and methodologic experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspectives specific to the topic under development. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore study questions, design and/or methodological approaches do not necessarily represent the views of individual technical and content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind nor contribute to the writing of the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as Technical Experts and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Alice Bonner, Ph.D., R.N.

Centers for Medicare & Medicaid Services

Washington, DC

Nicholas Castle, M.H.A., Ph.D.

Department of Health Policy & Management

University of Pittsburgh

Pittsburgh, PA

Cyndy Cordell, M.B.A.

Alzheimer's Association

Chicago, IL

Joseph Gaugler, Ph.D.

School of Nursing, Center on Aging

University of Minnesota

Minneapolis, MN

Laura Gitlin, Ph.D.

Department of Community Public Health

School of Nursing

Center for Innovative Care in Aging

Johns Hopkins University

Baltimore, MD

Robert Kane, M.D.

Center on Aging, School of Public Health

University of Minnesota Evidence-based Practice Center

Minneapolis, MN

Tina Kitchin, M.D.

Department of Human Services

Salem, OR

Maria Llorente, M.D.

Washington DC VA Medical Center

Washington, DC

Susan Mitchell, M.D., M.P.H.

Institute for Aging Research

Harvard Medical School

Boston, MA

Carol Whitlatch, Ph.D.

Margaret Blenkner Research Institute

Benjamin Rose Institute on Aging

Cleveland, OH