# Discussion

This report addressed a question commonly posed when an older adult with dementia requires long-term care beyond what can be provided by the family: What is the best care setting for an older adult with dementia who can no longer be cared for at home? Numerous options are available when this need arises, including traditional nursing homes (NHs), specific models of NHs (e.g., Green House homes), and residential care/assisted living (RC/AL). Because these options differ considerably in various attributes (e.g., settings are of different sizes, have different policies, and offer different services), we assembled and reviewed evidence on specific components of the organizational structure and care and their effects on a range of outcomes for residents who live in such settings. We sought similar information about the effects of interventions on informal caregivers (i.e., family members of long-term care residents), but we identified no eligible studies.

We broadly defined the scope of our review to include all organizational characteristics, structures, and processes of care as they exist in the United States; the substantial differences in health care systems and approaches to long-term care in other countries make studies from other countries less applicable to the United States. Also, we focused on articles published after 1990 to reflect the changing nature and evolution of NH and other residential long-term care settings, especially after the Omnibus Budget Reconciliation Act (OBRA) of 1987 (Public Law 100-203), which established new regulatory standards for NH care (www.access.gpo.gov/nara/cfr/waisidx_02/42cfr483_02.html).

Our review focused on four Key Questions (KQs), differentiated by two types of outcomes relevant to people with dementia and their informal caregivers: health outcomes (KQ 1 and KQ 3, respectively) and psychosocial outcomes (KQ 2 and KQ 4, respectively). We also examined the extent to which outcomes differed according to dementia severity and other characteristics of the person with dementia (KQ 5); these findings are subsumed under KQ 1 and KQ 2.

Below we summarize the main findings and strength of evidence (SOE) for each KQ. In the summary section that follows, we first present findings on outcomes by specific organizational characteristics, structures of care, or processes of care that the included studies had examined.

## Key Findings and Strength of Evidence: Outcomes

### KQ 1 Health Outcomes for People With Dementia

Ten studies examined organizational characteristics (2 prospective cohort studies), structures of care (2 randomized controlled trials [RCTs]), or processes of care (6 RCTs) related to health outcomes for people with dementia. Table 28 presents key findings and the related SOE grades. Across these 10 studies, the health outcomes assessed included functional impairment or decline (including self-care/maintenance), cognitive impairment or decline, depressive symptoms, pain or discomfort, sleep quality, morbidities (e.g., skin ulcers), hospitalization, and mortality. SOE grades are given for all major outcomes and comparisons. For many outcomes such as falls, no evidence was available at all, so SOE was insufficient (these are not noted in the table).

Table 28 Strength of evidence for the effect of organizational characteristics, structures, or processes of care for people with dementia on health outcomes

Outcome | Summary of Results | Strength of Evidence
Functional impairment/decline (including self-care/maintenance) | Functional impairment/decline was worse in RC/AL settings for residents living in a dementia SCU (1 study; 1,252 subjects). | Low
Functional impairment/decline (including self-care/maintenance) | Function was clinically significantly better (equivalent to moving from major to moderate or moderate to minor need for assistance) after functional skill training (1 study; 63 subjects). | Low
Cognitive impairment/decline | Alertness was modestly better (3 percentage points) after creative expression storytelling (1 study; number of subjects not reported). | Low
Depressive symptoms | Depressive symptoms were better for women but worse for men after a bright morning light intervention (1 study; 155 subjects). | Low
Pain/discomfort | Pain/discomfort was better after individualized assessment and management of discomfort (1 study; 114 subjects) and person-centered protocols for showering and bathing (1 study; 73 subjects). | Low
Sleep quality | Sleep quality was better for only those with aberrant sleep cycle timing following morning bright light (1 study; 46 subjects). | Low
New/worsening morbidity and various discrete measures | Morbidity across multiple measures differed little in RC/AL settings compared with NH settings, but was lower in SCUs than in non-SCUs in NHs (1 study; 1,252 subjects). | Low
Hospitalization | Hospitalization occurred more often for residents with mild dementia living in RC/AL settings than for residents in NH settings (1 study; 1,252 subjects). | Low
Hospitalization | Hospitalization occurred more often for NH residents (but not RC/AL residents) not living in dementia SCUs (1 study; 1,252 subjects). | Low
Mortality | Evidence did not support a difference based on residence in an NH setting vs. RC/AL setting or in an SCU vs. non-SCU (1 study; 1,252 subjects). | Low

Note: No study examined the outcomes of falls (insufficient SOE). Not all of the outcome categories in this table were examined in every one of the 10 studies. Only findings with low or better SOE are reported.

NH = nursing home; RC/AL = residential care/assisted living; SCU = special care unit

Regarding organizational characteristics reviewed, NHs and RC/AL differed little on a range of health outcomes. The evidence of the effect of organizational characteristics on these outcomes ranged from insufficient to low. Generally, single studies with no power calculations provided and with imprecise results merited insufficient SOE. Residents with mild dementia in RC/AL, when compared with NHs, had moderately higher hospitalization rates (low SOE) but little difference in morbidity rates regardless of dementia level (low to insufficient SOE). Evidence on SCUs within these settings was inconsistent. Residents of SCUs in RC/AL, when compared with non-SCUs in those settings, had a modestly greater decline in functioning over time (low SOE). On the other hand, residents of dementia SCUs in NHs, when compared with non-SCUs in those settings, had moderately lower rates of both hospitalization and new or worsening morbidity (low SOE).

Only two studies focused on structures of care, finding no effect in the overall populations studied for lighting interventions on sleep quality and depressive symptoms. Both studies found benefits for certain subgroups (women for depressive symptoms and those with aberrant sleep cycle timing for sleep quality). Although these studies suggest that lighting interventions may have more benefit on a person-by-person level as opposed to being a structural intervention throughout a setting, we judge the current evidence as insufficient based on these single studies with imprecise results which did not provide power calculations to justify sample size.

Regarding processes of care, evidence for group activity interventions was mixed. A functional skills training intervention produced moderate effect sizes for improving activities of daily living (ADLs), with effect sizes being equivalent to moving from major to moderate or from moderate to minor assistance in performing ADLs (low SOE). A storytelling intervention modestly improved cognitive alertness (low SOE). A single study of validation therapy groups did not find improvement in functional self-care or depressive symptoms, and a single study of attention-focusing did not find any improvement in cognitive impairment or dementia behavior. However, the evidence was insufficient in these two studies due to imprecise results which did not report power calculations to justify sample size. A personalized assessment and treatment intervention moderately reduced resident discomfort. Finally, personalized showering and towel bath interventions reduced resident discomfort.

### KQ 2 Psychosocial Outcomes for People With Dementia

Ten studies examined organizational characteristics (4 prospective cohort studies), structures of care (1 prospective cohort study), and/or processes of care (5 RCTs, 1 non-RCT, and 1 prospective cohort study) related to psychosocial outcomes for people with dementia. Table 29 presents key findings and the related SOE grades. Across these 10 studies, the psychosocial outcomes assessed included behavioral symptoms (e.g., agitation, aggression), engagement (e.g., social function, withdrawal), affect other than depressive symptoms (e.g., anxiety, pleasure), quality of life in Alzheimer's disease, quality of dying, use of restraints, and use of psychoactive medications. SOE grades are given for all major outcomes and comparisons. For many outcomes such as spiritual well-being, control, autonomy, choice, or satisfaction, no evidence was available at all, so the strength of evidence was insufficient (these are not noted in the table).

Table 29 Strength of evidence for the effect of organizational characteristics, structures, or processes of care for people with dementia on psychosocial outcomes

Outcome | Summary of Results | Strength of Evidence
Behavioral symptoms | Behavioral symptoms were worse after creative expression storytelling (1 study; number of subjects not reported). | Low
Behavioral symptoms | Physical and verbal aggression were better, and physical nonaggression was worse, after validation therapy (based on nurse report). Verbal aggression was worse after validation therapy (based on observer report) (1 study; 88 subjects). | Low
Behavioral symptoms | Agitation was clinically significantly better after pleasant sensory stimulation (2 studies; 99 subjects; decreased 75% to 83% in 1 study). | Moderate
Behavioral symptoms | Behavioral symptoms were better after individualized assessment and management of behavioral symptoms (70% vs. 40% return to baseline) (1 study; 114 subjects). | Low
Behavioral symptoms | Agitation and aggression were better after person-centered protocols for showering and bathing (mean time agitated/aggressive 24% to 26% vs. 36% for control group) (1 study; 73 subjects). | Low
Affect | Anxiety and sadness were worse after creative expression storytelling (1 study; number of subjects not reported). | Low
Engagement | Engagement was better after creative expression storytelling (1 study; number of subjects not reported). | Low
Quality of life | Quality of life over 6 months was statistically, but not clinically, significantly better when specialized workers were used and activities were encouraged (1 study; 421 subjects). | Low
Quality of dying | One study did not find a difference based on residence in an NH setting vs. RC/AL setting (1 study; 422 subjects). | Insufficient a
Psychoactive medication use | One study did not find a difference based on residence in an NH setting vs. RC/AL setting (1 study; 422 subjects) or after validation therapy (1 study; 88 subjects). | Insufficient a
Restraint use | Restraint use in imminently dying residents occurred more often in NH settings than in RC/AL settings (66% vs. 92%) (1 study; 422 subjects). | Low

Note: No study examined the outcomes of spiritual well-being, control, autonomy, choice, or satisfaction (insufficient SOE). Not all of the outcome categories in this table were examined in every one of the 10 studies. Except where indicated, only findings with low or better SOE are reported.

NH = nursing home; RC/AL = residential care/assisted living; vs.= versus

a Evidence was from a single study with imprecise estimates

Regarding organizational characteristics, NHs and RC/AL differed little on behavioral symptoms and engagement (low SOE). Quality of dying, quality of life, and psychoactive medication use also did not differ by setting. However evidence was insufficient concerning the effect of these organizational characteristics in these single studies that had imprecise results and no reported power calculations. Restraints were used more often in imminently dying residents in NHs than in RC/AL (low SOE). The authors suggested additional study of this finding considering that the use of physical restraints in NHs has been strongly discouraged following the Nursing Home Reform Act of 1987 and there is evidence that overall use of restraints is low.44 Behavioral symptoms and engagement did not differ based on residence in an SCU (low SOE), although the two studies reviewed were prospective cohort studies where risk adjustment potentially may not have been sufficient.

Regarding structures of care, quality of life did not differ based on many structures. However, evidence was insufficient concerning the effect of these structures on quality of life in this single study with imprecise results and no reported power calculations. Quality of life was statistically but not clinically significantly better when specialized workers were used (low SOE).

Regarding processes of care, evidence for group activity interventions was again mixed. A storytelling intervention resulted in more challenging behaviors, anxiety, and sadness, and also more engagement (low SOE). An intervention involving validation therapy groups resulted in less physical and verbal aggression, and also more physically nonaggressive behaviors (e.g., restlessness, repetitious mannerisms, pacing), although these findings were not consistent across raters (low SOE). More frequent encouragement of activity participation resulted in statistically but not clinically better quality of life (low SOE). Pleasant sensory stimulation, such as calm music and hand massage, produced a clinically significant decrease in agitation (moderate SOE). A personalized assessment and treatment intervention of behavioral symptoms increased return of behavior to baseline levels (low SOE). Finally, both personalized showering and towel bath interventions reduced behavioral symptoms (agitation and aggression) more in the intervention than control group (low SOE).

### KQs 3 and 4 Outcomes for Informal Caregivers

No studies met inclusion criteria for either of these KQs about the impact of organizational characteristics, structures of care, or processes of care on caregiver health or psychosocial outcomes. Thus, evidence is insufficient for these topics.

Three potential studies 49-51 were identified in this review, each addressing encouragement of family involvement in care as a means to promote improved family/staff relationships and thus improve resident care. While these studies were excluded for methodological shortcomings (e.g. selection bias, high attrition, inadequate randomization), this literature is evolving and represents an increasingly important aspect of NH and residential care for residents with and without dementia.

### KQ 5 Variation by Characteristics of People With Dementia

Two studies examined outcomes of residents with dementia in terms of dementia severity or sociodemographic variables. In one, hospitalization (but not other outcomes) for people in RC/AL settings was more likely for those with mild dementia than for those with moderate to severe dementia. Hospitalization rates did not differ by dementia severity for NH residents. In a second study, a lighting intervention produced better depressive symptoms outcomes for women exposed to morning bright light compared with all-day light, but worse outcomes for men exposed to morning bright light compared with standard light.

## Key Findings and Strength of Evidence: Organizational Characteristics, Structures of Care, and Processes of Care

Table 30 summarizes the SOE we found for statistically significant differences in health and psychosocial outcomes according to organizational characteristics, structures, and process of care.

Table 30 Strength of evidence for the effect of organizational characteristics, structures, or processes of care for people with dementia on health and psychosocial outcomes

Characteristics | Intervention/ Exposure | Summary of Results | Strength of Evidence
Organizational | NH vs. RC/AL | Morbidity across multiple measures differed little in RC/AL settings compared with NH settings (1 study; 1,252 subjects). | Low
Organizational | NH vs. RC/AL | Hospitalization occurred more often for residents with mild dementia living in RC/AL settings than for residents in NH settings (1 study; 1,252 subjects). | Low
Organizational | NH vs. RC/AL | Restraint use in imminently dying residents occurred more often in NH settings than in RC/AL settings (66% vs. 92%) (1 study; 422 subjects). | Low
Organizational | SCU in NH vs. no SCU | Morbidity was lower in SCUs than in non-SCUs in NHs (1 study; 1,252 subjects). | Low
Organizational | SCU in NH vs. no SCU | Hospitalization occurred more often for NH residents not living in SCUs (1 study; 1,252 subjects). | Low
Organizational | SCU in RC/AL vs. no SCU | Functional impairment/decline was worse in RC/AL settings for residents in SCUs (1 study; 1,252 subjects). | Low
Structures of Care | Morning bright light vs. all-day light/control | Depressive symptoms were better for women but worse for men after bright morning light (1 study; 155 subjects). | Low
Structures of Care | Morning bright light vs. all-day light/control | Sleep quality was better for only those with aberrant sleep cycle timing following morning bright light (1 study; 46 subjects). | Low
Structures of Care | Specialized workers vs. not | Quality of life over 6 months was statistically, but not clinically, significantly better when specialized workers were used (1 study; 421 subjects). | Low
Processes of Care | Functional skill training vs. no such training | Function was clinically significantly better (equivalent to moving from major to moderate or moderate to minor need for assistance) after functional skill training (1 study; 63 subjects). | Low
Processes of Care | Creative expression storytelling vs. no such activity | Alertness was modestly better (3 percentage points) after creative expression storytelling (1 study; number of subjects not reported). | Low
Processes of Care | Creative expression storytelling vs. no such activity | Behavioral symptoms, anxiety, and sadness were worse after creative expression storytelling (1 study; number of subjects not reported). | Low
Processes of Care | Validation therapy vs. no such activity | Physical and verbal aggression were better, and physical nonaggression was worse, after validation therapy (based on nurse report). Verbal aggression was worse after validation therapy (based on observer report) (1 study; 88 subjects). | Low
Processes of Care | Encourage activities more vs. less | Quality of life over 6 months was statistically, but not clinically, significantly better when activities were encouraged (1 study; 421 subjects). | Low
Processes of Care | Pleasant sensory stimulation vs. no such stimulation | Agitation was clinically significantly better after pleasant sensory stimulation (2 studies; 99 subjects; decreased 75% to 83% in 1 study). | Moderate
Processes of Care | Individualized assessment and management of discomfort and behavioral symptoms vs. no such protocols | Pain/discomfort was better after individualized assessment and management of discomfort (1 study; 114 subjects; discomfort score 0.89 times lower than control). | Low
Processes of Care | Individualized assessment and management of discomfort and behavioral symptoms vs. no such protocols | Behavioral symptoms were better after individualized assessment and management of behavioral symptoms (1 study; 114 subjects; 70% vs. 40% return to baseline). | Low
Processes of Care | Person-centered protocols for showering and bathing vs. no special protocols | Pain/discomfort was better after person-centered protocols for showering and bathing (1 study; 73 subjects; reduced discomfort by 26% for towel bath, and 14% for person-centered showering). | Low
Processes of Care | Person-centered protocols for showering and bathing vs. no special protocols | Agitation and aggression were better after person-centered protocols for showering and bathing (1 study; 73 subjects; mean time agitated/aggressive 24% to 26% vs. 36% for control group). | Low

NH = nursing home; RC/AL = residential care/assisted living; SCU = special care unit, vs.= versus

Note: No study examined the outcomes of falls, spiritual well-being, control, autonomy, choice, or satisfaction (insufficient SOE). Not all of the interventions/exposures in this table were examined in relation to all outcomes. Only findings with low or better SOE are reported.

### Findings in Relation to What Is Already Known

This systematic review is the first to examine these specific questions in this way. Therefore, we could not compare evidence reported here with any established knowledge base.

### Applicability

This review was intended to apply to all people with dementia regardless of their level of dementia. It also was intended to examine differences in outcomes related to the extent of dementia and other characteristics of the person with dementia, because people with mild, moderate, or severe dementia vary in the extent to which they are able to respond to interventions.

Studies varied in regard to the level of dementia represented. Some included residents only with severe dementia,41, 42 one with moderate to severe dementia,40 some with mild through severe dementia,25, 34-39 and some did not specify the level of dementia.43-46 Those that included only residents with severe dementia were one of the pleasant sensory stimulation studies and the study of individualized assessment and management of discomfort and behavioral symptoms; the findings from these studies are generally applicable to residents with severe dementia. Only one study considered the evidence in relation to the level of dementia severity, examining differences between NH settings and RC/AL settings based on dementia severity for several outcomes: mortality, hospitalization, new or worsening morbidity, and changes in function, cognition, depressive symptoms, behavioral problems, and engagement. It found no differences except an increased risk of hospitalization for residents with mild dementia in RC/AL.39 These findings, which generally did not favor either NHs or RC/AL and were of either insufficient or low SOE, nevertheless are broadly applicable to people with all levels of dementia severity. There is no evidence whether findings from the other studies differed in relation to the level of dementia severity. This is an important omission because needs vary as dementia progresses. Thus, what may be helpful at one point in time (such as to reduce wandering) may not be needed at a later time (if the person becomes bedridden), and what is needed at a later time may not be necessary earlier.

Only one other characteristic of the person with dementia was examined in any study. It found (with low SOE) that the effects of a lighting intervention differed for women and men, with depressive symptoms improved for women but worsened for men, making its implications specific to those subgroups.35 No studies examined differences by characteristics such as race or ethnicity, perhaps because no studies had samples with sufficient variability, especially in regard to ethnicity, to test such differences.

The evidence is therefore insufficient regarding whether the effects of some of the interventions/exposures under study would have been different for different subgroups of the populations. Other than for the small number of findings noted above, we cannot say whether they are the same or different for people at different stages of dementia severity or by other characteristics. This is a serious omission in the literature and our knowledge base.

The interventions/exposures under study included a broad range of organizational characteristics, structures, and processes of care. We had envisioned special interest in exposure to organizational characteristics, such as NH versus RC/AL, small NH versus large NH, and SCU versus no SCU. These are often the level at which families first make their decision regarding a setting of care. However, only four prospective cohort studies (one focused on care for imminently dying residents) provided evidence about these options. Thus, although the evidence is informative, our confidence in whether these effects will hold up over time is low, and future research could either confirm or change them.

The outcomes examined across these 14 studies included eight broad categories of health outcomes and seven categories of psychosocial outcomes. Not all were examined in all studies, and in some cases, a given intervention had both desired and undesired outcomes. For example, creative expression storytelling resulted in better alertness and more engagement but worse behavioral symptoms, anxiety, and sadness. In such instances, families are advised to consider which outcomes are most relevant and which they and the person with dementia most value, and make their decision accordingly.

The SOE for all findings reported in this review, except one, was either low or insufficient. Furthermore, although we found statistically significant effects for some organizational characteristics, structures, and processes of care, for many we found no significant effects. In addition, some statistically significant results were relatively small, meaning that their clinical importance is limited or unclear. Also, it is important to note that not all outcomes were examined in these studies, including falls, spiritual well-being, control, autonomy, choice, and satisfaction. Thus, even though these studies covered a wide array of outcomes, a substantial set of outcomes of interest was never examined. Issues of control, autonomy, choice, and satisfaction remain relevant until late in dementia, and merit better recognition.

Finally, we found no evidence related to health or psychosocial outcomes for informal caregivers of people with dementia. Thus, this review is not directly applicable to such family members or other caregivers, although understanding the benefits or harms of various organizational characteristics, structures, or processes of care for people with dementia may well promote better outcomes for informal caregivers; still, far more evidence is required on this point.

## Implications for Clinical and Policy Decisionmaking

Few studies met the evidence criteria; those that did provided information with only generally low SOE. We found limited evidence related to health and psychosocial outcomes for people with dementia, and none for informal caregivers. Additional research is needed to develop a sufficient evidence base to support family decisionmaking.

As documented in the preceding discussion and tables, the SOE was low for any impact of all but one of the organizational characteristics, structures, and processes of care we examined. The one exception is that SOE was moderate for use of pleasant sensory stimulation to reduce agitation, and we found no evidence that pleasant sensory stimulation resulted in negative outcomes. Therefore, families, providers, policy makers, advocates, and educators may want to promote the use of pleasant sensory stimulation, and researchers may want to study further the use of pleasant sensory stimulation to strengthen the available evidence.

In addition, we found evidence of positive impacts (all low SOE) and no evidence of any negative impacts for a limited number of outcomes in SCUs in NHs (but not RC/AL settings); protocols for individualized care including person-centered showering/bathing and assessment/management of discomfort and behavioral symptoms; functional skill training, use of specialized workers, and encouraging activities.

Apart from our review, other reviews focused on SCUs have shown mixed results on various outcomes. A Cochrane review identified no RCTs investigating the effects of SCUs on behavioral symptoms in dementia; in addition, it found no strong evidence of benefit from available non-RCTs.52 The Cochrane study authors suggested that implementing “best practices” may be more important for resident outcomes than providing a specialized care environment.52 Other specific studies (not included in our review) provide some evidence that SCU residents are at lower risk for hospitalization and more often receive better care, but also that they have greater use of antipsychotic medications.53-55 Conflicting results may in part reflect the fact that SCU residents may have different baseline characteristics from those not residing in SCUs.56 One study reviewed suggested that SCUs might be good for helping segregate populations with different needs.36

Personalized care protocols may have potential effectiveness in that they can be more accurately targeted and possibly have more of a direct effect on outcomes than group activity interventions. In particular, the person-centered showering and bathing intervention protocol that we examined in this review 40 has been widely adopted by practitioners; it is broadly considered an example of culture change that strives to deinstitutionalize NHs and individualize care.57 More generally, both in the United States and overseas, person-centered care has received broad support.58, 59 A wide range of personalized care interventions related to organizational characteristics, structures, and processes of care fit within this broader effort, including care provision in smaller, home-like settings.57 Further, the one study we reviewed that found both positive and negative outcomes related to the use of morning bright light (decreased depressive symptoms for women, increased depressive symptoms for men)35 suggests that lighting interventions may best be applied at the person level rather than the setting level.

Functional skill training in ADLs has also had mixed effects, including short-term but not long-term functional benefits.60 The functional skill training examined in this review,45 as well as a behavioral rehabilitation intervention for improving the performance of morning care activities61 both found some success. Given the challenges of improving function in this population and the limited research available, additional study is needed to test new interventions. This point is especially important because the functional skill training studied was conducted 5 days per week for 2.5 hours per day over 20 weeks, which limits its feasibility for wide-spread adoption.

Studies found both positive and negative evidence for a limited number of outcomes for residents of NH settings as compared with residents of RC/AL settings. Residents with mild dementia were less likely to be hospitalized if they resided in NHs, and residents in NHs were more likely to have stable health before death. The explanation may be that NH settings, as contrasted with RC/AL settings, can provide more medical care and have more nursing staff. However, we found no evidence regarding differences across these setting types in relation to behavioral symptoms, engagement, quality of life, quality of dying, and for imminently dying residents, psychoactive medication use. If people with dementia and their families are choosing between NH settings and RC/AL settings, considering the individual's current medical needs and health stability will be helpful. In addition, taking into account the difference in costs between these two settings (annual 2011 rate $78,000 to $87,000 in NHs and $42,000 in RC/AL settings)62 and the availability of Medicaid (should it be necessary) may also be important.

## Limitations of the Comparative Effectiveness Review Process

This comparative effectiveness review evaluated outcome differences examined over time. Thus, cross-sectional studies were considered as not as directly pertinent or appropriate to include. Many cross-sectional studies that have adjusted for confounders have been conducted over the years, and some might inform the research questions with respect to effectiveness.

We found almost 30 cross-sectional studies with potential relevance.53-55, 63-90 For example, evidence from cross-sectional studies has indicated that hospitalization is less likely in NH SCUs (compared with NHs with no SCU), when more residents with dementia are present in the NH, and when Medicaid payment rates are relatively higher. In addition, depressive symptoms and pain were higher in for-profit settings than nonprofit settings.54, 75, 89 This type of information may be helpful for family members when determining the optimal setting of care for relatives with dementia, but such studies might well have higher risks of bias than the studies we included and, therefore, would not produce findings of materially higher SOE.

In addition, we dropped from our analyses any study for which our quality rating was poor; we retained only trials or prospective cohort studies assessed as either good or fair. Given the fact that the SOE was principally low (if not insufficient), we do not believe that adding poor-quality studies, which may have involved yet other organizational characteristics, structures of care, or processes of care, would have improved the overall robustness or applicability of this body of evidence.

## Limitations of the Evidence Base

We excluded numerous studies of potential relevance conducted in NH settings and RC/AL settings for a variety of reasons determined a priori. Particularly relevant were two criteria: that the studies did not specify that at least 80 percent of the study population had dementia and that analyses had not been conducted specific to the subgroup of those with dementia. A total of 136 studies were excluded because they did not meet these criteria; some might have been excluded for other reasons as well and in none did at least 70 percent of the population have dementia. Despite the fact that a large proportion of residents in NH settings and RC/AL settings have dementia,25 we still had to ensure that the populations analyzed in the included studies were specific to this review.

## Research Gaps

Assuming that the overriding (or first) question for stakeholders is whether an individual with dementia is best served in an NH or RC/AL setting, or in an SCU, we reiterate that we found no RCTs to answer these questions and only quite sparse evidence from nonexperimental studies. RCTs would not be expected to inform the matter of NH settings versus RC/AL settings, given that they would be hard to justify in ethical or feasibility terms. Trials of placement in SCUs might be possible, however. All things considered, additional high-quality prospective cohort studies would be beneficial in clarifying the advantages and disadvantages of residence in different types of settings, especially because the majority of RC/AL residents have dementia7 and the number of RC/AL beds almost doubled in the last 20 years.91

The wide array of structural variables and process interventions/exposures that surfaced in this work reflects impressive thinking about all the factors that either experience or theory suggests might improve the quality of life and outcomes of people with dementia. This diversity did, however, make it impossible for us to improve estimates of effect sizes of any one characteristic, structure, or process by pooling data. We are not convinced that continued “one-off” studies are the best possible use of research resources. Instead, concerted emphasis on key structural variables or types of specialized services may be warranted in coming years, so that findings can be combined in quantitative analyses to yield stronger evidence for decisionmaking by all stakeholders. Two examples of this type of effort include the National Institute on Aging studies examining SCUs (launched in 1991), and the Robert Wood Johnson Foundation collaborative of research projects examining Green House NHs (launched in 2011). Related to this strategy is the suggestion that all studies conducted in NHs and other residential long-term care settings indicate the number and percentage of residents with dementia who composed the sample, and analyze data specific to these individuals.

Of special concern might be efforts to maintain or improve physical function and to decrease pain/discomfort and behavioral symptoms in this population. Thus, we emphasize that additional studies are warranted to test interventions that show some promise, including functional skill training,45 pleasant sensory stimulation,37, 42 and individualized protocols for care,40, 41 in addition to exploring the impact of enhanced or completely new interventions in this area. Of particular importance is to build on the existing empirical work and also on robust conceptual frameworks and clinical or behavioral theories about what might “work best” for these individuals.

Another consideration about future research involves the types of outcomes to be studied. As noted, we identified a considerable array of health and psychosocial outcomes about which we believed clinicians, people with dementia and their families, and other interested parties would want to know more. Of these, no evidence at all surfaced on several important matters, including falls and several aspects of psychosocial well-being including spiritual well-being, control, autonomy, choice, and satisfaction. Some research effort to clarify care related to these outcomes is warranted, although they may be less salient for decisionmaking than matters such as depressive symptoms, hospitalization, and quality of life. Falls are especially important insofar as they constitute a significant threat to safety and cost to the health care system, which is a matter of concern for residents and families, staff, administrators, and policymakers.

A related matter may be encouraging investigators to use established outcome measures that have proven reliability and validity. Consolidation on some types of measures might enhance the possibility of quantitative pooling of studies (other things equal) or at least of some qualitative interpretations of the same (or very similar) outcome information. Many studies in this review used the Cohen-Mansfield Agitation Inventory (CMAI, a measure of behavioral symptoms),37, 39, 42, 46 and other established measures are available for numerous other outcomes of interest.

Cutting across components of care and outcomes is the question of methods. As noted, of the 14 studies finally included, we could rate the quality of the investigation as good for only 4 studies. We excluded 15 studies because of substantial flaws that yielded quality ratings of poor (Appendix D). The principal problems of these studies, which hinge on threats to internal validity (substantial risks of bias), were performance bias (e.g., care providers provided care in both arms of the study),92-94 selection bias (e.g., groups were not similar at baseline),49, 51, 95-98 detection bias (e.g., raters were not blind to the group to which the resident belonged),99, 100 and attrition bias (e.g., greater than 20%).50, 101-103 Thus, we conclude that future research should attempt to overcome at least the primary deficits of this entire body of work. For example, investigators should attend more closely to masking raters and maintaining consistent raters over time, assuring similar representation of subjects across arms, focusing on fidelity, and accounting for missing data in their analyses.

Moreover, most studies were relatively small. Larger sample sizes might allow investigators to gain more precision in estimates of differential effects or changes over time. Then, they will be in a better position to say more about the superiority (or inferiority) of various organizational characteristics and interventions. Admittedly, larger studies are more costly to conduct, again highlighting the benefit of conducting studies with a concerted emphasis in one area, such as a program project or other collaborative studies wherein separate studies designed to inform different areas include similar subjects and use common measures. Similarity, more attention to the heterogeneity of people with dementia, and examining how different levels of dementia and other differences (measured in consistent ways) relate to outcomes, will better inform the matter of applicability.

Finally, the number of people with dementia who reside in traditional and emerging settings can only rise in the future. Finding answers to the numerous questions and concerns that people today might have about dementia care (for themselves and for family members) is crucial. Focusing on truly critical choices and questions, and improving the quality of studies, are crucial steps for providing actionable information for such difficult decisions.

To summarize, we suggest the following guidance for future research:

- Examine differences between NH settings versus RC/AL settings, and between SCUs and settings without SCUs as related to outcomes for people with dementia and their caregivers.
- Conduct studies with concerted emphasis on key organizational characteristics, structures, and processes of care as opposed to one-of studies.
- Indicate the number and percentage of residents with dementia who composed the sample, and analyze data specific to these individuals.
- Examine how results differ according to characteristics of the person with dementia, especially the degree of dementia.
- Continue studying outcomes of depressive symptoms, hospitalization, and quality of life, but also consider the relevance of other outcomes including falls, spiritual well-being, control, autonomy, choice, and satisfaction.
- Use established outcome measures to enable the pooling of data or qualitative interpretations.
- Employ rigorous methodologies that overcome bias, and use samples of sufficient size to provide precise estimates.

## Conclusions

Overall, we generally found either low or insufficient SOE about the effectiveness or comparative effectiveness of organizational characteristics, structures, and processes of care for people with dementia. This is true about both their health and their psychosocial outcomes. Virtually no good or fair evidence meeting our inclusion criteria exists about health and psychosocial outcomes for informal caregivers of people with dementia.

Even with those caveats, we can state some conclusions about interventions. In particular, findings of moderate SOE indicate that pleasant sensory stimulation reduces resident agitation. In addition, even though the SOE was only low, protocols for individualized care can reduce resident pain/discomfort and agitation/aggression, and functional skill training of people with dementia can improve their functioning. Further, if people with dementia and their families are making a choice between NH settings and RC/AL settings, considering the individual's current medical needs and health stability is important because these settings do not differ much in outcomes other than those relating to people for whom medical care is indicated or for whom NHs may be better suited on other grounds.