# Outcome Scales Commonly Used in Dementia Studies

Table E-1 Outcome scales commonly used in dementia studies

Abbreviated Name | Complete Name of Measure or Instrument | Description | Range or Mean of Scores | Improvement Denoted by
BEHAVE-AD | Behavioral Pathology in Alzheimer's Disease | - Measures behavioral and psychological symptoms of dementia in persons with Alzheimer's disease.; - Based on interview with the participant. | 0-42 | Decrease
CAREBA | Care Recipient Behavior Assessment | - Modification of the CMAI.; - Based on observations of the participant. | NR | Decrease
CMAI | Cohen Mansfield Agitation Inventory | - Assess manifestations of agitated behaviors in elderly people with cognitive impairment; - Based on caregiver report. | Varies | Decrease
CMAI-N | Nurse-derived Cohen-Mansfield Agitation Inventory | - Assess manifestations of agitated behaviors in elderly people with cognitive impairment; - Based on nursing staff report | Varies | Decrease
CMAI-O | Observer-derived Cohen-Mansfield Agitation Inventory | - Assess manifestations of agitated behaviors in elderly people with cognitive impairment; - Based on non-participant observations of video-tapes | Varies | Decrease
CSDD | Cornell Scale for Depression in Dementia | - Identification of depressive symptoms and sign in people with Alzheimer's Disease and other dementias.; - Based on participant and caregiver report and clinical observation. | 0-38 | Decrease
DBS | Dementia Behavior Scale | - Evaluate function deficits in cognitive and psychomotor areas.; - Based on observations of the participant | 0-48 | Decrease
Discomfort-DAT | Discomfort – Dementia of the Alzheimer's Type | - Measures overall discomfort by vocalizations, breathing, facial expressions, and body movement; - Based on observations of the participant | 0-900 | Decrease
FAST | Functional Assessment Staging | - Stages severity of dementia via a measurement of functional deficits, mental age, and MMSE score.; - Based on observations of the participant | Stages 1-7 | Decrease
GIPB | Geriatric Indices of Positive Behavior | - Measures the occurrence of verbal, nonverbal, and noninteractive, positive behaviors; - Base on observations of the participant | NR | Decrease
MDS-ADL | Minimum Data Set Activities of Daily Living Scale | - Used to measure activities of daily living | 0-21 | Decrease
MDS-COGS | Minimum Data Set Cognition Scale | - Assess the presence and severity of cognitive impairment. | 0-10 | Decrease
MMSE | Mini-Mental State Examination | - Measures global cognitive status in older people; - Based on interviews with the participant | 0-30 | Increase
MOSES | Multidimensional Observation Scale for Elderly Subjects | - Assess participants' psychosocial function; - Based on informant report | Varies | Decrease
PGCARS | The Philadelphia Geriatric Center Affect Rating Scale | - Assess positive and negative affect; - Based on observations of the participant | 0-100 | Decrease
QOL-AD | Quality of Life scale in Alzheimer's Disease | - Assess the quality of life of persons with dementia; - Based on self and caregiver report | 13-52 | Increase
SPMSQ | Short Portable Mental Status Questionnaire | - Assess the mental status of an elderly person; - Based on interview with the participant | 0-10 | Decrease