# Quality Assessment

This appendix describes the criteria relating to internal validity and the procedures that topic teams follow for all updates and new assessments in making these judgments.

All topic teams use initial “filters” to select studies for review that deal most directly with the question at issue and that are applicable to the population at issue. Thus, studies of any design that use outdated technology or that use technology that is not feasible for long-term residential care may be filtered out before the abstraction stage, depending on the topic and the decisions of the topic team. The teams justify such exclusion decisions if there could be reasonable disagreement about this step. The criteria below are meant for those studies that pass this initial filter.

Presented below are a set of minimal criteria for each study design and then a general definition of three categories: “good,” “fair,” and “poor,” based on those criteria. These specifications are not meant to be rigid rules but rather are intended to be general guidelines, and individual exceptions, when explicitly explained and justified, can be made. In general, a “good” study is one that meets all criteria well. A “fair” study is one that does not meet (or it is not clear that it meets) at least one criterion but has no known “fatal flaw.” “Poor” studies have at least one fatal flaw.

## Systematic Reviews

### Criteria

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important for systematic reviews

### Definition of Ratings From Above Criteria

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

## Case-Control Studies

### Criteria

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

### Definition of Ratings Based on Criteria Above

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.

Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rate less than 80 percent or attention to some but not all important confounding variables.

Poor: Major selection or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

## Randomized Controlled Trials and Cohort Studies

### Criteria

- Initial assembly of comparable groups: for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies, or intention to treat analysis for RCTs.

### Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow-up at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.

Fair: Studies will be graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with follow-up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.

Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs, intention to treat analysis is lacking.

## Criteria for Assessing External Validity (Generalizability) of Individual Studies

Each study that is identified as one that provides evidence to answer a KQ is assessed by according to its external validity (generalizability) using the following criteria.

### Study Population

The degree to which the people who were involved as subjects in the study constitute a special population because they were selected from a larger eligible population or were for other reasons unrepresentative of people who are likely to seek or be candidates for the preventive service. The selection has the potential to affect the following:

- absolute risk: The background rate of outcomes in the study could be greater or less than what might be expected in asymptomatic people because of the inclusion/exclusion criteria, because of non-participation, or for other reasons.
- harms: The harms observed in the study could be greater or less than what might be expected in asymptomatic people.

The following are features of the study population and the study design that may cause experience in the study to be different from what would be observed in the US long-term residential care population:

- demographics (age, gender, ethnicity, education, income): The criteria for inclusion/exclusion or non-participation do not encompass the range of people likely to be candidates for the preventive services in the US long-term residential care population.
- co-morbidities: the frequency of co-morbid conditions in the study population does not represent of the frequency likely to be encountered in people who seek the preventive service in the U.S. long-term residential care population.
- special inclusion/exclusion criteria: There are other special inclusion/exclusion criteria that make the study population unrepresentative.
- refusal rate (ratio of included to not-included but eligible participants): The refusal rate among eligible study subjects is high, making the enrollees in the study unrepresentative even of the people eligible for the study.
- adherence (run-in phase, frequent contact to monitor adherence): The design of the study has features that may make the effect of the intervention in the study greater than it would be in a clinically observed population.
- stage in natural history of dementia; severity of dementia: the selection of subjects for the study includes people with at a stage that is earlier or later than would be found in people who are candidates for the preventive service.
- source, intensity of recruitment: The sources for recruiting subjects for the study and/or the effort and intensity of recruitment may distort the characteristics of the study subjects in ways that could increase the effect of the intervention as it is observed in the study.

### Situation

The degree to which the clinical experience in the situation in which the study was conducted is likely to be reproduced in other settings

- healthcare system: The clinical experience in the system in which the study was conducted is not likely to be the same as experience in other systems because, for example, the system provides essential services for free when these services are only available at a high cost in other systems.
- country: The clinical experience in the country in which the study was conducted is not likely to be the same as in the U.S. because, for example, services available in the U.S. are not widely available in the other country of study conduct or vice versa.
- selection of participating centers: The clinical experience in which the study was conducted is not likely to be same as in other settings in which the service will be delivered to the U.S. long-term care population because, for example, the centers have ancillary services not available generally.
- time, effort, and system cost for the intervention: The time, effort, and cost to develop the service in the study is more than would be available outside the study setting.

### Providers

The degree to which the providers in the study have the skills and expertise likely to be available in general settings

- training to implement the intervention: The intervention in the study was done after giving providers special training not likely to be available or required in U.S. long-term residential care settings
- expertise, skill to implement intervention: The providers included in the study had expertise and/or skills at a level that is higher than the level likely to be encountered in typical settings.
- ancillary providers: The study intervention relied on ancillary providers who are not likely to be available in typical settings.

### Global Rating of External Validity (Generalizability)

External validity is rated “good” if the study differs minimally from the US long-term residential care population/ situation/ providers and only in ways that are unlikely to affect the outcome; it is highly probable (>90%) that the clinical experience with the intervention observed in the study will be attained in the US primary care setting.

External validity is rated “fair” if the study differs from the US long-term residential care population/ situation/ providers in a few ways that have the potential to affect the outcome in a clinically important way; it is only moderately probable (50%-89%) that the clinical experience with the intervention in the study will be attained in the US primary care setting.

External validity is rated “poor” if the study differs from the US long-term residential care population/ situation/ providers in many way that have a high likelihood of affecting the clinical outcomes; the probability is low (<50%) that the clinical experience with the intervention observed in the study will be attained in the US primary care setting.

## Quality Ratings

Table D-1 Quality ratings for trials

Author, Year Trial Name | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Were outcome assessors masked? | Were care providers masked? | | Were patients masked? | Was overall attrition ≥20%? | Was differential attrition ≥15%? | Did the study use ITT analyses? | Were outcome measures equal, valid and reliable? | | Quality Rating^a^
Chapman, 2007^1^ NA | Yes | Yes | No | No | No | | No | NR | NR | NR | Yes | | Poor
Cohen, 1999^2^ NA | NA | NA | No | Yes | NR | | No | Yes | No | NR | Yes | | Poor
Cohen, 2003^3^ NA | NA | NA | No | NR | No | | NR | No | Yes | NR | NR | | Poor
Dowling, 2005^4^ NA | Yes | No | NR | Yes | No | | No | NR | NR | Yes | Yes | | Fair
Dowling, 2007^5^ NA | Yes | No | NR | No | No | | No | NR | NR | NR | No | | Poor
Fritsch, 2009^6^ NA | Yes | NR | Yes | No | No | | No | NR | NR | No | Yes | | Fair
Hickman, 2007^7^ NA | Yes | No | Yes | No | No | | No | No | No | No | Yes | | Fair
Holmes, 2007^8^ NA | No | No | No | No | NA | | No | No | No | No | Yes | | Poor
Jablonski, 2005^9^ Family Involvement in Care | NR | NR | No | NR | No | | No | Yes | No | No | Yes | | Poor
Kovach, 2006^10^ NA | Yes | Yes | Yes | Yes | Yes | | Yes | No | No | No | Yes | | Good
Lawton, 1998^11^ NA | No | NR | NR | No | No | | NR | Yes | No | No | NR | | Poor
Lord, et al. 1993{#7197 | NR | NR | Yes | No | No | | No | NR | NR | NR | No | | Poor
Maas, 2004^12^ NA | Yes | No | Yes | NR | No | | No | Yes | NR | No | Yes | | Poor
McCallion, 1999^13^ NA | NR | NR | No | No | Yes | | No | No | NR | Yes | Yes | | Poor
Moyer, 1996^14^ NA | No. | No | No | yes | Yes | | Yes | NR | NR | NR | Mixed | | Poor
Reichenbach, 1991^15^ NA | Yes | NR | Yes | NR | NA | | NA | No | No | No | No | | Poor
Remington, 2002^16^ NA | Yes | Yes | Yes | No | No | | No | No | No | No | Yes | | Fair
Robison, 2007^17^ Partners in Care | NR | NR | No | NR | No | No | | No | No | No | | Yes | Poor
Rosswurm, 1990^18^ NA | NR | Yes | Yes | Yes | No | NR | | No | No | Yes | | Yes | Good
Schnelle, 1995 19 | NR | NR | NR | No | No | Yes | | No | No | No | | Yes | Poor
Sloane, 2004^20^ NA | NR | NR | Yes | Yes | No | No | | No | No | Unclear /NR | | Yes | Fair
Tappen, 1994^21^ NA | NR | NR | NR | Yes | No | NA | | NR | NR | No | | Yes | Fair
Tosleand, 1997^22^ NA | NR | NR | Yes | Yes | No | No | | Yes | No | Unclear /NR | | Yes | Fair
Whall, 1997^23^ NA | NA | No | NR | NR | NR | NR | | No | No | No | | Yes | Fair

a Rationale for poor quality studies can be found in Table 3.

Abbreviations: NA, not applicable; NR, not reported

Table D-2 Quality ratings for prospective cohort studies

Author, Year Trial Name | Were groups recruited from the same source population? | Were subject in both groups recruited over the same time period? | Were inclusion and exclusion criteria equally applied in both groups? | Was an attempt made to blind the outcome assessors? | Was the time of follow-up equal in both groups? | Were differences between groups taken into account in the statistical analysis? | Was confounding adequately accounted for either through study design or statistical analysis? | Was overall attrition ≥20%? | Was differential attrition ≥15%? | Were any participants who started the trial excluded from the analysis? | Were outcome measures equal, valid and reliable? | Quality Rating^a^
Leon, 1999^24^ NA | Yes | Yes | Yes | No | Yes | Yes | Yes | No | No | Yes | Yes | Fair
Sloane, 1991^25^ NA | Yes | Yes | Yes | No | Yes | Yes | Yes | No | No | No | Yes | Good
Sloane, 2005^26^ Collaborative Studies of Long-Term Care | Yes | Yes | Yes | No | Yes | Yes | Yes | NA | NA | No | Yes | Good
Sloane, 2008^27^ Collaborative Studies of Long-Term Care | Yes | No | Yes | No | Yes | Yes | Yes | No | No | No | Yes | Good
Volicer, 1994^28^ NA | No | Yes | Yes | No | Yes | NR | Yes | NR | NR | NR | Mixed | Poor
Zimmerman, 2005^29^ Dementia Care Project | Yes | Yes | Yes | No | Yes | Yes | Yes | No | No | No | Yes | Fair

a Rationale for poor quality studies can be found in Table 3.

Abbreviations: NA, not applicable; NR, not reported

Table D-3 Rationale for Poor Quality Rating

Author, Year Trial Name | Primary Reasons for Poor Quality Rating
Chapman, 2007^1^ NA | High potential for performance bias. Care providers were providing care in both arms of the study. High potential for selection bias. Differences between groups in baseline characteristics. Potential for attrition bias. Study did not report attrition statistic.
Cohen, 1999^2^ NA | High potential for selection bias. Baseline groups not similar, study not randomized and differences not controlled for. High potential for performance bias as care providers were not masked. High potential for attrition bias. Study attrition ≥ 20%. Not clear as to whether ITT analysis was used.
Cohen, 2003^3^ NA | High potential for selection bias. The study had different eligibility criteria for group 1 and group 2. High potential for attrition bias. Differential attrition equaled 28% between groups. Potential for performance bias. Changes in treatment which were not monitored were noted as confounder.
Dowling, 2007^5^ NA | High potential for detection bias. The raters were not blind and they changed over time; also, inter-rater reliability was not tested. High potential for selection bias. Allocation concealment was not adequate. Unequal sized groups with no report of block size or rationale for differences in size. Differences in baseline characteristics not tested for significance.
Holmes, 2007^8^ NA | High potential for performance bias. Study reports that the less worse affect scores may have been the result of more direct care hours. Also poor fidelity to the intervention. High potential for selection bias. Covariates for cognition and functional status did not strongly control enough for case mix differences at baseline. Continued direct care intervention at even higher pre-intervention levels may have caused the less worse affect in the intervention group.
Jablonski, 2005^9^ Family Involvement in Care | High potential for attrition bias. Attrition rate was >20%. Did not account for missing data in the analysis. Reported differences between those lost to attrition. High potential for selection bias. Groups dissimilar at baseline. High potential for performance bias. Differences in the “dose’ of the intervention per person.
Lawton, 1998^11^ NA | High potential for attrition bias. Attrition was 44%-49%, and ITT analyses were not done. High potential for performance bias. The study makes explicit mention related to poor fidelity. High potential for detection bias. Raters aware of the identity of control and experiment groups as well as the hypotheses of the intervention's impact.
Lord, 1993^30^ | High potential for selection bias. Randomization and allocation not adequate. Does not report on similarities or differences among groups at baseline. High potential for attrition bias. No attrition statistic reported. High potential for detection bias. Outcome measures not assessed for reliability or validity.
Maas, 2004^12^ NA | High potential for attrition bias. Overall attrition equaled 55%.
McCallion, 1999^13^ NA | High potential for selection bias. Randomization scheme not reported. Significant difference in baseline characteristics High potential of detection bias. Contamination by inadequate blinding.
Moyer, 1996^14^ NA | High potential for performance bias. Unclear that the interventions were different from each other at all. High potential for reporting bias. The abstract and body of the text differed in which group was experimental and which was control. Limited data are presented. High potential for selection bias. Study utilized convenience sample; residents of one larger facility were compared with 3 smaller ones.
Reichenbach, 1991^15^ NA | High potential for detection bias. Lack of assessor blinding, with consequent observer bias is strongly suspected based on statistically significant findings in all measures. High potential for selection bias. Lack of information on whether randomization occurred, and whether the experimental and control groups were within separate facilities or within both of the study facilities.
Robison, 2007^17^ Partners in Care | High potential for selection bias. Study does not report baseline statistics. High potential for reporting bias. Selective outcome reporting. High potential for attrition bias. Completer analysis used. When examining ITT analysis, most of the significant effects go away.
Schnelle, 1995^19^ NA | High potential for selection bias. Unclear if there are significant differences between groups at baseline due to lack of reporting. High potential for Attrition bias. Study report a loss of 51% of study participants and do not account for this in their analysis. High potential for detection bias. Assessors for the intervention group were not blinded. High potential for reporting bias. Investigators use different units of measurement between groups.

## References

1 Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. Oct. 2007;52(4):321-9. [pmid: 18232242].
2 Cohen CI, Hyland K, Devlin M. An evaluation of the use of the natural helping network model to enhance the well-being of nursing home residents. Gerontologist. Aug. 1999;39(4):426-33. [pmid: 10495580].
3 Cohen CI, Hyland K, Kimhy D. The utility of mandatory depression screening of dementia patients in nursing homes. Am J Psychiatry. Nov. 2003;160(11):2012-7. [pmid: 14594749].
4 Dowling GA, Hubbard EM, Mastick J, et al. Effect of morning bright light treatment for rest-activity disruption in institutionalized patients with severe Alzheimer's disease. Int Psychogeriatr. Jun. 2005;17(2):221-36. [pmid: 16050432].
5 Dowling GA, Graf CL, Hubbard EM, et al. Light treatment for neuropsychiatric behaviors in Alzheimer's disease. West J Nurs Res. Dec. 2007;29(8):961-75. [pmid: 17596638].
6 Fritsch T, Kwak J, Grant S, et al. Impact of TimeSlips, a creative expression intervention program, on nursing home residents with dementia and their caregivers. Gerontologist. Feb. 2009;49(1):117-27. [pmid: 19363009].
7 Hickman SE, Barrick AL, Williams CS, et al. The effect of ambient bright light therapy on depressive symptoms in persons with dementia. J Am Geriatr Soc. Nov. 2007;55(11):1817-24. [pmid: 17944896].
8 Holmes D, Teresi JA, Ramirez M, et al. An evaluation of a monitoring system intervention: falls, injuries, and affect in nursing homes. Clin Nurs Res. Nov. 2007;16(4):317-35. [pmid: 17991911].
9 Jablonski RA, Reed D, Maas ML. Care intervention for older adults with Alzheimer's disease and related dementias: effect of family involvement on cognitive and functional outcomes in nursing homes. J Gerontol Nurs. Jun. 2005;31(6):38-48. [pmid: 16138529].
10 Kovach CR, Logan BR, Noonan PE, et al. Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Jun-Jul. 2006;21(3):147-55. [pmid: 16869334].
11 Lawton MP, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. Int Psychogeriatr. Dec. 1998;10(4):379-95. [pmid: 9924833].
12 Maas ML, Reed D, Park M, et al. Outcomes of family involvement in care intervention for caregivers of individuals with dementia. Nurs Res. Mar-Apr. 2004;53(2):76-86. [pmid: 15084992].
13 McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
14 Moyer DM, Gilson A. Theoretical perspective concerning effects of environment on SDAT patients as a function of cognitive and behavioral functioning. AJA. 1996;11(5):32-8.
15 Reichenbach VR, Kirchman MM. Effects of a multi-strategy program upon elderly with organic brain syndrome. Phys Occup Ther Geriatr. 1991;9(3-4):131-51.
16 Remington R. Calming music and hand massage with agitated elderly. Nurs Res. Sep-Oct. 2002;51(5):317-23. [pmid: 12352780].
17 Robison J, Curry L, Gruman C, et al. Partners in caregiving in a special care environment: cooperative communication between staff and families on dementia units. Gerontologist. Aug. 2007;47(4):504-15. [pmid: 17766671].
18 Rosswurm MA. Attention-focusing program for persons with dementia. Clin Gerontol. 1990;10(2):3-16.
19 Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. [pmid: 7490386].
20 Sloane PD, Hoeffer B, Mitchell CM, et al. Effect of person-centered showering and the towel bath on bathing-associated aggression, agitation, and discomfort in nursing home residents with dementia: a randomized, controlled trial. J Am Geriatr Soc. Nov. 2004;52(11):1795-804. [pmid: 15507054].
21 Tappen RM. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. Jun. 1994;17(3):159-65. [pmid: 8184127].
22 Toseland RW, Diehl M, Freeman K, et al. The impact of validation group therapy on nursing home residents with dementia. J Appl Gerontol. 1997;16(1):31-50.
23 Whall AL, Black ME, Groh CJ, et al. Effect of natural environments upon agitation and aggression in late stage dementia patients. AJA. 1997;12(5):216-20.
24 Leon J, Ory MG. Effectiveness of Special Care Unit (SCU) placements in reducing physically aggressive behaviors in recently admitted dementia nursing home residents. American Journal of Alzheimer's Disease and Other Dementias. 1999;14(5):270-7.
25 Sloane PD, Mathew LJ, Scarborough M, et al. Physical and pharmacologic restraint of nursing home patients with dementia. Impact of specialized units. JAMA. Mar. 13. 1991;265(10):1278-82. [pmid: 1995975].
26 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Oct. Spec No 1. 2005;45(1):124-32. [pmid: 16230759].
27 Sloane PD, Zimmerman S, Williams CS, et al. Dying with dementia in long-term care. Gerontologist. Dec. 2008;48(6):741-51. [pmid: 19139248].
28 Volicer L, Collard A, Hurley A, et al. Impact of special care unit for patients with advanced Alzheimer's disease on patients' discomfort and costs. J Am Geriatr Soc. Jun. 1994;42(6):597-603. [pmid: 7515405].
29 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. Oct. Spec No 1. 2005;45(1):133-46. [pmid: 16230760].
30 Lord TR, Garner JE. Effects of music on Alzheimer patients. Percept Mot Skills. Apr. 1993;76(2):451-5. [pmid: 8483655].