# Evidence Tables

Evidence Table 1 Characteristics of included studies

Evidence Table 2 Characteristics of study populations

Evidence Table 3 Intervention/Exposure components

Evidence Table 4 Health outcomes for people with dementia: cognitive decline, functional decline, and pain

Evidence Table 5 Health outcomes for people with dementia: sleep quality and depressive symptoms

Evidence Table 6 Health outcomes for people with dementia: morbidity, mortality, hospitalizations, and falls

Evidence Table 7 Psychosocial outcomes for people with dementia: anxiety, affect, quality of life, use of psychoactive medications, use of restraints, and behavior

Evidence Table 8 Psychosocial outcomes for people with dementia: activity engagement, social engagement, agitation, satisfaction, wandering

Evidence Table 9 Psychosocial outcomes for people with dementia: autonomy, choice, control, pleasure, quality of dying, spiritual well-being

## References

1 Dowling GA, Hubbard EM, Mastick J, et al. Effect of morning bright light treatment for rest-activity disruption in institutionalized patients with severe Alzheimer's disease. Int Psychogeriatr. Jun. 2005;17(2):221-36. [pmid: 16050432].
2 Fritsch T, Kwak J, Grant S, et al. Impact of TimeSlips, a creative expression intervention program, on nursing home residents with dementia and their caregivers. Gerontologist. Feb. 2009;49(1):117-27. [pmid: 19363009].
3 Hickman SE, Barrick AL, Williams CS, et al. The effect of ambient bright light therapy on depressive symptoms in persons with dementia. J Am Geriatr Soc. Nov. 2007;55(11):1817-24. [pmid: 17944896].
4 Kovach CR, Logan BR, Noonan PE, et al. Effects of the Serial Trial Intervention on discomfort and behavior of nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Jun-Jul. 2006;21(3):147-55. [pmid: 16869334].
5 Leon J, Ory MG. Effectiveness of Special Care Unit (SCU) placements in reducing physically aggressive behaviors in recently admitted dementia nursing home residents. American Journal of Alzheimer's Disease and Other Dementias. 1999;14(5):270-7.
6 Remington R. Calming music and hand massage with agitated elderly. Nurs Res. Sep-Oct. 2002;51(5):317-23. [pmid: 12352780].
7 Rosswurm MA. Attention-focusing program for persons with dementia. Clin Gerontol. 1990;10(2):3-16.
8 Sloane PD, Hoeffer B, Mitchell CM, et al. Effect of person-centered showering and the towel bath on bathing-associated aggression, agitation, and discomfort in nursing home residents with dementia: a randomized, controlled trial. J Am Geriatr Soc. Nov. 2004;52(11):1795-804. [pmid: 15507054].
9 Sloane PD, Zimmerman S, Gruber-Baldini AL, et al. Health and functional outcomes and health care utilization of persons with dementia in residential care and assisted living facilities: comparison with nursing homes. Gerontologist. Oct. 2005;45 Spec No 1(1):124-32. [pmid: 16230759].
10 Sloane PD, Zimmerman S, Williams CS, et al. Dying with dementia in long-term care. Gerontologist. Dec. 2008;48(6):741-51. [pmid: 19139248].
11 Tappen RM. The effect of skill training on functional abilities of nursing home residents with dementia. Res Nurs Health. Jun. 1994;17(3):159-65. [pmid: 8184127].
12 Toseland RW, Diehl M, Freeman K, et al. The impact of validation group therapy on nursing home residents with dementia. J Appl Gerontol. 1997;16(1):31-50.
13 Whall AL, Black ME, Groh CJ, et al. Effect of natural environments upon agitation and aggression in late stage dementia patients. AJA. 1997;12(5):216-20.
14 Zimmerman S, Sloane PD, Williams CS, et al. Dementia care and quality of life in assisted living and nursing homes. Gerontologist. Oct. 2005;45 Spec No 1(1):133-46. [pmid: 16230760].