# Excluded Studies

## Excluded for Wrong PICOTS Element

Some demented patients are still able to execute advance directives. Geriatrics. Jul. 1996;51(7):23. [pmid: 11644794].
Abbey J, Piller N, De Bellis A, et al. The Abbey pain scale: a 1-minute numerical indicator for people with end-stage dementia. Int J Palliat Nurs. Jan. 2004;10(1):6-13. [pmid: 14966439].
Abraham IL, Neundorfer MM, Currie LJ. Effects of group interventions on cognition and depression in nursing home residents. Nurs Res. Jul-Aug. 1992;41(4):196-202. [pmid: 1383947].
Abrams RC, Teresi JA, Butin DN. Depression in nursing home residents. Clin Geriatr Med. May. 1992;8(2):309-22. [pmid: 1600481].
Akkerman RL, Ostwald SK. Reducing anxiety in Alzheimer's disease family caregivers: the effectiveness of a nine-week cognitive-behavioral intervention. Am J Alzheimers Dis Other Demen. Mar-Apr. 2004;19(2):117-23. [pmid: 15106393].
Albert SM, Del Castillo-Castaneda C, Sano M, et al. Quality of life in patients with Alzheimer's disease as reported by patient proxies. J Am Geriatr Soc. Nov. 1996;44(11):1342-7. [pmid: 8909350].
Albert SM, Jacobs DM, Sano M, et al. Longitudinal study of quality of life in people with advanced Alzheimer's disease. Am J Geriatr Psychiatry. Spring. 2001;9(2):160-8. [pmid: 11316620].
Alessi CA, Martin JL, Webber AP, et al. Randomized, controlled trial of a nonpharmacological intervention to improve abnormal sleep/wake patterns in nursing home residents. J Am Geriatr Soc. 2005:803-10. [pmid: 15877555].
Alessi CA, Schnelle JF, MacRae PG, et al. Does physical activity improve sleep in impaired nursing home residents?. J Am Geriatr Soc. Oct. 1995;43(10):1098-102. [pmid: 7560698].
Algase DL, Antonakos C, Beattie E, et al. Estimates of crowding in long-term care: comparing two approaches. HERD. Winter. 2011;4(2):61-74. [pmid: 21465435].
Algase DL, Beattie ER, Leitsch SA, et al. Biomechanical activity devices to index wandering behavior in dementia. Am J Alzheimers Dis Other Demen. Mar-Apr. 2003;18(2):85-92. [pmid: 12708223].
Allen RS, Burgio LD, Roth DL, et al. The Revised Memory and Behavior Problems Checklist--Nursing Home: instrument development and measurement of burden among certified nursing assistants. Psychol Aging. Dec. 2003;18(4):886-95. [pmid: 14692873].
Allen RS, DeLaine SR, Chaplin WF, et al. Advance care planning in nursing homes: correlates of capacity and possession of advance directives. Gerontologist. Jun. 2003;43(3):309-17. [pmid: 12810894].
Ancoli-Israel S, Gehrman P, Martin JL, et al. Increased light exposure consolidates sleep and strengthens circadian rhythms in severe Alzheimer's disease patients. Behav Sleep Med. 2003;1(1):22-36. [pmid: 15600135].
Ancoli-Israel S, Martin JL, Gehrman P, et al. Effect of light on agitation in institutionalized patients with severe Alzheimer disease. Am J Geriatr Psychiatry. Mar-Apr. 2003;11(2):194-203. [pmid: 12611749].
Ancoli-Israel S, Martin JL, Kripke DF, et al. Effect of light treatment on sleep and circadian rhythms in demented nursing home patients. J Am Geriatr Soc. Feb. 2002;50(2):282-9. [pmid: 12028210].
Anderson MA, Wendler MC, Congdon JC. Entering the world of dementia: CNA interventions for nursing home residents. J Gerontol Nurs. Nov. 1998;24(11):31-7. [pmid: 10392092].
Arling G, Kane RL, Cooke V, et al. Targeting residents for transitions from nursing home to community. Health Serv Res. Jun. 2010;45(3):691-711. [pmid: 20403058].
Arling G, Kane RL, Mueller C, et al. Nursing effort and quality of care for nursing home residents. Gerontologist. Oct. 2007;47(5):672-82. [pmid: 17989409].
Arling G, Williams AR. Cognitive impairment and resource use of nursing home residents: a structural equation model. Med Care. Jul. 2003;41(7):802-12. [pmid: 12835604].
Aronson MK, Cox D, Guastadisegni P, et al. Dementia and the nursing home: association with care needs. J Am Geriatr Soc. Jan. 1992;40(1):27-33. [pmid: 1727844].
Aronson MK, Post DC, Guastadisegni P. Dementia, agitation, and care in the nursing home. J Am Geriatr Soc. May. 1993;41(5):507-12. [pmid: 8486883].
Ashida S. The effect of reminiscence music therapy sessions on changes in depressive symptoms in elderly persons with dementia. J Music Ther. Fall. 2000;37(3):170-82. [pmid: 10990595].
Aud MA, Rantz MJ. Admissions to skilled nursing facilities from assisted living facilities. J Nurs Care Qual. Jan-Mar. 2005;20(1):16-25. [pmid: 15686073].
Ayalon L, Arean P, Bornfeld H, et al. Long term care staff beliefs about evidence based practices for the management of dementia and agitation. Int J Geriatr Psychiatry. Feb. 2009;24(2):118-24. [pmid: 18563863].
Barrick AL, Sloane PD, Williams CS, et al. Impact of ambient bright light on agitation in dementia. Int J Geriatr Psychiatry. Oct. 2010;25(10):1013-21. [pmid: 20104513].
Bartels SJ, Horn SD, Smout RJ, et al. Agitation and depression in frail nursing home elderly patients with dementia: treatment characteristics and service use. Am J Geriatr Psychiatry. Mar-Apr. 2003;11(2):231-8. [pmid: 12611753].
Barton C, Miller B, Yaffe K. Improved evaluation and management of cognitive impairment: results of a comprehensive intervention in long-term care. J Am Med Dir Assoc. Feb. 2006;7(2):84-9. [pmid: 16461249].
Bass BA, Greger LM. Stimulus complexity in reminiscence therapy and scores on the Beck Depression Inventory of a small group of nursing-home residents. Percept Mot Skills. Jun. 1996;82(3 Pt 1):973-4. [pmid: 8774040].
Bass DM, McClendon MJ, Brennan PF, et al. The buffering effect of a computer support network on caregiver strain. J Aging Health. Feb. 1998;10(1):20-43. [pmid: 10182416].
Bates-Jensen BM, Alessi CA, Al-Samarrai NR, et al. The effects of an exercise and incontinence intervention on skin health outcomes in nursing home residents. J Am Geriatr Soc. Mar. 2003;51(3):348-55. [pmid: 12588578].
Baumgarten M, Margolis D, van Doorn C, et al. Black/White differences in pressure ulcer incidence in nursing home residents. J Am Geriatr Soc. Aug. 2004;52(8):1293-8. [pmid: 15271116].
Beauchamp N, Irvine AB, Seeley J, et al. Worksite-based internet multimedia program for family caregivers of persons with dementia. Gerontologist. Dec. 2005;45(6):793-801. [pmid: 16326661].
Beaupre LA, Cinats JG, Jones CA, et al. Does functional recovery in elderly hip fracture patients differ between patients admitted from long-term care and the community?. J Gerontol A Biol Sci Med Sci. Oct. 2007;62(10):1127-33. [pmid: 17921426].
Beck C, Frank L, Chumbler NR, et al. Correlates of disruptive behavior in severely cognitively impaired nursing home residents. Gerontologist. Apr. 1998;38(2):189-98. [pmid: 9573663].
Beck CK, Vogelpohl TS, Rasin JH, et al. Effects of behavioral interventions on disruptive behavior and affect in demented nursing home residents. Nurs Res. Jul-Aug. 2002;51(4):219-28. [pmid: 12131234].
Becker M, Andel R, Boaz T, et al. The association of individual and facility characteristics with psychiatric hospitalization among nursing home residents. Int J Geriatr Psychiatry. Mar. 2009;24(3):261-8. [pmid: 18727143].
Becker MA, Boaz TL, Andel R, et al. Predictors of preventable nursing home hospitalizations: the role of mental disorders and dementia. Am J Geriatr Psychiatry. Jun. 2010;18(6):475-82. [pmid: 21217558].
Bellantonio S, Kenny AM, Fortinsky RH, et al. Efficacy of a geriatrics team intervention for residents in dementia-specific assisted living facilities: effect on unanticipated transitions. J Am Geriatr Soc. Mar. 2008;56(3):523-8. [pmid: 18179497].
Bellaver C, Daly JM, Buckwalter KC. Information resources and knowledge needs of rural nurses regarding Alzheimer's disease. J Contin Educ Nurs. May-Jun. 1999;30(3):114-9. [pmid: 10640069].
Bergman-Evans B. A health profile of spousal Alzheimer's caregivers. Depression and physical health characteristics. J Psychosoc Nurs Ment Health Serv. Sep. 1994;32(9):25-30. [pmid: 7799262].
Bernstein MA, Tucker KL, Ryan ND, et al. Higher dietary variety is associated with better nutritional status in frail elderly people. J Am Diet Assoc. Aug. 2002;102(8):1096-104. [pmid: 12171454].
Bewernitz MW, Mann WC, Dasler P, et al. Feasibility of machine-based prompting to assist persons with dementia. Assist Technol. Winter. 2009;21(4):196-207. [pmid: 20066886].
Bharani N, Snowden M. Evidence-based interventions for nursing home residents with dementia-related behavioral symptoms. Psychiatr Clin North Am. Dec. 2005;28(4):985-1005. x. [pmid: 16325737].
Biola H, Sloane PD, Williams CS, et al. Physician communication with family caregivers of long-term care residents at the end of life. J Am Geriatr Soc. Jun. 2007;55(6):846-56. [pmid: 17537084].
Bishop CE, Weinberg DB, Leutz W, et al. Nursing assistants' job commitment: effect of nursing home organizational factors and impact on resident well-being. Gerontologist. Jul. Spec No 1. 2008;48:36-45. [pmid: 18694985].
Blasi ZV, Hurley AC, Volicer L. End-of-life care in dementia: a review of problems, prospects, and solutions in practice. Journal of the American Medical Directors Association. 2002;3(2):57-65. [pmid: 12807540].
Blass DM, Black BS, Phillips H, et al. Medication use in nursing home residents with advanced dementia. Int J Geriatr Psychiatry. May. 2008;23(5):490-6. [pmid: 17944007].
Bonder BR, Miller B, Linsk N. Who should do what?: Staff and family responsibilities for persons with Alzheimer's disease in nursing homes. Clin Gerontol. 1991;10(4):80-4.
Bostick JE. Relationship of nursing personnel and nursing home care quality. J Nurs Care Qual. 2004;19(2).
Bostick JE, Rantz MJ, Flesner MK, et al. Systematic review of studies of staffing and quality in nursing homes. J Am Med Dir Assoc. Jul. 2006;7(6):366-76. [pmid: 16843237].
Bourgeois M, Schulz R, Burgio L, et al. Skills Training for Spouses of Patients with Alzheimer's Disease: Outcomes of an Intervention Study. Journal of Clinical Geropsychology. 2002;8(1):53-73.
Bouwen A, De Lepeleire J, Buntinx F. Rate of accidental falls in institutionalised older people with and without cognitive impairment halved as a result of a staff-oriented intervention. Age Ageing. 2008:306-10. [pmid: 18385186].
Brandeis GH, Baumann MM, Hossain M, et al. The prevalence of potentially remediable urinary incontinence in frail older people: a study using the Minimum Data Set. J Am Geriatr Soc. Feb. 1997;45(2):179-84. [pmid: 9033516].
Braun KL, Rose CL, Finch MD. Patient characteristics and outcomes in institutional and community long-term care. Gerontologist. 1991;31(5):648-56. [pmid: 1778491].
Brazzelli M, Saunders David H, Greig Carolyn A, et al. Physical fitness training for stroke patients, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Brodaty H, Green A, Koschera A. Meta-analysis of psychosocial interventions for caregivers of people with dementia (Structured abstract). J Am Geriatr Soc. 2003:657-64. [pmid: 12752841].
Brown JW, Chobor A, Zinn F. Dementia testing in the elderly. J Nerv Ment Dis. Nov. 1993;181(11):695-8. [pmid: 7901320].
Brown T, Kleist DM. Alzheimer's disease and the family: current research. Family Journal: Counseling and Therapy for Couples and Families. 1999;7(1):54-7.
Buettner LL, Fitzsimmons S. AD-venture program: therapeutic biking for the treatment of depression in long-term care residents with dementia. Am J Alzheimers Dis Other Demen. Mar-Apr. 2002;17(2):121-7. [pmid: 11954670].
Buettner LL, Fitzsimmons S. Activity calendars for older adults with dementia: what you see is not what you get. Am J Alzheimers Dis Other Demen. Jul-Aug. 2003;18(4):215-26. [pmid: 12955786].
Buettner LL, Fitzsimmons S, Dudley WN. Impact of underlying depression on treatment of neuropsychiatric symptoms in older adults with dementia. Res Gerontol Nurs. Jul. 2010;3(3):221-32. [pmid: 20635806].
Buettner LL, Lundegren H, Lago D, et al. Therapeutic recreation as an intervention for persons with dementia and agitation: an efficacy study. AJA. 1996;11(5):4.
Burgener SC, Jirovec M, Murrell L, et al. Caregiver and environmental variables related to difficult behaviors in institutionalized, demented elderly persons. J Gerontol. Jul. 1992;47(4):P242-9. [pmid: 1624701].
Burgener SC, Shimer R. Variables related to caregiver behaviors with cognitively impaired elders in institutional settings. Res Nurs Health. Jun. 1993;16(3):193-202. [pmid: 8497671].
Burgener SC, Yang Y, Gilbert R, et al. The effects of a multimodal intervention on outcomes of persons with early-stage dementia. Am J Alzheimers Dis Other Demen. Aug-Sep. 2008;23(4):382-94. [pmid: 18453642].
Burgio L, Scilley K, Hardin JM, et al. Environmental “white noise”: an intervention for verbally agitated nursing home residents. J Gerontol B Psychol Sci Soc Sci. Nov. 1996;51(6):P364-73. [pmid: 8931624].
Burgio LD, Allen-Burge R, Roth DL, et al. Come talk with me: improving communication between nursing assistants and nursing home residents during care routines. Gerontologist. Aug. 2001;41(4):449-60. [pmid: 11490043].
Burgio LD, Fisher SE, Fairchild JK, et al. Quality of care in the nursing home: effects of staff assignment and work shift. Gerontologist. 2004;44(3):368-77. [pmid: 15197291].
Burgio LD, McCormick KA, Scheve AS, et al. The effects of changing prompted voiding schedules in the treatment of incontinence in nursing home residents. J Am Geriatr Soc. Mar. 1994;42(3):315-20. [pmid: 8120318].
Burns BJ, Wagner HR, Taube JE, et al. Mental health service use by the elderly in nursing homes. Am J Public Health. Mar. 1993;83(3):331-7. [pmid: 8438968].
Burton LC, German PS, Gruber-Baldini AL, et al. Medical care for nursing home residents: differences by dementia status. Epidemiology of Dementia in Nursing Homes Research Group. J Am Geriatr Soc. Feb. 2001;49(2):142-7. [pmid: 11207867].
Burton LC, German PS, Rovner BW, et al. Physical restraint use and cognitive decline among nursing home residents. J Am Geriatr Soc. Aug. 1992;40(8):811-6. [pmid: 1353084].
Cahn-Weiner DA, Malloy PF, Rebok GW, et al. Results of a randomized placebo-controlled study of memory training for mildly impaired Alzheimer's disease patients. Appl Neuropsychol. 2003;10(4):215-23. [pmid: 14690802].
Cameron Ian D, Murray Geoff R, Gillespie Lesley D, et al. Interventions for preventing falls in older people in nursing care facilities and hospitals, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
Campbell SS, Dawson D, Anderson MW. Alleviation of sleep maintenance insomnia with timed exposure to bright light. J Am Geriatr Soc. Aug. 1993;41(8):829-36. [pmid: 8340561].
Canavan PK, Cahalin LP, Lowe S, et al. Managing gait disorders in older persons residing in nursing homes: a review of literature. J Am Med Dir Assoc. May. 2009;10(4):230-7. [pmid: 19426938].
Candy B, Jones L, Drake R, et al. Interventions for supporting informal caregivers of patients in the terminal phase of a disease, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Casarett D, Karlawish J, Morales K, et al. Improving the use of hospice services in nursing homes: a randomized controlled trial. JAMA. Jul. 13. 2005;294(2):211-7. [pmid: 16014595].
Cassie KM, Sanders S. Familial caregivers of older adults. Journal of Gerontological Social Work. 2008;50(Suppl. 1):293-320. [pmid: 18924398].
Castle NG. Differences in nursing homes with increasing and decreasing use of physical restraints. Med Care. 2000;38(12):1154-63. [pmid: 11186294].
Castle NG, Fogel B. Organizational structure and outcomes for nursing home residents with mental disorders. Journal of Mental Health and Aging. 1998;4(1):105-24.
Cervo FA, Raggi RP, Bright-Long LE, et al. Use of the certified nursing assistant pain assessment tool (CPAT) in nursing home residents with dementia. Am J Alzheimers Dis Other Demen. Apr-May. 2007;22(2):112-9. [pmid: 17545138].
Cevasco AM. Effects of the therapist's nonverbal behavior on participation and affect of individuals with Alzheimer's disease during group music therapy sessions. J Music Ther. Fall. 2010;47(3):282-99. [pmid: 21275336].
Cevasco AM, Grant RE. Comparison of different methods for eliciting exercise-to-music for clients with Alzheimer's disease. J Music Ther. Spring. 2003;40(1):41-56. [pmid: 17590967].
Chalmers JM, Pearson A. A systematic review of oral health assessment by nurses and carers for residents with dementia in residential care facilities. Spec Care Dentist. Sep-Oct. 2005;25(5):227-33. [pmid: 16454098].
Chan R, Webster J. End-of-life care pathways for improving outcomes in caring for the dying, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
Chen Y, Briesacher BA, Field TS, et al. Unexplained variation across US nursing homes in antipsychotic prescribing rates. Arch Intern Med. Jan. 11. 2010;170(1):89-95. [pmid: 20065204].
Chou SC, Boldy DP, Lee AH. Factors influencing residents' satisfaction in residential aged care. Gerontologist. Aug. 2003;43(4):459-72. [pmid: 12937325].
Christenson AM, Buchanan JA, Houlihan D, et al. Command use and compliance in staff communication with elderly residents of long-term care facilities. Behav Ther. Mar. 2011;42(1):47-58. [pmid: 21292051].
Christenson D, Moore I. Intensive case management in Alzheimer's disease home care: an interim report on the Cincinnati (Ohio) Medicare Alzheimer's Project. J Long Term Home Health Care. Fall. 1994;13(4):43-52. [pmid: 10172192].
Chung Jenny CC, Lai Claudia KY. Snoezelen for dementia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2002.
Clair AA, O'Konski M. The effect of rhythmic auditory stimulation (RAS) on gait characteristics of cadence, velocity, and stride length in persons with late stage dementia. J_Music Ther. 2006:154-63. [pmid: 16897907].
Clark PA, Bass DM, Looman WJ, et al. Outcomes for patients with dementia from the Cleveland Alzheimer's Managed Care Demonstration. Aging Ment Health. Jan. 2004;8(1):40-51. [pmid: 14690867].
Cogen R, Patterson B, Chavin S, et al. Surrogate decision-maker preferences for medical care of severely demented nursing home patients. Arch Intern Med. Sep. 1992;152(9):1885-8. [pmid: 1520056].
Cohen CI, Hyland K, Magai C. Interracial and intraracial differences in neuropsychiatric symptoms, sociodemography, and treatment among nursing home patients with dementia. Gerontologist. Jun. 1998;38(3):353-61. [pmid: 9640855].
Cohen-Mansfield J. Outdoor wandering parks for persons with dementia. Journal of Housing for the Elderly. 2007;21(1-2):35-53.
Cohen-Mansfield J, Dakheel-Ali M, Thein K, et al. The impact of stimulus attributes on engagement of nursing home residents with dementia. Arch Gerontol Geriatr. Jul-Aug. 2009;49(1):1-6. [pmid: 18602707].
Cohen-Mansfield J, Jensen B. Do interventions bringing current self-care practices into greater correspondence with those performed premorbidly benefit the person with dementia? A pilot study. Am J Alzheimers Dis Other Demen. Oct-Nov. 2006;21(5):312-7. [pmid: 17062549].
Cohen-Mansfield J, Libin A, Marx MS. Nonpharmacological treatment of agitation: a controlled trial of systematic individualized intervention. J Gerontol A Biol Sci Med Sci. Aug. 2007;62(8):908-16. [pmid: 17702884].
Cohen-Mansfield J, Marx MS, Dakheel-Ali M, et al. Can persons with dementia be engaged with stimuli?. Am J Geriatr Psychiatry. Apr. 2010;18(4):351-62. [pmid: 20306565].
Cohen-Mansfield J, Marx MS, Freedman LS, et al. The comprehensive process model of engagement. Am J Geriatr Psychiatry. Oct. 2011;19(10):859-70. [pmid: 21946802].
Cohen-Mansfield J, Marx MS, Thein K, et al. The impact of stimuli on affect in persons with dementia. J Clin Psychiatry. Apr. 2011;72(4):480-6. [pmid: 21527124].
Cohen-Mansfield J, Thein K, Dakheel-Ali M, et al. The value of social attributes of stimuli for promoting engagement in persons with dementia. J Nerv Ment Dis. Aug. 2010;198(8):586-92. [pmid: 20699725].
Coleman MT, Looney S, O'Brien J, et al. The Eden Alternative: findings after 1 year of implementation. J Gerontol A Biol Sci Med Sci. Jul. 2002;57(7):M422-7. [pmid: 12084803].
Colling KB, Buettner LL. Simple pleasures: interventions for the need-driven dementia-compromised behavior model. J Gerontol Nurs. 2002;28(10):16-20. [pmid: 12382455].
Cooke DD, McNally L, Mulligan KT, et al. Psychosocial interventions for caregivers of people with dementia: a systematic review (Structured abstract). Aging and Mental Health. 2001:120-35. [pmid: 11511059].
Cotter JJ, Leon J, Akers AJ, et al. Special care for persons with Alzheimer's disease and related dementias in Virginia adult care residences. American journal of Alzheimer's disease and other dementias. 2003;18(2):105-13.
Cox CL, Kaeser L, Montgomery AC, et al. Quality of life nursing care. An experimental trial in long-term care. J Gerontol Nurs. Apr. 1991;17(4):6-11. [pmid: 1901328].
Cummings SM, Chapin R, Dobbs D, et al. Assisted living facilities' response to residents' mental health needs: a study in two states. Journal of Mental Health and Aging. 2004;10(3):151-62.
Dahl LJ, Wright R, Xiao A, et al. Quality improvement in long term care: the psychotropic assessment tool (PAT). J Am Med Dir Assoc. Nov. 2008;9(9):676-83. [pmid: 18992701].
Davis RN, Massman PJ, Doody RS. Cognitive intervention in Alzheimer disease: a randomized placebo-controlled study. Alzheimer Dis Assoc Disord. Jan-Mar. 2001;15(1):1-9. [pmid: 11236819].
Decker FH. Nursing staff and the outcomes of nursing home stays. Med Care. Sep. 2006;44(9):812-21. [pmid: 16932132].
Dellefield ME. Prevalence rate of pressure ulcers in California nursing homes. J Gerontol Nurs. 2004;30(11):13-21. [pmid: 15575187].
Diwan S, Phillips VL. Agitation and dementia-related problem behaviors and case management in long-term care. Int Psychogeriatr. Mar. 2001;13(1):5-21. [pmid: 11352334].
Done DJ, Thomas JA. Training in communication skills for informal carers of people suffering from dementia: a cluster randomized clinical trial comparing a therapist led workshop and a booklet. Int J Geriatr Psychiatry. 2001:816-21. [pmid: 11536349].
Dowling GA, Mastick J, Hubbard EM, et al. Effect of timed bright light treatment for rest-activity disruption in institutionalized patients with Alzheimer's disease. Int J Geriatr Psychiatry. 2005;20(8):738-43. [pmid: 16035127].
Drentea P, Clay OJ, Roth DL, et al. Predictors of improvement in social support: Five-year effects of a structured intervention for caregivers of spouses with Alzheimer's disease. Social science & medicine. (1982). 2006:957-67. [pmid: 16616406].
Drinka PJ, Krause PF, Nest LJ, et al. Risk of acquiring influenza B in a nursing home from a culture-positive roommate. J Am Geriatr Soc. Aug. 2005;53(8):1437. [pmid: 16078980].
Duru OK, Ettner SL, Vassar SD, et al. Cost evaluation of a coordinated care management intervention for dementia. Am J Manag Care. Aug. 2009;15(8):521-8. [pmid: 19670955].
Dychtwald K. Riding the age wave: how America can stay afloat and enjoy the ride. Caring. Oct. 2011;30(10):26-30. 2. 4. 42. passim. [pmid: 22069902].
Eisdorfer C, Czaja SJ, Loewenstein DA, et al. The effect of a family therapy and technology-based intervention on caregiver depression. The Gerontologist. 2003:521-31. [pmid: 12937331].
Engel BT, Burgio LD, McCormick KA, et al. Behavioral treatment of incontinence in the long-term care setting. J Am Geriatr Soc. Mar. 1990;38(3):361-3. [pmid: 2107245].
Enmarker I, Olsen R, Hellzen O. Management of person with dementia with aggressive and violent behaviour: a systematic literature review. Int J Older People Nurs. Jun. 2011;6(2):153-62. [pmid: 21539720].
Evans LK, Strumpf NE, Allen-Taylor SL, et al. Clinical trial to reduce restraints in nursing homes. J Am Geriatr Soc. 1997;45(6):675-81. [pmid: 9180659].
Feng Z, Hirdes JP, Smith TF, et al. Use of physical restraints and antipsychotic medications in nursing homes: a cross-national study. Int J Geriatr Psychiatry. Oct. 2009;24(10):1110-8. [pmid: 19280680].
Ferris SH, Mittelman MS. Behavioral treatment of Alzheimer's disease. Int Psychogeriatr. Suppl 1. 1996;8:87-90. [pmid: 8934272].
French DD, Werner DC, Campbell RR, et al. A multivariate fall risk assessment model for VHA nursing homes using the minimum data set. J Am Med Dir Assoc. Feb. 2007;8(2):115-22. [pmid: 17289542].
Friedman R, Tappen RM. The effect of planned walking on communication in Alzheimer's disease. J Am Geriatr Soc. Jul. 1991;39(7):650-4. [pmid: 2061529].
Frytak JR, Kane RA, Finch MD, et al. Outcome trajectories for assisted living and nursing facility residents in Oregon. Health Serv Res. Apr. 2001;36(1 Pt 1):91-111. [pmid: 11324746].
Gallagher-Thompson D, Wang PC, Liu W, et al. Effectiveness of a psychoeducational skill training DVD program to reduce stress in Chinese American dementia caregivers: results of a preliminary study. Aging & mental health. 2010:263-73. [pmid: 20425645].
Gaugler JE, Mittelman MS, Hepburn K, et al. Predictors of change in caregiver burden and depressive symptoms following nursing home admission. Psychol Aging. Jun. 2009;24(2):385-96. [pmid: 19485656].
Gaugler JE, Pot AM, Zarit SH. Long-term adaptation to institutionalization in dementia caregivers. Gerontologist. Dec. 2007;47(6):730-40. [pmid: 18192627].
Gaugler JE, Zarit SH, Pearlin LI. Family involvement following institutionalization: modeling nursing home visits over time. Int J Aging Hum Dev. 2003;57(2):91-117. [pmid: 15151186].
Gessert CE, Mosier MC, Brown EF, et al. Tube feeding in nursing home residents with severe and irreversible cognitive impairment. J Am Geriatr Soc. Dec. 2000;48(12):1593-600. [pmid: 11129748].
Gilley DW, McCann JJ, Bienias JL, et al. Caregiver psychological adjustment and institutionalization of persons with Alzheimer's disease. J Aging Health. Apr. 2005;17(2):172-89. [pmid: 15750050].
Gitlin LN, Hodgson N, Jutkowitz E, et al. The cost-effectiveness of a nonpharmacologic intervention for individuals with dementia and family caregivers: the tailored activity program. The American journal of geriatric psychiatry : official journal of the American Association for Geriatric Psychiatry. 2010:510-9. [pmid: 20847903].
Good P, Cavenagh J, Mather M, et al. Medically assisted nutrition for palliative care in adult patients, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2008.
Goodman C. Evaluation of a model self-help telephone program: impact on natural networks. Soc Work. 1990:556-62. [pmid: 2284602].
Greene JA, Stone M, Johnson W. Evaluation of a multidisciplinary treatment approach in an inpatient geropsychiatric unit. J Tenn Med Assoc. Oct. 1994;87(10):421-4. [pmid: 7990451].
Greubel DL, Stokesberry C, Jelley MJ. Preventing costly falls in long-term care. Nurse Pract. Mar. 2002;27(3):83-5. [pmid: 11942438].
Gruber-Baldini AL, Boustani M, Sloane PD, et al. Behavioral symptoms in residential care/assisted living facilities: prevalence, risk factors, and medication management. J Am Geriatr Soc. Oct. 2004;52(10):1610-7. [pmid: 15450035].
Gruneir A, Lapane KL, Miller SC, et al. Does the presence of a dementia special care unit improve nursing home quality?. J Aging Health. 2008;20(7):837-54. [pmid: 18815412].
Haesler E, Bauer M, Nay R. Recent evidence on the development and maintenance of constructive staff-family relationships in the care of older people: a report on a systematic review update (Structured abstract). International Journal of Evidence-Based Healthcare. 2010:45-74. [pmid: 20923509].
Hall S, Kolliakou A, Petkova H, et al. Interventions for improving palliative care for older people living in nursing care homes. Cochrane Database Syst Rev. 2011;(3):CD007132. [pmid: 21412898].
Hall S, Kolliakou A, Petkova H, et al. Interventions for improving palliative care for older people living in nursing care homes, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Handoll Helen HG, Queally Joseph M, Parker Martyn J. Pre-operative traction for hip fractures in adults, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Hanson LC, Carey TS, Caprio AJ, et al. Improving decision-making for feeding options in advanced dementia: a randomized, controlled trial. J Am Geriatr Soc. 2011:2009-16. [pmid: 22091750].
Harrington C, Zimmerman D, Karon SL, et al. Nursing home staffing and its relationship to deficiencies. Journals of Gerontology: Series B: Psychological Sciences and Social Sciences. 2000;55B(5):S278-S87.
Hawley KS, Cherry KE. Memory interventions and quality of life for older adults with dementia. Activities, Adaptation and Aging. 2008;32(2):89-102.
Healey F, Oliver D, Milne A, et al. The effect of bedrails on falls and injury: a systematic review of clinical studies (Structured abstract). Age Ageing. 2008:368-78. [pmid: 18495686].
Hepburn K, Lewis M, Tornatore J, et al. The Savvy Caregiver program: the demonstrated effectiveness of a transportable dementia caregiver psychoeducation program. J Gerontol Nurs. 2007:30-6. [pmid: 17378189].
Hines S, McCrow J, Abbey J, et al. Thickened fluids for people with dementia in residential aged care facilities. Dysphagia. 2011;26(3):328.
Hinman MR, Heyl DM. Influence of the Eden Alternative on the Functional Status of Nursing Home Residents. Physical & Occupational Therapy in Geriatrics. 2001;20(2):1-20.
Holmes D, Teresi J, Monaco C. Special care units in nursing homes: Prevalence in five states. Gerontologist. 1992;32(2):191-6. [pmid: 1577314].
Horn SD, Buerhaus P, Bergstrom N, et al. RN staffing time and outcomes of long-stay nursing home residents: pressure ulcers and other adverse outcomes are less likely as RNs spend more time on direct patient care. Am J Nurs. Nov. 2005;105(11):58-70. quiz 1. [pmid: 16264305].
Horwitz GJ, Tariot PN, Mead K, et al. Discontinuation of antipsychotics in nursing home patients with dementia. Am J Geriatr Psychiatry. 1995;3(4):290-9.
Howe Tracey E, Rochester L, Neil F, et al. Exercise for improving balance in older people, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Huskamp HA, Stevenson DG, Grabowski DC, et al. Long and short hospice stays among nursing home residents at the end of life. J Palliat Med. Aug. 2010;13(8):957-64. [pmid: 20666661].
Intrator O, Castle NG, Mor V. Facility characteristics associated with hospitalization of nursing home residents: results of a national study. Med Care. Mar. 1999;37(3):228-37. [pmid: 10098567].
Intrator O, Zinn J, Mor V. Nursing home characteristics and potentially preventable hospitalizations of long-stay residents. J Am Geriatr Soc. Oct. 2004;52(10):1730-6. [pmid: 15450053].
Jerant AF, Azari RS, Nesbitt TS, et al. The Palliative Care in Assisted Living (PCAL) pilot study: successes, shortfalls, and methodological implications. Soc Sci Med. Jan. 2006;62(1):199-207. [pmid: 15987662].
Jogerst GJ, Daly JM, Dawson JD, et al. Iowa nursing home characteristics associated with reported abuse. J Am Med Dir Assoc. May. 2006;7(4):203-7. [pmid: 16698504].
Jogerst GJ, Daly JM, Hartz AJ. State policies and nursing home characteristics associated with rates of resident mistreatment. J Am Med Dir Assoc. Nov. 2008;9(9):648-56. [pmid: 18992697].
Kamble P, Sherer J, Chen H, et al. Off-label use of second-generation antipsychotic agents among elderly nursing home residents. Psychiatr Serv. Feb. 2010;61(2):130-6. [pmid: 20123817].
Kane RA, Lum TY, Cutler LJ, et al. Resident outcomes in small-house nursing homes: a longitudinal evaluation of the initial green house program. J Am Geriatr Soc. Jun. 2007;55(6):832-9. [pmid: 17537082].
Kane RL, Flood S, Keckhafer G, et al. Nursing home residents covered by Medicare risk contracts: early findings from the EverCare evaluation project. J Am Geriatr Soc. Apr. 2002;50(4):719-27. [pmid: 11982674].
Kane RL, Keckhafer G, Flood S, et al. The effect of Evercare on hospital use. J Am Geriatr Soc. Oct. 2003;51(10):1427-34. [pmid: 14511163].
Klugman A, Sauer J, Tabet N, et al. Alpha lipoic acid for dementia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
Knapp M, Thorgrimsen L, Patel A, et al. Cognitive stimulation therapy for people with dementia: cost-effectiveness analysis. The British journal of psychiatry : the journal of mental science. 2006:574-80. [pmid: 16738349].
Kochan NA, Breakspear M, Valenzuela M, et al. Cortical responses to a graded working memory challenge predict functional decline in mild cognitive impairment. Biol Psychiatry. Jul. 15. 2011;70(2):123-30. [pmid: 21546002].
Kolanowski A, Litaker M, Buettner L, et al. A randomized clinical trial of theory-based activities for the behavioral symptoms of dementia in nursing home residents. J Am Geriatr Soc. Jun. 2011;59(6):1032-41. [pmid: 21649633].
Kolanowski AM, Fick DM, Litaker MS, et al. Study protocol for the recreational stimulation for elders as a vehicle to resolve delirium superimposed on dementia (Reserve For DSD) trial. Trials. 2011;12:119. [pmid: 21569370].
Kolt GS, Schofield GM, Kerse N, et al. The healthy steps study: a randomized controlled trial of a pedometer-based green prescription for older adults. Trial protocol. BMC public health. 2009:404. [pmid: 19878605].
Konetzka RT, Spector W, Limcangco MR. Reducing hospitalizations from long-term care settings. Med Care Res Rev. Feb. 2008;65(1):40-66. [pmid: 17895516].
Konetzka RT, Spector W, Shaffer T. Effects of nursing home ownership type and resident payer source on hospitalization for suspected pneumonia. Med Care. Oct. 2004;42(10):1001-8. [pmid: 15377933].
Kong EH, Evans LK, Guevara JP. Nonpharmacological intervention for agitation in dementia: a systematic review and meta-analysis (Structured abstract). Aging and Mental Health. 2009:512-20. [pmid: 19629775].
Kovach CR, Taneli Y, Dohearty P, et al. Effect of the BACE intervention on agitation of people with dementia. Gerontologist. Dec. 2004;44(6):797-806. [pmid: 15611216].
Kovach CR, Wilson SA, Noonan PE. Effects of hospice interventions on behaviors, discomfort, and physical complications of end stage dementia nursing home residents. AJA. 1996;11(4):7.
Lapane KL, Hughes CM. Which organizational characteristics are associated with increased management of depression using antidepressants in US nursing homes?. Med Care. Oct. 2004;42(10):992-1000. [pmid: 15377932].
Leon J. Characteristics of dementia admissions to standard nursing homes and to special care units. AJA. 1998;13(1):15-28.
Leone E, Deudon A, Maubourguet N, et al. Methodological issues in the non pharmacological treatment of BPSD in nursing home--the TNM study. The journal of nutrition, health & aging. 2009:260-3.
Levy C, Morris M, Kramer A. Improving end-of-life outcomes in nursing homes by targeting residents at high-risk of mortality for palliative care: program description and evaluation. J Palliat Med. Mar. 2008;11(2):217-25. [pmid: 18333736].
Levy-Storms L, Miller-Martinez D. Family caregiver involvement and satisfaction with institutional care during the 1st year after admission. J Appl Gerontol. 2005;24(2):160-74.
Li Y, Cai X, Mukamel DB, et al. The volume-outcome relationship in nursing home care: an examination of functional decline among long-term care residents. Med Care. Jan. 2010;48(1):52-7. [pmid: 19890222].
Livingston G, Johnston K, Katona C, et al. Systematic review of psychological approaches to the management of neuropsychiatric symptoms of dementia. Am J Psychiatry. Nov. 2005;162(11):1996-2021. [pmid: 16263837].
Lloyd-Williams M, Payne S. Can multidisciplinary guidelines improve the palliation of symptoms in the terminal phase of dementia?. Int J Palliat Nurs. Aug. 2002;8(8):370-5. [pmid: 12271257].
Lou MF. The use of music to decrease agitated behaviour of the demented elderly: the state of the science (Structured abstract). Scand J Caring Sci. 2001:165-73. [pmid: 12078630].
Lum TY, Kane RA, Cutler LJ, et al. Effects of Green House nursing homes on residents' families. Health Care Financ Rev. Winter. 2008;30(2):35-51. [pmid: 19361115].
Lund DA, Hill RD, Caserta MS, et al. Video Respite: an innovative resource for family, professional caregivers, and persons with dementia. Gerontologist. Oct. 1995;35(5):683-7. [pmid: 8543227].
Majerovitz SD, Mollott RJ, Rudder C. We're on the same side: improving communication between nursing home and family. Health Commun. Jan. 2009;24(1):12-20. [pmid: 19204854].
Marks L, Flannery RB Jr., Spillane M. Placement challenges: implications for long-term care of dementia sufferers. Am J Alzheimers Dis Other Demen. Sep-Oct. 2001;16(5):285-8. [pmid: 11603164].
Martin JL, Marler MR, Harker JO, et al. Multicomponent nonpharmacological intervention improves activity rhythms among nursing home residents with disrupted sleep/wake patterns. Journals of Gerontology: Series A: Biological Sciences and Medical Sciences. 2007;62A(1):67-72.
Martin JL, Webber AP, Alam T, et al. Daytime sleeping, sleep disturbance, and circadian rhythms in the nursing home. Am J Geriatr Psychiatry. Feb. 2006;14(2):121-9. [pmid: 16473976].
Matteson MA, Linton AD, Cleary BL, et al. Management of problematic behavioral symptoms associated with dementia: a cognitive developmental approach. Aging (Milano). Oct. 1997;9(5):342-55. [pmid: 9458995].
McMurdo ME, Millar AM, Daly F. A randomized controlled trial of fall prevention strategies in old peoples' homes. Gerontology. 2000:83-7. [pmid: 10671804].
Mehr DR, Fries BE. Resource use on Alzheimer's special care units. Gerontologist. 1995;35(2):179-84. [pmid: 7750774].
Miller SC, Lima JC, Looze J, et al. Dying in U.S. nursing homes with advanced dementia: How does health care use differ for residents with, versus without, end-of-life medicare skilled nursing facility care?. Journal of Palliative Medicine. 2012;15(1):43-50. [pmid: 22175816].
Mitchell LA, Maercklein G. Effect of individualized special instruction on the behaviors of nursing home residents diagnosed with dementia. AJA. 1996;11(1):23-31.
Mitchell SL, Kiely DK, Gillick MR. Nursing home characteristics associated with tube feeding in advanced cognitive impairment. J Am Geriatr Soc. Jan. 2003;51(1):75-9. [pmid: 12534849].
Mitchell SL, Kiely DK, Lipsitz LA. The risk factors and impact on survival of feeding tube placement in nursing home residents with severe cognitive impairment. Arch Intern Med. Feb. 10. 1997;157(3):327-32. [pmid: 9040301].
Mitchell SL, Teno JM, Roy J, et al. Clinical and organizational factors associated with feeding tube use among nursing home residents with advanced cognitive impairment. JAMA. Jul. 2. 2003;290(1):73-80. [pmid: 12837714].
Möhler R, Richter T, Köpke S, et al. Interventions for preventing and reducing the use of physical restraints in long-term geriatric care, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
Moniz Cook Esme D, Swift K, James I, et al. Functional analysis-based interventions for challenging behaviour in dementia, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
Munroe DJ. The influence of registered nurse staffing on the quality of nursing home care. Res Nurs Health. Aug. 1990;13(4):263-70. [pmid: 2374834].
Musson ND, Kincaid J, Ryan P, et al. Nature, nurture, nutrition: interdisciplinary programs to address the prevention of malnutrition and dehydration. Dysphagia. 1990;5(2):96-101. [pmid: 2209103].
Neal M, Barton Wright P. Validation therapy for dementia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2003.
Negley EN. Environmental interventions in assaultive behavior. J Gerontol Nurs. 1990;16(3):29-33. [pmid: 2313060].
Nowalk MP, Prendergast JM, Bayles CM, et al. A randomized trial of exercise programs among older individuals living in two long-term care facilities: the FallsFREE program. J Am Geriatr Soc. 2001:859-65. [pmid: 11527475].
O'Brien JA, Shomphe LA, Caro JJ. Behavioral and psychological symptoms in dementia in nursing home residents: The economic implications. Int Psychogeriatr. 2000;12(SUPPL. 1):51-7.
Olazaran J, Reisberg B, Clare L, et al. Nonpharmacological therapies in Alzheimer's disease: a systematic review of efficacy. Dement Geriatr Cogn Disord. 2010;30(2):161-78. [pmid: 20838046].
Ouslander JG, Connell BR, Bliwise DL, et al. A nonpharmacological intervention to improve sleep in nursing home patients: results of a controlled clinical trial. J Am Geriatr Soc. Jan. 2006;54(1):38-47. [pmid: 16420196].
Peacock SC, Forbes DA. Interventions for caregivers of persons with dementia: a systematic review (Provisional abstract). Can J Nurs Res. 2003:88-107. [pmid: 14746123].
Perls TT, Herget M. Higher respiratory infection rates on an Alzheimer's special care unit and successful intervention. J Am Geriatr Soc. Dec. 1995;43(12):1341-4. [pmid: 7490383].
Phillips CD, Munoz Y, Sherman M, et al. Effects of facility characteristics on departures from assisted living: results from a national study. Gerontologist. 2003;43(5):690-6. [pmid: 14570965].
Phillips LJ, Reid-Arndt SA, Pak Y. Effects of a creative expression intervention on emotions, communication, and quality of life in persons with dementia. Nurs Res. Nov-Dec. 2010;59(6):417-25. [pmid: 21048483].
Pillemer K, Suitor JJ, Henderson CR Jr., et al. A cooperative communication intervention for nursing home staff and family members of residents. Gerontologist. Apr. Spec No 2. 2003;43:96-106. [pmid: 12711730].
Politis AM, Vozzella S, Mayer LS, et al. A randomized, controlled, clinical trial of activity therapy for apathy in patients with dementia residing in long-term care. Int J Geriatr Psychiatry. Nov. 2004;19(11):1087-94. [pmid: 15481065].
Price James D, Hermans D, Grimley Evans J. Subjective barriers to prevent wandering of cognitively impaired people, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
Pusey H, Richards D. A systematic review of the effectiveness of psychosocial interventions for carers of people with dementia (Structured abstract). Aging and Mental Health. 2001:107-19. [pmid: 11511058].
Quigley P, Bulat T, Kurtzman E, et al. Fall prevention and injury protection for nursing home residents. J Am Med Dir Assoc. May. 2010;11(4):284-93. [pmid: 20439049].
Quinn CC, Gruber-Baldini AL, Port CL, et al. The role of nursing home admission and dementia status on care for diabetes mellitus. J Am Geriatr Soc. Sep. 2009;57(9):1628-33. [pmid: 19682125].
Rahman A, Straker JK, Manning L. Staff assignment practices in nursing homes: review of the literature. J Am Med Dir Assoc. Jan. 2009;10(1):4-10. [pmid: 19111847].
Rantz MJ, Hicks L, Grando V, et al. Nursing home quality, cost, staffing, and staff mix. Gerontologist. Feb. 2004;44(1):24-38. [pmid: 14978318].
Ray WA, Taylor JA, Meador KG, et al. A randomized trial of a consultation service to reduce falls in nursing homes. JAMA. Aug. 20. 1997;278(7):557-62. [pmid: 9268276].
Reinardy J, Kane RA. Choosing an adult foster home or a nursing home: residents' perceptions about decision making and control. Soc Work. Nov. 1999;44(6):571-85. [pmid: 10568028].
Resnick B, Gruber-Baldini AL, Zimmerman S, et al. Nursing home resident outcomes from the Res-Care intervention. J Am Geriatr Soc. Jul. 2009;57(7):1156-65. [pmid: 19570158].
Roberts J, Browne G, Gafni A, et al. Specialized continuing care models for persons with dementia: a systematic review of the research literature. Canadian Journal on Aging. 2000;19(1):106-26.
Rochon PA, Normand SL, Gomes T, et al. Antipsychotic therapy and short-term serious events in older adults with dementia. Arch Intern Med. May. 26. 2008;168(10):1090-6. [pmid: 18504337].
Rohrer JE, Momany ET, Chang W. Organizational predictors of outcomes of long-stay nursing home residents. Soc Sci Med. Aug. 1993;37(4):549-54. [pmid: 8211267].
Rovner BW, Steele CD, Shmuely Y, et al. A randomized trial of dementia care in nursing homes. J Am Geriatr Soc. Jan. 1996;44(1):7-13. [pmid: 8537594].
Ryden MB, Snyder M, Gross CR, et al. Value-added outcomes: the use of advanced practice nurses in long-term care facilities. The Gerontologist. 2000:654-62. [pmid: 11131082].
Sailas Eila ES, Fenton M. Seclusion and restraint for people with serious mental illnesses, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2000.
Sainfort F, Ramsay JD, Monato H Jr. Conceptual and methodological sources of variation in the measurement of nursing facility quality: an evaluation of 24 models and an empirical study. Med Care Res Rev. Mar. 1995;52(1):60-87. [pmid: 10143577].
Sales AE, Hedrick SC, Sullivan J, et al. Factors affecting choice of community residential care setting. J Aging Health. Apr. 2005;17(2):190-206. [pmid: 15750051].
Samus QM, Mayer L, Baker A, et al. Characteristics and outcomes for assisted living residents with dementia: comparing dementia-specific care units with non-dementia-specific care units. J Am Geriatr Soc. 2008;56(7):1361-3. [pmid: 18774972].
Schnelle JF, Alessi CA, Al-Samarrai NR, et al. The nursing home at night: effects of an intervention on noise, light, and sleep. J Am Geriatr Soc. Apr. 1999;47(4):430-8. [pmid: 10203118].
Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. 2002:1476-83. [pmid: 12383143].
Schnelle JF, Kapur K, Alessi C, et al. Does an exercise and incontinence intervention save healthcare costs in a nursing home population?. J Am Geriatr Soc. Feb. 2003;51(2):161-8. [pmid: 12558711].
Schnelle JF, Simmons SF, Harrington C, et al. Relationship of nursing home staffing to quality of care. Health Serv Res. Apr. 2004;39(2):225-50. [pmid: 15032952].
Shinoda-Tagawa T, Leonard R, Pontikas J, et al. Resident-to-resident violent incidents in nursing homes. JAMA. Feb. 4. 2004;291(5):591-8. [pmid: 14762038].
Simmons SF, Schnelle JF. Individualized feeding assistance care for nursing home residents: staffing requirements to implement two interventions. J Gerontol A Biol Sci Med Sci. Sep. 2004;59(9):M966-73. [pmid: 15472163].
Simmons SF, Schnelle JF. Effects of an exercise and scheduled-toileting intervention on appetite and constipation in nursing home residents. J Nutr Health Aging. 2004;8(2):116-21. [pmid: 14978607].
Slaughter S, Calkins M, Eliasziw M, et al. Measuring physical and social environments in nursing homes for people with middle- to late-stage dementia. J Am Geriatr Soc. Sep. 2006;54(9):1436-41. [pmid: 16970655].
Sloane PD, Zimmerman S, Brown LC, et al. Inappropriate medication prescribing in residential care/assisted living facilities. J Am Geriatr Soc. Jun. 2002;50(6):1001-11. [pmid: 12110058].
Sloane PD, Zimmerman S, Hanson L, et al. End-of-life care in assisted living and related residential care settings: comparison with nursing homes. J Am Geriatr Soc. Nov. 2003;51(11):1587-94. [pmid: 14687388].
Snow AL, Weber JB, O'Malley KJ, et al. NOPPAIN: a nursing assistant-administered pain assessment instrument for use in dementia. Dement Geriatr Cogn Disord. 2004;17(3):240-6. [pmid: 14745230].
Specht JK, Lyons SS, Maas ML. Patterns and treatments of Urinary incontinence on special care units. J Gerontol Nurs. May. 2002;28(5):13-21. [pmid: 12035821].
Specht JK, Park M, Maas ML, et al. Interventions for residents with dementia and their family and staff caregivers: evaluating the effectiveness of measures of outcomes in long-term care. J Gerontol Nurs. Jun. 2005;31(6):6-14. [pmid: 16138525].
Spector WD, Takada HA. Characteristics of nursing homes that affect resident outcomes. J Aging Health. Nov. 1991;3(4):427-54. [pmid: 10115033].
Spitznagel MB, Tremont G, Davis JD, et al. Psychosocial predictors of dementia caregiver desire to institutionalize: caregiver, care recipient, and family relationship factors. J Geriatr Psychiatry Neurol. Mar. 2006;19(1):16-20. [pmid: 16449755].
Spruytte N, Van Audenhove C, Lammertyn F. Predictors of institutionalization of cognitively-impaired elderly cared for by their relatives. Int J Geriatr Psychiatry. Dec. 2001;16(12):1119-28. [pmid: 11748770].
Steele C, Rovner B, Chase GA, et al. Psychiatric symptoms and nursing home placement of patients with Alzheimer's disease. Am J Psychiatry. Aug. 1990;147(8):1049-51. [pmid: 2375439].
Stefanacci RG, Lester PE, Kohen I. Nursing home resident smoking policies. Director. Summer. 2008;16(3):37-9. 41. 3. [pmid: 19343890].
Stefanov DH, Bien Z, Bang WC. The smart house for older persons and persons with physical disabilities: structure, technology arrangements, and perspectives. IEEE Trans Neural Syst Rehabil Eng. Jun. 2004;12(2):228-50. [pmid: 15218937].
Stephens MA, Kinney JM, Ogrocki PK. Stressors and well-being among caregivers to older adults with dementia: the in-home versus nursing home experience. Gerontologist. Apr. 1991;31(2):217-23. [pmid: 2044994].
Sterke CS, Verhagen AP, van Beeck EF, et al. The influence of drug use on fall incidents among nursing home residents: a systematic review. Int Psychogeriatr. Oct. 2008;20(5):890-910. [pmid: 18416875].
Stiens G, Maeck L, Stoppe G. Filial maturity as a predictor for the burden of demented parents' caregivers. Z Gerontol Geriatr. Apr. 2006;39(2):120-5. [pmid: 16622633].
Strain LA, Blandford AA, Mitchell LA, et al. Cognitively impaired older adults: risk profiles for institutionalization. Int Psychogeriatr. Dec. 2003;15(4):351-66. [pmid: 15000415].
Strang VR, Koop PM, Dupuis-Blanchard S, et al. Family caregivers and transition to long-term care. Clin Nurs Res. Feb. 2006;15(1):27-45. [pmid: 16410621].
Street D, Burge S, Quadagno J, et al. The salience of social relationships for resident well-being in assisted living. J Gerontol B Psychol Sci Soc Sci. Mar. 2007;62(2):S129-34. [pmid: 17379682].
Strumpf NE, Tuch H, Stillman D, et al. Implementing Palliative Care in the Nursing Home. ANNALS OF LONG TERM CARE. 2004;12(11):35-41.
Stuckey JC, Neundorfer MM, Smyth KA. Burden and well-being: the same coin or related currency. Gerontologist. Oct. 1996;36(5):686-93. [pmid: 8942113].
Suhr J. Progressive Muscle Relaxation in the Management of Behavioural Disturbance in Alzheimer's Disease. Neuropsychological Rehabilitation. 1999;9(1):31-44.
Tappen RM, Roach KE, Applegate EB, et al. Effect of a combined walking and conversation intervention on functional mobility of nursing home residents with Alzheimer disease. Alzheimer Dis Assoc Disord. Oct-Dec. 2000;14(4):196-201. [pmid: 11186596].
Tappen RM, Williams CL. Therapeutic conversation to improve mood in nursing home residents with Alzheimer's disease. Res Gerontol Nurs. Oct. 2009;2(4):267-75. [pmid: 20077983].
Tappen RM, Williams CL, Barry C, et al. Conversation intervention with Alzheimer's patients: increasing the relevance of communication. Clin Gerontol. 2001;24(3-4):63-75. [pmid: 18270554].
Teno JM, Feng Z, Mitchell SL, et al. Do financial incentives of introducing case mix reimbursement increase feeding tube use in nursing home residents?. J Am Geriatr Soc. May. 2008;56(5):887-90. [pmid: 18331293].
Teno JM, Gozalo PL, Lee IC, et al. Does hospice improve quality of care for persons dying from dementia?. J Am Geriatr Soc. Aug. 2011;59(8):1531-6. [pmid: 21797834].
Teresi J, Holmes D, Benenson E, et al. Evaluation of primary care nursing in long-term care. Res Aging. 1993;15(4):414-32.
Teresi J, Holmes D, Benenson E, et al. A primary care nursing model in long-term care facilities: evaluation of impact on affect, behavior, and socialization. Gerontologist. Oct. 1993;33(5):667-74. [pmid: 8225012].
Teresi JA, Holmes D, Monaco C. Evaluation of the effects of commingling cognitively and noncognitively impaired individuals in long-term care facilities. Gerontologist. 1993;33(3):350-8. [pmid: 8325522].
Teri L, Logsdon RG, Uomoto J, et al. Behavioral treatment of depression in dementia patients: a controlled clinical trial. J Gerontol B Psychol Sci Soc Sci. Jul. 1997;52(4):P159-66. [pmid: 9224439].
Thapa PB, Meador KG, Gideon P, et al. Effects of antipsychotic withdrawal in elderly nursing home residents. J Am Geriatr Soc. Mar. 1994;42(3):280-6. [pmid: 7907098].
Tomlinson Claire L, Patel S, Meek C, et al. Physiotherapy versus placebo or no intervention in Parkinson's disease, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2001.
Tornatore JB, Hedrick SC, Sullivan JH, et al. Community residential care: comparison of cognitively impaired and noncognitively impaired residents. Am J Alzheimers Dis Other Demen. Jul-Aug. 2003;18(4):240-6. [pmid: 12955789].
Trappler B, Cohen CI. Use of SSRIs in “very old” depressed nursing home residents. Am J Geriatr Psychiatry. Winter. 1998;6(1):83-9. [pmid: 9469218].
Triplett P, Black BS, Phillips H, et al. Content of advance directives for individuals with advanced dementia. J Aging Health. Aug. 2008;20(5):583-96. [pmid: 18625761].
Van der Roest Henriëtte G, Wenborn J, Dröes RM, et al. Assistive technology for memory support in dementia, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
Vasse E, Vernooij-Dassen M, Spijker A, et al. A systematic review of communication strategies for people with dementia in residential and nursing homes. Int Psychogeriatr. Mar. 2010;22(2):189-200. [pmid: 19638257].
Vergidis P, Hamer DH, Meydani SN, et al. Patterns of antimicrobial use for respiratory tract infections in older residents of long-term care facilities. J Am Geriatr Soc. Jun. 2011;59(6):1093-8. [pmid: 21539527].
Voyer P, Richard S, Doucet L, et al. Factors associated with delirium severity among older persons with dementia. J Neurosci Nurs. Apr. 2011;43(2):62-9. [pmid: 21488579].
Wang PS, Schneeweiss S, Avorn J, et al. Risk of death in elderly users of conventional vs. atypical antipsychotic medications. N Engl J Med. Dec. 1. 2005;353(22):2335-41. [pmid: 16319382].
Wang SY. Weight loss and metabolic changes in dementia. J Nutr Health Aging. May. 2002;6(3):201-5. [pmid: 11887245].
Weisman GD, Kovach C, Cashin SE. Differences in dementia services and settings across place types and regions. Am J Alzheimers Dis Other Demen. Sep-Oct. 2004;19(5):291-8. [pmid: 15553985].
Werner P, Cohen-Mansfield J, Farley J, et al. Effects of removal of physical restraints on psychotropic medication in the nursing home. Journal of Geriatric Drug Therapy. 1994;8(4):59-71.
White HK. Nutrition in advanced Alzheimer's disease. N C Med J. Jul-Aug. 2005;66(4):307-12. [pmid: 16206538].
Whitlatch CJ, Zarit SH, von Eye A. Efficacy of interventions with caregivers: a reanalysis. Gerontologist. Feb. 1991;31(1):9-14. [pmid: 2007480].
Wigg JM. Liberating the wanderers: using technology to unlock doors for those living with dementia. Sociol Health Illn. Feb. 1. 2010;32(2):288-303. [pmid: 20422746].
Williams CL, Tappen RM. Effect of exercise on mood in nursing home residents with Alzheimer's disease. Am J Alzheimers Dis Other Demen. Oct-Nov. 2007;22(5):389-97. [pmid: 17959874].
Williams KN, Herman R, Gajewski B, et al. Elderspeak communication: impact on dementia care. Am J Alzheimers Dis Other Demen. Feb-Mar. 2009;24(1):11-20. [pmid: 18591210].
Woods B, Aguirre E, Spector Aimee E, et al. Cognitive stimulation to improve cognitive functioning in people with dementia, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
Woods DL, Rapp CG, Beck C. Escalation/de-escalation patterns of behavioral symptoms of persons with dementia. Aging and Mental Health. 2004;8(2):126-32. [pmid: 14982717].
Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol. Oct. 1998;179(4):999-1007. [pmid: 9790388].
Wyman JF, Fantl JA, McClish DK, et al. Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):223-9. [pmid: 9449301].
Yeatts DE, Cready CM. Consequences of empowered CNA teams in nursing home settings: a longitudinal assessment. Gerontologist. Jun. 2007;47(3):323-39. [pmid: 17565096].
Yin T, Zhou Q, Bashford C. Burden on family members. Caring for frail elderly: a meta-analysis of interventions (Structured abstract). Nurs Res. 2002:199-208. [pmid: 12063419].
Zimmerman S, Gruber-Baldini AL, Hebel JR, et al. Nursing home facility risk factors for infection and hospitalization: importance of registered nurse turnover, administration, and social factors. J Am Geriatr Soc. Dec. 2002;50(12):1987-95. [pmid: 12473010].
Zimmerman S, Sloane PD, Eckert JK, et al. How good is assisted living? Findings and implications from an outcomes study. J Gerontol B Psychol Sci Soc Sci. Jul. 2005;60(4):S195-204. [pmid: 15980295].
Zimmerman S, Williams CS, Reed PS, et al. Attitudes, stress, and satisfaction of staff who care for residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):96-105. [pmid: 16230756].
Zinn JS, Aaronson WE, Rosko MD. Variations in the outcomes of care provided in Pennsylvania nursing homes. Facility and environmental correlates. Med Care. Jun. 1993;31(6):475-87. [pmid: 8501995].

## Excluded for Wrong Study Design or Publication Type

Nursing homes report patients' mental problems. Health Care Strateg Manage. Jan. 1991;9(1):23. [pmid: 10170650].
Expanding the role of long-term care. The nursing home and beyond. Health Prog. Jun. 1992;73(5):27-33. [pmid: 10170988].
Quality of Life Award. Havenwood-Heritage Heights. Provider. Sep. 1995;21(9):46. 9. [pmid: 10172418].
Costs: measuring the economic burden of Alzheimer's disease care. J Nurs Adm. Jan. 1997;27(1):4. [pmid: 9006594].
Nonpharmacologic interventions for the Alzheimer's resident: adapted from a 1999 OPTIMA Awards entry. Nursing Homes Long Term Care Management. 2000;49(8):51.
Nature walk: from aimless wandering to purposeful walking. Nursing Homes Long Term Care Management. 2000;49(11):50.
Winners of the 2003 AMDA Foundation/Pfizer Quality Improvement Awards. J Am Med Dir Assoc. Sep-Oct. 2003;4(5):286-8. [pmid: 14503538].
New horizons in mental health care. Nurs Times. Aug. 23-29. 2005;101(34):49. [pmid: 16149707].
Adventure into Snoezelen therapy. Nursing Homes Long Term Care Management. 2005;54(10):64.
Antipsychotics are overprescribed for nursing home residents. Harv Ment Health Lett. Aug. 2011;28(2):7. [pmid: 21980636].
Abraham IL, MacDonald KM, Nadzam DM. Measuring the quality of nursing care to Alzheimer's patients. Nurs Clin North Am. Mar. 2006;41(1):95-104. vi. vii. [pmid: 16492456].
Abraham IL, Onega LL, Chalifoux ZL, et al. Care environments for patients with Alzheimer's disease. Nurs Clin North Am. Mar. 1994;29(1):157-72. [pmid: 8121818].
Alderman C. Drugs--who needs them?. Elder Care. Oct-Nov. 1998;10(5):7-8. [pmid: 9866495].
Alderman C. A drug-free zone. Nurs Stand. Aug. 12-18. 1998;12(47):21-3. [pmid: 9752154].
Alessi CA, Schnelle JF. Approach to sleep disorders in the nursing home setting. REVIEW ARTICLE. Sleep Med Rev. Feb. 2000;4(1):45-56. [pmid: 12531160].
Algase DL, Beattie ER, Antonakos C, et al. Wandering and the physical environment. Am J Alzheimers Dis Other Demen. Jun. 2010;25(4):340-6. [pmid: 20378834].
Allen RS, Burgio LD, Fisher SE, et al. Behavioral characteristics of agitated nursing home residents with dementia at the end of life. Gerontologist. Oct. 2005;45(5):661-6. [pmid: 16199401].
Allen-Burge R, Stevens AB, Burgio LD. Effective behavioral interventions for decreasing dementia-related challenging behavior in nursing homes. Int J Geriatr Psychiatry. Mar. 1999;14(3):213-28. discussion 28-32. [pmid: 10202663].
Aman E, Thomas DR. Supervised exercise to reduce agitation in severely cognitively impaired persons. J Am Med Dir Assoc. May. 2009;10(4):271-6. [pmid: 19426944].
Amella EJ. Factors influencing the proportion of food consumed by nursing home residents with dementia. J Am Geriatr Soc. Jul. 1999;47(7):879-85. [pmid: 10404936].
Amella EJ. Resistance at mealtimes for persons with dementia. J Nutr Health Aging. 2002;6(2):117-22. [pmid: 12166364].
Amella EJ. Feeding and hydration issues for older adults with dementia. Nurs Clin North Am. Sep. 2004;39(3):607-23. [pmid: 15331305].
Anders KT. Special care. Do Alzheimer's units make sense--or just dollars? Advocates tout better care and quality of life. Contemp Longterm Care. Feb. 1994;17(2):48-9. [pmid: 10171846].
Anders KT. Toilet (re)training. Contemp Longterm Care. Apr. 2000;23(4):41-2. 6. [pmid: 11183690].
Anderson AA. Getting a grip on depression. Provider. Jan. 2001;27(1):37-8. [pmid: 11191267].
Applegate WB, Pahor M. Geriatric medicine. JAMA. Jun. 18. 1997;277(23):1863-4. [pmid: 9185804].
Armstrong F. Residents with dementia respond to pampering. Aust Nurs J. Feb. 2001;8(7):30. [pmid: 11894566].
Aselage MB, Amella EJ, Watson R. State of the science: alleviating mealtime difficulties in nursing home residents with dementia. Nurs Outlook. Jul-Aug. 2011;59(4):210-4. [pmid: 21757077].
Ashcraft AS, Owen DC, Feng D. A comparison of cognitive and functional care differences in four long-term care settings. J Am Med Dir Assoc. Feb. 2006;7(2):96-101. [pmid: 16461251].
Attoe H. Centre of excellence. Elder Care. May-Jun. 1993;5(3):12-3. [pmid: 8324514].
Aud MA. Dangerous wandering: elopements of older adults with dementia from long-term care facilities. Am J Alzheimers Dis Other Demen. Nov-Dec. 2004;19(6):361-8. [pmid: 15633945].
Aud MA. Residents with dementia in assisted living facilities. The role of behavior in discharge decisions. J Gerontol Nurs. Jun. 2004;30(6):16-26. [pmid: 15227933].
Aupperle PM, MacPhee ER, Strozeski JE, et al. Hospice use for the patient with advanced Alzheimer's disease: the role of the geriatric psychiatrist. Am J Alzheimers Dis Other Demen. Mar-Apr. 2004;19(2):94-104. [pmid: 15106390].
Babrow AS. Moving mom. Health Commun. Mar. 2010;25(2):191-4. [pmid: 20390685].
Ball J, Haight BK. Creating a multisensory environment for dementia: the goals of a Snoezelen room. J Gerontol Nurs. Oct. 2005;31(10):4-10. [pmid: 16262085].
Ball MM, Perkins MM, Whittington FJ, et al. Managing decline in assisted living: the key to aging in place. J Gerontol B Psychol Sci Soc Sci. Jul. 2004;59(4):S202-12. [pmid: 15294924].
Barnes AP. Beyond guardianship reform: a reevaluation of autonomy and beneficence for a system of principled decision-making in long term care. Emory Law J. Summer. 1992;41(3):633-760. [pmid: 11657640].
Bautista MK, Meuleman JR, Shorr RI, et al. Description and students' perceptions of a required geriatric clerkship in postacute rehabilitative care. J Am Geriatr Soc. Sep. 2009;57(9):1685-91. [pmid: 19682134].
Beattie ER, Song J, LaGore S. A comparison of wandering behavior in nursing homes and assisted living facilities. Res Theory Nurs Pract. Summer. 2005;19(2):181-96. [pmid: 16025697].
Beattie W. Current challenges to providing personalized care in a long term care facility. Int J Health Care Qual Assur Inc Leadersh Health Serv. 1998;11(2-3):i-v. [pmid: 10185310].
Beck C. Identification and assessment of effective services and interventions: the nursing home perspective. Aging Ment Health. May. Suppl 1. 2001;5:S99-111. [pmid: 11513505].
Beck C, Ortigara A, Mercer S, et al. Enabling and empowering certified nursing assistants for quality dementia care. Int J Geriatr Psychiatry. Mar. 1999;14(3):197-211. discussion -2. [pmid: 10202662].
Beck C, Rossby L, Baldwin B. Correlates of disruptive behavior in cognitively impaired elderly nursing home residents. Arch Psychiatr Nurs. Oct. 1991;5(5):281-91. [pmid: 1750778].
Becker D, Kahana Z. Informed consent in demented patients: a question of hours. Med Law. 1993;12(3-5):271-6. [pmid: 8231693].
Beer C, Bosboom P, Almeida OP, et al. Rating the quality of life of people with dementia living in residential care facilities in routine research practice. Age Ageing. May. 2009;38(3):343-6. [pmid: 19269947].
Behuniak SM. Free bird. Am J Hosp Palliat Care. Oct-Nov. 2007;24(5):429. [pmid: 17998410].
Bell J, Smith J. The happy wanderer. Nurs Times. Jul 27-Aug 2. 2000;96(30):29-31. [pmid: 11962885].
Berg L. A wish list. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S373-4. [pmid: 8068282].
Berg L, Buckwalter KC, Chafetz PK, et al. Special care units for persons with dementia. J Am Geriatr Soc. 1991;39(12):1229-36. [pmid: 1960368].
Beville PK. Virtual Dementia Tour helps sensitize health care providers. Am J Alzheimers Dis Other Demen. May-Jun. 2002;17(3):183-90. [pmid: 12083349].
Bicket MC, Samus QM, McNabney M, et al. The physical environment influences neuropsychiatric symptoms and other outcomes in assisted living residents. Int J Geriatr Psychiatry. Oct. 2010;25(10):1044-54. [pmid: 20077498].
Billings JA. Recent advances: palliative care. BMJ. Sep. 2. 2000;321(7260):555-8. [pmid: 10968822].
Bittman BB, Bruhn KT, Lim PB, et al. Testing the power of music-making. Provider. 2004;30(11):39-41. [pmid: 15595426].
Blakeslee J, Goldman B, Papougenis D. Untying the elderly: Kendal's restraint-free program at Longwood and Crosslands. Generations. 1990;14(Suppl. 1990):79-80. [pmid: 11651079].
Boehm S, Whall AL, Cosgrove KL, et al. Behavioral analysis and nursing interventions for reducing disruptive behaviors of patients with dementia. Appl Nurs Res. Aug. 1995;8(3):118-22. [pmid: 7668853].
Bourgeois MS. Enhancing conversation skills in patients with Alzheimer's disease using a prosthetic memory aid. J Appl Behav Anal. Spring. 1990;23(1):29-42. [pmid: 2139873].
Bourgeois MS. Communication treatment for adults with dementia. J Speech Hear Res. Aug. 1991;34(4):831-44. [pmid: 1956191].
Boustani M, Zimmerman S, Williams CS, et al. Characteristics associated with behavioral symptoms related to dementia in long-term care residents. Gerontologist. Oct. Spec No 1. 2005;45(1):56-61. [pmid: 16230750].
Brawley EC. Environmental design for Alzheimer's disease: a quality of life issue. Aging Ment Health. May. Suppl 1. 2001;5:S79-83. [pmid: 11513503].
Brennan PF. Computer networks: new tools for nursing practice. Applied nursing research : ANR. 1996:159-60. [pmid: 8961571].
Brillhart B. Pressure sore and skin tear prevention and treatment during a 10-month program. Rehabil Nurs. May-Jun. 2005;30(3):85-91. [pmid: 15912672].
Buchanan RJ, Choi M, Wang S, et al. Nursing home residents with Alzheimer's disease in special care units compared to other residents with Alzheimer's disease. Dementia. 2005;4(2):249-67.
Buckbee C. Montessori methods enhance function. Provider. Aug. 1999;25(8):63. 5. 7. [pmid: 10747613].
Buckwalter K, Leibrock C, Klein PE. Residential care for persons with dementia. Are codes and regulations protective or counter-productive?. J Gerontol Nurs. Jun. 1996;22(6):43-7. [pmid: 9036155].
Burgio L. Direct observation of behavioral disturbances of dementia and their environmental context. Int Psychogeriatr. Suppl 3. 1996;8:343-6. [pmid: 9154586].
Burgio LD, Bourgeois M. Treating severe behavioral disorders in geriatric residential settings. Behavioral Interventions. 1992;7(2):145-68.
Burgio LD, Butler FR, Roth DL, et al. Agitation in nursing home residents: the role of gender and social context. Int Psychogeriatr. Dec. 2000;12(4):495-511. [pmid: 11263716].
Calkins M, Cassella C. Exploring the cost and value of private versus shared bedrooms in nursing homes. Gerontologist. Apr. 2007;47(2):169-83. [pmid: 17440122].
Calkins MP. Evidence-based long term care design. NeuroRehabilitation. 2009;25(3):145-54. [pmid: 19893184].
Camp CJ, Cohen-Mansfield J, Capezuti EA. Use of nonpharmacologic interventions among nursing home residents with dementia. Psychiatr Serv. Nov. 2002;53(11):1397-401. [pmid: 12407266].
Carter MW, Porell FW. Vulnerable populations at risk of potentially avoidable hospitalizations: the case of nursing home residents with Alzheimer's disease. Am J Alzheimers Dis Other Demen. Nov-Dec. 2005;20(6):349-58. [pmid: 16396440].
Cassidy EL, Rosen C, Solano N, et al. Assessment to intervention: utilizing a staff needs assessment to improve care for behaviorally challenging residents in long term care (part II). Clin Gerontol. 2005;29:27-38.
Chafetz PK. Two-dimensional grid is ineffective against demented patients' exiting through glass doors. Psychol Aging. Mar. 1990;5(1):146-7. [pmid: 2317295].
Chen CK, Zimmerman S, Sloane PD, et al. Assisted living policies promoting autonomy and their relationship to resident depressive symptoms. Am J Geriatr Psychiatry. Feb. 2007;15(2):122-9. [pmid: 17272732].
Clawson KR. Ballard Health Care Residence: a SWAT team in action. J Long Term Care Adm. Spring. 1992;20(1):24. [pmid: 10171074].
Clegg A, Siddiqi N, Holt R, et al. Interventions for preventing delirium in older people in institutional long term care, Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2012.
Clements SD. Today I placed my father.… A gerontologic nurse faces her father's life, and death, away from home. Geriatr Nurs. Nov-Dec. 1992;13(6):303-4. [pmid: 1334928].
Cohen-Mansfield J. Reflections on the assessment of behavior in nursing home residents. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S217-22. [pmid: 8068263].
Cohen-Mansfield J. New ways to approach manifestations of Alzheimer's disease and to reduce caregiver burden. Int Psychogeriatr. Suppl 1. 1996;8:91-4. [pmid: 8934273].
Cohen-Mansfield J, Libin A. Assessment of agitation in elderly patients with dementia: correlations between informant rating and direct observation. Int J Geriatr Psychiatry. Sep. 2004;19(9):881-91. [pmid: 15352147].
Cohen-Mansfield J, Marx MS, Thein K, et al. The impact of past and present preferences on stimulus engagement in nursing home residents with dementia. Aging Ment Health. Jan. 2010;14(1):67-73. [pmid: 20155522].
Cohen-Mansfield J, Werner P. Outdoor wandering parks for persons with dementia: a survey of characteristics and use. Alzheimer Dis Assoc Disord. Apr-Jun. 1999;13(2):109-17. [pmid: 10372955].
Colling J, Ouslander J, Hadley BJ, et al. The effects of patterned urge-response toileting (PURT) on urinary incontinence among nursing home residents. J Am Geriatr Soc. Feb. 1992;40(2):135-41. [pmid: 1740597].
Conant-Arp C, Robinson J. Long-term care design: life-enhancing design strategies at the Louis Feinstein Alzheimer Day Care Center. J Healthc Des. 1997;9:117-20. [pmid: 10539134].
Cosh J. Lost in space. Ment Health Today. Oct. 2007:18-9. [pmid: 17992755].
Cutler LJ, Kane RA. Post-occupancy evaluation of a transformed nursing home: The first four Green House settings. J. Hous. Elderly Journal of Housing for the Elderly. 2009;23(4):304-34.
Davidhizar R, Cosgray R. Helping the wanderer. Geriatr Nurs. Nov-Dec. 1990;11(6):280-1. [pmid: 1965970].
Davis KJ, Sloane PD, Mitchell CM, et al. Specialized dementia programs in residential care settings. Gerontologist. Feb. 2000;40(1):32-42. [pmid: 10750311].
Davis LL, Kathleen B. Family caregiving after nursing home admission. Abstracts in Social Gerontology. 2002;45(2):157-301.
Dawson P, Schacter Y. Special care units (SCUs): do they change how residents and staff relate to each other?. Perspectives (Montclair). Fall. 1999;23(3):22-3. [pmid: 12026410].
Detweiler MB, Murphy PF, Kim KY, et al. Scheduled medications and falls in dementia patients utilizing a wander garden. Am J Alzheimers Dis Other Demen. Aug-Sep. 2009;24(4):322-32. [pmid: 19366885].
Detweiler MB, Murphy PF, Myers LC, et al. Does a wander garden influence inappropriate behaviors in dementia residents?. Am J Alzheimers Dis Other Demen. Feb-Mar. 2008;23(1):31-45. [pmid: 18276956].
DeYoung S, Just G, Harrison R. Decreasing aggressive, agitated, or disruptive behavior: perticipation in a behavior management unit. J Gerontol Nurs. Jun. 2002;28(6):22-31. [pmid: 12071270].
Dickinson JI, McLain-Kark J. Wandering behavior and attempted exits among residents diagnosed with dementia-related illnesses: a qualitative approach. J Women Aging. 1998;10(2):23-34. [pmid: 9870039].
Diggins K. Moral courage. J Christ Nurs. Oct-Dec. 2011;28(4):190. [pmid: 21999080].
Dilworth-Anderson P. Family issues and the care of persons with Alzheimer's disease. Aging Ment Health. May. Suppl 1. 2001;5:S49-51. [pmid: 11513497].
Dobbs D, Munn J, Zimmerman S, et al. Characteristics associated with lower activity involvement in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):81-6. [pmid: 16230754].
Dokken D, English T. Designing of Alzheimer's centers. Using design elements that accommodate functional needs. Provider. Oct. 1998;24(10):70-1. 3. 4. 7. 8. [pmid: 10187743].
Doyle CJP. Social interventions to manage mental disorders of the elderly in long-term care. Australian Psychologist. 1993;28(1):25-30.
Duffin C. Designing care homes for people with dementia. Nurs Older People. May. 2008;20(4):22-4. [pmid: 18549112].
Dunbar J, Neufeld R. Focus on caregiving. Making restraint-free care work. Provider. May. 1997;23(5):75-6. 9. 81. [pmid: 10166887].
Dunkle RM. Beyond appearances: caring in the land of the living dead. J Christ Nurs. Sum. 1995;12(3):4-6. [pmid: 7629720].
Edelman P, Fulton BR, Kuhn D, et al. A comparison of three methods of measuring dementia-specific quality of life: perspectives of residents, staff, and observers. Gerontologist. Oct. Spec No 1. 2005;45(1):27-36. [pmid: 16230747].
Edelman P, Kuhn D, Fulton BR. Influence of cognitive impairment, functional impairment and care setting on dementia care mapping results. Aging Ment Health. Nov. 2004;8(6):514-23. [pmid: 15724833].
Edelman P, Ma T. Using technology to maximize the quality of life of people with dementia in adult day centers, assisted living facilities and nursing homes. Alzheimer's and Dementia. 2011;7(4):S499-S500.
Edwards N, Gardiner M, Ritchie DM, et al. Effect of exercise on negative affect in residents in special care units with moderate to severe dementia. Alzheimer Dis Assoc Disord. Oct-Dec. 2008;22(4):362-8. [pmid: 18978600].
Eggbeer WT. What's special about special care?. Pro. Provider. Dec. 1994;20(12):64. 2. [pmid: 10172200].
Ellis KS. How ‘sweet’ it is. A holistic approach to Alzheimer's nurtures patient and caregiver. Contemp Longterm Care. Jul. 2003;26(7):30-4. [pmid: 12891807].
Engel SE, Kiely DK, Mitchell SL. Satisfaction with end-of-life care for nursing home residents with advanced dementia. J Am Geriatr Soc. Oct. 2006;54(10):1567-72. [pmid: 17038076].
Engle VF. Care of the living, care of the dying: reconceptualizing nursing home care. J Am Geriatr Soc. Sep. 1998;46(9):1172-4. [pmid: 9736117].
Feldt KS, Ryden MB. Aggressive behavior. Educating nursing assistants. J Gerontol Nurs. May. 1992;18(5):3-12. [pmid: 1583285].
Fernie B, Fernie G. Organizing group programs for cognitively impaired elderly residents of nursing homes. Clin Gerontol. 1990;9(3-4):123-34. Note: Included in special issue “Mental Health in the Nursing Home”. [pmid: 49862].
Fink R. Focus on caregiving. Assessing pain in nonverbal patients. Provider. Aug. 2001;27(8):51-2. 5. [pmid: 11840628].
Finucane T. Thinking about life-sustaining treatment late in the life of a demented person. Georgia Law Rev. Winter. 2001;35(2):691-705. [pmid: 15119321].
Flood D. Hugs not drugs--an alternative management tool. Lamp. May. 1994;51(4):24. [pmid: 7869818].
Foltz G. One step at a time. Assisted living managers are learning the art of keeping wandering in check. Contemp Longterm Care. Sep. 1997;20(9):54-60. [pmid: 10173134].
Foltz-Gray D. Rough waters. Attention to residents' individual needs. Contemp Longterm Care. Sep. 1995;18(9):66-8. 70. [pmid: 10172467].
Foltz-Gray D. Designing for dementia. Contemp Longterm Care. 1996;(Suppl):28-30. [pmid: 10161671].
Foltz-Gray D. Feeding frenzy. Contemp Longterm Care. Jan. 53. 1996;19(1):49-4. 7. 9. [pmid: 10172587].
Ford K. Promoting independence in people with Alzheimer's disease. Elder Care. Jun-Jul. 1997;9(3):12-6. [pmid: 9295561].
Francese T, Sorrell J, Butler FR. The effects of regular exercise on muscle strength and functional abilities of late stage Alzheimer's residents. American Journal of Alzheimer's Disease and Other Dementias. May/June. 1997. 1997;12(3):122-7.
Freeman IC. One more faulty solution is novelty without progress a reply to “medical decision-making for the unbefriended nursing home resident. J Ethics Law Aging. Fall-Winter. 1995;1(2):93-6. [pmid: 11654400].
Fries BE, Mehr DR, Schneider D, et al. Mental dysfunction and resource use in nursing homes. Med Care. Oct. 1993;31(10):898-920. [pmid: 8412392].
Fulner C, Hyde J, Zeisel J. Assisted living Alzheimer's units provide specialized services. Provider. Sep. 1992;18(9):67. [pmid: 10171241].
Funaki Y, Kaneko F, Okamura H. Study on factors associated with changes in quality of life of demented elderly persons in group homes. Scand J Occup Ther. Mar. 2005;12(1):4-9. [pmid: 16389993].
Garity J. Caring for a family member with Alzheimer's disease: coping with caregiver burden post-nursing home placement. J Gerontol Nurs. Jun. 2006;32(6):39-48. [pmid: 16773862].
Gatz D. Moving to a restraint-free environment. Balance. Nov-Dec. 2000;4(6):12-5. [pmid: 11188242].
Gaugler JE. Family involvement in residential long-term care: a synthesis and critical review. Aging Ment Health. Mar. 2005;9(2):105-18. [pmid: 15804627].
Gaugler JE, Anderson KA, Leach CR. Predictors of Family Involvement in Residential Long-Term Care. Journal of Gerontological Social Work. 2004/05/14. 2004;42(1):3-26.
Gaugler JE, Anderson KA, Leach MS, et al. The emotional ramifications of unmet need in dementia caregiving. Am J Alzheimers Dis Other Demen. Nov-Dec. 2004;19(6):369-80. [pmid: 15633946].
Gaugler JE, Anderson KA, Zarit SH, et al. Family involvement in nursing homes: effects on stress and well-being. Aging Ment Health. Jan. 2004;8(1):65-75. [pmid: 14690870].
Gelhaus L. High-tech homes mean a brighter future for seniors. Provider. Sep. 2002;28(9):40-2. [pmid: 12235625].
Gelhaus L. Achieving quality in assisted living. Provider. Aug. 2002;28(8):22-4. 7. 8. 31. 4. passim. [pmid: 12221798].
Gessert CE, Haller IV, Kane RL, et al. Rural-urban differences in medical care for nursing home residents with severe dementia at the end of life. J Am Geriatr Soc. Aug. 2006;54(8):1199-205. [pmid: 16913985].
Giancola PR, Zeichner A. Aggressive behavior in the elderly: a critical review. Clin Gerontol. 1993;13(2):3-22.
Givens JL, Kiely DK, Carey K, et al. Healthcare proxies of nursing home residents with advanced dementia: decisions they confront and their satisfaction with decision-making. J Am Geriatr Soc. Jul. 2009;57(7):1149-55. [pmid: 19486200].
Gold DT, Sloane PD, Mathew LJ, et al. Special care units: a typology of care settings for memory-impaired older adults. Gerontologist. Aug. 1991;31(4):467-75. [pmid: 1909986].
Gonzalez-Salvador T, Lyketsos CG, Baker A, et al. Quality of life in dementia patients in long-term care. Int J Geriatr Psychiatry. Feb. 2000;15(2):181-9. [pmid: 10679850].
Gould MO. Resident-centered care. Teresian House takes a team-based approach to care of the elderly. Health Prog. Nov-Dec. 2001;82(6):56-8. 72. [pmid: 11763583].
Gruber-Baldini AL, Zimmerman S, Boustani M, et al. Characteristics associated with depression in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):50-5. [pmid: 16230749].
Gruneir A, Lapane KL, Miller SC, et al. Is dementia special care really special? A new look at an old question. J Am Geriatr Soc. 2008;56(2):199-205. [pmid: 18179483].
Gruneir A, Miller SC, Intrator O, et al. Hospitalization of nursing home residents with cognitive impairments: the influence of organizational features and state policies. Gerontologist. Aug. 2007;47(4):447-56. [pmid: 17766666].
Gugel RN. Behavioral approaches for managing patients with Alzheimer's disease and related disorders. Med Clin North Am. Jul. 1994;78(4):861-7. [pmid: 8022233].
Halbert RJ. Lessons from the original ‘Eden’. Provider. Jun. 2000;26(6):49-51. [pmid: 11182956].
Hanson LC, Gilliam R, Lee TJ. Successful clinical trial research in nursing homes: the Improving Decision-Making Study. Clin Trials. Dec. 2010;7(6):735-43. [pmid: 20729251].
Hauer M, Ewald CJ. A blueprint for dementia care. How Anna's House became a home to so many. Contemp Longterm Care. May. 2001;24(5):31. [pmid: 11373957].
Haynes SL. Sponsor program helps families adjust to facility placement. Provider. Sep. 1992;18(9):63. [pmid: 10171240].
Hegland A. Accidental diets. Weight loss in Alzheimer's patients is the result of behavior, not disease. Contemp Longterm Care. Dec. 1993;16(12):65-6. [pmid: 10171756].
Hepburn KW, Caron W, Luptak M, et al. The Family Stories Workshop: stories for those who cannot remember. Gerontologist. Dec. 1997;37(6):827-32. [pmid: 9433000].
Hernandez D. Dignity and life purpose for AD (Alzheimer's disease) residents. Balance. Jan-Feb. 7. 1998;2(1):22-8. 39. [pmid: 10178525].
Hewawasam LC. The use of two-dimensional grid patterns to limit hazardous ambulation in elderly patients with Alzheimer's disease. Journal of Research in Nursing Journal of Research in Nursing. 1996;1(3):217-27.
Hoeffer B, Rader J, McKenzie D, et al. Reducing aggressive behavior during bathing cognitively impaired nursing home residents. J Gerontol Nurs. May. 1997;23(5):16-23. [pmid: 9180505].
Hogstel O. To what extent are dementia (all types) and depression diagnosed and treated in nursing facilities?. J Gerontol Nurs. Feb. 1999;25(2):52-3. [pmid: 10347437].
Jablonski RA, Kolanowski A, Therrien B, et al. Reducing care-resistant behaviors during oral hygiene in persons with dementia. BMC Oral Health. 2011;11:30. [pmid: 22100010].
Joseph A, Boult C. Managed primary care of nursing home residents. J Am Geriatr Soc. Sep. 1998;46(9):1152-6. [pmid: 9736112].
Joshi S, Flaherty JH. Elder abuse and neglect in long-term care. Clin Geriatr Med. May. 2005;21(2):333-54. [pmid: 15804554].
Kamble P, Chen H, Sherer JT, et al. Use of antipsychotics among elderly nursing home residents with dementia in the US: an analysis. of National Survey Data Drugs Aging. 2009;26(6):483-92. [pmid: 19591523].
Kane RA. Harbingers of the future? Seeking the “special” in the dementia special care unit. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S425-8. [pmid: 8068291].
Kane RA, Chan J, Kane RL. Assisted living literature through May 2004: taking stock. Gerontologist. 2007;47(Special Issue 3):125-40. [pmid: 18162575].
Kang H, Smith M, Buckwalter KC, et al. Anxiety, depression, and cognitive impairment in dementia-specific and traditional assisted living. J Gerontol Nurs. Jan. 2010;36(1):18-30. quiz 2-3. [pmid: 20047249].
Kayser-Jones J, Schell E. The mealtime experience of a cognitively impaired elder: ineffective and effective strategies. J Gerontol Nurs. Jul. 1997;23(7):33-9. [pmid: 9287604].
Kayser-Jones J, Schell ES. Staffing and the mealtime experience of nursing home residents on a special care unit. AJA. 1997;12(2):67-72.
Kim H, Whall AL. Factors associated with psychotropic drug usage among nursing home residents with dementia. Nurs Res. Jul-Aug. 2006;55(4):252-8. [pmid: 16849977].
Kim KY, Hall SB. A VA inpatient respite program for patients with dementia. Psychiatr Serv. Jun. 2003;54(6):821-2. 4. [pmid: 12773594].
Kim KY, Yeaman PA, Keene RL. End-of-life care for persons with Alzheimer's disease. Psychiatr Serv. Feb. 2005;56(2):139-41. [pmid: 15703339].
Knapp M. What are the critical success factors for providing quality dementia care in assisted living?. J Gerontol Nurs. Oct. 1999;25(10):46-9. [pmid: 10776153].
Kolanowski AM, Litaker MS, Baumann MA. Theory-based intervention for dementia behaviors: a within-person analysis over time. Appl Nurs Res. 2002;15(2):87-96. [pmid: 11994825].
Kopetz S, Steele CD, Brandt J, et al. Characteristics and outcomes of dementia residents in an assisted living facility. Int J Geriatr Psychiatry. Jul. 2000;15(7):586-93. [pmid: 10918338].
Kovach CR, Cashin JR, Sauer L. Deconstruction of a complex tailored intervention to assess and treat discomfort of people with advanced dementia. J Adv Nurs. Sep. 2006;55(6):678-88. [pmid: 16925616].
Kovach CR, Morgan S, Noonan PE, et al. Using principles of diffusion of innovation to improve nursing home care. J Nurs Care Qual. Apr-Jun. 2008;23(2):132-9. [pmid: 18344779].
Kovach CR, Stearns SA. DSCUs: a study of behavior before and after residence. J Gerontol Nurs. Dec. 1994;20(12):33-9. [pmid: 7852710].
Kovach CR, Weissman DE, Griffie J, et al. Assessment and treatment of discomfort for people with late-stage dementia. J Pain Symptom Manage. Dec. 1999;18(6):412-9. [pmid: 10641467].
Kuhn D, Kasayka RE, Lechner C. Behavioral observations and quality of life among persons with dementia in 10 assisted living facilities. Am J Alzheimers Dis Other Demen. 2002;17(5):291-8. [pmid: 12392266].
Lai CKY. Vocally disruptive behaviors in people with cognitive impairment: current knowledge and future research directions. AJA. 1999;14(3):172-80.
Lakdawalla P. ‘Sea-ing’ results: an aquarium can help boost Alzheimer's patients' appetites. Contemporary Long Term Care. 2003;28.
Lange-Alberts ME, Shott S. Nutritional intake. Use of touch and verbal cuing. J Gerontol Nurs. Feb. 1994;20(2):36-40. [pmid: 8106722].
Larrat EP, McKernan-Markoff JL, Lareau M, et al. Development of Alzheimer's disease special care units on a statewide level. American Journal of Alzheimer's Care and Related Disorders and Research. 1994;9(2):22-6.
Lawton MP, Van Haitsma K, Klapper J. A balanced stimulation and retreat program for a special care dementia unit. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S133-8. [pmid: 8068253].
Ledger AJ, Baker FA. An investigation of long-term effects of group music therapy on agitation levels of people with Alzheimer's Disease. Aging Ment Health. May. 2007;11(3):330-8. [pmid: 17558584].
Lippa CF. Changing environment and activities for the patients with dementia: What can we do to ease the burden?. American journal of Alzheimer's disease and other dementias. 2010;25(3):187-8.
Luo H, Fang X, Liao Y, et al. Associations of special care units and outcomes of residents with dementia: 2004 national nursing home survey. Gerontologist. Aug. 2010;50(4):509-18. [pmid: 20462932].
Maas ML, Buckwalter KC, Kelley LS, et al. Family members' perceptions: how they view care of Alzheimer's patients in a nursing home. Journal of Long-Term Care Administration. 1991;19(1):21-5. [pmid: 10110685].
Mackenzie L, James IA, Morse R, et al. A pilot study on the use of dolls for people with dementia. Age Ageing. Jul. 2006;35(4):441-4. [pmid: 16638759].
Marquardt G. Wayfinding for people with dementia: a review of the role of architectural design. HERD. Winter. 2011;4(2):75-90. [pmid: 21465436].
Martichuski DK, Bell PA, Bradshaw B. Including Small Group Activities in Large Special Care Units. J Appl Gerontol. 1996;15(2):224-37.
McCormick KA, Burgio LD, Engel BT, et al. Urinary incontinence: an augmented prompted void approach. J Gerontol Nurs. Mar. 1992;18(3):3-10. [pmid: 1556395].
McCracken AL. Special care units: meeting the needs of cognitively impaired persons. J Gerontol Nurs. 1994;20(4):41-6. [pmid: 8195569].
McGregor C. The use of plush animals in long-term care facilities. Director. Summer. 1998;6(3):111-3. [pmid: 10531864].
McMinn B, Draper B. Vocally disruptive behaviour in dementia: development of an evidence based practice guideline. Aging Ment Health. Jan. 2005;9(1):16-24. [pmid: 15841828].
Mentes JC, Buckwalter KC. Dementia special care units programming and staffing issues. J Gerontol Nurs. Jan. 1998;24(1):6-8. [pmid: 9510715].
Merrilees JJ, Miller BL. Long-term care of patients with frontotemporal dementia. J Am Med Dir Assoc. Nov-Dec. 2003;4(6 Suppl):S162-4. [pmid: 14613593].
Mezey M, Fulmer T. Quality care for the frail elderly. Nurs Outlook. Nov-Dec. 1998;46(6):291-2. [pmid: 9879088].
Miglis MG. A piece of my mind. Annie. JAMA. Nov. 9. 2011;306(18):1960-1. [pmid: 22068983].
Mirotznik J. Does cognitive status moderate the health effects of single-person room transfers on nursing home residents?. Gerontologist. Oct. 2002;42(5):634-42. [pmid: 12351798].
Mitchell SL, Teno JM, Intrator O, et al. Decisions to forgo hospitalization in advanced dementia: a nationwide study. J Am Geriatr Soc. Mar. 2007;55(3):432-8. [pmid: 17341248].
Montgomery RJ. Family measures in the special care unit context. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S242-6. [pmid: 8068267].
Namazi KH, Johnson BD. How familiar tasks can enhance concentration in Alzheimer's disease patients. American Journal of Alzheimer's Disease and Other Dementias. January/February. 1992. 1992;7(1):35-40.
Namazi KH, Johnson BD. The effects of environmental barriers on the attention span of Alzheimer's disease patients. American Journal of Alzheimer's Disease and Other Dementias. January/February. 1992. 1992;7(1):9-15.
Nasr SZ, Osterweil D. The Nonpharmacologic Management of Agitation in the Nursing Home: A Consensus Approach. NURSING HOME MEDICINE. 1999;7(5):171-80.
Nelson J. The influence of environmental factors in incidents of disruptive behavior. J Gerontol Nurs. May. 1995;21(5):19-24. [pmid: 7759791].
Netz Y, Jacob T. Exercise and the psychological state of institutionalized elderly: a review. Percept Mot Skills. Dec. 1994;79(3 Pt 1):1107-18. [pmid: 7898996].
Oliver D. Bed falls and bedrails--what should we do?. Age Ageing. Sep. 2002;31(5):415-8. [pmid: 12242214].
Osborn CL, Marshall MJ. Self-feeding performance in nursing home residents. J Gerontol Nurs. Mar. 1993;19(3):7-14. [pmid: 8445166].
Peak T. Families and the Nursing Home Environment: Adaptation in a Group Context. Journal of Gerontological Social Work. 2000;33:51-66.
Pearson J. The colour coded Moorside home for older people. Elder Care. Feb-Mar. 1999;11(1):28-9. [pmid: 10542506].
Peskind ER. Management of depression in long-term care of patients with Alzheimer's disease. J Am Med Dir Assoc. Nov-Dec. 2003;4(6 Suppl):S141-5. [pmid: 14613590].
Phillips CD, Sloane PD, Hawes C, et al. Effects of residence in Alzheimer disease special care units on functional outcomes. JAMA. Oct. 22-29. 1997;278(16):1340-4. [pmid: 9343465].
Phillips CD, Spry KM, Sloane PD, et al. Use of physical restraints and psychotropic medications in Alzheimer special care units in nursing homes. Am J Public Health. Jan. 2000;90(1):92-6. [pmid: 10630143].
Philpott RM. Residential care for patients with dementia. Current Opinion in Psychiatry. 1990;3(4):522-7.
Porell F, Caro FG, Silva A, et al. A longitudinal analysis of nursing home outcomes. Health Serv Res. Oct. 1998;33(4 Pt 1):835-65. [pmid: 9776939].
Port CL, Zimmerman S, Williams CS, et al. Families filling the gap: comparing family involvement for assisted living and nursing home residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):87-95. [pmid: 16230755].
Powers BA, Watson NM. Meaning and practice of palliative care for nursing home residents with dementia at end of life. Am J Alzheimers Dis Other Demen. Aug-Sep. 2008;23(4):319-25. [pmid: 18453644].
Rader J, Barrick AL, Hoeffer B, et al. The bathing of older adults with dementia. Am J Nurs. Apr. 2006;106(4):40-8. quiz 8-9. [pmid: 16575237].
Reed PS, Zimmerman S, Sloane PD, et al. Characteristics associated with low food and fluid intake in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):74-80. [pmid: 16230753].
Reingold J, Werner B. The evolution of specialized dementia care: The relationship between research and program planning. Alzheimer Dis Assoc Disord. 1994;8(SUPPL. 1):S126-S32. [pmid: 8068252].
Reingold J, Werner BJ. Vocational workshop for residents and day care participants with dementia. AJA. 1995;10(4):18-21.
Rovner BW. Behavioral disturbances of dementia in the nursing home. Int Psychogeriatr. Suppl 3. 1996;8:435-7. [pmid: 9154603].
Ryden MB, Feldt KS, Oh HL, et al. Relationships between aggressive behavior in cognitively impaired nursing home residents and use of restraints, psychoactive drugs, and secured units. Arch Psychiatr Nurs. Aug. 1999;13(4):170-8. [pmid: 10478495].
Sambandham M, Schirm V. Music as a nursing intervention for residents with Alzheimer's disease in long-term care. Geriatr Nurs. Mar-Apr. 1995;16(2):79-83. [pmid: 7774824].
Samus QM, Rosenblatt A, Steele C, et al. The association of neuropsychiatric symptoms and environment with quality of life in assisted living residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):19-26. [pmid: 16230746].
Sand BJ, Yeaworth RC, McCabe BW. Alzheimer's disease. Special care units in long-term care facilities. J Gerontol Nurs. Mar. 1992;18(3):28-34. [pmid: 1556394].
Scanland SG, Emershaw LE. Reality orientation and validation therapy. Dementia, depression, and functional status. J Gerontol Nurs. Jun. 1993;19(6):7-11. [pmid: 8509612].
Schnelle JF, Cruise PA, Alessi CA, et al. Sleep hygiene in physically dependent nursing home residents: behavioral and environmental intervention implications. Sleep. Aug. 1. 1998;21(5):515-23. [pmid: 9703592].
Schnelle JF, Newman D, White M, et al. Maintaining continence in nursing home residents through the application of industrial quality control. Gerontologist. Feb. 1993;33(1):114-21. [pmid: 8440494].
Schnelle JF, Newman DR, Fogarty T. Management of patient continence in long-term care nursing facilities. Gerontologist. Jun. 1990;30(3):373-6. [pmid: 2354796].
Schnelle JF, Powell ML, Newman DR, et al. Subject screening strategy for nursing home residents: run-in versus mental status testing. Behavior, Health, and Aging. 1993;3(1):13-21.
Schonfeld L, King-Kallimanis B, Brown LM, et al. Wanderers with cognitive impairment in Department of Veterans Affairs nursing home care units. J Am Geriatr Soc. May. 2007;55(5):692-9. [pmid: 17493188].
Schulz M. Giving the best day possible. Can Nurse. Oct. 2011;107(8):44. [pmid: 22128711].
Simard J, Volicer L. Effects of Namaste Care on residents who do not benefit from usual activities. Am J Alzheimers Dis Other Demen. Feb. 2010;25(1):46-50. [pmid: 19332652].
Simard-Taggart J. Hospice lends a hand. Provider. Aug. 1994;20(8):41-2. [pmid: 10171909].
Sinclair M. Electronic eyes open. Improving and enhancing resident safety. Contemp Longterm Care. Nov-Dec. 2004:14-5. [pmid: 15957283].
Sloane PD, Davidson S, Knight N, et al. Severe disruptive vocalizers. J Am Geriatr Soc. Apr. 1999;47(4):439-45. [pmid: 10203119].
Sloane PD, Lindeman DA, Phillips C, et al. Evaluating Alzheimer's special care units: reviewing the evidence and identifying potential sources of study bias. Gerontologist. Feb. 1995;35(1):103-11. [pmid: 7890195].
Sloane PD, Mathew LJ, Scarborough M, et al. Physical and pharmacologic restraint of nursing home patients with dementia. Impact of specialized units. JAMA. Mar. 13. 1991;265(10):1278-82. [pmid: 1995975].
Sloane PD, Mitchell CM, Preisser JS, et al. Environmental correlates of resident agitation in Alzheimer's disease special care units. J Am Geriatr Soc. Jul. 1998;46(7):862-9. [pmid: 9670873].
Smith DA. The interdisciplinary team approach to long-term care of the dementia patient. J Long Term Care Adm. Summer. 1990;18(2):8-11. [pmid: 10170583].
Smith-Jones SM, Francis GM. Disruptive, institutionalized elderly: a cost-effective intervention. J Psychosoc Nurs Ment Health Serv. Oct. 1992;30(10):17-20. [pmid: 1404005].
Snowden M, Sato K, Roy-Byrne P. Assessment and treatment of nursing home residents with depression or behavioral symptoms associated with dementia: A review of the literature. J Am Geriatr Soc. 2003;51(9):1305-17. [pmid: 12919245].
Snyder M, Egan EC, Burns KR. Efficacy of hand massage in decreasing agitation behaviors associated with care activities in persons with dementia. Geriatr Nurs. Mar-Apr. 1995;16(2):60-3. [pmid: 7774819].
Snyder M, Tseng Y, Brandt C, et al. A glider swing intervention for people with dementia. Geriatr Nurs. Mar-Apr. 2001;22(2):86-90. [pmid: 11326215].
Somboontanont W, Sloane PD, Floyd FJ, et al. Assaultive behavior in Alzheimer's disease: identifying immediate antecedents during bathing. J Gerontol Nurs. Sep. 2004;30(9):22-9. quiz 55-6. [pmid: 15471060].
Specht JP, Kelley LS, Manion P, et al. Who's the boss? Family/staff partnership in care of persons with dementia. Nurs Adm Q. Spring. 2000;24(3):64-77. [pmid: 10986933].
Stermer M. Improving service in Alzheimer's care units. Provider. Mar. 1997;23(3):61-2. 4. 6. [pmid: 10172911].
Stevenson DG, Bramson JS. Hospice care in the nursing home setting: a review of the literature. J Pain Symptom Manage. Sep. 2009;38(3):440-51. [pmid: 19735904].
Straley PF, Cameron KL. Operating a financially viable Alzheimer's disease treatment unit. Top Health Care Financ. Summer. 1991;17(4):32-41. [pmid: 1907036].
Streim JE, Katz IR. Federal regulations and the care of patients with dementia in the nursing home. Med Clin North Am. Jul. 1994;78(4):895-909. [pmid: 8022236].
Swane CE. Improving environment and care for elderly people with dementia. Dan Med Bull. Jun. 1992;39(3):253-5. [pmid: 1638893].
Swanson EA, Maas ML, Buckwalter KC. Catastrophic reactions and other behaviors of Alzheimer's residents: special unit compared with traditional units. Arch Psychiatr Nurs. Oct. 1993;7(5):292-9. [pmid: 8257198].
Taft LB, Barkin RL. Drug abuse? Use and misuse of psychotropic drugs in Alzheimer's care. J Gerontol Nurs. Aug. 1990;16(8):4-10. [pmid: 2201718].
Tellis-Nayak M. The postacute continuum of care. Understanding your patient's options. Am J Nurs. Aug. 1998;98(8):44-8. discussion 9. [pmid: 9711149].
Teno JM. Looking beyond the “form” to complex interventions needed to improve end-of-life care. J Am Geriatr Soc. Sep. 1998;46(9):1170-1. [pmid: 9736116].
Teresi J, Lawton MP, Ory M, et al. Measurement issues in chronic care populations: dementia special care. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S144-83. [pmid: 8068256].
Tetlow K. The dirt on bath design. Contemp Longterm Care. 1995;(Suppl):18-9. 21. [pmid: 10172433].
Thomas DR, Verdery RB, Gardner L, et al. A prospective study of outcome from protein-energy malnutrition in nursing home residents. JPEN J Parenter Enteral Nutr. Jul-Aug. 1991;15(4):400-4. [pmid: 1910102].
Tornatore JB, Grant LA. Burden among family caregivers of persons with Alzheimer's disease in nursing homes. Gerontologist. Aug. 2002;42(4):497-506. [pmid: 12145377].
Tornatore JB, Grant LA. Family caregiver satisfaction with the nursing home after placement of a relative with dementia. J Gerontol B Psychol Sci Soc Sci. Mar. 2004;59(2):S80-8. [pmid: 15014095].
Tune LE, Porsteinsson A, Weinberg A. Dementia management: regulations, rules, and research. J Am Med Dir Assoc. Jul-Aug. 2003;4(4 Suppl):H13-6. [pmid: 12857362].
van der Ploeg ES, O'Connor DW. Evaluation of personalised, one-to-one interaction using Montessori-type activities as a treatment of challenging behaviours in people with dementia: the study protocol of a crossover trial. BMC geriatrics. 2010:3. [pmid: 20096137].
Van Ort S. Nursing intervention to promote functional feeding. J Gerontol Nurs. 1995;21(10):6-14. [pmid: 7594252].
van Someren EJ, Mirmiran M, Swaab DF. Non-pharmacological treatment of sleep and wake disturbances in aging and Alzheimer's disease: chronobiological perspectives. Behav Brain Res. Nov. 30. 1993;57(2):235-53. [pmid: 8117428].
Verbeek H, van Rossum E, Zwakhalen SM, et al. Small, homelike care environments for older people with dementia: a literature review. Int Psychogeriatr. Apr. 2009;21(2):252-64. [pmid: 19102801].
Volicer L, Hurley AC, Camberg L. A Model of Psychological Well-Being in Advanced Dementia. JOURNAL OF MENTAL HEALTH AND AGING. 1999;5(1):83-94.
Volicer L, Simard J, Pupa JH, et al. Effects of continuous activity programming on behavioral symptoms of dementia. J Am Med Dir Assoc. Sep. 2006;7(7):426-31. [pmid: 16979086].
Wagner AW, Teri L, Orr-Rainey N. Behavior problems among dementia residents in special care units: changes over time. J Am Geriatr Soc. Jul. 1995;43(7):784-7. [pmid: 7602032].
Wagner L. The special care touch. Provider. Dec. 1996;22(12):28-31. 3. 6. 9. [pmid: 10172954].
Walker C, Marchand L. The evolution of a unit for the cognitively impaired elderly. Dimens Health Serv. Jun-Jul. 1990;67(5):21-2. [pmid: 2271050].
Wall M, Duffy A. The effects of music therapy for older people with dementia. Br J Nurs. Jan 28-Feb 10. 2010;19(2):108-13. [pmid: 20220649].
Waltman RE, Hart ED. The nursing home. Nursing-home management of the demented patient. Geriatric Medicine Today. 1991;10(8):27-33.
Ward-Smith P, Llanque SM, Curran D. The effect of multisensory stimulation on persons residing in an extended care facility. Am J Alzheimers Dis Other Demen. Dec. 2010 Jan. 2009;24(6):450-5. [pmid: 19846683].
Weisman GD, Calkins M, Sloane P. The environmental context of special care. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S308-20. [pmid: 8068274].
Whitlatch CJ, Schur D, Noelker LS, et al. The stress process of family caregiving in institutional settings. Gerontologist. Aug. 2001;41(4):462-73. [pmid: 11490044].
Wilber KH, Machemer J. Balancing the competing values of freedom and safety in long-term dementia care: the secured perimeter program. J Ethics Law Aging. Fall-Winter. 1999;5(2):121-30. [pmid: 11657955].
Wilder DA, Higbee TS, Williams WL, et al. A simplified method of toilet training adults in residential settings. J Behav Ther Exp Psychiatry. Sep. 1997;28(3):241-6. [pmid: 9327303].
Williams CS, Zimmerman S, Sloane PD, et al. Characteristics associated with pain in long-term care residents with dementia. Gerontologist. Oct. Spec No 1. 2005;45(1):68-73. [pmid: 16230752].
Wimberley ET, Kutner NG. Atlanta case study: determining what is “special” in an Alzheimer disease special care unit. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S115-25. [pmid: 8068251].
Winakur J. What are we going to do with dad?. Health Aff (Millwood). Jul-Aug. 2005;24(4):1064-72. [pmid: 16012147].
Winblad B. Relationship of behavioral disturbances in demented patients to institutional care. Int Psychogeriatr. Suppl 1. 1996;8:133-5. [pmid: 8934284].
Witucki JM, Twibell RS. Effect of sensory stimulation activities on the psychological well being of patients with advanced Alzheimer's disease. AJA. 1997;12(1):10.
Wolf-Klein GP. Symptoms, diagnosis, and management of Alzheimer's disease. Compr Ther. Sep. 1990;16(9):25-9. [pmid: 2122939].
Wood W, Harris S, Snider M, et al. Activity situations on an Alzheimer's disease special care unit and resident environmental interactions, time use, and affect. Am J Alzheimers Dis Other Demen. Mar-Apr. 2005;20(2):105-18. [pmid: 15844757].
Yang-Lewis T, Moody HR. The forgetful mourner. Hastings Cent Rep. Jan-Feb. 1995;25(1):32. discussion -3. [pmid: 7730049].
Yao L, Algase D. Environmental ambiance as a new window on wandering. West J Nurs Res. Feb. 2006;28(1):89-104. [pmid: 16676727].
Yeaworth R. Coalition to change assisted living regulations governing special units for dementia patients. Nurs Outlook. Nov-Dec. 2000;48(6):314-5. [pmid: 11135149].
Yeaworth RC. Regulations governing special care units. J Gerontol Nurs. May. 2000;26(5):54-6. [pmid: 11111521].
Yurick A, Burgio L, Paton SM. Assessing disruptive behaviors of nursing home residents: use of microcomputer technology to promote objectivity in planning nursing interventions. J Gerontol Nurs. 1995;21(4):29-34. [pmid: 7602054].
Zandi T. Understanding difficult behaviors of nursing home residents: a prerequisite for sensitive clinical assessment and care. Alzheimer Dis Assoc Disord. Suppl 1. 1994;8:S345-54. [pmid: 8068278].
Zeisel J, Silverstein NM, Hyde J, et al. Environmental correlates to behavioral health outcomes in Alzheimer's special care units. Gerontologist. Oct. 2003;43(5):697-711. [pmid: 14570966].
Zhou X, Xu J, Zhao Y. Risk factors of distress in Alzheimer's patients. Ann Acad Med Singapore. 2007:253-8. [pmid: 17483854].
Zimmerman S, Scott AC, Park NS, et al. Social engagement and its relationship to service provision in residential care and assisted living. Soc Work Res. March. 1. 2003. 2003;27(1):6-18.

## Excluded for Wrong Country

Committed to caring: Carer experiences after a relative goes into nursing or residential care. Quality in ageing. 2002;3(3):16-26.
Achterberg WP, Gambassi G, Finne-Soveri H, et al. Pain in European long-term care facilities: cross-national study in Finland, Italy and The Netherlands. Pain. Jan. 2010;148(1):70-4. [pmid: 19910119].
Alfredson BB, Annerstedt L. Staff attitudes and job satisfaction in the care of demented elderly people: group living compared with long-term care institutions. J Adv Nurs. Nov. 1994;20(5):964-74. [pmid: 7745191].
Almberg B, Grafstrom M, Krichbaum K, et al. The interplay of institution and family caregiving: relations between patient hassles, nursing home hassles and caregivers' burnout. Int J Geriatr Psychiatry. Oct. 2000;15(10):931-9. [pmid: 11044875].
Almvik R, Woods P, Rasmussen K. Assessing risk for imminent violence in the elderly: the Broset Violence Checklist. Int J Geriatr Psychiatry. Sep. 2007;22(9):862-7. [pmid: 17236252].
Ames D. Depression among elderly residents of local-authority residential homes. Its nature and the efficacy of intervention. Br J Psychiatry. May. 1990;156:667-75. [pmid: 2095943].
Andersen-Ranberg K, Schroll M, Jeune B. Healthy centenarians do not exist, but autonomous centenarians do: a population-based study of morbidity among Danish centenarians. J Am Geriatr Soc. Jul. 2001;49(7):900-8. [pmid: 11527481].
Anderson K, Bird M, Macpherson S, et al. Findings from a pilot investigation of the effectiveness of a snoezelen room in residential care: should we be engaging with our residents more?. Geriatric nursing (New York, N.Y.). 2011:166-77.
Andersson M, Gottfries CG. Nursing home care: factors influencing the quality of life in a restricted life situation. Aging (Milano). Sep. 1991;3(3):229-39. [pmid: 1764491].
Andrews C. Happy eaters. Nurs Times. Dec 14-2001 Jan 3. 2000;96(50):26. [pmid: 11965800].
Andrews S, McInerney F, Robinson A. Realizing a palliative approach in dementia care: strategies to facilitate aged care staff engagement in evidence-based practice. Int Psychogeriatr. Apr. Suppl 1. 2009;21:S64-8. [pmid: 19288969].
Angelini A, Bendini C, Neviani F, et al. Behavioral and psychological symptoms of dementia (BPSD) in elderly demented subjects: is the long lasting use of atypical antipsychotic drugs useful and safe?. Arch Gerontol Geriatr. Suppl 1. 2007;44:35-43. [pmid: 17317431].
Annerstedt L, Sanada J, Gustafson L. A dynamic long-term care system for the demented elderly. Int Psychogeriatr. Winter. 1996;8(4):561-74. [pmid: 9147170].
Arcand M, Monette J, Monette M, et al. Educating nursing home staff about the progression of dementia and the comfort care option: impact on family satisfaction with end-of-life care. J Am Med Dir Assoc. Jan. 2009;10(1):50-5. [pmid: 19111853].
Bakker TJ, Duivenvoorden HJ, van der Lee J, et al. Integrative psychotherapeutic nursing home program to reduce multiple psychiatric symptoms of cognitively impaired patients and caregiver burden: randomized controlled trial. The American journal of geriatric psychiatry : official journal of the American Association for Geriatric Psychiatry. 2011:507-20. [pmid: 20808147].
Baldelli MV, Fabbo A, Costopulos C, et al. Is it possible to reduce job burnout of the health care staff working with demented patients?. Arch Gerontol Geriatr Suppl. 2004;(9):51-6. [pmid: 15207396].
Ballard C, Brown R, Fossey J, et al. Brief psychosocial therapy for the treatment of agitation in Alzheimer disease (the CALM-AD trial). Am J Geriatr Psychiatry. Sep. 2009;17(9):726-33. [pmid: 19700946].
Ballard C, Fossey J, Chithramohan R, et al. Quality of care in private sector and NHS facilities for people with dementia: cross sectional survey. BMJ. Aug. 25. 2001;323(7310):426-7. [pmid: 11520838].
Ballard C, O'Brien J, James I, et al. Quality of life for people with dementia living in residential and nursing home care: the impact of performance on activities of daily living, behavioral and psychological symptoms, language skills, and psychotropic drugs. Int Psychogeriatr. Mar. 2001;13(1):93-106. [pmid: 11352339].
Ballard CG, Margallo-Lana M, Fossey J, et al. A 1-year follow-up study of behavioral and psychological symptoms in dementia among people in care environments. J Clin Psychiatry. Aug. 2001;62(8):631-6. [pmid: 11561936].
Beer C, Flicker L, Horner B, et al. Factors associated with self and informant ratings of the quality of life of people with dementia living in care facilities: a cross sectional study. PLoS One. 2010;5(12):e15621. [pmid: 21179448].
Beer C, Horner B, Almeida OP, et al. Current experiences and educational preferences of general practitioners and staff caring for people with dementia living in residential facilities. BMC Geriatr. 2009;9:36. [pmid: 19674462].
Bell JS, Taipale HT, Soini H, et al. Sedative load among long-term care facility residents with and without dementia: a cross-sectional study. Clin Drug Investig. 2010;30(1):63-70. [pmid: 19995099].
Ben Natan M, Akrish O, Zaltkina B, et al. Physically restraining elder residents of long-term care facilities from a nurses' perspective. Int J Nurs Pract. Oct. 2010;16(5):499-507. [pmid: 20854348].
Bergh S, Engedal K. The withdrawal of antipsychotics and antidepressants from patients with dementia and BPSD living in nursing homes: an open pilot study. Int J Geriatr Psychiatry. Aug. 2008;23(8):877-9. [pmid: 18655022].
Bono G, Raineri C, Greco L, et al. Medium-term outcomes of Alzheimer patients in special care units. Funct Neurol. May-Aug. 1997;12(3-4):219-20. [pmid: 9218983].
Bowie P, Mountain G. The relationship between patient behaviour and environmental quality for the dementing. Int J Geriatr Psychiatry. Jul. 1997;12(7):718-23. [pmid: 9251933].
Brooker DJ, Argyle E, Scally AJ, et al. The enriched opportunities programme for people with dementia: a cluster-randomised controlled trial in 10 extra care housing schemes. Aging Ment Health. Nov. 2011;15(8):1008-17. [pmid: 21702705].
Bruce DG, Paley GA, Nichols P, et al. Physical disability contributes to caregiver stress in dementia caregivers. J Gerontol A Biol Sci Med Sci. Mar. 2005;60(3):345-9. [pmid: 15860472].
Burns A, Allen H, Tomenson B, et al. Bright light therapy for agitation in dementia: a randomized controlled trial. Int Psychogeriatr. Aug. 2009;21(4):711-21. [pmid: 19323872].
Carrier N, West GE, Ouellet D. Cognitively impaired residents' risk of malnutrition is influenced by foodservice factors in long-term care. J Nutr Elder. 2006;25(3-4):73-87. [pmid: 18032217].
Chenoweth L, King M, Luscombe G, et al. Study protocol of a randomised controlled group trial of client and care outcomes in the residential dementia care setting. Worldviews on evidence-based nursing / Sigma Theta Tau International, Honor Society of Nursing. 2011;8(3):153-65.
Christofoletti G, Oliani MM, Gobbi S, et al. A controlled clinical trial on the effects of motor intervention on balance and cognition in institutionalized elderly patients with dementia. Clin Rehabil. Jul. 2008;22(7):618-26. [pmid: 18586813].
Chung JCC. Activity Participation and Well-being of People with Dementia in Long-Term-Care Settings. OTJR Occupation, Participation and Health. 2004;24(1):22-31.
Claus JJ, Kwa VI, Teunisse S, et al. Slowing on quantitative spectral EEG is a marker for rate of subsequent cognitive and functional decline in early Alzheimer disease. Alzheimer Dis Assoc Disord. Sep. 1998;12(3):167-74. [pmid: 9772019].
Clyburn LD, Stones MJ, Hadjistavropoulos T, et al. Predicting caregiver burden and depression in Alzheimer's disease. J Gerontol B Psychol Sci Soc Sci. Jan. 2000;55(1):S2-13. [pmid: 10728125].
Cohen LW, Steen JT, Reed D, et al. Family Perceptions of End-of-Life Care for Long-Term Care Residents with Dementia: Differences Between the United States and the Netherlands. J Am Geriatr Soc. 2012;60(2):316-22. Language: English. Entry Date: 20120316. Revision Date: 20120316. Publication Type: journal article. [pmid: 22288500].
Cooke M, Moyle W, Shum D, et al. A randomized controlled trial exploring the effect of music on quality of life and depression in older people with dementia. J Health Psychol. Jul. 2010;15(5):765-76. [pmid: 20603300].
Cowan P. “Special care” for dementia patients. Can Nurse. Jun. 1999;95(6):49-50. [pmid: 10624221].
Cox H, Burns I, Savage S. Multisensory environments for leisure: promoting well-being in nursing home residents with dementia. J Gerontol Nurs. Feb. 2004;30(2):37-45. [pmid: 15022825].
Dechamps A, Diolez P, Thiaudiere E, et al. Effects of exercise programs to prevent decline in health-related quality of life in highly deconditioned institutionalized elderly persons: a randomized controlled trial. Arch Intern Med. Jan. 25. 2010;170(2):162-9. [pmid: 20101011].
Declercq A. Organizational culture as an instrument in residential care for dementing elderly. Stud Health Technol Inform. 1998;48:317-9. [pmid: 10186539].
Deponte A, Missan R. Effectiveness of validation therapy (VT) in group: preliminary results. Arch Gerontol Geriatr. Mar-Apr. 2007;44(2):113-7. [pmid: 16712981].
Ducharme F, Levesque L, Giroux F, et al. Follow-up of an intervention program for caregivers of a relative with dementia living in a long-term care setting: Are there any persistent and delayed effects?. Aging Ment Health. Sep. 2005;9(5):461-9. [pmid: 16024406].
Edberg AK, Hallberg IR. Effects of clinical supervision on nurse-patient cooperation quality: a controlled study in dementia care. Clin Nurs Res. May. 1996;5(2):127-46. discussion 47-9. [pmid: 8704662].
Edvardsson D, Sandman PO, Nay R, et al. Associations between the working characteristics of nursing staff and the prevalence of behavioral symptoms in people with dementia in residential care. Int Psychogeriatr. Aug. 2008;20(4):764-76. [pmid: 18304386].
Eggermont LH, Blankevoort CG, Scherder EJ. Walking and night-time restlessness in mild-to-moderate dementia: a randomized controlled trial. Age Ageing. Nov. 2010;39(6):746-9. [pmid: 20823127].
Eggermont LH, Knol DL, Hol EM, et al. Hand motor activity, cognition, mood, and the rest-activity rhythm in dementia: a clustered RCT. Behav Brain Res. Jan. 23. 2009;196(10):271-8. [pmid: 18926856].
Eggermont LH, Swaab DF, Hol EM, et al. Walking the line: a randomised trial on the effects of a short term walking programme on cognition in dementia. J Neurol Neurosurg Psychiatry. Jul. 2009;80(7):802-4. [pmid: 19531688].
Eggermont LH, Swaab DF, Hol EM, et al. Observation of hand movements by older persons with dementia: effects on cognition: a pilot study. Dement Geriatr Cogn Disord. 2009;27(4):366-74. [pmid: 19321984].
Elmstahl S, Annerstedt L, Ahlund O. How should a group living unit for demented elderly be designed to decrease psychiatric symptoms?. Alzheimer Dis Assoc Disord. Mar. 1997;11(1):47-52. [pmid: 9071444].
Engstrom M, Lindqvist R, Ljunggren B, et al. Relatives' opinions of IT support, perceptions of irritations and life satisfaction in dementia care. J Telemed Telecare. 2006;12(5):246-50. [pmid: 16848937].
Evans J. Effective care for vulnerable people. Elder Care. Apr-May. 1997;9(2):37-9. [pmid: 9180466].
Evans J, Armitage D. Improving end stage dementia care: a practice development approach. Geriaction. 2005. Jun. 2005;23(2):25-9.
Faxen-Irving G, Andren-Olsson B, af Geijerstam A, et al. The effect of nutritional intervention in elderly subjects residing in group-living for the demented. Eur J Clin Nutr. Mar. 2002;56(3):221-7. [pmid: 11960297].
Finnema E, de Lange J, Droes RM, et al. The quality of nursing home care: do the opinions of family members change after implementation of emotion-oriented care?. J Adv Nurs. Sep. 2001;35(5):728-40. [pmid: 11529975].
Finnema E, Droes RM, Ribbe M, et al. The effects of emotion-oriented approaches in the care for persons suffering from dementia: a review of the literature (Structured abstract). Int J Geriatr Psychiatry. 2000:141-61. [pmid: 10679846].
Fontana Gasio P, Krauchi K, Cajochen C, et al. Dawn-dusk simulation light therapy of disturbed circadian rest-activity cycles in demented elderly. Exp Gerontol. Jan-Feb. 2003;38(1-2):207-16. [pmid: 12543279].
Forbes D, Morgan DG, Bangma J, et al. Light therapy for managing sleep, behaviour, and mood disturbances in dementia. Cochrane Database Syst Rev. 2004;(2):CD003946. [pmid: 15106228].
Forbes DA. Strategies for managing behavioural symptomatology associated with dementia of the Alzheimer type: a systematic overview (Structured abstract). Can J Nurs Res. 1998:67-86. [pmid: 9807289].
Fuchs-Lacelle S, Hadjistavropoulos T, Lix L. Pain assessment as intervention: a study of older adults with severe dementia. Clin J Pain. Oct. 2008;24(8):697-707. [pmid: 18806535].
Furniss L, Burns A, Craig SK, et al. Effects of a pharmacist's medication review in nursing homes. Randomised controlled trial. The British journal of psychiatry : the journal of mental science. 2000:563-7. [pmid: 10974963].
Gaspard G, Garm A. The caring journey. Nurs BC. Feb. 2009;41(1):22-6. [pmid: 19266981].
Gerber GJ, Prince PN, Snider HG, et al. Group activity and cognitive improvement among patients with Alzheimer's disease. Hosp Community Psychiatry. Aug. 1991;42(8):843-5. [pmid: 1894261].
Goddaer J, Abraham IL. Effects of relaxing music on agitation during meals among nursing home residents with severe cognitive impairment. Arch Psychiatr Nurs. Jun. 1994;8(3):150-8. [pmid: 8080303].
Gold DP, Reis MF, Markiewicz D, et al. When home caregiving ends: a longitudinal study of outcomes for caregivers of relatives with dementia. J Am Geriatr Soc. Jan. 1995;43(1):10-6. [pmid: 7806732].
Harris T, Shah SM, Carey IM, et al. Depression indicators in a national sample of older community and care home patients: applying the Quality and Outcomes Framework. Br J Gen Pract. Feb. 2011;61(583):135-8. [pmid: 21276341].
Haslam C, Haslam SA, Jetten J, et al. The social treatment: the benefits of group interventions in residential care settings. Psychol Aging. Mar. 2010;25(1):157-67. [pmid: 20230136].
Heals D. Development and implementation of a palliative care link-nurse programme in care homes. Int J Palliat Nurs. Dec. 2008;14(12):604-9. [pmid: 19104477].
Helton MR, Cohen LW, Zimmerman S, et al. The importance of physician presence in nursing homes for residents with dementia and pneumonia. J Am Med Dir Assoc. Jan. 2011;12(1):68-73. [pmid: 21194663].
Henderson AS, Korten AE, Jorm AF, et al. Are nursing homes depressing?. Lancet. Oct. 15. 1994;344(8929):1091. [pmid: 7934473].
Hicks-Moore SL. Relaxing music at mealtime in nursing homes: effects on agitated patients with dementia. J Gerontol Nurs. Dec. 2005;31(12):26-32. [pmid: 16375095].
Holmes C, Knights A, Dean C, et al. Keep music live: music and the alleviation of apathy in dementia subjects. Int Psychogeriatr. Dec. 2006;18(4):623-30. [pmid: 16805928].
Holt Francesca E, Birks Theodore PH, Thorgrimsen Lene M, et al. Aroma therapy for dementia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2003.
Isaksson U, Astrom S, Sandman PO, et al. Factors associated with the prevalence of violent behaviour among residents living in nursing homes. J Clin Nurs. Apr. 2009;18(7):972-80. [pmid: 19284432].
Isaksson U, Graneheim UH, Astrom S, et al. Physically violent behaviour in dementia care: Characteristics of residents and management of violent situations. Aging Ment Health. Jul. 1. 2011;15(5):573-9. [pmid: 21815849].
Jackson GA, Lyons D. Psychiatric clinics in residential homes for the elderly. Psychiatric Bulletin. 1996;20(9):516-8.
Jilek R. Elderly toileting: is two hourly too often?. Nurs Stand. Aug. 11-17. 1993;7(47):25-6. [pmid: 8398749].
Keating N, Fast J, Dosman D, et al. Services Provided by Informal and Formal Caregivers to Seniors in Residential Continuing Care. CANADIAN JOURNAL ON AGING. 2001;20:23-46.
Kerse N, Peri K, Robinson E, et al. Does a functional activity programme improve function, quality of life, and falls for residents in long term care? Cluster randomised controlled trial. BMJ (Clinical research ed.). 2008:a1445.
Klages K, Zecevic A, Orange JB, et al. Potential of Snoezelen room multisensory stimulation to improve balance in individuals with dementia: a feasibility randomized controlled trial. Clin Rehabil. 2011:607-16. [pmid: 21382864].
Knight G, Lewis M, Jordan C. Improving end-of-life care in the care home sector. Pract. Dev. Health Care Practice Development in Health Care. 2008;7(4):189-97.
Koch S, Haesler E, Tiziani A, et al. Effectiveness of sleep management strategies for residents of aged care facilities: findings of a systematic review. J Clin Nurs. Oct. 2006;15(10):1267-75. [pmid: 16968431].
Kverno KS, Black BS, Nolan MT, et al. Research on treating neuropsychiatric symptoms of advanced dementia with non-pharmacological strategies, 1998-2008: a systematic literature review (Structured abstract). Int Psychogeriatr. 2009:825-43. [pmid: 19586562].
Lai CK, Yeung JH, Mok V, et al. Special care units for dementia individuals with behavioural problems. Cochrane Database Syst Rev. 2009;(4):CD006470. [pmid: 19821370].
Landi F, Russo A, Bernabei R. Physical activity and behavior in the elderly: a pilot study. Arch Gerontol Geriatr Suppl. 2004;(9):235-41. [pmid: 15207420].
Littbrand H, Carlsson M, Lundin-Olsson L, et al. Effect of a high-intensity functional exercise program on functional balance: preplanned subgroup analyses of a randomized controlled trial in residential care facilities. J Am Geriatr Soc. Jul. 2011;59(7):1274-82. [pmid: 21718270].
Littbrand H, Rosendahl E, Lindelof N, et al. A high-intensity functional weight-bearing exercise program for older people dependent in activities of daily living and living in residential care facilities: evaluation of the applicability with focus on cognitive function. Phys Ther. Apr. 2006;86(4):489-98. [pmid: 16579666].
Luk KY, Lai KY, Li CC, et al. The effect of horticultural activities on agitation in nursing home residents with dementia. Int J Geriatr Psychiatry. 2011:435-6. [pmid: 21412848].
Marriott A, Donaldson C, Tarrier N, et al. Effectiveness of cognitive-behavioural family intervention in reducing the burden of care in carers of patients with Alzheimer's disease. Br J Psychiatry. Jun. 2000;176:557-62. [pmid: 10974962].
Mathews K, Finch J. Using the Liverpool Care Pathway in a nursing home. Nurs Times. Sep. 12-18. 2006;102(37):34-5. [pmid: 17004697].
Mathey MF, Siebelink E, de Graaf C, et al. Flavor enhancement of food improves dietary intake and nutritional status of elderly nursing home residents. J Gerontol A Biol Sci Med Sci. Apr. 2001;56(4):M200-5. [pmid: 11283191].
Mayer R, Darby SJ. Does a mirror deter wandering in demented older people?. Int. J. Geriat. Psychiatry International Journal of Geriatric Psychiatry. 1991;6(8):607-9.
McGilton KS, Rivera TM, Dawson P. Can we help persons with dementia find their way in a new environment?. Aging Ment Health. Sep. 2003;7(5):363-71. [pmid: 12959805].
Miskelly F. Electronic tracking of patients with dementia and wandering using mobile phone technology. Age Ageing. Sep. 2005;34(5):497-9. [pmid: 16107453].
Mooney P, Nicell PL. The importance of exterior environment for Alzheimer residents: effective care and risk management. Healthc Manage Forum. Summer. 1992;5(2):23-9. [pmid: 10171068].
Morgan DG, Stewart MJ. Multiple occupancy versus private rooms on dementia care units. Environment and Behavior. 1998/07//. 1998;30(4):487+.
Morgan DG, Stewart NJ, D'Arcy KC, et al. Evaluating rural nursing home environments: dementia special care units versus integrated facilities. Aging Ment Health. May. 2004;8(3):256-65. [pmid: 15203407].
Nair BK, Heim C, Krishnan C, et al. The effect of Baroque music on behavioural disturbances in patients with dementia. Australas J Ageing. Mar. 2011;30(1):11-5. [pmid: 21395934].
Nobili A, Piana I, Balossi L, et al. Alzheimer special care units compared with traditional nursing home for dementia care: are there differences at admission and in clinical outcomes?. Alzheimer Dis Assoc Disord. Oct-Dec. 2008;22(4):352-61. [pmid: 18978601].
Opie J, Doyle C, O'Connor DW. Challenging behaviours in nursing home residents with dementia: a randomized controlled trial of multidisciplinary interventions. Int J Geriatr Psychiatry. Jan. 2002;17(1):6-13. [pmid: 11802224].
Opie J, Rosewarne R, O'Connor DW. The efficacy of psychosocial approaches to behaviour disorders in dementia: a systematic literature review (Structured abstract). Aust N Z J Psychiatry. 1999:789-99. [pmid: 10619204].
Orrell M, Hancock G, Hoe J, et al. A cluster randomised controlled trial to reduce the unmet needs of people with dementia living in residential care. Int J Geriatr Psychiatry. Nov. 2007;22(11):1127-34. [pmid: 17394129].
Ostaszkiewicz J, Johnston L, Roe B. Timed voiding for the management of urinary incontinence in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
Rolland Y, Pillard F, Klapouszczak A, et al. Exercise program for nursing home residents with Alzheimer's disease: a 1-year randomized, controlled trial. J Am Geriatr Soc. Feb. 2007;55(2):158-65. [pmid: 17302650].
Rosendahl E, Gustafson Y, Nordin E, et al. A randomized controlled trial of fall prevention by a high-intensity functional exercise program for older people living in residential care facilities. Aging clinical and experimental research. 2008:67-75. [pmid: 18283231].
Rosendahl E, Lindelöf N, Littbrand H, et al. High-intensity functional exercise program and protein-enriched energy supplement for older persons dependent in activities of daily living: a randomised controlled trial. The Australian journal of physiotherapy. 2006:105-13. [pmid: 16764547].
Sackley CM, van den Berg ME, Lett K, et al. Effects of a physiotherapy and occupational therapy intervention on mobility and activity in care home residents: a cluster randomised controlled trial. BMJ (Clinical research ed.). 2009:b3123.
Schrijnemaekers V, van Rossum E, Candel M, et al. Effects of emotion-oriented care on elderly people with cognitive impairment and behavioral problems. Int J Geriatr Psychiatry. 2002:926-37. [pmid: 12325052].
Simpson AH, Lamb S, Roberts PJ, et al. Does the type of flooring affect the risk of hip fracture?. Age Ageing. May. 2004;33(3):242-6. [pmid: 15082428].
Skea D, Lindesay J. An Evaluation of Two Models of Long-Term Residential Care for Elderly People with Dementia. Int J Geriatr Psychiatry. 1996;11(3):233-41.
Slaughter SE, Eliasziw M, Morgan D, et al. Incidence and predictors of eating disability among nursing home residents with middle-stage dementia. Clin Nutr. Apr. 2011;30(2):172-7. [pmid: 20950899].
Smit D, te Boekhorst S, de Lange J, et al. The long-term effect of group living homes versus regular nursing homes for people with dementia on psychological distress of informal caregivers. Aging Ment Health. Jul. 1. 2011;15(5):557-61. [pmid: 21815847].
Smith R, Mathews RM, Gresham M. Pre- and postoccupancy evaluation of new dementia care cottages. Am J Alzheimers Dis Other Demen. May. 2010;25(3):265-75. [pmid: 20150654].
Soto ME, Andrieu S, Gillette-Guyonnet S, et al. Risk factors for functional decline and institutionalisation among community-dwelling older adults with mild to severe Alzheimer's disease: one year of follow-up. Age Ageing. May. 2006;35(3):308-10. [pmid: 16533876].
Spector A, Thorgrimsen L, Woods B, et al. Efficacy of an evidence-based cognitive stimulation therapy programme for people with dementia: randomised controlled trial. Br J Psychiatry. Sep. 2003;183:248-54. [pmid: 12948999].
Stevens J, Killeen M. A randomised controlled trial testing the impact of exercise on cognitive symptoms and disability of residents with dementia. Contemp Nurse. Feb-Mar. 2006;21(1):32-40. [pmid: 16594879].
Suzuki K, Nomura T, Sakurai M, et al. Relationship between number of present teeth and nutritional intake in institutionalized elderly. Bull Tokyo Dent Coll. Nov. 2005;46(4):135-43. [pmid: 16829712].
te Boekhorst S, Depla MF, de Lange J, et al. The effects of group living homes on older people with dementia: a comparison with traditional nursing home care. Int J Geriatr Psychiatry. Sep. 2009;24(9):970-8. [pmid: 19452499].
te Boekhorst S, Pot AM, Depla M, et al. Group living homes for older people with dementia: the effects on psychological distress of informal caregivers. Aging Ment Health. Nov. 2008;12(6):761-8. [pmid: 19023727].
Thorgrimsen L, Schweitzer P, Orrell M. Evaluating reminiscence for people with dementia: a pilot study. The Arts in Psychotherapy. 2002;29(2):93-7.
Torrington J. What has architecture got to do with dementia care?: Explorations of the relationship between quality of life and building design in two EQUAL projects. Quality in Ageing and Older Adults. 2006;7(1):34-48.
Verbeek H, Zwakhalen SM, van Rossum E, et al. Dementia care redesigned: Effects of small-scale living facilities on residents, their family caregivers, and staff. J Am Med Dir Assoc. Nov. 2010;11(9):662-70. [pmid: 21030001].
Verkaik R, van Weert JC, Francke AL. The effects of psychosocial methods on depressed, aggressive and apathetic behaviors of people with dementia: a systematic review. Int J Geriatr Psychiatry. Apr. 2005;20(4):301-14. [pmid: 15799081].
Wells D, Dawson P, Sidani S, et al. The benefits of abilities-focused morning care for residents with dementia and their caregivers. Perspectives (Gerontological Nursing Association (Canada)). 2000:17. [pmid: 12026330].
Wells DL, Dawson P, Sidani S, et al. Effects of an abilities-focused program of morning care on residents who have dementia and on caregivers. J Am Geriatr Soc. Apr. 2000;48(4):442-9. [pmid: 10798473].
Wetzels RB, Zuidema SU, de Jonghe JF, et al. Prescribing pattern of psychotropic drugs in nursing home residents with dementia. Int Psychogeriatr. Oct. 2011;23(8):1249-59. [pmid: 21682938].
Willemse BM, Smit D, de Lange J, et al. Nursing home care for people with dementia and residents' quality of life, quality of care and staff well-being: design of the Living Arrangements for people with Dementia (LAD)-study. BMC geriatrics. 2011:11. [pmid: 21414185].
Wimo A, Nelvig A, Nelvig J, et al. Can changes in ward routines affect the severity of dementia? A controlled prospective study. Int Psychogeriatr. Fall. 1993;5(2):169-80. [pmid: 8292770].
Wright F. The role of family care-givers for an older person resident in a care home. The British journal of social work. 2000;30(5):649.
Young KW, Greenwood CE, van Reekum R, et al. A randomized, crossover trial of high-carbohydrate foods in nursing home residents with Alzheimer's disease: associations among intervention response, body mass index, and behavioral and cognitive function. J Gerontol A Biol Sci Med Sci. Aug. 2005;60(8):1039-45. [pmid: 16127110].
Ziv N, Granot A, Hai S, et al. The effect of background stimulative music on behavior in Alzheimer's patients. J Music Ther. Winter. 2007;44(4):329-43. [pmid: 17997624].

## Excluded for Small Sample Size

Alexander BJ, Plank P, Carlson MB, et al. Methods of pain assessment in residents of long-term care facilities: a pilot study. J Am Med Dir Assoc. Mar-Apr. 2005;6(2):137-43. [pmid: 15871890].
Altus DE, Engelman KK, Mathews RM. Finding a practical method to increase engagement of residents on a dementia care unit. Am J Alzheimers Dis Other Demen. Jul-Aug. 2002;17(4):245-8. [pmid: 12184514].
Anderson KH, Hobson A, Steiner P, et al. Patients with dementia involving families to maximize nursing care. J Gerontol Nurs. Jul. 1992;18(7):19-25. [pmid: 1629528].
Churchill M, Safaoui J, McCabe BW, et al. Using a therapy dog to alleviate the agitation and desocialization of people with Alzheimer's disease. J Psychosoc Nurs Ment Health Serv. Apr. 1999;37(4):16-22. [pmid: 10218187].
Cohen-Mansfield J, Werner P. The effects of an enhanced environment on nursing home residents who pace. Gerontologist. Apr. 1998;38(2):199-208. [pmid: 9573664].
Connell BR, Sanford JA, Lewis D. Therapeutic effects of an outdoor activity program on nursing home residents with dementia. Journal of Housing for the Elderly. 2007;21(3-4):195-209.
Denney A. Quiet music: an intervention for mealtime agitation?. J Gerontol Nurs. 1997;23(7):16-23. [pmid: 9287602].
Dickinson JI, McLain-Kark J, Marshall-Baker A. The effects of visual barriers on exiting behavior in a dementia care unit. Gerontologist. 1995;35(1):127-30. [pmid: 7890199].
Kincaid C, Peacock JR. Effect of a wall mural on decreasing four types of door-testing behaviors. J Appl Gerontol. 2003;22(1):76-88.
Kolanowski AM, Buettner L, Costa PT, et al. Capturing Interests: Therapeutic Activities for Persons with Dementia. Therapeutic recreation journal. 2001;35:220-35.
Kutner NG, Mistretta EF, Barnhart HX, et al. Family members' perceptions of quality of life change in dementia SCU residents. J Appl Gerontol. 1999;18(4):423-39.
Mathews RM, Clair AA, Kosloski K. Keeping the beat: use of rhythmic music during exercise activities for the elderly with dementia. Am J Alzheimers Dis Other Demen. Nov-Dec. 2001;16(6):377-80. [pmid: 11765863].
Milev RV, Kellar T, McLean M, et al. Multisensory stimulation for elderly with dementia: a 24-week single-blind randomized controlled pilot study. Am J Alzheimers Dis Other Demen. Aug-Sep. 2008;23(4):372-6. [pmid: 18453647].
Monahan DJ. Informal caregivers of institutionalized dementia residents: predictors of burden. Journal of Gerontological Social Work. 1995;23(3-4):63-82.
Namazi KH, Johnson BD. Physical environmental cues to reduce the problems of incontinence in Alzheimer's disease units. American Journal of Alzheimer's Care and Related Disorders and Research. 1991;6(6):22-8.
Namazi KH, Johnson BD. Environmental effects on incontinence problems in Alzheimer's disease patients. American Journal of Alzheimer's Care and Related Disorders and Research. 1991;6(6):16-21.
Namazi KH, Johnson BD. Environmental issues related to visibility and consumption of food in an Alzheimer's disease unit. American Journal of Alzheimer's Care and Related Disorders and Research. 1992;7(1):30-4.
Namazi KH, Rosner TT, Rechlin L. Long-term memory cuing to reduce visuo-spatial disorientation in Alzheimer's disease patients in a special care unit. American Journal of Alzheimer's Care and Related Disorders and Research. 1991;6(6):10-5.
Nolan BA, Mathews RM. Facilitating resident information seeking regarding meals in a special care unit: an environmental design intervention. J Gerontol Nurs. Oct. 2004;30(10):12-6. quiz 55-6. [pmid: 15515440].
Oleson M, Torgerud R, Bernette D, et al. Improving nursing home quality of life: residents helping residents. AJA. 1998;13(3):138-45.
Orsulic-Jeras S, Schneider NM, Camp CJ. Special feature: Montessori-based activities for long-term care residents with dementia. Topics in Geriatric Rehabilitation. 2000;16(1):78-91.
Rabinovich BA, Cohen-Mansfield J. Impact of participation in structured recreational activities on the agitated behavior of nursing home residents: an observational study. Activities, Adaptation and Aging. 1992;16(4):89-98.
Saxton J, Silverman M, Ricci E, et al. Maintenance of mobility in residents of an Alzheimer special care facility. Int Psychogeriatr. Jun. 1998;10(2):213-24. [pmid: 9677508].
Schnelle JF, Newman DR, White M, et al. Reducing and managing restraints in long-term-care facilities. J Am Geriatr Soc. 1992:381-5. [pmid: 1556366].
Snyder M, Egan EC, Burns KR. Interventions for decreasing agitation behaviors in persons with dementia. J Gerontol Nurs. Jul. 1995;21(7):34-40. [pmid: 7615916].
Swanson EA, Maas ML, Buckwalter KC. Alzheimer's residents' cognitive and functional measures: special and traditional care unit comparison. Clin Nurs Res. Feb. 1994;3(1):27-41. [pmid: 8167575].
Thomas DW, Glogoski C, Johnson J. Effect of a supervised walking program on wandering among residents with dementia. Activities, Adaptation and Aging. 2007;30(4):1-13.
Walters D. Effect of multi-sensory ministry on the affect and engagement of women with dementia. Dementia. 2007;6(2):233-43.

## Excluded for Data prior to 1990

Balderston C, Negley EN, Kelly GR, et al. Data-based interventions to reduce assaults by geriatric inpatients. Hosp Community Psychiatry. Apr. 1990;41(4):447-9. [pmid: 2110112].
Coleman EA, Barbaccia JC, Croughan-Minihane MS. Hospitalization rates in nursing home residents with dementia. A pilot study of the impact of a special care unit. J Am Geriatr Soc. Feb. 1990;38(2):108-12. [pmid: 2299114].
Day K, Carreon D, Stump C. The therapeutic design of environments for people with dementia: a review of the empirical research. Gerontologist. Aug. 2000;40(4):397-416. [pmid: 10961029].
Holmes D, Teresi J, Weiner A, et al. Impacts associated with special care units in long-term care facilities. Gerontologist. 1990;30(2):178-82. [pmid: 2189792].
Hopp F. Patterns and predictors of formal and informal care among elderly persons living in board and care homes. Gerontologist. April. 1. 1999;39(2):167-76. [pmid: 10224713].
Rovner BW, Lucas-Blaustein J, Folstein MF, et al. Stability over one year in patients admitted to a nursing home dementia unit. Int J Geriatr Psychiatry. 1990;5(2):77-82.
Timko C, Nguyen AT, Williford WO, et al. Quality of care and outcomes of chronic mentally ill patients in hospitals and nursing homes. Hosp Community Psychiatry. Mar. 1993;44(3):241-6. [pmid: 8444434].

## Poor Quality Studies

Chapman DG, Toseland RW. Effectiveness of advanced illness care teams for nursing home residents with dementia. Soc Work. Oct. 2007;52(4):321-9. [pmid: 18232242].
Cohen CI, Hyland K, Devlin M. An evaluation of the use of the natural helping network model to enhance the well-being of nursing home residents. Gerontologist. Aug. 1999;39(4):426-33. [pmid: 10495580].
Cohen CI, Hyland K, Kimhy D. The utility of mandatory depression screening of dementia patients in nursing homes. Am J Psychiatry. Nov. 2003;160(11):2012-7. [pmid: 14594749].
Dowling GA, Graf CL, Hubbard EM, et al. Light treatment for neuropsychiatric behaviors in Alzheimer's disease. West J Nurs Res. Dec. 2007;29(8):961-75. [pmid: 17596638].
Holmes D, Teresi JA, Ramirez M, et al. An evaluation of a monitoring system intervention: falls, injuries, and affect in nursing homes. Clin Nurs Res. Nov. 2007;16(4):317-35. [pmid: 17991911].
Jablonski RA, Reed D, Maas ML. Care intervention for older adults with Alzheimer's disease and related dementias: effect of family involvement on cognitive and functional outcomes in nursing homes. J Gerontol Nurs. Jun. 2005;31(6):38-48. [pmid: 16138529].
Lawton MP, Van Haitsma K, Klapper J, et al. A stimulation-retreat special care unit for elders with dementing illness. Int Psychogeriatr. Dec. 1998;10(4):379-95. [pmid: 9924833].
Lord TR, Garner JE. Effects of music on Alzheimer patients. Percept Mot Skills. Apr. 1993;76(2):451-5. [pmid: 8483655].
Maas ML, Reed D, Park M, et al. Outcomes of family involvement in care intervention for caregivers of individuals with dementia. Nurs Res. Mar-Apr. 2004;53(2):76-86. [pmid: 15084992].
McCallion P, Toseland RW, Freeman K. An evaluation of a family visit education program. J Am Geriatr Soc. Feb. 1999;47(2):203-14. [pmid: 9988292].
Moyer DM, Gilson A. Theoretical perspective concerning effects of environment on SDAT patients as a function of cognitive and behavioral functioning. AJA. 1996;11(5):32-8.
Reichenbach VR, Kirchman MM. Effects of a multi-strategy program upon elderly with organic brain syndrome. Phys Occup Ther Geriatr. 1991;9(3-4):131-51.
Robison J, Curry L, Gruman C, et al. Partners in caregiving in a special care environment: cooperative communication between staff and families on dementia units. Gerontologist. Aug. 2007;47(4):504-15. [pmid: 17766671].
Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. [pmid: 7490386].
Volicer L, Collard A, Hurley A, et al. Impact of special care unit for patients with advanced Alzheimer's disease on patients' discomfort and costs. J Am Geriatr Soc. Jun. 1994;42(6):597-603. [pmid: 7515405].