# Search Strategy

We outline our search strategies by database below.

## Initial Search

We performed the initial searches on July 15, 2011.

Table A-1 MEDLINE^®^

Search | Queries | Result
#1 | Search “dementia”[MeSH Terms] OR “dementia”[All Fields] OR “alzheimer disease”[MeSH Terms] OR “alzheimer”[All Fields] OR “alzheimer disease”[All Fields] | 124861
#2 | Search #1 Limits: Humans, English | 96335
#3 | Search “Assisted Living Facilities”[MeSH Terms] | 653
#4 | Search #2 AND #3 | 126
#5 | Search “Nursing Homes”[MeSH Terms] | 28793
#6 | Search #2 AND #5 | 2508
#7 | Search “Long-Term Care”[MeSH Terms] | 19577
#8 | Search #2 AND #7 | 892
#9 | Search “Group Homes”[MeSH Terms] | 746
#10 | Search #2 AND #9 | 56
#11 | Search “Homes for the Aged”[MeSH Terms] | 9773
#12 | Search #2 AND #11 | 1099
#13 | Search “Housing for the Elderly”[MeSH Terms] | 1336
#14 | Search #2 AND #13 | 72
#15 | Search “Institutionalization”[MeSH Terms] | 7326
#16 | Search #2 AND #15 | 545
#17 | Search “long term care”[tiab] | 12016
#18 | Search #2 AND #17 | 862
#19 | Search “residential care”[tiab] | 1588
#20 | Search #2 AND #19 | 196
#21 | Search “institutional care”[tiab] | 1252
#22 | Search #2 AND #21 | 142
#23 | Search skilled nursing facilit* | 3995
#24 | Search #2 AND #23 | 162
#25 | Search group home* | 1122
#26 | Search #2 AND #25 | 69
#27 | Search nursing home* | 32683
#28 | Search #2 AND #27 | 3181
#29 | Search assist* living | 27313
#30 | Search #2 AND #29 | 782
#31 | Search “Wellspring” | 38
#32 | Search #2 AND #31 | 1
#33 | Search Eden alternative* | 18
#34 | Search #2 AND #33 | 0
#35 | Search green house* | 173
#36 | Search #2 AND #35 | 1
#37 | Search green home* | 7
#38 | Search #2 AND #37 | 0
#39 | Search #4 OR #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 OR #22 OR #24 OR #26 OR #28 OR #30 OR #32 OR #34 OR #36 OR #38 | 5250
#40 | Search #39 Limits: Editorial, Letter, Addresses, Autobiography, Bibliography, Biography, Case Reports, Comment, Congresses, Consensus Development Conference, Consensus Development Conference, NIH, Dictionary, Directory, Festschrift, In Vitro, Interactive Tutorial, Interview, Lectures, Legal Cases, Legislation, Patient Education Handout, Periodical Index, Portraits, Scientific Integrity Review, Video-Audio Media, Webcasts | 477
#41 | Search #39 NOT #40 | | 4773
#42 | Search #41 Limits: Middle Aged: 45-64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years | | 4128
#43 | Search ((#42) AND “1990/01/01”[Publication Date] : “3000”[Publication Date]) AND “0”[Publication Date] : “3000”[Publication Date] Sort by: Author | | 3646

Table A-2 Cochrane Database

ID | Search | Hits
#1 | “dementia”[MeSH Terms] OR “dementia”[All Fields] OR “alzheimer disease”[MeSH Terms] OR “alzheimer”[All Fields] OR “alzheimer disease”[All Fields] | 9351
#2 | “Assisted Living Facilities”[MeSH Terms] | 38
#3 | “Nursing Homes”[MeSH Terms] | 1217
#4 | “Long-Term Care”[MeSH Terms] | 2229
#5 | “Group Homes”[MeSH Terms] | 64
#6 | “Homes for the Aged”[MeSH Terms] | 415
#7 | “Housing for the Elderly”[MeSH Terms] | 34
#8 | “Institutionalization”[MeSH Terms] | 308
#9 | “long term care”[tiab] | 2229
#10 | “residential care”[tiab] | 281
#11 | “institutional care”[tiab] | 193
#12 | skilled nursing facilit* | 191
#13 | group home* | 16569
#14 | nursing home* | 4813
#15 | assist* living | 2258
#16 | Wellspring | 1
#17 | Eden alternative* | 30
#18 | green house* | 87
#19 | green home* | 217
#20 | (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19) | 20704
#21 | (#1 AND #20) | 1263
#22 | (#21), from 1990 to 2011 | 1220
#23 | “Humans”[Mesh] | 412650
#24 | (#22 AND #23) | 921
#25 | (#24) | 916

Table A-3 CINAHL, AgeLine, PsycINFO

# | Query | Limiters/Expanders | Last Run Via | Results
S29 | S27 and S28 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 1890
S28 | DE “United States” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 238126
S27 | S25 and S26 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 2786
S26 | DE “Older Adults” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 102053
S25 | S4 and S23 | Limiters - English Language; Exclude MEDLINE records; Human; Language: English; Publication Year from: 1990-2011; Publication Type: Journal article; Publication Year from: 1990-2011; English; Language: English; Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 6791
S24 | S4 and S23 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 11975
S23 | S5 or S6 or S7 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 94213
S22 | green home* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 80
S21 | green house* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 87
S20 | Eden alternative* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 100
S19 | “Wellspring” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 115
S18 | assist* living | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 5359
S17 | nursing home* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 48507
S16 | group home* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 5106
S15 | skilled nursing facilit* | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 3417
S14 | “institutional care” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 4684
S13 | “residential care” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 16659
S12 | “long term care” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 34904
S11 | “Institutionalization” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 9680
S10 | “Housing for the Elderly” | Search modes - Boolean/Phrase | Interface - EBSCOhost Search Screen - Advanced Search Database - CINAHL with Full Text;AgeLine;PsycINFO | 2288

Table A-4 EMBASE Database Search

ID | Search | Results
2 | ‘dementia’/exp/mj | 119986
3 | ‘alzheimer disease’/exp/mj | 60262
4 | #2 OR #3 | 119986
6 | ‘nursing home’/exp/mj OR ‘long term care’/exp/mj OR ‘residential home’/exp/mj OR ‘home for the aged’/exp/mj OR ‘institutionalization’/exp/mj OR ‘residential care’/exp/mj OR ‘institutional care’/exp/mj OR ‘skilled nursing facility’ OR ‘assisted living facility’/exp | 60593
7 | #4 AND #6 | 1684
8 | #4 AND #6 AND (‘article’/it OR ‘article in press’/it OR ‘conference abstract’/it OR ‘conference paper’/it OR ‘review’/it) | 1514
9 | #8 AND [humans]/lim AND [english]/lim AND ([embase]/lim OR [embase classic]/lim) AND [1990-2012]/py | 543

Total number of records identified: 5,589

## Update Search

We performed update searches from March 21 - 23, 2012.

PubMed: 21 March 2012

Search | Query | Items found
#1 | Search “dementia”[MeSH Terms] OR “dementia”[All Fields] OR “alzheimer disease”[MeSH Terms] OR “alzheimer”[All Fields] OR “alzheimer disease”[All Fields] | 130527
#2 | Search #1 Limits: Humans, English | 100658
#3 | Search “Assisted Living Facilities”[MeSH Terms] | 694
#4 | Search #2 AND #3 | 132
#5 | Search “Nursing Homes”[MeSH Terms] | 29462
#6 | Search #2 AND #5 | 2622
#7 | Search “Long-Term Care”[MeSH Terms] | 20040
#8 | Search #2 AND #7 | 931
#9 | Search “Group Homes”[MeSH Terms] | 772
#10 | Search #2 AND #9 | 60
#11 | Search “Homes for the Aged”[MeSH Terms] | 10039
#12 | Search #2 AND #11 | 1144
#13 | Search “Housing for the Elderly”[MeSH Terms] | 1361
#14 | Search #2 AND #13 | 74
#15 | Search “Institutionalization”[MeSH Terms] | 7436
#16 | Search #2 AND #15 | 558
#17 | Search “long term care”[tiab] | 12478
#18 | Search #2 AND #17 | 919
#19 | Search “residential care”[tiab] | 1679
#20 | Search #2 AND #19 | 209
#21 | Search “institutional care”[tiab] | 1301
#22 | Search #2 AND #21 | 147
#23 | Search skilled nursing facilit* | 4094
#24 | Search #2 AND #23 | 164
#25 | Search group home* | 1159
#26 | Search #2 AND #25 | 73
#27 | Search nursing home* | 33580
#28 | Search #2 AND #27 | 3336
#29 | Search assist* living | 29200
#30 | Search #2 AND #29 | 831
#31 | Search “Wellspring” | 40
#32 | Search #2 AND #31 | 1
#33 | Search Eden alternative* | 19
#34 | Search #2 AND #33 | 0
#35 | Search green house* | 182
#36 | Search #2 AND #35 | 1
#37 | Search green home* | 7
#38 | Search #2 AND #37 | 0
#39 | Search #4 OR #6 OR #8 OR #10 OR #12 OR #14 OR #16 OR #18 OR #20 OR #22 OR #24 OR #26 OR #28 OR #30 OR #32 OR #34 OR #36 OR #38 | 5503
#40 | Search #39 Limits: Editorial, Letter, Addresses, Autobiography, Bibliography, Biography, Case Reports, Comment, Congresses, Consensus Development Conference, Consensus Development Conference, NIH, Dictionary, Directory, Festschrift, In Vitro, Interactive Tutorial, Interview, Lectures, Legal Cases, Legislation, Patient Education Handout, Periodical Index, Portraits, Scientific Integrity Review, Video-Audio Media, Webcasts | 492
#41 | Search #39 NOT #40 | 5011
#42 | Search #41 Limits: Middle Aged: 45-64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years | 4326
#43 | Search (#42) AND (“2011/04/01”[Date - Entrez] : “3000”[Date - Entrez]) | 142

Cochrane: 21 March 2012

ID | Search | Hits
#1 | “dementia”[MeSH Terms] OR “dementia”[All Fields] OR “alzheimer disease”[MeSH Terms] OR “alzheimer”[All Fields] OR “alzheimer disease”[All Fields] | 9771
#2 | “Assisted Living Facilities”[MeSH Terms] | 45
#3 | “Nursing Homes”[MeSH Terms] | 1328
#4 | “Long-Term Care”[MeSH Terms] | 2445
#5 | “Group Homes”[MeSH Terms] | 68
#6 | “Homes for the Aged”[MeSH Terms] | 436
#7 | “Housing for the Elderly”[MeSH Terms] | 37
#8 | “Institutionalization”[MeSH Terms] | 334
#9 | “long term care”[tiab] | 2445
#10 | “residential care”[tiab] | 330
#11 | “institutional care”[tiab] | 210
#12 | skilled nursing facilit* | 254
#13 | group home* | 17986
#14 | nursing home* | 5656
#15 | assist* living | 2978
#16 | Wellspring | 1
#17 | Eden alternative* | 57
#18 | green house* | 679
#19 | green home* | 1714
#20 | (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17 OR #18 OR #19) | 22643
#21 | (#1 AND #20) | 1529
#22 | (#21), from 2011 to 2012 | 191
#23 | “Humans”[Mesh] | 429201
#24 | (#22 AND #23) | 171

CINAHL, AgeLine, PsycINFO: 23 March 2012

# | Query | Results
S28 | S27 Limiters - Published Date from: 20110701-20120431; English Language; Human; Language: English; Age Groups: All Adult; Publication Year from: 2011-2012; Publication Type: Journal Article; Publication Year from: 2011-2012; English; Age Groups: Adulthood (18 yrs & older); Population Group: Human; Exclude Dissertations Search modes - Boolean/Phrase | 10
S27 | S23 and S26 | 1995
S26 | S24 or S25 | 416805
S25 | DE “United States” | 245288
S24 | (MH “United States+”) | 332536
S23 | S20 and S21 and S22 | 5348
S22 | S18 or S19 | 692901
S21 | S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 | 113110
S20 | S1 or S2 or S3 or S4 | 83188
S19 | DE “Older Adults” | 102212
S18 | (MH “Adult+”) OR (MH “Frail Elderly”) | 590689
S17 | DE “Long Term Care” | 25056
S16 | (MH “Residential Care+”) | 4106
S15 | (MH “Institutionalization+”) | 57237
S14 | DE “Institutionalization” | 5718
S13 | (MH “Housing for the Elderly”) | 1593
S12 | DE “Homes for the Elderly” | 670
S11 | (MH “Long Term Care”) | 14191
S10 | DE “Nursing Homes” | 27470
S9 | (MH “Nursing Homes+”) | 14695
S8 | DE “Assisted Living Facilities” | 1492
S7 | DE “Assisted Living” | 1919
S6 | “assisted living” | 4760
S5 | (MH “Assisted Living”) | 1518
S4 | DE “Dementia” | 44708
S3 | (DE “Dementia” OR DE “AIDS Dementia Complex” OR DE “Dementia with Lewy Bodies” OR DE “Presenile Dementia” OR DE “Semantic Dementia” OR DE “Senile Dementia” OR DE “Vascular Dementia”) | 48489
S2 | (MH “Dementia+”) | 28434
S1 | Dementia | 73994

EMBASE: 23 March 2012

ID | Search | Results
1 | ‘dementia’/exp/mj | 128,476
2 | ‘alzheimer disease’/exp/mj | 64,758
3 | #1 OR #2 | 128,476
4 | ‘nursing home’/exp/mj OR ‘long term care’/exp/mj OR ‘residential home’/exp/mj OR home for the aged’/exp/mj OR ‘institutionalization’/exp/mj OR ‘residential care’/exp/mj OR ‘institutional care’/exp/mj OR ‘skilled nursing facility’ OR ‘assisted living facility’/exp | 64,845
5 | #3 AND #4 | 1,823
6 | #5 AND ([adult]/lim OR [aged]/lim) AND [humans]/lim AND [english]/lim AND [1-7-2011]/sd NOT [31-3-2012]/sd | 71

Total number of records identified: 353

## Handsearches

Handsearches of the following references yielded 341 additional records.

- Alessi CA, Schnelle JF. Approach to sleep disorders in the nursing home setting. REVIEW ARTICLE. Sleep Med Rev. Feb. 2000;4(1):45-56. [pmid: 12531160].
- Allen-Burge R, Stevens AB, Burgio LD. Effective behavioral interventions for decreasing dementia-related challenging behavior in nursing homes. Int J Geriatr Psychiatry. Mar. 1999;14(3):213-28. discussion 28-32. [pmid: 10202663].
- Aoyama L, Weintraub N, Reuben DB. Is weight loss in the nursing home a reversible problem?. Journal of the American Medical Directors Association. 2005;6(4):250-6. [pmid: 16005411].
- Blasi ZV, Hurley AC, Volicer L. End-of-life care in dementia: a review of problems, prospects, and solutions in practice. Journal of the American Medical Directors Association. 2002;3(2):57-65. [pmid: 12807540].
- Cunje A, Molloy DW, Standish TI, et al. Alternate forms of logical memory and verbal fluency tasks for repeated testing in early cognitive changes. Int Psychogeriatr. Feb. 2007;19(1):65-75. [pmid: 16684396].
- Day K, Carreon D, Stump C. The therapeutic design of environments for people with dementia: a review of the empirical research. Gerontologist. Aug. 2000;40(4):397-416. [pmid: 10961029].
- DiBartolo MC. Careful hand feeding: a reasonable alternative to PEG tube placement in individuals with dementia. J Gerontol Nurs. 2006;32(5):25-33. [pmid: 16708981].
- Doyle CJP. Social interventions to manage mental disorders of the elderly in long-term care. Australian Psychologist. 1993;28(1):25-30.
- Finkel SI. Behavioral and psychological signs and symptoms of dementia: implications for research and treatment. Int Psychogeriatr. 1996;8(Suppl. 3):215-542. [pmid: 9221032].
- Finnema E, Droes RM, Ribbe M, et al. The effects of emotion-oriented approaches in the care for persons suffering from dementia: a review of the literature (Structured abstract). Int J Geriatr Psychiatry. 2000:141-61. [pmid: 10679846].
- Fleming R, Purandare N. Long-term care for people with dementia: environmental design guidelines. Int Psychogeriatr. Nov. 2010;22(7):1084-96. [pmid: 20478095].
- Forbes D, Morgan DG, Bangma J, et al. Light therapy for managing sleep, behaviour, and mood disturbances in dementia. Cochrane Database Syst Rev. 2004;(2):CD003946. [pmid: 15106228].
- Forbes DA. Strategies for managing behavioural symptomatology associated with dementia of the Alzheimer type: a systematic overview (Structured abstract). Can J Nurs Res. 1998:67-86. [pmid: 9807289].
- Gaugler JE. Family involvement in residential long-term care: a synthesis and critical review. Aging Ment Health. Mar. 2005;9(2):105-18. [pmid: 15804627].
- Gaugler JE, Kane RL. Families and Assisted Living. Gerontologist. 2007;47:83-99.
- Hall S, Kolliakou A, Petkova H, et al. Interventions for improving palliative care for older people living in nursing care homes. Cochrane Database Syst Rev. 2011;(3):CD007132. [pmid: 21412898].
- Jorm AF. The epidemiology of depressive states in the elderly: implications for recognition, intervention and prevention. Soc Psychiatry Psychiatr Epidemiol. Mar. 1995;30(2):53-9. [pmid: 7754416].
- Konetzka RT, Spector W, Limcangco MR. Reducing hospitalizations from long-term care settings. Med Care Res Rev. Feb. 2008;65(1):40-66. [pmid: 17895516].
- Kong EH, Evans LK, Guevara JP. Nonpharmacological intervention for agitation in dementia: a systematic review and meta-analysis (Structured abstract). Aging and Mental Health. 2009:512-20. [pmid: 19629775].
- Lai CK, Yeung JH, Mok V, et al. Special care units for dementia individuals with behavioural problems. Cochrane Database Syst Rev. 2009;(4):CD006470. [pmid: 19821370].
- Livingston G, Johnston K, Katona C, et al. Systematic review of psychological approaches to the management of neuropsychiatric symptoms of dementia. Am J Psychiatry. Nov. 2005;162(11):1996-2021. [pmid: 16263837].
- Lum TY, Kane RA, Cutler LJ, et al. Effects of Green House nursing homes on residents' families. Health Care Financ Rev. Winter. 2008;30(2):35-51. [pmid: 19361115].
- Olazaran J, Reisberg B, Clare L, et al. Nonpharmacological therapies in Alzheimer's disease: a systematic review of efficacy. Dement Geriatr Cogn Disord. 2010;30(2):161-78. [pmid: 20838046].
- Oliver D, Connelly JB, Victor CR, et al. Strategies to prevent falls and fractures in hospitals and care homes and effect of cognitive impairment: systematic review and meta-analyses. BMJ. Jan. 13. 2007;334(7584):82. [pmid: 17158580].
- Opie J, Rosewarne R, O'Connor DW. The efficacy of psychosocial approaches to behaviour disorders in dementia: a systematic literature review (Structured abstract). Aust N Z J Psychiatry. 1999:789-99. [pmid: 10619204].
- Ostaszkiewicz J, Johnston L, Roe B. Timed voiding for the management of urinary incontinence in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
- Price James D, Hermans D, Grimley Evans J. Subjective barriers to prevent wandering of cognitively impaired people, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
- Rahman A, Straker JK, Manning L. Staff assignment practices in nursing homes: review of the literature. J Am Med Dir Assoc. Jan. 2009;10(1):4-10. [pmid: 19111847].
- Roberts J, Browne G, Gafni A, et al. Specialized continuing care models for persons with dementia: a systematic review of the research literature. Canadian Journal on Aging. 2000;19(1):106-26.
- Rosenblatt A, Samus QM, Steele CD, et al. The Maryland Assisted Living Study: prevalence, recognition, and treatment of dementia and other psychiatric disorders in the assisted living population of central Maryland. J Am Geriatr Soc. Oct. 2004;52(10):1618-25. [pmid: 15450036].
- Vasse E, Vernooij-Dassen M, Spijker A, et al. A systematic review of communication strategies for people with dementia in residential and nursing homes. Int Psychogeriatr. Mar. 2010;22(2):189-200. [pmid: 19638257].
- Verkaik R, van Weert JC, Francke AL. The effects of psychosocial methods on depressed, aggressive and apathetic behaviors of people with dementia: a systematic review. Int J Geriatr Psychiatry. Apr. 2005;20(4):301-14. [pmid: 15799081].
- Zimmerman S, Cohen LW. Evidence behind The Green House and similar models of nursing home care. Aging Health. 2010;6(6):717-37.

Total references from initial and update search and handsearches after duplicates removed=6,209.