# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officers, Stephanie Chang, M.D. and Beth A. Collins Sharp, Ph.D., R.N, and that of the former Task Order Officer, Sonia Tyutyulkova, M.D., Ph.D., as well as our Associate Editor, Melissa McPheeters, Ph.D., M.P.H. We extend our appreciation to our Key Informants and members of our Technical Expert Panel, all of whom provided thoughtful advice and input during our research process.

The investigators deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at RTI International–University of North Carolina Evidence-based Practice Center. We express our gratitude to the following individuals for their contributions to this project: Carol Woodell, B.S.P.H., our Project Manager; Megan Van Noord, M.S.L.S., our EPC Librarian; Jennifer Drolet and Carol Offen, our copy editors; Cheryl Miller, MSG; and Loraine Monroe, our EPC publications specialist.