# Results

## Literature Search

Of the 2,000 records identified through the literature search, 1,986 were excluded at various stages of screening and 14 records were included. The PRISMA diagram (Figure 2) depicts the flow of search screening and study selection. We sought, but did not find, nonrandomized comparative studies (observational, case-control, and cohort studies) of populations, comparisons, interventions, and outcomes that were not adequately studied in the randomized controlled trials (RCTs).

Figure 2 PRISMA diagram for identified trials

This figure depicts the PRISMA diagram for identified trials related to key questions. A total of 1644 citations were derived from searching electronic databases. Of these 33 duplicate citations were removed. The title and abstracts of the remaining 1611 citations were screened and 702 citations were excluded. Remaining 909 citations were reviewed in full text and 895 were excluded. Of these 895 excluded, 523 were non relevant design, 82 were non relevant diseases, 108 did not report relevant outcomes, 176 had sample size less than 100, 5 were written in non-English language and 1 did not report primary data. 14 unique articles were identified. Further, 4 additional articles were identified through gray literature and hand search. Thus a total of 18 articles were included in the review.

## Gray Literature Search

We evaluated the results of the gray literature search with results summarized in Figure 3.

- Regulatory information: The search yielded three 510(k) summaries for procalcitonin assay; BRAHMS PCT LIA,8 VIDAS^®^ BRAHMS PCT,9 and BRAHMS PCT sensitive KRYPTOR^®^ Test System.10 Citations in the summary documents were screened against the main bibliographic databases. No new studies were identified from this source.
- Clinical trial registries: Citations for published articles linked to trials registered at ClinicalTrials.gov were included. The search yielded 91 clinical trials of which 89 were excluded during the title and abstract screen: 47 were duplicate (literature citations already included in our reference database), 16 were ongoing studies and 26 met the exclusion criterion (study did not compare procalcitonin-guided antibiotic therapy to an alternative). Two references (Manzano et al., 2010^26^ and Burkhardt et al., 2010^27^) were reviewed in full-text and were included according to the study protocol.
- Abstracts and conference papers: The search yielded 450 citations of which 447 were excluded during the title and abstract screen: 183 references were duplicates and 264 met the exclusion criterion. The three remaining references (Jensen et al., 2011^28^; Rho 2010^29^; Sanches et al., 2010^30^) were randomized studies comparing procalcitonin-guided antibiotic therapy to an alternative. Two of these studies (Rho 2010^29^ and Sanches et al., 2010^30^) were published only as abstracts at international meetings and were, therefore, excluded. The remaining study (Jensen et al., 2011^28^) was included in the report.
- Grants and federally funded research: The search yielded three citations and all three were excluded as they met the exclusion criterion.
- Manufacturer database (SIPs): In response, scientific information packets (SIPs) were received from Thermo Fisher Scientific. The submissions consisted of 67 published references or listings of clinical trials with abstracts; no unpublished data were provided by the company. Of the 67 references, 65 were excluded during abstract and title screen: 52 were duplicate and 12 met the exclusion criterion and one study could not be retrieved. The remaining two references were reviewed in full-text and one was excluded as it met the exclusion criterion. The remaining study (Long et al., 2011^31^) was included in the report.

Figure 3 PRISMA diagram for identified gray literature

ACCP = American College of Chest Physicians; AHRQ GOLD = Agency for Healthcare Research and Quality Grants On-Line Database; CSA = database at www.csa.com; FDA = Food and Drug Administration; HSRPROJ = Health Services Research Projects in Progress; ICAAC = Annual Interscience Conference on Antimicrobial Agents and Chemotherapy; IDSA = Infectious Diseases Society of America; PAS = Annual meeting of Pediatric Academic Societies; PRISMA = Preferred Reporting Items for Systematic Reviews and Meta-Analyses; RePORTER = Research Portfolio Online Reporting Tools; WHO = World Health Organization

PRISMA Diagram for Gray Literature. This figure depicts the PRISMA Diagram for Identified Gray Literature. For regulatory information, FDA website was searched for 510(k) summaries for commercially FDA approved procalcitonin assays. The search yielded three 510(k) summaries for procalcitonin assay. Citations in the summary documents were screened against the main bibliographic databases. No new studies were identified from this source. Four clinical trial registries were searched. These were clinicaltrials.gov, current controlled trials, clinical study results and WHO clinical trials. This search yielded 91 studies. Of these, 47 studies were duplicate, 16 were ongoing and 26 met the exclusion criterion and therefore these 89 references were excluded. Remaining 2 articles were included after a full text review. Six sources for conference abstracts and papers were searched for the gray literature. They were conference papers index or CSA, Scopus, annual meeting of Interscience Conference on Antimicrobial Agents and Chemotherapy or ICAAC, annual meeting of Infectious Diseases Society of America or IDSA, annual meeting of American College of Chest Physicians or ACCP and annual meeting of Pediatric Academic Societies or PAS. The search of these sources yielded 450 citations. Of these, 183 references were duplicate and 264 studies met the exclusion criterion and therefore these 447 references were excluded. Of the remaining 3 references- 2 were further excluded as full text article was unpublished and 1 was included after full-text review. Three sources for grants and federally funded research were searched. The first was NIH RePORTER, which is a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions. The second was HSRPROJ, which is a database providing access to ongoing grants and contracts in health services research. The third was AHRQ GOLD, which is an online searchable database of AHRQ grants, working papers and HHS recovery act projects. The search of all 3 databases yielded 3 citations and all were excluded as they met the exclusion criterion. For identifying gray literature in the manufacturer database, the scientific information packets or SIPs was reviewed. The SIPs supplied by Thermo Fisher Scientific contained 67 published references or listings of clinical trials with abstracts. Of these 52 were duplicate and 12 met the exclusion criterion and one study could not be retrieved. Therefore these 67 references were excluded. Remaining 2 references were reviewed in full-text. One was excluded as it met the exclusion criterion and remaining study was included in the report. Overall the gray literature search resulted in 4 new relevant references to inform this review.

Overall, search of gray literature yielded four published studies26-28,31 that were included in the present evidence review. No unpublished studies meeting eligibility criteria were found.

We reviewed all published RCTs of the use of procalcitonin-guided initiation or discontinuation of antibiotic therapy, as well as studies that used procalcitonin for other interventions in patients with infection and/or sepsis. A total of 18 RCTs were identified for the review. Data abstraction tables can be found in Appendix C. The studies identified looked at very distinct clinical conditions in different patient populations and therefore, we grouped these 18 studies into 5 patient populations. These were: (1) critically ill adult patients in intensive care unit (ICU), including patients with ventilator-associated pneumonia (VAP) and those critically ill with suspected bacterial infections, severe sepsis, and septic shock; (2) patients with symptoms and signs of various respiratory tract infections; (3) neonates with suspected sepsis; (4) children between 1 to 36 months of age with fever of unknown source; and (5) postoperative patients at risk of infection (pre-emptive antibiotic therapy). In addition to being different patient populations with respect to age, underlying diseases, and morbidity and mortality, some studies also differed with respect to the specific algorithms for procalcitonin-guided management. Among these different strategies, one strategy used procalcitonin measurements to discontinue antibiotic therapy, while other strategies used procalcitonin levels to intensify or initiate antibiotic therapy. Sixteen studies27,28,31-44 used a BRAHMS^®^ quantitative procalcitonin assay and remaining two studies26,45 used the BRAHMS semi-quantitative assay. The cutoffs for initiation and discontinuation of therapy were for the most part similar in each group, and many of the studies used similar measures for the outcomes of interest.

We also reviewed ongoing clinical trials that use procalcitonin-guided antibiotic therapy listed at ClinicalTrials.gov. The details of these ongoing trials including sample size, presenting condition, primary and secondary outcomes and expected date of completion are summarized in Appendix D.

## Critically Ill/Ventilator-Associated Pneumonia

There were a total of seven RCTs28,32-35,39,45 comparing procalcitonin-guided therapy with standard antibiotic therapy in this population. Five studies32-35,39 addressed procalcitonin-guided discontinuation of antibiotics. Two studies28,45 addressed procalcitonin-guided intensification of antibiotic therapy.

### Procalcitonin-Guided Antibiotic Discontinuation

#### Study Characteristics

There were five RCTs32-35,39 comparing procalcitonin-guided therapy with standard antibiotic therapy (Table 2). Analyses of outcomes tested superiority of procalcitonin-guided therapy in all but one case: one study39 conducted a noninferiority analysis for mortality. Sample sizes ranged from 27 to 621, with three studies34,35,39 greater than 100. Overall, 938 patients were enrolled into these trials.

Table 2 Summary of characteristics for five trials included in the analysis of procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients

Author, Year, Country | Disease State | N | PCT for ABT Discontinuation | Control Interventions | Study Duration | Predefined Endpoints
Bouadma, 2010, France39 | Critically ill, suspected bacterial infection | PCT 307 Ctrl 314 | PCT <0.5 ng/mL or >/= 80% decrease from peak | Broad-spectrum ABTs started ASAP; de-escalation based on cultures if possible; ABT duration by local and international guidelines | 60 days | Primary outcome mortality, number of days without ABT Secondary ABT exposure, morbidity
Schroeder, 2009, Germany33 | Severe sepsis | PCT 14 Ctrl 13 | PCT ≤1 ng/mL or 25-35% of baseline | Dx of severe sepsis by ACCP guidelines; standard ABT therapy | Not defined | Not defined
Stolz, 2009, Switzerland & USA35 | ICU, VAP | PCT 51 Ctrl 50 | PCT <0.5 ng/mL or decrease of > /= 80% from baseline | VAP Dx by ATS guidelines; standard ABT therapy | 28 days | Primary outcome ABT-free days at day 28
Nobre, 2008, Switzerland32 | Severe sepsis | PCT 39 Ctrl 40 | PCT <0.25 ng/mL or decreased by 90% from baseline | Sepsis, septic shock Dx by ACCP criteria; standard broad-spectrum ABT therapy | 28 days | Primary outcome ABT exposure Secondary outcomes 28 day mortality, ICU LOS, other
Hochreiter, 2009, Germany34 | ICU, sepsis | PCT 57 Ctrl 53 | PCT <1 ng/mL or 25-35% of baseline over 3 days | SIRS Dx by ACCP criteria; standard ABT therapy for 8 days | Not defined | Not defined

ABT = antibiotic; ACCP = American College of Chest Physicians; ASAP = as soon as possible; ATS = American Thoracic Society; Ctrl = control; Dx = diagnosis; ICU = intensive care unit; LOS = length of stay; PCT = procalcitonin; SIRS = systemic inflammatory response syndrome; VAP = ventilator-associated pneumonia

Procalcitonin criteria for discontinuation of antibiotic varied somewhat. Absolute values that prompted antibiotic discontinuation included 0.25, 0.5, and 1 ng/mL. Relative values included 25 to 35 percent of baseline or 80 and 90 percent reductions from baseline. Physicians in the control groups administered antibiotics according to their standard practice. In the largest study by Bouadma et al.,39 local and international guidelines on duration of antibiotic therapy were available on a website. While the lack of specificity about what constituted antibiotic could be viewed as a limitation in study designs, it could also be viewed as a strength regarding applicability to actual practice. Study duration varied, but was for the duration of hospitalization, at least 28 days in three studies,32,35,39 and at 60 days in one study.39

Three studies32,35,39 identified antibiotic use as a primary outcome and two studies33,34 did not mention a primary endpoint. One study39 looked at mortality as a primary outcome, and mortality was a predefined secondary outcome in one other study.32 Mortality data were available from all five studies.

#### Study Quality

The overall rating for three studies32,35,39 was good and fair for the remaining two studies33,34 (Table 3). All studies assembled groups appearing to have similarly distributed potential confounders with no obvious imbalances. Two studies33,34 did not describe their procedure for allocation concealment.

Table 3 Procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients—study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Bouadma, 2010^39^ | Y | Y | Y | Y | Y | Y | Y | Good
Schroeder, 2009^33^ | Y^*^ | Y | Y | Y | Y | Y | Y | Fair
Stolz, 2009^35^ | Y | Y | Y | Y | Y | Y | Y | Good
Nobre, 2008^32^ | Y | Y | Y | Y | Y | Y | Y | Good
Hochreiter, 2009^34^ | Y^*^ | Y | Y | Y | Y | Y | Y | Fair

USPSTF = United States Preventive Services Task Force; Y = yes

* No details on allocation concealment, but groups were comparable

Judgments of whether outcome measurements were equal, valid and reliable usually depend in part on the requirement for blinded outcome assessor. However, in these studies, it was not feasible to blind the treating physicians to the patient's assigned treatment. Decisions on antibiotic use were made by unblinded physicians who could take other clinical information into account and override the algorithm based on their clinical judgment. Procalcitonin guidance is intended as an adjunct to, not a replacement for, clinical criteria for assessing and managing infection. In this setting, we did not require use of a blinded outcome assessor as a dimension of study quality.

Intention-to-treat analyses were consistently performed. One study32 reported both intention-to-treat and per-protocol analyses. The study designed to test noninferiority of mortality in the procalcitonin-guided group was powered to exclude a 10 percent between-group mortality difference. No other studies were powered to detect differences in mortality or morbidity outcomes.

#### Antibiotic Use

Outcomes related to antibiotic use are summarized in Table 4. The duration of antibiotic therapy was reduced in the procalcitonin-guided arm of all five studies.32-35,39 The absolute difference ranged from -1.7 to -5 days, with a percent reduction of 21 to 38 percent. Figure 4 shows the results of a meta-analysis of antibiotic duration. It included three studies33,34,39 that reported sufficient information for pooling and yielded a statistically significant pooled mean difference of 2.05 days (95% CI: -2.59, -1.52) favoring procalcitonin guidance and an I^2^ value of 41 percent, indicating moderate statistical heterogeneity. The two excluded studies32,35 that did not report sufficient information for pooling reported larger effects than the pooled estimate, so including them would have produced a stronger pooled effect favoring procalcitonin guidance. Three studies reported the reduction in antibiotic use in terms of days without antibiotic therapy. Again, this favored procalcitonin-guided therapy, with an additional 2.3 to 3.8 days without antibiotics, an 18 to 37 percent reduction. Three studies32,35,39 reported total antibiotic exposure, which also accounted for the use of multiple agents (intensity), as well as duration of therapy. Total exposure per 1,000 patient-days ranged from 644 to 1,341 for the control groups, with a longer duration seen for VAP, but in all 3 studies total exposure in the procalcitonin-guided arm was reduced by 16 to 20 percent. The study32 that reported both intention-to-treat and per-protocol analyses found statistically significant reductions only with the latter for antibiotic duration, days without antibiotic and total antibiotic exposure. In summary, procalcitonin-guided therapy resulted in consistent reductions in antibiotic use by all measures. The range of reduction in antibiotic use was also similar across studies.

Table 4 Procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients––outcomes related to antibiotic use

Outcome | Author, Year | N | PCT-Guided TherapyΨ | ControlΨ | Difference PCT-CTRL (95% CI) | p-Value
ABT Duration (days) | Hochreiter, 2009^34^ | 110 | 5.9 | 7.9 | -2.0 (-2.5, -1.5) | < 0.001
ABT Duration (days) | Nobre, 2008^32^ | 79 | 6 6 | 9.5 (ITT) 10 (PP) | -2.6 (5.5, -0.3), -3.2 (-1.1,- 5.4) | 0.15 0.003
ABT Duration (days) | Schroeder, 2009^33^ | 27 | 6.6 | 8.3 | -1.7 (-2.4, -1.0) | <0.001
ABT Duration (days) | Stolz, 2009^35^ | 101 | 10 (6-16)^‡^ | 15 (10-23)^‡^ | -5 | 0.049
ABT Duration (days) | Bouadma, 2010^39^ | 621 | 10.3 | 13.3 | -3.0 (-4.20,-1.80) | <0.0001
Days without ABTs (day 28) | Nobre, 2008^32^ | 79 | 15.3 17.4 | 13 13.6 | 2.3 (-5.9, 1.8) 3.8 (0.1, 7.5) § | 0.28 0.04
Days without ABTs (day 28) | Stolz, 2009^35^ | 101 | 13 (2-21)^‡^ | 9.5 (1.5-17)^‡^ | 3.5 | 0.049
Days without ABTs (day 28) | Bouadma, 2010^39^ | 621 | 14.3 | 11.6 | 2.7 (1.4, 4.1) | <0.001
Total ABT exposure^*^ | Nobre, 2008^32^ | 79 | 541 504 | 644 655 | 1.1^**^ (0.9, 1.3) 1.3^**^ (1.1, 1,5)^§^ | 0.07 0.0002
Total ABT exposure^*^ | Stolz, 2009^35^ | 101 | 1077 | 1341
Total ABT exposure^*^ | Bouadma^*^, 2010^39^ | 621 | 653 | 812 | -159 (-185, -131) | <0.001

ABT = antibiotic; CI = confidence interval; CTRL = control; ITT = intention to treat; PCT = procalcitonin; PP = per protocol

* Per 1,000 inpatient days

** Rate ratios

§ Per protocol analysis

Ψ Values are mean unless specified

‡ Median (interquartile range)

Figure 4 Meta-analysis of mean differences, antibiotic duration (days) in critically ill/ventilator-associated pneumonia patients

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the mean difference in the duration of antibiotic use in days between procalcitonin-guided therapy and control in the critically ill/ventilator-associated pneumonia patients. Results show a pooled point estimate of 2.05 day reduction in duration of antibiotic use (95% CI -2.59 to -1.52) favoring the procalcitonin-guided therapy group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between reduction of 2.59 days and a reduction of 1.52 days. There was no statistically significant heterogeneity across the 3 studies that were included.

#### Mortality

Three studies32,35,39 reported 28-day mortality, one study39 reported both 28- and 60-day mortality, two studies32,35 reported in-hospital mortality, and two studies33,34 reported overall mortality (Table 5). Mortality rates at 28 days in control arms ranged from 20 to 24 percent.

Table 5 Procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients––mortality

Outcome | Author, Year | N | Mortality PCT-Guided Therapy | Mortality Control | Difference PCT-CTRL (95% CI) | p-Value
28-day mortality | Nobre, 2008^32^ | 79 | 8/39 (20.5%) 5/31 (16.1%) | 8/40 (20.0%) 6/37 (16.2%) | 0.5 (-17.2, 18.2), -0.1 (-17.7, 17.5) § | 0.95 0.99
28-day mortality | Stolz, 2009^35^ | 101 | 8/51 (15.7%) | 12/50 (24.0%) | -8.3 (-23.8, 7.2) | 0.29
28-day mortality | Bouadma, 2010^39^ | 621 | 65/307 (21.2%) | 64/314 (20.4%) | 0.8 (-5.6, 7.2) | 0.81
60-day mortality | Bouadma, 2010^39^ | 621 | 92/307 (30.0%) | 82/314 (26.1%) | 3.9 (-3.2, 10.9) | 0.29
In-hospital mortality | Nobre, 2008^32^ | 79 | 9/39 (23.1%) 6/31 (19.4%) | 9/40 (22.5%) 7/37 (18.9%) | 0.6 (-17.9, 19.1) 0.4+ (-18.3, 19.2) | 0.95 0.96
In-hospital mortality | Stolz, 2009^35^ | 101 | 10/51 (19.6%) | 14/50 (28.0%) | -8.4, (-24.9, 8.1) | 0.32
In-hospital mortality | Hochreiter, 2009^34^ | 110 | 15/57 (26.3%) | 14/53 (26.4%) | -0.1, (-16.6, 16.4) | 0.99
In-hospital mortality | Schroeder, 2009^33^ | 27 | 3/14 (21.4%) | 3/13 (23.1%) | -1.7, (-33.1, 29.8) | 0.92

CI = confidence interval; CTRL = control; PCT = procalcitonin

§ Per protocol analysis

In one study,33 the reduction in 28-day mortality with procalcitonin-guided therapy was 8.3 percent, and in two studies, mortality increased by 0.5 percent32 and 0.8 percent.39 None of these differences was statistically significant.

Only one study39 reported 60-day mortality. There was a 3.9 percent increase in mortality in the procalcitonin-guided group that was not statistically significant, but procalcitonin-guided therapy met the predefined criteria for noninferiority with respect to 60-day mortality. Additionally, deaths between 28 and 60 days were analyzed, and none was related to relapse of infection. In-hospital mortality was higher in the procalcitonin-guided group by 0.6 percent in one study32 and reduced by 8.4 percent in one study,35 but neither difference reached statistical significance. Overall mortality was slightly reduced in the two studies from 0.1^34^ to 1.7^33^ percent reduction, but the differences were not significant.

Most studies were powered to determine if there was a difference in antibiotic use, and not powered to detect differences in morbidity and mortality. Only the study by Bouadma et al.,39 the largest RCT looking at procalcitonin-guided therapy to date, was powered to determine noninferiority of procalcitonin-guided therapy versus standard care. The study was powered to have an 80 percent power to exclude a 10 percent difference in mortality between groups. Noninferiority was met for 28-day and 60-day mortality in this study, but there is concern whether the 10 percent margin chosen is the appropriate noninferiority margin to assure there is no excess mortality associated with procalcitonin-guided antibiotic therapy in this patient population.

A meta-analysis was performed to pool mortality data from all five studies32-35,39 in order to increase the probability of detecting a significant difference in between-group mortality. Pooling was performed for studies reporting short-term (28-day or in-hospital) mortality. Results show a pooled point estimate of 0.4 percentage point reduction in mortality (95% CI: -6 percent, 5 percent) favoring the procalcitonin-guided therapy group (Figure 5). Statistical heterogeneity, as expressed by the I^2^ statistic, was found to be 0 percent.

Figure 5 Meta-analysis of risk differences, short-term mortality (in-hospital or 28-day) in critically ill/ventilator-associated pneumonia patients

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the risk difference of the probability of short-term mortality (28 day or in-hospital mortality) between procalcitonin-guided therapy and control in the critically ill/ventilator-associated pneumonia patients. Results show a pooled point estimate of 4 percentage point reduction in mortality (95% CI -6% to 5%) favoring the procalcitonin-guided therapy group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between reduction by 6 percentage point and increase by 5 percentage point. There was no statistically significant heterogeneity across the 5 studies that were included.

#### Morbidity

Three studies32,35,39 evaluated hospital length of stay (LOS), four studies32-34,39 evaluated ICU LOS, one study35 evaluated ICU-free days alive, three studies33,34,39 evaluated some type of severity of illness score, and three studies35,39 reported on days without mechanical ventilation (Table 6). Hospital LOS was reduced by 0 to 2.5 days in the procalcitonin-guided arms. This represents a 0 to 11 percent reduction in LOS, but the difference was not statistically significant in any of the studies. ICU LOS similarly was reduced by 0.3 to 4.6 days in three studies, and increased by 1.5 days in another study. The only study reporting a significant decrease in ICU LOS was the Nobre study32 of severe sepsis and septic shock, where ICU LOS was reduced by 43 percent. The study by Stolz35 found that the difference in ICU-free days alive within 28 days was higher by 1.5 days in the procalcitonin-guided therapy group, but it was not statistically significant. Among studies reporting severity of illness scales, there was a small difference in severity that favored procalcitonin-guided therapy in two33,34 out of three33,34,39 studies, but the differences were not significant. Only one study39 showed a significant increase in the severity of illness at 28 days, but the difference was minimal and the absolute severity scores were extremely low for both groups. One study39 reported a reduction in mechanical ventilation and one study35 reported an increase in mechanical ventilation, but none of the differences was significant.

Table 6 Procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients––morbidity

Outcome | Author, Year | N | PCTΨ | ControlΨ | Difference, PCT-CTRL (95% CI) | p-Value
LOS (days) | Nobre, 2008^32^ | 79 | 17 | 23.5 | -2.5 (-6.5, 1.5) | 0.85
LOS (days) | Stolz, 2009^35^ | 101 | 26 (7-21)^‡^ | 26 (16.8-22.3)^‡^ | 0 | 0.15
LOS (days) | Bouadma, 2010^39^ | 621 | 26.1 | 26.4 | -0.3 (-3.2, 2.7) | 0.87
ICU LOS (days) | Hochreiter, 2009^34^ | 110 | 15.5 | 17.7 | -2.2 | 0.046
ICU LOS (days) | Nobre, 2008^32^ | 79 | 4 | 7 | -4.6 (-8.2, -1.0) | 0.02
ICU LOS (days) | Schroeder, 2009^33^ | 27 | 16.4 | 16.7 | -0.3,(-5.6, 5.0) | NSS
ICU LOS (days) | Bouadma, 2010^39^ | 621 | 15.9 | 14.4 | 1.5 (-0.9, 3.1) | 0.23
ICU-free days alive, 1-28 | Stolz, 2009^35^ | 101 | 10 (0-18)^‡^ | 8.5 (0-18)^‡^ | 1.5 | 0.53
SOFA day 28 | Bouadma, 2010^39^ | 621 | 1.5 | 0.9 | 0.6 (0.0, 1.1) | 0.037
SOFA score max | Schroeder, 2009^33^ | 27 | 7.3 | 8.3 | -8.1 (-4.1, 1.7) | NSS
SAPS II score | Hochreiter, 2009^34^ | 110 | 40.1 | 40.5 | -0.4 (-6.4, 5.6) | > 0.05
Days without MV | Stolz, 2009^35^ | 101 | 21 (2-24)^‡^ | 19 (8.5-22.5)^‡^ | 2.0 | 0.46
Days without MV | Bouadma, 2010^39^ | 621 | 16.2 | 16.9 | -0.7 (-2.4, 1.1) | 0.47

CI = confidence interval; CTRL = control; ICU = intensive care unit; LOS = length of stay; MV = mechanical ventilation; NSS = not statistically significant; PCT = procalcitonin; SAPS = Simplified Acute Physiology Score; SOFA = Sepsis-Related Organ Failure Assessment

Ψ All values are mean unless specified.

‡ Median (interquartile range).

Because ICU LOS was reported by four studies,32-34,39 we considered conducting meta-analysis on this outcome. One study32 did not report data necessary for calculation, so only three studies were represented in the meta-analysis (Figure 6). The pooled mean difference is 0.33 days, but the 95% CI is between -1.88 days and 2.53 days, suggesting that neither procalcitonin nor control are favored. Statistical heterogeneity was negligible (I^2^=14 percent).

Figure 6 Meta-analysis of mean differences, ICU length of stay (days) in critically ill/ventilator-associated pneumonia patients

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the mean difference in the ICU length of stay between procalcitonin-guided therapy and control in the critically ill/ventilator-associated pneumonia patients. Results show a pooled point estimate of 0.33 day increase in ICU length of stay (95% CI -1.88 to 2.53) favoring the control group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between reduction of 1.88 days and increase of 2.53 days. There was no statistically significant heterogeneity across the 3 studies that were included.

#### Adverse Events of Antibiotic Therapy

Only one study39 reported on adverse effects of antibiotic therapy. Bouadma et al. reported on emergence of multidrug resistant (MDR) organisms (17.9% vs. 16.6% in the procalcitonin vs. the control group respectively, difference 1.3%, 95% CI: -4.6, 7.2, p=0.67) and superinfection (34.5% vs. 30.9% in the procalcitonin vs. the control group respectively, difference 3.6%, 95% CI: -3.8, 11, p=0.29).

#### GRADE Evidence

Methods for grading strength of evidence25 developed for the AHRQ Effective Health Care Program were applied to this body of literature (Table 7). The quality of studies reviewed was an important consideration. Three of the five studies32,35,39 received a good quality rating and two studies33,34 received a fair rating.

Table 7 Procalcitonin-guided antibiotic discontinuation in the critically ill/ventilator-associated pneumonia patients––GRADE evidence table

Outcome Category | Outcome | No. of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Antibiotic use | Duration | 5 RCTs (n=938)32-35,39 | Low | Consistent | Direct | Precise | High
Antibiotic use | Days without ABTs (day 28) | 3 RCTs (n=801)32,35,39 | Low | Consistent | Direct | Precise | High
Antibiotic use | Total exposure | 3 RCTs (n=801)32,35,39 | Low | Consistent | Direct | Precise | High
Mortality | In-hospital, overall or 28 day | 5 RCTs (n=938)32-35,39 | Low | Consistent | Direct | Precise | Low^*^
Morbidity | ICU length of stay | 5 RCTs (n=837)32-35,39 | Low | Consistent | Direct | Precise | Moderate^**^

ABT = antibiotic; GRADE = grading of recommendations assessment, development, and evaluation; ICU = intensive care unit; RCT = randomized controlled trial

* The overall grade was low based on uncertainty about the appropriate minimum important difference for assessing noninferiority with respect to mortality.

** Only three studies reported sufficient details for pooling into a meta-analysis for this outcome.

For the body of evidence reviewed here, the strength of evidence was graded high for a reduction in antibiotic use. There were three different measures of antibiotic use: antibiotic duration in days, antibiotic prescription rate as a proportion and total antibiotic exposure as a rate: The consistency of findings across these three measures strengthened our confidence that there was a high strength of evidence. The three studies32,35,39 judged as good quality included 85 percent of the total patient population (801 of 938) and also reported on all three antibiotic use measures. The results consistently favored procalcitonin-guided therapy, and differences were generally highly statistically significant and were of a magnitude that has been associated with clinical benefits using other approaches to reduction of antibiotic use, such as active interventions of antibiotic stewardship programs and implementation of practice guidelines.46-48 The absolute difference in antibiotic use duration, the measure that was reported by all five studies, ranged from -1.7 to -5 days, with a percent reduction of 21 to 38 percent.

The strength of evidence that there was no difference in mortality with procalcitonin-guided discontinuation of antibiotic therapy in the critically ill/VAP patients was graded as low. The results of all five studies32-35,39 were consistent in finding no significant difference in short-term (28-day or in-hospital) mortality between procalcitonin-guided therapy and control groups. Four of the studies32-35 were not sufficiently powered to assess mortality. The largest study by Bouadma et al.39 was a noninferiority study that had 80 percent power to exclude a 10 percent difference in mortality between groups. Meta-analysis was performed to increase the power of detecting a significant difference in between-group mortality. Results show a pooled point estimate of 0.4 percentage point reduction in mortality favoring the procalcitonin-guided therapy group (95% CI: -6%, 5%).

The strength of evidence grading system described by Owens25 was designed with the assumption of a superiority conclusion. A conclusion of noninferiority only requires sufficient precision to exclude a minimal important difference (MID), i.e., the noninferiority margin.49 In grading the strength of evidence as low that procalcitonin-guided antibiotic therapy does not increase mortality, a major concern was disagreement about the appropriate noninferiority margin for mortality. Although a 10 percent noninferiority margin has been recommended by the IDSA and American College of Chest Physicians (ACCP) in relevant populations, there is also strong sentiment that this is too high a noninferiority margin for mortality, which was expressed among our peer reviewers and also in the published literature. Moreover, there are presently two large trials in progress, which may in the future yield more precise estimates of mortality.

All five studies32-34,39 reported on ICU LOS as a measure of morbidity. Risk of bias was rated low due to the preponderance of patients in good quality studies. Evidence was judged consistent as four of five studies32-34 reported shorter ICU LOS for procalcitonin arm. Evidence was considered direct and sufficiently precise to support the judgment that procalcitonin guidance does not increase morbidity as indicated by ICU LOS. The strength of evidence that procalcitonin does not increase ICU LOS was graded moderate primarily because only three studies reported sufficient details for pooling into a meta-analysis for this outcome.

### Procalcitonin-Guided Antibiotic Intensification

#### Study Characteristics

There were two RCTs28,45 of procalcitonin-guided antibiotic intensification (Table 8). Both studies evaluated critically ill patients in the ICU. The Svoboda study45 was limited to patients in the surgical ICU, while surgical patients were only a portion, but well represented, subgroup in the Jensen study.28 One study45 followed the patients for the duration of hospitalization, while the other study28 looked at outcomes at 28 days. Both studies reported intention-to-treat to treat analysis. Svoboda et al.45 enrolled 72 patients and Jensen28 enrolled 1,200 patients. In the Svoboda study45 an elevated procalcitonin level prompted IV catheter changes and changes in the antibiotic regimen. In the Jensen study,28 an algorithm for expanded radiographic evaluation and broadening the spectrum of antimicrobial therapy was used for patients with elevated procalcitonin. In the Svoboda study,45 the only description of antibiotic therapy in the control group was that it was standard of care. Jensen,28 in contrast, had a very detailed approach to antibiotic therapy and physicians were educated as to the approach to be taken for empiric therapy and intensification of antibiotic therapy. Mortality was the primary outcome for the large study by Jensen.28 The other study45 did not predetermine outcomes to be assessed.

Table 8 Summary of characteristics for two trials included in the analysis of procalcitonin-guided antibiotic intensification in the critically ill/ventilator-associated pneumonia patients

Author, Year, Country | Disease State | N | PCT for ABT Discontinuation | Other PCT-Guided Interventions | Control Interventions | Study Duration | Predefined Endpoints
Svoboda, 2007, Czechoslovakia45 | Severe sepsis, septic shock | PCT 38 Ctrl 34 | NA | PCT >2, change catheters and ABTs, PCT <2, US or CT and repeat surgery | Standard supportive care; broad-spectrum ABTs; catheter changes as indicated by guidelines | Not defined | Not defined
Jensen, 2011, Denmark28 | Critically ill in the ICU | PCT 604 Ctrl 596 | NA | PCT ≥1.0 or less than 10% lower than previous day, enhanced radiographic evaluation and broadened spectrum of ABT therapy | Standard microbiological and radiographic evaluation, ABT therapy | 28 days | Primary 28-day mortality Secondary Duration of organ failure; duration of stay in the ICU

ABT = antibiotic; CT = computed tomography; Ctrl = control; ICU = intensive care unit; NA = not applicable; PCT = procalcitonin; US = ultrasound

#### Study Quality

The quality ratings for the two studies28,45 are described in Table 9. Both studies28,45 assembled comparable groups and described randomization concealment. The study by Jensen28 clearly outlined the specific interventions for intensification, while the other study45 only vaguely described a push to change intravenous (IV) catheter and change antibiotics. One study45 broadly described an initiative to change antibiotics and IV catheters, pursue radiographic imaging, and reoperation if a local infection was confirmed, but did not give any details regarding these interventions. The outcomes were strictly defined, and in the higher quality study by Jensen,28 there was assurance that physicians, investigators, and coordinators were unaware of outcomes during the study or procalcitonin levels in the control group.

Table 9 Procalcitonin-guided antibiotic intensification in the critically ill/ventilator-associated pneumonia patients—study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Svoboda, 2007^45^ | Y | Y | Y | Y | N | Y | Y | Fair
Jensen, 2011^28^ | Y | Y | Y | Y | Y | Y | Y | Good

N = no; USPSTF = United States Preventive Services Task Force; Y = yes

#### Antibiotic Use

In the study by Jensen,28 procalcitonin-guided intensification resulted in a 2-day (50%) increase in the duration of antibiotic therapy (Table 10). It also resulted in greater antibiotic exposure with a 7.9 percent increase in number of days on three or more antibiotics in the ICU.

Table 10 Procalcitonin-guided antibiotic intensification in the critically ill/ventilator-associated pneumonia patients—outcomes related to antibiotic use

Author, Year | Outcome | N | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Jensen, 2011^28^ | ABT Duration (days) | 1200 | 6 (3-11)^‡^ | 4 (3-10)^‡^ | NR | NR
Jensen, 2011^28^ | Days spent in ICU on ≥ 3 ABTs | 1200 | 3,570/5,447 (65.5%) | 2,721/4,717 (57.7%) | 7.9% (6.0 to 9.7) | 0.002

ABT = antibiotic; CI = confidence interval; CTRL = control; ICU = intensive care unit; NR = not reported; PCT = procalcitonin

‡ Median (interquartile range)

#### Mortality

The impact of procalcitonin-guided antibiotic intensification on mortality is described in Table 11. There was a statistically insignificant reduction in mortality in the Svoboda45 study, which was not powered to show differences in mortality. Jensen28 was a superiority trial powered to test a 7.5 percent decrease in 28-day mortality, but no significant difference in mortality was observed with procalcitonin-guided intensification. Jensen28 showed no beneficial or adverse effect on mortality with procalcitonin-guided intensification.

Table 11 Procalcitonin-guided antibiotic intensification in the critically ill/ventilator-associated pneumonia patients––28-day mortality

Author, Year | N | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Svoboda, 2007^45^ | 72 | 10/38 (26.3%) | 13/34 (38.2%) | -11.9 (-33.4, 9.6) | 0.28
Jensen, 2011^28^ | 1200 | 190/604 (31.5%) | 191/596 (32.0%) | -0.6 (-4.7 to 5.9) | 0.83

CI = confidence interval; CTRL = control; PCT = procalcitonin

#### Morbidity

The Svoboda45 showed a 3.3-day reduction in ICU stay, which was not statistically significant. Jensen28 study showed a significant 1-day increase in ICU LOS (Table 12). Furthermore, this larger, good quality study demonstrated a significant increase in organ dysfunction, specifically an extra 5 days of mechanical ventilation and an additional 5 days of abnormal renal function, both of which were statistically significant.

Table 12 Procalcitonin-guided antibiotic intensification in the critically ill/ventilator-associated pneumonia patients––morbidity

Outcome | Author, Year | N | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
ICU LOS (days)Ψ | Svoboda, 2007^45^ | 72 | 16.1 | 19.4 | -3.3 (-7.0, 0.4) | 0.09
ICU LOS (days)Ψ | Jensen, 2011 28 | 1200 | 6 (3-12)^‡^ | 5 (3-11)^‡^ | 1 | 0.004
SOFA scoreΨ | Svoboda, 2007^45^ | 72 | 7.9 | 9.3 | -1.4. (-2.8, 0.0) | 0.06
Days on MVΨ | Svoboda, 2007^45^ | 72 | 10.3 | 13.9 | -3.6 (-7.6, 0.4) | 0.08
Days on MVΨ | Jensen, 2011^28^ | 1200 | 3569 (65.5%) | 2861 (60.7%) | 4.9% (3 to 6.7) | < 0.0001
Percent days in ICU with GFR <60 | Jensen, 2011^28^ | 1200 | 2796 (51.3%) | 2187 (46.4%) | 5.0 % (3.0 to 6.9) | <0.0001

CI = confidence interval; CTRL = control; GFR = glomerular filtration rate; ICU = intensive care unit; LOS = length of stay; MV = mechanical ventilation; PCT = procalcitonin

Ψ Values are mean unless specified.

‡ Median (inter quartile range).

#### Adverse Events of Antibiotic Therapy

None of the studies in this patient group reported the adverse events of antibiotic therapy.

#### GRADE Evidence

The strength of evidence is moderate that procalcitonin-guided intensification of antibiotic therapy increases morbidity. The large (n=1,200) good quality study by Jensen28 was judged to have low risk of bias. This study was notable for its specificity in describing study interventions, especially treatment algorithms. Consistency was rated as unknown (single study). The evidence is direct and sufficiently precise to judge that procalcitonin-guided intensification does not improve outcomes in critically ill patients. A second study (n=72)45 was too small to be informative.

## Respiratory Tract Infections

There were eight studies27,31,36-38,40-42 in total, seven randomized controlled trials27,31,36,38,40-42 and one cluster-randomized controlled trial.37 All studies compared procalcitonin-guided initiation and/or discontinuation of antibiotics in patients with respiratory tract infections to standard therapy. The sample size in these studies ranged from 162 to 1,359, with all studies having populations larger than 100. Overall, 3,492 patients were enrolled in these trials.

### Study Characteristics

The populations in this study consisted of patients with acute upper and lower respiratory tract infections in the community, including CAP, acute exacerbation of chronic obstructive pulmonary disease (COPD), and acute bronchitis (Table 13). The study populations and settings varied between studies. Three studies31,36,41 looked only at CAP, but the settings varied in these studies. One study31 included patients from the outpatient setting, one study36 included patients from the emergency department, and one study41 included patients admitted to the hospital. Two studies27,42 included patient populations that had upper or lower respiratory tract infections. Both of these studies looked at patients in the outpatient setting (primary care clinics). Two studies37,40 included patients with lower respiratory tract infections only, and both of these studies enrolled patients that presented to emergency departments. One study38 looked only at patients with acute exacerbation of COPD in the emergency department.

Table 13 Summary of characteristics for eight trials included in the analysis of procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections

Author, Year, Country | Disease State | N | PCT for ABT Initiation | PCT for ABT Discontinuation | Study Duration | Predefined Endpoints
Long, 2011, China31 | Suspected CAP outpatient | PCT 81 Ctrl 81 | PCT >0.25 ng/mL | PCT< 0.1ng/mL strongly discouraged PCT 0.1-0.25 ng/mL antibiotics discouraged | 28 days | Primary : Total ABT use and duration of ABT treatment, ABT prescription rate Secondary outcomes: Treatment failure, treatment success, death, recurrence, relapse, patients lost to followup
Burkhardt, 2010, Germany27 | Acute respiratory tract infection | PCT 275 Ctrl 275 | PCT ≥0.25 ng/ml | PCT <0.25 ng/mL | 28 days | Primary: Number of days with significant health impairment due to RTI at day 14 Secondary: Prescription rate, duration of ABTs, days with ABT-associated SEs, symptoms on day 14 and 28, revisit within 28 days, change of ABTs within 28 days, hospitalization within 28 days, 28 day mortality
Schuetz, 2009, Switzerland40 | LRTI; (CAP, AECOPD, acute bronchitis) | PCT 671 Ctrl 688 | PCT <0.1 ng/mL, strongly discouraged; PCT ≤0.25 ng/mL, discouraged; PCT > 0.25 ng/mL, encouraged; PCT >0.5 ng/mL, strongly encouraged | PCT <10% of baseline, stopping strongly encouraged; PCT <20% of baseline, stopping discouraged | 30 days | Primary: (Noninferiority) Total adverse event rate at 30 days (composite outcome of death, ICU admission, disease-specific complications, and recurrent LRTI in need of ABTs with or without hospital readmission) Secondary: ABT exposure, duration, adverse effects, LOS
Kristoffersen, 2009, Denmark41 | LRTI (CAP) | PCT 103 Ctrl 107 | PCT <0.25 ng/mL, discouraged PCT 0.25-5.0 ng/mL, encouraged PCT >0.5 ng/mL, strongly encouraged | PCT <0.25 ng/mL, discontinued | Not defined | Primary: ABT duration, LOS Secondary: Proportion of patients for whom physicians disregarded treatment guidelines
Briel, 2008, Switzerland42 | URTI (cold, sinusitis, pharyngitis, tonsillitis), LRTI (CAP, AECOPD, tracheobronchitis) | PCT 232 Ctrl 226 | PCT >0.25 ng/mL, recommended PCT 0.1-0.25 ng/mL, not recommended, PCT increase 50% with worse symptoms, ABTs, recommended | PCT ≤0.25 | 28 days | Primary: (Noninferiority) Number of days of restricted activity due to respiratory infection Secondary: ABT prescription rate and duration, discomfort scale, days work missed, days with adverse effects of medication, relapse of infection, serious adverse events
Stolz, 2007, Switzerland38 | Acute exacerbation of COPD | PCT 102 Ctrl 106 | PCT <0.1 ng/mL strongly discouraged; PCT ≥1.0 ≤0.25 ng/mL, ABTs based on clinical condition; PCT >0.25 ng/mL, encouraged | NA | 6 months | Primary: ABT use at index AECOPD ABT use up to 6 months Secondary: Success, LOS, ICU need, CRP, PCT, PFTs on admission, short- and long-term F/U, exacerbation rate, time to next exacerbation
Christ-Crain, 2006, Switzerland36 | CAP admitted to ED, single center | PCT 151 Ctrl 151 | PCT <0.1 strongly discouraged PCT ≥0.1, <0.25, discouraged PCT ≥0.25, ≤0.5 ng/mL, encouraged PCT >0.5 ng/mL, strongly encouraged | If baseline >10 ng/mL, ABTs discontinued if less than 10% of initial value | 6 weeks | Primary: Total ABT use (prescription) and duration Secondary: Laboratory, clinical outcomes
Christ-Crain, 2004, Switzerland37 | LRTI (CAP, AECOPD, acute bronchitis, asthma) | PCT 124 Ctrl 119 | PCT ≤0.1 ng/mL, strongly discouraged PCT 0.1-0.25 ng/mL, discouraged PCT 0.25-0.5 ng/mL, encouraged PCT ≥0.5 ng/mL, strongly encouraged | PCT <0.25 ng/mL | 14 days | Primary: ABT prescription rate, ABT exposure, costs Secondary: QOL, Temp, WBC count, CRP, PCT, Admission rates, LOS, ICU, death for LRTIs, Re-exacerbation, readmission for AECOPD

ABT = antibiotic; AECOPD = acute exacerbation of chronic obstructive pulmonary disease; CAP = community acquired pneumonia; COPD = chronic obstructive pulmonary disease; CRP = C-reactive protein; Ctrl = control; ED = emergency department; F/U = followup; ICU = intensive care unit; LOS = length of stay; LRTI = lower respiratory tract infection; NA = not applicable; PCT = procalcitonin; PFT = pulmonary function test; QOL = quality of life; RTI = respiratory tract infection; SEs = side effects; URTI = upper respiratory tract infection; WBC = white blood cells

All studies27,31,36-38,40-42 evaluated the use of procalcitonin for the initiation of antibiotics. All studies encouraged initiation of antibiotics with procalcitonin levels greater than 0.25 ng/mL, and four studies36,37,40,41 strongly encouraged antibiotics with procalcitonin levels greater than 0.5 ng/mL. Seven studies27,31,36,37,40-42 used procalcitonin measurement to recommend discontinuation of antibiotics. Five studies 27,31,37,41,42 recommended discontinuing antibiotics if procalcitonin level was less than 0.25 ng/mL, and one of these studies31 strongly recommended discontinuation if level was less than 0.1 ng/mL. One study40 recommended discontinuation if the procalcitonin level was less than 20 percent of the baseline level, and strongly recommended discontinuation if the level was less than 10 percent. One study36 recommended discontinuation of antibiotics if the procalcitonin level was 10 percent of baseline, if the baseline level was greater than 10 ng/mL.

Physicians in the control groups administered antibiotics according to their own standard practices and/or evidence-based guidelines. Two studies31,36 used international guidelines on standard therapy that were cited in the references. One study40 used evidence-based, international guidelines which were stated in the methods section but not cited in the references.

The study durations ranged from 14 days to 30 days in five studies,27,31,40,37,42 6 weeks in one study,36 and 6 months in one study.38 Study duration was not defined in one study.41

The primary endpoints varied by the study. Prescription rate^a^, antibiotic duration and total antibiotic exposure^b^ were primary endpoints in four studies.31,36-38 Number of days of restricted activity was the primary endpoint in two studies.27,42 LOS was a primary endpoint in one study,41 and cost was a primary endpoint in another study.37 The 2009 study by Schuetz et al.40 was a noninferiority trial that calculated a composite outcome of total adverse events as the primary endpoint.

a Defined as the percentage of patients that are initiated on antibiotic therapy, either during initial presentation or subsequent followup.

b Calculated by multiplying the total number of antibiotics by the number of days the patient is receiving each of antibiotic divided by total duration of antibiotic therapy.

### Study Quality

The overall study rating was good for four studies27,36,40,42 and poor for the other four studies31,37,38,41 (Table 14). Four of the studies were given a poor rating because of lack of intention-to-treat analysis. The studies rated poor because of percentages of excluded patients are: Christ-Crain et al. (2004)37 (8.6%), Kristoffersen et al., (2009)41 (5.8%), Long et al., (2011)31 (5.8%), and Stolz et al., (2007)38 (8.0%). All studies assembled groups appearing to have similarly distributed potential confounders with no obvious imbalances. Allocation concealment was not explicitly stated in two studies,31,38 and concealment was not applicable in the one cluster-randomized controlled trial.37 All studies had clearly defined interventions.

Table 14 Procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections––study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Schuetz, 2009^40^ | Y-balanced Y-concealment | Y | Y | Y | Y | Y | Y | Good
Christ-Crain, 2004^37^ (cluster-randomized controlled trial) | Y-balanced N/A-concealment | Y | Y | Y | Y | Y | N | Poor^*^
Kristoffersen, 2009^41^ | Y- balanced Y-concealment | Y | Y | Y | Y | Y | N | Poor^*^
Briel, 2008^42^ | Y- balanced Y-concealment | Y | Y | Y | Y | Y | Y | Good
Long, 2011^31^ | Y- balanced U-concealment | Y | Y | Y | Y | Y | N | Poor^*^
Burkhardt, 2010^27^ | Y balanced Y-concealment | Y | Y | Y | Y | Y | Y | Good
Stolz, 2007^38^ | Y- balanced U-concealment | Y | Y | Y | Y | Y | N | Poor^*^
Christ-Crain, 2006^36^ | Y- balanced Y-concealment | Y | Y | Y | Y | Y | Y | Good

N = no; U = unknown; USPSTF = United States Preventive Services Task Force; Y = yes

* Overall study rating was poor due to >5% of patients excluded from analyses.

Judgments of whether outcome measurements were equal, valid and reliable usually depend in part on the requirement for blinded outcome assessor. For studies comparing procalcitonin-guided therapy and standard therapy, this requirement was not applied. In these studies, it was not feasible to blind treating physicians to which group participants were allocated. Decisions on antibiotic use were made by unblinded physicians who could take other clinical information into account and override the algorithm based on their clinical judgment. Procalcitonin guidance is intended as an adjunct to, not a replacement for, clinical criteria for assessing and managing infection. In this setting, we did not require use of a blinded outcome assessor as a dimension of study quality.

Five of the trials27,31,36,38,41 were superiority trials with intention-to-treat analyses, and two trials40,42 were noninferiority trials with both intention-to-treat and per-protocol analyses. One study40 tested for noninferiority of the composite adverse event rate, including death, ICU admission, disease-specific complications, or recurrent infection requiring antibiotic treatment within 30 days. A predefined noninferiority boundary of 7.5 percent was used, and based on this noninferiority boundary, a sample size of 1,002 patients was determined to allow for an adverse outcome rate in the control group of 20 percent or less with a power of 90 percent. A second study42 used noninferiority design to compare the number of days of restricted activity due to respiratory infection. Noninferiority was defined as a difference between the procalcitonin-guided therapy and control groups of no more than one day.

### Antibiotic Use

The results consistently demonstrated reduction in antibiotic use, with regard to duration, prescription rates, and total exposure (Table 15).

Table 15 Procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections––outcomes related to antibiotic use

Outcome | Author, Year | N | PCT | Control | Absolute Difference PCT-CTRL (95% CI) | p-Value | Relative Difference PCT-CTRL (95% CI) | p-Value
ABT Duration (days Ψ ) | Schuetz, 2009^40^ | 1359 | 5.7 | 8.7 | -3.0 | -- | -34.8% (-40.3 to -28.7) | --
ABT Duration (days Ψ ) | Christ-Crain, 2004^37^ | 243 | 10.9 | 12.8 | -1.9 (-3.1 to -0.7) | 0.002 | -14.8% | --
ABT Duration (days Ψ ) | Kristoffersen, 2009^41^ | 210 | 5.1 | 6.8 | -1.7 | -- | -25% | 0.007
ABT Duration (days Ψ ) | Briel, 2008^42^ | 458 | 6.2 | 7.1 | -1.0 (-1.7 to -0.4) | <0.05 | -12.7% | --
ABT Duration (days Ψ ) | Long, 2011^31^ | 162 | 5 (3-6)^‡^ | 7 (5-9)^‡^ | -2.0 | <0.001 | -28.6% | --
ABT Duration (days Ψ ) | Burkhardt, 2010^27^ | 550 | 7.8 | 7.7 | 0.1 (-0.7 to 0.9) | 0.8 | 1.3% | --
ABT Duration (days Ψ ) | Christ-Crain, 2006^36^ | 302 | 5.8 | 12.9 | -7.1(-8.4 to -5.8) | <0.0001 | -55.0% | --
ABT Prescription Rate (%) | Schuetz, 2009^40^ | 1,359 | 506/671 (75.4%) | 603/688 (87.6%) | -12.2% (-16.3 to -8.1) | <0.05 | -- | --
ABT Prescription Rate (%) | Christ-Crain, 2004^37^ | 243 | 55/124 (44.4%) | 99/119 (83.2%) | -38.8% (-49.9 to -27.8) | <0.0001 | -- | --
ABT Prescription Rate (%) | Kristoffersen, 2009^41^ | 210 | 88/103 (85.4%) | 85/107 (79.4%) | 6.0% (-4.3 to 16.2) | 0.25 | -- | --
ABT Prescription Rate (%) | Briel, 2008^42^ | 458 | 58/232 (25.0%) | 219/226 (96.9%) | -72% (-78 to -66) | <0.05 | -- | --
ABT Prescription Rate (%) | Long, 2011^31^ | 162 | NR (84.4%) | NR (97.5%) | -13.1% | 0.004 | -- | --
ABT Prescription Rate (%) | Stolz, 2007^38^ | 208 | 41/102 (40.2%) | 76/106 (71.7%) | -31.5% (-44.3 to -18.7) | <0.0001 | -- | --
ABT Prescription Rate (%) | Christ-Crain, 2006^36^ | 302 | 128/151 (84.8%) | 149/151 (98.79%) | -13.9% (-19.9 to -7.9) | <0.0001 | -- | --
ABT Prescription Rate (%) | Burkhardt, 2010^27^ | 550 | 84/275 (30.5%) | 89/275 (32.4%) | -1.8% (-9.6 to 5.9) | 0.701 | -- | --
Total ABT Exposure | Stolz, 2007^38^ | 208 | NR | NR | -31.5% (18.7 to 44.3) | <0.0001 | 44% (0.27 to 0.57) | <0.0001
Total ABT Exposure | Long, 2011^31^ | 162 | NR | NR | NR | -- | 0.55^*^ (0.51 to 0.60) | 0.003
Total ABT Exposure | Christ-Crain, 2006^36^ | 302 | 136^**^ | 323^**^ | -- | -- | 0.52 (0.48 to 0.55)∞ | <0.001
Total ABT Exposure | Christ-Crain, 2004^37^ | 243 | 332^**^ | 661^**^ | -- | -- | 0.49 (0.44 to 0.55)^‡^∞ | <0.0001

ABT = antibiotic; CI = confidence interval; CTRL = control; NR = not reported; PCT = procalcitonin

Ψ Values are mean unless specified.

* Relative risk.

** Mean per 1,000 days of followup.

‡ Adjusted for potential confounding and possible cluster effects.

∞ Rate ratios.

‡ Median (interquartile range).

Antibiotic duration was reported in all studies except for one.38 The duration of antibiotic therapy was reduced with procalcitonin-guided therapy in six of the seven studies, and the absolute reduction ranged from -1.0 to -7.1 days, with a relative reduction of -12.7 to -55 percent. Only one study27 reported an absolute increase in antibiotic duration of 0.1 days with a relative increase of 1.3 percent. The absolute reduction was statistically significant in four of the five studies in which p values were either reported or calculated. Meta-analysis of 4 studies (Figure 7) found a statistically significant pooled mean difference of -2.35 days favoring procalcitonin (95% CI: -4.38, -0.33). A high degree of statistical heterogeneity was observed (I^2^=97%). Three studies31,40,41 did not report sufficient detail to be included in the pooling but the largest study40 which accounted for more than three quarters of the total patients, had a greater mean difference (-3.0) than the pooled mean difference. Thus, if these studies could have also been pooled, the difference likely would still favor procalcitonin.

Figure 7 Meta-analysis of mean differences, antibiotic duration (days) in patients with respiratory tract infections

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the mean difference in the duration of antibiotic use in days between procalcitonin-guided therapy and control in patients with respiratory tract infections. Results show a pooled point estimate of 2.35 day reduction in duration of antibiotic use (95% CI -4.38 to -0.33) favoring the procalcitonin-guided therapy group. The 95% CI indicates that the uncertainty surrounding the pooled estimate which extends between reduction by 4.38 days and reduction by 0.33 days. There was statistically significant heterogeneity across the 4 studies that were included.

Antibiotic prescription rate was reported in all eight studies.27,31,36-38,40-42 An absolute reduction in antibiotic prescription rate was demonstrated with procalcitonin-guided therapy in seven of the eight studies. The absolute reduction in prescription rates ranged from -1.8 to -72 percent, and the reductions were statistically significant in all seven studies, with five being highly statistically significant. Only one study41 reported an absolute increase in prescription rate by 6.0 percent, which was not statistically significant. Meta-analysis of eight studies (Figure 8) yielded a statistically significant pooled risk difference of -22 percent (95% CI: -41%, -4%). The degree of statistical heterogeneity was quite high (I^2^=98%).

Figure 8 Meta-analysis of risk differences, antibiotic prescription rate in patients with respiratory tract infections

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the risk difference in antibiotic prescription rate between procalcitonin-guided therapy and control in patients with respiratory infections. Results show a pooled point estimate of 22 percentage point reduction in antibiotic prescription rate (95% CI -41% to -4%) favoring the procalcitonin-guided therapy group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between decrease by 41 percentage point and decrease by 4 percentage point. There was statistically significant heterogeneity across the 8 studies that were included.

Four studies31,36-38 reported on total antibiotic exposure, which accounted for the use of multiple agents, as well as duration of therapy. Two studies36,37 reported total exposure per 1,000 patient-days with relative reductions of 0.52 and 0.49, which were both highly statistically significant. One study38 reported an absolute reduction of -31.5 percent, which was highly statistically significant. One study31 reported a statistically significant relative risk of 0.55, but no additional details were given.

### Mortality

Overall, mortality results were consistent and did not suggest higher mortality rates with procalcitonin-guided therapy as compared to the control arm (Table 16). Mortality rates in patients in the control arm ranged from 0 to 13.2 percent. The absolute differences between the procalcitonin and control arms ranged from -3.6 to 1.0 percent. One study36 reported higher mortality rates in both the procalcitonin-guided therapy and control groups which appear to be due to disease-related mortality.

Table 16 Procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections––mortality

Outcome | Author, Year | N | PCT | Control | Absolute Difference PCT-CTRL (95% CI) | p-Value
6-month mortality | Stolz, 2007^38^ | 208 | 5/102 (4.9%) | 9/106 (8.5%) | -3.6% (-10.3 to 3.2) | 0.30
6-week mortality | Christ-Crain, 2006^36^ | 302 | 18/151 (11.9%) | 20/151 (13.2%) | -1.3% (-8.8 to 6.2) | 0.73
≤28-day mortality | Christ-Crain, 2004^37^ | 243 | 4/124(3.2%) | 4/119 (3.4%) | -0.1% (-4.6 to 4.4) | 0.95
≤28-day mortality | Schuetz, 2009 (30-day)40 | 1359 | 34/671(5.1%) | 33/688(4.8%) | 0.3% (-2.1 to 2.5) | 0.82
≤28-day mortality | Briel, 2008^42^ | 458 | 0/231(0%) | 1/224 (0.4%) | -0.4% (-1.3 to 0.4) | 0.31
≤28-day mortality | Burkhardt, 2010^27^ | 550 | 0/275(0%) | 0/275 (0%) | 0 | --
≤28-day mortality | Kristoffersen, 2009^41^ | 210 | 2/103(1.9%) | 1/107 (0.9%) | 1.0% (-2.2 to 4.2) | 0.54
≤28-day mortality | Long, 2011^31^ | 162 | 0/81 (0%) | 0/81 (0%) | 0 | --

CI = confidence interval; CTRL = control; PCT = procalcitonin

Note: All studies performed intention-to-treat analyses.

Six studies27,31,37,40-42 reported 28-day mortality, and only one study37 reported a reduction in mortality with procalcitonin-guided therapy by -0.1 percent. The other five studies27,31,40-42 reported absolute differences ranging from 0 to 1.0 percent. None of the differences in 28-day mortality were statistically significant.

One study36 reported 6-week mortality with an absolute reduction in mortality of 1.3 percent. Studies reporting mortality at 6 weeks or less were pooled in a meta-analysis (Figure 9), but those reporting zero events in either arm were excluded. Combining four studies36,37,40,41 produces a risk difference of 0.3 percent with a very narrow 95% CI (-1 percent, 2 percent). Statistical heterogeneity was nil (I^2^=0 percent).

Figure 9 Meta-analysis of risk differences, short-term mortality (≤6 weeks) in patients with respiratory tract infections

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the risk difference of the probability of short-term mortality (≤ 6 weeks) between procalcitonin-guided therapy and control in patients with respiratory tract infections. Results show a pooled point estimate of 3 percentage point reduction in short-term mortality (95% CI -1% to 2%) favoring the control group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between reduction by 1 percentage point and also increase by 2 percentage point. There was no statistically significant heterogeneity across the 4 studies that were included.

One study 38reported 6-month mortality with an absolute reduction in mortality of 3.6 percent. None of the 6-week or 6-month absolute reductions in mortality rate were statistically significant.

### Morbidity

Overall, studies did not suggest an increase in-hospital LOS, ICU admission rates, antibiotic adverse events, or days of restricted activity with procalcitonin-guided therapy (Table 17).

Table 17 Procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections—morbidity

Outcome | Author, Year | N | PCT | Control | Absolute Difference PCT-CTRL (95% CI) | p-Value
LOS (daysΨ) | Schuetz, 2009^40^ | 1,359 | 9.4 | 9.2 | 0.2 days | --
LOS (daysΨ) | Christ-Crain, 2004^37^ | 224 | 10.7 ± 8.9 | 11.2 ± 10.6 | -0.5 days (-3.0 to 2.0) | 0.69
LOS (daysΨ) | Kristoffersen, 2009^41^ | 210 | 5.9 | 6.7 | -0.8 days | 0.22
LOS (daysΨ) | Stolz, 2007^38^ | 208 | 9 (1-15)^‡^ | 10 (1-15)^‡^ | -1 days | 0.96
LOS (daysΨ) | Christ-Crain, 2006^36^ | 302 | 12.0±9.1 | 13.0±9.0 | -1 days (-3.0 to 1.0) | 0.34
ICU Admission (%) | Schuetz, 2009^40^ | 1,359 | 43/671 (6.4%) | 60/688 (8.7%) | -2.3% (-5.2 to 0.4) | 0.12
ICU Admission (%) | Christ-Crain, 2004^37^ | 224 | 5/124 (4.0%) | 6/119 (5.0%) | -1.0% (-6.2 to 4.2) | 0.71
ICU Admission (%) | Kristoffersen, 2009^41^ | 210 | 7/103 (6.8%) | 5/107 (4.7%) | -2.1% (-4.2 to 8.4) | 0.51
ICU Admission (%) | Stolz, 2007^38^ | 208 | 8/102 (7.8%) | 11/106 (10.4%) | -2.5% (-10.3 to 5.3) | 0.53
ICU Admission (%) | Christ-Crain, 2006^36^ | 302 | 20/151 (13.2%) | 21/151 (13.94%) | -0.7% (-8.4 to 7.1) | 0.87
Antibiotic Adverse Events | Schuetz, 2009^40,†^ | 1,359 | 133/671 (19.8%) | 193/688 (28.1%) | -8.2% (-12.7 to -3.7) | --
Antibiotic Adverse Events | Briel, 2008^42,‡^ | 458 | 2.3±4.6 days | 3.6±6.1 days | -1.1 days(-2.1 to -0.1) | <0.05
Antibiotic Adverse Events | Burkhardt, 2010^27^∞ | 550 | 11 /59 (18.6%) | 16/101 (15.8%) | 2.8% (-9.4 to 15.0) | 0.65
Restricted Activity (days)^*^ | Briel, 2008^42^ | 458 | 8.7±3.9 | 8.6±3.9 | 0.2 days (-0.4 to 0.9) | >0.05
Restricted Activity (days)^*^ | Burkhardt, 2010^27^ | 550 | 9.1 | 8.8 | 0.25 days (-0.52 to 1.03) | >0.05

CI = confidence interval; CTRL = control; ICU = intensive care unit; LOS = length of stay; PCT = procalcitonin

Ψ Values are mean unless specified.

† Nausea, diarrhea, and rash.

‡ Abdominal pain, diarrhea, nausea, vomiting, and rash.

∞ Antibiotic adverse events not defined.

* Days during the first 14 days of illness that work and leisure activities were restricted.

‡ Median (interquartile range).

Five studies36,38,40-42 reported hospital LOS. Hospital LOS was reduced with procalcitonin-guided therapy in four of five studies with an absolute reduction in days ranging from -0.5 to -1. The differences were not statistically significant in any of the studies. One study40 reported an absolute increase in LOS by 0.2 days.

Five studies36,38,40-42 reported need for ICU admission. ICU admission rates were reduced with procalcitonin-guided therapy with absolute reductions ranging from -0.7 to -2.5 percent. None of the reductions in ICU admissions was statistically significant. Meta-analysis of these five studies (Figure 10) produced a risk difference of -1 percent with a very narrow 95% CI (-4%, 1%). No statistical heterogeneity was detected (I^2^=0 percent).

Figure 10 Meta-analysis of risk differences in ICU admission in patients with respiratory tract infections

CI = confidence interval; IV = inverse variance weighted; SD = standard deviation

This figure displays a forest plot of studies reporting the risk difference of the probability of ICU admission between procalcitonin-guided therapy and control in patients with respiratory tract infections. Results show a pooled point estimate of 1 percentage point reduction in ICU admission (95% CI -4% to 1%) favoring the procalcitonin-guided therapy group. The 95% CI indicates the uncertainty surrounding the pooled estimate which extends between decrease by 4 percentage point and increase by 1 percentage point. There was no statistically significant heterogeneity across the 5 studies that were included.

Two studies27,42 evaluated days of restricted activity. It was defined as number of self-assessed impaired days of daily work and/or leisure activities within the first 14 days of illness. The absolute differences were -0.25 and 0.2 days and none were statistically significant.

### Adverse Events of Antibiotic Therapy

For the respiratory tract infection studies, three studies27,40,42 reported on adverse antibiotic effects, but the definition of antibiotic adverse events differed with each study. Schuetz et al.40 reported a reduction in the proportion of patients with an antibiotic adverse events (19.8% vs. 28.1%, difference – 8.2%, 95% CI: -12.7, -3.7) that favored procalcitonin-guided therapy. Briel et al.42 reported that there was a statistically significant decrease in the days with adverse antibiotic effects in the procalcitonin-guided arm (2.3±4.6 vs. 3.6±6.1, difference -1.1, 95% CI: -2.1, -0.1) that was mainly due to a lower incidence of antibiotic-associated diarrhea. Burkhardt et al.27 reported a lower incidence of antibiotic adverse effects (11/275 vs. 16/275, p=0.331) and fewer days with antibiotic adverse effects (5.6±2.2 vs. 6.1±3.7, p=0.94), but neither difference was statistically significant.

### GRADE Evidence

Methods for grading strength of evidence developed for the AHRQ Effective Health Care Program25 were applied to this body of literature. An important consideration in grading the literature was the quality ratings of the studies. Four27,36,40,42 of the eight studies27,31,36-38,40-42 received a good quality rating, but the other four studies31,37,38,41 received a poor quality rating due to lack of intention-to-treat analysis (Table 18). However, the studies receiving a poor rating represent 23.6 percent of the total patients in these studies (823 of 3,492 patients).

Table 18 Procalcitonin-guided antibiotic initiation and/or discontinuation in patients with respiratory tract infections—GRADE evidence table

Outcome | No. of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall GRADE
Antibiotic duration | 7 RCTs (n=3,284)27,31,36,37,40-42 | Low | Consistent | Direct | Precise | High
Antibiotic prescription rate | 8 RCTs (n=3,492)27,31,36-38,40-42 | Low | Consistent | Direct | Precise | High
Total antibiotic exposure | 4 RCTs (n=915)31,36-38 | Medium | Consistent | Direct | Precise | Moderate
Mortality | 8 RCTs (n=3,492)27,31,36-38,40-42 | Low | Consistent | Direct | Precise | Moderate
Hospital length of stay | 5 RCTs (n=2,303)36-38,40,41 | Medium | Consistent | Direct | Precise | Moderate
ICU admission rates | 5 RCTs (n=2,303)36-38,40,41 | Medium | Consistent | Direct | Precise | Moderate
Antibiotic adverse events | 3 RCTs (n=2,367)27,40,42 | Low | Inconsistent | Direct | Imprecise | Insufficient

GRADE = grading of recommendations assessment, development, and evaluation; ICU = intensive care unit; RCT = randomized controlled trial

Overall, the grade of the strength of evidence was high, and the data demonstrate a reduction in antibiotic duration and prescription rates which were reported in the majority of studies. The risk of bias was low and the evidence was consistent, direct, and precise for these antibiotic outcomes. The reduction in antibiotic duration ranged from -1.0 to -7.1 days and from -1.8 to -72 percent for antibiotic prescription rates.

The overall grade of the evidence for total antibiotic exposure was moderate. Total antibiotic exposure was only reported by four studies,31,36-38 but three of these studies31,37,38 were given a poor quality rating. In general, total antibiotic exposure is difficult to calculate, and the data for this outcome were reported differently in these studies. Two studies31,35 reported relative risk ratios without providing additional details, and two studies36,37 reported means per 1,000 days of followup. Because the majority of these studies were poor quality and the reporting differed, the data were graded to have a moderate risk of bias. The evidence was graded to be consistent, direct, and precise. All of the absolute or relative reductions reported in total antibiotic exposure were statistically significant, and overall, the data suggest a reduction in total antibiotic exposure.

The mortality data were given a moderate overall grade. All eight studies27,31,36-38,40-42 reported mortality rates. The absolute difference in 28-day mortality rates ranged from -0.3 to 0.4 percent, but none of these differences was statistically significant. The data were graded to have a low risk of bias and be consistent, direct, and precise. Overall grade was moderate, largely due to the low baseline mortality rates in patients with respiratory tract infections. While the confidence interval around the pooled estimate was narrow, uncertainty about the minimum important difference for mortality leads us to rule out high strength of evidence.

The overall grade of the evidence for hospital LOS and ICU admission rates was moderate. Five studies36,38,40-42 reported these outcomes. The data were graded to have a M risk of bias because three37,38,41 of the five studies36,38,40-42 were given a poor quality rating. The absolute differences in LOS and ICU admission rates ranged from -1 to 0.2 days and -2.5 to -0.7 percent, respectively, but none of these differences was statistically significant. Thus, the present evidence does not suggest an increase in hospital LOS or ICU admission rates.

The current data do not permit a conclusion regarding the effects of procalcitonin-guided therapy on antibiotic adverse events, and the overall grade was insufficient. Three studies27,40,42 with a low risk of bias reported this outcome; however, the data were inconsistent and imprecise. Two studies reported percentages with absolute differences of -8.2 percent40 and 2.8 percent,27 and one study42 reported an absolute difference of -1.1 days that was statistically significant. The data for this outcome are limited, and therefore, no conclusions can be drawn on the impact of procalcitonin-guided therapy on antibiotic adverse events.

## Neonatal Sepsis

### Study Characteristics

There was only one RCT43 of procalcitonin-guided antibiotic therapy for suspected early onset neonatal sepsis that included 101 neonates, both arms stratified by the likelihood of infection (Table 19). Neonatal sepsis was suspected on the basis of risk factors, as well as clinical signs and symptoms including apnea, tachycardia or bradycardia, hypotension, seizures, “floppiness,” irritability, or ileus, and standard laboratory tests, including C-reactive protein and immature leukocyte ratio. Procalcitonin values used to decide on antibiotic initiation and discontinuation were based on a nomogram based on the time since birth, since procalcitonin is elevated in the first three days of life due to birth stress. Antibiotic therapy in the standard group was based on the attending physician's assessment. The trial was designed to have 90 percent power to detect a 30 percent difference in antibiotic duration. The primary outcomes for this study were the duration of antibiotics and the proportion of neonates on antibiotics longer than 72 hours. Secondary outcomes were recurrence of infection and mortality, but the study was not powered to detect differences in these outcomes. Followup duration was 21 days.

Table 19 Summary of characteristics for one trial included in the analysis of procalcitonin-guided antibiotic therapy in neonatal sepsis

Author, Year, Country | Disease State | N | PCT for ABT Initiation | PCT for ABT Discontinuation | Other PCT-Guided Interventions | Study Duration | Predefined Endpoints
Stocker, 2010, Switzerland43 | Suspected early onset neonatal sepsis | PCT 60 Ctrl 61 | PCT according to nomogram based on age since birth, hours | PCT according to nomogram based on age since birth, hours | NA | 30 days | Primary outcome ABTs ≥72 hours, duration of ABTs Secondary outcomes, Survival, recurrence of infection

ABT = antibiotic; Crtl = control; PCT = procalcitonin; NA = not applicable

### Study Quality

The quality rating for the one study is described in Table 20. In this study43 of neonatal sepsis, neonates in the two arms were comparable at baseline. Details of allocation concealment were described. Analysis was appropriate, but again, this study was not powered to detect differences in morbidity or mortality.

Table 20 Procalcitonin-guided antibiotic therapy in neonatal sepsis—study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Stocker, 2010^43^ | Y | Y | Y | Y | Y | Y | Y | Good

USPSTF = United States Preventive Services Task Force; Y = yes

### Antibiotic Use

Outcomes related to antibiotic use are summarized in Table 21. The duration of antibiotic use was significantly decreased overall by 22.4 hours (24 percent reduction), with the greatest differences seen for the 80 to 85 percent of neonates who had possible infection or were unlikely to have infection and little difference for the small proportion of neonates with proven of probable infection. The proportion of neonates on antibiotics for 72 or more hours was significantly reduced overall by 27 percent, again with the difference seen only for neonates with possible sepsis (38 percent reduction) or neonates unlikely to have infection (27 percent reduction).

Table 21 Procalcitonin-guided antibiotic therapy in neonatal sepsis in the study by Stocker et al., 2010^43^ (n=121)—outcomes related to antibiotic use

Outcome | Patient Subgroup | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
ABTs ≥72 hours (%) | All neonates | 33/60 (55%) | 50/61 (82%) | -27.0 (-42.8 to -11.1) | 0.002
ABTs ≥72 hours (%) | Infection proven/probably | 9/9 (100%) | 12/12 (100%) | 0% (0 to 0) | NA
ABTs ≥72 hours (%) | Infection possible | 13/21 (61.9%) | 19/19 (100%) | -38.1 (-58.9 to -17.3) | 0.003
ABTs ≥72 hours (%) | Infection unlikely | 11/30 (36.7%) | 19/30 (63.3%) | -26.6 (-51.1 to -2.3) | 0.038
ABT duration, hours | All neonates | 79.1 | 101.5 | -22.4 | 0.012
ABT duration, hours | Infection proven/probably | 177.8 | 170.8 | -7 | NSS
ABT duration, hours | Infection possible | 83.4 | 111.5 | -28.1 | < 0.001
ABT duration, hours | Infection unlikely | 46.5 | 67.4 | -20.9 | 0.001

ABT = antibiotic; CI = confidence interval; CTRL = control; NA = not applicable; NSS = not statistically significant; PCT = procalcitonin

### Mortality

Only in-hospital mortality was reported by Stocker et al.43 No deaths occurred in either study arm (Table 22).

Table 22 Mortality and morbidity data for early onset neonatal sepsis in the study by Stocker et al., 2010^43^ (n=121)

Outcome | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Mortality (in-hospital) | 0% | 0% | 0 (0 to 0) | NA
Morbidity (recurrence of infection) | 32% | 39% | -7 | 0.45

CI = confidence interval; CTRL = control; NA = not applicable; PCT = procalcitonin

### Morbidity

There was a small but statistically insignificant reduction in the rate of recurrence of infection in the study by Stocker et al.,43 i.e., the neonates treated with antibiotics for 120 or more hours (Table 22).

### Adverse Events of Antibiotic Therapy

The study by Stocker et al.43 did not report adverse events of antibiotic therapy.

### GRADE Evidence

The strength of evidence was judged to be moderate that use of procalcitonin guidance reduces the use of antibiotic therapy for suspected neonatal sepsis. This good quality study was judged to have low risk of bias. The finding that significant reduction in duration of antibiotic therapy was observed in the subgroups with possible or unlikely infection, rather than those with probable infection, lends face validity to the results. Consistency was rated as unknown (single study). The evidence was direct and sufficiently precise to conclude that procalcitonin guidance reduces antibiotic use. This small study43 (n=121) was not powered to detect mortality or morbidity outcomes, and strength of evidence was judged insufficient to make conclusions on mortality and morbidity.

## Fever of Unknown Source (Children Ages 1–36 Months)

### Study Characteristics

There was only one RCT26 of procalcitonin-guided antibiotic therapy for fever of unknown source in children 1–36 months of age (Table 23). This study used BRAHMS PCT-Q^®^ semi-quantitative assay method for procalcitonin measurement. Three-hundred and eighty-four children were enrolled. Sixty-two (16 percent) were subsequently diagnosed with a serious bacterial infection and 10 (2.6 percent) were found to be neutropenic. Procalcitonin values used to decide on antibiotic initiation and discontinuation were based on a nomogram based on the time since birth, since procalcitonin is elevated in the first three days of life due to birth stress. Antibiotic therapy in the standard group was based on the attending physician's assessment. The primary outcome for this study26 was the antibiotic prescription rate. The secondary outcome was difference in hospitalization rate. Sample size needed was calculated based on rates of antibiotic prescription. Followup duration for this study was 30 days.

Table 23 Summary of characteristics for one trial included in the analysis of procalcitonin-guided antibiotic therapy in children (ages 1-36 months) with fever of unknown source

Author, Year, Country | Disease State | N | PCT for ABT Initiation | PCT for ABT Discontinuation | Other PCT-Guided Interventions | Study Duration | Predefined Endpoints
Manzano, 2010, Canada26 | Fever without a source, children 1-36 months of age | PCT 192 Ctrl 192 | PCT < 0.5, infection unlikely; PCT ≥ 0.5, moderate risk; PCT ≥ 2.0, high risk | ---- | ---- | 30 days | Primary outcome ABT prescription rate Secondary outcomes Hospitalization, additional studies

ABT = antibiotic; Ctrl = control; PCT = procalcitonin

### Study Quality

The quality rating for the one study is described in Table 24. The two study arms were comparable, but more than 10 percent of patients in each arm were excluded from the analysis (insufficient blood for assay) and no strategy to adjust for missing data was performed. Details of allocation concealment were described. This study was not powered to detect differences for the morbidity and mortality outcomes.

Table 24 Procalcitonin-guided antibiotic therapy in children (ages 1-36 months) with fever of unknown source—study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Manzano, 2010^26^ | Y | Y | Y | Y | Y | Y | N | Poor

N = no; USPSTF = United States Preventive Services Task Force; Y = yes

### Antibiotic Use

There were no differences in the antibiotic prescription rates or hospitalization rate, although rates were low for both arms with only one-quarter of children being hospitalized and receiving antibiotics26 (Table 25).

Table 25 Procalcitonin-guided antibiotic therapy in children (ages 1–36 months) with fever of unknown source–outcomes related to antibiotic use in the study by Manzano et al., 2010^26^ (n=384)

Outcome | Subgroup | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Antibiotic prescription rate (%) | All children | 48/192 (25%) | 54/192 (28.0%) | -3.1 (-12.0 to 5.7) | 0.49
Antibiotic prescription rate (%) | No SBI or neutropenia | 14/158 (9%) | 16/154 (10%) | -1.5 (-8.1 to -5.0) | 0.65

CI = confidence interval; CTRL = control; PCT = procalcitonin; SBI = serious blood infection

### Mortality

Only in-hospital mortality was reported, and mortality was 0 percent in both arms (Table 26).

Table 26 Mortality and morbidity data for fever of unknown source in children ages 1-36 months in the study by Manzano et al., 2010^26^ (n=384)

Outcome | Subgroup | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Mortality | All children | 0% | 0% | 0 (0 to 0) | NA
Morbidity (hospitalization rate) | All children | 50/192 (26%) | 48/192 (25%) | 1 (-8 to 10) | 0.81
Morbidity (hospitalization rate) | No SBI or neutropenia | 16/158 (10%) | 11/154 (7%) | 3 (-3 to 10) | 0.34

CI = confidence interval; CTRL = control; NA = not applicable; PCT = procalcitonin; SBI = serious blood infection

### Morbidity

In this single RCT,26 overall rates of hospitalization were relatively low, with only one quarter of the children being admitted (Table 26). This rate was even lower for those children who did not have a serious bacterial infection or neutropenia. There were no significant differences in the proportion of infants who were started on empiric antibiotic therapy, all children, and the subgroup of children without a serious blood infection or neutropenia. Overall, procalcitonin measurement did not have a statistically significant effect on antibiotic use or hospitalization in this population.

### Adverse Events of Antibiotic Therapy

The study by Manzano et al.26 did not report adverse events of antibiotic therapy.

### GRADE Evidence

The strength of evidence was judged insufficient to draw conclusions on outcome of procalcitonin-guided antibiotic therapy for fever of unknown source in children 1–36 months of age. This RCT26 (n=384) reported no significant results.

## Preemptive Postoperative Antibiotic Therapy

There was only one study44 that evaluated the value of monitoring procalcitonin postoperatively in 250 consecutive patients undergoing colorectal surgery (Table 27). Procalcitonin levels were used to identify patients at risk for local and systemic infectious complications who might benefit from antibiotic therapy (ceftriaxone) given as a prophylaxis or preemptive therapy in patients without other clinical evidence of infection. Of 230 patients with low postoperative procalcitonin, only 16 local wound infections (7.0 percent) not requiring surgery or antibiotics occurred and systemic infection occurred in only 4 patients (1.7 percent). The negative predictive value of procalcitonin for systemic infections requiring antibiotics was 98.3 percent and 93.0 percent for local wound infections that resolved without antibiotics or re-operation.

Table 27 Summary of characteristics for one trial44 included in the analysis of procalcitonin-guided preemptive postoperative antibiotic therapy

Author, Year, Country | Disease State | N | PCT for ABT Initiation | PCT for ABT Discontinuation | Other PCT-Guided Interventions | Study Duration | Predefined Endpoints
Chromik, 2005, Germany44 | Colorectal surgery patients | 250 patients overall 230 patients with low PCT, 20 with elevated PCT post-op | PCT > 1.5 post-op randomized to receive preemptive ABTs or standard care | | | Not defined | Primary outcome Local and systemic infectious complications Secondary outcomes Mortality, decreased LOS, duration of ABTs

ABT = antibiotic; LOS = length of stay; PCT = procalcitonin; Post-op = postoperative

The other 20 patients had two or more procalcitonin measurements greater than 1.5 ng/mL in the first three postoperative days, and these patients were randomized to receive IV ceftriaxone or standard management. The 10 patients in the control arm of the randomized portion of this study were treated when signs of infection became evident. Patients were followed for the duration of their hospitalization.

### Study Quality

The quality rating for the one study is described in Table 28. The patients in the two arms of the interventional part of this trial44 were comparable at baseline. Details of allocation concealment were described. Analysis was appropriate, but again, this study was not powered to detect differences in morbidity or mortality.

Table 28 Procalcitonin-guided preemptive postoperative antibiotic therapy—study quality

Author, Year | Assembled Comparable Groups | Maintained Comparable Groups | Minimal Followup Loss | Measurements Equal, Valid, and Reliable | Interventions Clearly Defined | Important Outcomes Considered | Appropriate Analysis of Results | Overall USPSTF Rating
Chromik, 2005^44^ | Y | Y | Y | Y | Y | Y | Y | Good

USPSTF = United States Preventive Services Task Force; Y = yes

### Antibiotic Use

Although all patients in the preemptive ceftriaxone arm received this antibiotic for a period of time (range: 4–11 days), the duration of antibiotic therapy was lower by 3.5 days in the procalcitonin-guided therapy group compared with the control group44 (Table 29). This difference, however, did not reach statistical significance.

Table 29 Procalcitonin-guided preemptive postoperative antibiotic therapy–outcomes related to antibiotic use in the study by Chromik et al., 2005^44^

N | Outcome | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
20 | ABT duration (days) | 5.5 | 9 | -3.5 | 0.27

ABT = antibiotic; CI = confidence interval; CTRL = control; PCT = procalcitonin

### Mortality

Mortality was 20 percent higher in the control arm (Table 30). This was not statistically significant.

Table 30 Procalcitonin-guided preemptive postoperative antibiotic therapy—mortality and morbidity data in the study by Chromik et al., 2005^44^ (n=20)

| Outcome | PCT | Control | Difference PCT-CTRL (95% CI) | p-Value
Mortality | | 1/10 (10%) | 3/10 (30%) | -20 (-54.0 to 14.0) | 0.07
Morbidity | Hospital LOS (days) | 18 | 30 | -12 | 0.057
Morbidity | Local wound infection (%) | 1/10 | 2/10 | -10 (-41.0 TO 21.0) | 0.53
Morbidity | Systemic infection (%) | 3/10 | 7/10 | -40.0 (-80.2 to 0.2) | 0.07
Morbidity | Sepsis/SIRS (%) | 2/10 | 8/10 | -60.0 (-95.1 to -24.9) | 0.007

CI = confidence interval; CTRL = control; LOS = length of stay; PCT = procalcitonin; SIRS = systemic inflammatory response syndrome

### Morbidity

Patients in the control arm of the study had a more prolonged LOS (12 days longer), and the difference approached statistical significance (Table 30). The control arm also had a higher incidence of local and systemic infection. Patients in the control arm were significantly more likely to have systemic inflammatory response syndrome (SIRS) or sepsis and require vasopressors for shock.

### Adverse Events of Antibiotic Therapy

The study by Chromik et al.44 did not report adverse events of antibiotic therapy.

### GRADE Evidence

This single RCT44 suggests procalcitonin levels can identify postoperative patients who are at risk for wound and systemic infection who will benefit from prophylaxis or preemptive antibiotic therapy. Not only did procalcitonin identify a group of patient for whom antibiotics can prevent significant morbidity and mortality, but low procalcitonin levels accurately identified a low-risk group for whom antibiotics were unnecessary. The use of procalcitonin helped limit the use of antibiotic prophylaxis to 8 percent of the entire postsurgical population. Further studies of this strategy are needed to confirm this result. The evidence on procalcitonin-guided preemptive postoperative antibiotic therapy was deemed insufficient to be graded as only one small study (n=20) was available for peer review.