# References

1 Pierrakos C, Vincent JL. Sepsis biomarkers: a review. Crit Care. 2010;14(1):R15. [pmid: 20144219].
2 Marshall JC, Reinhart K. Biomarkers of sepsis. Crit Care Med. Jul. 2009;37(7):2290-8. [pmid: 19487943].
3 Tang H, Huang T, Jing J, et al. Effect of procalcitonin-guided treatment in patients with infections: a systematic review and meta-analysis. Infection. Dec. 2009;37(6):497-507. [pmid: 19826761].
4 Jones AE, Fiechtl JF, Brown MD, et al. Procalcitonin test in the diagnosis of bacteremia: a meta-analysis. Ann Emerg Med. Jul. 2007;50(1):34-41. [pmid: 17161501].
5 Becker KL, Snider R, Nylen ES. Procalcitonin in sepsis and systemic inflammation: a harmful biomarker and a therapeutic target. Br J Pharmacol. Jan. 1. 2010;159(2):253-64. [pmid: 20002097].
6 Brunkhorst FM, Heinz U, Forycki ZF. Kinetics of procalcitonin in iatrogenic sepsis. Intensive Care Med. Aug. 1998;24(8):888-9. [pmid: 9757936].
7 Dandona P, Nix D, Wilson MF, et al. Procalcitonin increase after endotoxin injection in normal subjects. J Clin Endocrinol Metab. Dec. 1994;79(6):1605-8. [pmid: 7989463].
8 510(k) Summary of Safety and Effectiveness: B.R.A.H.M.S PCT LIA. January. 7. 2005. www.accessdata.fda.gov/cdrh_docs/pdf4/K040887.pdf. August 18 2011.
9 510(k) Summary VIDAS B.R.A.H.M.S PCT Assay. October. 11. 2007. www.accessdata.fda.gov/cdrh_docs/pdf7/K071146.pdf. August 18 2011.
10 510(k) Summary B.R.A.H.M.S PCT sensitive KRYPTOR® Test System. March. 31. 2008. www.accessdata.fda.gov/cdrh_docs/pdf7/K070310.pdf. August 18 2011.
11 Schneider HG, Lam QT. Procalcitonin for the clinical laboratory: a review. Pathology. Aug. 2007;39(4):383-90. [pmid: 17676478].
12 Bone RC, Balk RA, Cerra FB, et al. Definitions for sepsis and organ failure and guidelines for the use of innovative therapies in sepsis. The ACCP/SCCM Consensus Conference Committee. American College of Chest Physicians/Society of Critical Care Medicine. Chest. Jun. 1992;101(6):1644-55. [pmid: 1303622].
13 Polin RA. The “ins and outs” of neonatal sepsis. J Pediatr. Jul. 2003;143(1):3-4. [pmid: 12915813].
14 Harbarth S, Holeckova K, Froidevaux C, et al. Diagnostic value of procalcitonin, interleukin-6, and interleukin-8 in critically ill patients admitted with suspected sepsis. Am J Respir Crit Care Med. Aug. 1. 2001;164(3):396-402. [pmid: 11500339].
15 Simon L, Gauvin F, Amre DK, et al. Serum procalcitonin and C-reactive protein levels as markers of bacterial infection: a systematic review and meta-analysis. Clin Infect Dis. Jul. 15. 2004;39(2):206-17. [pmid: 15307030].
16 Christ-Crain M, Muller B. Biomarkers in respiratory tract infections: diagnostic guides to antibiotic prescription, prognostic markers and mediators. Eur Respir J. Sep. 2007;30(3):556-73. [pmid: 17766633].
17 Chiesa C, Panero A, Rossi N, et al. Reliability of procalcitonin concentrations for the diagnosis of sepsis in critically ill neonates. Clin Infect Dis. Mar. 1998;26(3):664-72. [pmid: 9524841].
18 Luyt CE, Guerin V, Combes A, et al. Procalcitonin kinetics as a prognostic marker of ventilator-associated pneumonia. Am J Respir Crit Care Med. Jan. 1. 2005;171(1):48-53. [pmid: 15447947].
19 Schuetz P, Chiappa V, Briel M, et al. Procalcitonin algorithms for antibiotic therapy decisions: a systematic review of randomized controlled trials and recommendations for clinical algorithms. Arch Intern Med. Aug. 8. 2011;171(15):1322-31. [pmid: 21824946].
20 Agarwal R, Schwartz DN. Procalcitonin to guide duration of antimicrobial therapy in intensive care units: a systematic review. Clin Infect Dis. Aug. 2011;53(4):379-87. [pmid: 21810753].
21 Kopterides P, Siempos II, Tsangaris I, et al. Procalcitonin-guided algorithms of antibiotic therapy in the intensive care unit: a systematic review and meta-analysis of randomized controlled trials. Crit Care Med. Nov. 2010;38(11):2229-41. [pmid: 20729729].
22 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011.
23 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
24 Brown P, Brunnhuber K, Chalkidou K, et al. How to formulate research recommendations. BMJ. Oct. 14. 2006;333(7572):804-6. [pmid: 17038740].
25 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
26 Manzano S, Bailey B, Girodias JB, et al. Impact of procalcitonin on the management of children aged 1 to 36 months presenting with fever without source: a randomized controlled trial. Am J Emerg Med. Jul. 2010;28(6):647-53. [pmid: 20637377].
27 Burkhardt O, Ewig S, Haagen U, et al. Procalcitonin guidance and reduction of antibiotic use in acute respiratory tract infection. Eur Respir J. Sep. 2010;36(3):601-7. [pmid: 20185423].
28 Jensen JU, Hein L, Lundgren B, et al. Procalcitonin-guided interventions against infections to increase early appropriate antibiotics and improve survival in the intensive care unit: A randomized trial. Crit Care Med. 2011. May. 12. [pmid: 21572328].
29 Roh YH. Antibiotic Therapy With the Guidance of Procalcitonin in Patients With Community-Acquired Pneumonia. Chest. October. 1. 2010. 2010;138:592A.
30 Sanches PR, Deliberato RO, Paes AT, et al. Procalcitonin as a marker to shorten antimicrobial treatment in septic patient in intensive care setting. Fifth Decennial International Conference on Healthcare-Associated Infections. 2010. Atlanta, USA.
31 Long W, Deng X, Zhang Y, et al. Procalcitonin guidance for reduction of antibiotic use in low-risk outpatients with community-acquired pneumonia. Respirology. Jul. 2011;16(5):819-24. [pmid: 21507143].
32 Nobre V, Harbarth S, Graf JD, et al. Use of procalcitonin to shorten antibiotic treatment duration in septic patients: a randomized trial. Am J Respir Crit Care Med. Mar. 1. 2008;177(5):498-505. [pmid: 18096708].
33 Schroeder S, Hochreiter M, Koehler T, et al. Procalcitonin (PCT)-guided algorithm reduces length of antibiotic treatment in surgical intensive care patients with severe sepsis: results of a prospective randomized study. Langenbecks Arch Surg. Mar. 2009;394(2):221-6. [pmid: 19034493].
34 Hochreiter M, Kohler T, Schweiger AM, et al. Procalcitonin to guide duration of antibiotic therapy in intensive care patients: a randomized prospective controlled trial. Crit Care. 2009;13(3):R83. [pmid: 19493352].
35 Stolz D, Smyrnios N, Eggimann P, et al. Procalcitonin for reduced antibiotic exposure in ventilator-associated pneumonia: a randomised study. Eur Respir J. Dec. 2009;34(6):1364-75. [pmid: 19797133].
36 Christ-Crain M, Stolz D, Bingisser R, et al. Procalcitonin guidance of antibiotic therapy in community-acquired pneumonia: a randomized trial. Am J Respir Crit Care Med. Jul. 1. 2006;174(1):84-93. [pmid: 16603606].
37 Christ-Crain M, Jaccard-Stolz D, Bingisser R, et al. Effect of procalcitonin-guided treatment on antibiotic use and outcome in lower respiratory tract infections: cluster-randomised, single-blinded intervention trial. Lancet. Feb. 21. 2004;363(9409):600-7. [pmid: 14987884].
38 Stolz D, Christ-Crain M, Bingisser R, et al. Antibiotic treatment of exacerbations of COPD: a randomized, controlled trial comparing procalcitonin-guidance with standard therapy. Chest. Jan. 2007;131(1):9-19. [pmid: 17218551].
39 Bouadma L, Luyt CE, Tubach F, et al. Use of procalcitonin to reduce patients' exposure to antibiotics in intensive care units (PRORATA trial): a multicentre randomised controlled trial. Lancet. Feb. 6. 2010;375(9713):463-74. [pmid: 20097417].
40 Schuetz P, Christ-Crain M, Thomann R, et al. Effect of procalcitonin-based guidelines vs standard guidelines on antibiotic use in lower respiratory tract infections: the ProHOSP randomized controlled trial. JAMA. Sep. 9. 2009;302(10):1059-66. [pmid: 19738090].
41 Kristoffersen KB, Sogaard OS, Wejse C, et al. Antibiotic treatment interruption of suspected lower respiratory tract infections based on a single procalcitonin measurement at hospital admission--a randomized trial. Clin Microbiol Infect. May. 2009;15(5):481-7. [pmid: 19416298].
42 Briel M, Schuetz P, Mueller B, et al. Procalcitonin-guided antibiotic use vs a standard approach for acute respiratory tract infections in primary care. Arch Intern Med. Oct. 13. 2008;168(18):2000-7. discussion 7-8. [pmid: 18852401].
43 Stocker M, Fontana M, El Helou S, et al. Use of procalcitonin-guided decision-making to shorten antibiotic therapy in suspected neonatal early-onset sepsis: prospective randomized intervention trial. Neonatology. 2010;97(2):165-74. [pmid: 19776651].
44 Chromik AM, Endter F, Uhl W, et al. Pre-emptive antibiotic treatment vs ‘standard’ treatment in patients with elevated serum procalcitonin levels after elective colorectal surgery: a prospective randomised pilot study. Langenbecks Arch Surg. Jun. 2006;391(3):187-94. [pmid: 16369855].
45 Svoboda P, Kantorova I, Scheer P, et al. Can procalcitonin help us in timing of re-intervention in septic patients after multiple trauma or major surgery?. Hepatogastroenterology. Mar. 2007;54(74):359-63. [pmid: 17523274].
46 Carling P, Fung T, Killion A, et al. Favorable impact of a multidisciplinary antibiotic management program conducted during 7 years. Infect Control Hosp Epidemiol. Sep. 2003;24(9):699-706. [pmid: 14510254].
47 Chastre J, Wolff M, Fagon JY, et al. Comparison of 8 vs 15 days of antibiotic therapy for ventilator-associated pneumonia in adults: a randomized trial. JAMA. Nov. 19. 2003;290(19):2588-98. [pmid: 14625336].
48 Ibrahim EH, Ward S, Sherman G, et al. Experience with a clinical guideline for the treatment of ventilator-associated pneumonia. Crit Care Med. Jun. 2001;29(6):1109-15. [pmid: 11395584].
49 Assessing Equivalence and Non-Inferiority (Draft). Rockville, MD. Agency for Healthcare Rsearch and Quality. September. 2011.
50 Kollef MH, Sherman G, Ward S, et al. Inadequate antimicrobial treatment of infections: a risk factor for hospital mortality among critically ill patients. Chest. Feb. 1999;115(2):462-74. [pmid: 10027448].
51 Gonzales R, Steiner JF, Lum A, et al. Decreasing antibiotic use in ambulatory practice: impact of a multidimensional intervention on the treatment of uncomplicated acute bronchitis in adults. JAMA. Apr. 28. 1999;281(16):1512-9. [pmid: 10227321].
52 Freifeld AG, Bow EJ, Sepkowitz KA, et al. Clinical practice guideline for the use of antimicrobial agents in neutropenic patients with cancer: 2010 update by the infectious diseases society of america. Clin Infect Dis. Feb. 15. 2011;52(4):e56-93. [pmid: 21258094].
53 McGowan JE Jr. Antimicrobial resistance in hospital organisms and its relation to antibiotic use. Rev Infect Dis. Nov-Dec. 1983;5(6):1033-48. [pmid: 6318289].
54 Levy SB. Balancing the drug-resistance equation. Trends Microbiol. Oct. 1994;2(10):341-2. [pmid: 7850197].
55 Dellit TH, Owens RC, McGowan JE Jr., et al. Infectious Diseases Society of America and the Society for Healthcare Epidemiology of America guidelines for developing an institutional program to enhance antimicrobial stewardship. Clin Infect Dis. Jan. 15. 2007;44(2):159-77. [pmid: 17173212].
56 Liew YX, Chlebicki MP, Lee W, et al. Use of procalcitonin (PCT) to guide discontinuation of antibiotic use in an unspecified sepsis is an antimicrobial stewardship program (ASP). Eur J Clin Microbiol Infect Dis. Jul. 2011;30(7):853-5. [pmid: 21279532].
57 Layios N, L B, Ledoux D, Morimont P, Massion P, Garweg C, Frippiat F, Nys M, Chapelle JP, Damas P. Usefulness of procalcitonin for the decision of antibiotic treatment in ICU patients. Vienna. 2009. http://poster-consultation.esicm.org/ModuleConsultationPoster/posterDetail.aspx?intIdPoster=486. September 6 2011.
58 Long W, Deng XQ, Tang JG, et al. The value of serum procalcitonin in treatment of community acquired pneumonia in outpatient. Zhonghua Nei Ke Za Zhi. Mar. 2009;48(3):216-9. [pmid: 19576090].
59 Kaul S, Diamond GA. Good enough: a primer on the analysis and interpretation of noninferiority trials. Ann Intern Med. Jul. 4. 2006;145(1):62-9. [pmid: 16818930].
60 Tarnow-Mordi W, Gebski V. Procalcitonin in intensive care units: the PRORATA trial. Lancet. May. 8. 2010;375(9726):1605. author reply 6-7. [pmid: 20452513].
61 Landman GW, Kleefstra N. Procalcitonin in intensive care units: the PRORATA trial. Lancet. May. 8. 2010;375(9726):1606. author reply -7. [pmid: 20452516].
62 Gibot S. Procalcitonin in intensive care units: the PRORATA trial. Lancet. May. 8. 2010;375(9726):1605-6. author reply 6-7. [pmid: 20452514].
63 European Medicines Agency Guideline on the Choice of the Non-Inferiorirty Margin. 2005. www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003636.pdf. September 6 2011.
64 Zinsmeister AR, Connor JT. Ten common statistical errors and how to avoid them. Am J Gastroenterol. Feb. 2008;103(2):262-6. [pmid: 18289193].